# Appendixes

Appendix A Exact Search Strings and List of Manufacturers

Appendix B Sample Data Extraction Forms

Appendix C Evidence Tables

Appendix D Excluded Studies and Background Papers

Appendix E Technical Expert Panel and Peer Reviewers