# Acknowledgments

We wish to thank Marguerite Klein, M.S. (National Institutes of Health [NIH] Office of Dietary Supplements [ODS]); Linda Duffy, Ph.D. (NIH National Center for Complementary and Alternative Medicine); Dan D. Levy, Ph.D. (Food and Drug Administration Center for Food Safety and Applied Nutrition); and Anne Thurn, Ph.D. (ODS) for their guidance and support. We wish to thank the members of the Technical Expert Panel: Michael Cabana, M.D., M.P.H.; Cara Fiore, Ph.D.; Barry Goldin, Ph.D.; Patricia L. Hibberd, M.D., Ph.D.; David Mills, Ph.D.; Mary Ellen Sanders, Ph.D.; Maija-Liisa Saxelin, Ph.D.; Alain L Servin, Ph.D.; and Jon A. Vanderhoof, M.D., for their helpful suggestions and recommendations. We also would like to thank Louis M.A. Akkermans, Ph.D.; Marc Besselink, M.D.; Daniel Buijs, M.Sc., and Ger Rijkers, Ph.D., who provided peer reviews of the draft report.