# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ATCC: American Type Culture Collection
CAERS: CFSAN Adverse Event Reporting System
CBER: Center for Biologics Evaluation and Research
CCTs: controlled clinical trials
CFSAN: Center for Food Safety and Applied Nutrition
cfu: colony forming units
CI: confidence interval
CTCAE: Common Terminology Criteria for Adverse Events classification system
DARE: Database of Abstracts of Reviews of Effects
EFSA: European Food Safety Authority
EPC: Evidence-based Practice Center
FAO/WHO: Food and Agriculture Organization of the United Nations and the World Health Organization
FDA: Food and Drug Administration
GRAS: generally recognized as safe
IND: investigational new drug
ITT: intention-to-treat
MANTIS: Manual, Alternative and Natural Therapy Index System
NCCAM: National Center for Complementary and Alternative Medicine
NCI-CTC: National Cancer Institute Common Toxicity Criteria
NTIS: National Technical Information Service
ODS: National Institutes of Health Office of Dietary Supplements
RCT: randomized controlled trial
RD: risk difference
RR: risk ratio
SAE: serious adverse event
TEP: Technical Expert Panel