# Evidence Tables

Evidence Table 1. Overview of randomized trials with cardiovascular endpoints that were 4 weeks or longer in duration and compared garlic with placebo or other therapy

Study | Randomization Process | Intervention | Control Group | Double Blind? | Cointervention | Endpoints | | | | | Trial Length (weeks) | Dropouts
Study | Randomization Process | Intervention | Control Group | Double Blind? | Cointervention | Clinical | Lipids | Blood pressure | Glucose | Thrombotic | Trial Length (weeks) | Dropouts
Adler (1997) ^79^ | Unclear | Dehydrated tablet: Kwai ^®^ | 1. Placebo 2. Fish oil | Yes | None | | X | X | | | 12 | 8% Garlic 8% Placebo
Auer (1990) ^39^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | X | | 12 | Unclear
Barrie (1987) ^36^ | Unclear | Oil macerate | Placebo (garlic odor) | Yes | None | | X | X | | X | 4 ^a^ | Unclear
Berthold (1998) ^95^ | Probably adequate | Garlic distillate: Tegra ^®^ | Placebo (garlic odor) | Yes | None | | X | | | | 12 ^a^ | 4%
Bordia (1981) ^34^ | Unclear (not clearly randomized) | Garlic ether extract | Placebo | Yes | None | | X | | | | 43 | 9%
Bordia (1989) ^71^ | Unclear (not clearly randomized) | Garlic ether extract | Placebo | Unclear | "Habitual coronary therapy" | X | X | X | | | 156 | Unclear
Bordia (1998) ^72^ | Unclear (not clearly randomized) | Garlic ether extract | Placebo | Unclear | None | | X | | X | X | 13 | Unclear
Buhshan (1979) ^35^ | Unclear | Raw garlic | No garlic | No | "Restricted" physical activity | | X | | | | 8 | Unclear
Chutani (1981) ^74^ | Unclear | Raw garlic Fried garlic | No garlic | No | Unclear | | | | | X | 4 | Unclear
Czerny (1996) ^70^ | Unclear | Oil macerate/ soya/hawthorn/ wheat germ | Placebo | Yes | Unclear | X | X | X | X | X | 16 | Unclear
de Santos (1993) ^81^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Antilipid diet | | X | X | | | 24 | 17% Garlic 10% Placebo
de Santos (1995) ^83^ | Unclear | Dehydrated tablet: Kwai ^®^ | Garlic Oil: Original Garlic Oil ^®^ | No | Unclear | | X | X | | | 16 | 10% Dehydrated 15% Oil
Gardner (1999) ^64^ | Unclear | Dehydrated tablet | Placebo (garlic odor) | Yes | None | | X | X | | | 12 | 4% Garlic 0% Placebo
Holzgartner (1992) ^85^ | Probably adequate | Dehydrated tablet: Kwai ^®^ | Antilipidemic | Yes | Antilipid diet | | X | X | | | 12 | 0%
Isaacsohn (1998) ^86^ | Probably adequate | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Antilipid diet | | X | X | | | 12 | 14% Garlic 18% Placebo
Jain (1993) ^24^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | X | | 12 | Unclear
Kandziora (1988) ^37^ | Unclear | Dehydrated tablet: Kwai ^®^ and antihypertensive | Antihypertensive only | Yes | None | | X | X | X | | 12 | Unclear
Kandziora (1988) ^38^ | Unclear | Dehydrated tablet: Kwai ^®^ | Antihypertensive | Single | None | | X | X | X | | 12 | Unclear
Kannar (1998) ^78^ | Adequate | Dehydrated enteric-coated tablet: noncommercial | 1. Placebo 2. Inulin 3. Garlic and inulin | Yes | Antilipid diet | | X | X | | | 12 | 3%
Kenzelmann (1993) ^99^ | Probably adequate | Dehydrated tablet/Ginkoba ^®^ | Placebo | Yes | "Extreme dietary conditions" | | X | | | | 8 | 4% Garlic 9% Placebo
Kiesewetter (1991) ^87^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | X | X | 4 | Unclear
Kiesewetter (1993) ^69^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | 90 minutes per week of physical therapy | X | X | X | | X | 12 | 20% Garlic 20% Placebo
Koscielny (1999) ^88^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | X | X | 208 | 33% Garlic (3 m) 40% Garlic (6 m) 19% Placebo (3 m) 21% Placebo (6 m)
Lash (1998) ^76^ | Unclear | Dehydrated tablet: Pure-Gar ^®^ | Placebo | Unclear | Antilipid diet | | X | | | | 12 | Unclear
Lau (1) (1987) ^30^ | Unclear | "Aged garlic extract^TM^" | Placebo | Unclear | None | | X | | | | 26 | 6% Garlic 25% Placebo
Lau (2) (1987) ^30^ | Unclear | "Aged garlic extract^TM^" | Placebo | Unclear | None | | X | | | | 26 | Unclear
Luley (1) (1986) ^96^ | Unclear | Dehydrated tablet | Placebo | Yes | None | | X | X | X | | 6 ^a^ | 0%
Luley (2) (1986) ^96^ | Unclear | Dehydrated tablet | Placebo | Yes | None | | X | X | X | X | 6 ^a^ | 0%
Lutomski (1984) ^100^ | Unclear | Dehydrated combination tablet: Ilja Rogoff ^®^ | Placebo | Yes | None | | X | X | | | 12 | 20%
Mader (1990) ^89^ | Probably adequate | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | | | 16 | 17% Garlic 13% Placebo
Mansell (1996) ^84^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Unclear | Unclear | | X | X | X | | 12 | Unclear
McCrindle (1998) ^90^ | Probably adequate | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Antilipid diet | | X | X | | X | 8 | 3%
Melvin (1996) ^82^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Not reported | | X | | | | 4 ^a^ | Unclear
Morcos (1997) ^97^ | Unclear | Dehydrated tablet with fish oil | Placebo | Single | None | | X | | | | 4 ^a^ | 0%
Neil (1996) ^47^ | Adequate | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Antilipid diet | | X | | | | 24 | 9%
Plengvidhya (1988) ^40^ | Unclear | Dehydrated tablet | Placebo | Yes | None | | X | | | | 6 ^a^ | Unclear
Rotzsch (1992) ^91^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | 100 g of butter consumption one time at 3-week intervals | | X | | | | 6 | Unclear
Saradeth (1994) ^92^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | | | 15 | 3% Garlic 8% Placebo
Simons (1995) ^93^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Antilipid diet | | X | X | | | 12 ^a^ | 7%
Sitprija (1987) ^73^ | Unclear | Dehydrated tablet | Placebo | Yes | None | | X | | X | | 4 | 21%
Steiner (1996) ^94^ ^102^ | Unclear | "Aged garlic extract^TM^" | Placebo | Yes | Antilipid diet | | X | X | | X | 26 ^a^ | 21% (Entire period)
Superko (2000) ^80^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | Antilipid diet | | X | X | | | 12 | Unclear
Ventura (1990) ^98^ | Unclear | Dehydrated tablet/hawthorn/ other | Placebo | Yes | None | | X | X | | | 8 | 0%
Vorberg (1990) ^75^ | Unclear | Dehydrated tablet: Kwai ^®^ | Placebo | Yes | None | | X | X | | | 16 | Unclear
Yeh (1997) ^77^ | Unclear | "Aged garlic extract^TM^" | Placebo | Yes | Usual diet | | X | X | | | 20 | 6%

a Crossover trial (trial length of first parallel period is given). Randomization clearly adequate: Centralized randomization by telephone; randomization scheme controlled by pharmacy; numbered or coded identical containers administered sequentially; onsite computer system that can only be accessed after entering the characteristics of an enrollee participant; or sequentially numbered, sealed, opaque envelopes. Randomization probably adequate: Sealed envelopes but not sequentially numbered or opaque; list of random numbers read by someone entering patient into trial (open list); or a trial in which the description suggests adequate concealment, but other features are suspicious (for example, markedly unequal controls and trial groups). Randomization unclear: Process was not clearly described.

Evidence Table 2. Characteristics of trials that evaluated nonstandardized garlic preparations

Study | Country of Study | Size (n=) | Mean Age | Male % | Participant Characteristics | Inclusion Criteria | Recruitment Setting | Garlic Preparation | Daily Dosage
Barrie (1987) ^36^ | Canada | 20 | 26 | Not given | All previously healthy TC 130 to 270 mg/dL | None | Student volunteers | Oil macerate | 18 mg
Berthold (1998) ^95^ | Germany | 26 | 58.3 | 54 | No diabetics No coronary disease | TC 240 to 348 mg/dL and TG < 265 mg/dL | Community volunteers | Garlic distillate: Tegra ^®^ | 5 mg
Bordia (1981) ^34^ | India | 68 | 54 | Not given | 45% with TC > 250 mg/dL 8% Diabetic | Coronary artery disease TC 250 to 350 mg/dL | Unclear | Garlic ether extract | 0.25 mg/kg
Bordia (1989) ^71^ | India | 432 | Not given | Not given | Not given | History of myocardial infarction | Unclear | Garlic ether extract | 0.1 mg/kg 6 to 10 grams
Bordia (1998) ^72^ | India | 60 | Not given | Not given | No aspirin for 2 weeks All taking nitrates | History of myocardial infarction | Unclear | Garlic ether extract | Unclear
Buhshan (1979) ^35^ | India | 25 | Range 18 to 35 | 100 | TC 160 to 250 mg/dL No smokers | Normal lipids, no medical conditions | Unclear | Raw garlic | 10,000 mg
Chutani (1981) ^74^ | India | 30 | 50 | Not given | Not given | Ischemic heart disease | Unclear | 1. Raw garlic 2. Fried garlic | 0.5 g/kg/d
Czerny (1996) ^70^ | Poland | 100 | 55 | 65 | Mean baseline TC 217 mg/dL Mean baseline TG 202 mg/dL Mean baseline BP 163/102 mm Hg | Hyperlipidemia Atherosclerotic claudication | Unclear | Oil macerate/ soya/ hawthorn/ wheat germ | 400 mg
de Santos (1995) ^83^ | United Kingdom | 80 | 56 | 35 | No lipid or antihypertensive drug | Mild hypercholesterolemia | 1 general practice | Hoefels Original Garlic Oil ^®^ | 1.98 mg
Gardner (1999) ^64^ | United States | 53 | 52 | 51 | All hyperlipidemic No diabetics or cardiac disease No lipid or antihypertensive drug | LDL 130 to 190 mg/dL | Community volunteers | Dehydrated tablet | 500 mg 1,000 mg
Kenzelmann (1993) ^99^ | Switzerland | 46 | 43 | 33 | TC 230 to 390 mg/dL | TC > 230 mg/dL | Volunteers from four general practices | Dehydrated tablet/Ginkoba ^®^ | 200 mg
Lau (1) (1987) ^30^ | United States | 32 | 52 | 56 | No chronic medical conditions TC 220 to 440 mg/dL 44% Vegetarians | Hyperlipidemia | Community and outpatient clinic volunteers | "Aged garlic extract^TM^" | 4 ml extract 1000 mg
Lau (2) (1987) ^30^ | United States | 14 | 26 | 56 | No chronic medical conditions TC 150 to 200 mg/dL 57% Vegetarians | Normolipidemia | Community and outpatient clinic volunteers | "Aged garlic extract^TM^" | 4 ml extract 1,000 mg
Luley (1) (1986) ^96^ | Germany | 34 | Not given | Not given | Not given | Hyperlipoproteinemia types IIa, IIb, or IV | Unclear | Dehydrated tablet | 594 mg
Luley (2) (1986) ^96^ | Germany | 51 | Not given | Not given | Not given | Hyperlipoproteinemia types IIa, IIb, or IV | Unclear | Dehydrated tablet | 1,350 mg
Lutomski (1984) ^100^ | Poland | 102 | 53 | 49 | "Arteriosclerosis sequelae and mild gastrointestinal troubles" | Age 45 to 60 | Unclear | Dehydrated combination tablet: Ilja Rogoff ^®^ | 300 mg
Morcos (1997) ^97^ | United States | 40 | 53 | 58 | 35 % Hypertensive 13% Coronary disease 8% Diabetic No smokers | TC or TG > 200 mg/dL | Community clinic volunteers | Dehydrated tablet/fish oil | 1,200 mg
Plengvidhya (1988) ^40^ | Thailand | 30 | 49 | 33 | 30% Obese TC 168 to 429 mg/dL | "Moderately" elevated TC and TG | Unclear | Dehydrated tablet | 700 mg
Sitprija (1987) ^73^ | Thailand | 40 | 50 | 33 | All adult diabetics | Diabetes without complications | "Selected" from outpatient clinic | Dehydrated tablet | 700 mg
Steiner (1996) ^94^ | United States | 52 | Range 32 to 68 | 100 | Not given | TC 220 to 290 mg/dL | Majority prior heart health study enrollees | "Aged garlic extract^TM^" | 7,200 mg
Ventura (1990) ^98^ | Italy | 40 | 59 | 38 | 33% Hypertensive Peripheral vascular disease | TC 200 to 350 mg/dL; TG 180 to 300 mg/dL | Community volunteers | Dehydrated tablet/ hawthorn/other | 450 mg
Yeh (1997) ^77^ | United States | 34 | 48 | 100 | No chronic medical conditions | Hyperlipidemic | Community volunteers | "Aged garlic extract^TM^" | 7,200 mg

To convert cholesterol, LDL, and HDL values from mg/dL to mmol/dL, divide by 38.7. To convert triglyceride values from mg/dL to mmol/dL, divide by 88.2.

"Hyperlipidemia" usually referred to total cholesterol higher than 230 mg/dL.

Abbreviations used: BP = blood pressure; G/kg/d = grams per kilogram per day; HDL = high density lipoprotein; LDL = low density lipoprotein; mg = milligrams; mg/dL = milligrams per deciliter; mg/kg = milligrams per kilogram; ml = milliliter; mm Hg = millimeters mercury; TC = total cholesterol; TG = triglycerides.

Evidence Table 3. Results of trials reporting blood pressure outcomes after garlic supplementation

Study | Participants | Intervention | Mean Baseline Blood Pressure (treatment group) | Time at Reported Endpoint | Reported Change in Garlic Group | Reported Change in Control Group
Adler ^79^ | Hyperlipidemic | Dehydrated tablet: Kwai ^®^ vs. placebo | Uc 120/81 | 12 weeks | -2.4 to 4.2% ^a^ | "None"
Auer ^39^ | Hypertensive | Dehydrated tablet: Kwai ^®^ vs. placebo | Sp 171/102 Sd 171/101 | 4 weeks | -4% Sp S -8% Sp D | -4% Sp S -5% Sp D
Auer ^39^ | Hypertensive | Dehydrated tablet: Kwai ^®^ vs. placebo | Sp 171/102 Sd 171/101 | 12 weeks | -11% Sp S -13% Sp D -12% Sd S -11% Sd D | -5% Sp S -4% Sp D -6% Sd S -4% Sd D
Barrie ^Cr^ ^36^ | None | Cold pressed garlic oil vs. placebo | St M 94 | 4 weeks | -5.4% | -2.3%
Bordia ^71^ | Postmyocardial infarction | Garlic ether extract vs. placebo | Not stated | 1, 2, and 3 years | "Clearly lower" S and D | Unclear
Czerny ^70^ | Hyperlipidemic and peripheral vascular disease | Garlic oil macerate vs. placebo | Uc 162/100 | 4 weeks | -7% S -2% D | -2% S -4% D
Czerny ^70^ | Hyperlipidemic and peripheral vascular disease | Garlic oil macerate vs. placebo | Uc 162/100 | 12 weeks | -13% S -12% D | -5% S -7% D
Czerny ^70^ | Hyperlipidemic and peripheral vascular disease | Garlic oil macerate vs. placebo | Uc 162/100 | 13 weeks | -11% S 0% D | -4% S 0% D
Czerny ^70^ | Hyperlipidemic and peripheral vascular disease | Garlic oil macerate vs. placebo | Uc 162/100 | 26 weeks | -17% S -11% D | -1% S 0% D
de Santos ^81^ | Hyperlipidemic | Dehydrated tablet: Kwai ^®^ vs. placebo | Uc 145/91 | 4 Weeks | -8% S -7% D | -4% S 0% D
de Santos ^83^ | Hyperlipidemic | Dehydrated tablet: Kwai ^®^ vs. Hoefels Original Garlic Oil ^®^ | Kwai ^®^ St 151/96 Hoefels Original Garlic Oil St 138/88 | 16 weeks | Kwai ^®^ -17% St S -18% St D | Garlic oil "No change" St S -2% St D
Gardner ^64^ | Hyperlipidemic | Dehydrated tablet vs. placebo | Not stated | 12 weeks | "No significant differences" | "No significant differences"
Holzgartner ^85^ | Hyperlipidemic | Dehydrated tablet: Kwai ^®^ vs. antilipidemic | Uc 143/83 | 12 weeks | -5% Uc S -5% Uc D | "Change not significant"
Isaacsohn ^86^ | Hyperlipidemic | Dehydrated tablet: Kwai ^®^ vs. placebo | St 121/72 | 12 weeks | +2% St S +1% St D | 0% St S +4% St D
Jain ^24^ | Hyperlipidemic | Dehydrated tablet: Kwai ^®^ vs. placebo | St 128/83 | 12 weeks | +1% St S -1% St D | -1% St S -1% St D
Kandziora ^37^ | Hypertensive | Dehydrated tablet: Kwai ^®^ and antihypertensive vs. antihypertensive | Sp 178/100 Sd 174/99 | 4 weeks | -6% Sp S -12%Sp D -6% Sd S -12% Sd D | -2% Sp S -7% Sp D -3% Sd S -7% Sd D
Kandziora ^37^ | Hypertensive | Dehydrated tablet: Kwai ^®^ and antihypertensive vs. antihypertensive | Sp 178/100 Sd 174/99 | 12 weeks | -9% Sp S -15% Sp D -9% Sd S -16% Sd D | -3% Sp S -9% Sp D-3% Sd S-8% Sd D
Kandziora ^38^ | Hypertensive | Dehydrated tablet: Kwai ^®^ vs. antihypertensive | Sp 176/99 Sd 178/100 | 4 weeks | -6% Sp S -11% Sp D -5% Sd S -12% Sd D | -6% Sp S -11% Sp D -6% Sd S -11% Sd D
Kandziora ^38^ | Hypertensive | Dehydrated tablet: Kwai ^®^ vs. antihypertensive | Sp 176/99 Sd 178/100 | 12 weeks | -7% Sp S -14% Sp D -6% Sd S -15% Sd D | -7% Sp S -14% Sp D -7% Sd S -14% Sd D
Kannar ^78^ | Hyperlipidemic | Dehydrated tablet: Cotter Foods^®^ vs. placebo | St 126/76 | 12 weeks | -1% St S +1.4 St D | -2.8 St S +0.3 St D
Kiesewetter^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai^®^ vs. placebo | Uc 116/74 | 4 weeks | -9.5% Uc S | "Change not significant"
Kiesewetter^69^ | Lower extremity peripheral vascular disease | Dehydrated tablet: Kwai^®^ vs. placebo | Uc D 85 | 12 weeks | "No change" Uc S -3.5% Uc D | "No change" Uc S -2% Uc D
Luley (1) ^Cr^ ^96^ | Hyperlipidemic | Dehydrated tablet vs. placebo | Not given | 6 weeks | "No change" | "No change"
Luley(2) ^Cr^ ^96^ | Hyperlipidemic | Dehydrated tablet vs. placebo | Not given | 6 weeks | "No change" | "No change"
Mansell^84^ | Diabetics | Dehydrated tablet vs. placebo | Not given | Not given | "No significant effect" | "No significant effect"
McCrindle^90^ | Hyperlipidemic and early coronary artery disease | Dehydrated tablet: Kwai^®^ vs. placebo | Uc 102/62 | 8 weeks | +2% Uc S 0% Uc D | "Change not significant"
Saradeth^92^ | Age 18 to 50 | Dehydrated tablet: Kwai^®^ vs. placebo | Uc 125/81 | 5 weeks | -1% Uc S 0% Uc D | -3% Uc S 0% Uc D
Saradeth^92^ | Age 18 to 50 | Dehydrated tablet: Kwai^®^ vs. placebo | Uc 125/81 | 15 weeks | +2% Uc S +2% Uc D | -1% Uc S -1% Uc D
Simons ^Cr^ ^93^ | Hyperlipidemic | Dehydrated tablet: Kwai^®^ vs. placebo | Uc 127/80 | 12 weeks | "Change not significant" | "Change not significant"
Steiner ^b^ ^Cr^ ^94^ | Hyperlipidemic | "Aged garlic extract^TM^" vs. placebo | Uc 134/84 | 13 weeks | -7% Uc S -2% Uc D | -4% Uc S -7% Uc D
Steiner ^b^ ^Cr^ ^94^ | Hyperlipidemic | "Aged garlic extract^TM^" vs. placebo | Uc 134/84 | 26 weeks | -7% Uc S -2% Uc D | -3% Uc S -4% Uc D
Superko^80^ | Hyperlipidemic | Dehydrated tablet: Kwai^®^ vs. placebo | Not given | 12 weeks | "Change not significant" (no between group differences) | "Change not significant" (no between group differences)
Ventura^98^ | Hyperlipidemic | Dehydrated tablet/hawthorn vs. placebo | Uc 164/84 | 8 weeks | -8% Uc S -2% Uc D | -2% Uc S -2% Uc D
Vorberg^75^ | Hyperlipidemic | Dehydrated tablet: Kwai^®^ vs. placebo | Sp 146/92 | 4 weeks | -1% Sp S -3% Sp D | 0% Sp S 0% Sp D
Vorberg^75^ | Hyperlipidemic | Dehydrated tablet: Kwai^®^ vs. placebo | Sp 146/92 | 12 weeks | -1% Sp S -4% Sp D | +1% Sp S +3% Sp D
Vorberg^75^ | Hyperlipidemic | Dehydrated tablet: Kwai^®^ vs. placebo | Sp 146/92 | 16 weeks | -3% Sp S -4% Sp D | +2% Sp S +3% Sp D
Yeh ^77^ | Hyperlipidemic | "Aged garlic extract^TM^" vs. placebo | Uc 121/82 | 8 weeks 16 weeks 20 weeks | 2% Uc S -5% Uc D 5% Uc S 2% Uc D 2% Uc S 1% Uc D | -5% Uc S -4% Uc D 1% Uc S -1% Uc D 1% Uc S 0% Uc D

a Reported result was for several treatment arms (including garlic) that achieved reductions somewhere within the given range for each of the parameters listed (p<0.05).

b Our reported changes are derived from graphs presented in the original article.^94^

Cr Crossover trial

Abbreviations used: D = diastolic measures; M = mean measures; S = systolic measures; Sd = standing; Sp = supine; St = sitting; Uc = position unclear.

Evidence Table 4. Results of trials assessing effect of garlic supplementation on serum glucose

Study | Participants | Intervention | Time at Outcome (weeks) | Reported Glucose Result (garlic) | Reported Glucose Result (placebo)
Auer ^39^ | Hypertensives | Dehydrated tablet: Kwai^®^ vs. placebo | 0 | Not given | Not given
Auer ^39^ | Hypertensives | Dehydrated tablet: Kwai^®^ vs. placebo | 4 | "No significant changes" | "No significant changes"
Bordia ^72^ | History of myocardial infarction | Garlic ether extract vs. placebo | 0 | 96.8 +/- ^ SE^ 3.7 mg/dL | 93.3 +/- ^ SE^ 3.0 mg/dL
Bordia ^72^ | History of myocardial infarction | Garlic ether extract vs. placebo | 6 | 97.9 +/- ^ SE^ 3.3 mg/dL | 92.2 +/- ^ SE^ 3.3 mg/dL
Bordia ^72^ | History of myocardial infarction | Garlic ether extract vs. placebo | 12 | 100.8 +/- ^ SE^ 2.5 mg/dL | 96.1 +/- ^ SE^ 2.3 mg/dL
Czerny ^70^ | Hyperlipidemia and intermittent claudication | Garlic oil macerate combination vs. placebo | 0 | Not given | Not given
Czerny ^70^ | Hyperlipidemia and intermittent claudication | Garlic oil macerate combination vs. placebo | 12 | "No relevant change" | "No relevant change"
Jain ^24^ | Hyperlipidemics | Dehydrated tablet: Kwai ^®^ vs. placebo | 0 | 100 +/- ^ SD^ 11 mg/dL | 98 +/- ^ SD^ 9 mg/dL
Jain ^24^ | Hyperlipidemics | Dehydrated tablet: Kwai ^®^ vs. placebo | 6 | 102 +/- ^ SD^ 13 mg/dL | 97 +/- ^ SD^ 7 mg/dL
Jain ^24^ | Hyperlipidemics | Dehydrated tablet: Kwai ^®^ vs. placebo | 12 | 98 +/- ^ SD^ 12 mg/dL | 97 +/- ^ SD^ 7 mg/dL
Kandziora ^38^ | Hypertensives | Dehydrated tablet: Kwai ^®^ vs. antihypertensive | 0 | Not given | Not given
Kandziora ^38^ | Hypertensives | Dehydrated tablet: Kwai ^®^ vs. antihypertensive | 12 | "No change" | "No change"
Kandziora ^37^ | Hypertensives | Dehydrated tablet: Kwai ^®^ and antihypertensive vs. antihypertensive | 0 | 112 +/- ^ SD^ 15 mg/dL | 117 +/- ^ SD^ 10 mg/dL
Kandziora ^37^ | Hypertensives | Dehydrated tablet: Kwai ^®^ and antihypertensive vs. antihypertensive | 12 | 110 +/- ^ SD^ 11 mg/dL | 113 +/- ^ SD^ 11 mg/dL
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | 0 | 89.4 +/- ^ SD^ 8.7 mg/dL | Not given
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | 4 | 79.0 +/- ^ SD^ 11.9 mg/dL | "No influence"
Koscielny ^88^ | Asymptomatic advanced atherosclerotic plaques of femoral or carotid artery | Dehydrated tablet: Kwai ^®^ vs. placebo | 0 | Results not reported | Results not reported
Koscielny ^88^ | Asymptomatic advanced atherosclerotic plaques of femoral or carotid artery | Dehydrated tablet: Kwai ^®^ vs. placebo | 26 | Results not reported | Results not reported
Luley (1) ^Cr^ ^96^ | Hyperlipoproteinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | 0 | Results not reported | Results not reported
Luley (1) ^Cr^ ^96^ | Hyperlipoproteinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | 6 | Results not reported | Results not reported
Luley (2) ^Cr^ ^96^ | Hyperlipoproteinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | 0 | Results not reported | Results not reported
Luley (2) ^Cr^ ^96^ | Hyperlipoproteinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | 6 | Results not reported | Results not reported
Mansell ^84^ | Adult diabetics | Dehydrated tablet vs. placebo | 12 | "No significant effect" | "No significant effect"
Sitprija ^73^ | Adult diabetics without complications | Dehydrated tablet vs. placebo | 0 | 185 mg/dL ^a^ | 185 +/- ^ SD^ 15 mg/dL ^a^
Sitprija ^73^ | Adult diabetics without complications | Dehydrated tablet vs. placebo | 4 | "No influence" | "No influence"

a Imputed from graphical data, no variance given for treatment group.

To convert cholesterol, LDL, and HDL values from mg/dL to mmol/dL, divide by 38.7. To convert triglyceride values from mg/dL to mmol/dL, divide by 88.2.

Abbreviations used: CR = crossover study; mg/dL = milligrams per deciliter; SD = standard deviation; SE = standard error of the mean.

Evidence Table 5. Reported results from trials assessing the effect of garlic supplementation on thrombotic factors

Study | Inclusion Criteria | Intervention | Cointervention | Endpoint | Method | Time at Outcome (weeks) | Reported Result (garlic) | Reported Result (placebo)
Barrie^Cr^ ^36^ | None | Garlic oil macerate vs. placebo | None | PA | Born 1962 | 0 | Not provided | Not provided
Barrie^Cr^ ^36^ | None | Garlic oil macerate vs. placebo | None | PA | Born 1962 | 4 | CS: -16.4% | CS: +5.6%
Bordia ^72^ | History of myocardial infarction | Garlic oil extract vs. placebo | None | SF | Nath and Debnath 1970 | 0 | 308.7 +/- ^SE^ 16.1 mg/dL | 298.7 +/- ^ SE^ 12.3 mg/dL
Bordia ^72^ | History of myocardial infarction | Garlic oil extract vs. placebo | None | SF | Nath and Debnath 1970 | 6 | 310.1 +/- ^ SE^ 14.7 mg/dL | 300.8 +/- ^ SE^ 10.1 mg/dL
Bordia ^72^ | History of myocardial infarction | Garlic oil extract vs. placebo | None | SF | Nath and Debnath 1970 | 12 | 298.5 +/- ^ SE^ 15.2 mg/dL | 305.3 +/- ^ SE^ 12.9 mg/dL
Bordia ^72^ | History of myocardial infarction | Garlic oil extract vs. placebo | None | FA | Euglobulin lysis time | 0 | 50.4 +/- ^ SE^ 5.7 U | 55.0 +/- ^ SE^ 3.9 U
Bordia ^72^ | History of myocardial infarction | Garlic oil extract vs. placebo | None | FA | Euglobulin lysis time | 6 | 70.3 +/- ^ SE^ 6.5 U | 60.8 +/- ^ SE^ 5.5 U
Bordia ^72^ | History of myocardial infarction | Garlic oil extract vs. placebo | None | FA | Euglobulin lysis time | 12 | 78.2 +/- ^ SE^ 5.9 U | 56.8 +/- ^ SE^ 4.7
Chutani ^74^ | History of myocardial infarction | Raw garlic vs. no garlic | Prepared in 3 g of butter | FA | Euglobulin lysis time | 0 | 66.0 +/- ^ SE^ 6.1 U | 57.7 +/- ^ SE^ 6.2 U
Chutani ^74^ | History of myocardial infarction | Raw garlic vs. no garlic | Prepared in 3 g of butter | FA | Euglobulin lysis time | 4 | 122.0 +/- ^ SE^ 7.3 U | 59.4 +/- ^ SE^ 5.2 U
Chutani ^74^ | History of myocardial infarction | Fried garlic vs. no garlic | Prepared in 3 g of butter | FA | Euglobulin lysis time | 0 | 64.0 +/- ^ SE^ 5.0 U | 57.7 +/- ^ SE^ 6.2 U
Chutani ^74^ | History of myocardial infarction | Fried garlic vs. no garlic | Prepared in 3 g of butter | FA | Euglobulin lysis time | 4 | 110.2 +/- ^ SE^ 8.0 U | 59.4 +/- ^ SE^ 5.2 U
Czerny ^70^ | Hyperlipidemia and atherosclerotic claudication | Garlic oil macerate vs. placebo | None | PA | Not specified | 0 | Not provided | Not provided
Czerny ^70^ | Hyperlipidemia and atherosclerotic claudication | Garlic oil macerate vs. placebo | None | PA | Not specified | 16 | CS: -46% | CS: +7
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PA | Breddin 1975 | 0 | 40.7 +/-23.3 | Not provided
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PA | Breddin 1975 | 4 | 17.8 +/-23.2 | Not provided
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PV | Capillary tube plasmaviscometer Jung 1983 | 0 | 1.25 +/-0.34 mPas | Not provided
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PV | Capillary tube plasmaviscometer Jung 1983 | 4 | 1.21 +/-0.43 mPas | "No change"
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | None | SF | Not specified | 0 | Not provided | Not provided
Kiesewetter ^87^ | Elevated spontaneous platelet aggregation | Dehydrated tablet: Kwai ^®^ vs. placebo | None | SF | Not specified | 4 | "No change" | "No change"
Kiesewetter ^69^ | Lower extremity peripheral vascular disease | Dehydrated tablet: Kwai ^®^ vs. placebo | 90 minutes per week of physical therapy | PA | Breddin 1975 | 0 | 29.5 +/- ^ SD^ 23.8 | Not provided
Kiesewetter ^69^ | Lower extremity peripheral vascular disease | Dehydrated tablet: Kwai ^®^ vs. placebo | 90 minutes per week of physical therapy | PA | Breddin 1975 | 12 | 12.1 +/- ^ SD^ 12.3 | "No change"
Kiesewetter ^69^ | Lower extremity peripheral vascular disease | Dehydrated tablet: Kwai ^®^ vs. placebo | 90 minutes per week of physical therapy | PV | Not specified | 0 | 1.39 +/- ^ SD^ 0.89 mPas | Not provided
Kiesewetter ^69^ | Lower extremity peripheral vascular disease | Dehydrated tablet: Kwai ^®^ vs. placebo | 90 minutes per week of physical therapy | PV | Not specified | 12 | 1.34 +/- ^ SD^ 0.61 mPas | "No change"
Koscielny ^88^ | Asymptomatic advanced atherosclerotic plaque of femoral or carotid artery | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PA | Not specified | 0 | Not provided | Not provided
Koscielny ^88^ | Asymptomatic advanced atherosclerotic plaque of femoral or carotid artery | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PA | Not specified | 26 | Not provided | Not provided
Koscielny ^88^ | Asymptomatic advanced atherosclerotic plaque of femoral or carotid artery | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PV | Not specified | 0 | Not provided | Not provided
Koscielny ^88^ | Asymptomatic advanced atherosclerotic plaque of femoral or carotid artery | Dehydrated tablet: Kwai ^®^ vs. placebo | None | PV | Not specified | 26 | Not provided | Not provided
Luley (1) ^Cr^ ^96^ | Hyperlipopro-teinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | None | SF | "Auto-fi" | 0 | Pooled crossover results only | Pooled result only
Luley (1) ^Cr^ ^96^ | Hyperlipopro-teinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | None | SF | "Auto-fi" | 6 | "No significant change" | "No significant change"
Luley (1) ^Cr^ ^96^ | Hyperlipopro-teinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | None | FA | Euglobulin lysis time | 0 | Pooled crossover results only | Pooled result only
Luley (1) ^Cr^ ^96^ | Hyperlipopro-teinemia types IIa, IIb, or IV | Dehydrated tablet vs. placebo | None | FA | Euglobulin lysis time | 6 | "No significant change" | "No significant change"
McCrindle ^90^ | TC > 185 mg/dL and family history of hyperlipidemia and early coronary artery disease | Dehydrated tablet: Kwai ^®^ vs. placebo | NCEP step II diet | SF | Not specified | 0 | 243 +/- ^ SD^ 56 mg/dL | 254 +/- ^ SD^ 47 mg/dL
McCrindle ^90^ | TC > 185 mg/dL and family history of hyperlipidemia and early coronary artery disease | Dehydrated tablet: Kwai ^®^ vs. placebo | NCEP step II diet | SF | Not specified | 8 | CS: -19 mg/dL (CI: -64 to +26) | CS: -7.8 mg/dL (CI: -26 to +11)
McCrindle ^90^ | TC > 185 mg/dL and family history of hyperlipidemia and early coronary artery disease | Dehydrated tablet: Kwai ^®^ vs. placebo | NCEP step II diet | SH | Not specified | 0 | 6.49 +/- ^ SD^ 1.17 mcM | 8.25 +/- ^ SD^ 2.32 mcM
McCrindle ^90^ | TC > 185 mg/dL and family history of hyperlipidemia and early coronary artery disease | Dehydrated tablet: Kwai ^®^ vs. placebo | NCEP step II diet | SH | Not specified | 8 | CS: +0.67mcM (CI: -0.5 to +1.8) | CS: +10.5mcM (CI -5 to +26)
Steiner^102^ | Hyperlipidemic men | "Aged garlic extract ^TM^ " vs. placebo | NCEP step I diet | PA | Adhesion of platelet rich plasma to Fibrinogen | 0 12 24 | Not provided 0.74+/- ^ SD^ 0.3 0.68+/- ^ SD^ 0.27 X10 ^6^/cm ^2^ | Not provided 1.1+/- ^ SD^ 0.4 1.2+/- ^ SD^ 0.35 X10^6^/cm ^2^

To convert cholesterol, LDL, and HDL values from mg/dL to mmol/dL, divide by 38.7. To convert triglyceride values from mg/dL to mmol/dL, divide by 88.2.

Abbreviations used: CI = 95% confidence interval; CR = crossover study; CS = change score; FA = fibrinolytic activity; g = gram; McM = micromoles/L; Mg/dL = milligrams per deciliter; Mpas = millipascals; NCEP = National Cholesterol Education Program; PA = platelet aggregation; PV = plasma viscosity; SD = standard deviation; SE = standard error of the mean; SF = serum fibrinogen; SH = serum homocysteine; TC = total cholesterol.

Evidence Table 6. Summary of associations between garlic and cancer

Cancer | Study Type | Inverse Association | Garlic Exposure | Analysis Comparison
Laryngeal | Population based case-control ^116^ | Test for trend significant p = 0.02 | Monthly garlic consumption | Tertiles
Breast | Case-cohort ^106^ | RR 0.75 ^a^ (0.41 to 1.38) | Daily garlic supplement use | Supplement vs. none
| Hospital based case-control ^115^ | Test for trend not significant | Weekly garlic consumption | Tertiles
Lung | Case-cohort ^113^ | RR 1.78* (1.08 to 2.92) | Daily garlic supplement use | Supplement vs. none
Esophageal | Population based case-control ^118^ | OR 0.48 for 1 to 3X (0.19 to 1.25) OR 0.30 for >3X (0.19 to 0.47) | Monthly garlic consumption | At least once monthly vs. once monthly or none
| Population based case-control ^117^ | Men: OR 1.11 (0.77 to 1.59) Women: OR 0.80 (0.51 to 1.27) | Monthly garlic consumption | At least once monthly vs. once monthly or none
Gastric | Case-cohort ^112^ | RR 1.27* (0.61 to 2.64) | Daily garlic supplement use | Supplement vs. none
| Population based case-control ^118^ | OR 0.40 for 1 to 3X (0.21 to 0.76) OR 0.31 for >3X (0.22 to 0.44) | Monthly garlic consumption | At least once monthly vs. once monthly or none
| Population based case-control ^111^ | OR 0.8 for 0.1 to 1.5 kg (0.5 to 1.2) OR 0.7 for >1.5 kg (0.4 to 1.0) | kg of annual garlic consumption | Annual consumption vs. none
| Population based case-control ^56^ | Test for trend significant p<0.001 | Usual annual cooked garlic consumption | Tertiles
Colorectal | Case-cohort ^108^ | RR 1.28* (0.63 to 2.60) for rectal cancer RR 1.36* (0.79 to 2.35) for colon cancer | Daily garlic supplement use | Supplement vs. none
| Case cohort ^60^ | Test for trend significant p<0.05 for distal colon cancer | Weekly servings of fresh garlic cloves or powder | Tertiles
| Hospital based case-control ^59^ | Test for trend significant p<0.01 | Weekly garlic consumption | Tertiles
Endometrial | Hospital based case-control ^114^ | Test for trend significant p<0.05 | Weekly garlic consumption | Tertiles
Prostate | Population based case-control ^61^ | Negative test for trend p = 0.129 | Monthly garlic consumption | Three categories of frequency vs. none

a Given for garlic supplement use exclusive of other supplements.

Abbreviations used: kg = kilogram; OR = odds ratio; RR = risk ratio.

Evidence Table 7. Summary of associations between garlic and precancerous conditions

Cancer | Evidence Type | Inverse Association | Garlic Exposure | Analysis Comparison
Colonic polyps | Community health plan case-control study ^105^ | Positive test for trend p = 0.01 | Weekly garlic consumption | Tertiles
Chronic atrophic gastritis and gastric metaplasia | Small selective survey ^104^ | Negative tests for trend | Kilograms of annual garlic consumed | Tertiles

Evidence Table 8. Studies addressing protective associations between garlic and cancer

Study | Cases | Controls | Exposure Definition | Outcomes
You ^104^ (China) Precancerous lesion: Chronic atrophic gastritis and metaplasia/ dysplasia Survey, 1998 | No. of survey participants: 197 (147 with chronic atrophic gastritis and 20 with metaplasia or dysplasia) Mean age: Not given Male: 49% Selection: Community Response eligible population: 30% Histological confirmed: 100% | Not Applicable (147 with atrophic gastritis and 20 with metaplasia or dysplasia) | Type and frequency: Kilograms of garlic consumed annually Assessment method: Interviewer administered questionnaire Recall bias possibility: Yes | Odds ratio (95% CI) Comparison groups 0 to 4.9 kg vs. 5 to 15 kg Chronic atrophic gastritis 0.70 (0.21 to 2.30) Metaplasia/Dysplasia 0.55 (0.08 to 3.71) Adjusted for: Age, cigarette smoking, eggs, grain, meat, salt, fresh vegetables other than Allium, salted vegetables, sex
Witte^105^ (United States) Precancerous lesion: colorectal polyps Population-based-matched case-control study, 1996 | No. of cases: 488 Mean age: 62 Male: 66% Selection: Hospital Response eligible population: 84% Histological confirmed: 100% | No. of controls: 488 Mean age: 62 Male: 66% Selection: Hospital Response eligible population: 84% | Type and frequency: Servings of garlic per week Assessment method: Interviewer administered semiquantitative food-frequency questionnaire given 5 months after sigmoidoscopy Recall bias possibility: Yes | Odds ratio (95% CI) Referent group: No garlic 0.5 0.92 (0.64 to 1.34) 1.0 to 2.5 0.98 (0.61 to 1.56) >3.0 0.66 (0.43 to 1.01) "The test for trend for the adjusted odds ratio was statistically significant, p=0.01" Adjusted for:β-carotene, calories, body mass index, folate, physical activity, race, saturated fat, smoking, sources of fiber, vitamin C
Buiatti^56^ (Italy) Gastric cancer Population-based case-control study, 1989 | No. of cases: 1,016 Mean age: 60 (approximate) Male: 63% Selection: Community population, specialty clinic, hospital, cancer registry Response eligible population: 83% Histological confirmed: 100% | No. of controls: 1,159 Mean age: 60 (approximate) Male: 61% Selection: Community population, specialty clinic, hospital, cancer registry Response eligible population: 83% | Type and frequency: Average consumption of cooked garlic Assessment method: Interview administered food-frequency questionnaire Recall bias possibility: Yes | Odds ratio (95% CI) Referent group: Lowest tertile of consumption Middle tertile 0.6 (CI not given) Highest tertile 0.4 (CI not given) Test for trend p<0.001 Adjusted for: Age, family history of gastric cancer, migration from south, Quetelet index, residence, sex, social class
Cook-Mozaffari ^117^ (Iran) Esophageal cancer Case-control study, 1979 | No. of cases: 324 Mean age: Not given Male: 63% (approximate) Selection: Population-based cancer registry Histological confirmed: 4% histology and 71% radiology | No. of controls: 648 Mean age: Not given Male: 63% (approximate) Selection: Community population | Type and frequency: Raw garlic consumption Assessment method: Structured questionnaire Recall bias possibility: No | Odds ratio (95% CI) Referent group: Comparison More than once per month vs. less than once per month Men: 1.11 (0.77 to 1.59) Women: 0.80 (0.51 to 1.27) Adjusted for: Not adjusted
Dorant ^106^ (Netherlands) Breast cancer Case-cohort study, 1995 | No. of cases: 469 Mean age: 62 Male: 0% Selection: Community Response eligible population: Estimated 95% Histological confirmed: 100% | No. of controls: 1,713 Mean age: 62 Male: 0% Selection: Community Response eligible population: Estimated 95% | Type and frequency: Garlic supplement (daily use at least 1 year in past 5 years) Assessment method: Self-administered semiquantitative food-frequency questionnaire Recall bias possibility: No | Risk ratio (95% CI) Referent group: No garlic Only garlic supplement: 0.75 (0.41 to 1.38) Garlic with or without any other supplements: 0.87 (0.58 to 1.31) Adjusted for: Age at first birth, age at menarche, age at menopause, age, alcohol consumption, artificially induced menopause, breast cancer in mother and/or sister, dietary intake of vitamin C and β-carotene, education, history of benign breast disease, oral contraceptive use, nulliparity, parity, Quetelet index, smoking status
Dorant ^113^ (Netherlands) Lung cancer Case-cohort study, 1994 | No. Cases: 484 Mean age: 62 Male: 89% Selection: Community population Response eligible population: Estimated 95% Histological confirmed: 100% | No. of controls: 3,123 Mean age: 61 Male: 49% Selection: Community population Response eligible population: Estimated 95% | Type and frequency: Garlic supplement (daily use at least 1 year in past 5 years) Assessment method: Self-administered semiquantitative food-frequency questionnaire Recall bias possibility: No | Risk ratio (95% CI) Referent group: No garlic Only garlic supplement: 1.78 (1.08 to 2.92) Garlic with or without any other supplements: 1.22 (0.81 to 1.86) 0.92 (0.46 to 1.86) Adjusted for: Age, gender, dietary intake of vitamin C and β-carotene, education, history of COPD, onion and leek consumption, smoking
Dorant ^108^ (Netherlands) Colorectal cancer Case-cohort study, 1996 | No. of cases: 443 Mean age: 61 Male: 54% Selection: Population-based cancer registry Response eligible population: Estimated 95% Histological confirmed: 100% | No. of controls: 3,123 Mean age: 61 Male: 49% Selection: Population-based cancer registry Response eligible population: Estimated 95% | Type and frequency: Garlic supplement (daily use at least 1 year in past 5 years) Assessment method: Self-administered semiquantitative food-frequency questionnaire Recall bias possibility: No | Risk ratio (95% CI) Referent group: No garlic Colon: Only garlic supplement: 1.36 (0.79 to 2.35) Garlic with or without any other supplements: 1.26 (0.84 to 1.91)Any other supplements: 0.93 (0.51 to 1.71) Referent group: No garlic Rectum: Only garlic supplement: 1.28 (0.63 to 2.60) Garlic with or without any other supplements: 0.77 (0.41 to 1.46) Adjusted for: Age, education, family history of intestinal cancer, gender, history of chronic intestinal disease or cholecystetectomy, smoking status, Vitamin C and β-carotene
Dorant^112^ (Netherlands) Gastric cancer Case-cohort study, 1996 | No. of cases: 139 Mean age: Not given Male: 77% Selection: Community population Response eligible population: Estimated 95% Histological confirmed:100% | No. of controls: 3,123 Mean age: Not given Male:49% Selection: Community populations Response eligible population: Estimated 95% | Type and frequency: Garlic supplement (daily use at least 1 year in past 5 years) Assessment method: Self-administered semiquantitative food-frequency questionnaire Recall bias possibility: No | Risk ratio (95% CI) Referent group: No garlic Only garlic supplement: 1.27 (0.61 to 2.64) Garlic with or without any other supplements: 1.28 (0.45 to 3.66) Adjusted for: Age, alcohol intake, β-carotene intake, education, family history of stomach cancer, history of stomach disorders, onion and leek consumption, sex, smoking status, vitamin C intake
Gao^118^ (China) Esophageal cancer Case-control study, 1999 | No. of cases: 81 Mean age: 59 Male:54% Selection: Population-based cancer registry Histological confirmed: 100% | No. of controls: 234 Mean age: 59 Male: 66% Selection: Community | Type and frequency: Garlic consumption divided in six categories Assessment method: Structured interview-administered questionnaire Recall bias possibility: No | Odds ratio (95% CI) Comparisons: One to three times per month vs. less than once per month or never 0.48 (0.19 to 1.25) Once per week vs. less than once permonth or never 0.30 (0.19 to 0.47) Adjusted for: Age, gender, income, smoking, drinking status, tea, intake of leftover gruel, pickled vegetables, meat, fruit, tomatoes, eggs, snap beans
Gao^118^ (China) Gastric cancer Case-control study, 1999 | No. of cases: 153 Mean age: 59 Male: 72% Selection: Population-based cancer registry Histological confirmed: 100% | No. of controls: 234 Mean age:59 Male: 66% Selection: Community | Type and frequency: Garlic consumption divided in six categories Assessment method: Structured interview-administered questionnaire Recall bias possibility: No | Odds ratio (95% CI) Comparisons: One to three times per month vs. less than once per month or never 0.40 (0.21 to 0.76) Once per week vs. less than once per month or never 0.31 (0.22 to 0.44) Adjusted for: Age, gender, income, smoking, drinking status, tea, intake of leftover gruel, pickled vegetables, meat, fruit, tomatoes, eggs, snap beans
Key^61^ (England) Prostate cancer Population-based case-control study, 1997 | No. of cases: 328 Mean age: 68 Male: 100% Selection: General practitioner list, cancer registry Response eligible population: 81% Histological confirmed: Probably 100% but unclear | No. of controls: 328 Mean age: 68 Male: 100% Selection: General practitioners list, cancer registry Response eligible population: 81 | Type and frequency: Garlic consumption, including supplements consumed weekly and monthly Assessment method: Interview-administered food-frequency questionnaire Recall bias possibility: Yes | Odds ratio (95% CI) Referent group: No garlic < 1 time per month 0.94 (0.51 to 1.73) 1 to 4 times per month 0.77 (0.49 to 1.20) >2 times per week 0.64 (0.38 to 1.09) Adjusted for: Social class
Levi^59^ (Switzerland) Colorectal cancer Hospital-based case-control study, 1999 | No. of cases: 223 Mean age: 63 (median) Male: 64% Selection: Hospital Response eligible population: 85% Histological confirmed: 100% | No. of controls: 491 Mean age: 58 (median) Male: 43% Selection: Hospital Response eligible population: 85% | Type and frequency: Garlic (not specified) Assessment method: Interview-administered food-frequency questionnaire Recall bias possibility: Yes | Odds ratio (95% CI) Referent group: Lowest tertile of consumption Middle tertile 0.50 (0.34 to 0.74) Highest tertile 0.39 (0.21 to 0.70) Adjusted for: Age, alcohol, body mass index, education, meat and vegetable consumption, physical activity, sex, smoking, total energy intake
Levi^114^ (Switzerland, Italy) Endometrial cancer Cooperative case-control study, 1993 | No. of cases: 274 Mean age: 61 Male: 0% Selection: Hospital-based cancer registry Histological confirmed: 100% | No. of controls: 572 Mean age: 59 Male: 0% Selection: Hospital-based cancer registry | Type and frequency: Weekly garlic consumption Assessment method: Self-reported structured questionnaire Recall bias possibility: No | Odds ratio (95% CI) Referent group: Lowest tertile of garlic consumption Middle tertile 0.67 (CI not given) Highest tertile 0.71 (CI not given) Adjusted for: Age and study center
Levi^115^ (Switzerland) Breast cancer Case-control study, 1993 | No. of cases: 107 Mean age: 54 Male: 0% Selection: University hospital-based cancer registry Histological confirmed: 100% | No. of controls: 318 Mean age: 55 Male: 0% Selection: University hospital | Type and frequency: Weekly garlic consumption Assessment method: Self-reported subjective-structured questionnaire Recall bias possibility: No | Odds ratio (95% CI) Referent group: Lowest tertile of garlic consumption Middle tertile 0.7 (CI not given) Highest tertile 0.6 (CI not given) Adjusted for: Age
Steinmetz^60^ (United States) Colorectal cancer Case-cohort study, 1994 | No. Cases: 212 Mean age: 62 Male: 0% Selection: Community population Response eligible population: 80% Histological confirmed:100% | No. of controls: 35,004 Mean age: 62 Male: 0% Selection:Community population Response eligible population: 84% | Type and frequency: Garlic clove or shake (powder) servings per week Assessment method: Self-administered, 127-item, food-frequency questionnaire Recall bias possibility: No | Risk ratio (95% CI) Referent group: No garlic intake Proximal colon cancer: .5 1.32 (0.79 to 2.22) >1.0 1.00 (0.56 to 1.79) Distal colon cancer: .5 0.85 (0.53 to 1.36) >1.0 0.52 (0.30 to 0.93) The adjusted odds ratio for trend was significant for distal but not proximal or overall colon cancer. Adjusted for: Age and energy intake
You^55^ ^110^ ^111^ (China) Gastric cancer Population-based case-control study, 1991 | No. of cases: 564 Mean age: Not given Male: Not given Selection: Census roster, county and community hospitals Response eligible population: 82% Histological confirmed: Histology 50%, surgery or endoscopy without histology 32%, radiologic or clinical grounds 17% | No. of controls: 1,131 Mean age: Not given Male: Not given Selection: Census roster, county and community hospitals Response eligible population: 82% | Type and frequency: Kilograms of whole garlic and garlic stalks consumed annually Assessment method: Food-frequency questionnaire Recall bias possibility: Yes | Odds ratio (95% CI) Referent group: No garlic Whole garlic: 0.1 to 1.5 0.8 (0.5 to 1.2)>1.5 0.7 (0.4 to 1.0) Adjusted for: Age, income, intake of otherAllium vegetables, sex
Zheng^116^ (China) Laryngeal cancerCase-control study, 1988-1990 | No. of cases: 201 Mean age: Not given Male: 88% Selection: Community population Histological confirmed: 92% | No. of controls: 414 Mean age:Not given Male: 65% Selection: Community population | Type and frequency: Monthly garlic consumption Assessment method:Structured questionnaire Recall bias possibility: No | Odds ratio (95% CI) Referent group: Lowest tertile of garlic consumption Middle tertile 0.6 (CI not given) Highest tertile 0.5 (CI not given) Adjusted for: Age, education, smoking, alcohol consumption, income, exposure to asbestos or coal dust, kerosene stove usage.

Abbreviations used: CI = confidence interval; kg = kilogram; COPD = chronic obstructive pulmonary disease.

Evidence Table 9. Summary of adverse effects

Adverse Effect | Type of Garlic Exposure | Level of Evidence
Breath or body odor | Oral use of standardized dehydrated tablet | Randomized controlled trials
Skin manifestations: Contact dermatitis Ulcero-necrotic lesions Skin blisters, bullae, vescicles | Oral use for one case of contact dermatitisTopical use for the remaining lesions | Case series and multiple case reports with resolution of lesions after discontinuation of garlic; no rechallenge tests
Allergic manifestations: Asthma Rhinitis Conjunctivitis Urticaria Anaphylaxis Angioedema | Oral use for one case of asthma and rhinitisGarlic dust inhalation for the remaining cases | Case series and multiple case reports with resolution of symptoms after discontinuation of garlic; positive rechallenge tests for asthma
Cardiovascular: Myocardial infarction | Oral use | Single case report
Coagulation dysfunction: Postoperative bleeding Spontaneous spinal epidural hematoma Increased International Normalized Ratio Clotting time prolongation Failure of platelet aggregation test | Oral use | Five case reports
Gastrointestinal: Small intestine obstruction Epigastric and esophageal pain Flatulence Hematemesis, hematochezia | Oral use | Case reports and case series
Other: Meniere's Botulism Garlic smell in the breath of newborn infant | Oral use | Case-control study for botulismCase report for Meniere's and infant garlic breath