# Bibliography

Adler AJ, Holub BJ. Effect of garlic and fish-oil supplementation on serum lipid and lipoprotein concentrations in hypercholesterolemic men. Am J Clin Nutr. 1997;65:445-50. [pmid: 9022529].
Agarwal RK, Dewar HA, Newell DJ, et al. Controlled trial of the effect of cycloalliin on the fibrinolytic activity of venous blood. Atherosclerosis. 1977;27:347-51. [pmid: 332196].
Akl KF. Adverse effects of herbal medicine. J Bahrain Med Soc. 1994;6:41-2.
The American Journal of Occupational Therapy (AJOT). Am J Occup Ther 1980;34:10.
Andre F, Andre C, Colin L, et al. Role of new allergens and of allergens consumption in the increased incidence of food sensitizations in France. Toxicology. 1994;93:77-83. [pmid: 7974507].
Angelini G, Vena GA, Filotico R, et al. Allergic contact dermatitis from Capparis spinosa L. applied as wet compress. Contact Dermatitis. 1991;24:382-3. [pmid: 1893693].
Anibarro B, Fontela JL, De La Hoz F. Occupational asthma induced by garlic dust. J Allergy Clin Immunol. 1997;100:734-8. [pmid: 9438479].
Armentia A, Vega JM. Can inhalation of garlic dust cause asthma? [published erratum appears in Allergy 1997; 52: 358]. Allergy. 1996;51:137-8. [pmid: 8738525].
Arora RC, Arora S. Comparative effect of clofibrate, garlic and onion on alimentary hyperlipemia. Atherosclerosis. 1981;39:447-52. [pmid: 7259824].
Arora RC, Arora S, Gupta RK. The long-term use of garlic in ischemic heart disease: an appraisal. Atherosclerosis. 1981;40:175-9. [pmid: 7306257].
Asero R, Mistrello G, Roncarolo D, et al. A case of garlic allergy. J Allergy Clin Immunol. 1998;101:427-8. [pmid: 9525465].
Auer W, Eiber A, Hertkorn E, et al. Hypertension and hyperlipidaemia: garlic helps in mild cases. Br J Clin Pract Symp Suppl. 1990;69:3-6. [pmid: 2083170].
Augusti KT. Hypocholesterolaemic effect of garlic, Allium sativum Linn. Indian J Exp Biol. 1977;15:489-90. [pmid: 598887].
Ballard-Barbash R, Krebs-Smith S, Subar AF. Re: "Vegetables, fruit, and colon cancer in the Iowa Women's Health Study." [published erratum appears in Am J Epidemiol 1995; 141: 697]. Am J Epidemiol. 1995;141:84-6.
Barrie SA, Wright JV, Pizzorno JE. Effects of garlic oil on platelet aggregation, serum lipids and blood pressure in humans. J Orthomol Med. 1987;2:15-21.
Benes J, Prerovsky K, Rehurek L, et al. [Garlic food allergy with symptoms of Meniere's disease]. [Czech]. Cas Lek Cesk. 1966;105:825-7. [pmid: 5958055].
Berthold HK, Sudhop T, von Bergmann K. Effect of a garlic oil preparation on serum lipoproteins and cholesterol metabolism: a randomized controlled trial. JAMA. 1998;279:1900-2. [pmid: 9634262].
Bimmermann A, Weingart K, Schwartzkopff W. Allium sativum: studie zur Wirksamkeit bie Hyperlipoproteinamie. Therapiewoche. 1988;38:3885-90.
Bimmermann A, Schleicher J, Von Baeyer H, et al. On the efficiency of garlic medicaments on the lipids of the blood. Results of 7 clinical studies on allium sativum. Med Welt. 1991;42:14-5.
Blania G, Spangenberg B. [Formation of allicin from dried garlic (Allium sativum): a simple HPTLC method for simultaneous determination of allicin and ajoene in dried garlic and garlic preparations]. [German]. Planta Med. 1991;57:371-5. [pmid: 1775580].
Bleumink E, Doeglas HM, Klokke AH, et al. Allergic contact dermatitis to garlic. Br J Dermatol. 1972;87:6-9. [pmid: 5043200].
Bleumink E, Nater JP. Contact dermatitis to garlic: crossreactivity between garlic, onion and tulip. Arch Dermatol Forsch. 1973;247:117-24. [pmid: 4748763].
Block E. Biologically active organic sulfur compounds in garlic. Dtsch Apoth Ztg. 1989;129:3-4.
Block E. The chemistry of garlic and onions. Sci Am. 1985;252:94-114, 119.
Block E. Garlic as a functional food: a status report. In: Shibamoto T, Teroa J, Osawa T, editors. Functional foods for disease prevention. vol. 2. Washington: American Chemical Society; 1998. p.125-43.
Block E. The organosulfur chemistry of the genus Allium: implications for the organic chemistry of sulfur. Angew Chem Int Ed Engl. 1992;31:1135-78.
Block E, Purcell PF, Yolen SR, et al. Onions and heartburn. Am J Gastroenterol. 1992;87:679-80.
Boccafogli A, Vicentini L, Camerani A, et al. Adverse food reactions in patients with grass pollen allergic respiratory disease. Ann Allergy. 1994;73:301-8. [pmid: 7943997].
Body SC. A taste of allicin?. Anaesth Intensive Care. 1986;14.
Bojs G, Svensson A. Contact allergy to garlic used for wound healing. Contact Dermatitis. 1988;18:179-81. [pmid: 3365975].
Bolton S, Null G, Troetel WM. The medical uses of garlic-fact and fiction. Am Pharm. 1982;22:40-3.
Borchers AT, Hackman RM, Keen CL, et al. Complementary medicine: a review of immunomodulatory effects of Chinese herbal medicines. Am J Clin Nutr. 1997;66:1303-12. [pmid: 9394679].
Bordia A, Arora SK, Kothari LK, et al. The protective action of essential oils of onion and garlic in cholesterol-fed rabbits. Atherosclerosis. 1975;22:103-9. [pmid: 1156467].
Bordia A. Effect of garlic on blood lipids in patients with heart disease. Am J Clin Nutr. 1981;34:2100-3. [pmid: 7293938].
Bordia A, Joshi HK, Sanadhya YK, Bhu N. Effect of essential oil of garlic on serum fibrinolytic activity in patients with coronary artery disease. Atherosclerosis. 1977;28:155-9. [pmid: 911374].
Bordia A, Verma SK. Effect of garlic feeding on regression of experimental atherosclerosis in rabbits. Artery. 1980;7:428-37. [pmid: 7213027].
Bordia A, Verma SK, Srivastava KC. Effect of garlic (Allium sativum) on blood lipids, blood sugar, fibrinogen and fibrinolytic activity in patients with coronary artery disease. Prostaglandins Leukot Essent Fatty Acids. 1998;58:257-63. [pmid: 9654398].
Bordia A, Verma SK, Srivastava KC. Effect of garlic on platelet aggregation in humans: a study in healthy subjects and patients with coronary artery disease. Prostaglandins Leukot Essent Fatty Acids. 1996;55:201-5. [pmid: 8931120].
Bordia A, Verma SK, Vyas AK, et al. Effect of essential oil of onion and garlic on experimental atherosclerosis in rabbits. Atherosclerosis. 1977;26:379-86. [pmid: 192252].
Bordia A, Verma SK, Khabia BL, et al. The effective of active principle of garlic and onion on blood lipids and experimental atherosclerosis in rabbits and their comparison with clofibrate. J Assoc Physicians India. 1977;25:509-16. [pmid: 614376].
Bordia AK, Sanadhya SK, Rathore AS, et al. Essential oil of garlic on blood lipids and fibrinolytic activity in patients of coronary artery disease. Part I. J Assoc Physicians India. 1978;26:327-31. [pmid: 730712].
Borins M. The dangers of using herbs: what your patients need to know. Postgrad Med. 1998;104:91-5, 99-100. [pmid: 9676564].
Borstelmann S. Mit Allium sativum das kardiale risiko verringern. Gesundes Leben. 1998;75:63-5.
Boullin DJ. Garlic as a platelet inhibitor. Lancet. 1981;1:776-7. [pmid: 6110972].
Boyle FM. Adverse interaction of herbal medicine with breast cancer treatment. Med J Aust. 1997;167.
Brenner S, Ruocco V, Wolf R, et al. Pemphigus and dietary factors. In vitro acantholysis by allyl compounds of the genus Allium. Dermatology. 1995;190:197-202. [pmid: 7599380].
Brooks DN. An onion in your ear. J Laryngol Otol. 1986;100:1043-6. [pmid: 3531372].
Brosche T, Platt D. Garlic. Br Med J. 1991;303.
Brosche T, Platt D, Dorner H. The effect of a garlic preparation on the composition of plasma lipoproteins and erythrocyte membranes in geriatric subjects. Br J Clin Pract Symp Suppl. 1990;69:12-9. [pmid: 2083168].
Bruynzeel DP, Prevoo RLMA. Patch tests with some spices. Dermatol Clin. 1990;8:85-7. [pmid: 2302865].
Bruynzeel DP. Bulb dermatitis. Dermatological problems in the flower bulb industries. Contact Dermatitis. 1997;37:70-7. [pmid: 9285168].
Bubenzer R. Knoblauchtherapie: Positive wirkungen auf lipidstatus und hämodilution nachgewiesen. Therapiewoche. 1990;40:1755-6.
Buchan RF. Garlic breath odor. JAMA. 1974;227:559-60. [pmid: 4405809].
Buck AC. Phytotherapy for the prostate. Br J Urol. 1996;78:325-36. [pmid: 8881937].
Buck C, Donner AP, Simpson H. Garlic oil and ischaemic heart disease. Int J Epidemiol. 1982;11:294-5. [pmid: 7129745].
Bhushan S, Sharma SP, Singh SP, et al. Effect of garlic on normal blood cholesterol level. Indian J Physiol Pharmacol. 1979;23:211-4. [pmid: 521124].
Buiatti E, Palli D, Decarli A, et al. A case-control study of gastric cancer and diet in Italy: I. Int J Cancer. 1989;44:611-6. [pmid: 2793233].
Buiatti E, Palli D, Decarli A, et al. A case-control study of gastric cancer and diet in Italy: II. Association with nutrients. Int J Cancer. 1990;45:896-901. [pmid: 2335393].
Burden AD, Wilkinson SM, Beck MH, et al. Garlic-induced systemic contact dermatitis. Contact Dermatitis. 1994;30:299-300. [pmid: 8088146].
Burnham BE. Garlic as a possible risk for postoperative bleeding. Plast Reconstr Surg. 1995;95.
Campolmi P, Lombardi P, Lotti T, et al. Immediate and delayed sensitization to garlic. Contact Dermatitis. 1982;8:352-3.
Canduela V, Mongil I, Carrascosa M, et al. Garlic: always good for the health?. Br J Dermatol. 1995;132:161-2. [pmid: 7756138].
Caporaso N, Smith SM, Eng RH. Antifungal activity in human urine and serum after ingestion of garlic (Allium sativum). Antimicrob Agents Chemother. 1983;23:700-2. [pmcid: 184790]. [pmid: 6870217].
Challier B, Perarnau JM, Viel JF. Garlic, onion and cereal fibre as protective factors for breast cancer: a French case-control study. Eur J Epidemiol. 1998;14:737-47. [pmid: 9928867].
Chan EF, Mowad C. Contact dermatitis to foods and spices. Am J Contact Dermat. 1998;9:71-9. [pmid: 9601906].
Cheng JY, Meng CL, Tzeng CC, et al. Optimal dose of garlic to inhibit dimethylhydrazine-induced colon cancer. World J Surg. 1995;19:621-6. [pmid: 7676710].
Chi MS. Effects of garlic products on lipid metabolism in cholesterol-fed rats (41494). Proc Soc Exp Biol Med. 1982;171:174-8. [pmid: 7178122].
Christopher Ranch. Garlic: good taste and good health! [Web site]. http://www.christopher-ranch.com/website5.htm [accessed May 4, 1999].
Chutani SK, Bordia A. The effect of fried versus raw garlic on fibrinolytic activity in man. Atherosclerosis. 1981;38:417-21. [pmid: 7225179].
Cook-Mozaffari PJ, Azordegan F, Day NE, et al. Oesophageal cancer studies in the Caspian Littoral of Iran: results of a case-control study. Br J Cancer. 1979;39:293-309. [pmid: 465299].
Cooperative Group for Essential Oil of Garlic. The effect of essential oil of garlic on hyperlipemia and platelet aggregation-an analysis of 308 cases. J Tradit Chin Med. 1986;6:117-20. [pmid: 3773559].
Couturier P, Bousquet J. Occupational allergy secondary inhalation of garlic dust. J Allergy Clin Immunol. 1982;70.
Couturier P, Kreuter M, Loupi J. Allergie a la poussière d'ail. A propos de deux observations. Rev Fr Allergol. 1980;20:145-7.
Croissant PD. Spinal epidural hematoma and garlic ingestion (I: Reply). Neurosurgery. 1990;27.
Cronin E. Dermatitis of the hands in caterers. Contact Dermatitis. 1987;17:265-9. [pmid: 2963723].
Czerny B, Samochowiec J. Klinische Untersuchungen mit einem Knoblauch-Lezithin-Präparat. Arztez Naturheilverfahren. 1996;37:126-9.
Das T, Choudhury AR, Sharma A, et al. Effects of crude garlic extract on mouse chromosomes in vivo. Food Chem Toxicol. 1996;34:43-7. [pmid: 8603796].
Dausch JG, Nixon DW. Garlic: a review of its relationship to malignant disease. Prev Med. 1990;19:346-61. [pmid: 2198557].
Day A. Gothic gardening: ye olde gothick herball. http://www.gothic.net/~malice/garlic.html [accessed May 24, 1999].
de Blay F, Pauli G, Bessot JC. Cross-reactions between respiratory and food allergens. Allergy Proc. 1991;12:313-7. [pmid: 1720408].
de Santos AOS, Grunwald J. Effect of garlic powder tablets on blood lipids and blood pressure: a six month placebo controlled, double blind study. Br J Clin Res. 1993;4:37-44.
de Santos AOS, Jones RA. Effects of garlic powder and garlic oil preparations on blood lipids, blood pressure and well-being. Br J Clin Res. 1995;6:91-100.
De Smet PAG, Brouwers JRB. Pharmacokinetic evaluation of herbal remedies: basic introduction, applicability, current status and regulatory needs. Clin Pharmacokinet. 1997;32:427-36. [pmid: 9195114].
De Smet PA. An introduction to herbal pharmacoepidemiology. J Ethnopharmacol. 1993;38:197-208. [pmid: 8510469].
Delaney TA, Donnelly AM. Garlic dermatitis. Australas J Dermatol. 1996;37:109-10. [pmid: 8687326].
Delin Y. An experimental research on anticancerous effect of garlic (abstract). Eur J Pharmacol. 1990;183.
DiPaolo JA, Carruthers C. The effect of allicin from garlic on tumor growth. Cancer Res. 1960;20:431-4. [pmid: 13816895].
Dorant E, van den Brandt PA, Goldbohm RA. Allium vegetable consumption, garlic supplement intake, and female breast carcinoma incidence. Breast Cancer Res Treat. 1995;33:163-70. [pmid: 7749142].
Dorant E, van den Brandt PA, Goldbohm RA. A prospective cohort study on Allium vegetable consumption, garlic supplement use, and the risk of lung carcinoma in The Netherlands. Cancer Res. 1994;54:6148-53. [pmid: 7954460].
Dorant E, van den Brandt PA, Goldbohm RA. A prospective cohort study on the relationship between onion and leek consumption, garlic supplement use and the risk of colorectal carcinoma in The Netherlands. Carcinogenesis. 1996;17:477-84. [pmid: 8631133].
Dorant E, van den Brandt PA, Goldbohm RA, et al. Garlic and its significance for the prevention of cancer in humans: a critical review. Br J Cancer. 1993;67:424-9. [pmid: 8439494].
Dorant E, van den Brandt PA, Goldbohm RA, Sturmans F. Consumption of onions and a reduced risk of stomach carcinoma. Gastroenterology. 1996;110:12-20. [pmid: 8536847].
Dubick MA. Historical perspectives on the use of herbal preparations to promote health. J Nutr. 1986;116:1348-54. [pmid: 3528430].
Eastman P. "Phytamins" are not ready for public consumption. J Natl Cancer Inst. 1995;87:1430-2. [pmid: 7674327].
Edelstein AJ, Johnstown PA. Dermatitis caused by garlic. Arch Dermatol. 1950;61.
El Mofty MM, Sakr SA, Essawy A, et al. Preventive action of garlic on aflatoxin B1-induced carcinogenesis in the toad Bufo regularis. Nutr Cancer. 1994;21:95-100. [pmid: 8183725].
Eliason BC, Kruger J, Mark D, et al. Dietary supplement users: demographics, product use, and medical system interaction. J Am Board Fam Pract. 1997;10:265-71. [pmid: 9228621].
Eming SA, Piontek JO, Hunzelmann N, et al. Severe toxic contact dermatitis caused by garlic. Br J Dermatol. 1999;141:391-2. [pmid: 10468845].
Ernst E. Cardiovascular effects of garlic (allium sativum): a review. Pharmatherapeutica. 1987;5:83-9. [pmid: 3310019].
Ernst E, Weihmayr T, Matrai A. Garlic and blood lipids. Br Med J (Clin Res Ed). 1985;291.
Estrada CA, Young MJ. Patient preferences for novel therapy: an N-of-1 trial of garlic in the treatment for hypertension. J Gen Intern Med. 1993;8:619-21. [pmid: 8289103].
Falleroni AE, Zeiss CR, Levitz D. Occupational asthma secondary to inhalation of garlic dust. J Allergy Clin Immunol. 1981;68:156-60. [pmid: 7252000].
Farbman KS, Barnett ED, Bolduc GR, et al. Antibacterial activity of garlic and onions: a historical perspective. Pediatr Infect Dis J. 1993;12:613-4. [pmid: 8346006].
Farrell AM, Staughton RCD. Garlic burns mimicking herpes zoster. Lancet. 1996;347.
Fedder SL. Spinal epidural hematoma and garlic ingestion (I). Neurosurgery. 1990;27.
Fenwick GR, Hanley AB. The genus Allium-Part 1. Crit Rev Food Sci Nutr. 1985;22:199-271. [pmid: 3902370].
Fernandez de Corres L, Leanizbarrutia I, Munoz D, et al. [Allergic contact dermatitis caused by garlic, Primula, Frullania and Compositae]. [Spanish]. Allergol Immunopathol (Madr). 1985;13:291-9. [pmid: 4083225].
Fleischer S, Bayerl C, Jung EG. [Occupational allergic hand dermatitis to garlic in a pizza baker]. [German]. Aktuelle Dermatol. 1996;22:278-9.
Foldesiova V, Springer V. [Drugs containing garlic in therapeutic practice]. [Slovak]. Farmaceuticky Obzor. 1993;62:441-8.
Franceschi S, Negri E, Salvini S, et al. Reproducibility of an Italian food frequency questionnaire for cancer. Eur J Cancer. 1993;29:2298-305.
Gaddoni G, Selvi M, Resta F, et al. Allergic contact dermatitis to garlic in a cook. Ann Ital Dermatol Clin Sperimentale. 1994;48:120-1.
Gadkari JV, Joshi VD. Effect of ingestion of raw garlic on serum cholesterol level, clotting time and fibrinolytic activity in normal subjects. J Postgrad Med. 1991;37:128-31. [pmid: 1784022].
Gail MH, You WC, Chang YS, et al. Factorial trial of three interventions to reduce the progression of precancerous gastric lesions in Shandong, China: design issues and initial data. Control Clin Trials. 1998;19:352-69. [pmid: 9683311].
Gall H, Kalveram CM, Schunter M. Sofortallergie auf Lauch. Allergo Journal. 1996;51.
Gao CM, Takezaki T, Ding JH, et al. Protective effect of allium vegetables against both esophageal and stomach cancer: a simultaneous case-referent study of a high-epidemic area in Jiangsu Province, China. Jpn J Cancer Res. 1999;90:614-21. [pmid: 10429652].
Gardner CD, Chatterjee L, Carlson J. Effect of garlic supplementation on plasma lipids in hypercholesterolemic men and women [abstract]. Circulation. 1999;99.
[Garlic as a potential antiatherogenic substance]. [German]. Munch Med Wochenschr. 1993;135.
Garty BZ. Garlic burns. Pediatrics. 1993;91:658-9. [pmid: 8441577].
Gebhardt R. Garlic: the key to sophisticated lowering of hepatocellular lipid. Nutrition. 1997;13:379-80. [pmid: 9178295].
German K, Kumar U, Blackford HN. Garlic and the risk of TURP bleeding. Br J Urol. 1995;76.
Ghadirian P. Food habits of the people of the Caspian Littoral of Iran in relation to esophageal cancer. Nutr Cancer. 1987;9:147-57. [pmid: 3562293].
Graham S, Marshall J, Haughey B, et al. Dietary epidemiology of cancer of the colon in western New York. Am J Epidemiol. 1988;128:490-503. [pmid: 2843038].
Grieve M. A modern herbal: garlic [Web site]. http://www.botanical.com/botanical/mgmh/g/garlic06.html [accessed May 4, 1999].
Grunwald J. Garlic and cardiovascular risk factors. Br J Clin Pharmacol. 1990;29:582-3. [pmid: 2350537].
Grunwald J. Garlic (II). Lancet. 1990;335.
Grunwald J, Buttel K. [The European market for phytotherapeutics. Figures, trends and analyses]. [German]. Pharm Industrie. 1996;58:209-14.
Grunwald J, Goldberg A. [The market of herbal remedies in the USA. Market development, users, legislation and organization]. [German]. Pharm Industrie. 1997;59:485-90.
Gupta MK, Mittal SR, Mathur AK, et al. Garlic: the other side of the coin. Int J Cardiol. 1993;38.
Haenszel W, Berg JW, Segi M, et al. Large-bowel cancer in Hawaiian Japanese. J Natl Cancer Inst. 1973;51:1765-79. [pmid: 4797262].
Haenszel W, Kurihara M, Segi M. Cancer among Japanese in Hawaii. J Natl Cancer Inst. 1972;49:969-88. [pmid: 4678140].
Haenszel W, Locke FB, Segi M. A case-control study of large bowel cancer in Japan. J Natl Cancer Inst. 1980;64:17-22. [pmid: 6928043].
Hageman G, Krul C, van Herwijnen M, et al. Assessment of the anticarcinogenic potential of raw garlic in humans. Cancer Lett. 1997;114:161-2. [pmid: 9103278].
Hallel-Halevy D, Zlotogorski A, Grunwald MH, et al. Multifaceted dermatitis artefacta caused by garlic. J Eur Acad Dermatol Venereol. 1997;9:185-7.
Han J. Highlights of the cancer chemoprevention studies in China. Prev Med. 1993;22:712-22. [pmid: 8234211].
Han J, Lawson L, Han G, et al. A spectrophotometric method for quantitative determination of allicin and total garlic thiosulfinates. Anal Biochem. 1995;225:157-60. [pmid: 7778769].
Harada K, Namiki M. [Acute gastric mucosal lesions induced by drugs and irritating foods]. [Japanese]. Saishin Igaku. 1989;44:2056-60.
Harenberg J, Giese C, Zimmermann R. Effect of dried garlic on blood coagulation, fibrinolysis, platelet aggregation and serum cholesterol levels in patients with hyperlipoproteinemia. Atherosclerosis. 1988;74:247-9. [pmid: 3240334].
Harris CM, Mitchell SC, Waring RH, et al. The case of the black-speckled dolls: an occupational hazard of unusual sulphur metabolism. Lancet. 1986;1:492-3. [pmid: 2869220].
Hasler A. [Quality criteria of garlic]. [German]. Schweiz Apoth Ztg. 1992;130:501-2.
Healthy Way. Incredible edibles: garlic galore. http://www.bc.sympatico.ca/contents/health/healthyway/rec_gar.html [accessed May 4, 1999].
Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando (FL): Academic Press; 1985.
Hemminki E, Mantyranta T, Malin M, et al. A survey on the use of alternative drugs during pregnancy. Scand J Soc Med. 1991;19:199-204. [pmid: 1796254].
Henson GE. Garlic: an occupational factor in the etiology of bronchial asthma. J Fla Med Assoc. 1940;27.
Hjorth N, Roed Petersen J. Occupational protein contact dermatitis in food handlers. Contact Dermatitis. 1976;2:28-42. [pmid: 145923].
Holzgartner H, Schmidt U, Kuhn U. Comparison of the efficacy and tolerance of a garlic preparation vs. bezafibrate. Arzneimittelforschung. 1992;2:1473-7.
Horhammer L, Wagner H, Seitz M, et al. [On determination of the value of garlic preparations. 1. Chromatographic studies on the genuine contents of Allium sativum L]. [German]. Pharmazie. 1968;23:462-7. [pmid: 5715558].
Huang C, Zhang X, Qiao Z, et al. A case-control study of dietary factors in patients with lung cancer. Biomed Environ Sci. 1992;5:257-65. [pmid: 1333225].
Hung OL, Shih RD, Chiang WK, et al. Herbal preparation use among urban emergency department patients. Acad Emerg Med. 1997;4:209-13. [pmid: 9063549].
Ip C, Lisk DJ. The attributes of selenium-enriched garlic in cancer prevention. Adv Exp Med Biol. 1996;401:179-87. [pmid: 8886136].
Isaacsohn JL, Moser M, Stein EA, et al. Garlic powder and plasma lipids and lipoproteins: a multicenter, randomized, placebo-controlled trial. Arch Intern Med. 1998;158:1189-94. [pmid: 9625398].
Jacob BG, Schwandt P. [Cholesterol lowering effect of garlic?]. [German]. Dtsch Med Wochenschr. 1992;117:397-8.
Jain AK, Vargas R, Gotzkowsky S, et al. Can garlic reduce levels of serum lipids? A controlled clinical study. Am J Med. 1993;94:632-5. [pmid: 8506890].
Jain RC. Effect of garlic on serum lipids, coagulability and fibrinolytic activity of blood. Am J Clin Nutr. 1977;30:1380-1. [pmid: 900054].
Jeannel D, Hubert A, De Vathaire F, et al. Diet, living conditions and nasopharyngeal carcinoma in Tunisia: A case-control study. Int J Cancer. 1990;46:421-5. [pmid: 2394508].
Jesse J, Mohseni M, Sha N. http://wilkes1.wilkes.edu/~kklemow/Allium.html [accessed May 6, 1999].
Jung EM, Jung F, Mrowietz C, et al. Influence of garlic powder on cutaneous microcirculation. A randomized placebo-controlled double-blind cross-over study in apparently healthy subjects. Arzneimittelforschung. 1991;41:626-30. [pmid: 1930351].
Jung F, Jung EM, Mrowietz C, et al. [The effects of garlic powder on cutaneous microcirculation. A cross-over test with healthy test persons]. [German]. Med Welt. 1991;42:28-30.
Jung F, Kiesewetter H. [The effects of fat-strain on plasma lipids and capillary blood circulation under a garlic treatment. Dosage-related lowering of the haematocrit readings]. [German]. Med Welt. 1991;42:16-9.
Kamanna VS, Chandrasekhara N. Effect of garlic (Allium sativum linn) on serum lipoproteins and lipoprotein cholesterol levels in albino rats rendered hypercholesteremic by feeding cholesterol. Lipids. 1982;17:483-8. [pmid: 7121209].
Kandziora J. Antihypertensive Wirksamkeit und Verträglichkeit eines Knoblauch-Präparates. Arztl Forsch. 1988;1:1-8.
Kandziora J. Blutdruck-und lipidsenkende Wirkung eines Knoblauch-Praparates in Kombination mit einem Diuretikum. Arztl Forsch. 1988;3:3-8.
Kanerva L, Estlander T, Jolanki R. Occupational allergic contact dermatitis from spices. Contact Dermatitis. 1996;35:157-62. [pmid: 8930476].
Kannar D. Clinical evaluation of Australian based garlic and its combination with inulin in mild and moderate hyperlipidaemia [dissertation]. Clayton, Australia: Monash University; 1998. p. i-vi, 6, 67-114.
Kaplan B, Schewach Millet M, Yorav S. Factitial dermatitis induced by application of garlic. Int J Dermatol. 1990;29:75-6. [pmid: 2329032].
Kendler BS. Garlic (Allium sativum) and onion (Allium cepa): a review of their relationship to cardiovascular disease. Prev Med. 1987;16:670-85. [pmid: 3317392].
Kenzelmann R, Kade F. Limitation of the deterioration of lipid parameters by a standardized garlic-ginkgo combination product. A multicenter placebo-controlled double-blind study. Arzneimittelforschung. 1993;43:978-81. [pmid: 8240462].
Key TJA, Silcocks PB, Davey GK, et al. A case-control study of diet and prostate cancer. Br J Cancer. 1997;76:678-87. [pmid: 9303371].
Kiesewetter H, Jung F, Jung EM, et al. Effects of garlic coated tablets in peripheral arterial occlusive disease. Clin Investig. 1993;71:383-6.
Kiesewetter H, Jung F, Mrowietz C, et al. Effects of garlic on blood fluidity and fibrinolytic activity: a randomised, placebo-controlled, double-blind study. Br J Clin Pract Suppl. 1990;69:24-9. [pmid: 2128029].
Kiesewetter H, Jung F, Pindur G, et al. Effect of garlic on thrombocyte aggregation, microcirculation, and other risk factors. Int J Clin Pharmacol. 1991;29:151-5.
Kirsten D, Meister W. [Occupational allergy due to garlic]. [German]. Allergologie. 1985;8:511-2.
Kleijnen J, Knipschild P, Ter Riet G. Garlic, onions and cardiovascular risk factors. A review of the evidence from human experiments with emphasis on commercially available preparations. Br J Clin Pharmacol. 1989;28:535-44. [pmid: 2686739].
Kleiner SM. Defense plants: foods that fight disease. Physician Sportsmedicine. 1997;25:89-90.
Klipstein Grobusch K, Kroke A, Voss S, et al. [Influence of lifestyle on the use of supplements in the Brandenburg nutrition and cancer study]. [German]. Z Ernahrungswiss. 1998;37:38-46. [pmid: 9556866].
Knoblauch: Symposium über die Chemie, Pharmakologie und medizinische Anwendung, Lüneburg, 23 bis 25 Februar 1989. Dtsch Apoth Ztg 1989;129:1-25.
Knobloch K, Lawson LD. Terminology concerning garlic research. Planta Med. 1990;56.
Koch HP. [How safe is garlic? Toxic, allergic and other undesired side-effects]. [German]. Dtsch Apoth Ztg. 1992;132:1419-28.
Koch HP, Lawson L, editors. Garlic: the science and therapeutic application of Allium sativum L and related species. 2nd ed. Baltimore (MD): Williams & Wilkins; 1996.
Koch K. Studie mit fadem Nageschmack: ein Verlag verkauft das Recht, die Artikel für seine Fachzeitschrift auszuwählen-und bekommt prompt Ärger mit einer zweifelhaften Veröffentichung [newspaper]. Suddeutsche Zeitung 1999.
Koscielny J, Klussendorf D, Latza R, et al. The antiatherosclerotic effect of Allium sativum. Atherosclerosis. 1999;144:237-49. [pmid: 10381297].
Krishnaswamy K, Raghuramulu N. Bioactive phytochemicals with emphasis on dietary practices. Indian J Med Res. 1998;108:167-81. [pmid: 9863273].
Kummel B. [Lipid reducing effects of garlic oil maceration-capsules]. [German]. Med Welt. 1991;42.
Kurzen M, Bayerl C. [Immediate-type hypersensitivity to garlic]. [German]. Aktuelle Dermatol. 1997;23:145-7.
Kyriakos T. Herbal medicine. Can Pharm J. 1996;129:46-7, 49.
Langer JW. [Drug information: garlic is healthy-but the jungle of preparations is dense]. [Danish]. Sygeplejersken. 1992;92.
Lash JP, Cardoso LR, Mesler PM, et al. The effect of garlic on hypercholesterolemia in renal transplant patients. Transplant Proc. 1998;30:189-91. [pmid: 9474997].
Lau BH, Adetumbi MA, Sanchez A. Allium sativum (garlic) and atherosclerosis: a review. Nutr Res. 1983;3:119-28.
Lau BHS, Lam F, Wang Cheng R. Effect of an odor-modified garlic preparation on blood lipids. Nutr Res. 1987;7:139-49.
Lau BHS, Tadi PP, Tosk JM. Allium sativum (garlic) and cancer prevention. Nutr Res. 1990;10:937-48.
Lautier R, Wendt V. [Contact allergy to Alliaceae. Case report and literature review]. [German]. Derm Beruf Umwelt. 1985;33:213-5. [pmid: 2936593].
Lawson LD. Garlic powder for hyperlipidemia: analysis of recent negative results. Q Rev Natural Med 1998; 187-9.
Lawson LD, Ransom DK, Hughes BG. Inhibition of whole blood platelet-aggregation by compounds in garlic clove extracts and commercial garlic products. Thromb Res. 1992;65:141-56. [pmid: 1579891].
Lawson LD, Wang ZY, Hughes BG. Identification and HPLC quantitation of the sulfides and dialk(en)yl thiosulfinates in commercial garlic products. Planta Med. 1991;57:363-70. [pmid: 1775579].
Lawson LD, Wood SG, Hughes BG. HPLC analysis of allicin and other thiosulfinates in garlic clove homogenates. Planta Med. 1991;57:263-70. [pmid: 17226157].
Lea MA. Organosulfur compounds and cancer. Adv Exp Med Biol. 1996;401:147-54. [pmid: 8886133].
Lee TY, Lam TH. Contact dermatitis due to topical treatment with garlic in Hong Kong. Contact Dermatitis. 1991;24:193-6. [pmid: 1831097].
Legnani C, Frascaro M, Guazzaloca G, et al. Effects of a dried garlic preparation on fibrinolysis and platelet aggregation in healthy subjects. Arzneimittelforschung. 1993;43:119-22. [pmid: 8457236].
Lehmann B, Brewitt B. [Lipid regulation with standardized natural medicaments]. [German]. Med Welt. 1991;42.
Lembo G, Balato N, Patruno C, et al. Allergic contact dermatitis due to garlic (Allium sativum). Contact Dermatitis. 1991;25:330-1. [pmid: 1839726].
Lemiere C, Cartier A, Lehrer SB, et al. Occupational asthma caused by aromatic herbs. Allergy. 1996;51:647-9. [pmid: 8899117].
Levi F, Franceschi S, Negri E, et al. Dietary factors and the risk of endometrial cancer. Cancer. 1993;71:3575-81. [pmid: 8490907].
Levi F, La Vecchia C, Gulie C, et al. Dietary factors and breast cancer risk in Vaud, Switzerland. Nutr Cancer. 1993;19:327-35. [pmid: 8346081].
Levi F, Pasche C, La Vecchia C, et al. Food groups and colorectal cancer risk. Br J Cancer. 1999;79:1283-7. [pmid: 10098773].
LoBuono P, Jothikumar T, Kornblee L. Acquired digital fibrokeratoma. Cutis. 1979;24:50-1. [pmid: 477378].
Lu DP. Bone marrow transplantation in the People's Republic of China. Chinese Bone Marrow Transplant Registry. Bone Marrow Transplant. 1994;13:703-4. [pmid: 7920297].
Luley C, Lehmann-Leo W, Moller B, et al. Lack of efficacy of dried garlic in patients with hyperlipoproteinemia. Arzneimittelforschung. 1986;36:766-8. [pmid: 3521619].
Lutomski J. Klinische Untersuchungen zur therapeutischen Wirksamkeit von Ilha Rogoff Knoblauchpillen mit Rutin. Z Phytother. 1984;5:938-42.
Lutomski J. [The significance of garlic and garlic preparations in phytotherapy]. [German]. Pharm Unserer Zeit. 1980;9:45-50. [pmid: 7367451].
Lybarger JA, Gallagher JS, Pulver DW, et al. Occupational asthma induced by inhalation and ingestion of garlic. J Allergy Clin Immunol. 1982;69:448-54. [pmid: 7076985].
Mader FH. Treatment of hyperlipidaemia with garlic-powder tablets. Evidence from the German Association of General Practitioners' multicentric placebo-controlled double-blind study. Arzneimittelforschung. 1990;40:1111-6. [pmid: 2291748].
Manousos O, Day NE, Trichopoulos D, et al. Diet and colorectal cancer: a case-control study in Greece. Int J Cancer. 1983;32:1-5. [pmid: 6862688].
Mansell P, Reckless JPD. Garlic: effects on serum lipids, blood pressure, coagulation, platelet aggregation, and vasodilatation. BMJ. 1991;303:379-80. [pmid: 1912802]. [pmcid: 1670690].
Mansell P, Reckless JPD, Lloyd L. The effect of dried garlic powder tablets on serum lipids in non-insulin dependent diabetic patients. Eur J Clin Res. 1996;8:25-6.
Martinescu E. [Contact dermatitis caused by Allium sativum]. [Romanian]. Rev Med Chir Soc Med Nat Iasi. 1981;85:541-2. [pmid: 6461044].
Marwick C. And some recommend it as a vampire prophylactic. JAMA. 1990;264:2614-5. [pmid: 2232030].
Mazza G, Ciaravolo S, Chiricosta G, et al. Volatile flavour components from ripening and mature garlic bulbs. Flavour Fragrance J. 1992;7:111-6.
McCrindle BW, Helden E, Conner WT. Garlic extract therapy in children with hypercholesterolemia. Arch Pediatr Adolesc Med. 1998;152:1089-94. [pmid: 9811286].
McFadden JP, White IR, Rycroft RJG. Allergic contact dermatitis from garlic. Contact Dermatitis. 1992;27:333-4. [pmid: 1493696].
Meding B. Skin symptoms among workers in a spice factory. Contact Dermatitis. 1993;29:202-5. [pmid: 8281784].
Mei X, Wang ML, Xu HX, et al. Garlic and gastric cancer: the effect of garlic on nitrite and nitrate in gastric juice. Acta Nutrimenta Sinica. 1982;4:53-6.
Melvin KR. Effects of garlic powder tablets on patients with hyperlipidaemia in Canadian clinical practice. Eur J Clin Res. 1996;8:30-2.
Mennella JA, Beauchamp GK. Maternal diet alters the sensory qualities of human milk and the nursling's behavior. Pediatrics. 1991;88:737-44. [pmid: 1896276].
Mikhin VP. [The use of alisat for correction of level of lipids and their peroxidation products in blood of patients with atherosclerosis]. [Russian]. Biull Eksp Biol Med. 1998;126:345-9. [pmid: 9805629].
Mikhin VP, Gromnatskii NI. [The effect of garlic preparation alisat on the level of lipid peroxidation products, activity of various antioxidant enzymes, and blood level of lipoproteins in patients with atherosclerosis]. [Russian]. Biull Eksp Biol Med. 1996;122:502-4. [pmid: 8998336].
Miller LG. Herbal medicinals: selected clinical considerations focusing on known or potential drug-herb interactions. Arch Intern Med. 1998;158:2200-11. [pmid: 9818800].
Minocha YC, Dogra A, Sood VK. Contact sensitivity in palmar hyperkeratotic dermatitis. Indian J Dermatol Venereol Leprol. 1993;59:60-3.
Miron T, Rabinkov A, Mirelman D, et al. The mode of action of allicin: its ready permeability through phospholipid membranes may contribute to its biological activity. Biochim Biophys Acta. 2000;1463:20-30. [pmid: 10631291].
Mitchell JC. Contact sensitivity to garlic (Allium). Contact Dermatitis. 1980;6:356-7. [pmid: 7418398].
Mitka M. FDA never promised an herb garden-but sellers and buyers eager to see one grow. JAMA. 1998;280:1554-6. [pmid: 9820245].
Mochizuki E, Nakayama A, Kitada Y, et al. Liquid chromatographic determination of alliin in garlic and garlic products. J Chromatogr. 1988;455:271-7. [pmid: 3235614].
Mochizuki E, Yamamoto T, Suzuki S, et al. Electrophoretic identification of garlic and garlic products. J AOAC Int. 1996;79:1466-70. [pmid: 8946725].
Molina C, Lachaussee R, Jeanneret A, et al. [A garlic story]. [French]. Presse Med. 1983;12.
Moneret Vautrin DA, Kanny G. [Food-induced anaphylaxis. A new French multicenter study]. [French]. Bull Acad Natl Med. 1995;179:161-72, 178-84. [pmid: 7788443].
Morcos NC. Modulation of lipid profile by fish oil and garlic combination. J Natl Med Assoc. 1997;89:673-8. [pmid: 9347681].
Morris J, Burke V, Mori TA, et al. Effects of garlic extract on platelet aggregation: a randomized placebo-controlled double-blind study. Clin Exp Pharmacol Physiol. 1995;22:414-7. [pmid: 8582091].
Mouren X, Caillard P, Schwartz F. Study of the antiischemic action of EGb 761 in the treatment of peripheral arterial occlusive disease by T_C_PO2 determination. Angiology. 1994;45:413-7. [pmid: 8203766].
Muller B. Garlic (Allium sativum): quantitative analysis of the tracer substances alliin and allicin. Planta Med. 1990;56:589-90.
Muller-Christiansen K. [A new phytotherapeutic lipid lowering agent.]. [German]. Therapiewoche. 1990;40:1455-8.
Munday JS, James KA, Fray LM, et al. Daily supplementation with aged garlic extract, but not raw garlic, protects low density lipoprotein against in vitro oxidation. Atherosclerosis. 1999;143:399-404. [pmid: 10217370].
Mutsch Eckner M, Sticher O, Meier B. Reversed-phase high-performance liquid chromatography of S-alk(en)yl-L-cysteine derivatives in Allium sativum including the determination of (+)-S-allyl-L-cysteine sulphoxide, gamma-L-glutamyl-S-allyl-L-cysteine and gamma-L-glutamyl-S-(trans-1-propenyl)-L-cyst. J Chromatogr. 1992;625:183-90.
Myers SP, Smith AJ. Cardioprotection and garlic. Lancet. 1997;349:131-2.
Nagda KK, Ganeriwal SK, Nagda KC, et al. Effect of onion and garlic on blood coagulation and fibrinolysis in vitro. Indian J Physiol Pharmacol. 1983;27:141-5. [pmid: 6885127].
Neil HA, Silagy CA, Lancaster T, et al. Garlic powder in the treatment of moderate hyperlipidaemia: a controlled trial and meta-analysis. J R Coll Physicians Lond. 1996;30:329-34. [pmid: 8875379].
Nishino H, Iwashima A, Itakura Y, et al. Antitumor-promoting activity of garlic extracts. Oncology. 1989;46:277-80. [pmid: 2500627].
Nitiyanant W, Ploybutr S, Wasuwat S, et al. Effect of the dried powder extract, water soluble of garlic (Allium sativum) on cholesterol, triglyceride and high density lipoprotein in the blood. J Med Assoc Thai. 1987;70:646-8. [pmid: 3443797].
Oertmann C, Bergmann CK. [Occupational inhalated allergies to plants]. [German]. Allergologie. 1995;18:185-91.
Osler M, Schultz K. [Garlic - natural remedy for atherosclerosis - related symptoms]. [Danish]. Ugeskr Laeger. 1985;147:151-5. [pmid: 3992725].
Papageorgiou C, Corbet JP, Menezes Brandao F, et al. Allergic contact dermatitis to garlic (Allium sativum L.). Identification of the allergens: the role of mono-, di-and trisulfides present in garlic. A comparative study in man and animal (guinea-pig). Arch Dermatol Res. 1983;275:229-34. [pmid: 6625648].
Parish RA, McIntire S, Heimbach DM. Garlic burns: a naturopathic remedy gone awry. Pediatr Emerg Care. 1987;3:258-60. [pmid: 3324067].
Pentz R, Guo Z, Kress G, et al. Standardisation of garlic powder preparations by the estimation of free and hydrolysable SH groups. Planta Med. 1990;56.
Perez-Pimiento AJ, Moneo I, Santaolalla M, de Paz S, et al. Anaphylactic reaction to young garlic. Allergy. 1999;54:626-9. [pmid: 10435479].
Petkov V. Bulgarian traditional medicine: a source of ideas for phytopharmacological investigations. J Ethnopharmacol. 1986;15:121-32. [pmid: 3520155].
Petry JJ. Garlic and postoperative bleeding. Plast Reconstr Surg. 1995;96:483-4. [pmid: 7662027].
Phelps S, Thomas Pinto, Harris WS. Garlic supplementation and lipoprotein oxidation susceptibility. Lipids. 1993;28:475-7. [pmid: 8316057].
Pirogova EP, Katiukhina ZD. [Artificial dermatitis caused by garlic]. [Russian]. Vestn Dermatol Venerol. 1970;44:53-4.
Platt D, Brosche T. [A cholesterol-lowering effect of garlic? [German]. Dtsch Med Wochenschr. 1992;117:962-3. [pmid: 1600875].
Plengvidhya C, Chinayon S, Sitprija S, et al. Effects of spray dried garlic preparation on primary hyperlipoproteinemia. J Med Assoc Thai. 1988;71:748-52.
Rabinkov A, Miron T, Konstantinovski L, et al. The mode of action of allicin: trapping of radicals and interaction with thiol containing proteins. Biochim Biophys Acta. 1998;1379:233-44. [pmid: 9528659].
Rahman K, Billington D, Rigby G. Cardioprotection and garlic. Lancet. 1997;349.
Rance F, Dutau G. Labial food challenge in children with food allergy. Pediatr Allergy Immunol. 1997;8:41-4. [pmid: 9260218].
Rauterberg A. [Allergic contact dermatitis due to garlic in a cook]. [German]. Aktuelle Dermatol. 1995;21:317-8.
Read MH, Jeor SS, Seymour K, et al. Supplementation practices of a group of patients with cancer. J Am Diet Assoc. 1990;90:278-9. [pmid: 2303668].
Reuter HD. [3rd International ESCOP-Symposium]. [German]. Z Phytother. 1994;15:145-54.
Reuter HD. [Satellite symposium 'International Garlic Research']. [German]. Z Phytother. 1996;17:13-25.
Roberge RJ, Leckey R, Spence R, et al. Garlic burns of the breast. Am J Emerg Med. 1997;15.
Robertson D. Controlled trial of standardized garlic powder tablets for lowering serum lipids. Drug Ther. 1993;23.
Romano A, Di Fonso M, Giuffreda F, et al. Food-dependent exercise-induced anaphylaxis: diagnostic value of in vivo and in vitro allergologic tests. Int J Immunopathol Pharmacol. 1998;11:35-40.
Rose KD, Croissant PD, Parliment CF, et al. Spontaneous spinal epidural hematoma with associated platelet dysfunction from excessive garlic consumption: a case report. Neurosurgery. 1990;26:880-2. [pmid: 2352608].
Rosenthal R. Meta-analytic procedures for social research. Rev. ed. Newbury Park (CA): Sage Publications; 1991.
Roser D. Garlic. Lancet. 1990;335:114-5.
Rosin S, Tuorila H, Uutela A. Garlic: a sensory pleasure or a social nuisance?. Appetite. 1992;19:133-43. [pmid: 1489211].
Rotzsch W, Richter V, Rassoul F, et al. [Postprandial lipemia under treatment with Allium sativum. Controlled double-blind study of subjects with reduced HDL2-cholesterol]. [German]. Arzneimittelforschung. 1992;42:1223-7. [pmid: 1472142].
Ruocco V, Brenner S, Lombardi ML. A case of diet-related pemphigus. Dermatology. 1996;192:373-4. [pmid: 8864379].
Sainani GS, Desai DB, Gorhe NH, et al. Effect of garlic and onion on important lipid and coagulation parameters in alimentary hyperlipaemia. J Assoc Physicians India. 1979;27:57-64. [pmid: 511823].
Saradeth T, Seidl S, Resch K, et al. Does garlic alter the lipid pattern in normal volunteers?. Phytomedicine. 1994;1:183-5.
Schiermeier Q. German garlic study under scrutiny [newsletter]. Nature. 1999;401.
Schiewe FP, Hein T. [Garlic in hyperlipidemia. Influence of a garlic preparation on the lipid serum levels of patients with primary hyperlipidaemia]. [German]. Z Phytother. 1995;16:343-8.
Schollmann C. Knoblauch mindert die Risikofaktoren der Atherosklerose. Gesund Leben. 1994;71:16-20.
Schultz OE, Mohrmann HL. [Contribution on the analysis of the contents of garlic Allium sativum L. 2. Gas chromatography of garlic oil]. [German]. Pharmazie. 1965;20:441-7. [pmid: 5882481].
Schultz OE, Mohrmann HL. [A contribution to the analysis of the contents of garlic-Allium sativum L. I. Thin-layer chromatography of garlic oil]. [German]. Pharmazie. 1965;20:379-81. [pmid: 5864390].
Sendl A, Elbl G, Steinke B, et al. Comparative pharmacological investigations of Allium ursinum and Allium sativum. Planta Med. 1992;58:1-7. [pmid: 1620734].
Seuri M, Taivanen A, Ruoppi P, et al. Three cases of occupational asthma and rhinitis caused by garlic. Clin Exp Allergy. 1993;23:1011-4. [pmid: 10779294].
Shanmugasundaram ER, Sundaram P, Srinivas K, et al. Double-blind cross-over study of modified Anna Pavala Sindhooram in patients with hyperlipidemia or ischemic heart disease. J Ethnopharmacol. 1991;31:85-99. [pmid: 2030596].
Sharp S. Sbe23: meta-regression. Stata Tech Bull. 1998;42:16-22.
Shen FW. Traditional Chinese herbal and medicinal remedies. Practitioner. 1983;227:1599-600. [pmid: 6634629].
Shoetan A, Augusti KT, Joseph PK. Hypolipidemic effects of garlic oil in rats fed ethanol and a high lipid diet. Experientia. 1984;40:261-3. [pmid: 6698185].
Silagy C, Neil A. Garlic as a lipid lowering agent: a meta-analysis. J R Coll Physicians Lond. 1994;28:39-45. [pmid: 8169881].
Silagy CA, Neil HA. A meta-analysis of the effect of garlic on blood pressure. J Hypertens. 1994;12:463-8. [pmid: 8064171].
Simons LA, Balasubramaniam S, von Konigsmark M, et al. On the effect of garlic on plasma lipids and lipoproteins in mild hypercholesterolaemia. Atherosclerosis. 1995;113:219-25. [pmid: 7605361].
Simpson A, Boddington J. Garlic's protective effect. Br Med J. 1995;310.
Singer DRJ, Markandu ND, Bath PMW, et al. Effects of garlic on blood pressure, lipids and platelets in patients with essential hypertension and raised cholesterol [unpublished abstract].
Sinha SM, Pasricha JS, Sharma R, et al. Vegetables responsible for contact dermatitis of the hands. Arch Dermatol. 1977;113:776-9. [pmid: 869548].
Sitprija S, Plengvidhya C, Kangkaya V, et al. Garlic and diabetes mellitus phase II clinical trial. J Med Assoc Thai. 1987;70:223-7.
Snell SB. Garlic on the baby's breath. Lancet. 1973;2.
Square D. Sage advice from my garden. Can Med Assoc J. 1998;159:1495-7. [pmid: 9988572]. [pmcid: 1229900].
St Louis ME, Peck SHS, Bowering D, et al. Botulism from chopped garlic: delayed recognition of a major outbreak. Ann Intern Med. 1988;08:363-8.
Steiner M, Khan AH, Holbert D, et al. A double-blind crossover study in moderately hypercholesterolemic men that compared the effect of aged garlic extract and placebo administration on blood lipids. Am J Clin Nutr. 1996;64:866-70. [pmid: 8942410].
Steiner M, Lin RS. Changes in platelet function and susceptibility of lipoproteins to oxidation associated with administration of aged garlic extract. J Cardiovasc Pharmacol. 1998;31:904-8. [pmid: 9641475].
Steinmetz KA, Kushi LH, Bostick RM, et al. Vegetables, fruit and colon cancer in the Iowa Women's Health Study. Am J Epidemiol. 1994;139:1-15. [pmid: 8296768].
Steinmetz KA, Potter JD. Food-group consumption and colon cancer in the Adelaide Case-Control Study. I. Vegetables and fruit. Int J Cancer. 1993;53:711-9. [pmid: 8449594].
Sucur M. Effect of garlic on serum lipids and lipoproteins in patients suffering from hyperlipoproteinemia. Diabetoliogia Croatica. 1980;9:323-8.
Sugai T. [Skin safety evaluation of Eaudeleman medicated bathing agent (TM) and body shampoo (TM) in comparison with commercial product]. [Japanese]. Skin Res. 1992;34:496-502.
Sunter W. Warfarin and garlic. Pharm J. 1991;246.
Superko HR, Krauss RM. Garlic powder, effect on plasma lipids, postprandial lipemia, low-density lipoprotein particle size, high-density lipoprotein subclass distribution and lipoprotein(a). J Am Coll Cardiol. 2000;35:321-6. [pmid: 10676676].
Svensson A, Bojs G, Hradil E, et al. [Garlic and olive oil: good in food but unsuitable for skin care]. [Swedish]. Lakartidningen. 1991;88:733-4. [pmid: 2002740].
Swanson CA, Mao BL, Li JY, et al. Dietary determinants of lung-cancer risk: results from a case-control study in Yunnan Province, China. Int J Cancer. 1992;50:876-80. [pmid: 1555887].
Symposium aber Fettstoffwechselstîrungen und Arterisklerose in Dresden. Einfluss von Knoblauch auf Fettstoffwechsel/Arteriosklerose/Bericht von einem Symposium in Dresden. Natura Med. 1991;6:176-8.
Szliska C, Rakoski J, Seifert HU. Beruflich erworbene Sofortallergien gegen Blumen, Kräuter und Samen [abstract]. Allergologie. 1990;13:315-6.
Szybejko J, Zukowski A, Herbec R. [Unusual cause of obturation of the small intestine]. [Polish]. Wiad Lek. 1982;35:163-4. [pmid: 7101938].
Thomas Pinto J, Qiao C, Xing J, et al. Effects of garlic thioallyl derivatives on growth, glutathione concentration, and polyamine formation of human prostate carcinoma cells in culture. Am J Clin Nutr. 1997;66:398-405. [pmid: 9250120].
Tuyns AJ, Kaaks R, Haelterman M. Colorectal cancer and the consumption of foods: a case-control study in Belgium. Nutr Cancer. 1988;11:189-204. [pmid: 3405870].
Ulutan F, Sultan N, Davutoglu E, et al. [Outbreak of food poisoning caused by Salmonella typhimurium]. [Turkish]. Mikrobiyol Bul. 1988;22:95-100. [pmid: 3078795].
University of Texas Center for Alternative Medicine Research in Cancer. Garlic [Web site]. http://www.sph.uth.tmc.edu/utcam/agents/garlic.htm. [accessed April 16, 1999].
van den Akker TW, Roesyanto-Mahadi ID, van Toorenenbergen AW, et al. Contact allergy to spices. Contact Dermatitis. 1990;22:267-72. [pmid: 2383985].
van den Brandt PA, Goldbohm RA, van't Veer P, et al. A large-scale prospective cohort study on diet and cancer in The Netherlands. J Clin Epidemiol. 1990;43:285-95. [pmid: 2313318].
van Ketel WG, de Haan P. Occupational eczema from garlic and onion. Contact Dermatitis. 1978;4:53-4.
Ventura P, Girola M, Lattuada V. [Clinical evaluation and tolerability of a drug with garlic and hawthorn]. [Italian]. Acta Toxicol Ther. 1990;11:365-72.
Vorberg G, Schneider B. Therapy with garlic: results of a placebo-controlled, double-blind study. Br J Clin Pract Symp Suppl. 1990;69:7-11. [pmid: 2083173].
Walper A, Rassoul F, Purschwitz K, et al. Efficacy of dietary recommendations and phytotherapy with Allium sativum in mild and moderate hypercholesterinemia. Med Welt. 1994;45:327-32.
Wargovich MJ. Diallyl sulfide, a flavor component of garlic (Allium sativum), inhibits dimethylhydrazine-induced colon cancer. Carcinogenesis. 1987;8:487-9. [pmid: 3815744].
Wargovich MJ, Imada O, Stephens LC. Initiation and post-initiation chemopreventive effects of diallyl sulfide in esophageal carcinogenesis. Cancer Lett. 1992;64:39-42. [pmid: 1596875].
Warshafsky S, Kamer RS, Sivak SL. Effect of garlic on total serum cholesterol. A meta-analysis. Ann Intern Med. 1993;119:599-605. [pmid: 8363171].
Watanabe Y, Arase S, Senoue M, et al. [Statistical study on garlic (Allium) related contact dermatitis]. [Japanese]. Nishinihon J Dermatol. 1988;50:439-44.
Weisberger AS, Pensky J. Tumor inhibition by a sulfhydryl-blocking agent related to an active principle of garlic (Allium sativum). Cancer Res. 1958;18:1301-8. [pmid: 13608437].
Witte JS, Longnecker MP, Bird CL, et al. Relation of vegetable, fruit, and grain consumption to colorectal adenomatous polyps. Am J Epidemiol. 1996;144:1015-25. [pmid: 8942431].
Woerdenbag HJ. [Garlic and garlic preparations]. [Dutch]. Pharm Weekbl. 1992;127:498-501.
Wunderer H. [The garlic dilemma]. [German]. Dtsch Apoth Ztg. 1990;130:1743-5.
Yang GM. [Effects of desensitization and immunologic changes in patients with allergic asthma]. [Chinese]. Chung Hua Chieh Ho Ho Hu Hsi Tsa Chih. 1989;12:359-60, 382. [pmid: 2636057].
Yeh YY, Lin RI, Yeh SM, et al. Garlic reduces plasma cholesterol in hypercholesterolemic men maintaining habitual diets. In: Ohigashi H, Osawa T, Terao J, Watanabe S, editors. Food factors for cancer prevention. Tokyo, Japan: Springer-Verlag; 1997. p. 226-30.
Yoshikawa K, Hadame K, Saitoh K, et al. Patch tests with common vegetables in hand dermatitis patients. Contact Dermatitis. 1979;5:274-5. [pmid: 498779].
You WC, Blot WJ, Chang YS, et al. Allium vegetables and reduced risk of stomach cancer. J Natl Cancer Inst. 1989;81:162-4. [pmid: 2909758].
You WC. [A study on the relationship between consumption of allium vegetables and gastric cancer]. [Chinese]. Chung Hua Yu Fang I Hsueh Tsa Chih. 1988;22:321-3. [pmid: 3248454].
You WC, Chang YS, Yang ZT, et al. Etiological research on gastric cancer and its precursor lesions in Shandong, China. IARC Sci Publ. 1991;105:33-8. [pmid: 1855874].
You WC, Zhang L, Gail MH, et al. Helicobacter pylori infection, garlic intake and precancerous lesions in a Chinese population at low risk of gastric cancer. Int J Epidemiol. 1998;27:941-4. [pmid: 10024185].
Zhang JL, Shi ZX, Zhang HY. [Progress in the prevention and treatment of ischemic cerebrovascular diseases with garlic extract]. [Chinese]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1995;15:124-6. [pmid: 7787391].
Zheng S, Yang H, Zhang S, et al. Initial study on naturally occurring products from traditional Chinese herbs and vegetables for chemoprevention. J Cell Biochem Suppl. 1997;27:106-12. [pmid: 9591200].
Zheng W, Blot WJ, Shu XO, et al. A population-based case-control study of cancers of the nasal cavity and paranasal sinuses in Shanghai. Int J Cancer. 1992;52:557-61. [pmid: 1399136].
Zheng W, Blot WJ, Shu XO, et al. Diet and other risk factors for laryngeal cancer in Shanghai, China. Am J Epidemiol. 1992;136:178-91. [pmid: 1415140].
Zimmermann K. [untitled] [Web site]. http//www.magpage.com/bigshout/health1.txt [accessed May 4, 1999].
Zimmermann W, Zimmermann B. Reduction in elevated blood lipids in hospitalised patients by a standardised garlic preparation. Br J Clin Pract Symp Suppl. 1990;69:20-3. [pmid: 2083169].