# References

1 Healthy Way. Incredible edibles: garlic galore [Web site]. http://www1.sympatico.ca/healthyway/HEALTHYWAY/archive/rec_gar.html.
2 Day A. Gothic gardening: Ye olde gothick herball. http://www.gothic.net/~malice/garlic.html [accessed May 24, 1999].
3 Koch HP, Lawson L, editors. Garlic: the science and therapeutic application of Allium sativum L. and related species. 2nd ed. Baltimore, MD: Williams & Wilkins; 1996.
4 Grieve M. A modern herbal: garlic [Web site]. http://www.botanical.com/botanical/mgmh/g/garlic06.html [accessed May 4, 1999].
5 Jesse J, Mohseni M, Sha N. Medical attributes of Allium sativum - garlic [Web site]. http://wilkes1.wilkes.edu/~kklemow/Allium.html [accessed May 6, 1999].
6 Ranch C. Garlic: good taste and good health! [Web site]. http://www.christopher-ranch.com/website5.htm [accessed May 4, 1999].
7 Fenwick GR, Hanley AB. The genus Allium-Part 1. Crit Rev Food Sci Nutr. 1985;22:199-271. [pmid: 3902370].
8 Block E. Biologically active organic sulfur compounds in garlic. Dtsch Apoth Ztg. 1989;129:3-4.
9 Block E. The chemistry of garlic and onions. Sci Am. 1985;252:94-114, 119.
10 Block E. The organosulfur chemistry of the genus Allium: implications for the organic chemistry of sulfur. Angew Chem Int Ed Engl. 1992;31:1135-78.
11 Rabinkov A, Miron T, Konstantinovski L, et al. The mode of action of allicin: trapping of radicals and interaction with thiol containing proteins. Biochim Biophys Acta. 1998;1379:233-44. [pmid: 9528659].
12 Miron T, Rabinkov A, Mirelman D, et al. The mode of action of allicin: its ready permeability through phospholipid membranes may contribute to its biological activity. Biochim Biophys Acta. 2000;1463:20-30. [pmid: 10631291].
13 Kendler BS. Garlic (Allium sativum) and onion (Allium cepa): a review of their relationship to cardiovascular disease. Prev Med. 1987;16:670-85. [pmid: 3317392].
14 Farbman KS, Barnett ED, Bolduc GR, et al. Antibacterial activity of garlic and onions: a historical perspective. Pediatr Infect Dis J. 1993;12:613-14. [pmid: 8346006].
15 Bolton S, Null G, Troetel WM. The medical uses of garlic-fact and fiction. Am Pharm. 1982;22:40-3.
16 University of Texas Center for Alternative Medicine Research in Cancer. Garlic [Web site]. http://www.sph.uth.tmc.edu/utcam/therapies/garlic.htm [accessed April 16, 1999].
17 Bordia A, Arora SK, Kothari LK, et al. The protective action of essential oils of onion and garlic in cholesterol-fed rabbits. Atherosclerosis. 1975;22:103-9. [pmid: 1156467].
18 Bordia A, Verma SK. Effect of garlic feeding on regression of experimental atherosclerosis in rabbits. Artery. 1980;7:428-37. [pmid: 7213027].
19 Bordia A, Verma SK, Khabia BL, et al. The effective of active principle of garlic and onion on blood lipids and experimental atherosclerosis in rabbits and their comparison with clofibrate. J Assoc Physicians India. 1977;25:509-16. [pmid: 614376].
20 Bordia A, Verma SK, Vyas AK, et al. Effect of essential oil of onion and garlic on experimental atherosclerosis in rabbits. Atherosclerosis. 1977;26:379-86. [pmid: 192252].
21 Kamanna VS, Chandrasekhara N. Effect of garlic (Allium sativum linn) on serum lipoproteins and lipoprotein cholesterol levels in albino rats rendered hypercholesteremic by feeding cholesterol. Lipids. 1982;17:483-8. [pmid: 7121209].
22 Shoetan A, Augusti KT, Joseph PK. Hypolipidemic effects of garlic oil in rats fed ethanol and a high lipid diet. Experientia. 1984;40:261-3. [pmid: 6698185].
23 Jain RC. Effect of garlic on serum lipids, coagulability and fibrinolytic activity of blood. Am J Clin Nutr. 1977;30:1380-1. [pmid: 900054].
24 Jain AK, Vargas R, Gotzkowsky S, et al. Can garlic reduce levels of serum lipids? A controlled clinical study. Am J Med. 1993;94:632-5. [pmid: 8506890].
25 Augusti KT. Hypocholesterolaemic effect of garlic, Allium sativum Linn. Indian J Exp Biol. 1977;15:489-90. [pmid: 598887].
26 Ernst E, Weihmayr T, Matrai A. Garlic and blood lipids. Br Med J (Clin Res Ed). 1985;291.
27 Harenberg J, Giese C, Zimmermann R. Effect of dried garlic on blood coagulation, fibrinolysis, platelet aggregation and serum cholesterol levels in patients with hyperlipoproteinemia. Atherosclerosis. 1988;74:247-9. [pmid: 3240334].
28 Brosche T, Platt D, Dorner H. The effect of a garlic preparation on the composition of plasma lipoproteins and erythrocyte membranes in geriatric subjects. Br J Clin Pract Symp Suppl. 1990;69:12-9. [pmid: 2083168].
29 Gadkari JV, Joshi VD. Effect of ingestion of raw garlic on serum cholesterol level, clotting time and fibrinolytic activity in normal subjects. J Postgrad Med. 1991;37:128-31. [pmid: 1784022].
30 Lau BHS, Lam F, Wang Cheng R. Effect of an odor-modified garlic preparation on blood lipids. Nutr Res. 1987;7:139-49.
31 Arora RC, Arora S. Comparative effect of clofibrate, garlic and onion on alimentary hyperlipemia. Atherosclerosis. 1981;39:447-52. [pmid: 7259824].
32 Arora RC, Arora S, Gupta RK. The long-term use of garlic in ischemic heart disease: an appraisal. Atherosclerosis. 1981;40:175-9. [pmid: 7306257].
33 Nitiyanant W, Ploybutr S, Wasuwat S, et al. Effect of the dried powder extract, water soluble of garlic (Allium sativum) on cholesterol, triglyceride and high density lipoprotein in the blood. J Med Assoc Thai. 1987;70:646-8. [pmid: 3443797].
34 Bordia A. Effect of garlic on blood lipids in patients with heart disease. Am J Clin Nutr. 1981;34:2100-3. [pmid: 7293938].
35 Bhushan S, Sharma SP, Singh SP, et al. Effect of garlic on normal blood cholesterol level. Indian J Physiol Pharmacol. 1979;23:211-4. [pmid: 521124].
36 Barrie SA, Wright JV, Pizzorno JE. Effects of garlic oil on platelet aggregation, serum lipids and blood pressure in humans. J Orthomolecular Med. 1987;2:15-21.
37 Kandziora J. Blutdruckund lipidsenkende Wirkung eines Knoblauch-Praparates in Kombination mit einem Diuretikum. Arztl Forsch. 1988;3:3-8.
38 Kandziora J. Antihypertensive Wirksamkeit und Verträglichkeit eines Knoblauch-Präparates. Arztl Forsch. 1988;1:1-8.
39 Auer W, Eiber A, Hertkorn E, et al. Hypertension and hyperlipidaemia: garlic helps in mild cases. Br J Clin Pract Symp Suppl. 1990;69:3-6. [pmid: 2083170].
40 Plengvidhya C, Chinayon S, Sitprija S, et al. Effects of spray dried garlic preparation on primary hyperlipoproteinemia. J Med Assoc Thai. 1988;71:748-52.
41 Lawson LD. Garlic powder for hyperlipidemia: analysis of recent negative results. Q Rev Nat Med. 1998;Fall:187-9.
42 Warshafsky S, Kamer RS, Sivak SL. Effect of garlic on total serum cholesterol. A meta-analysis. Ann Intern Med. 1993;119:599-605. [pmid: 8363171].
43 Ernst E. Cardiovascular effects of garlic (allium sativum): a review. Pharmatherapeutica. 1987;5:83-9. [pmid: 3310019].
44 Silagy C, Neil A. Garlic as a lipid lowering agent: a meta-analysis. J R Coll Physicians Lond. 1994;28:39-45. [pmid: 8169881].
45 Kleijnen J, Knipschild P, Ter Riet G. Garlic, onions and cardiovascular risk factors. A review of the evidence from human experiments with emphasis on commercially available preparations. Br J Clin Pharmacol. 1989;28:535-44. [pmid: 2686739].
46 Silagy CA, Neil HA. A meta-analysis of the effect of garlic on blood pressure. J Hypertens. 1994;12:463-8. [pmid: 8064171].
47 Neil HA, Silagy CA, Lancaster T, et al. Garlic powder in the treatment of moderate hyperlipidaemia: a controlled trial and meta-analysis. J R Coll Physicians Lond. 1996;30:329-34. [pmid: 8875379].
48 Lea MA. Organosulfur compounds and cancer. Adv Exp Med Biol. 1996;401:147-54. [pmid: 8886133].
49 Dorant E, van den Brandt PA, Goldbohm RA, et al. Garlic and its significance for the prevention of cancer in humans: a critical review. Br J Cancer. 1993;67:424-9. [pmid: 8439494].
50 Lau BHS, Tadi PP, Tosk JM. Allium sativum (garlic) and cancer prevention. Nutr Res. 1990;10:937-48.
51 Dausch JG, Nixon DW. Garlic: a review of its relationship to malignant disease. Prev Med. 1990;19:346-61. [pmid: 2198557].
52 Das T, Choudhury AR, Sharma A, et al. Effects of crude garlic extract on mouse chromosomes in vivo. Food Chem Toxicol. 1996;34:43-7. [pmid: 8603796].
53 Cheng JY, Meng CL, Tzeng CC, et al. Optimal dose of garlic to inhibit dimethylhydrazine-induced colon cancer. World J Surg. 1995;19:621-6. [pmid: 7676710].
54 El Mofty MM, Sakr SA, Essawy A, et al. Preventive action of garlic on aflatoxin B1-induced carcinogenesis in the toad Bufo regularis. Nutr Cancer. 1994;21:95-100. [pmid: 8183725].
55 You WC, Chang YS, Yang ZT, et al. Etiological research on gastric cancer and its precursor lesions in Shandong, China. IARC Sci Publ. 1991;105:33-8. [pmid: 1855874].
56 Buiatti E, Palli D, Decarli A, et al. A case-control study of gastric cancer and diet in Italy: I. Int J Cancer. 1989;44:611-6. [pmid: 2793233].
57 Zheng S, Yang H, Zhang S, et al. Initial study on naturally occurring products from traditional Chinese herbs and vegetables for chemoprevention. J Cell Biochem Suppl. 1997;27:106-12. [pmid: 9591200].
58 Challier B, Perarnau JM, Viel JF. Garlic, onion and cereal fibre as protective factors for breast cancer: a French case-control study. Eur J Epidemiol. 1998;14:737-47. [pmid: 9928867].
59 Levi F, Pasche C, La Vecchia C, et al. Food groups and colorectal cancer risk. Br J Cancer. 1999;79:1283-7. [pmid: 10098773].
60 Steinmetz KA, Kushi LH, Bostick RM, et al. Vegetables, fruit, and colon cancer in the Iowa Women's Health Study. Am J Epidemiol. 1994;139:1-15. [pmid: 8296768].
61 Key TJA, Silcocks PB, Davey GK, et al. A case-control study of diet and prostate cancer. Br J Cancer. 1997;76:678-87. [pmid: 9303371].
62 Block E. Garlic as a functional food: a status report. In: Shibamoto T, Teroa J, Osawa T, editors. Functional foods for disease prevention. Vol. 2. Washington: American Chemical Society; 1998. p. 125-43.
63 Zimmermann K. [untitled] [Web site]. http//www.magpage.com/bigshout/health1.txt [accessed May 4, 1999].
64 Gardner CD, Chatterjee L, Carlson J. Effect of garlic supplementation on plasma lipids in hypercholesterolemic men and women [abstract]. Circulation. 1999;99.
65 Singer DRJ, Markandu ND, Bath PMW, et al. Effects of garlic on blood pressure, lipids and platelets in patients with essential hypertension and raised cholesterol [unpublished abstract].
66 Hedges LV, Olkin I. Statistical methods for meta-analysis. Orlando (FL): Academic Press; 1985.
67 Rosenthal R. Meta-analytic procedures for social research. Rev. ed. Newbury Park (CA): Sage Publications; 1991.
68 Sharp S. Sbe23: meta-regression. Stata Tech Bull. 1998;42:16-22.
69 Kiesewetter H, Jung F, Jung EM, et al. Effects of garlic coated tablets in peripheral arterial occlusive disease. Clin Investig. 1993;71:383-6.
70 Czerny B, Samochowiec J. Klinische Untersuchungen mit einem Knoblauch-Lezithin-Präparat. Arztezeitschr Naturheilverf. 1996;37:126-9.
71 Bordia A. [Garlic and coronary heart disease. Results of a 3-year treatment with garlic extract on the reinfarction and mortality rate]. [Ger]. Deutsche Apotheker Zeitung. 1989;129(28 Suppl 15):16-17.
72 Bordia A, Verma SK, Srivastava KC. Effect of garlic (Allium sativum) on blood lipids, blood sugar, fibrinogen and fibrinolytic activity in patients with coronary artery disease. Prostaglandins Leukot Essent Fatty Acids. 1998;58:257-63. [pmid: 9654398].
73 Sitprija S, Plengvidhya C, Kangkaya V, et al. Garlic and diabetes mellitus phase II clinical trial. J Med Assoc Thai. 1987;70:223-7.
74 Chutani SK, Bordia A. The effect of fried versus raw garlic on fibrinolytic activity in man. Atherosclerosis. 1981;38:417-21. [pmid: 7225179].
75 Vorberg G, Schneider B. Therapy with garlic: results of a placebo-controlled, double-blind study. Br J Clin Pract Symp Suppl. 1990;69:7-11. [pmid: 2083173].
76 Lash JP, Cardoso LR, Mesler PM, et al. The effect of garlic on hypercholesterolemia in renal transplant patients. Transplant Proc. 1998;30:189-91. [pmid: 9474997].
77 Yeh YY, Lin RI, Yeh SM, et al. Garlic reduces plasma cholesterol in hypercholesterolemic men maintaining habitual diets. In: Ohigashi H, Osawa T, Terao J, Watanabe S, editors. Food factors for cancer prevention. Tokyo, Japan: Springer-Verlag; 1997. p. 226-30.
78 Kannar D. Clinical evaluation of Australian based garlic and its combination with inulin in mild and moderate hyperlipidaemia [dissertation]. Clayton, Australia: Monash University; 1998. p. i-vi, 6, 67-114.
79 Adler AJ, Holub BJ. Effect of garlic and fish-oil supplementation on serum lipid and lipoprotein concentrations in hypercholesterolemic men. Am J Clin Nutr. 1997;65:445-50. [pmid: 9022529].
80 Superko HR, Krauss RM. Garlic powder, effect on plasma lipids, postprandial lipemia, low-density lipoprotein particle size, high-density lipoprotein subclass distribution and lipoprotein(a). J Am Coll Cardiol. 2000;35:321-6. [pmid: 10676676].
81 de Santos AOS, Grunwald J. Effect of garlic powder tablets on blood lipids and blood pressure: a six month placebo controlled, double blind study. Br J Clin Res. 1993;4:37-44.
82 Melvin KR. Effects of garlic powder tablets on patients with hyperlipidaemia in Canadian clinical practice. Eur J Clin Res. 1996;8:30-2.
83 de Santos AOS, Jones RA. Effects of garlic powder and garlic oil preparations on blood lipids, blood pressure and well-being. Br J Clin Res. 1995;6:91-100.
84 Mansell P, Reckless JPD, Lloyd L. The effect of dried garlic powder tablets on serum lipids in non-insulin dependent diabetic patients. Eur J Clin Res. 1996;8:25-6.
85 Holzgartner H, Schmidt U, Kuhn U. Comparison of the efficacy and tolerance of a garlic preparation vs. bezafibrate. Arzneimittelforschung. 1992;42:1473-7. [pmid: 1288512].
86 Isaacsohn JL, Moser M, Stein EA, et al. Garlic powder and plasma lipids and lipoproteins: a multicenter, randomized, placebo-controlled trial. Arch Intern Med. 1998;158:1189-94. [pmid: 9625398].
87 Kiesewetter H, Jung F, Pindur G, et al. Effect of garlic on thrombocyte aggregation, microcirculation, and other risk factors. Int J Clin Pharmacol Ther Toxicol. 1991;29:151-5. [pmid: 2071264].
88 Koscielny J, Klussendorf D, Latza R, et al. The antiatherosclerotic effect of Allium sativum. Atherosclerosis. 1999;144:237-49. [pmid: 10381297].
89 Mader FH. Treatment of hyperlipidaemia with garlic-powder tablets. Evidence from the German Association of General Practitioners' multicentric placebo-controlled double-blind study. Arzneimittelforschung. 1990;40:1111-6. [pmid: 2291748].
90 McCrindle BW, Helden E, Conner WT. Garlic extract therapy in children with hypercholesterolemia. Arch Pediatr Adolesc Med. 1998;152:1089-94. [pmid: 9811286].
91 Rotzsch W, Richter V, Rassoul F, et al. [Postprandial lipemia under treatment with Allium sativum. Controlled double-blind study of subjects with reduced HDL2-cholesterol]. [Ger]. Arzneimittelforschung. 1992;42:1223-7. [pmid: 1472142].
92 Saradeth T, Seidl S, Resch K, et al. Does garlic alter the lipid pattern in normal volunteers?. Phytomedicine. 1994;1:183-5.
93 Simons LA, Balasubramaniam S, von Konigsmark M, et al. On the effect of garlic on plasma lipids and lipoproteins in mild hypercholesterolaemia. Atherosclerosis. 1995;113:219-25. [pmid: 7605361].
94 Steiner M, Khan AH, Holbert D, et al. A double-blind crossover study in moderately hypercholesterolemic men that compared the effect of aged garlic extract and placebo administration on blood lipids. Am J Clin Nutr. 1996;64:866-70. [pmid: 8942410].
95 Berthold HK, Sudhop T, von Bergmann K. Effect of a garlic oil preparation on serum lipoproteins and cholesterol metabolism: a randomized controlled trial. JAMA. 1998;279:1900-2. [pmid: 9634262].
96 Luley C, Lehmann-Leo W, Moller B, et al. Lack of efficacy of dried garlic in patients with hyperlipoproteinemia. Arzneimittelforschung. 1986;36:766-8. [pmid: 3521619].
97 Morcos NC. Modulation of lipid profile by fish oil and garlic combination. J Natl Med Assoc. 1997;89:673-8. [pmid: 9347681].
98 Ventura P, Girola M, Lattuada V. [Clinical evaluation and tolerability of a drug with garlic and hawthorn]. [Ita]. Acta Toxicol Ther. 1990;11:365-72.
99 Kenzelmann R, Kade F. Limitation of the deterioration of lipid parameters by a standardized garlic-ginkgo combination product. A multicenter placebo-controlled double-blind study. Arzneimittelforschung. 1993;43:978-81. [pmid: 8240462].
100 Lutomski J. Klinische Untersuchungen zur therapeutischen Wirksamkeit von Ilha Rogoff Knoblauchpillen mit Rutin. Z Phytother. 1984;5:938-42.
101 Schiermeier Q. German garlic study under scrutiny [newsletter]. Nature. 1999;401.
102 Steiner M, Lin RS. Changes in platelet function and susceptibility of lipoproteins to oxidation associated with administration of aged garlic extract. J Cardiovasc Pharmacol. 1998;31:904-8. [pmid: 9641475].
103 Koch K. Studie mit fadem Nageschmack: ein Verlag verkauft das Recht, die Artikel für seine Fachzeitschrift auszuwählen-und bekommt prompt Ärger mit einer zweifelhaften Veröffentichung [newspaper]. Suddeutsche Zeitung 1999 May.
104 You WC, Zhang L, Gail MH, et al. Helicobacter pylori infection, garlic intake and precancerous lesions in a Chinese population at low risk of gastric cancer. Int J Epidemiol. 1998;27:941-4. [pmid: 10024185].
105 Witte JS, Longnecker MP, Bird CL, et al. Relation of vegetable, fruit, and grain consumption to colorectal adenomatous polyps. Am J Epidemiol. 1996;144:1015-25. [pmid: 8942431].
106 Dorant E, Van den Brandt PA, Goldbohm RA. Allium vegetable consumption, garlic supplement intake, and female breast carcinoma incidence. Breast Cancer Res Treat. 1995;33:163-70. [pmid: 7749142].
107 Ballard-Barbash R, Krebs-Smith S, Subar AF. Re: "Vegetables, fruit, and colon cancer in the Iowa Women's Health Study. " [published erratum appears in Am J Epidemiol 1995; 141:697]. Am J Epidemiol. 1995;141:84-6.
108 Dorant E, van den Brandt PA, Goldbohm RA. A prospective cohort study on the relationship between onion and leek consumption, garlic supplement use and the risk of colorectal carcinoma in The Netherlands. Carcinogenesis. 1996;17:477-84. [pmid: 8631133].
109 van den Brandt PA, Goldbohm RA, van't Veer P, et al. A large-scale prospective cohort study on diet and cancer in The Netherlands. J Clin Epidemiol. 1990;43:285-95. [pmid: 2313318].
110 You WC. [A study on the relationship between consumption of allium vegetables and gastric cancer]. [Chi]. Chung Hua Yu Fang I Hsueh Tsa Chih. 1988;22:321-3. [pmid: 3248454].
111 You WC, Blot WJ, Chang YS, et al. Allium vegetables and reduced risk of stomach cancer. J Natl Cancer Inst. 1989;81:162-4. [pmid: 2909758].
112 Dorant E, van den Brandt PA, Goldbohm RA, et al. Consumption of onions and a reduced risk of stomach carcinoma. Gastroenterology. 1996;110:12-20. [pmid: 8536847].
113 Dorant E, van den Brandt PA, Goldbohm RA. A prospective cohort study on Allium vegetable consumption, garlic supplement use, and the risk of lung carcinoma in The Netherlands. Cancer Res. 1994;54:6148-53. [pmid: 7954460].
114 Levi F, Franceschi S, Negri E, et al. Dietary factors and the risk of endometrial cancer. Cancer. 1993;71:3575-81. [pmid: 8490907].
115 Levi F, La Vecchia C, Gulie C, et al. Dietary factors and breast cancer risk in Vaud, Switzerland. Nutr Cancer. 1993;19:327-35. [pmid: 8346081].
116 Zheng W, Blot WJ, Shu XO, et al. Diet and other risk factors for laryngeal cancer in Shanghai, China. Am J Epidemiol. 1992;136:178-91. [pmid: 1415140].
117 Cook-Mozaffari PJ, Azordegan F, Day NE, et al. Oesophageal cancer studies in the Caspian Littoral of Iran: results of a case-control study. Br J Cancer. 1979;39:293-309. [pmid: 465299].
118 Gao CM, Takezaki T, Ding JH, et al. Protective effect of allium vegetables against both esophageal and stomach cancer: a simultaneous case-referent study of a high-epidemic area in Jiangsu Province, China. Jpn J Cancer Res. 1999;90:614-21. [pmid: 10429652].
119 Graham S, Marshall J, Haughey B, et al. Dietary epidemiology of cancer of the colon in western New York. Am J Epidemiol. 1988;128:490-503. [pmid: 2843038].
120 Haenszel W, Berg JW, Segi M, et al. Large-bowel cancer in Hawaiian Japanese. J Natl Cancer Inst. 1973;51:1765-79. [pmid: 4797262].
121 Haenszel W, Locke FB, Segi M. A case-control study of large bowel cancer in Japan. J Natl Cancer Inst. 1980;64:17-22. [pmid: 6928043].
122 Manousos O, Day NE, Trichopoulos D, et al. Diet and colorectal cancer: a case-control study in Greece. Int J Cancer. 1983;32:1-5. [pmid: 6862688].
123 Steinmetz KA, Potter JD. Food-group consumption and colon cancer in the Adelaide Case-Control Study. I. Vegetables and fruit. Int J Cancer. 1993;53:711-9. [pmid: 8449594].
124 Tuyns AJ, Kaaks R, Haelterman M. Colorectal cancer and the consumption of foods: a case-control study in Belgium. Nutr Cancer. 1988;11:189-204. [pmid: 3405870].
125 Swanson CA, Mao BL, Li JY, et al. Dietary determinants of lung-cancer risk: results from a case-control study in Yunnan Province, China. Int J Cancer. 1992;50:876-80. [pmid: 1555887].
126 Zheng W, Blot WJ, Shu XO, et al. A population-based case-control study of cancers of the nasal cavity and paranasal sinuses in Shanghai. Int J Cancer. 1992;52:557-61. [pmid: 1399136].
127 Haenszel W, Kurihara M, Segi M. Cancer among Japanese in Hawaii. J Natl Cancer Inst. 1972;49:969-88. [pmid: 4678140].
128 Jeannel D, Hubert A, De Vathaire F, et al. Diet, living conditions and nasopharyngeal carcinoma in Tunisia: a case-control study. Int J Cancer. 1990;46:421-5. [pmid: 2394508].
129 Mei X, Wang ML, Xu HX, et al. Garlic and gastric cancer: the effect of garlic on nitrite and nitrate in gastric juice. Acta Nutr Sinica. 1982;4:53-6.
130 Gail MH, You WC, Chang YS, et al. Factorial trial of three interventions to reduce the progression of precancerous gastric lesions in Shandong, China: design issues and initial data. Controlled Clin Trials. 1998;19:352-69. [pmid: 9683311].
131 Lawson LD, Wang ZY, Hughes BG. Identification and HPLC quantitation of the sulfides and dialk(en)yl thiosulfinates in commercial garlic products. Planta Med. 1991;57:363-70. [pmid: 1775579].
132 De Smet PA. An introduction to herbal pharmacoepidemiology. J Ethnopharmacol. 1993;38:197-208. [pmid: 8510469].
133 Watanabe Y, Arase S, Senoue M, et al. [Statistical study on garlic (Allium) related contact dermatitis]. [Jap]. Nishinihon J Dermatol. 1988;50:439-44.
134 Gaddoni G, Selvi M, Resta F, et al. Allergic contact dermatitis to garlic in a cook. Ann Ital Dermatol Clin Sperimentale. 1994;48:120-1.
135 Gall H, Kalveram CM, Schunter M. Sofortallergie auf Lauch. Allergo J. 1996;51.
136 Edelstein AJ, Johnstown PA. Dermatitis caused by garlic. Arch Dermatol. 1950;61.
137 Bleumink E, Doeglas HM, Klokke AH, et al. Allergic contact dermatitis to garlic. Br J Dermatol. 1972;87:6-9. [pmid: 5043200].
138 Campolmi P, Lombardi P, Lotti T, et al. Immediate and delayed sensitization to garlic. Contact Dermatitis. 1982;8:352-3.
139 Seuri M, Taivanen A, Ruoppi P, et al. Three cases of occupational asthma and rhinitis caused by garlic. Clin Exp Allergy. 1993;23:1011-4. [pmid: 10779294].
140 van Ketel WG, de Haan P. Occupational eczema from garlic and onion. Contact Dermatitis. 1978;4:53-4.
141 Delaney TA, Donnelly AM. Garlic dermatitis. Australas J Dermatol. 1996;37:109-10. [pmid: 8687326].
142 Mitchell JC. Contact sensitivity to garlic (Allium). Contact Dermatitis. 1980;6:356-7. [pmid: 7418398].
143 McFadden JP, White IR, Rycroft RJG. Allergic contact dermatitis from garlic. Contact Dermatitis. 1992;27:333-4. [pmid: 1493696].
144 Fleischer S, Bayerl C, Jung EG. [Occupational allergic hand dermatitis to garlic in a pizza baker]. [Ger]. Aktuelle Dermatol. 1996;22:278-9.
145 Rauterberg A. [Allergic contact dermatitis due to garlic in a cook]. [Ger]. Aktuelle Dermatol. 1995;21:317-8.
146 Lautier R, Wendt V. [Contact allergy to Alliaceae. Case report and literature review]. [Ger]. Derm Beruf Umwelt. 1985;33:213-5. [pmid: 2936593].
147 Bojs G, Svensson A. Contact allergy to garlic used for wound healing. Contact Dermatitis. 1988;18:179-81. [pmid: 3365975].
148 Lee TY, Lam TH. Contact dermatitis due to topical treatment with garlic in Hong Kong. Contact Dermatitis. 1991;24:193-6. [pmid: 1831097].
149 Svensson A, Bojs G, Hradil E, et al. [Garlic and olive oil: good in food but unsuitable for skin care]. [Swe]. Lakartidningen. 1991;88:733-4. [pmid: 2002740].
150 Burden AD, Wilkinson SM, Beck MH, et al. Garlic-induced systemic contact dermatitis. Contact Dermatitis. 1994;30:299-300. [pmid: 8088146].
151 Fernandez de Corres L, Leanizbarrutia I, Munoz D, et al. [Allergic contact dermatitis caused by garlic, Primula, Frullania and Compositae]. [Spa]. Allergol Immunopathol (Madr). 1985;13:291-9. [pmid: 4083225].
152 Kanerva L, Estlander T, Jolanki R. Occupational allergic contact dermatitis from spices. Contact Dermatitis. 1996;35:157-62. [pmid: 8930476].
153 Meding B. Skin symptoms among workers in a spice factory. Contact Dermatitis. 1993;29:202-5. [pmid: 8281784].
154 Cronin E. Dermatitis of the hands in caterers. Contact Dermatitis. 1987;17:265-9. [pmid: 2963723].
155 Hjorth N, Roed Petersen J. Occupational protein contact dermatitis in food handlers. Contact Dermatitis. 1976;2:28-42. [pmid: 145923].
156 Yoshikawa K, Hadame K, Saitoh K, et al. Patch tests with common vegetables in hand dermatitis patients. Contact Dermatitis. 1979;5:274-5. [pmid: 498779].
157 Papageorgiou C, Corbet JP, Menezes Brandao F, et al. Allergic contact dermatitis to garlic (Allium sativum L.). Identification of the allergens: the role of mono-, di-, and trisulfides present in garlic. A comparative study in man and animal (guinea-pig). Arch Dermatol Res. 1983;275:229-34. [pmid: 6625648].
158 Sinha SM, Pasricha JS, Sharma R, et al. Vegetables responsible for contact dermatitis of the hands. Arch Dermatol. 1977;113:776-9. [pmid: 869548].
159 Minocha YC, Dogra A, Sood VK. Contact sensitivity in palmar hyperkeratotic dermatitis. Indian J Dermatol Venereol Leprol. 1993;59:60-3.
160 Yang GM. [Effects of desensitization and immunologic changes in patients with allergic asthma]. [Chi]. Chung Hua Chieh Ho Ho Hu Hsi Tsa Chih. 1989;12:359-60, 382. [pmid: 2636057].
161 van den Akker TW, Roesyanto-Mahadi ID, van Toorenenbergen AW, et al. Contact allergy to spices. Contact Dermatitis. 1990;22:267-72. [pmid: 2383985].
162 Lembo G, Balato N, Patruno C, et al. Allergic contact dermatitis due to garlic (Allium sativum). Contact Dermatitis. 1991;25:330-1. [pmid: 1839726].
163 Bruynzeel DP, Prevoo RLMA. Patch tests with some spices. Dermatol Clin. 1990;8:85-7. [pmid: 2302865].
164 Bleumink E, Nater JP. Contact dermatitis to garlic: crossreactivity between garlic, onion and tulip. Arch Dermatol Forsch. 1973;247:117-24. [pmid: 4748763].
165 Ruocco V, Brenner S, Lombardi ML. A case of diet-related pemphigus. Dermatology. 1996;192:373-4. [pmid: 8864379].
166 Eming SA, Piontek JO, Hunzelmann N, et al. Severe toxic contact dermatitis caused by garlic. Br J Dermatol. 1999;141:391-2. [pmid: 10468845].
167 Pirogova EP, Katiukhina ZD. [Artificial dermatitis caused by garlic]. [Rus]. Vestn Dermatol Venerol. 1970;44:53-4.
168 Canduela V, Mongil I, Carrascosa M, et al. Garlic: always good for the health?. Br J Dermatol. 1995;132:161-2. [pmid: 7756138].
169 Garty BZ. Garlic burns. Pediatrics. 1993;91:658-9. [pmid: 8441577].
170 Roberge RJ, Leckey R, Spence R, et al. Garlic burns of the breast. Am J Emerg Med. 1997;15.
171 Parish RA, McIntire S, Heimbach DM. Garlic burns: a naturopathic remedy gone awry. Pediatr Emerg Care. 1987;3:258-60. [pmid: 3324067].
172 Martinescu E. [Contact dermatitis caused by Allium sativum]. [Rom]. Rev Med Chir Soc Med Nat Iasi. 1981;85:541-2. [pmid: 6461044].
173 Kaplan B, Schewach Millet M, Yorav S. Factitial dermatitis induced by application of garlic. Int J Dermatol. 1990;29:75-6. [pmid: 2329032].
174 Farrell AM, Staughton RCD. Garlic burns mimicking herpes zoster. Lancet. 1996;347.
175 Hallel-Halevy D, Zlotogorski A, Grunwald MH, et al. Multifaceted dermatitis artefacta caused by garlic. J Eur Acad Dermatol Venereol. 1997;9:185-7.
176 Henson GE. Garlic: an occupational factor in the etiology of bronchial asthma. J Fla Med Assoc. 1940;27.
177 Kirsten D, Meister W. [Occupational allergy due to garlic]. [Ger]. Allergologie. 1985;8:511-2.
178 Lemiere C, Cartier A, Lehrer SB, et al. Occupational asthma caused by aromatic herbs. Allergy. 1996;51:647-9. [pmid: 8899117].
179 Couturier P, Bousquet J. Occupational allergy secondary inhalation of garlic dust. J Allergy Clin Immunol. 1982;70.
180 Couturier P, Kreuter M, Loupi J. Allergie a la poussière d'ail. A propos de deux observations. Rev Fr Allergol. 1980;20:145-7.
181 Falleroni AE, Zeiss CR, Levitz D. Occupational asthma secondary to inhalation of garlic dust. J Allergy Clin Immunol. 1981;68:156-60. [pmid: 7252000].
182 Armentia A, Vega JM. Can inhalation of garlic dust cause asthma? [published erratum appears in Allergy 1997; 52: 358]. Allergy. 1996;51:137-8. [pmid: 8738525].
183 Anibarro B, Fontela JL, De La Hoz F. Occupational asthma induced by garlic dust. J Allergy Clin Immunol. 1997;100:734-8. [pmid: 9438479].
184 Lybarger JA, Gallagher JS, Pulver DW, et al. Occupational asthma induced by inhalation and ingestion of garlic. J Allergy Clin Immunol. 1982;69:448-54. [pmid: 7076985].
185 Molina C, Lachaussee R, Jeanneret A, et al. [A garlic story]. [Fre]. Presse Med. 1983;12.
186 Asero R, Mistrello G, Roncarolo D, et al. A case of garlic allergy. J Allergy Clin Immunol. 1998;101:427-8. [pmid: 9525465].
187 Kurzen M, Bayerl C. [Immediate-type hypersensitivity to garlic]. [Ger]. Aktuelle Dermatol. 1997;23:145-7.
188 Boccafogli A, Vicentini L, Camerani A, et al. Adverse food reactions in patients with grass pollen allergic respiratory disease. Ann Allergy. 1994;73:301-8. [pmid: 7943997].
189 Rance F, Dutau G. Labial food challenge in children with food allergy. Pediatr Allergy Immunol. 1997;8:41-4. [pmid: 9260218].
190 Andre F, Andre C, Colin L, et al. Role of new allergens and of allergens consumption in the increased incidence of food sensitizations in France. Toxicology. 1994;93:77-83. [pmid: 7974507].
191 Perez-Pimiento AJ, Moneo I, Santaolalla M, et al. Anaphylactic reaction to young garlic. Allergy. 1999;54:626-9. [pmid: 10435479].
192 Rose KD, Croissant PD, Parliment CF, et al. Spontaneous spinal epidural hematoma with associated platelet dysfunction from excessive garlic consumption: a case report. Neurosurgery. 1990;26:880-2. [pmid: 2352608].
193 Burnham BE. Garlic as a possible risk for postoperative bleeding. Plast Reconstr Surg. 1995;95.
194 German K, Kumar U, Blackford HN. Garlic and the risk of TURP bleeding. Br J Urol. 1995;76.
195 Sunter W. Warfarin and garlic. Pharm J. 1991;246.
196 Gupta MK, Mittal SR, Mathur AK, et al. Garlic: the other side of the coin. Int J Cardiol. 1993;38.
197 Szybejko J, Zukowski A, Herbec R. [Unusual cause of obturation of the small intestine]. [Pol]. Wiad Lek. 1982;35:163-4. [pmid: 7101938].
198 Harada K, Namiki M. [Acute gastric mucosal lesions induced by drugs and irritating foods]. [Jap]. Saishin Igaku. 1989;44:2056-60.
199 Caporaso N, Smith SM, Eng RH. Antifungal activity in human urine and serum after ingestion of garlic (Allium sativum). Antimicrob Agents Chemother. 1983;23:700-2. [pmcid: 184790]. [pmid: 6870217].
200 Jung F, Jung EM, Mrowietz C, et al. [The effects of garlic powder on cutaneous microcirculation. A cross-over test with healthy test persons]. [Ger]. Med Welt. 1991;42:28-30.
201 Benes J, Prerovsky K, Rehurek L, et al. [Garlic food allergy with symptoms of Meniere's disease]. [Cze]. Cas Lek Cesk. 1966;105:825-7. [pmid: 5958055].
202 St Louis ME, Peck SHS, Bowering D, et al. Botulism from chopped garlic: delayed recognition of a major outbreak. Ann Intern Med. 1988;108:363-8. [pmid: 3341673].
203 Snell SB. Garlic on the baby's breath. Lancet. 1973;2.
204 Mennella JA, Beauchamp GK. Maternal diet alters the sensory qualities of human milk and the nursling's behavior. Pediatrics. 1991;88:737-44. [pmid: 1896276].
205 Rosin S, Tuorila H, Uutela A. Garlic: a sensory pleasure or a social nuisance?. Appetite. 1992;19:133-43. [pmid: 1489211].