# Results

## Results: Cardiovascular Risks and Disease

### Overview of the Evidence

There were 45 RCTs lasting at least 4 weeks that tested the effects of garlic on cardiovascular-related endpoints (Evidence Table 1). All but three RCTs reported intermediate physiological outcomes rather than clinical outcomes such as cardiovascular events or mortality. ^69^ ^70^ ^71^ Reported trial protocols included lipid measurements (n=44), blood pressure measurements (n=30), serum glucose concentration (n=12), antithrombotic activity (n=10), walking distance (n=2), myocardial infarctions and deaths (n=1), and regression of atherosclerotic plaques (n=1). Placebo comparisons were used in 39 trials, a "no garlic" comparison in 2, an active antilipidemic or antihypertensive agent in 3, and a head-to-head comparison of two garlic preparations in 1.

Trials were conducted in Germany (n=13), North America (n=14), India (n=5), United Kingdom (n=4), Thailand (n=2), Poland (n=2), Switzerland (n=1), Italy (n=1), Europe (n=1), and Australia (n=2). Industry sponsorship and free provision of commercially developed garlic products were stated in 35 trials and were unclear in 3. Seven trials stated no commercial sponsorship. ^34^ ^35^ ^40^ ^71^ ^72^ ^73^ ^74^ Four trials were published in symposia or meeting proceedings, ^39^ ^71^ ^75^ ^76^ one in a book, ^77^ one as a thesis, ^78^ and the remainder in journals. We did not review the peer-review processes that were used by the journals.

Twenty-two studies used dehydrated garlic preparations that were standardized to an alliin content of 0.52 percent of the total tablet mass (Table 5). ^24^ ^37^ ^38^ ^39^ ^47^ ^69^ ^75^ ^79^ ^80^ ^81^ ^82^ ^83^ ^84^ ^85^ ^86^ ^87^ ^88^ ^89^ ^90^ ^91^ ^92^ ^93^ Such standardization is reportedly equivalent to a potential 0.6 percent allicin release. One study standardized to a guaranteed minimum release of 3,000 per million (0.3 percent) allicin. ^76^ Another study standardized to produce 2.4 mg allicin per tablet. ^78^

Table 5. Characteristics of trials that evaluated standardized dehydrated garlic powder preparations

Study | Country of Study | Size (n=) | Mean Age | Male % | Participant Characteristics | Inclusion Criteria | Recruitment Setting | Garlic Preparation | Daily Dosage
Adler (1997)^79^ | Canada | 23 | 46 | 100 | No diabetics or cardiac disease No lipid or antihypertensive drug | TC > 200 mg/dL | Unclear | Dehydrated tablet: Kwai^®^ | 900 mg
Auer (1990)^39^ | Germany | 47 | 58 | 45 | 45% with TC > 250 8% Diabetic | DBP 95 to 104 mm Hg | 11 General practices | Dehydrated tablet: Kwai^®^ | 600 mg
Holzgartner (1992)^85^ | Germany | 98 | 57 | 39 | 40% Smokers 35% Hypertensive 2% Diabetic | TC or TG > 250 mg/dL Hyperlipoproteinemia types IIa, IIb, or IV | 5 General practices | Dehydrated tablet: Kwai^®^ | 900 mg
Isaacsohn (1998)^86^ | United States | 50 | 58 | 54 | 2% Coronary disease 2% Smokers 22% Hypertensive | LDL > 160 mg/dL and TG < 350 mg/dL | Specialty clinic | Dehydrated tablet: Kwai^®^ | 900 mg
Jain (1993)^24^ | United States | 42 | 52 | 45 | No diabetics 26% Smokers | TC > 220 mg/dL | Community volunteers | Dehydrated tablet: Kwai^®^ | 900 mg
Kandziora (1988)^37^ | Germany | 40 | Range 43-65 | Not given | Base: TC 280 mg/dL Base: TG 209 mg/dL No diabetics | DBP 95 to 104 mm Hg | Unclear | Dehydrated tablet: Kwai^®^ | 600 mg
Kandziora (1988)^38^ | Germany | 40 | 56 | 83 | Base: TC 292 mg/dL Base: TG 207 mg/dL No diabetics 70% Smokers | DBP 95 to 104 mm Hg | Unclear | Dehydrated tablet: Kwai^®^ | 600 mg
Kannar (1998)^78^ | Australia | 90 | 54 | 54 | No diabetics or cardiac disease No lipid or antihypertensive drug | TC > 250 mg/dL | Community volunteers | Dehydrated enteric-coated tablet: noncommercial | 880 mg
Kiesewetter (1991)^87^ | Germany | 60 | 24 | 30 | 13% Smokers | Elevated spontaneous platelet activity | Unclear | Dehydrated tablet: Kwai^®^ | 800 mg
Kiesewetter (1993)^69^ | Germany | 80 | 60 | 54 | 75% Smokers 75% Elevated TC 60% "Obese" 40% Diabetic | Lower extremity peripheral vascular disease | Unclear | Dehydrated tablet: Kwai^®^ | 800 mg
Koscielny (1999)^88^ | Germany | 280 | 60 | 71 | 65% Elevated TC 27% Smokers 38% Hypertensive 6% Diabetic | Asymptomatic advanced atherosclerotic plaques in femoral or carotid artery | Unclear | Dehydrated tablet: Kwai^®^ | 900 mg
Lash (1998)^76^ | United States | 35 | 45 | 49 | All postrenal transplant | TC > 240 mg/dL and LDL > 160 mg/dL | Unclear | Dehydrated tablet: Pure-Gar^®^ | 1,360 mg
Mader (1990)^89^ | Germany | 261 | 59 | 44 | 47% Hypertensive 7% Diabetic 12% Coronary disease | TC and/or TG > 200 mg/dL | Community clinic | Dehydrated tablet: Kwai^®^ | 800 mg
Mansell (1996)^84^ | United Kingdom | 60 | 63 | 76 | All noninsulin dependent diabetes | Unclear | Unclear | Dehydrated tablet: Kwai^®^ | 900 mg
McCrindle (1998)^90^ | Canada | 31 | 14 | 52 | No significant alcohol or tobacco use | TC > 185 mg/dL, family history of hyperlipidemia and early coronary artery disease | Specialty clinic | Dehydrated tablet: Kwai^®^ | 900 mg
Melvin (1996)^82^ | Canada | 34 | 41 to 77 | 47 | All hyperlipidemic | Off all drug therapy "Elevated cholesterol" | Unclear | Dehydrated tablet: Kwai^®^ | 900 mg
Neil (1996)^47^ | United Kingdom | 115 | 53 | 61 | Mean BMI > 27 15% Smokers | TC 230 to 325 mg/dL and LDL > 130 mg/dL | Community clinic | Dehydrated tablet: Kwai^®^ | 900 mg
Rotzsch (1992)^91^ | Germany | 24 | 37 | 42 | 29% Hypertensive | HDL < 10 mg/dL (men); HDL < 15 mg/dL (women) | Unclear | Dehydrated tablet: Kwai^®^ | 900 mg
de Santos (1993)^81^ | United Kingdom | 60 | 52 | 33 | No lipid or antihypertensive drug | TC > 250 mg/dL | Community clinic | Dehydrated tablet: Kwai^®^ | 900 mg
de Santos (1995)^83^ | United Kingdom | 80 | 56 | 35 | No lipid or antihypertensive drug | Mild hypercholesteremia | 1 general practice | Dehydrated tablet: Kwai^®^ | 600 mg
Saradeth (1994)^92^ | Europe | 72 | 39 | 29 | No fibrinolytic or anticoagulant meds | Age 18 to 50 | Community volunteers | Dehydrated tablet: Kwai^®^ | 600 mg
Simons (1995)^93^ | Australia | 31 | 54 | 52 | No diabetics or cardiac disease No lipid or antihypertensive drug | TC 230 to 300 mg/dL; TG < 260 mg/dL | Community volunteers | Dehydrated tablet: Kwai^®^ | 900 mg
Superko (2000)^80^ | United States | 50 | 53 | Unclear | No lipid drugs | Moderate hypercholesteremia | Unclear | Dehydrated tablet: Kwai^®^ | 900 mg
Vorberg (1990)^75^ | Germany | 40 | 50 | 43 | No diabetics | TC 230 to 350 mg/dL | Community clinic | Dehydrated tablet: Kwai^®^ | 900 mg

Note: To convert cholesterol, LDL, and HDL values from mg/dL to mmol/dL, divide by 38.7. To convert triglyceride values from mg/dL to mmol/dL, divide by 88.2.

Abbreviations used: MI = body mass index; DBP = diastolic blood pressure; HDL = high density lipoprotein; LDL = low density lipoprotein; mg/dL = milligrams per deciliter; mm Hg = millimeters mercury; TC = total cholesterol; TG = triglycerides.

Twenty-two trials used nonstandardized preparations or preparations in which standardization was unclear (Evidence Table 2). ^30^ ^34^ ^35^ ^36^ ^40^ ^64^ ^70^ ^71^ ^72^ ^73^ ^74^ ^77^ ^83^ ^94^ ^95^ ^96^ ^97^ ^98^ ^99^ ^100^ Three trials used garlic ether extracts; ^34^ ^71^ ^72^ four used "aged garlic extract^TM^" ^30^ ^77^ ^94^ one used cold-pressed garlic oil; ^36^ two used raw or fried garlic; ^35^ ^74^ one used "a garlic oil;" ^83^ one used a steam-distilled, enteric-coated, beta-cyclodextrin-bound garlic oil preparation; ^95^ two used "dried garlic tablets;" ^96^ two used a "spray-dried garlic" preparation; ^40^ ^73^ and five used combination products of garlic with other substances such as fish oil, ginkgo, soya, and hawthorn. ^70^ ^97^ ^98^ ^99^ ^100^ Although some authors equated different garlic preparations to equivalencies of whole or "fresh garlic," processes such as alcohol extraction, steam distillation, and aging may liberate constituents not present in fresh or whole garlic, making such comparisons meaningless. Thus, dosages in Evidence Table 2 are given only in terms of individual preparations that were used in each study.

### Quality of the Trials

Numbers of participants in studies were fewer than 100 except for six studies that had sample sizes ranging from 100 to 432. ^47^ ^70^ ^71^ ^88^ ^89^ ^100^ Descriptions of randomization processes were scant; two studies clearly defined methods that were used to assure concealed allocation. ^47^ ^78^ It was unclear if two trials were actually randomized. ^71^ ^72^ Attempts to clarify randomization processes with the author were unsuccessful. In 12 trials, there was no mention of baseline equivalency between groups for lipids or other important parameters, ^30^ ^34^ ^35^ ^36^ ^37^ ^39^ ^70^ ^71^ ^72^ ^74^ ^82^ ^84^ while 7 reported minor differences in baseline lipids, ^24^ ^38^ ^40^ ^75^ ^76^ ^86^ ^90^ 2 in gender ratios, ^81^ ^83^ 1 in systolic blood pressure, ^83^ and 1 in alcohol consumption and activity level. ^91^ Five trials specifically conducted intention-to-treat analyses or had no dropouts. ^47^ ^85^ ^96^ ^97^ ^98^

Eleven trials were either not designed as double-blind studies or failed to state clearly whether blinding was attempted. ^30^ ^35^ ^38^ ^71^ ^72^ ^74^ ^76^ ^83^ ^84^ ^97^ Three trials specifically used a placebo with a garlic odor. ^36^ ^64^ ^95^ Of 28 trials with reported dropout rates, 4 were equal to or greater than 20 percent. ^69^ ^73^ ^88^ ^94^ Compliance with prescribed therapy was reportedly assessed in 18 trials; ^24^ ^30^ ^47^ ^64^ ^69^ ^70^ ^78^ ^79^ ^82^ ^83^ ^86^ ^88^ ^90^ ^93^ ^94^ ^95^ ^96^ results of this assessment were not given in 4. ^24^ ^70^ ^82^ ^88^ In one trial, 20 percent of participants were excluded from the statistical analysis due to "insufficient" compliance. ^69^ Compliance that was less than 80 percent during the intervention period was reported in three trials (i.e., 72 percent, 51 percent of garlic recipients less than 75 percent compliant, and 53 percent of garlic recipients less than 80 percent compliant). ^47^ ^90^ ^94^ Some trials only reported within-group differences or reported statistically significant differences between groups that we were not able to replicate or verify. ^69^ ^71^ ^87^ ^94^ The authenticity of one trial has been challenged because of concerns about the ultrasound pictures accompanying the published text, the randomization process, and the high dropout rate without intention-to-treat analyses. ^88^ ^101^

Dietary or activity recommendations were included in several trial protocols. Seven reported no changes in diet during the trial, ^64^ ^77^ ^79^ ^80^ ^90^ ^93^ ^95^ 1 reported decreases in fat intake in the garlic group compared with the placebo group, ^78^ 12 reported no changes in body mass or weight, ^24^ ^34^ ^64^ ^77^ ^79^ ^80^ ^82^ ^86^ ^92^ ^93^ ^95^ ^99^ and 2 reported that activity did not change. ^64^ ^90^ Dissolution standards of the garlic preparations and lots that were used in the trials were rarely reported. ^78^

### Clinical Outcomes

#### Antilipidemic Effects

Of the 45 randomized trials, 44 evaluated the effectiveness of garlic preparations on various serum lipid endpoints. Five evaluated combination preparations of garlic with either fish oil, hawthorn, or ginkgo biloba. ^70^ ^97^ ^98^ ^99^ ^100^ Placebos were used as comparisons except in the following instances: a "no garlic" control, ^35^ an antilipidemic agent, ^85^ an antihypertensive agent, ^38^ Kwai^®^ plus an antihypertensive agent versus an antihypertensive agent only, ^37^ and a head-to-head comparison of two different garlic preparations. ^83^

Ten studies specified low-fat, low-cholesterol, high-fiber diets for participants. ^47^ ^80^ One study was conducted under "dietary extremes during Christmas holiday season" with, presumably, high fat and caloric intakes. ^99^ Another gave participants 100 g of butter to test effects of garlic on postprandial lipid influences. ^91^ Other studies defined no specific dietary measures and generally allowed "usual diets."

Because of significant variability in lipid measurement, strict standards of measurement have been suggested. Ideally, weight and diet should be stable for more than 2 weeks, repeat measurements should be used to establish a baseline mean, and some measurements, such as triglycerides, should be obtained after at least a 12-hour fast. LDL should be calculated when possible using the Friedewald equation. Trials of garlic used various lipid measurement protocols; a few followed the suggested stringent guidelines. ^47^ ^64^ ^77^ ^78^ ^80^ ^86^

#### Trial Results

One multicenter trial involving 98 adults with hyperlipidemia found no differences in lipid outcomes at 3 months between persons given an antilipidemic agent (bezafibrate) and persons given a standardized dehydrated garlic preparation (Kwai^®^). ^85^ The trial that compared a garlic fish oil combination with placebo reported decreases in total cholesterol with active therapy that were of greater magnitude than reductions of most other trials and that were statistically significant. ^97^ The single head-to-head comparison of a standardized dehydrated preparation (Kwai^®^) with garlic oil (Hoefels Original Garlic Oil^®^) was an open trial that did not attempt blinding. ^83^ This trial found no significant differences between the two preparations in total cholesterol or HDL measurements at 1, 2, 3, and 4 months. A statistically significant reduction in low density lipoprotein cholesterol (LDL-C) favoring Kwai^®^over Original Garlic Oil was found at 4-month, but not 2-month, followup observations.

Meta-analyses of other trials that were placebo controlled and that reported total cholesterol outcomes at 4 to 6 weeks, 8 to 12 weeks, and 20 to 24 weeks were conducted. (Of note, the study by Kandziora that compared garlic plus an antihypertensive agent with antihypertensive therapy alone is included in some of the analyses.) Prior to conducting meta-analyses, examination of Galbraith and funnel plots as well as statistical testing for heterogeneity identified some trials with outlier results (Figures 3-8). Review of the design and protocol characteristics of such trials did not elucidate obvious systematic differences that could explain their outlier status. Quantitative analyses were performed with and without outliers. Results are described below for analyses without the outlier studies. (Including the outliers yielded slightly different effect sizes that were in the same direction and usually of the same statistical significance as the results that excluded the outliers.)

Figure 4. Funnel plot of studies with total cholesterol results at 4 to 6 weeks.

Figure 5. Galbraith plot of studies with total cholesterol results at 8 to 12 weeks

Figure 6. Funnel plot of studies with total cholesterol results at 8 to 12 weeks

Figure 7. Galbraith plot of studies with total cholesterol results at 20 to 24 weeks

Figure 3. Galbraith plot of studies with total cholesterol results at 4 to 6 weeks

Figure 8. Funnel plot of studies with total cholesterol results at 20 to 24 weeks

Figure 9 shows results of meta-analyses for trials reporting total cholesterol outcomes at 4 to 6 weeks. Combining all studies, regardless of preparation type, statistically showed that garlic preparations compared with placebo significantly reduced total cholesterol levels on average by 7.2 mg/dL (95 percent confidence interval [CI] 1.2 to 13.2 mg/dL). Combining only studies that used standardized dehydrated garlic preparations showed average reductions of 10.2 mg/dL (95 percent CI 3.1 to 17.3 mg/dL). A few studies that reported outcomes at 4 to 6 weeks could not be included in the figure or meta-analyses. Two studies reported that garlic significantly decreased cholesterol. ^36^ ^82^

Figure 9. Forest plot of studies with total cholesterol results at 4 to 6 weeks

Figure 10 gives total cholesterol results at 8 to 12 weeks. Combining all studies, regardless of preparation type, statistically showed that garlic preparations compared with placebo significantly reduced total cholesterol levels on average by 17.1 mg/dL (95 percent CI 12.4 to 21.9 mg/dL). Combining only studies that used standardized dehydrated garlic preparations showed average reductions of 19.2 mg/dL (95 percent CI 13.0 to 25.4 mg/dL). Of note, one 12-week study that is not shown in the figure stated that "garlic tablets (Kwai^®^) led to a marginal fall in total cholesterol at 6 weeks that was not sustained at 12 weeks." ^84^

Figure 10. Forest plot of studies with total cholesterol results at 8 to 12 weeks

Figure 11 shows results of the eight trials that reported total cholesterol outcomes at 20 to 24 weeks. Average reductions with garlic preparations compared with placebo at this time point were not significant (1.2 mg/dL, 95 percent CI --8.2 to 10.7 mg/dL). Limiting this analysis to the three 6-month studies that compared standardized dehydrated garlic preparations with placebo also was not significant (2.8 mg/dL, 95 percent CI -8.7 to 14.4 mg/dL) (Figure 11). Removing Koscielny's study from these analyses because of its questioned authenticity yields a larger but still nonsignificant effect. The statistical significance of these analyses should be interpreted cautiously because of few studies and low power. One additional trial that was not shown in the figure reported that total cholesterol decreased significantly after 3 years of followup in postinfarction patients who were given 6 to 10 g of garlic ether extract compared with patients given placebo (reported total cholesterol changes: 6.85 to 6.21 mmol with garlic and "no change" with placebo). ^71^

Figure 11. Forest plot of studies with total cholesterol results at 20 to 24 weeks

Figure 12 shows the total cholesterol summary results for the different time periods. Observed reductions at 4 to 6 weeks appear smaller than observed reductions at 8 to 12 weeks, but not smaller than reductions at 20 to 24 weeks. It is not clear whether these observations are due to systematic differences among studies that have longer and shorter followup durations or are due to time-dependent effects of garlic. For example, there were few long-term studies; longer studies had higher dropout rates, and longer studies may have used preparations of Kwai^®^ that had lower allicin-release properties. Observations depicted in Figure 12 also suggest, but do not prove, that standardized dehydrated preparations may result in greater short-term (4- to 12-week) total cholesterol reductions than other preparations.

Figure 12. Forest plot of pooled results of total cholesterol findings at different time periods

LDL reductions at 8 to 12 weeks for "all studies regardless of preparation type compared with placebo (n=13)" and for "dehydrated preparation studies only compared with placebo (n=10)" were 6.2 mg/dL (95 percent CI 0.8 to 11.7 mg/dL) and 6.7 mg/dL (95 percent CI 0 to 13.5 mg/dL), respectively. Triglyceride reductions at 8 to 12 weeks for "all studies regardless of preparation type compared with placebo (n=17)" and for "dehydrated preparation studies only compared with placebo (n=13)" were 19.1 mg/dL (95 percent CI 7.6 to 30.4 mg/dL) and 21.1 mg/dL (95 percent CI 8.3 to 34.0 mg/dL), respectively. None of the analyses regarding HDL values were statistically significant, possibly because few studies reported HDL. At 8 to 12 weeks, the average HDL reduction for "all garlic preparations compared with placebo (n=14)" was 0.9 mg/dL (95 percent CI --1.0 to 2.8 mg/dL), and for "standardized dehydrated preparations only compared with placebo (n=10)" was 0.2 mg/dL (95 percent CI --2.1 to 2.4 mg/dL). LDL, triglyceride, and HDL analyses are given in Appendix A.

Sensitivity analyses that were limited to trials that specifically included only participants with hyperlipidemia did not vary significantly from those presented above. (Few trials had normal mean values of total cholesterol at baseline; thus, few were excluded in this sensitivity analyses.) Finally, sensitivity analyses that excluded studies that were not designed as double blind were not different than the analyses presented above.

#### Antihypertensive Effects

Thirty trials reported protocols that included blood pressure measurement. ^24^ ^36^ ^37^ ^38^ ^39^ ^64^ ^69^ ^70^ ^71^ ^75^ ^77^ ^78^ ^79^ ^80^ ^81^ ^83^ ^84^ ^85^ ^86^ ^87^ ^88^ ^89^ ^90^ ^92^ ^93^ ^94^ ^96^ ^98^ ^100^ Two did not comment on blood pressure results. ^88^ ^89^ Baseline blood pressures and outcomes from the 27 trials that reported results are listed in Evidence Table 3. Nineteen of the trials tested standardized dehydrated garlic preparations. ^24^ ^39^ ^64^ ^69^ ^75^ ^79^ ^80^ ^81^ ^83^ ^85^ ^86^ ^87^ ^88^ ^89^ ^90^ ^92^ ^93^ ^93^ All except four used placebo controls: Holzgartner compared garlic with an antilipidemic agent, ^85^ Kandziora compared garlic with an antihypertensive agent (a reserpine-diuretic combination), ^38^ Kandziora used an antihypertensive cointervention in both the garlic and control group with no placebo addition in the control group, ^37^ and de Santos compared the dehydrated preparation with a garlic oil preparation. ^83^

Participants in the studies were sometimes prescribed antilipidemic diets, ^78^ ^80^ ^81^ ^85^ ^86^ ^90^ ^94^ or physical activity. ^69^ Both trials with antihypertensive regimens specifically excluded participants from taking other antihypertensive medications. ^37^ ^38^ Seven trials precluded use of antihypertensive agents. ^64^ ^70^ ^78^ ^79^ ^81^ ^83^ ^87^

Initial blood pressures of participants were variable. In 14 trials, participants were normotensive. Six trials included normotensive and hypertensive participants; mean baseline blood pressures ranged from systolic pressures of 140 to 165 mmHg and/or diastolic pressures of 85 to 100 mmHg. ^36^ ^75^ ^81^ ^83^ ^85^ ^98^ Three studies specifically evaluated hypertensive patients, and one studied patients with atherosclerotic peripheral vascular disease. ^37^ ^38^ ^39^ ^70^ Average baseline blood pressures in these four trials ranged from systolic pressures of 170 to 180 millimeters of mercury (mm Hg) and diastolic pressures of 99 to 102 mm Hg.

#### Trial Results

Several trials reported significant reductions in blood pressure in participants given garlic at 10-- to 13--week followup times (within-group comparisons). However, our comparisons between groups showed that only three trials demonstrated statistically significant reductions in blood pressure with garlic compared with placebo. ^39^ ^75^ ^79^ Three showed small statistically significant reductions in diastolic blood pressure that ranged from 2 to 7 percent. ^39^ ^75^ ^79^ One showed small statistically significant reductions in systolic blood pressure of approximately 3 percent. ^79^ Other trials showed no statistically significant differences in blood pressure between participants assigned to garlic and those assigned to placebo. ^37^ ^38^ ^64^ ^69^ ^70^ ^78^ ^80^ ^81^ ^84^ ^85^ ^90^ ^92^ ^94^ ^96^ ^98^ Of note, these data were not pooled because half of the studies did not present numerical data that could be used in a quantitative analysis, multiple different methods of blood pressure measurement were used, and few studies had a priori hypotheses related to blood pressure.

Three trials, which did not specifically study hypertensive participants, reported blood pressure outcomes at 5 to 6 months. ^77^ ^81^ ^94^ One of these trials found that a standardized, dehydrated tablet preparation (Kwai^®^) reduced systolic (by 22 mm Hg) and diastolic blood pressures (by 11 mm Hg) significantly more than placebo. ^81^ Another reported that "aged garlic extract^TM^" significantly reduced systolic and diastolic blood pressures compared with placebo, but our analyses using adjusted values derived from the reported baseline figures and followup values from the crossover point did not confirm statistically significant diastolic differences in favor of garlic. ^94^ A third trial reported that "aged garlic extract^TM^" did not significantly reduce systolic or diastolic blood pressures more than placebo. ^77^ The 3-year trial in postinfarction patients reported that blood pressure levels at followup were "significantly lower" in participants given garlic compared with those given placebo, but actual values were not given. ^71^

Analyses adjusting for baseline differences of the trial that compared different preparations of garlic found that the standardized dehydrated preparation (Kwai^®^) led to statistically significant greater reductions in systolic and diastolic blood pressures compared with the oil preparation (Hoefels Original Garlic Oil^®^) at 1-, 2-, 3-, and 4-month followup periods. ^83^ There were no statistically significant differences in blood pressure between groups at 4- and 12-week followup points in the study with hypertensive subjects that compared dehydrated garlic with an antihypertensive agent. ^38^ The trial with hypertensive subjects that compared garlic with no garlic in patients who were given an antihypertensive agent also found no significant differences in blood pressure between groups. ^37^

#### Antiglycemic Effects

Twelve trials assessed the effect of garlic supplementation on serum glucose concentration (Evidence Table 4). ^24^ ^37^ ^38^ ^39^ ^70^ ^72^ ^73^ ^84^ ^87^ ^88^ ^96^ Two of the trials considered glucose a primary outcome; ^73^ ^84^ one included glycosylated hemoglobin outcomes; ^84^ one addressed the responsiveness of serum insulin concentration to oral glucose tolerance testing in patients treated with garlic; ^73^ and another included serum insulin and C peptide results. ^84^

Participant characteristics in the trials with glucose outcomes were quite variable. Two trials studied adults with diabetes. ^73^ ^84^ Three followed participants with a known atherosclerotic disease process such as coronary or peripheral arterial occlusive disease. ^70^ ^72^ ^88^ Three had participants with hypertension, ^37^ ^38^ ^39^ and two had participants with high serum lipids. ^37^ ^38^ No trials assessed changes in diet or activity level between the groups. Four reported equivalent body masses of patients at baseline, but only one reported that there were no changes in body mass between the groups at the end of the intervention. ^24^

#### Trial Results

One study reported a statistically significant benefit in serum glucose lowering from garlic supplementation that was not found in the control group. ^87^ This trial studied 60 patients with baseline elevated spontaneous platelet aggregation values and measured serum glucose as a secondary endpoint over 4 weeks of study. Baseline serum glucose was 89.0 mg/dL. No other studies reported significant effects of garlic on glucose. No significant changes in postprandial insulin levels, glycosylated hemoglobin, or C peptide were reported. ^73^ ^84^

#### Antithrombotic Effects

Ten trials assessed the effectiveness of oral garlic supplementation on potential prothrombotic risk factors (Evidence Table 5). ^36^ ^69^ ^70^ ^72^ ^74^ ^87^ ^88^ ^90^ ^96^ ^102^ Four used standardized dehydrated garlic preparations. ^69^ ^87^ ^88^ ^90^ All except one, which used no treatment in the control group, ^74^ compared garlic supplementation with placebo controls. Results were reported in all but one of the publications, ^88^ amounting to a cumulative database of only 409 patients.

##### Spontaneous platelet aggregation

Five trials lasting at least 4 weeks measured the effects of garlic consumption on platelet aggregation; four trials provided results. ^36^ ^69^ ^70^ ^87^ ^102^ In two of these trials, Kiesewetter reported statistically significant reductions in platelet aggregation with a standardized dehydrated garlic preparation (Kwai^®^) compared with placebo. One of Kiesewetter's trials involved persons with known elevations of spontaneous platelet aggregation and a followup period of 4 weeks. ^87^ The other trial involved patients with lower extremity peripheral arterial occlusive disease who were followed for 12 weeks. ^69^ Another study in healthy Canadian volunteers reported a 16.4 percent reduction in platelet aggregation after 4 weeks of daily supplementation with cold pressed garlic compared with a 5.6 percent increase in the placebo group. ^36^ Czerny's trial involved patients with hyperlipidemia, peripheral vascular disease, and claudication who were followed for 16 weeks. ^70^ Outcomes were measured as the increase in added adenosine diphosphate (ADP) required to aggregate platelets. A 46 percent reduction in aggregation in the treatment group after 16 weeks compared with a 7 percent increase in the placebo group was found. A 6-month trial assessed platelet aggregation in a subgroup of 15 participants from a larger trial of 52 participants. ^102^ "Aged garlic extract^TM^" compared with placebo did not have statistically significant effects on ADP-induced aggregation, but it did significantly decrease epinephrine-induced platelet aggregation.

##### Fibrinolytic activity

Three trials assessed changes in fibrinolytic activity. Two were performed in Indian patients with preexisting coronary artery disease. ^72^ ^74^ In one, Bordia reported that garlic oil ethyl acetate extract compared with placebo significantly increased fibrinolytic activity at 6- and 12-week followup points. ^72^ In the other, Chutani reported that both raw and fried garlic preparations given in 3 g of butter compared with no garlic resulted in increased fibrinolytic activity at 4 weeks. ^74^ The third trial assessed effects of a nonstandardized dehydrated tablet in German patients with type IIa, IIb, or IV hyperlipoproteinemia. ^96^ This crossover trial with therapy periods of 6 weeks reported "no significant change" in either the garlic or placebo groups.

##### Serum fibrinogen levels

None of four trials reported any significant change in this endpoint. ^72^ ^87^ ^90^ ^96^

##### Plasma viscosity

Changes in plasma viscosity following supplementation with a standardized dehydrated tablet were assessed in three trials. ^69^ ^87^ ^88^ One did not report viscosity results. ^88^ The remaining two trials were performed on German participants by the same investigators. One 4-week trial reported that Kwai^®^ was associated with a statistically significant reduction in viscosity that was not reproduced in the placebo group, but estimates of between-group differences were not statistically significant. ^87^ The second trial reported that Kwai^®^ statistically reduced viscosity significantly more than placebo at 12 weeks.

#### Effects of Garlic on Morbidity and Mortality

Of three trials with clinical endpoints, two assessed improvement in pain-free walking distances. ^69^ ^70^ Kiesewetter evaluated 80 patients with cardiovascular risk factors and stage II peripheral vascular occlusive disease of the lower extremities (femoral, popliteal, or tibial occlusive disease more than 60 percent). ^69^ All participants received 90 minutes of supervised physical therapy per week and were randomized to standardized dehydrated garlic or placebo. They were followed for 12 weeks. Treatment and placebo groups were comparable in their consumption of antilipidemic, antihypertensive, antidiabetic, and other cardiac drugs. Outcomes were assessed in 64 patients who completed the study. Attrition was 20 percent in each group; 10 percent of the treatment group dropped out due to intolerance of garlic odor. Pain-free walking from baseline increased by approximately 40 meters in the treatment group compared with approximately 30 meters in the placebo group. Although the authors reported these as significant differences, our analyses showed that the differences were not statistically significant. The authors apparently compared shorter walking distances obtained during a run-in period with distances obtained at 12 weeks, while we compared longer distances obtained at baseline when randomization occurred with those obtained at followup.

Czerny assessed pain-free treadmill walking distance in 100 patients with "arteriosclerotic dependent illnesses such as phase II intermittent claudication." ^70^ Participants were randomized to 4 months of supplementation with a garlic oil macerate/soya lecithin/hawthorn oil/wheat germ oil combination or placebo. No attrition was reported in either group. Maximum walking distance increased significantly in the treatment group (114 percent) compared with the placebo group (17 percent) (p<0.05). Whether soya lecithin, hawthorn oil, or wheat germ oil have independent effects on walking distance could not be evaluated.

Bordia addressed reinfarction rates in 432 patients who had sustained prior myocardial infarctions. ^71^ Recruitment setting, method of diagnosis of infarction, and time between prior infarct and randomization were not clear. Despite contacting this author repeatedly, we were unable to verify the randomization process and any blinding methods. Baseline health characteristics were reportedly equivalent between groups, and all participants received "standard medical therapy" for postinfarction patients. Compliance, adverse effects, and dropouts were not reported. At the 3-year followup, the author reported 11 deaths and 15 reinfarctions in the 222 participants randomized to garlic (0.1 gram per kilogram per day [g/kg/d]) and 20 deaths and 22 reinfarctions in the 210 placebo recipients. Although the author reported significant differences, when data between groups were analyzed with a chi-square test, there were no statistically significant differences in total mortality (p=0.07) or myocardial infarction (p=0.13).

#### Atherosclerotic Plaque Regression

Regression of atherosclerotic plaque volume and intimal-medial plaque thickness as estimated by B-mode ultrasound of carotid and femoral arteries was assessed in one trial. ^88^ Two hundred eighty patients with atherosclerotic risk factors and advanced, but not flow-limiting, stenoses were treated with standardized dehydrated garlic tablets (Kwai^®^) or placebo over 48 months. Baseline risk factors, plaque localization, average plaque volume, and gender ratio were matched at baseline. However, women assigned to placebo were younger than those assigned to garlic: 39 percent in the placebo group were 45 to 55 years old compared with only 9 percent in the garlic group. Results were given for the 152 (91 placebo and 61 garlic) persons who completed all 4 years of the trial (46 percent attrition). Mean plaque volume decreased 2.6 percent with garlic and increased 15.6 percent with placebo (p<0.0001 for difference between groups). The progression of plaque volume in women in the placebo group (53 percent increase over 4 years) was significantly greater than any other group (p<0.0001). The difference between garlic- and placebo-treated men over the course of the study was 4.4 percent favoring garlic treatment (p<0.0001). (Of note, the authenticity of this trial has been challenged because of questions about the legitimacy of the ultrasound figures that accompanied the publication and because of the high unequal dropout rates that were not accounted for in the analysis. ^101^ ^103^ As of December 1999, these allegations were still under investigation.)

## Results: Associations With Cancer

One survey (analyzed as a case-control study), 10 case-control studies, and 2 case-cohort studies examined whether garlic consumption is associated with decreased incidence of precancerous lesions or cancer. ^55^ ^56^ ^59^ ^60^ ^61^ ^104^ ^105^ ^106^ ^107^ ^108^ ^109^ ^110^ ^111^ ^112^ ^113^ ^114^ ^115^ ^116^ ^117^ ^118^ One case-cohort study ^109^ examined associations with multiple cancers, including breast, ^106^ colorectal, ^108^ gastric, ^112^ and lung cancer. ^113^ Several other case-control studies evaluated associations of cancer with Allium vegetables such as onions and leeks or with mixtures of ingredients, but did not separately assess garlic associations. Such studies were not included in this report. ^58^ ^119^ ^120^ ^121^ ^122^ ^123^ ^124^ ^125^ ^126^ ^127^ ^128^ In addition, a Chinese survey that did not state the numbers of cases and controls was not included. ^129^ This survey reported that death from gastric cancer was lower in a county where garlic consumption was high compared with a neighboring county where garlic consumption was low. (Of note, we know of a relevant recently completed case-control study from Israel, but were unable to obtain analysis from this study as of December 30, 1999. In addition, we found an ongoing, but not yet reported, large trial in China that is evaluating effects of two garlic preparations on gastric precancerous lesions. ^130^ )

Two summary tables (Evidence Table 6 summarizes cancer, and Evidence Table 7 summarizes precancerous conditions) of the findings of the included studies follow. Descriptions of individual studies are then presented, followed by Evidence Table 8, which depicts individual studies.

### Laryngeal Cancer

A single, population-based, case-control study from Shanghai, China evaluated associations between garlic consumption and laryngeal cancer. ^116^ Of the 263 participants with laryngeal cancer who were identified from a population-based cancer registry, 201 (76 percent) were interviewed; 92 percent of these had histologically proven disease. Age- and gender-matched control participants were randomly selected from the general population. Of 414 interviewed control participants, 48 (12 percent) were chosen as "second controls" because initially selected controls had died or could not be located. Garlic exposure was assessed with a structured questionnaire that asked about the usual frequency and amount of consumption in the previous 10-year period, ignoring any recent changes. Whether interviewers were aware of participants' disease status was not stated. The odds ratios were adjusted for age, education, and smoking and used the lowest tertile of garlic consumption as the referent point. The odds ratio was 0.6 for the middle tertile of garlic consumption and 0.5 for the highest tertile. No CIs were given, but the test for trend was statistically significant (p=0.02).

### Breast Cancer

A large prospective cohort study, which began in 1986, on diet and cancer in The Netherlands assessed associations between the use of garlic supplements and breast cancer. ^106^ ^109^ The cohort of 120,852 men and women, age 55 to 69 years, originated from 204 population registries. Cancer followup was linked to pathology and cancer registries. Completeness of cancer followup for the first 3.3 years of the study was estimated to be 95 percent. Dietary history regarding the consumption of 150 food items in the year prior to the start of the study was assessed with a self-administered semiquantitative food-frequency questionnaire. Consumption of fresh garlic was not assessed in the baseline questionnaire; a later version of the questionnaire completed by a sample of the cohort in 1990 suggests that less than 2 percent of the participants consumed fresh garlic daily, while 13 percent consumed up to one clove per week.

Garlic supplement users were defined as persons who self-reported daily use of any garlic supplement for at least 1 year in the 5-year period before baseline. Recall was estimated to be 78 percent accurate. Types and brands of garlic supplements were not reported. (Of note, Lawson analyzed 23 brands and 4 types [powder tablets, gel-suspended powder capsules, steam-distilled oil capsules, and oil macerate capsules] of European supplements that were available in the late 1980s. Marked variation in allicin yields, allyl sulfide content, and sulfur compounds were found.) ^131^

After 3.3 years of followup, a case-cohort analysis was performed that assessed whether garlic consumption was associated with incident primary breast cancer that had been microscopically confirmed in 469 women. The comparison group, consisting of 1,716 women, was a randomly selected subcohort from the original cohort sample. Persons with prevalent cancer other than skin cancer, in situ breast cancer, or breast cancer other than carcinoma (sarcoma, lymphoma, or unspecified morphology) were excluded from analyses.

Multivariable analyses were adjusted for age, parity, age at menarche, age at first birth, age at menopause, artificially induced menopause, oral contraceptive use, history of benign breast disease, breast cancer in the mother, breast cancer in sisters, alcohol consumption, Quetelet index, highest level of personal education, smoking status, and dietary intake of vitamin C and β-carotene. Using persons who denied any supplement use as the reference, the following adjusted rate ratios were found: garlic supplement use with or without use of other supplements was 0.87 (95 percent CI 0.58 to 1.31) and garlic supplement use only without any other supplement use was 0.75 (95 percent CI 0.41 to 1.38).

A hospital-based, case-control study examined 107 incident, histologically confirmed cases of breast cancer. ^115^ Case participants were women younger than 76 years old who were admitted or referred to a hospital in Lausanne, Switzerland. Cases were linked to incidence data from the Vaud Cancer Registry. The hospital control participants were 318 women with admission diagnoses unrelated to known or suspected risk factors for breast cancer. Specifically, women with breast, gynecological, hormonal, metabolic, or neoplastic disease were excluded. Most case participants were admitted for trauma (30 percent) or surgical conditions (30 percent). Less than 15 percent of the persons who were approached for interview refused. Garlic exposure was assessed with a self-reported subjective score that assessed the general weekly level of intake. Serving size was not reported. The odds ratios given for garlic were adjusted for age and used the lowest tertile of garlic consumption as the referent point. The odds ratio was 0.7 for the middle tertile of use and 0.6 for the highest tertile. CIs were not given, and the chi-square test for trend was negative.

### Lung Cancer

The Netherlands cohort study, previously described, also examined associations between garlic supplement use and lung cancer after 3.3 years of followup. ^113^ This case-cohort analysis involved 484 cases of microscopically confirmed incident lung carcinoma and 3,123 randomly sampled subcohort members. No participants had other prevalent cancers (except for skin cancer), in situ lung carcinoma, or lung cancer other than carcinoma.

Multivariable analyses were adjusted for gender, age, pack years of past smoking, pack years of current smoking, highest educational level, history of obstructive lung disease, onion and leek consumption, and dietary intake of vitamin C and β-carotene. Using persons who denied any supplement use as the reference, the following adjusted rate ratios were found: garlic supplement use with or without use of other supplements was 1.22 (95 percent CI 0.81 to 1.86) and garlic supplement use exclusive of other supplements was 1.78 (95 percent CI 1.08 to 2.92). Using any other supplement use as the reference, adjusted rate ratios for garlic with or without other supplements was 0.92 (95 percent CI 0.46 to 1.86).

### Esophageal and Stomach/Gastric Cancer

Two case-control studies examined associations with esophageal cancer. ^117^ ^118^ One case-cohort study and three case-control studies examined associations with gastric carcinoma. ^56^ ^111^ ^112^ ^118^

#### Esophageal Cancer

A case-control study from the Jiangsu province of China involved 81 persons with histopathologically confirmed esophageal cancer who were identified from a regional cancer registry. ^118^ Population controls were randomly selected from the same villages as the cases. Initially, control selection was age and gender matched but later was only matched to nearest residence. Response rates of case and control participants were 100 percent. Garlic exposure was assessed using a structured interview-administered questionnaire that assessed the frequency of garlic consumption in six categories, ranging from every day to less than monthly or never. Serving size was not defined. Whether interviewers were aware of participants' disease status was not stated. Odds ratios were adjusted for age, gender, income, smoking and drinking status, tea consumption, and intake of leftover gruel, pickled vegetables, meat, fruit, tomatoes, eggs, and snap beans. The adjusted odds ratio for garlic consumption one to three times monthly compared with less than once monthly or none was 0.48 (95 percent CI 0.19 to 1.25). The ratio for consumption of garlic at least once weekly compared with less than once monthly or none was 0.30 (95 percent CI 0.19 to 0.47).

A case-control study from Iran involved 324 persons with esophageal cancer who were identified from the Caspian Cancer Registry. ^117^ Diagnoses were confirmed by histology (4 percent) and by radiology (71 percent). Population-based control participants were matched by age, gender, and village residence. Interview information was obtained for 54 percent of the registered patients with esophageal cancer; approximately one-fifth of the interviews were obtained from relatives because patients were too ill or had died. The response rate of selected control participants was not clear, although all control participants were interviewed directly. Interviewers appeared aware of the participants' disease status. A structured questionnaire was used to assess the "present" frequency of raw garlic consumption. Serving size was not defined. Odds ratios relating to garlic consumption were not adjusted for other factors. In men, the odds ratio of more than once monthly consumption of garlic compared with less than once monthly was 1.11 (95 percent CI 0.77 to 1.59). In women, the corresponding odds ratio was 0.80 (95 percent CI 0.51 to 1.27).

#### Stomach or Gastric Cancer

The case-cohort study examining associations with gastric cancer was from the first 3.3 years of followup in The Netherlands cohort study. ^112^ It involved 139 microscopically proven incident gastric carcinoma cases and 3,123 randomly sampled subcohort members. Risk ratios were adjusted for age, gender, smoking status, education, family history of stomach cancer, history of stomach disorders, vitamin C and β-carotene intake, and onion and leek consumption. Using persons who denied any garlic supplement use as the reference, the adjusted rate ratio for garlic supplement use exclusive of other supplements was 1.27 (95 percent CI 0.61 to 2.64). Using any other supplement use as the reference, the adjusted rate ratio was 1.28 (95 percent CI 0.45 to 3.66).

The first case-control study that evaluated associations with gastric cancer was the study described above from the Jiangsu province of China that assessed associations with esophageal cancer. ^118^ The study involved 153 persons with histopathological diagnosis of stomach cancer. Controls, response rates, and assessment of exposure were as described above. The adjusted odds ratio for garlic consumption one to three times monthly compared with less than once monthly was 0.40 (95 percent CI 0.21 to 0.76). The ratio for garlic consumption at least weekly compared with less than once monthly was 0.31 (95 percent CI 0.22 to 0.44).

The second case-control study involved 685 Chinese patients with stomach cancer who had been identified from 1984 to 1986 from a specially established reporting system involving county and commune hospitals in Linqu County. ^111^ Cancer diagnoses were established with histology (50 percent), surgery or endoscopy without histology (32 percent), and radiologic or clinical grounds (17 percent). Age- and gender-matched controls were 1,131 persons who were randomly selected from census rosters. Of the potentially eligible cases, 82 percent participated in the study. Only one person who was selected as a control refused participation. Garlic exposure was assessed using a food-frequency questionnaire that assessed consumption of garlic and garlic stalks "several years prior to the interview." Whether interviewers were aware of participants' disease status was not stated. Odds ratios were adjusted for age, sex, family economic situation, and intake of other Allium vegetables. Using no garlic consumption as the reference, the adjusted odds ratio for persons who reported consuming 0.1 to 1.5 kg of garlic annually was 0.8 (95 percent CI 0.5 to 1.2). Using the same reference, the adjusted odds ratio for persons who reported consuming greater than 1.5 kg of garlic annually was 0.7 (95 percent CI 0.4 to 1.0).

The third case-control study involved 1,016 Italian persons with histologically proven stomach cancer and 1,159 age- and gender-matched population controls. ^56^ Cases were identified from surgery and gastroenterology departments and outpatient gastroscopy services of private and public hospitals. Of the potentially eligible cases, 83 percent participated in the study. Of the potentially eligible controls, 77 percent participated. Initially, garlic exposure was assessed using a food-frequency questionnaire that assessed consumption of garlic and onions together. Persons were asked how much they consumed in a 12-month period approximately 2 years before the interview. During the last year of data collection, a question specific to garlic intake was added. Only 27 percent of the participants were asked this question. Whether interviewers were aware of participants' disease status was not stated. Odds ratios were adjusted for age, sex, resident and migration status, socioeconomic status, family history of gastric cancer, Quetelet index (weight/height squared), and consumption of other food items. Odds ratios related to consumption of raw garlic were not calculated because consumption was "too low for evaluation." Using the lowest tertile of cooked garlic consumption as the reference, the reported odds ratio was 0.6 for the middle tertile of consumers of cooked garlic and 0.4 for the highest tertile of consumers. The p value for trend was reportedly significant (p<0.001).

### Colorectal Cancer

Two case-cohort studies and one case-control study assessed associations between garlic and colorectal cancer. ^59^ ^60^ ^108^ The first case-cohort study was from the first 3.3 years of followup in The Netherlands cohort study. ^108^ It involved 293 microscopically proven incident colon carcinoma cases, 150 microscopically proven incident rectal carcinoma cases, and 3,123 randomly sampled subcohort members. Risk ratios were adjusted for age, gender, smoking status, education, family history of intestinal cancer, previous history of chronic intestinal disease, cholecystectomy, and dietary intake of vitamin C and β-carotene. Using persons who denied any garlic supplement use as the reference, the following adjusted rate ratios for colon carcinoma were found: garlic supplement use with or without use of other supplements was 1.26 (95 percent CI 0.84 to 1.91) and garlic supplement use exclusive of other supplements was 1.36 (95 percent CI 0.79 to 2.35). Using any other supplement use as the reference, the adjusted rate ratio for garlic with or without other supplements was 0.93 (95 percent CI 0.51 to 1.71). Using persons who denied any supplement use as the reference, the following adjusted rate ratios for rectal carcinoma were found: garlic supplement use with or without use of other supplements was 0.77 (95 percent CI 0.41 to 1.46) and garlic supplement use exclusive of other supplements was 1.28 (95 percent CI 0.63 to 2.60).

The second case-cohort study involved 41,837 women from Iowa, age 55 to 69 years. ^60^ Participants had completed a self-administered 127-item food-frequency questionnaire in 1986 and were monitored for cancer incidence for 5 years. Garlic consumption that was queried included fresh cloves or powdered preparations (shakes). A "serving" was defined as a commonly used portion size. Participants in the cohort were randomly selected from licensed drivers; 43 percent returned questionnaires. Pathologically confirmed incident colon cancer cases were identified from state and national registries. Persons with prevalent cancer other than skin cancer, calculated daily energy intakes of less than 600 kilocalories, and more than 30 missing items on questionnaires were excluded from all analyses. After applying these exclusion criteria, 80 percent of cases and 84 percent of noncases remained. Relative risks were adjusted for age and energy intake. (Relative risks that were adjusted for other factors, such as body mass index, physical activity, smoking, alcohol intake, and history of colitis or polyps, were reportedly similar to those adjusted only for age and energy intake.) Using persons denying any garlic intake as the reference, persons who reported consuming a half-serving per week had relative risks for proximal colon cancer of 1.32 (95 percent CI 0.79 to 2.22) and those consuming one or more servings per week had risks of 1.00 (95 percent CI 0.56 to 1.79). Using persons denying any garlic intake as the reference, persons who reported consuming a half-serving per week had relative risks for distal colon cancer of 0.85 (95 percent CI 0.53 to 1.36) and those consuming one or more servings per week had risks of 0.52 (95 percent CI 0.30 to 0.93). The chi-square test for trend for the protective association with distal colon cancer data was significant (p<0.05) for unadjusted, but not adjusted, analyses.

The case-control study involved 223 persons with histologically confirmed colon (n=119) or rectal (n=104) cancer who had been admitted to a Swiss hospital. ^59^ Controls were 491 patients who had been admitted to the same university hospital for a "wide spectrum of acute nonneoplastic conditions unrelated to long-term modifications of diet." Acute conditions included traumatic and nontraumatic orthopedic conditions (49 percent); surgical conditions (32 percent); and miscellaneous medical, ear, nose, and throat and skin diseases (19 percent). Numbers of eligible participants were not stated, but fewer than 15 percent of the persons who were approached for interview refused. Garlic exposure was assessed using a food-frequency questionnaire that assessed average weekly consumption during the 2 years before cancer diagnosis or hospital admission. Whether interviewers were aware of participants' disease status was not stated. Odds ratios were adjusted for age, sex, education, smoking, alcohol, body mass index, physical activity, and meat and vegetable intake. Using the lowest tertile of garlic consumers as the reference, the adjusted odds ratio for the middle tertile of garlic consumers was 0.50 (95 percent CI 0.34 to 0.74). The adjusted odds ratio for the highest tertile was 0.39 (95 percent CI 0.21 to 0.70). The chi-square test for trend was significant (p<0.01).

### Endometrial Cancer

A single case-control study examined 274 incident, histologically confirmed cases of endometrial cancer. ^114^ Case participants were recruited using a population-based cancer registry in Switzerland and hospital records in Northern Italy. Control participants were women who had been admitted to the same networks of hospitals in which cases had been identified. They had primary diagnoses unrelated to known or suspected risk factors for endometrial cancer or to any long-term modification in diet. Specifically, women with gynecological, hormonal, metabolic, or neoplastic disease or who had undergone hysterectomy were excluded. Most case participants were admitted for trauma (32 percent) or surgical conditions (26 percent). Less than 10 percent of the persons approached for interview refused. Garlic exposure was assessed with a self-reported subjective score that assessed general weekly level of intake; serving size was not reported. The odds ratios given for garlic were adjusted for age and study center and used the lowest tertile of garlic consumption as the reference. The odds ratio was 0.67 for the middle tertile of use and 0.71 for the highest tertile. CIs were not given, but the chi-square test for trend was positive (p<0.05).

### Prostate Cancer

One British case-control study involved 328 white men with prostate cancer who were diagnosed before age 75 years, and 328 age-matched population controls. ^61^ Of 425 eligible participants, 77 percent of those identified through histopathology or other laboratory records and cancer registries participated in dietary interviews. The response rate in the first selected controls was 81 percent. Garlic use was ascertained by a food-frequency questionnaire and by asking participants if they had regularly taken nutritional supplements during the last 5 years. The food-frequency questionnaire queried the usual frequency of consumption of standard portion sizes. Whether interviewers were aware of participants' disease status was not clear. Odds ratios were adjusted for social class. Using no consumption of garlic in the last 5 years as the reference, adjusted odds ratios were: 0.94 (95 percent CI 0.51 to 1.73) for consuming garlic less than once monthly; 0.77 (95 percent CI 0.49 to 1.20) for consuming garlic one to four times monthly; and 0.64 (95 percent CI 0.38 to 1.09) for consuming garlic at least twice weekly. The p value for trend was 0.13. Adjusted odds ratios examining garlic exposure from food plus supplements were similar to those examining exposure from food (within 0.05).

### Precancerous Lesions

One survey from a village of garlic farmers in China examined gastroscopy-proven precancerous lesions in 197 villagers who consumed various quantities of garlic. ^104^ Participating villagers represented 30 percent of the eligible population. Reasons for refusing participation were not given. Garlic consumption over an unspecified time period (presumably 1 year) was assessed by questionnaire; whether garlic intake referred mainly to raw garlic or various home preparations was not stated. Dietary interviews appeared to have occurred prior to knowledge of gastroscopy results. The small study found a statistically significant positive association between helicobacter pylori with histologically proven chronic atrophic gastritis and gastric metaplasia or dysplasia. Higher garlic consumption was not associated with statistically significant lower prevalence of helicobacter . Garlic consumption of 5 to 15 kg annually compared with 0 to 5 kg annually was associated with decreased, but not statistically significant, odds of chronic atrophic gastritis (odds ratio 0.70, 95 percent CI 0.21 to 2.30) and metaplasia/dysplasia (odds ratio 0.55, 95 percent CI 0.08 to 3.71).

A large age- and gender-matched case-control study from two Southern California Kaiser Permanente Medical Centers examined the associations between multiple vegetables, including garlic, and colorectal polyps. ^105^ All 976 study participants had screening sigmoidoscopies between 1991 and 1993; none had known invasive cancer, inflammatory bowel disease, or severe gastrointestinal symptoms. Approximately 80 percent of all eligible persons participated. Cases were defined as persons who had histologically confirmed adenomatous polyps, whereas controls were defined as persons who had no polyps at sigmoidoscopy and no history of polyps. Food consumption was assessed by a 126-item, semiquantitative, food-frequency questionnaire covering diet in the year before sigmoidoscopy. Serving size was not reported. The food interview was administered approximately 5 months after sigmoidoscopy; interviewers were unaware of the participants' disease status for 70 percent of the cases and 87 percent of the controls. Odds ratios were adjusted for race; body mass index; physical activity; smoking; calories; saturated fat; vitamin c, β-carotene, and folate intake; and dietary fiber. The adjusted odds ratio for colorectal polyps in persons reporting 0.5 "servings" of garlic per week compared with no garlic consumption was 0.92 (95 percent CI 0.64 to 1.34). Comparisons with persons reporting 1.0 to 2.5 servings per week and more than 3.0 servings per week were 0.98 (95 percent CI 0.61 to 1.56) and 0.66 (95 percent CI 0.43 to 1.01), respectively. A linear model assessing trend was statistically significant (p=0.01).

## Results: Adverse Effects of Garlic

In addition to the RCTs, 73 studies were found that addressed adverse effects. Most (97 percent) were case reports or small case series (Evidence Table 9). The literature reviewed gives a limited picture of adverse effects attributable to garlic for many reasons. First, searching for studies that report adverse effects is difficult. Many studies may mention adverse effects in passing, but do not use adverse effects as a key index word or in their abstracts. If these studies do not otherwise meet selection criteria in a review, they will be missed. Second, in most case reports and case series, adverse effects cannot be directly attributed to garlic because chance, coincidence, or confounding factors could have been responsible for the adverse effect. For example, alternative causes of reported adverse effects were possible in 22 percent of the reviewed studies and could not be excluded definitively in 69 percent. Third, case reports and case series may miss delayed adverse reactions because such associations are more difficult to make than those that occur immediately after garlic is administered. Fourth, although case reports and case series can provide qualitative information about the nature of an adverse effect, incidence cannot be estimated from such evidence. ^132^

### Garlic Breath or Body Odor

Five trials reported that statistically significant greater numbers of persons who were given standardized dehydrated tablets (Kwai^®^ or noncommercial enteric-coated preparation) had breath or body odor (as perceived by themselves or others) compared with persons given placebo. ^47^ ^78^ ^88^ ^89^ ^93^ Other trials reported that persons receiving dehydrated tablets (Kwai^®^) had smelly breath or body odor, but the trials had too few numbers to compare differences between garlic and placebo groups. ^24^ ^39^ ^64^ ^69^ ^86^ ^90^ ^93^ In one trial, some persons taking "aged garlic extract ^TM^" as well as some taking placebo reportedly perceived unusual body odor. ^94^ In another trial, participants taking steam distilled garlic and those taking placebos with coatings tasting like garlic reported garlic odor. ^95^ Neither of the latter studies reported numbers of participants with these adverse effects.

### Skin Manifestations

#### Contact Dermatitis

Fourteen reports describe the occurrence of contact dermatitis after topical application of garlic, and one describes this adverse effect after the oral administration of garlic tablets. Most reports involved people who continuously handled garlic during their work (e.g., cooks and workers in factories making sauces containing garlic), ^133^ ^134^ ^135^ ^136^ ^137^ ^138^ ^139^ ^140^ ^141^ ^142^ ^143^ ^144^ ^145^ ^146^ while three reports describe patients who used garlic temporarily, but for many consecutive hours (e.g., persons using garlic topical remedy for skin care). ^147^ ^148^ ^149^ Most studies reported improvement of skin lesions once exposure to garlic was discontinued, but formal rechallenge tests were not conducted. ^136^ ^138^ ^140^ ^144^ ^145^ ^146^ ^147^ ^149^ ^150^ Some studies gave possible alternative explanations other than garlic for skin manifestations. ^139^ ^141^ ^143^ ^148^ ^150^ Patch tests were sometimes used to help confirm the etiology of dermatitis. ^136^ ^137^ ^138^ ^141^ ^143^ ^147^ ^148^ Different types of patch tests were used. All patch-tested patients had positive reactions, although one patient had a negative patch test when weaker concentrations of aqueous extract and diallyl disulfide were used. Some patients had a positive reaction to fresh garlic, but not to garlic extract. ^148^

Several additional studies used patch tests with various potential allergens, including garlic, to examine the etiology of dermatitis or allergic disease. ^140^ ^151^ ^152^ ^153^ ^154^ ^155^ ^156^ ^157^ ^158^ ^159^ ^160^ ^161^ ^162^ ^163^ ^164^ These studies included persons with occupational dermatitis (e.g., food handlers, workers in a spice factory, etc.) ^140^ ^152^ ^153^ ^154^ ^155^ or patients with contact dermatitis who were referred to dermatology clinics. ^156^ ^157^ ^158^ ^159^ ^160^ ^161^ ^162^ ^163^ ^164^ Various patch tests with varying concentrations and preparations of garlic were used. Markedly varying incidence of skin test positivity was found across studies and within studies that used different types of patch tests (2.5 percent to 100 percent). Because patch tests with garlic are not standardized and their accuracy for establishing etiology are suspect, these studies do not clarify whether garlic is a common cause of dermatitis.

#### Ulcero-Necrotic Lesions, Skin Blisters, Bullae, and Vescicles

Eleven case reports describe patients with more severe skin lesions such as ulcero-necrotic lesions, blisters, bullae, erythematous rash, and pemphigus. ^165^ ^166^ ^167^ ^168^ ^169^ ^170^ ^171^ ^172^ ^173^ ^174^ ^175^ Three patients were children (6 months, 17 months, and 6 years of age). ^168^ ^169^ ^171^ Unlike reported cases of dermatitis where described garlic exposure was usually chronic, exposure to garlic was acute in these case reports. All but two cases used fresh garlic (poultice or crushed) that was directly applied to the skin as a remedy for different problems. Applications or exposures varied from 5 minutes to 24 hours; skin lesions appeared either during the application or within a few hours of removing the application. All lesions showed improvement once garlic application was discontinued, but some took 2 weeks or longer to heal. ^168^ ^169^ ^171^ No alternative cause of skin lesions other than garlic were noted. In one case, a 49-year-old man suffered from superficial pemphigus while consuming a garlic-rich diet. ^165^ The rash resolved on a garlic-free diet, and it recurred when the man unintentionally ate a garlic-spiced fish meal.

### Allergic Manifestations

In addition to the skin manifestations described above, other reported allergic reactions to garlic include: asthma, rhinitis, conjunctivitis, urticaria, anaphylaxis, and angioedema. Several case reports and two case series reported respiratory symptoms such as asthma and rhinitis. ^139^ ^160^ ^176^ ^177^ ^178^ ^179^ ^180^ ^181^ ^182^ ^183^ ^184^ ^185^ In almost all cases, the respiratory symptoms occurred after occupational chronic inhalation of garlic dust. Most patients had a delay of at least 5 years between the first exposure to garlic dust and the appearance of the symptoms. ^139^ ^182^ ^183^ ^184^ In one person, the exposure interval was 3 months, ^178^ and in another, respiratory symptoms were precedent to the chronic garlic exposure. ^181^

Diagnostic tests confirming the allergic etiology of respiratory symptoms, such as the prick test and bronchial challenge test, were usually positive for multiple allergens, including garlic. ^139^ ^160^ ^176^ ^177^ ^178^ ^181^ ^182^ ^183^ ^184^ In six of eight reports, symptoms were noted to improve once garlic exposure was discontinued, and to recur with rechallenge or new exposure. ^139^ ^178^ ^179^ ^180^ ^181^ ^184^ One report did not comment on resolution of symptoms, ^183^ and another noted symptoms improved after exposure to garlic was discontinued, but a bronchial challenge test was negative. ^182^ In this latter case, the prick test, radioallergosorbent test (RAST), and bronchial challenge test were positive for Tyrophagus putrescentiae , raising the possibility that asthma that is induced by garlic dust inhalation may be related to dust contaminants with other allergens such as storage mites.

Of the above reports addressing respiratory symptoms with chronic inhalation of garlic, three noted some persons complained of allergic symptoms after eating garlic. ^139^ ^183^ ^184^ Allergic symptoms included urticaria, asthma, angioedema, and anaphylaxis. A positive formal oral challenge test in one person with asthma and angioedema was reported. ^183^

There were two reports of persons without occupational exposure to garlic dust who had allergic reactions to garlic ingestion; ^186^ ^187^ the first person had recurrent episodes of systemic urticaria and angioedema following ingestion of foods containing both raw or cooked garlic. He also had a strong reaction on the skin prick test to commercial garlic extract and fresh garlic. The second person had nausea, diarrhea, dizziness, tachycardia, and Quicke's edema 4 hours after he ingested raw garlic. A scratch test was positive for lid edema.

We found three case series and a case report that included patients with suspected food allergy who were tested for garlic. ^188^ ^189^ ^190^ ^191^ In the first case series, 12 of 219 persons with suspected food allergy complained of itching, urticaria, and/or gastrointestinal symptoms after eating garlic. Seven of the 12 persons had increased Immunoglobulin E (IgE) for garlic, while only one reacted positively to a commercial extract skin prick test. In the second case series, 1 of 142 children with suspected food allergy had a positive skin prick test, specific serum IgE, and labial food challenge test for garlic. ^189^ The third case series described 580 persons who had been evaluated from 1984 to 1992 for food sensitization or allergy. The frequency of positive allergy tests for garlic in persons seen during different time periods was 13 percent from 1984 to 1986, 18 percent from 1987 to 1989, and 20 percent from 1984 to 1992. ^190^

### Coagulation Dysfunction

Four patients with bleeding following garlic ingestion have been described. ^24^ ^192^ ^193^ ^194^ None had received medication known to cause bleeding disorders. Spontaneous spinal epidural hematoma causing paraplegia was reported in a patient who consumed an average of four garlic cloves per day. ^192^ This patient had a prolonged bleeding time and normal prothrombin time, partial thromboplastin time, and platelet count. The prolonged bleeding time corrected within 1 week of presentation. "Significant" bloody oozing during an augmentation mammoplasty and a 200-cubic-centimeter postoperative hematoma was reported in a patient who retrospectively admitted to heavy garlic intake preoperatively. ^193^ This patient also had a prolonged bleeding time that normalized within 1 week. Significant bleeding during and after transurethral resection of the prostate was described in a man taking garlic tablets. ^194^ He had normal cephalin clotting time and prothrombin time at surgery. Platelet function studies that were obtained 3 months after he resumed his normal dose of garlic tablets showed a failure of platelet aggregation in the presence of collagen. Of note, one of the double-blind trials reports a participant with oozing on shaving. He was taking placebo.

Increased INR results have been reported in two patients who were previously stabilized on warfarin and were taking garlic pearls or tablets without changes to medication or other habits. ^195^ A small, unpublished double-blind trial that evaluated effects of "aged garlic extract^TM^" in patients who were stabilized on warfarin reportedly found no "extra bleeding" with garlic compared with placebo (personal communication from Kyolic^®^ representative).

### Cardiovascular Dysfunctions

An acute inferior myocardial infarction after excessive consumption of garlic was described in a 23-year-old man who had no risk factors for cardiovascular disease. ^196^ "Cardiospasm" was described in a 56-year-old man, with probable cutaneous sensitivity to macerated garlic, who was given an oral challenge of an unspecified amount of garlic. ^136^

### Gastrointestinal Dysfunctions

Mechanical bowel obstruction was described in a 66-year-old man who ate a whole garlic bulb for his cold-like symptoms. ^197^ A report of 309 patients with epigastric pain, hematemesis and/or hematochezia, and associated acute gastric mucosal lesions at endoscopy noted that some of the patients reported garlic ingestion prior to developing symptoms. ^198^ Five volunteers who were given 10 to 25 milliliters (ml) of garlic extract containing 100 to 250 g of hulled garlic cloves complained of burning sensations in the mouth, esophagus, and stomach that lasted less than 15 minutes. One of these volunteers, who was given 25 ml of extract, also experienced nausea, diaphoresis, and lightheadedness. ^199^ Other volunteers who were given 900 mg of garlic powder reported increased flatulence (n<10). ^200^ Several of the randomized trials reported that a few persons who were given standardized dehydrated tablets experienced abdominal pain, fullness, anorexia, or flatulence. ^64^ ^76^ ^78^ ^81^ ^86^ ^88^ ^89^ ^93^ As numbers were always very small, comparisons between persons given garlic and those given placebo were not made.

### Other Dysfunctions

One case report described a person with symptoms of Meniere's disease after consuming garlic. ^201^ A case-control study reported botulism in 36 persons who ate sandwiches made with garlic-buttered bread. The source was thought to be bottled chopped garlic in soybean oil that had been stored unrefrigerated for 8 months. ^202^

Garlic breath was reported "on more than one occasion" in newborn infants delivered to Pakistani mothers. ^203^ A randomized, placebo-controlled crossover trial evaluated whether effects of garlic consumption (1.5 g of garlic extract) in eight mothers altered infants' suckling behaviors. A change in the perceived intensity of breast milk odor was noted in each mother 2 hours after garlic ingestion. Infants attached to the breast for statistically significant longer periods of time, but their numbers of feeds and amounts of breast milk consumed did not increase when their mothers were given garlic compared with mothers who were given placebo. ^204^

### Beliefs About Garlic

A survey of 65 persons who were recruited at six supermarkets in Helsinki gave information about attitudes and beliefs that related to garlic. Most participants had positive health beliefs about garlic (62 percent). Positive health beliefs were related to frequent and heavy consumption of garlic. Survey participants perceived garlic odor as disturbing, but less offensive than many other odors. ^205^