# Appendix C. Acronyms and Abbreviations

ADP:adenosine diphosphate

ASA:acetyl-salicilic acid

BMI:body mass index

BP:blood pressure

°C:degrees Celsius

CI:95% confidence interval

Cr:crossover

CS:change score

D:diastolic measure

DBP:diastolic blood pressure

FA:fibrinolytic activity

g:gram

g/kg/d:grams per kilogram per day

HDL:high-density lipoprotein levels

IBIDS:International Bibliographic Information on Dietary Supplements

IgE:Immunoglobulin E

INR:International Normalized Ratio

kg:kilogram

LDL:low-density lipoprotein levels

M:mean measure

mcM:micromoles

mg:milligram

mg/dL:milligrams per deciliter

mg/g:milligrams per gram

mg/kg:milligrams per kilogram

ml:milliliter

mm Hg:millimeters Mercury

mmol/dL:millimoles per deciliter

mPas:millipascals

NCEP:National Cholesterol Education Program

OR:odds ratio

PA:platelet aggregation

PV:plasma viscosity

RCT:randomized controlled trial

RR:risk ratio

S:systolic measure

SAC:S-allylcysteine

SDstandard deviation

Sd:standing

SE:standard error of the mean

SF:serum fibrinogen

SH:serum homocysteine

Sp:suprine

St:sitting

TC:total cholesterol

TG:triglycerides

Uc:position unclear