# Appendix B. Contributors

We owe a major debt of gratitude to the following groups of multidisciplinary experts from around the world who assisted in preparing this report: 10 national advisory panel members and 5 technical experts who helped define the scope and shape the content, 20 peer reviewers representing a variety of backgrounds and viewpoints, and 4 scientific authors who provided additional data from their studies.

## National Advisory Panel

Marilyn Barrett, PhD Owner and Principal Pharmacognosy Consulting Services

Mark Blumenthal Executive Director American Botanical Council

David Eisenberg, MD Beth Israel Deaconess Medical Center

Lucinda Miller, PharmD, BCPS Editor Journal of Herbal Pharmacotherapy

Richard Nahin, MPH, PhD Acting Director Division of Extramural Research National Center for Complementary and Alternative Medicine

Mary Ann Richardson, DrPH Assistant Professor and Director The University of Texas -- Houston Health Science Center School of Public Health The University of Texas Center for Alternative Medicine Research in Cancer

Nancy Ridenour, RN, PhD, CS, FNC, FAAN Dean College of Nursing Illinois State University

David Schardt Associate Nutritionist Center for Science in the Public Interest

William A. Watson, PharmD, DABAT, FAACT Professor (Clinical) and Managing Director Department of Surgery South Texas Poison Center The University of Texas Health Science Center at San Antonio

Elizabeth Yetley, PhD Director Office of Special Nutritionals Center for Food Safety and Applied Nutrition Food and Drug Administration

## Technical Experts

Eric Block, PhD Professor Department of Chemistry State University of New York at Albany

Powel Brown, MD, PhD Associate Professor and Director Cancer Prevention Program Baylor Breast Center Baylor College of Medicine

Christopher Gardner, PhD Nutrition Specialist Center for Research in Disease Prevention Stanford University

Paul Heidenreich, MD, MS Assistant Professor Division of Cardiovascular Medicine Department of Medicine Stanford University Medical Center Palo Alto Veterans Affairs Health Care System

Nancy C. Russell, MPH Cancer Prevention Specialist The University of Texas MD Anderson Cancer Center

## Peer Reviewers

Twenty peer reviewers provided insightful comments and feedback on our draft report.

Harunobu Amagase, PhD Director Research and Development Wakunga of America Co., Ltd.

Terry Bazzarre, PhD Staff Scientist American Heart Association National Center

Heiner Berthold, MD, PhD Director Institute for Clinical Research Department of Clinical Pharmacology Center for Cardiovascular Diseases Rotenberg

Shah Ebrahim, MD Professor Department of Social Medicine University of Bristol

Robert Eckel, MD Professor Division of Endocrinology, Metabolism, and Diabetes Department of Medicine University of Colorado Health Science Center

Patricia Ganz, MD Professor Division of Cancer Prevention and Control Research Jonsson Comprehensive Cancer Center University of California at Los Angeles Schools of Medicine and Public Health

Eric Gershwin, MD Division Chief and Professor Division of Rheumatology/Allergy/Clinical Immunology Department of Internal Medicine University of California at Davis School of Medicine

Lee Hooper, BSc, SRD Sub-Editor Cochrane Heart Group

Elizabeth Jeffery, PhD Associate Professor Department of Food Science and Human Nutrition University of Illinois at Urbana-Champaign

Peter Josling, BSc Director Garlic Information Centre

Ruth Kava, PhD, RD Director of Nutrition American Council on Science and Health

Larry Lawson, PhD Research Scientist Murdock Madaus Schwabe

David Lee, PhD Director Natural Products Laboratory McLean Hospital

Klaus Linde, MD Researcher Centre for Complementary Medicine Research Department of Internal Medicine Technical University

Srini Srinivasan, PhD Director Dietary Supplements Division U. S. Pharmacopeia

Kathleen Stevens, RN, EdD, FAAN Professor Department of Family Nursing The University of Texas Health Science Center at San Antonio

Margaret Thorogood, MD Reader in Public Health and Preventative Medicine Department of Public Health and Policy London School of Hygiene and Tropical Medicine

Jeffrey White, MD Director Office of Cancer Complementary and Alternative Medicine National Cancer Institute National Institutes of Health

Christopher Williams, MD Coordinating Editor Cochrane Gynaecological Cancer Review Group Institute of Health Sciences

Wendell Winters, MD Associate Professor Department of Microbiology The University of Texas Health Science Center at San Antonio

## Authors Who Provided Additional Data

Some articles included in this report had relevant missing data from their publications. We contacted the authors requesting this information. Our heartfelt thanks to those who responded:

- Heiner K. Berthold, MD, PhD
- Jürgen Koscielny, MD, PhD
- Benjamin H.S. Lau, MD
- Christopher Gardner, PhD

## San Antonio Evidence-based Practice Center and Veterans Evidence-based Research, Dissemination, and Implementation Center Staff

### Project Leaders

Cynthia Mulrow, MD, MSc EPC Director

Valerie Lawrence, MD, MSc Principal Investigator

### Project Investigators

Ronald Ackermann, MD Laura Morbidoni, MD Christine Aguilar, MD, MPH Elaine Chiquette, PharmD Veronica Young, PharmD

### Meta-Analysts

Gilbert Ramirez, DrPH John E. Cornell, PhD

### Information Specialists

Andrew Vickers, MD (Consultant) Martha Harris, MLS, MA

### Technical Writer and Peer-Review Coordinator

Jennifer Arterburn, MTSC

### Computer Resources

David Mullins

### Administrative Support

Annie Almanza Linn Morgan