# Appendix A. Supplemental Figures

## Figure A-1. LDL, 8 to 12 weeks, Galbraith plot

[image]

## Figure A-2. LDL, 8 to 12 weeks, funnel plot

[image]

## Figure A-3. LDL, 8 to 12 weeks, forest plot

[image]

## Figure A-4. HDL, 8 to 12 weeks, Galbraith plot

[image]

## Figure A-5. HDL, 8 to 12 weeks, funnel plot

[image]

## Figure A-6. HDL, 8 to 12 weeks, forest plot

[image]

## Figure A-7. Triglyceride, 8 to 12 weeks, Galbraith plot

[image]

## Figure A-8. Triglyceride, 8 to 12 weeks, funnel plot

[image]

## Figure A-9. Triglyceride, 8 to 12 weeks, forest plot

[image]