# Appendixes

Appendix A. Supplemental Figures

Appendix B. Contributors

Appendix C. Acronyms and Abbreviations