# List of Abbreviations

ADL: Activities of daily living

AHCPR: Agency for Health Care Policy and Research

AIS: Abbreviated injury score

ANCOVA: Analysis of covariance

BVRT: Benton Visual Retention Test

CACR: Computer-aided cognitive rehabilitation

CCR: Compensatory cognitive rehabiliation

CFT: Complex Figure Test

CIQ: Community Integration Questionnaire

CT: Computerized tomography

D/C: Discharge

DRS: Disability rating scale

EMF: Everyday memory failure

EPC: Evidence-based Practice Center

FAM: Functional Adaptability Measure

FIM: Functional Independence Measure

GCS: Glasgow Coma Scale

GOS: Glasgow Outcomes Scale

HCFA: Health Care Financing Administration

ICP: Intracranial pressure

ILP: Independent living programs

ISS: Injury severity scale

KAS: Katz Adjustment Scale

LOS: Length of stay

MANOVA: Multivariable analysis of variance

MAR: Monthly activity ratio

MER: Monthly employment ratio

MMPI: Minnesota Multiphasic Personality Inventory

OHSU: Oregon Health Sciences University

OT: Occupational therapy

PAI: Portland Adaptability Inventory

PASAT: Paced Auditory Serial Addition Task

PT: Physical therapy

PTA: Post-traumatic amnesia

RBMT: Rivermead Behavioral Memory Test

RCR: Restorative cognitive rehabilitation

RCT: Randomized, controlled trial

RKE: Rabideau Kitchen Evaluation

RLA: Ranch Los Amigo

RLAS: Ruff Language Assessment Scale

RT: Reaction time

SRT: Selective Reminding Test

ST: Speech therapy

TBI: Traumatic brain injury

TCDB: Traumatic Coma Data Bank

TEP: Transitional employment program

TLT: Trail Learning Test

VerPa: Verbal Paired Associated Task

VisPa: Visual Paired Associates Task

WAIS: Wechser Adult Intelligence Scale

WMS: Wechser Memory Scale

WRP: Work reentry program