# References

Abrams D, Toms Barker L. Enhancing employment success for individuals with traumatic brain injury. Report to Social Security Administration by Sharp Rehabilitation Center, San Diego, CA 1991.
Alberico AM, Ward JD, Choi SC, et al. Outcome after severe head injury. Relationship to mass lesions, diffuse injury, and ICP course in pediatric and adult patients. J Neurosurg. 1987;67(5):648-56. [pmid: 3668633].
Andersen J, Sharkey W, Schwartz ML, et al. Injury severity score, head injury, and patient wait days: Contributions to extended trauma patient length of stay. J Trauma. 1992;33(2):219-20. [pmid: 1507284].
Anderson DC, Bundlie S, Rockswold GL. Multimodality evoked potentials in closed head trauma. Arch Neurol. 1984;41(4):369-74. [pmid: 6703937].
Annoni JM, Beer S, Kesselring J. Severe traumatic brain injury: Epidemiology and outcome after 3 years. Disabil Rehabil. 1992;14(1):23-6. [pmid: 1534029].
Aronow HU. Rehabilitation effectiveness with severe brain injury: Translating research into policy. J Head Trauma Rehabil. 1987;2(3):24-36.
Ashley MJ, Persel CS, Krych DK. Changes in reimbursement climate: Relationship among outcome, cost, and payor type in the postacute rehabilitation environment. J Head Trauma Rehabil. 1993;8(4):30-47.
Ashley MJL, Krych DK, Persel CS, et al. Post-acute rehabilitation outcome: Relationship to case-management techniques and strategy. J Ins Med. 1994;26 (3):348-54. [pmid: 10150511].
Asikainen I, Kaste M, Sarna S. Patients wtih with traumatic brain injury referred to a rehabilitation and re-employment programme: Social and professional outcome for 508 Finnish patients 5 or more years after injury. Brain Inj. 1996;10(12):883-99. [pmid: 8939307].
Basso A, Capitani E, Vignolo LA. Influence of rehabilitation on language skills in aphasic patients: A controlled study. Arch Neurol. 1979;36(4):190-6. [pmid: 426663].
Batchelor J, Shores EA, Marosszeky JE, et al. Cognitive rehabilitation of severely closed-head-injured patients using computer-assisted and noncomputerized treatment techniques. J Head Trauma Rehabil. 1988;3(3):78-85.
Ben-Yishay Y, Silver S, Plasetsky E, et al. Relationship between employability and vocational outcome after intensive holistic cognitive rehabilitation. J Head Trauma Rehabil. 1987;2(1):35-48.
Bergman TA, Rockswold GL, Haines SJ, et al. Outcome of severe closed head injury in the Midwest. A review and comparison with other major head trauma studies. Minn Med. 1987;70(7):397-401. [pmid: 3614179].
Bishara SN, Partridge FM, Godfrey HP, et al. Post-traumatic amnesia and Glasgow Coma Scale related to outcome in survivors in a consecutive series of patients with severe closed-head injury. Brain Inj. 1992;6(4):373-80. [pmid: 1638271].
Blackerby WF. Intensity of rehabilitation and length of stay. Brain Inj. 1990;4(2):167-73. [pmid: 2331546].
Bond MR. The stages of recovery from severe head injury with special reference to late outcome. Int Rehabil Med. 1979;1(4):155-9. [pmid: 263003].
Born JD, Albert A, Hans P, et al. Relative prognostic value of best motor response and brain stem reflexes in patients with severe head injury. Neurosurgery. 1985;16(5):595-601. [pmid: 4000430].
Bowers SA, Marshall LF. Outcome in 200 consecutive cases of severe head injury treated in San Diego County: A prospective analysis. Neurosurgery. 1980;6(3):237-42. [pmid: 7383286].
Braakman R, Gelpke GJ, Habbema JD, et al. Systematic selection of prognostic features in patients with severe head injury. Neurosurgery. 1980;6(4):362-70. [pmid: 7393417].
Brooks N, Campsie L, Symington C, et al. The five-year outcome of severe blunt head injury: A relative's view. J Neurol Neurosurg Psychiatry. 1986;49:764-70. [pmid: 3746307].
Brooks N, McKinlay W, Symington C, et al. Return to work within the first seven years of severe head injury. Brain Inj. 1987;1(1):5-19. [pmid: 3454672].
Bullock R, Chesnut R, Clifton G, et al. Guidelines for the management of severe head injury. Revision 1. New York:Brain Trauma Foundation; 1998.
Carey RG, Seibert JH, Posavac EJ. Who makes the most progress in inpatient rehabilitation? An analysis of functional gain. Arch Phys Med Rehabil. 1988;69(5):337-43. [pmid: 3365113].
Carnevale GJ. Natural-setting behavior management for individuals with traumatic brain injury: Results of a three-year caregiver training program. J Head Trauma Rehabil. 1996;11(1):27-38.
Cavallo MM, Kay T, Ezrachi O. Problems and changes after traumatic brain injury: Differing perceptions within and between families. Brain Inj. 1992;6(4):327-35. [pmid: 1638266].
Centers for Disease Control and Prevention. Unpublished data from the National Center for Injury Prevention and Control. Personal communication from David Thurman. May 1998.
Chan L, Koepsell TD, Deyo RA, et al. The effect of Medicare's payment system for rehabilitation hospitals on length of stay, charges, and total payments. N Engl J Med. 1997;337:978-85. [pmid: 9309104].
Chelimsky ESW, Shadish W, editors. Evaluation for the 21st century: A handbook. Thousand Oaks, CA: Sage Publications; 1997.
Chesnut RM, Alexander D, Antoinette T, et al. Toward an integrated approach to quantitative research on the rehabilitation of patients with TBI: A call for consensus formation of a universal, uniform data set. Forthcoming.
Chesnut RM, Marshall LF, Klauber MR, et al. The role of secondary brain injury in determining outcome from severe head injury. J Trauma. 1993;34(2):216-22. [pmid: 8459458].
Chesnut RM, Marshall SB, Piek J, et al. Early and late systemic hypotension as a frequent and fundamental source of cerebral ischemia following severe brain injury in the Traumatic Coma Data Bank. Acta Neurochir Suppl. 1993;59:121-5. [pmid: 8310858].
Choi SC, Narayan RK, Anderson RL, et al. Enhanced specificity of prognosis in severe head injury. J Neurosurg. 1988;69(3):381-5. [pmid: 3404236].
Cicerone KD, Smith LC, Ellmo W, et al. Neuropsychological rehabilitation of mild traumatic brain injury. Brain Inj. 1996;10:277-86. [pmid: 9044693].
Cifu DX, Kreutzer JS, Marwitz JH, et al. Functional outcomes of older adults with traumatic brain injury: A prospective, multicenter analysis. Arch Phys Med Rehabil. 1996;77(9):883-8. [pmid: 8822678].
Cifu DX, Keyser-Marcus L, Lopez E, et al. Acute predictors of successful return to work 1 year after traumatic brain injury: A multicenter analysis. Arch Phys Med Rehabil. 1997;78(2):125-31. [pmid: 9041891].
Coelho CA, DeRuyter F, Stein M. Treatment efficacy: Cognitive-communicative disorders resulting from traumatic brain injury in adults. J Speech Hear Res. 1996;39(5):S5-17. [pmid: 8898262].
Commission for Case Manager Certification. CCM certification guide: Certified Case Manager. Rolling Meadows, IL: Commission for Case Manager Certification; 1996.
Cope DN. The effectiveness of traumatic brain injury rehabilation rehabilitation: A review. Brain Inj. 1995;9:649-70. [pmid: 8680395].
Cope DN, Cole JR, Hall KM, et al. Brain injury: Analysis of outcome in a post-acute rehabilitation system. Part 2: Subanalyses. [see comments]. Brain Inj. 1991;5(2):127-39. [pmid: 1908341].
Cope DN, Hall K. Head injury rehabilitation: Benefit of early intervention. Arch Phys Med Rehabil. 1982;63(9):433-7. [pmid: 7115044].
Corrigan JD, Bogner JA, Mysiw WJ, et al. Systematic bias in outcome studies of persons with traumatic brain injury. Arch Phys Med Rehabil. 1997;78(2):132-7. [pmid: 9041892].
Courtney C. A model for community support and case coordination networks for persons with traumatic brain injury. Final report submitted to Rehabilitation Services Administration, CSDA #84.235, Award H128A91121. St Paul: State of Minnesota Department of Jobs and Training, Division of Rehabilitation Services and Minnesota Head Injury Association; 1992.
Cowen TD, Meythaler JM, DeVivo MJ, et al. Influence of early variables in traumatic brain injury on functional independence measure scores and rehabilitation length of stay and charges. Arch Phys Med Rehabil. 1995;76(9):797-803. [pmid: 7668948].
Crepeau F, Scherzer P. Predictors and indicators of work status after traumatic brain injury: A meta-analysis. Neuropsychol Rehabil. 1993;3(1):5-35.
Curl RM, Chisholm LA. Unlocking coworker potential in competitive employment: Keys to a cooperative approach. J Vocational Rehabil. 1993;3(3):72-84.
Curl RM, Fraser RT, Cook RG, et al. Traumatic brain injury vocational rehabilitation: preliminary findings for the coworker as trainer project. J Head Trauma Rehabil. 1996;11(1):75-85.
David R, Enderby P, Bainton D. Treatment of acquired aphasia: Speech therapists and volunteers compared. J Neurol Neurosurg Psychiatry. 1982;45(11):957-61. [pmid: 6184453].
Dawson DR, Chipman M. The disablement experienced by traumatically brain-injured adults living in the community. Brain Inj. 1995;9(4):339-53. [pmid: 7640680].
Deacon D, Campbell K. Decision making following closed head injury: Can response speed be trained?. J Clin Exp Neuropsychol. 1991;13:639-51. [pmid: 1955521].
Devany CW, Kreutzer JS, Halberstadt LJ, et al. Referrals for supported employment after brain injury: Neuropsychological, behavioral, and emotional characteristics. J Head Trauma Rehabil. 1991;6(3):59-70.
Dikmen S, Machamer J, Temkin N. Psychosocial outcome in patients with moderate to severe head injury: 2-year follow-up. Brain Inj. 1993;7(2):113-24. [pmid: 8453410].
Dikmen S, Reitan RM, Temkin NR. Neuropsychological recovery in head injury. Arch Neurol. 1983;40(6):333-8. [pmid: 6847436].
Dikmen SS, Temkin NR, Machamer JE, et al. Employment following traumatic head injuries. Arch Neurol. 1994;51(2):177-86. [pmid: 8304843].
Dombovy ML, Olek AC. Recovery and rehabilitation following traumatic brain injury. Brain Inj. 1997;11(5):305-18. [pmid: 9146836].
Dresser AC, Meirowsky AM, Weiss GH, et al. Gainful employment following head injury. Prognostic factors. Arch Neurol. 1973;29(2):111-6. [pmid: 4717717].
Eames P, Cotterill G, Kneale TA, et al. Outcome of intensive rehabilitation after severe brain injury: A long-term follow-up study. Brain Inj. 1996;10(9):631-50. [pmid: 8853867].
Eames P, Wood R. Rehabilitation after severe brain injury: A follow-up study of a behaviour modification approach. J Neurol Neurosurg Psychiatry. 1985;48(7):613-9. [pmid: 4031905].
Edna TH, Cappelen J. Return to work and social adjustment after traumatic head injury. Acta Neurochir. 1987;85(1-2):40-3. [pmid: 3604770].
Eliason MR, Topp BW. Predictive validity of Rappaport's Disability Rating Scale in subjects with acute brain dysfunction. Phys Ther. 1984;64(9):1357-60. [pmid: 6473516].
Ellerd DA, Moore SC. Follow-up at twelve and thirty months of persons with traumatic brain injury engaged in supported employment placements. J Appl Rehabil Couns. 1992;23(3):48-50.
Evans R, Ruff RM. Outcome and value: A perspective on rehabilitation outcomes achieved in acquired brain injury. J Head Trauma Rehabil. 1992;7(4):24-36.
Evans RW, Watke M. Catastrophic neurologic injury: Improving outcomes through case management. Case Manager. 1995;6(3):83-5, 87-8.
Ewing CL, Thomas DJ, Sansces A, et al. Impact of injury of the head and spine. Springfield, IL: Thomas; 1983.
Ezrachi O, Ben-Yishay Y, Kay T, et al. Predicting employment in traumatic brain injury following neuropsychological rehabilitation. J Head Trauma Rehabil. 1991;6:71-84.
Fabiano RJ, Crewe N. Variables associated with employment following severe traumatic brain injury. Rehabil Psychol. 1995;40:223-31.
Fairweather G, Sanders DL, Maynard H, et al. Community life for the mentally ill: An experiment in social innovation. Chicago: Aldine; 1969.
Fearnside MR, Cook RJ, McDougall P, et al. The Westmead Head Injury Project. Physical and social outcomes following severe head injury. Br J Neurosurg. 1993;7(6):643-50. [pmid: 8161426].
Fiedler RC, Granger CV. Uniform data system for medical rehabilitation: report of first admissions for 1995. Am J Phys Med Rehabil. 1997;76(1):76-81. [pmid: 9036916].
Fraser R, Dikmen S, McLean A, et al. Employability of head injury survivors: First year post-injury. Special issue: Traumatic brain injury. Rehabil Couns Bull. 1988;31(4):276-288.
Fryer LJ, Haffer WJ. Cognitive rehabilitation and community readaption: Outcomes from two program models. J Head Trauma Rehabil. 1987;2:51-63.
Gerber L. Case management models: Geriatric nursing prototypes for growth. J Gerontol Nurs. 1994;20(7):18-24. [pmid: 8046214].
Giacino JT, Kezmarsky MA, DeLuca J, et al. Monitoring rate of recovery to predict outcome in minimally responsive patients. Arch Phys Med Rehabil. 1991;72(11):897-901. [pmid: 1929808].
Girard D, Brown J, Burnett-Stolnack M, et al. The relationship of neuropsychological status and productive outcomes following traumatic brain injury. Brain Inj. 1996;10:663-76. [pmid: 8853869].
Godfrey H, Knight R, Bishara S. The relationship between social skill and family problem-solving following very severe closed head injury. Brain Inj. 1991;5(2):207-11. [pmid: 1873606].
Goering PNW,[Wasylenki DA,] Farkas M, Lancee WJ, et al. What difference does case management make?. Hosp Community Psychiatry. 1988;39(3):272-6. [pmid: 3356432].
Goldstein K. The organism: A holistic approach to biology derived from pathological data in man. New York: Urzone; 1995.
Goldstein G, McCue M, Turner S, et al. An efficacy study of memory training for patients with closed-head injury. Clin Neuropsychologist. 1988;2:251-9.
Goodwin D. Nursing case management activities: How they differ between employment settings. J Nurs Adm. 1994;24(2):29-34. [pmid: 8301392].
Gopinath SP, Robertson CS, Contant CF, et al. Jugular venous desaturation and outcome after head injury. J Neurol Neurosurg Psychiatry. 1994;57(6):717-23. [pmid: 8006653].
Gouvier WD, Blanton PD, LaPorte KK, et al. Reliability and validity of the Disability Rating Scale and the Levels of Cognitive Functioning Scale in monitoring recovery from severe head injury. Arch Phys Med Rehabil. 1987;68(2):94-7. [pmid: 3813863].
Granger CV, Hamilton BB, Sherwin FS. Guide for use of the uniform data set for medical rehabilitation. Buffalo, NY: Uniform Data System for Medical Rehabilitation; 1986.
Gray JM, Robertson I, Pentland B. Microcomputer-based attentional retraining after brain damage: A randomised group controlled trial. Neuropsychol Rehabil. 1992;2(2):97-115.
Greenspan AI, Wrigley JM, Kresnow M, Fine PR et al. Factors influencing failure to return to work due to traumatic brain injury. Brain Inj. 1996;10(3):207-18. [pmid: 8777392].
Greenwood RJM, Brooks DN. Effects of case management after severe head injury. BMJ. 1994;308:1199-1205. [pmid: 8180536].
Gronwall D. Paced auditory serial-addition task: A measure of recovery from concussion. Percept Mot Skills. 1977;44:367-73. [pmid: 866038].
Gronwall D. Rehabilitation programs for patients with mild head injury: Components, problems, and evaluation. J Head Trauma Rehabil. 1986;1(2):53-62.
Gronwall D, Wrightson P. Duration of post-traumatic amnesia after mild head injury. J Clin Neuropsychol. 1980;2(1):251-60.
Haffey WJ, Abrams DL. Employment outcomes for participants in a brain injury work reentry program: Preliminary findings. J Head Trauma Rehabil. 1991;6(3):24-34.
Hagen C, Malkmus D, Durham P, et al. Levels of cognitive functioning. Rehabilitation of the head injured adult. Comprehensive physical management. Downey, CA: Professional Staff Association, Rancho Los Amigos Hospital; 1979.
Hall K, Cope DN, Rappaport M. Glasgow Outcome Scale and Disability Rating Scale: Comparative usefulness in following recovery in traumatic head injury. Arch Phys Med Rehabil. 1985;66(1):35-7. [pmid: 3966866].
Hall KM, Cope DN. The benefit of rehabilitation in traumatic brain injury: A literature review. J Head Trauma Rehabil. 1995;10(1):1-13.
Hall KM, Mann N, High WM, et al. Functional measures after traumatic brain injury: Ceiling effects of FIM, FIM+FAM, DRS, and CIQ. J Head Trauma Rehabil. 1996;11(5):27-39.
Hawkins ML, Lewis FD, Medeiros RS. Serious traumatic brain injury: An evaluation of functional outcomes. J Trauma. 1996;41(2):257-63; discussion 263-4. [pmid: 8760533].
Heinemann AW, Hamilton B, Linacre JM, et al. Functional status and therapeutic intensity during inpatient rehabilitation. Am J Phys Med Rehabil. 1995;74(4):315-26. [pmid: 7632391].
Heinemann AW, Sabgal V, Cichowski K, et al. Functional outcomes following traumatic brain injury. J Neurol Rehabil. 1990;4:27-37.
Helffenstein D, Wechsier R. The use of interpersonal process recall (PR) in the remediation of interpersonal and communication skill deficits in the newly brain injured. Clin Neuropsychol. 1982;4:139-43.
Hendryx P. Psychosocial changes perceived by closed-head-injured adults and their families. Arch Phys Med Rehabil. 1989;(70):526-30. [pmid: 2742468].
High WM Jr, Boake C, Lehmkuhl LD. Critical analysis of studies evaluating the effectiveness of rehabilitation after traumatic head injury. J Head Trauma Rehabil. 1995;10(1):14-26.
High WM Jr, Hall KM, Rosenthal M, et al. Factors affecting hospital length of stay and charges following traumatic brain injury of injured adults living in the community. Brain Inj. 1996;9(4):339-53.
Ip RY, Dornan J, Schentag C. Traumatic brain injury: factors predicting return to work or school. Brain Inj. 1995;9:517-32. [pmid: 7550223].
Jacobs HE. The Los Angeles Head Injury Survey: Procedures and initial findings. Arch Phys Med Rehabil. 1988;69(6):425-31. [pmid: 3132129].
Jennett B, Bond M. Assessment of outcome after severe brain damage: A practical scale. Lancet. 1975:1480-4.
Jennett B, Snoek J, Bond MR, et al. Disability after severe head injury: Observations of the use of the Glasgow Outcome Scale. J Neurol Neurosurg Psychiatry. 1981;44(4):285-93. [pmid: 6453957].
Jennett B, Teasdale G, Galbraith S, et al. Prognosis in patients with severe head injury. Acta Neurochir Suppl. 1979;28(1):149-52. [pmid: 158290].
Johnson D, Roethig-Johnston K. Head injury: Early rehabilitation of head-injured patients. Nurs Times. 1989;85(4):25-8. [pmid: 2928171].
Johnson R. Return to work after severe head injury. Int Disabil Studies. 1987;9:49-54. [pmid: 3680106].
Johnston MV. Outcomes of community re-entry programmes for brain injury survivors. Part 2: Further investigations [see comments]. Brain Inj. 1991;5(2):155-68. [pmid: 1651796].
Johnston MV, Hall K. Outcomes evaluation in TBI rehabilitation Part I: Overview and system principles. Arch Phys Med Rehabil. 1994;75:SC2-SC28.
Johnston MV, Lewis FD. Outcomes of community re-entry programmes for brain injury survivors. Part 1: Independent living and productive activities. Brain Injury. 1991;5(2):141-54. [pmid: 1873601].
Jones C. Outcome following closed head injury. J Neurosurg Nurs. 1981;13(4):178-83. [pmid: 6921219].
Jones ML, Evans RW. Outcome validation in post-acute rehabilitation: Trends and correlates in treament and outcome. J Ins Med. 1992;24(3):186-92. [pmid: 10147828].
Jones PA, Andrews PJ, Midgley S, et al. Measuring the burden of secondary insults in head-injured patients during intensive care. J Neurosurg Anesth. 1994;6(1):4-14. [pmid: 8298263].
Jorgensen HS. Hospital rehabilitation of patients with severe brain injuries. II.Prognosis and effect of early intensive, specialized rehabilitation. Ugeskr Laeger. 1997;159(26):4093-9. [pmid: 9229866].
Kaitaro T, Koskinen S, Kaipio ML. Neurophysiological problems in everyday life: A 5-year follow-up study of young severely closed-head-injured patients. Brain Inj. 1995;9(7):713-27. [pmid: 8680398].
Kerner MJ, Acker M. Computer delivery of memory retraining with head injured patients. Cogn Rehabil. 1985;Nov-Dec:26-31.
Klauber MR, Marshall LF, Luerssen TG, et al. Determinants of head injury mortality: Importance of the low risk patient. Neurosurgery. 1989;24(1):31-6. [pmid: 2927596].
Kock C, Fuhrmann R. [Early neurologic rehabilitation--an urgent requirement] [German]. Rehabilitation. 1992;31(4):217-9. [pmid: 1484994].
Kosubek C, Feldmann M, Schwendemann G. Early neurological rehabilitation. Local demand for early rehabilitation places for adult patients illustrated for the Land Bremen[Early neurologic-neurosurgical rehabilitation--on the epidemiology of the need for early rehabilitation beds by adult patients exemplified by the Bremen federal district][German]. Rehabilitation (Stuttgart). 1996;35(1):29-32. [pmid: 8693185]. [pmcid: 26585].
Kozloff R. Networks of social support and the outcome from severe head injury. J Head Trauma Rehabil. 1987;2(3):14-23.
Kraft JF, Schwab KA, Salazar AM, et al. Occupational and educational achievements of head injured Vietnam veterans at 15-year follow-up. Arch Phys Med Rehabil. 1993;74(6):596-601. [pmid: 8503749].
Kraus J, Sorenson S. Epidemiology. In Silver JM, Yudofsky SC, Hales RE, editors, Neuropsychiatry of traumatic brain injury. Washington, DC: American Psychiatric Press; 1994.
Kraus JF, McArthur DL. Epidemiologic aspects of brain injury. Neurologic Clinics. 1996;14(2):435-50. [pmid: 8827181].
Kreutzer J, Wehman P, Morton MV, et al. Supported employment and compensatory strategies for enhancing vocational outcome following traumatic brain injury. Brain Inj. 1988;2(3):205-23. [pmid: 3167277].
Kreutzer JS, Doherty R, Harris JA. Alcohol abuse among persons with traumatic brain injury. J Head Trauma Rehabil. 1990;5:9-20.
Kreutzer JS, Marwitz JH, Kepler K. Traumatic brain injury: Family response and outcome. Arch Phys Med Rehabil. 1992;73(8):771-8. [pmid: 1642529].
Kwasnica CM, Heinemann A. Coping with traumatic brain injury: Representative case studies. Arch Phys Med Rehabil. 1994;75(4):384-9. [pmid: 8172495].
Leathem J, Heath E, Woolley C. Relatives' perceptions of role change, social support and stress after traumatic brain injury. Brain Inj. 1996;10(1):27-38. [pmid: 8680390].
Lehmkulh LD, Hall KM, Mann N, et al. Factors that influence costs and length of stay in persons with traumatic brain injury in acute care and inpatient rehabilitation. J Head Trauma Rehabil. 1993;8(2):88-100.
Levin HS, Benton AL, Grossman RG. Neurobehavioral consequences of closed head injury. New York: Oxford University Press; 1982.
Levin HS, Gary HE Jr, Eisenberg HM, et al. Neurobehavioral outcome 1 year after severe head injury. Experience of the Traumatic Coma Data Bank. J Neurosurg. 1990;73(5):699-709. [pmid: 2213159].
Levin HS, O'Donnell VM, Grossman RG. The Galveston Orientation and Amnesia Test. A practical scale to assess cognition after head injury. J Nerv Ment Dis. 1979;167(11):675-84. [pmid: 501342].
Lewin ICF. The cost of disorders of the brain. Washington, DC: National Foundation for the Brain; 1992.
Lezak MD. Assessment for rehabilitation planning. In Meier M, Benton AL, Diller L, Neuropsychological rehabilitation. New York: Guilford Press; 1987.
Lezak MD. Neuropsychological assessment. New York: Oxford University Press; 1995.
Livingston MG, Brooks DN, Bond MR. Patient outcome in the year following severe head injury and relatives' psychiatric and social functioning. J Neurol Neurosurg Psychiatry. 1985;48:876-81. [pmid: 4045482].
Lomas J, Kertesz A. Patterns of spontaneous recovery in aphasic groups: A study of adult stroke patients. Brain Lang. 1978;5(3):388-401. [pmid: 656906].
Mackay LE, Bernstein BA, Chapman PE, et al. Early intervention in severe head injury: Long-term benefits of a formalized program. Arch Phys Med Rehabil. 1992;73(7):635-41. [pmid: 1622318].
Malec JF, Buffington AL, Moessner AM, et al. Maximizing vocational outcome after brain injury: Integration of medical and vocational hospital-based services. Mayo Clin Proc. 1995;70(12):1165-71. [pmid: 7490918].
Malec JF, Smigielski JS, DePompolo RW, et al. Outcome evaluation and prediction in a comprehensive-integrated post-acute outpatient brain injury rehabilitation programme. Brain Inj. 1993;7(1):15-29. [pmid: 8425113].
Marion DW, editor. Traumatic brain injury. New York: Thieme; 1999; pp.121-2.
Marion DW, Carlier PM. Problems with initial Glasgow Coma Scale assessment caused by prehospital treatment of patients with head injuries: Results of a national survey. J Trauma. 1994;36(1):89-95. [pmid: 8295256].
Marmarou A, Anderson RL, Ward JD, et al. Impact of ICP instability and hypotension on outcome in patients with severe head trauma. J Neurosurg. 1991;75(Suppl):S159-66.
Marshall LF, Bowers-Marshall S, Klauber MR, et al. A new classification of head injury based on computerized tomography. J Neurosurg. 1991;75(Suppl):S14-20.
Marshall LF, Gautille T, Klauber MR, et al. The outcome of severe head injury. J Neurosurg. 1991;75(Suppl):S28-36.
Maslow A. Motivation and personality, 3rd edition. Harper & Row: New York; 1987.
Mayer T, Walker ML, Shasha I, et al. Effect of multiple trauma on outcome of pediatric patients with neurologic injuries. Childs Brain. 1981;8(3):189-97. [pmid: 7238136].
McLaughlin AM, Peters S. Evaluation of an innovative cost-effective programme for brain injury patients: Response to a need for flexible treatment planning. Brain Inj. 1993;7(1):71-5. [pmid: 8425118].
McMillan TMG, Morris JR, Brooks DN, et al. An introduction to the concept of head injury case mangement with respect to the need for service provision. Clin Rehabil. 1988;2:319-22.
McMordie WR, Barker SL. The financial trauma of head injury. Brain Inj. 1988;2(4):357-64. [pmid: 3203182].
Middleton DK, Lambert MJ, Seggar LB. Neuropsychological rehabilitation: microcomputer-assisted treatment of brain-injured adults. Percept Mot Skills. 1991;72:527-30. [pmid: 1852561].
Mills VM, Nesbeda T, Katz DI, et al. Outcomes for traumatically brain-injured patients following post-acute rehabilitation programmes. Brain Inj. 1992;6(3):219-28. [pmid: 1581745].
Morgan AS, Chapman P, Tokarski L. Improved care of the traumatically brain injured. Presented at Eastern Association for Surgery of Trauma. First Annual Conference; January 15, 1988; Longboat Key, FL.
Morton MV, Wehman P. Psychosocial and emotional sequelae of individuals with traumatic brain injury: A literature review and recommendations. Brain Inj. 1995;9(1):81-92. [pmid: 7874099].
Najenson T, Groswasser Z, Mendelson L, et al. Rehabilitation outcome of brain damaged patients after severe head injury. Int Rehabil Med. 1980;2(1):17-22. [pmid: 7440083].
Neistadt ME. Occupational therapy treatments for constructional deficits. Am J Occup Ther. 1992;46(2):141-8. [pmid: 1595825].
Niemann H, Ruff RM, Baser CA. Computer-assisted attention retraining in head-injured individuals: A controlled efficacy study of an outpatient program. J Consult Clin Psychol. 1990;58(6):811-7. [pmid: 2292631].
Novack TA, Caldwell SG, Duke LW, et al. Focused versus unstructured intervention for attention deficits after traumatic brain injury. J Head Trauma Rehabil. 1996;11(3):52-60.
Oddy M, Humphrey M. Social recovery during the year following severe head injury. J Neurol Neurosurg Psychiatry. 1980;43(9):798-802. [pmid: 7420103].
Olver JH, Ponsford JL, Curran CA. Outcome following traumatic brain injury: A comparison between 2 and 5 years after injury. Brain Inj. 1996;10(11):841-8. [pmid: 8905161].
Ommaya AK, Salazar AM, Dannenberg AL et al. Outcome after traumatic brain injury in the U.S. military medical system. J Trauma. 1996;41(6):972-5. [pmid: 8970548].
Ostby S, Sakata R, Leung P. Perceived persistence of problems in post-head-injury rehabilitation. Brain Inj. 1991;5(1):9-16. [pmid: 2043914].
Panikoff LB. Recovery trends of functional skills in the head-injured adult. Am J Occup Ther. 1983;37(11):735-43. [pmid: 6650646].
Panting AM, Merry PH. Long term rehabilitation of severe head injuries with particular reference to need for social and medical support for the patient's family. Rehabilitation. 1972:8233-7.
Partridge TM. An investigation into the vocational rehabilitation practices provided by brain injury services throughout the United Kingdom. Work. 1996;7:63-72.
Pazzaglia P, Frank G, Frank F, et al. Clinical course and prognosis of acute post-traumatic coma. J Neurol Neurosurg Psychiatry. 1975;38(2):149-54. [pmid: 1151395].
Pentland B, Miller JD. Head injury rehabilitation in Edinburgh. Health Bull. 1986;44(2):105-9. [pmid: 3700092].
Peters MD, Gluck M, McCormick M. Behaviour rehabilitation of the challenging client in less restrictive settings. Brain Inj. 1992;6(4):299-314. [pmid: 1638264].
Pettifer S. Leisure as compensation for employment and unfulfilling work: Reality or pipedream. J Occupational Sci. 1993;1(2):20-8.
Ponsford JL, Kinsella G. Evaluation of a remedial programme for attentional deficits following closed-head injury. J Clin Exp Neuropsychol. 1988;10(6):693-708. [pmid: 3235646].
Ponsford JL, Olver JH, Curran C. A profile of outcome: 2 years after traumatic brain injury. Brain Inj. 1995;9(1):1-10. [pmid: 7874089].
Powell T, Pancsofar EL, Steere KE, et al. Supported employment: Providing integrated employment opportunities for persons with disabilities. New York: Longman; 1991.
Prigatano G. Neuropsychological rehabilitation of the traumatically brain injured. Baltimore: Johns Hopkins University Press; 1986.
Prigatano GP, Fordyce DJ, Zeiner HK, et al. Neuropsychological rehabilitation after closed head injury in young adults. J Neurol Neurosurg Psychiatry. 1984;47(5):505-13. [pmid: 6736983].
Ragnarsson KT, Thomas JP, Zasler ND. Model systems of care for individuals with traumatic brain injury. J Head Trauma Rehabil. 1993;8(2):1-11.
Rao N, Kilgore KM. Predicting return to work in traumatic brain injury using assessment scales. Arch Phys Med Rehabil. 1992;73(10):911-6. [pmid: 1417465].
Rappaport M, Hall KM, Hopkins K, et al. Disability rating scale for severe head trauma: Coma to community. Arch Phys Med Rehabil. 1982;63(3):118-23. [pmid: 7073452].
Rappaport M, Herrero-Backe C, Rappaport ML, et al. Head injury outcome up to ten years later. Arch Phys Med Rehabil. 1989;70(13):885-92. [pmid: 2596962].
Reeder KP, Rosenthal M, Lichtenberg P, et al. Impact of age on functional outcome following traumatic brain injury. J Head Trauma Rehabil. 1996;11(3):22-31.
Resnick C. The effect of head injury on family and marital stability. Soc Work Health Care. 1993;18(2):49-62. [pmid: 8332939].
Robertson CS, Contant CF, Gokaslan ZL, et al. Cerebral blood flow, arteriovenous oxygen difference, and outcome in head injured patients. J Neurol Neurosurg Psychiatry. 1992;55(7):594-603. [pmid: 1640238].
Roe A. The psychology of occupations. New York: Wiley; 1956.
Roessler R, Schriner K, Price P. Employment concerns of people with head injuries. J Rehabil. 1992;58:17-22.
Rosenbaum MNT, Najenson T. Changes in life patterns and symptoms of low mood as reported by wives of severely injured soldiers. J Consult Clin Psychol. 1976;44(6):881-8. [pmid: 993425].
Rosenthal M, Young T. Effective family intervention after traumatic brain injury: Theory and practice. J Head Trauma Rehabil. 1988;3(4):42-50.
Ruff RM, Niemann H. Cognitive rehabilitation versus day treatment in head-injured adults: Is there an impact on emotional and psychosocial adjustment?. Brain Inj. 1990;4(4):339-47. [pmid: 2252966].
Ruff RM, Baser CA, Johnston JW, et al. Neuropsychological rehabilitation: An experimental study with head-injured patients. J Head Trauma Rehabil. 1989;4(3):20-36. [pmid: 2665706].
Ruff R, Mahaffey R, Engel J, et al. Efficacy study of THINKable in the attention and memory retraining of traumatically head-injured patients. Brain Inj. 1994;8:3-14. [pmid: 8124315].
Ruff RM, Marshall LF, Crouch J, et al. Predictors of outcome following severe head trauma: Follow-up data from the Traumatic Coma Data Bank. Brain Inj. 1993;7(2):101-11. [pmid: 8453409].
Ruff RM, Marshall LF, Klauber MR, et al. Alcohol abuse and neurological outcome of the severely head injured. J Head Trauma Rehabil. 1990;5:21-31.
Rusk HA, Block JM, Lowman EW. Rehabilitation following traumatic brain damage; Immediate and long-term follow-up results in 127 cases. Med Clin North Am. 1969;53(3):677-84. [pmid: 5780626].
Russell WR. Cerebral involvement in head injury. Brain. 1932;55:549-603.
Russell WR. Amnesia following head injuries. Lancet. 1935;2:762-3.
Russell WR, Nathan PW. Traumatic amnesias. Brain. 1946;69:280-301. [pmid: 20287646].
Russell WR, Smith A. Post-traumatic amnesia in closed head injury. Arch Neurol. 1961;5:4-17. [pmid: 13744864].
Ryan T, Ruff R. The effect of structured memory retraining in a group comparison of head trauma patients. Arch Clin Neuropsychol. 1988;3:165-79. [pmid: 14591268].
Sakata R, Ostby S, Leung P. Functional status, referral and cost of treatment for persons with traumatic head injury. Brain Inj. 1991;5(4):411-9. [pmid: 1786504].
Sale P, West M, Sherron P, et al. Exploratory analysis of job separations from supported employment for persons with traumatic brain injury. J Head Trauma Rehabil. 1991;6(3):1-11.
Sample PRA, Rowntree AJ. Employment intervention strategies for individuals with brain injury. Occup Ther Health Care. 1995;9(1):45-56.
Sander AM, Kreutzer JS, Rosenthal M, et al. A multicenter longitudinal investigation of return to work and community integration following traumatic brain injury. J Head Trauma Rehabil. 1996;11(5):70-84.
Saneda DL, Corrigan JD. Predicting clearing of post-traumatic amnesia following closed-head injury. Brain Inj. 1992;6(2):167-74. [pmid: 1571721].
Sanguinetti M, Catanzaro M. A comparison of discharge teaching on the consequences of brain injury. J Neurosci Nurs. 1987;19(5):271-5. [pmid: 2960761].
Sarno MT. The status of research in recovery from aphasia. In Lebrun Y, Hoops R, editors, Recovery in aphasics. Amsterdam: Swets and Zeitlinger; 1976.
Sbordone R, Liter J, Pettler-Jennings P. Recovery of function following severe traumatic brain injury: A retrospective 10-year follow-up. Brain Inj. 1995;9(3):285-99. [pmid: 7541681].
Schalen WN, Nordstrom G, Nordstrom CH. Economic aspects of capacity for work after severe traumatic brain lesions. Brain Inj. 1994;8(1):37-47. [pmid: 8124316].
Scherzer BP. Rehabilitation following severe head trauma: results of a three-year program. Arch Phys Med Rehabil. 1986;67(6):366-74. [pmid: 3718196].
Schmitter-Edgecombe M, Fahy JF, Whelan JP, et al. Memory remediation after severe closed head injury: Notebook training versus supportive therapy. J Consult Clin Psychol. 1995;63(3):484-9. [pmid: 7608363].
Schwab K, Grafman J, Salazar AM, et al. Residual impairments and work status 15 years after penetrating head injury: Report from the Vietnam Head Injury Study. Neurology. 1993;43(1):95-103. [pmid: 8423917]. [pmcid: 123722].
Shepherd G. Psychological disorder and unemployment. Bull Br Psychol Soc. 1981;34:345-8.
Sherburne E. A rehabilitation protocol for the neuroscience intensive care unit. J Neurosci Nurs. 1986;18(3):140-5. [pmid: 2941500].
Sohlberg M, Mateer C. Introduction to cognitive rehabilitation, theory and practice. New York: Guilford Press; 1989.
Sosin DM, Sniezek JE, Waxweiler RJ. Trends in death associated with traumatic brain injury, 1979 through 1992. Success and failure. JAMA. 1995;273:1778-80. [pmid: 7769773].
Sparadeo FR, Gill D. Effects of prior alcohol use on head injury recovery. J Head Trauma Rehabil. 1989:475-82.
Sparadeo FR, Strauss D, Barth JT. The incidence, impact, and treatment of substance abuse in head trauma rehabilitation. J Head Trauma Rehabil. 1990;5(3):1-8.
Spatt J, Zebenholzer K, Oder W. Psychosocial long-term outcome of severe head injury as perceived by patients, relatives, and professionals. Acta Neurol Scand. 1997;95:173-9. [pmid: 9088387].
Spettell CM, Ellis DW, Ross SE, et al. Time of rehabilitation admission and severity of trauma: Effect on brain injury outcome. Arch Phys Med Rehabil. 1991;72(5):320-5. [pmid: 2009049].
Spivack G, Spettell CM, Ellis DW, et al. Effects of intensity of treatment and length of stay on rehabilitation outcomes. Brain Inj. 1992;6(5):419-34. [pmid: 1393175].
Stambrook MM, Peters LC, Deviaene C, et al. Effects of mild, moderate and severe closed head injury on long-term vocational status. Brain Inj. 1990;4(2):183-90. [pmid: 2331548].
Stonnington HH, Burns CT, Sale PR. Return to work for persons with traumatic brain injury: A supported employment approach. Arch Phys Med Rehabil. 1990;71(13):1047-52. [pmid: 2256804].
Swaine BR, Sullivan SJ. Longitudinal profile of early motor recovery following severe traumatic brain injury. Brain Inj. 1996;10(5):347-66. [pmid: 8735665].
Tate RL, Lulham JM, Broe GA, et al. Psychosocial outcome for the survivors of severe blunt head injury: The results from a consecutive series of 100 patients. J Neurol Neurosurg Psychiatry. 1989;52(10):1128-34. [pmid: 2795038].
Teasdale G, Jennett B. Assessment of coma and impaired consciousness: A practical scale. Lancet. 1974:281-4.
Tennant A, Macdermott N, Neary D. The long-term outcome of head injury: Implications for service planning. Brain Inj. 1995;9(6):595-605. [pmid: 7581355].
Thatcher RW, Cantor DS, McAlister R, et al. Comprehensive predictions of outcome in closed head-injured patients. The development of prognostic equations. Ann NY Acad Sci. 1991;620:82-101. [pmid: 2035948].
Thomas-Stonell N, Johnson P, Schuller R et al. Evaluation of a computer-based program for remediation of cognitive-communication skills. J Head Trauma Rehabil. 1994;9(4):25-37.
Thomsen IV. Verbal learning in aphasic and non-aphasic patients with severe head injuries. Scand J Rehabil Med. 1977;9(2):73-7. [pmid: 897614].
Thomsen IV. Late psychosocial outcome in severe traumatic brain injury: Preliminary results of a third follow-up study after 20 years. Scand J Rehabil Med Suppl. 1992;26:142-52. [pmid: 1488637].
Torkelson RM, Jellinek HM, Malec JF et al. Traumatic brain injury: Psychological and medical factors related to rehabilitation outcome. Rehabil Psychology. 1983;28(3):169-76.
Treadwell K, Page T. Functional analysis: Identifying the environmental determinants of severe behavior disorders. J Head Trauma Rehabil. 1996;11(1):62-74.
Tuel SM, Presty SK, Meythaler JM, et al. Functional improvement in severe head injury after readmission for rehabilitation. Brain Inj. 1992;6(4):363-72. [pmid: 1638270].
Twum M, Parente R. Role of imagery and verbal labeling in the performance of paired associates tasks by persons with closed head injury. J Clin Exp Neuropsychol. 1994;16(4):630-9. [pmid: 7962364].
van Balen HG, Mulder T, Keyser A. Towards a disability-oriented epidemiology of traumatic brain injury. Disability Rehabil. 1996;18(4):181-90. [pmid: 8744906].
Vilkki J, Ahola K, Holst P, Ohman J, et al. Prediction of psychosocial recovery after head injury with cognitive tests and neurobehavioral ratings. J Clin Exp Neuropsychol. 1994;16(3):325-38. [pmid: 7929700].
Vollmer DG, Torner JC, Jane JA, et al. Age and outcome following traumatic coma: Why do older patients fare worse?. J Neurosurg. 1991;75(Suppl):S37-49.
Waxman K, Sundine MJ, Young RF. Is early prediction of outcome in severe head injury possible?. Arch Surg. 1991;126(10):1237-41; discussion 1242. [pmid: 1929824].
Weddell R, Oddy M, Jenkins D. Social adjustment after rehabilitation: A two year follow-up of patients with severe head injury. Psychol Med. 1980;10(2):257-63. [pmid: 7384328].
Wehman P, Kreutzer J, Sale P, et al. Cognitive impairment and remediation: Implications for employment following traumatic brain injury. J Head Trauma Rehabil. 1989;4(3):66-75.
Wehman P, Kreutzer JS, Stonnington HH, et al. Supported employment for persons with traumatic brain injury: A preliminary report. J Head Trauma Rehabil. 1988;3(4):82-93.
Wehman P, Kreutzer J, West M, et al. Employment outcomes of persons following traumatic brain injury: Pre-injury, post-injury, and supported employment. Brain Inj. 1989;3(4):397-412. [pmid: 2819319].
Wehman P, Kreutzer J, West M, et al. Return to work for persons with traumatic brain injury: A supported employment approach. Arch Phys Med Rehabil. 1990;71:1047-52. [pmid: 2256804].
Wehman P, West M, Fry R, et al. Effect of supported employment on the vocational outcomes of persons with traumatic brain injury. Special Issue: Supported employment. J Appl Behavior Analysis. 1989;22(4):395-405. [pmid: 2515185].
Wehman P, Sherron P, Kregel J, et al. Return to work for persons following severe traumatic brain injury. Supported employment outcomes after five years. Am J Phys Med Rehabil. 1993;72(6):355-63. [pmid: 8260128].
Wehman PH, Revell WG, Kregel J, et al. Supported employment: An alternative model for vocational rehabilitation of persons with severe neurologic, psychiatric, or physical disability. Arch Phys Med Rehabil. 1991;72(2):101-5. [pmid: 1991008].
Whitlock JA Jr. Functional outcome of low-level traumatically brain-injured admitted to an acute rehabilitation programme. Brain Inj. 1992;6(5):447-59. [pmid: 1393177].
Whitlock JA Jr, Hamilton BB. Functional outcome after rehabilitation for severe traumatic brain injury. Arch Phys Med Rehabil. 1995;76(12):1103-12. [pmid: 8540785].
Wilson B, Evans J, Emslie H, et al. Evaluation of NeuroPage: A new memory aid. J Neurol Neurosurg Psychiatry. 1997;63:113-5. [pmid: 9221980].
Wood RL, Fussey I. Computer based cognitive retraining: a controlled study. Int Disabil Studies. 1987;9:149-53. [pmid: 3440786].
Woolf PD, Hamill RW, Lee LA, et al. The predictive value of catecholamines in assessing outcome in traumatic brain injury. J Neurosurg. 1987;66(6):875-82. [pmid: 3572517].
Woolf SH , Battista RN, Anderson GM, et al. Assessing the clinical effectiveness of preventive maneuvers: Analytic principles and systematic methods in reviewing evidence and developing clinical practice recommendations. A report by the Canadian Task Force on the Periodic Health Examination. J Clin Epidemiol. 1990;43:891-905. [pmid: 2145399].
Wrigley JM, Yoels WC, Webb CR, et al. Social and physical factors in the referral of people with traumatic brain injuries to rehabilitation. Arch Phys Med Rehabil. 1994;75(2):149-55. [pmid: 8311670].
Ylvisaker M, Feeney T. Executive functions after traumatic brain injury: Supported cognition and self-advocacy. Semin Speech Lang. 1996;17(3):217-32. [pmid: 8912437].
Zafonte RD, Hammond FM, Mann NR, et al. Relationship between Glasgow coma scale and functional outcome. Am J Phys Med Rehabil. 1996;75(5):364-9. [pmid: 8873704].