# Acknowledgments

The authors thank the members of the Brain Injury Support Group of Portland for their support and the use of their library. They also thank the Portland State University Capstone students who volunteered their time to help with the project: Heather Brooks, Samantha Cohen, Justin Davis, Cynthia Davis-O'Reilly, Julie Geil, Cheryl Matsumura, and Jeana Schoonover.

The American Academy of Family Practice provided the model, its Clinical Policy Review Form, on which the authors based their review form for this report.