# Appendix 5. Project Personnel

## Research Team

- Principal Investigator
- Randall M. Chesnut, M.D.
- Associate Professor of Neurological Surgery
- Director, Neurotrauma and Neurosurgical Critical Care
- Oregon Health Sciences University

- Task Order Manager
- Nancy Carney, Ph.D.
- Division of Medical Informatics and Outcomes Research
- Oregon Health Sciences University

- N. Clay Mann, Ph.D.
- Assistant Professor of Emergency Medicine
- Oregon Health Sciences University

- Hugo Maynard, Ph.D.
- Professor of Psychology
- Portland State University
- Portland, OR

- Patricia Patterson, Ph.D.
- Assistant Professor of Nursing and Medical Informatics
- and Outcomes Research
- Oregon Health Sciences University

- Petronella Davies, M.S.
- Reference Librarian
- Oregon Health Sciences University

- Cynthia Davis-O'Reilly
- Division of Medical Informatics and Outcomes Research
- Oregon Health Sciences University

- Mark C. Hornbrook, Ph.D.
- Program Director
- Health Services, Social and Economics Studies
- Kaiser Permanente Center for Health Research

- Susan Mahon, M.P.H.
- Research Associate
- Division of Medical Informatics and Outcomes Research
- Oregon Health Sciences University

- Martie Sucec
- Senior Technical Writer
- Kaiser Permanente Center for Health Research

- James Wallace
- Operations Director, Outcomes Research
- Division of Medical Informatics and Outcomes Research
- Oregon Health Sciences University

- Melanie Zimmer-Gembeck, Ph.D.
- Senior Data Analyst
- Office of Planning and Development
- Multnomah County Health Department

- Mark Helfand, M.D., M.P.H.
- Director, Evidence-Based Practice Center
- Associate Professor of Internal Medicine and Medical Informatics and Outcomes Research
- Oregon Health Sciences University

- Kathryn Pyle Krages, A.M.L.S., M.A.
- Administrator, Evidence-Based Practice Center
- Division of Medical Informatics and Outcomes Research
- Oregon Health Sciences University

## National Expert Panel

- Bryna Helfter, M.A., C.T.R.S.
- Director, Technical Assistance Center
- Traumatic Brain Injury State Demonstration Grant Program of Maryland

- James Kelly, M.D.
- Director, Brain Injury Program
- Rehabilitation Institute of Chicago

- Jeffrey Kreutzer, Ph.D.
- Director of Rehabilitation Psychology and Neuropsychology
- Medical College of Virginia

- Nathan Zasler, M.D.
- Executive Medical Director, National NeuroRehabilitation Consortium, Inc.
- Medical Director, Concussion Care Centre of Virginia

## Local Expert Panel

- Robert Brown
- Survivor
- Brain Injury Support Group of Portland

- Carol Christofero-Snider
- Spouse of Survivor
- Brain Injury Support Group of Portland

- Danielle Erb, M.D.
- Rehabilitation Medicine Associates

- Molly Hoeflich, M.D.
- Physiatrist

- Daniel Irwin
- Vocational Rehabilitation Division
- Oregon Department of Human Services

- Donald Lange, Ph.D.
- Neuropsychologist

- Hugo Maynard, Ph.D.
- Professor of Psychology
- Portland State University

- Aimee Mooney, M.S.
- Rehabilitation Program Coordinator
- Legacy Rehabilitation Services Community Re-entry Service

- Meg Munger, R.N., M.S.
- Rehabilitation Program Coordinator
- Kaiser Permanente

## Reviewers

- Brian Andrews, M.D., F.A.C.S.
- San Francisco, CA
- Representing the American Association of Neurological Surgeons

- Harriet Udin Aronow, Ph.D.
- Associate Director of Research
- Casa Colina Hospital for Rehabilitative Medicine
- Los Angeles, CA

- Dawn Bunting, M.S.N., R.N.
- Plantsville, CT
- Representing the Association of Rehabilitation Nurses
- Consensus Development Conference Panel for Rehabilitation of Persons with Traumatic Brain Injury
- c/o Judith M. Whalen
- Associate Director for Science Policy, Analysis and Communication
- National Institute of Child Health and Human Development
- Bethesda, MD

- Patricia Goodall
- VA Department of Rehabilitative Services
- Richmond, VA
- Representing the Association for Persons in Supported Employment

- Richard J. Greenwood, M.D., F.R.C.P.
- Regional Neurological Rehabilitation Unit
- Homerton Hospital
- London, England

- Candace F. Gustafson, R.N.
- Burlington, MA
- Representing the Development Conference Panel for Rehabilitation of Persons with Traumatic Brain Injury

- Allen Heinemann, Ph.D.
- Rehabilitation Institute of Chicago
- Chicago, IL

- Jess F. Kraus, Ph.D.
- Southern California Injury Prevention Research Center
- UCLA School of Public Health
- Los Angeles, CA
- Representing the Brain Injury Association

- Mark Melgard, M.D.
- Workers Compensation Division
- Department of Consumer & Business Services
- State of Oregon
- Salem, OR

- Anthony Morgan, M.D., F.A.C.S.
- Chief of Trauma Services
- Saint Francis Hospital and Medical Center
- Hartford, CT

- Thomas Novack, Ph.D.
- Spain Rehabilitation Center
- Birmingham, AL

- Kristjan T. Ragnarsson, M.D.
- Department of Rehabilitation Medicine
- Mount Sinai Medical Center
- New York, NY
- Representing the Consensus Development Conference Panel for Rehabilitation of Persons with Traumatic Brain Injury

- Cheryl Ramandan-Jradi
- Mercer Island, WA
- Representing the American Occupational Therapy Association

- Ronald Ruff, Ph.D.
- San Francisco Neuropsychology Associates
- San Francisco, CA

- Barbara Scheffel, R.N.
- Scheffel Associates, Inc.
- Bedminster, NJ
- Representing the Case Management Association of America

- Maureen Schmitter-Edgecombe, Ph.D.
- Department of Psychology
- Washington State University
- Pullman, WA

- Marymargaret Sharp-Pucci, Ed.D., M.P.H.
- Technology Evaluation Center
- Blue Cross Blue Shield Association
- Chicago, IL

- McKay Moore Sohlberg, Ph.D.
- Department of Communications Disorders & Sciences
- University of Oregon
- Eugene, OR

- Linda Toms Barker
- Berkeley Planning Associates
- Oakland, CA

- Charles Turkelson, Ph.D.
- ECRI
- Plymouth Meeting, PA

- Dennis A. Turner, M.D.
- Division of Neurosurgery
- Duke University Medical Center
- Durham, NC

- Professor Barbara Wilson
- Medical Research Council
- Applied Psychology Unit
- Addenbrooke's Hospital
- Cambridge, England

- Mark Ylvisaker, Ph.D.
- Department of Communications Disorders
- College of Saint Rose
- Schenectady, NY

- Nathan Zasler, M.D.
- Executive Medical Director, NationalNeuroRehabilitation Consortium, Inc.
- Medical Director, Concussion Care Centre of Virginia
- Glen Allen, VA