# Appendix 4. Initial Abstraction Instrument

Abstraction Instrument, items 1-17 [image]

Abstraction Instrument, items 18-28 [image]

Abstraction Instrument, items 29-37 [image]

Abstraction Instrument, Question #1: Does the Application of Early, Interdisciplinary Rehabilitation Improve Outcomes for Persons With Traumatic Brain Injury? (items 1-7) [image]

Abstraction Instrument, Question 1, items 8-12 [image]

Abstraction Instrument, Question #2: Does the Intensity of In-Patient Rehabilitation Affect Outcomes for Persons With Traumatic Brain Injury? (items 1-5) [image]

Abstraction Instrument, Question 2, items 6-11 [image]

Abstraction Instrument, Question #3: Does the Application of Compensatory Cognitive Rehabilition Enhance Outcomes for Persons Who Sustain Traumatic Brain Injury (items 1-8) [image]

Abstraction Instrument, Question 3, items 9-13 [image]

Abstraction Instrument, Question #4: Does the Application of supported Employment Enhance Outcomes for Persons With Traumatic Brain Injury? (items 1-8) [image]

Abstraction Instrument, Question 4, items 9-11 [image]

Abstraction Instrument, Question #5: Does the Provision of Long-Term Care Coordination Enhance the General Functional Status of Persons With Traumatic Brain Injury? What is the Cost-Effectiveness of the Provision of this Intervention? (items 1-9 [image]

Abstraction Instrument, Question 5 item 10 [image]