# The Effect of Interventions To Mitigate the Effects of Low Health Literacy

## Introduction

This chapter presents the results of our literature search for key question (KQ) 2. The analytic framework for this question is presented in Chapter 2. In brief, KQ 2 asked about effective interventions to mitigate the effects of low health literacy on (a) use of health care services, (b) health outcomes, (c) costs of health care, and (d) health disparities. As we noted in our methods, the best studies to answer this question would have included analyses specific [underlined: to] individuals with low health literacy. However, much of the research about interventions designed to mitigate the effects of low health literacy has been done in populations that include a combination of low and high health literacy individuals and failed to perform literacy-specific subgroup analyses. Instead of excluding a large portion of the intervention literature, we decided to permit inclusion of studies with a combination of low and high literacy individuals and no subgroup analysis, knowing that they may provide only indirect information about the effect of interventions on an exclusively low literacy population.

For KQ 2, we present our results in two ways. First, where interventions use single strategies to mitigate the effects of low health literacy, we present results by intervention strategy (e.g., alternative document design, alternative numerical presentation, additive or alternative pictorial representation, alternative media, alternative readability, and document design) in an effort to aid intervention developers. The majority of results in this section focus on comprehension following the intervention, although a few180,181 also focus on the use of health care services. Second, where interventions use multiple strategies (preventing conclusions about the active intervention components), we organize results in accordance with outcomes in our analytic framework.

Table 43 Summary of included intervention studies

Source | Design (Sample Size) | Quality Score | Population, Health Literacy Levels | Control | Intervention | Outcomes | Analysis Stratified by Literacy Level
Interventions using single strategies for low health literacy
Bryant et al., 2009^213^ | RCT (232) | Fair | 28% < high school on REALM Mean REALM score: 59 | Standard American Urological Association BPH Symptom Score (AUA-SS) | Multimedia AUA-SS | Comprehension | Yes^a^
Campbell et al., 2004^200^ | RCT (233) | Fair | 50% Low (< 8th grade reading level on Woodcock Johnson) Average REALM score: 56.3 | Standard print consent form | 1. Simplified print consent form; 2. Video consent; 3. Computerized consent | Knowledge | Yes^a^
Coyne et al., 2003^199^ | RCT (226) | Fair | Mean REALM: 65 | Standard Consent Form | Simplified consent form | Comprehension | No
Galesic et al., 2009^217^ | RCT (162) | Fair | Mean numeracy on 12-pt scale derived from Lipkus & Schwartz: Overall: 9.7 Older adults: 8.6 Younger adults: 10.3 | Conditional probabilities (%) Presented to illustrate the positive predictive value of genetic testing for early detection of diabetes or trisomy 21 | Natural frequencies (x/10,000) Presented to illustrate the positive predictive value of genetic testing for early detection of diabetes or trisomy 21 | Accuracy of positive predictive value estimates | Yes
Galesic et al., 2009^216^ | Factorial RCT (171) | Fair | Mean numeracy score on 12-pt scale derived from Lipkus & Schwartz: Older adults: 8.6 Students: 10.3 | Numerical Risk (presented alternately as ARR or RRR) | Icon arrays | Accuracy of risk perception | Yes
Garcia-Retamero and Galesic, 2009^219^ | RCT (1047) | Fair | 49% Low numeracy (> median score on 9-item scale adapted from Lipkus and Schwartz)^b^ (Germany: 49%^b^, US 48%^a^) | Numerical information about RRR (including information with varying size denominators) | Numerical information (RRR) plus icon array (including information presented with varying sizes of denominators) | Accuracy of risk perception | Yes^a^
Greene et al., 2008^185^ | RCT (303) | Fair | 50% Low (score less than 10 on DR Numeracy Test) | 1. Side-by-side (random) comparison of characteristics; 2. No framework | 1 Common/unique presentation of characteristics; 2a Short framework; 2b Long framework | Comprehension | Yes
Greene and Peters, 2009^214^ | RCT (122) | Fair | 57% TOFHLA Cloze score ≤ 18 (out of 20) | Standard Medicaid health plan comparison chart | Simplified Medicaid health plan comparison chart | Comprehension | Yes
Hwang et al., 2005^195^ | Quasi-, pre-post (130) | Fair | 5% REALM ≤ 6th grade 22% REALM 7-8th grade | Medication label text:; A. Take with water; B. May cause drowsiness; C. Take with food; D. No alcohol; E. Take on an empty stomach | Medication label text + illustration | Comprehension | No
Kang et al., 2009^212^ | RCT (90) | Fair | Patient: Median REALM and WRAT scores: high school Parent: Median REALM and WRAT score: high school | Standard Consent Form | 1. Modified informed consent for (MIC); 2. Modified informed consent + slide show (MIC + SS); Note: Interventions delivered to both patient and parent | Comprehension | No
Mayhorn and Goldsworthy, 2007^189^ | Quasi-, post-only (700) | Fair | 42.9% Low literacy (REALM, NOS) | Original teratogen symbol (slash through pregnant woman) | 1 Original symbol, but woman taking pill; 2 Cross and skull bones in pregnant belly; 4 2 pictures: Original symbol + skull bones in pregnant belly; 5 2 pictures: #4 but more caricatured; 6 1 picture combining original symbol + skull bones in pregnant belly; 7 skull bones in pregnant belly + inlay with slash through person taking pills | Comprehension | No
Peters et al., 2007^188^ (Study 1) | RCT (303) | Fair | 50% Low (score less than 10 on DR Numeracy Test) | Nonordered, nonquality info. | 1. Ordered cost, quality, non-quality info.; 2. Cost and quality info. only | Comprehension, choice of higher quality option | Yes
Peters et al., 2007^188^ (Study 2) | RCT (303) | Fair | 50% Low (score less than 10 on DR Numeracy Test) | Numbers only | 1. essential info (e.g. death rates) accompanied by black/white symbols; 2. essential info (e.g. death rates) accompanied by traffic symbols; 3. essential and non-essential info (e.g. death rates and satisfaction) accompanied by black/white symbols; 4. essential and non-essential info (e.g. death rates and satisfaction) accompanied by traffic symbols | Comprehension, choice of higher quality option | Yes
Peters et al., 2007^188^ (Study 3) | RCT (303) | Fair | 50% Low (score less than 10 on DR Numeracy Test) | Lower number is better quality, no symbols | 1. Higher number is better quality, no symbols; 2. Lower number is better quality, symbols; 3. Higher number is better quality, symbols | Comprehension, choice of higher quality option | Yes
Seligman et al., 2005^181^ | cRCT (63 MDs, 182 pts) | Fair | 74% TOFHLA inadeq. 16% TOFHLA marginal | Usual Care for Diabetes | Physician notification of patients' health literacy status | Self-efficacy HgbA1c Physician use of effective communication strategies | No
Sudore et al., 2007^204^ Sudore et al., 2008^208^ | RCT (205) | Fair | 40% TOFHLA < 22 (inadeq. or marginal) | Standard Advanced Directive | Simplified Advanced Directive | Comprehension | No
Sudore et al., 2006^192^ | Quasi-, post-only (204) | Fair | 22% TOFHLA inadeq. 18% TOFHLA marginal | None | Simplified consent form | Comprehension | Yes^a^
Volandes et al., 2009^184^ | RCT (200) | Good | 18% ≤ 6^th^ grade on REALM 12% 7-8^th^ grade on REALM | Verbal narrative about advanced dementia | Verbal narrative + video showing features of advanced dementia | Knowledge Intent | Yes^a^
Walker et al., 2007^133^ | RCT (363) | Fair | 15% with REALM < 60 (9th grade) | Standard Arthritis Booklet | Standard Arthritis booklet + Mind Map | Knowledge | No
Wright et al., 2009^186^ | RCT (140) | Fair | 41% Low (incorrect answer to 1^st^ question on Lipkus numeracy scale) | Dispersed dot icon array (3 different risk magnitudes: 3%, 6%, 50%) | Grouped dot icon array (3 different risk magnitudes: 3%, 6%, 50%) | Comprehension | Yes
Yates and Pena, 2006^191^ | RCT (200) | Fair | 1.5% REALM < 7th grade^c^ 14% REALM 7-8th grade^c^ | Standard head trauma advice form | Simplified head trauma advice form | Comprehension | Yes^a^
Interventions using mixed interventions for low health literacy
Bosworth et al., 2005^201^ | RCT (588) | Fair | 38% low literacyd | Usual care | Tailored adherence intervention | Knowledge Adherence | No
Brock and Smith, 2007^220^ | Quasi-, pre-post (51) | Fair (although poor for adherence) | 55% REALM < 8th grade | NA | Adherence video on PDA | Knowledge Adherence | No
Davis et al., 2008^205^ | Quasi-, pre-post (101) | Fair | 49% REALM < 6th grade 22% REALM 7-8th grade | None | Weight loss intervention | Knowledge, Self-efficacy | No
DeWalt et al., 2006^202^ | RCT (127) | Fair | 41% S-TOFHLA inadeq. | Usual care + low literacy pamphlet on CHF | CHF self-management program | Knowledge Self-efficacy Behavior Quality of life Use of health care services | Yes^a^
Ferreira et al., 2005^196^ | cRCT (113 MDs, 1,978 pts) | Fair | 31% Low (< 9th grade on TOFHLA) Note: measured only in 19% of patients | Usual Care | Educational Intervention for Physicians and Patients on Colorectal Cancer screening | Use of Healthcare Services | Yes
Gerber et al., 2005^194^ | RCT (144) | Fair | 56% S-TOFHLA < 22 (inadeq. or marginal) | Usual care + computerized quizzes on diabetes-related concepts | Diabetes self-management intervention | Knowledge Self-efficacy HgbA1c Use of health care Services | Yes^a^
Jay et al., 2009^218^ | RCT (56) | Fair | 17% Limited literacy (score ≤ 22) on S-TOFHLA | Standard FDA materials explaining nutrition label | Nutrition label information card and video tutorial | Comprehension | Yes^a^
Kim et al., 2004^197^ | Quasi-, pre-post (92) | Fair | 23% S-TOFHLA < 22 (inadeq. or marginal) (15% inadeq. on TOFHLA) | None | Diabetes self-management intervention | Knowledge Behavior HgbA1c | Yes^a^
Kripalani et al., 2007^190^ | Quasi-, pre-post (242) | Fair | 42% REALM < 6th grade 37% REALM 7-8th grade | None | CHD adherence intervention (pill card) | Self-efficacy | No
Kripalani et al., 2007^203^ | RCT (303) | Fair | 38% REALM < 3^rd^ grade 18% REALM 4-6th grade 23% REALM 7- 8th grade | Handout, NOS Unclear if prostate content or other content | 1. Educational Intervention on Prostate Cancer Screening; 2. Cue to Discuss Prostate Cancer screening | Use of Healthcare Services | No
Kripalani et al., 2008^206^ | Quasi-, post only (408) | Fair | 21% REALM < 3^rd^ grade 25% REALM 4-6th grade 31% REALM 7-8th grade | No control | 1. Modified Print informed Consent with Oral Overview | Knowledge | Yes^a^
Murray et al., 2007^182^ | RCT (314) | Good | 29% “not literate” on S-TOFHLA (NOS) | Usual care | CHF adherence intervention | Adherence Quality of Life Use of Health care Services Cost | No
Paasche-Orlow et al., 2005^79^ | Quasi-, pre-post (73) | Fair | 22% S-TOFHLA Inadeq. | NA | Asthma Self-Management Intervention | Knowledge Adherence Asthma symptom control | Yes^a^
Robinson et al., 2008^207^ | Quasi-, pre-post (110) | Fair | Mean Gilmore Oral Reading Test Score: 3.2 | NA | Asthma Self-Management Intervention | Self-efficacy Use of Healthcare Services | Yes^a^
Rothman et al., 2004^198^ | Quasi-, pre-post (159) | Fair | 55% Lower literacy 32% REALM ≤ 3^rd^ grade 23% REALM Score 4-6th grade | NA | Diabetes Self-Management Intervention | HgbA1c (and other biomarkers) | Yes
Rothman et al., 2004^183^ Rothman et al., 2006^250^ | RCT (217) | Good | 38% REALM ≤ 6th grade | 1-hour education session | Diabetes Self Management Intervention | HgbA1c (and other biomarkers) | Yes^a^
Rudd et al., 2009^209^ | RCT (127) | Fair | 19% REALM ≤ high school | Arthritis Management Intervention (arthritis pamphlet, medicine calendar, hospital map) | Arthritis Management Intervention + Individual Counseling | Self-efficacy, Adherence, Quality of Life | No
Schillinger et al., 2008^187^ Schillinger et al., 2009^210^ | RCT (339) | Fair | 59% S-TOFHLA ≤ 22 (inadeq. or marginal) | Usual care | 1. Diabetes Self Management Program (automated telephone delivery); 2. Diabetes Self-Management Program (group medical visit delivery) | Self-efficacy Behavior Hgba1c (and other biomarkers) Quality of life | No
Sobel et al., 2009^215^ | Quasi, pre-post (130) | Fair | 26% with low literacy (0-44 on REALM) 33% with marginal literacy (45-60 on REALM) | No control | Linear video tutorial about asthma and its management | Knowledge | Yes^a^
Wallace et al., 2009^211^ | Quasi-, pre-post (250) | Fair | 29% TOFHLA inadeq. 14% TOFHLA marginal | NA | Diabetes Self-Management Intervention | Knowledge Self-efficacy | Yes
Weiss et al., 2006^193^ | RCT (70) | Fair | Mean REALM score: 47 | Usual care | Adult Basic and Literacy Education (ABLE) | Depression Severity | No

a adjusted for relevant confounders;

b weighted percents;

c Read from Table;

d determined through personal communication with author

12-p= 12-point; ABLE=Adult Basic and Literacy Education; ARR=absolute risk reduction; AUA-SS=American Urological Association-Symptom Score; BPH=benign prostatic hyperplasia; CHD=coronary heart disease; CHF=congestive heart failure; cRCT=cluster randomized controlled trial; FDA=The Federal Drug Administration; HgbA1c=glycosylated hemoglobin; inadeq.inadequate; info.information; MDs= medical doctors; MIC= modified informed consent; MIC + SS=modified informed consent + slide show; NA=not applicable; NOS=not otherwise specified; PDA=personal digital assistant; pt=point; pts=patients; Quasi-=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy for Adults; RRR=relative risk reduction; S-TOFHLA=short form Test of Functional Health literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; US=United States; WRAT=Wide Range Achievement Test.

Table 44 Intervention study detail

Author | Description | Medium | # of sessions | Contact time | Who Delivered | Literacy Strategies | Individual Tailoring | Theory Driven | Pre-testing
Basic Interventions: Alternative Document Design
Greene et al., 2008^185^ | 1. Common presentation of information (vs. random presentation); 2. Short Framework (vs. long or no framework) | Print | 1 | NR | Researchers | Chunking of ideas | NA | NA | Yes^a^
Peters et al., 2007^188^ (study 1) | 1. Ordered info. (vs. unordered info.); 2. Essential info. (vs. nonessential info.) | Print | 1 | < 1 hour^a^ | Researchers | Ordering, Essential info. only | NA | NA | Yes^a^
Basic Interventions: Alternative Numerical Presentation
Galesic et al., 2009^217^ | Natural frequencies (x/10,000) Presented to illustrate the positive predictive value of genetic testing for early detection of diabetes or trisomy 21 | Print | 1 | <5 min^a^ | Self-administered on computer | Numerical simplification | NA | NA | Yes^a^
Garcia-Retamero and Galesic, 2009^219^ | Same (vs. different) denominators for baseline risk and treatment benefit | Print | 1 | 1-2 minutes | Self-administered on Computer | Numerical simplification | NA | NA | Yes^a^
Peters et al., 2007^188^ (study (3) | 1. Higher number better quality (vs. lower number better quality) | Print | 1 | < 1 hour^a^ | Researchers | Numerical simplification | NA | NA | Yes^a^
Basic Interventions: Additive and Alternative Pictorial Presentation
Galesic et al., 2009^216^ | Icon arrays (vs. none) | Print | 1 | <10 min^a^ | Self-administered on computer | Graphical presentation | NA | NA | Yes
Garcia-Retamero and Galesic, 2009^219^ | Icon arrays (vs. none) | Print | 1 | 1-2 minutes | Self-administered on Computer | Graphical presentation | NA | NA | Yes^a^
Hwang et al., 2005^195^ | Illustrations (vs. none) | Print | 1 | NR | Researchers | Graphics | NA | NA | No
Mayhorn and Goldsworthy, 2007^189^ | 7 alternate teratogen symbols | Print | 1 | 25 min | Researchers | Graphics | NA | NA | Yes
Peters et al., 2007^188^ (study (2) | 1. color symbols (vs. black-white or no symbols) | Print | 1 | < 1 hour^a^ | Researchers | Graphics, Color | NA | NA | Yes^a^
Peters et al., 2007^188^ (study (3) | 1. symbols to indicate higher/lower quality (vs. none) | Print | 1 | < 1 hour^a^ | Researchers | Graphics | NA | NA | Yes^a^
Walker et al., 2007^133^ | Mind map (vs. none) | Print | 1 | Unknown^a^ | Researchers^a^ | Conceptual depiction | NA | NA | No
Wright et al., 2009^186^ | Grouped dot icon arrays (vs. dispersed dot) | Print | 1 | NR | Researchers | Graphical simplification | NA | NA | NR
Basic Interventions: Alternative Media
Bryant et al., 2009^213^ | Print + Video BPH Symptom Score (vs. Print Score) | Video, Computer | 1 | 15 min^a^ | Researchers | Oral delivery, color-coding of symptom score answers, Visual demonstration of scoring | NA | NA | No^a^
Campbell et al., 2004^200^ | 1. Simplified consent form; 2. Video consent; 3. Computerized consent | Print, Video, Computer | 1 | < 1 hr | Researchers | Simple language, Chunking of ideas, White space, Pictures, Oral delivery | NA | NA | Yes^a^
Kang et al., 2009^212^ | 1. Modified informed consent form; 2. Modified informed consent + slide show | Print, Slide show | 1 | 10-15 min. for Print; length of slide show NOS | Self-administered, although researchers delivered slide show | 7th-grade reading level, large font, white space simple language, active voice, “action” cues Suitability Assessment of Materials score: 69% | NA | NA | Yes
Volandes et al., 2009^184^ | Verbal narrative + Video showing features of advanced dementia | Oral, Video | 1 | 2 min. | Researchers | Video | No | Yes^a^ | No
Basic Interventions: Alternative Reading Level and Document Design
Campbell et al., 2004^200^ | 1. Simplified consent form; 2. Video consent; 3. Computerized consent | Print, Video, Computer | 1 | < 1 hr | Researchers | Simple language, Chunking of ideas, White space, Pictures, Oral delivery | NA | NA | Yes^a^
Coyne et al., 2003^199^ | Simplified consent form (vs. standard form) | Print | 1 | NR | Researchers | 7th-8th grade reading level, Simple language, 1 idea per paragraph, Large font, White space, Pictures | NA | NA | No
Greene and Peters, 2009^214^ | Simplified Medicaid health plan comparison chart (vs. standard chart) | Print | 1 | 20 min^a^ | Self-administered | Simplified document complexity (high school reading level), font size, focus on differences in information ordering | NA | NA | Yes^a^
Kang et al., 2009^212^ | 1. Modified informed consent form; 2. Modified informed consent + slide show | Print, Slide show | 1 | 10-15 min. for Print; length of slide show NOS | Self-administered, although researchers delivered slide show | 7th-grade reading level, large font, white space simple language, active voice, “action” cues Suitability Assessment of Materials score: 69% | NA | NA | Yes
Sudore et al., 2007^204^ Sudore, 2008^208^ | Simplified advanced directive (vs. standard) | Print | 1 | < 30 min | Researchers | 5th-grade reading level, values clarification questions. Large Font, Graphics | NA | NA | No
Sudore et al., 2006^192^ | Simplified consent form | Print, Oral | 1 | 10 min | Researchers | 6th-grade reading level. Simple language, Large Font, Teach-back | NA | NA | No
Yates and Pena, 2006^191^ | Simplified instruction sheet (vs. standard form at same readability) | Print | 1 | 5-10 min | Researchers | Word reduction, Simple language, Chunking of ideas, Large Font, White space | NA | NA | Yes^a^
Basic Interventions: Provider Notification of Patient Literacy Status
Seligman et al., 2005^181^ | Provider notification of patient literacy level | Print | 1 | NA | Researchers | NA | NA | NA | No
Mixed Interventions: Adherence
Bosworth et al., 2005^201^ | Adherence intervention for HTN (education, skill building) | Telephone | ∼12 | 44 min (avg) | Nurses | Oral presentation, key concepts, information given to family/friend^a^ | Yes | Yes | No
Brock and Smith, 2007^220^ | Adherence intervention for HIV (education, skill building) | Video on PDA | 1 | 17 min | Self | Simple language, Pictures/Graphics | No | NR | Yes
Kripalani et al., 2007^190^ | Adherence intervention for CHD (pill card) | Individual Counseling, Print | 1^a^ | 5 min^a^ | Pharmacist | Pictures, Large Font | Yes | Social Cognitive Theory^a^ | Yes
Murray et al., 2007^182^ | Adherence intervention for CHF (education, graphic med labels, skill building, monitoring and feedback, provider communication) | Patient: Individual counseling, Print Provider: telephone, paging, email | Variable, range not available^a^ | ∼10-20 hours^a^ | Pharmacist | 6th grade reading level, Organization by mental schema, Lists/short paragraphs, Pictures | Yes | No (but patient-centered principles) | Yes
Mixed Interventions: Self-Management
DeWalt et al., 2006^202^ | Self Management intervention for CHF (education, skill building) | Individual counseling, Print, Telephone | 10 to 16 | Not measured^a^ | Pharmacist or Health Educator | 6th grade readability, Teach back | Yes | Social Cognitive Theory^a^ | Yes
Gerber et al., 2005^194^ | Self Management Intervention for DM (education, feedback) | Computer with audio/video | 2.9 on average^a^ | 53.5 min on average^a^ | Self | Audio/Video, Testimonials | Yes | Yes | No
Kim et al., 2004^197^ | Self Management Intervention for DM (NR) | Individual and group counseling | 4 | 10 hoursa | Diabetes Educators | 6th grade reading level^a^ | Noa | None^a^ | NA^a^
Paasche-Orlow et al., 2005^79^ | Self Management Intervention for Asthma (skill building) | Individual counseling, Print | 1 | 30 min+ | Researcher | Teach back | No | N | No
Robinson et al., 2008^207^ | Self Management Intervention for Asthma (literacy education, asthma education, skill building, goal setting, communication training) | Group counseling | 29 | 68 hrs | Trained facilitators, NOS | NR | No | NR | Yes for asthma, no for literacy
Schillinger et al., 2008^187^ Schillinger et al., 2009^210^ | 2 Self Management Interventions for DM (education, skill building) | 1. Telephone; 2. Group Counseling | 1 39 29 | 1. 312 min; 2. 810 min | 1. Automated Calls, Nurse; 2. PCP, health educator | Oral presentation^a^ | Yes^a^ | No^a^ | Yes^a^
Wallace et al., 2009^211^ | Self Management Intervention for DM (education, goal setting) | Individual counseling, Print, Telephone | 3 | 20-45 minutes based on measurement at 1 site | Researcher | Simple language, Conversational tone, Pictures | No | Yes | Yes
Mixed Interventions: Disease Management
Rothman et al., 2004^198^ | Disease Management Intervention for DM (education, trouble-shooting, med adjustment) | Individual counseling, Print, Telephone | ∼15^a^ | ∼336 min^a^ | Pharmacists | Simple language, Pictures, Simple organizational structure, Teach Back | Yes | No (general principles of Social Cognitive Theory applied) a | No^a^
Rothman et al., 2004^183^ | Disease Management Intervention for DM (education, skill building, med adjustment) | Individual counseling, Print, Telephone | 13+ | 463.2 min^a^ | Pharmacists or Diabetes Care Coordinators | Simple language, Pictures, Simplified organizational structure, Teach Back, Repetition | Yes | No (general principles of Social Cognitive Theory applied) a | Yes^a^
Mixed Interventions: Screening
Ferreira et al., 2005^196^ | Educational Intervention on Colorectal Screening | Provider: workshops Patient: Video, Print | Provider: 4-5 Patient: NR | Provider: 5-6 hr Patient: NR | Researchers | Provider: education on low health literacy communication strategies, NOSa Patient: Simple languagea | Providers: Yes Patients: No | Provider: none (although followed quality improvement principals) a Patient: Health Belief Modela | Providers: NR Patients: Yes
Kripalani et al., 2007^203^ | 1. Educational Intervention on Prostate Cancer Screening; 2. Cue to Discuss Prostate Cancer Screening | Print | 1^a^ | Not measureda | Researchers | Simple language, Pictures, Large Font, Key Concepts, Q and A | No | None^a^ | Yes
Mixed Interventions: Other
Davis et al., 2008^205^ | Weight loss Intervention | Provider: workshops (education) Patient: Video (education, motivation) | Provider: 2 Patient: 1 | Provider: 4 hr Patient: 15 min | Researchers | Physician: specific education interactions with low lit population Patient: 1^st^-2^nd^ grade readability, teach back | No | Yes | No
Jay et al., 2009^218^ | Nutrition label information card and video tutorial | Print, Video | 1 | ∼10-15 min | Researchers | Color, Chunking of ideas, Video | No | NR | Card: Yes Video: NR
Kripalani et al., 2008^206^ | 1. Modified Print Informed Consent with Oral Overview | 1. Print; 2. Individual oral education | 1 | 7-8 min on averagea | Researchers | 1. 8th grade readability, Chunking of ideas; 2. teach back | No | No | No
Rudd et al., 2009^209^ | 1. Arthritis Management Intervention (education, medicine calendar, hospital map); 2. Arthritis Management Intervention + Individual Counseling | Individual Counseling, Print | 1+^a^ | ∼1 hra | Arthritis Educator | 5th to 8th grade readability, Avoidance of jargon | Yes (intervention (2) | Social Cognitive Theorya | Yes^a^
Sobel et al., 2009^215^ | Linear video about asthma and its management | Video | 1 | 6-20 min | Researchers | Specific to content, Video, Small number of new concepts | Yes | NR | NA, pilot study
Weiss et al., 2006^193^ | Adult Basic and Literacy Education Intervention (education and job skill building) | Individual Counseling, Print, Computer | NR | 18.1 hr (range 0-74 hr) | Program Staff | 4th-grade readability, Short Sentences, Large Font, White Space, Avoid jargon | No | None (although focus on empowerment and locus of control) a | Yes^a^

a determined via personal contact with authors

AUA-SS=American Urological Association-Symptom Score; BPH=benign prostatic hyperplasia; avg=average; CHD=coronary heart disease; CHF=congestive heart failure; DM=diabetes; HIV=human immunodeficiency virus; hr=hour; HTN=hypertension; info.=information; med=medicine; min=minute; NA=not applicable; NOS=not otherwise specified; NR=not reported; PCP=primary care provider; PDA=personal digital assistant; Q and A=question and answer; RRR=relative risk reduction; vs.=versus.

Table 46 KQ 2 specific interventions: strength of evidence grades by type of outcome

Outcome | Number of Studies | Results | Overall Grade
Alternative Document Design | 2 RCTs examining multiple simplifications | Highlighting common quality features (n = 1): No effect Providing a framework for quality features (i.e., chunking advantages and disadvantages; n = 1): Improved comprehension for high literacy, worsened comprehension for low literacy if long rather than short list of features Presenting only essential quality info (i.e., death rates, not satisfaction) (n = 1): Improved comprehension and choice of higher quality plans Presenting essential quality info first (n = 1): Improved comprehension for low literacy only, no effect on health plan choice | Insufficient
Alternative Numerical Presentation | 3 RCTs examining different numerical presentations | Presenting quality information such that the higher number (vs. lower number) is better: Improved comprehension and choices of higher quality options for low (but not high) numeracy individuals Presenting information about the baseline risk of disease and treatment benefit information with the same vs. different numbers: Improved accuracy of risk perception with greater effect in low vs. high numeracy group Presenting positive predictive values as natural frequencies rather than conditional probabilities: improved comprehension equally for low and high literacy individuals | Low
Alternative Pictorial Representations | 6 RCTs and 2 quasi-experimental studies examining (1) adding symbols to numerical information, (2) adding icon arrays to numbers, (3) adding illustrations to prose, (4) using different pictorial representations for same concept | Adding symbols to numerical info (n = 2): Mixed effects depending on the symbols and the information to which they were added. Plus/minus signs to indicate fewer/more had no overall effect, although there was an interaction by whether higher quality was indicated by higher or lower numbers. Black and white and colored traffic light circles had no effect on comprehension, but increased the proportion of individuals choosing high quality hospitals. However, there was an interaction by (1) whether essential (i.e., death rates) or both essential and non-essential (i.e., death rates and satisfaction) quality information was presented, and (2) by numeracy level. Adding icon arrays to numbers (n = 2): Improved understanding of both ARR and RRR presentations when icons were added. Interaction by (1) numeracy level, and (2) whether numbers and icon arrays depicted baseline risk and the risk following treatment with the same or different denominators. Adding illustrations to prose (n = 2): No effect of mind map added to brochure or illustrations added to simple medication label text Using different pictorial representations for the same concept (n = 2): No overall improvement with grouped (vs. random) icon arrays, although interaction by numeracy level. Some teratogen warning symbols | Insufficient
Alternative Media | 4 RCT examining alternate media; 3 examining adding or substituting other media for print and 1 examining adding video to verbal narrative | Effect of adding or substituting for print (n = 3): Effect for adding video, computer, or slide show presentations to print were mixed. Effect for simplified print were mixed depending on the reading level of the printed materials and study design and quality Effect of adding video to verbal narrative (n = 1): Improved knowledge and preference for comfort care. | Insufficient
Alternative Readability and Document Design | 6 RCTs, 1 quasi-experimental study with post-only data | Mixed results depending on degree of simplification, literacy level of population, and study quality | Insufficient
Physician Notification of Patient Literacy Status | 1 cRCT | No effect on patient level outcomes | Low

RCTs=randomized controlled trials; info=information; vs.=versus; cRCT=cluster randomized controlled trial

Table 53 KQ 2 Mixed interventions: strength of evidence grades by type of outcome

Outcome | Number of Studies | Results | Overall Grade
Use of Healthcare Services | 4 RCTs, 1cRCT, and 1 quasi-experimental study | Preventive services (n = 2): Increased use across literacy levels ED visits (n = 2): Reduced use across literacy levels Hospitalizations (n = 3): Reduced use (or trends toward reduced use) across literacy levels; greater reductions in low literacy population | Moderate
Knowledge | 3 RCTs and 7 quasi-experimental studies (including 2 with post-test only data on knowledge, which precluded conclusions) | Mixed results with 4 of 8 studies with interpretable data showing an effect on knowledge | Insufficient
Self Efficacy | 4 RCTs and 5 quasi-experimental studies | Mixed results depending on intensity of intervention; for intensive interventions although these analyses for these interventions weren't stratified by literacy level | Insufficient
Skill | 1 RCT | Improved label reading skill with greater effect in those with high literacy (However, 2 studies from 2004 review found mixed results) | Insufficient^a^
Behavior | 2 RCTs and 1 quasi-experimental study | Improved self-management behaviors, greater improvement in adequate literacy group in the 1 study that performed analysis stratified by literacy level | Moderate
Adherence | 3 RCTs and 2 quasi-experimental studies (1 with post-test only data) | Mixed results related to the intensity of the intervention and measure of adherence | Insufficient
Disease Prevalence and Severity | 4 RCTs, 3 quasi-experimental studies | Self-management programs (n = 3): mixed effects on biomarkers depending on study quality Disease management programs (n = 2): improved HbA1c in low literacy group, improved BP across literacy levels Adult Basic and Literacy Education (n = 1): improved depression severity across literacy levels | Self-management programs: Insufficient Disease management programs: moderate Adult basic and literacy education: low
Quality of Life | 4 RCTs (1 measured QoL only post-test in intervention group) | Mixed results | Insufficient
Costs | 2 RCT | Non-significant trend toward reduced cost across literacy groups | Insufficient

a data from 2004 review modified the overall strength of evidence from low to insufficient

RCTs=randomized controlled trials; HbA1c=glycosylated hemoglobin; BP=blood pressure; QoL=quality of Life; cRCT=cluster randomized controlled trial; ED=emergency department

Table 47 Single intervention strategies: alternative numerical presentation

Author, Date of Publication, Quality | Study design | Control | Intervention | Sample Size | % population with Limited Literacy/ Numeracy | Outcomes | Difference
Peters et al., 2007^188^ (Study 3) Fair | RCT | Lower is better, no symbols | 1. higher is better, no symbols; 2. lower is better, symbols; 3. higher is better, symbols | 303 | 50% (score < 10 on DR Numeracy Test) | Mean # correct responses to comprehension questions (range 0-4) % choosing higher quality hospital | Higher is better vs. Lower is better (unadjusted): Comprehension: Overall: +0.4, (P < 0.001) High literacy Subgroup:+0.2, NS Low literacy Subgroup: +0.7 a, (P < 0.01) Choice: Overall: +13%, (P < 0.01) High Literacy Subgroup: NR (interaction by symbols) Low Numeracy Subgroup: +20% a, (P < 0.05) Symbols vs. No Symbols: Comprehension: Overall: NR, P < 0.10 High Literacy Subgroup: -0.3a, (P < 0.05) Low Literacy Subgroup: -0.1^a^, NR Choice: Higher Literacy Subgroup: -7%a, NR Lower Literacy Subgroup: +5%a, NR Higher # better, no symbols vs. Control: High Literacy Subgroup: Comprehension: +0.3, NR Choice: -4% Low Literacy Subgroup: Comprehension: +0.3, NR Choice: +26%, (P < 0.05) Lower # better + symbols vs. Control (unadjusted): High Literacy Subgroup: Comprehension: -0.2, NR Choice: -19% Low Literacy Subgroup: Comprehension: -0.2, NR Choice: +12%, NR Higher # better + symbols vs. Control (unadjusted): High Literacy Subgroup: Comprehension: -0.1, NR Choice: +1% Low Literacy Subgroup: Comprehension: +0.5, NR Choice: +25%, (P < 0.05)
Galesic et al., 2009^217^ Fair | RCT | Information about genetic testing for early detection of diabetes or trisomy 21 presented as conditional probabilities (% with condition, probability of + test with disease, probability of negative test with disease) | Natural frequencies (x/10,000) Presented to illustrate the positive value of genetic testing for early detection of diabetes or trisomy 21 | 162 (47 older adults, 115 younger adults) | Mean numeracy on 12-pt scale derived from Lipkus & Schwartz: Overall: 9.7 Older adults: 8.6 Younger adults: 10.3 | % Accurately perceiving risk | Natural frequency vs. conditional probability overall (unadjusted): NR, (P = 0.001) High numeracy vs. low numeracy, overall (unadjusted): NR, (P +0.01) Absolute difference in accurate answers (% all correct) by numeracy (unadjusted): High numeracy (natural frequency vs. conditional probability): + 24%^a^, NR Low numeracy (natural frequency vs. conditional probability): +27%^a^, NR Absolute difference (younger vs. older, overall): NR, (P = 0.31)
Garcia-Retamero et al., 2009^219^ Fair | Factoria l RCT | Numerical information with different denominators for baseline risk and treatment benefit (800/100 or 100/800) | Numerical information with the same denominators for baseline risk and treatment benefit (800/800 and 100/100) | 1047 (534 from German, 513 from US) | 49% Low numeracy (> median score on 9-item scale adapted from Lipkus and Schwartz) (Germany: 49%^b^, US: 48%^c^) | % Accurate perception of risk reduction | % accurate, same versus different denominators (with or without icon arrays): Low numeracy: +25%^c^, P not reported High numeracy: +16%^c^, P not reported Overall effect of denominator: not reported, adjusted (P = 0.001) Overall effect of numeracy: adjusted (P = 0.001)

a Calculated by reviewers;

b Weighted percent;

c Calculated by research team

12-pt=12-point; NR=not reported; NS=not significant; RCT=randomized controlled trial; vs.=versus.

Table 48 Single intervention strategies: additive and alternative pictorial representation

Author, Date of Publication, Quality | Study design | Control | Intervention | Sample Size | % Population with Limited Literacy | Outcomes | Difference
Galesic et al., 2009^216^ Fair | Factorial RCT | No icon arrays (either ARR or RRR numerical presentation) | Icon arrays | 171 (59 older adults, 112 students) | Mean numeracy on 12-pt scale derived from Lipkus & Schwartz: Older adults: 8.6 Students: 10.3 | % Accurately perceiving risk | Older adults, high numeracy: Icons vs Numerical RRR (unadjusted): +11%, NS^a^ Icons vs Numerical ARR (unadjusted): +5%, NS^a^ Older adults, low numeracy: Icons vs Numerical RRR (unadjusted): +75%, sig^a^ Icons vs. Numerical ARR (unadjusted): +30%, sig^a^ Students, high numeracy: Icons vs Numerical RRR (unadjusted): +23%,sig^a^ Icons vs Numerical ARR (unadjusted): -1%, NS^a^ Students, low numeracy: Icons vs Numerical RRR (unadjusted): +24%, NS^a^ Icons vs Numerical ARR (unadjusted): +21%, NS^a^ Overall p for numerical format (ARR vs RRR): +49%^b^, (P = 0.001) overall p for icon array (yes/no):+23%^b^ (P = 0.002)
Garcia-Retamero et al., 2009^219^ Fair | Factorial RCT | Numerical information only (including varying sizes of denominator) | Numerical information plus icon array (including information presented with varying sizes of denominators) | 1047 (534 from German, 513 from US) | 49% Low numeracy (> median score on 9-item scale adapted from Lipkus and Schwartz) (Germany: 49%^c^, US: 48%^c^) | % Accurate perception of risk reduction | Accurate estimates difference (when size of denominators different; unadjusted): Low numeracy: +32%c, P NR High numeracy: +11%c, P NR Accurate estimates difference (when size of denominator same; unadjusted): Low numeracy: +11%c, P NR High numeracy: -16%c, P NR Interactions between numeracy and icon arrays (P = 0.008) and size of denominators and icon arrays (P = 0.001)
Hwang et al., 2005^195^ Fair | Quasi-(post-post) | Medication label text:; A. Take with water; B. May cause drowsiness; C. Take with food; D. No alcohol; E. Take on an empty stomach | Medication label text + illustration | 130 | 5% REALM ≤ 6th grade 22% REALM 7th-8th grade | % correctly interpreting prescription label | Change in Interpretation of Label B with illustration: Improved: 5 No Change: 87% Worse: 9% (unadjusted P = 0.33) Change in Interpretation of Label E with illustration Improved: 7% No Change: 86% Worse: 7% (unadjusted P = 1.00) Note: change in interpretation of labels A, C, D = 0
Mayhorn and Goldsworthy, 2007^189^ Fair | Quasi-(post only) | Original teratogen symbol (slash through pregnant woman) | 1 Original symbol, but woman taking pill; 2 Cross and skull bones in pregnant belly; 4 2 pictures: Original symbol + skull bones in pregnant belly; 5 2 pictures: #4 but more caricatured; 6 1 picture combining original symbol + skull bones in pregnant belly; 7 skull bones in pregnant belly + inlay with slash through person taking pills | 700 | 42.9% Low literacy (REALM, NOS) | % Who correctly identify symbol meaning as “don't take if pregnant” % Who correctly identify symbol as “causes birth defect” | “Don't take if pregnant” (x versus original symbol 3); - Symbol 1 +4%, NR; - Symbol 2: -8%, NR; - Symbol 4: +3%, NR; - Symbol 5: +8%, NR; - Symbol 6: -29%, NR; - Symbol 7: -10%, NR; “Causes birth defects” (x versus original symbol 3); - Symbol 1: -1%, NR; - Symbol 2: +14%, NR; - Symbol 4: +19%, NR; - Symbol 5: +14%, NR; - Symbol 6: +4%, NR; - Symbol 7: +15%, NR; Note: addition of text that says “causes birth defects” increase understanding for all
Peters et al., 2007^188^ (Study 2) Fair | RCT | Numbers only | 1. essential info (e.g. death rates) accompanied by black/white symbols; 2. essential info (e.g. death rates) accompanied by traffic symbols; 3. essential and non-essential info (e.g. death rates and satisfaction) accompanied by black/white symbols; 4. essential and non-essential info (e.g. death rates and satisfaction) accompanied by traffic symbols | 303 | 50% (Median split) | Mean # of correct comprehension questions (range 0-3) % choosing higher quality hospital | Symbols vs. Numbers (unadjusted): Overall: Comprehension: NR, NS Choice: +14%, (P < 0.05) High Numeracy Subgroup: Comprehension: NR Choice: +18%^c^, NR Low Numeracy Subgroup: Comprehension: NR Choice: -5%^c^, NR p for interaction by numeracy: Comprehension: (P < 0.001) Choice: NR Colored vs. B & W symbols (unadjusted): Overall: Comprehension: NR Choice: +3%^d^, NS High Literacy Subgroup: Comprehension: NR Choice: 16%^d^, (P < 0.05) Low Literacy Subgroup: Comprehension: NR Choice: -11%^d^, NS Effect of Symbols on Choice: Essential info with B&W symbols (unadjusted): High Literacy Subgroup: +12%, NR Low Literacy Subgroup: +11%, NR Essential info with traffic light symbols (unadjusted): High Literacy Subgroup: +29%, NR Low Literacy Subgroup: +6%, NR Essential and non-essential info with B&W symbols (unadjusted): High Literacy Subgroup: +7%, NR Low Literacy Subgroup: -9%, NR Essential and non-essential info with traffic light symbols (unadjusted): High Literacy Subgroup: +22%, NR Low Literacy Subgroup: -26%, NR p for interaction (essential vs. non-essential): P < 0.05 p for interaction (literacy level): P < 0.05
Peters et al., 2007^188^ (Study 3) Fair | RCT | Lower number is better quality, no symbols | 1. higher number is better quality, no symbols; 2. lower number is better quality, symbols; 3. higher number is better quality, symbols | 303 | 50% (score < 10 on DR Numeracy Test) | Mean # correct responses to comprehension questions (range 0-4) % choosing higher quality hospital | Symbols vs. No Symbols (unadjusted): Comprehension: Overall: NR, P < 0.10 High Literacy Subgroup: -0.3 c, (P < 0.05) Low Literacy Subgroup: -0.1^d^, NR Choice: Higher Literacy Subgroup: -7%^c^, NR Lower Literacy Subgroup: +5%^c^, NR Higher # better, no symbols vs. Control (unadjusted): High Literacy Subgroup: Comprehension: +0.3, NR Choice: -4% Low Literacy Subgroup: Comprehension: +0.3, NR Choice: +26%, (P < 0.05) Lower # better + symbols vs. Control (unadjusted): High Literacy Subgroup: Comprehension: -0.2, NR Choice: -19%, P not reported Low Literacy Subgroup: Comprehension: -0.2, NR Choice: +12%, P, NR Higher # better + symbols vs. Control (unadjusted): High Literacy Subgroup: Comprehension: -0.1, NR Choice: +1% Low Literacy Subgroup: Comprehension: +0.5, NR Choice: +25%, (P < 0.05)
Walker et al., 2007^133^ Fair | RCT | Standard Arthritis Booklet | Standard Arthritis booklet + Mind Map | 363 | 15% REALM < 60 (9th grade) | Mean Rheumatoid Arthritis Knowledge Score (range -40 to 40) | Overall: -0.11, (unadjusted P > 0.3) Note: REALM score predicts change in knowledge, (adjusted P < 0.003)
Wright et al., 2009^186^ Fair | RCT | Dispersed dot icon arrays (3 different risk magnitudes: 3%, 6%, 50%) | Grouped dot icon arrays (3 different risk magnitudes: 3%, 6%, 50%) | 140 | 41% Low (incorrect answer to 1st question on Lipkus numeracy scale) | % correctly identifying largest of 3 displayed risks | Grouped vs. dispersed dot icon arrays, adjusted OR comprehension: 2.26 (95% CI 0.779 to 6.57) d Comprehension with grouped dot icon array (unadjusted OR high vs. low numeracy): 3.830 (95% CI, 1.301-11.280) Comprehension with dispersed dot icon array (unadjusted OR high vs. low numeracy): 10.2, CI, NR Interaction term (display by numeracy): NS

a difference calculated by research team, significance read from figure;

b Calculated by research team;

c Weighted percents;

d Calculated by research team

12-pt=12-point; ARR=absolute risk ratio; B&W symbols=black and white symbols; CI=confidence interval; e.g.=example; info=information; NOS=not otherwise specified; NR=not reported; NS= not significant; OR=odds ratio; Quasi-=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; RRR=relative risk ratio; sig=significant; US=United States; vs.=versus.

Table 49 Single intervention strategies: alternative media

Author, Date of Publication, Quality | Study design | Control | Intervention | Sample Sizes | % Population Limited Literacy | Outcomes | Difference
Bryant et al., 2009^213^ Fair | RCT | | Multimedia computer version of American Urological Association's BPH symptom score AUA-SS | 232 | 28% < high school on REALM Mean REALM score: 59 | Mean number of errors on AUA-SS compared with health-professional-administered AUA-SS % understanding AUA-SS questions (i.e. less than 2-pt difference between experimental derived and interviewer derived scores) Accuracy of categorical classification on AUA-SS | Mean symptom score error: Overall (multimedia-written): -1.51 (P < 0.001) ≥ HS: -1.24 (P <0.001) < HS: -2.31 (P 0.03) % understanding of questions overall (multimedia-written): 19% (P NR) ≥ HS: +18% (P NR) < HS: +25% (P NR) Accuracy of classification: +13% (P = 0.04)
Campbell et al., 2004^200^ Fair | RCT | Standard print consent form | 1. Simplified print consent form; 2. Video consent; 3. Computerized consent | 233 | 50% Low (≤ 8th grade reading level on Woodcock Johnson) Average REALM score 56.3 | % of total information remembered on free recall % of correct answers on prompted recall | % of total information remembered on free recall (adjusted): Simplified vs. standard: +0.1%, NS Video vs. standard: 0.1% < NS Computer vs. standard: -0.1%, NS Note: No interaction by literacy level (unadjusted) % correct answers on prompted recall (adjusted): Simplified vs. standard: +6%, NS Note: Trend toward improvement in low literacy group (unadjusted) Video vs. standard: +3%, NS Computer vs. standard: +4%, (P = 0.08)
Kang et al., 2009^212^ Fair | RCT | Standard informed consent | 1. MIC form; 2. MIC + slide show; (MIC + SS) | 90 | Patient: Median REALM and WRAT scores: high school Parent: Median REALM and WRAT scores: high school Note: Intervention delivered to patient and parent | % with combined recall of info and comprehension | Combined recall and comprehension (unadjusted): Patient: MIC vs. control: +6.5%^a^, NS MIC +SS vs. control: -1.2%^a^, NS Note: recall improves with MIC + SS (10.5%, P < 0.05), comprehension does not (+6.3%, NS) Parent: MIC vs. control: 1.4%^a^, NS MIC + SS vs. control: +10.0^a^, (P < 0.05) Note: recall improves with MIC + SS (+8.9^a^, P < 0.05), so does comprehension (+11.6%^a^, P < 0.001)
Volandes et al., 2009^184^ Good | RCT | | Verbal narrative + Video showing features of advanced dementia | 200 | 18% ≤ 6th grade on REALM 12% 7-8th grade on REALM | Mean knowledge on 5-point scale (higher scores better) % Preferring comfort care | Mean knowledge: Unadjusted difference: +0.9, (P < 0.001) Overall preference for comfort care: Unadjusted difference: +22% (95% CI, 11% to 34%) Adjusted OR: 3.9 (1.8-8.6) Preference for comfort care by HL group: Unadjusted differences: ≤ 6th grade HL: ref 7th-8th grade HL: 13% (-13 to 38%) ≥ 9th grade HL: 39% (21% to 56%) Adjusted OR: ≤ 6th grade HL: ref 7th-8th grade HL: 1.7 (0.54-5.3) ≥ 9th grade HL: 4.1 (1.6-10.8)

a Calculated by research team

2-pt=2-point; AUA-SS=American Urological Association-Symptom Score; BPH=benign prostatic hyperplasia; CI=confidence interval; HL=health literacy; HS=high school; info=information; MIC=modified informed consent; MIC + SS=modified informed consent + slide show; NR=not reported; NS=not significant; OR=odds ratio; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; ref=reference; vs.=versus; WRAT=Wide Range Achievement Test.

Table 50 Single intervention strategies: Alternative readability and document design

Author, Date of Publication, Quality | Study design | Control | Intervention | Sample Size | % Population with Limited Literacy | Outcomes | Difference
Campbell et al., 2004^200^ Fair | RCT | Standard print consent form | 1. Simplified print consent form; 2. Video consent; 3. Computerized consent | 233 | 50% Low (≤ 8th grade reading level on Woodcock Johnson) Average REALM score 56.3 | % of total information remembered on free recall % of correct answers on prompted recall | % of total information remembered on free recall (adjusted): Simplified vs. standard: +0.1%, NS Note: No interaction by literacy level % correct answers on prompted recall (adjusted): Simplified vs. standard: +6%, NS Note: Trend toward improvement in low literacy group
Coyne et al., 2003^199^ Fair | RCT | Standard Consent Form | Simplified consent form | 44 oncology groups 226 patients | Mean REALM: 65 | % of answers correct to 23 comprehension questions Note: Also measured decision to participate | Overall difference (unadjusted): 3%, (P = 0.21)
Greene and Peters, 2009^214^ Fair | RCT | | Revised Medicaid health plan comparison chart with four key changes:; 1. List only the benefits with differences between plans; 2. Cost-sharing and benefit information in rows rather than columns; 3. Arranged plans from most generous to least generous based on cost-sharing and benefits (instead of alphabetically); 4. Increased font size to 10 (13 for headers) | 122 | 57% TOFHLA Cloze score ≤ 18 (out of 20) | Comprehension (# of correct answers) | Full index (unadjusted, out of 9): Overall: NR Low Lit: +0.1a, NS High Lit: +0.7a, NS Identifying subindex (unadjusted, out of 6): Overall: NR Low Lit: -0.2a, NS High Lit: +0.5a, NS Synthesizing Subindex (unadjusted, out of 3): Overall: NR Low Lit: +0.3a, NS High Lit: +0.1a, NS p for interaction for full and sub-indices < 0.05
Kang et al., 2009^212^ Fair | RCT | Standard informed consent | 1. Modified informed consent form (MIC); 2. Modified informed consent + slide show (MIC + SS) | 90 | Patient: Median REALM and WRAT scores: high school Parent: Median REALM and WRAT scores: high school Note: Intervention delivered to patient and parent | % with combined recall of info and comprehension | Combined recall and comprehension (unadjusted difference): Patient: MIC-control: +6.5%^a^, NS Parent: MIC-control: 1.4%^a^, NS
Sudore et al., 2006^192^ Fair | Quasi-(post only) | None | Simplified consent form | 204 | 22% TOFHLA Inadequate 18% TOFHLA Marginal | # of passes through the teach-to-goal consent process required to obtain consent # of comprehension statements missed on the first pass of questioning | Overall # of passes through teach to goal: 1: 28% 2: 53% 3: 20% Unadjusted P for literacy interaction: 0.02; 11% of those with inadequate literacy required only 1 pass whereas 36% of individuals with adequate literacy required only 1 pass Adjusted OR for requiring more than 1 pass (for each 1-pt decrease in s-TOFHLA): 1.04 (95% CI 1.00 to 1.07) # of comprehension statements missed on first pass questioning: 0: 28% 1: 30% 2 or more: 42% Adjusted OR for missing comprehension (for each 1-pt decrease in s-TOFHLA): 1.04 (95% CI 1.00 to 1.07)
Sudore et al., 2007^204^ Sudore et al., 2008^208^ Fair | RCT | Standard Advanced Directive | Simplified Advanced Directive | 205 | 40% TOFHLA < 22 (Inadequate or Marginal) | Knowledge of advance directive topics, Advance directive completion at 6 months Note: Also measure % of form completed | Knowledge (adjusted for baseline knowledge): +1%, (P = 0.30) Advance directive completed at 6 months (unadjusted): +11%, (P = 0.03)
Yates and Pena, 2006^191^ Fair | RCT | Standard head trauma advice form | Simplified head trauma advice form | 200 | 1.5% REALM < 7th gradeb 14% REALM 7th-8th gradeb | Mean comprehension score (range 0-10) | Median score: +1 correct: (unadjusted P < 0.0001) Adjusted OR comprehension (simplified versus std): 4.14 (2.19 -7.81) No interaction by literacy level

a Calculated by research team;

b Read from table

Lit=literacy; NR=not reported; NS=not significant; OR=odds ratio; Quasi-=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; std=standard; TOFHLA=Test of Functional Health Literacy in Adults; WRAT=Wide Range Achievement Test.

Table 51 Single intervention strategies: physician notification of patient literacy levels^a^

Author, Date of Publication, Quality | Study design | Control | Intervention | Sample Size | % Population Limited Literacy | Outcomes | Difference
Seligman et al., 2005^181^ Fair | cRCT | Usual Care for Diabetes | Physician notification of patients' health literacy status | 63 MDs 182 pts | 74% TOFHLA Inadequate 16% TOFHLA Marginal | % of physicians reporting use of > 3 communication enhancing strategies Mean patient Self-efficacy using Patient Enablement Instrument (range 0-12) Mean HgbA1c | % physicians with intensive use of communication strategies (adjusted OR): 4.7, 95% CI, 1.4-16.0 Note: trends toward differences for individual communication strategies of involving family/friends and referring to a nutritionist Patient Self-efficacy (adjusted): -0.3, (P = 0.61) HbA1c (adjusted): -0.27, 95% CI, -0.80-0.27

a Communication strategies include Involving family members or friends; referring to a nutritionist; using pictures of diagrams; referring to a diabetes educator; reviewed understanding of medications; spending time teaching about diabetes

CI=confidence interval; cRCT=cluster randomized controlled trial; HgbA1c=glycosylated hemoglobin; MDs=medical doctors; OR=odds ratio; pts=patients; TOFHLA=Test of Functional Health Literacy in Adults.

Table 52 Effect of mixed interventions on use of health care services

Author, Date of Publication, Quality | Study Design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference
DeWalt et al., 2006^202^ Fair | RCT | Usual Care + low literacy pamphlet on CHF | CHF Self-Management program | 127 | 41% S-TOFHLA inadequate | Hospitalization | Hospitalization or death: Overall: IRR (unadjusted) = 0.69 (95% CI, 0.40-1.19) Inadequate literacy subgroup: IRR (adjusted) = 0.39 (95% CI, 0.16-0.91) Marginal/adequate literacy subgroup: IRR (adjusted) = 0.56 (95% CI, 0.30-1.04)
Ferreira et al., 2005^196^ Fair | cRCT | Usual Care | Educational Intervention for Physicians and Patients on Colorectal Cancer screening | 113 MDs 1978 pts | 31% Low (< 9th grade on TOFHLA) Note: measured only in 19% of patients | % of patients for whom any CRC screening test^a^ is recommended in 18 months following visit % of patients for whom screening is completed within × timeframe | Difference in Any Recommendations: Overall: 6.6%, (P = 0.02) Literacy subgroup results NR Difference in Completion of Any Tests: Overall: 8.9%, (P = 0.003) Low Literacy Subgroup: 25.7%, (unadjusted P = 0.002)^b^ High Literacy Subgroup: 3%, (unadjusted P =0.65)^b^
Gerber et al., 2005^194^ Fair | RCT | Usual Care + computerized quizzes on diabetes-related concepts | Diabetes Self-Management Intervention | 144 | 56% S-TOFHLA < 22 (Inadequate or marginal) | Receipt of Recommended Medical Services (NOS) | Low Literacy Subgroup: Change Medical Care (adjusted): -0.29, NS High Literacy Subgroup: Change Medical Care (adjusted): -0.07, NS
Kripalani et al., 2007^203^ Fair | RCT | Handout, NOS Unclear if prostate content or other content | 1. Educational Intervention on Prostate Cancer Screening; 2. Cue to Discuss Prostate Cancer screening | 303 | 38% REALM < 3rd grade 18% REALM 4th-6th grade 23% REALM 7th-8th grade | PSA test ordered DRE documented | Education PSA test ordered (adjusted OR): 7.62; CI, 1.62-35.83 DRE documented (adjusted OR): 0.85; CI 0.21-3.37 Cue PSA test ordered (adjusted OR): 5.86; CI, 1.24-27.81 DRE documented (adjusted OR): 1.04; CI, 0.29-3.76
Murray et al., 2007^182^ Good | RCT | Usual Care | CHF Adherence Intervention | 314 | 29% “not literate” on S-TOFHLA (NOS) | ED visit Hospitalization | ED visits: Absolute difference(unadjusted): -0.52, NR Incidence rate ratio (unadjusted): 0.82 (0.70 to 0.95) Hospitalizations: Absolute difference (unadjusted): -0.21, NR Incidence rate ratio (unadjusted): 0.81 (95%, CI 0.64-1.04)
Robinson et al., 2008^207^ Fair | Quasi (pre-post) | NA | Asthma Self-Management Intervention | 110 | Mean Gilmore Oral Reading Test Score: 3.2 | Asthma-related ED visits: Asthma-related hospitalizations: | ED visits (unadjusted): - 29.6%, (P < 0.01) Interaction by literacy subgroup: adjusted OR for Effect of reading level on ER visits: 0.34 (0.22 - 0.52) Hospitalizations (unadjusted): -14.9%, (P < 0.001) Interaction by literacy subgroup: adjusted OR for effect of reading level on ER visits: 1.31 (0.82 to 2.10)

a any CRC screening test includes home fecal occult blood testing, sigmoidoscopy, and colonoscopy;

b adjusted only for effects of clustering of patients within providers

CHF=congestive heart failure; CI=confidence interval; CRC=colorectal cancer; cRCT=cluster randomized controlled trial; DRE=digital rectal examination; ED=emergency department; ER=emergency room; IRR=incidence rate ratio; MDs=medical doctors; NA=not applicable; NOS=not otherwise specified; NR=not reported; NS=not significant; OR=odds ratio; PSA= prostate specific antigen; pts=patients; Quasi=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; S-TOFHLA=short form Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults

Table 54 Effect of mixed interventions on knowledge

Author, Date of Publication, Quality | Design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference Between Control and Intervention Groups
Bosworth et al., 2005^201^ Fair | RCT | Usual Care | Tailored Adherence Intervention | 588 | 38% low literacy^a^ | Mean Change in Hypertension knowledge (score range 0 - 10) | Overall: 0, (unadjusted P = 0.49)
Brock and Smith, 2007^220^ Fair (although poor for adherence) | Quasi- (pre-post) | NA | Adherence Video on PDA | 51 | 55% REALM < 8th grade | Mean HIV and HIV medication Knowledge (9-pt. scale) | Overall: NR, (unadjusted P < 0.005)
Davis et al., 2008^205^ Fair | Quasi- (pre-post) | None | Weight loss intervention | 101 | 49% REALM < 6th grade 22% REALM 7th-8th grade | Patient recall of MD recs. to lose weight, increase physical activity or see a dietician | Patient recall of recommendations: Lose weight +43%, (unadjusted P = 0.02) Increase physical activity +41%, (unadjusted P = 0.01) Go to dietician +39%, (unadjusted P = 0.002)
DeWalt et al., 2006^202^ Fair | RCT | Usual Care + low literacy pamphlet on CHF | CHF Self-Management program | 127 | 41% S-TOFHLA inadeq. | % CHF Knowledge questions correct | Overall (adjusted): 12% (95% CI, 6-18%)
Gerber et al., 2005^194^ Fair | RCT | Usual Care + computerized quizzes on diabetes-related concepts | Diabetes Self-Management Intervention | 144 | 56% S-TOFHLA < 22 (Inadeq. or marginal) | Mean Change in Diabetes Knowledge (scale NR) | Low Literacy Change Knowledge (adjusted): -0.12, NS High Literacy Change Knowledge (adjusted): +0.3, NS
Kripalani et al., 2008^206^ Fair | Quasi- (post only) | No control | 1. Modified Print informed Consent with Oral Overview | 408 | 21% REALM < 3rd grade 25% REALM 4th - 6th grade 31% REALM 7th - 8th grade | Odds of correctly teaching back consent and HIPAA information on first attempt (relative to those with literacy level < 3rd grade | Correct teach back 1st attempt by literacy subgroup (adjusted): 4th - 6th grade - 2.259 (1.048-4.869) 7th - 8th grade - 2.275 (1.049-4.935) > 9th grade - 4.344 (1.814-10.404)
Kim et al., 2004^197^ Fair | Quasi- (pre-post) | None | Diabetes Self-Management Intervention | 92 | 23% S-TOFHLA < 22 (Inadeq. or marginal) (15% inadeq. on TOFHLA) | % Diabetes Knowledge Questions Correct | Overall (adjusted): NR, sig Adeq. vs. Inadeq. HL (adjusted): NR (+), (P < 0.001)
Paasche-Orlow et al., 2005^79^ Fair | Quasi- (pre-post; pre-test only for knowledge) | NA | Asthma Self-Management Intervention | 73 | 22% S-TOFHLA Inadeq. | Asthma Knowledge (range 0-10) % Mastering discharge medication regimen | Asthma Knowledge: NR % Mastering discharge medication regimen (baseline- 2 weeks): Overall (unadjusted): + 20%, NR; p for interaction by literacy: (P = 0.40)
Sobel et al., 2009^215^ Fair | Quasi-experimental (pre-post) | No control | Linear video tutorial about asthma and its management | 130 | 26% with low literacy (0-44 on REALM) 33% with marginal literacy (45-60 on REALM) | Mean score on 12 asthma knowledge questions (range 0-12) | Mean knowledge score (post-pre, unadjusted): +2.6 b, (P < 0.001) Mean knowledge score (post-pre, adjusted) compared to adequate literacy score: Adequate: reference Marginal: -0.8 (95% CI, -1.5 to -0.1) Low: -1.5 (95% CI, -2.3 to -0.6)
Wallace et al., 2009^211^ Fair | Quasi- (pre-post) | NA | Diabetes Self-Management Intervention | 250 | 29% TOFHLA inadeq. 14% TOFHLA marginal | % of Diabetes Knowledge questions correct | Overall (unadjusted): 6.16%, (P <0.001) Adequate Literacy subgroup (unadjusted): +6.94%, NR Marginal/inadequate Literacy subgroup (unadjusted): +5.21%, NR Unadjusted P for interaction by literacy level: 0.23

a Determined through personal communication with author;

b absolute difference calculated by research team

9-pt. scale=9-point scale; adeq.=adequate; CHF=congestive heart failure; CI=confidence interval; HIPAA=Health Insurance Portability and Accountability Act of 1996; HIV=human immunodeficiency virus; HL=health literacy; inadeq.=inadequate; MD rec.=physician's recommendations; NA=not applicable; NR=not reported; NS=not significant; PDA=personal digital assistant; Quasi-=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; sig=significant; S-TOFHLA=short form Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; vs.=versus.

Table 55 Effect of mixed interventions on self-efficacy

Author, Date of Publication, Quality | Study Design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference
Davis et al., 2008^205^ Fair | Quasi-(pre-post) | None | Weight loss intervention | 101 | 49% REALM < 6th grade 22% REALM 7th-8th grade | % patients reporting confidence in ability to lose weight | Overall (unadjusted): +27%, (P = 0.01)
DeWalt et al., 2006^202^ Fair | RCT | Usual Care + low literacy pamphlet on CHF | CHF Self-Management program | 127 | 41% S-TOFHLA inadeq. | Mean difference in CHF self-efficacy (range of scores 0-2(4) | Overall (adjusted): 2 (95% CI, 0.7-3.1)
Gerber et al., 2005^194^ Fair | RCT | Usual Care + computerized quizzes on diabetes-related concepts | Diabetes Self-Management Intervention | 144 | 56% S-TOFHLA < 22 (Inadeq. or marginal) | Change in Mean Diabetes Self-efficacy – (score range NR) | Low Literacy Change Self-efficacy (adjusted): +0.52, 0.113 High Literacy Change Self-efficacy (adjusted): -0.20, NS
Kripalani et al., 2007^190^ Fair | Quasi-(pre-post) | None | CHD adherence intervention (pill card) | 242 | 42% REALM ≤ 6th grade 37% REALM 7th-8th grade | Mean Self Efficacy for Appropriate Medication Use Scale (score range 13-39) | Overall (unadjusted): +2.5, NR
Robinson et al., 2008^207^ Fair | Quasi-(pre-post) | NA | Asthma Self-Management Intervention | 110 | Mean Gilmore Oral Reading Test Score: 3.2 | Mean Asthma Self Efficacy Scale (scale 40-100) | Overall (unadjusted): 10.4, (P < 0.001)
Rudd et al., 2009^209^ Fair | RCT | Arthritis Management Intervention (arthritis pamphlet, medicine calendar, hospital map) | Arthritis Management Intervention + Individual Counseling | 127 | 19% REALM ≤ high school | Mean self-efficacy (score range 1-4) | Overall at 12 mo. (adjusted): NR, (P = 0.12)
Schillinger et al., 2008^187^; Schillinger et al., 2009^210^ Fair | RCT | usual care | 1. Diabetes Self Management Program (automated telephone delivery); 2. Diabetes Self-Management Program (group medical visit delivery) | 339 | 59% S-TOFHLA ≤ 22 (inadeq. or marginal) | Mean Diabetes self-efficacy (0 -100 scale) | ATSM-Usual Care (adjusted): 6.0 (2.0 to 10.1) GMV-Usual Care (adjusted): 5.5 (1.4 to 9.6) ATSM-GMV (adjusted): 0.5 (-3.6 to 4.6)
Wallace et al., 2009^211^ Fair | Quasi-(pre-post) | NA | Diabetes Self-Management Intervention | 250 | 29% TOFHLA inadeq. 14% TOFHLA marginal | Mean diabetes self-care self-efficacy (0–100 scale) | Overall (unadjusted): 4.29, (P < 0.001) Adequate literacy subgroup (unadjusted): 4.8, NR Inadequate literacy subgroup (unadjusted): +3.67, NR Unadjusted P for interaction by literacy subgroup: 0.29

ATSM=automated telephone self-management support; ATSM-GMV=automated telephone self-management support-group medical visits; CHD=coronary heart disease; CHF=congestive heart failure; CI=confidence interval; GMV=group medical visits; inadeq.=inadequate; mo.=month; NA=not applicable; NR=not reported; NS=not significant; quasi-=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; S-TOFHLA=short form Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults.

Table 56 Effect of mixed interventions on skills

Author, Date of Publication, Quality | Design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference Between Control and Intervention Groups
Jay et al., 2009^218^ Fair | RCT | Standard FDA written materials | Nutrition label information card and video tutorial | 56 | 17% limited literacy (score ≤ 22) on S-TOFHLA | % correct on 12-item food label quiz | intervention-control (adjusted): Overall: + 11.8%^b,^ (P < 0.05) Adequate literacy: +23%^a^ Inadequate literacy: +1%^a^ p for interaction: < 0.05

a absolute difference calculated by research team

FDA=The Food and Drug Administration; RCT=randomized controlled trial; S-TOFHLA=short form Test of Functional Health Literacy in Adults

Table 57 Effect of mixed interventions on behavior

Author, Date of Publication, Quality | Study Design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference
DeWalt et al., 2006^202^ Fair | RCT | Usual Care + low literacy pamphlet on CHF | CHF Self-Management program | 127 | 41% S-TOFHLA inadequate | % weighing daily at 12 months | Overall (adjusted): NR, (P < 0.001)
Kim et al., 2004^197^ Fair | Quasi-(Pre-post) | None | Diabetes Self-Management Intervention | 92 | 23% S-TOFHLA < 22 (Inadequate or marginal) (15% inadequate on TOFHLA) | # self-care days in last 7 days | Overall (adjusted): NR, sig Adeq. vs. Inadeq. HL (adjusted): Diet: NR, (P < 0.001; Inadeq. better) Exercise: NR, (P = 0.022; Adeq. better) Foot care: NR, (P = 0.001; Inadeq. better) Medication adherence: NR, (P = 0.751) Self-glucose monitoring: NR, (P = 0.002; Inadeq. better)
Schillinger et al., 2008^187^; Schillinger et al., 2009^210^ Fair | RCT | Usual Care | 1. Diabetes Self Management Program (automated telephone delivery); 2. Diabetes Self-Management Program (group medical visit delivery) | 339 | 59% S-TOFHLA ≤ 22 (inadequate or marginal) | Mean # of days self care behavior performed in last 7 days (score range 0-7) Mean # minutes engaged in moderate or vigorous physical activity/week | Overall # self-care days: ATSM-Usual Care (adjusted): 0.6 (0.4 to 0.9) GMV-Usual Care (adjusted): 0.3 (0.01 to 0.6) ATSM-GMV (adjusted): 0.3 (0.1 to 0.6) Minutes of moderate physical activity: ATSM-Usual Care (adjusted): 123.9 (14.8 to 233.0) GMV-Usual Care (adjusted): 69.1 (-42.1 to 179.4) ATSM-GMV (adjusted): 54.8 (-62.1 to 186.3) Minutes of vigorous physical activity: ATSM-Usual Care (adjusted): 32.2 (-9.8 to 74.2) GMV-Usual Care (adjusted): 23.3 (-19 to 65.5) ATSM-GMV (adjusted): 8.9 (-33.7 to 51.5)

Adeq.=adequate; ATSM=automated telephone self-management support; ATSM-GMV=automated telephone self-management support-group medical visits; CHF=congestive heart failure; GMV=group medical visits; HL=health literacy; inadeq=inadequate; NR=not reported; Quasi=quasi-experimental study; RCT=randomized controlled trial; S-TOFHLA=short form Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults.

Table 58 Effect of mixed interventions on adherence

Author, Date of Publication, Quality | Study Design | Control Group | Intervention | Sample Size | % population with Limited Literacy | Outcome | Difference
Bosworth et al., 2005^201^ Fair | RCT | Usual care | Tailored Adherence Intervention | 588 | 38% low literacy^a^ | Change in % reporting agreement to any question in Morisky adherence scale | Overall change (unadjusted): 0.007% (95% CI, -0.62%-0.076%) Change among those initially adherent (unadjusted): -2%, (P = 0.68) Change among those initially non-adherent (unadjusted): +12%, (P = 0.08)
Kim et al., 2004^197^ Fair | Quasi-(pre-post) | None | Diabetes Self-Management Intervention | 92 | 23% S-TOFHLA < 22 (Inadequate or marginal) (15% inadequate on TOFHLA) | # days of Medication adherence in last week | Overall: +0.7^b^, NR Adeq. vs. Inadequate HL (adjusted): NR, (P = 0.751)
Murray et al., 2007^182^ Good | RCT | Usual Care | CHF Adherence Intervention | 314 | 29% “not literate” on S-TOFHLA (NOS) | % of prescribed medication taken (according to MEMS cap) | % of prescribed medication taken: During intervention (unadjusted): +10.9% (95% CI, 5%-16.7%) Post Intervention (unadjusted): +3.9% (-2.8%-10.7%)
Paasche-Orlow et al., 2005^79^ Fair | Quasi-(pre-post) | NA | Asthma Self-Management Intervention | 73 | 22% S-TOFHLA Inadequate | % with adherence less than 50% for inhalers or meds (according to Doser CT or MEMS cap) | Poor adherence, by literacy subgroups (adjusted): NR, p for interaction: (P = 0.45)
Rudd et al., 2009^209^ Fair | RCT | Arthritis Management Intervention (arthritis pamphlet, medicine calendar, hospital map) | Arthritis Management Intervention + Individual Counseling | 127 | 19% REALM < high school | Mean score on Levine medication adherence assessment (range 0-3, 3 best) | Mean percent change in medication adherence (unadjusted): 6 mo: -5.01%, p 0.33 12 mo: -9.09%, p 0.10

a Determined through personal communication with author;

b Calculated by team

Adeq.=adequate; CHF=congestive heart failure; CI=confidence interval; HL=health literacy; meds=medications; MEMS cap=Medication Event Monitoring System cap; NA=not applicable; NOS=not otherwise specified; NR=not reported; Quasi-=quasi-experimental study; RCT=randomized controlled trial; S-TOFHLA=short form Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; vs.=versus.

Table 59 Effect of mixed interventions on disease prevalence and severity

Author, Date of Publication, Quality | Study design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference
Gerber et al., 2005^194^ Fair | RCT | Usual Care + computerized quizzes on diabetes-related concepts | Diabetes Self-Management Intervention | 144 | 56% S-TOFHLA < 22 (Inadequate or marginal) | Mean Change in Hemoglobin A1C Mean Change in Systolic and Diastolic Blood Pressure (mmHg) Mean Change in Body Mass Index (kg/m2) | Low Literacy Subgroup (adjusted): Change in HgbA1C: -0.1, NS Change in SBP: -1 mmHg, NS Change in DBP: 3 mmHg, NS Change in BMI: NR, NS High Literacy Subgroup (adjusted): Change in HgbA1C: 0.0, NS Change in SBP: +1 mmHg, NS Change in DBP: -7 mmHg, NS Change in BMI: -1 kg/m2, NS Note: in exploratory subgroup analyses of Hgba1c > 9 (n = 26), intervention more effective than control for low literacy (but not high literacy) group
Kim et al., 2004^197^ Fair | Quasi-(pre-post) | None | Diabetes Self-Management Intervention | 92 | 23% S-TOFHLA < 22 (Inadequate or marginal) (15% inadequate on TOFHLA) | Mean HgbA1c | Overall (unadjusted): -1.3a, Sig Adeq. vs. Inadeq. HL (adjusted): NR, (P = 0.086)
Paasche-Orlow et al., 2005^79^ Fair | Quasi-(pre-post) | NA | Asthma Self-Management Intervention | 73 | 22% S-TOFHLA Inadequate | Mean score on asthma symptom questionnaire (range 0-6) | Overall: NR By subgroup: NR p for interaction: (P = 0.69)
Rothman et al., 2004^198^ Fair | Quasi -(Pre-post) | NA | Diabetes Disease Management Intervention | 159 | 55% Lower Literacy 32% REALM ≤ 3^rd^ grade 23% REALM Score 4th-6th grade | Mean HgbA1c | Lower Literacy Subgroup (unadjusted): -1.9% points (95% CI, -2.5 to -1.2) Higher Literacy Subgroup (unadjusted): -1.8% points (95% CI, -2.5 to -1.0)
Rothman et al., 2004^183^ Good | RCT | 1-hour education session | Diabetes Disease Management Intervention | 217 | 38% REALM ≤ sixth grade | Mean HgbA1c Systolic blood pressure | Overall (adjusted): SBP -7.6 mmHg (-13 to -2.2 mmHg) Low literacy subgroup: HgbA1c (adjusted): -1.4%; 95% CI, -2.3% to -0.6%) High literacy subgroup): HgbA1c (adjusted): -0.5%; 95% CI, -1.4%-0.3%
Schillinger et al., 2008^187^; Schillinger et al., 2009^210^ | RCT | Usual Care | 1. Diabetes Self Management Program (automated telephone delivery); 2. Diabetes Self-Management Program (group medical visit delivery) | 339 | 59% S-TOFHLA ≤ 22 (inadequate or marginal) | Mean Hemoglobin A1C Mean Systolic and diastolic blood pressure (mmHg) Mean Body Mass Index (kg/m^2^) | HgbA1C ATSM-Usual Care (adjusted): -0.1 (-0.5 to 0.4) GMV-Usual Care (adjusted): 0.2 (-0.2 to 0.7) ATSM-GMV (adjusted): -0.3 (-0.8 to 0.7) SBP ATSM-Usual Care (adjusted): -3.2 mmHg (-8.3 to 1.9 mmHg) GMV-Usual Care (adjusted): -3.9 mmHg (-9.0 to 1.2 mmHg) ATSM-GMV(adjusted): 0.7 mmHg (-4.5 to 5.9 mmHg) DBP ATSM-Usual Care(adjusted): -1.6 mmHg (-5.1 to 2.0 mmHg) GMV-Usual Care (adjusted): -3.1 mmHg (-6.6 to 0.4 mmHg) ATSM-GMV (adjusted): 1.5 mmHg (-2.0 to 5.1 mmHg) BMI ATSM-Usual Care (adjusted): 0.1 kg/m2 (-0.4 to 0.5 kg/m^2^) GMV-Usual Care (adjusted): 0.02 kg/m2 (-0.5 to 0.5 kg/m^2^) ATSM-GMV (adjusted): 0.1 kg/m^2^ (-0.4 to 0.5)
Weiss et al., 2006^193^ Fair | RCT | Usual care | Adult Basic and Literacy Education (ABLE) | 70 | Mean REALM score 47 | Mean depression severity score on Patient Health Questionnaire (score range 0-27) | Overall (unadjusted): 1st follow-up: 0, P = 0.25 2nd follow-up: -3, P = 0.03 3rd follow-up: -4, P = 0.04 Note baseline difference in REALM

a Calculated by team

ABLE=Adult Basic and Literacy Education; Adeq.=adequate; ATSM=automated telephone self-management support; ATSM-GMV=automated telephone self-management support-group medical visists; BMI=body mass index; CI=confidence interval; DBP=diastolic blood pressure; GMV=group medical visit-usual care; HgbA1c=glycosylated hemoglobin; HL=health literacy; inad=inadequate; NA=not applicable; NR=not reported; NS=not significant; Quasi-=quasi-experimental study; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; SBP=systolic blood pressure; sig=significant; S-TOFHLA=short form Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; vs.=versus

Table 60 Effect of mixed interventions on quality of life

Author, Date of Publication, Quality | Study Design | Control Group | Intervention | Sample Size | % population with Limited Literacy | Outcome | Difference
DeWalt et al., 2006^202^ Fair | RCT | Usual Care + low literacy pamphlet on CHF | CHF Self-Management program | 127 | 41% S-TOFHLA inadequate | CHF related Quality of Life by MLHF (range of scores 0-105) | Heart failure-related quality of life (adjusted): 2 (95% CI, 9 to -5) Adequate Health Literacy Subgroup (adjusted): -4.2 (95% CI -14 to 6) Inadequate Health Literacy Subgroup (adjusted): -1.6, 95% CI -15 to 12
Murray et al., 2007^182^ Good | RCT | Usual Care | CHF Adherence Intervention | 314 | 29% “not literate” on S-TOFHLA (NOS) | Mean score on Chronic Heart Failure Questionnaire (range from 1 to 7; better functioning = higher) | Within Intervention Group (unadjusted): +0.39
Rudd et al., 2009^209^ Fair | RCT | Arthritis Management Intervention (arthritis pamphlet, medicine calendar, hospital map) | Arthritis Management Intervention + Individual Counseling | 127 | 19% REALM ≤ high school | HAQ scores (range of scores 0 - 3, 0 best) | Mean percent change in HAQ scores at 12 months: 6 months: -3.60%^a^*, p 0.45 12 months: -2.12%^a^*, p0.64
Schillinger et al., 2008;^187^ Schillinger et al., 2009^210^ | RCT | Usual Care | 1. Diabetes Self Management Program (automated telephone delivery); 2. Diabetes Self-Management Program (group medical visit delivery) | 339 | 59% S-TOFHLA ≤ 22 (inadequate or marginal) | SF12-Mental health scale (score range 0 -100) SF-12 Physical health scale (score range 0-100) Mean # days in bed in last month due to health problems Extent to which diabetes limits normal activity (score range 0 - 5, lower = less) | SF-12 mental health: ATSM-Usual Care (adjusted): 3.7 (-2 to 9.4) GMV-Usual Care (adjusted): -2.9 (-8.6 to 2.9) ATSM-GMV (adjusted): -6.5 (0.7 to 12.4) SF-12 physical health: ATSM-Usual Care (adjusted): 2.7 (-4.0 to 9.5) GMV-Usual Care (adjusted): -0.1 (-6.9 to 6.7) ATSM-GMV(adjusted): 2.9 (-4 to 9.7) # Bed Days over prior month: ATSM-Usual Care (adjusted): -1.7 (-3.3 to -0.1) GMV-Usual Care(adjusted): 0.6 (-1.0 to 2.2) ATSM-GMV (adjusted): -2.3 (-3.9 to -0.4) Extent limited activity: ATSM-Usual Care: NR, (P = 0.02) GMV-Usual Care: NR, NS ATSM-GMV: NR, NS

a Calculated by research team

ATSM=automated telephone self-management support; ATSM-GMV=automated telephone self-management support-group medical visits; CHF=congestive heart failure; CI=confidence interval; GMV=group medical visits; HAQ=the Health Assessment Questionnaire; MLHF=the Minnesota Living with Heart Failure Questionnaire; NOS=not otherwise specified; NR=not reported; NS=not significant; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; SF-12 Mental health scale=12-item short-form mental health scale; S-TOFHLA=short form Test of Functional Health Literacy in Adults.

Table 61 Effect of mixed interventions on health care costs

Author, Date of Publication, Quality | Study design | Control Group | Intervention | Sample Size | % Population with Limited Literacy | Outcome | Difference
Murray et al., 2007^182^ Good | RCT | Usual Care | CHF Adherence Intervention | 314 | 29% “not literate” on S-TOFHLA (NOS) | Total intervention, outpatient, and inpatient costs | -$2960 (95% CI, -$7603-$1338)
Rothman et al., 2004^183^ Rothman et al., 2006^250^ Good | RCT | Usual Care + Education Session | Diabetes Disease Management Intervention | 217 | 38% REALM ≤ sixth grade | Labor costs for intervention delivery; Total costs (labor costs + indirect costs) | Labor costs: $25.50 per patient per month (Sens. analysis $12.01 to $55.35 per patient per month) Total costs: $36.97 per patient per month (Sens. Analysis $16.22 to $88.56 per patient per month)

CHF=congestive heart failure; CI=confidence interval; NOS=not otherwise specified; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; sens.=sensitivity; S-TOFHLA=short form Test of Functional Health Literacy in Adults

Because this report is an update, we needed to integrate findings from our first review in 2004 with those of our current review. To do this, we reorganized findings from the first review using the organizational structure described above and note in each section how results from the first review are similar to or different from current findings and whether they modify our current conclusions.

To facilitate conclusions, we provide insights based on observations about the common features of effective interventions. These “cross-cutting” observations are presented at the end of the chapter.

## Search Results

We identified 56 articles reporting on 53 unique studies to include in our updated review.

## Study Quality

Of all 53 studies, we rated 3 as good quality182-184 and 38 studies as fair quality.79,133,181,185-219 One additional study was rated fair for intermediate outcomes and poor for followup outcomes.220 Finally, we rated 11 studies as poor quality and excluded them from further review.221-231

## Characteristics of Included Studies

Below we report on the 42 good- or fair-quality studies identified in our updated review. Included studies had a wide variety of designs (Table 43). Across all 42 studies, 27 were randomized controlled trials (RCTs), two were cluster randomized trials, and 13 were quasi-experimental studies.

With respect to interventions, 21 used one specific strategy to mitigate the effects of low health literacy and 21 used a mixture of strategies combined into one intervention (Table 44). Of intervention studies that used one specific low-literacy strategy to enhance patient comprehension, two focused on alternative document design, three on alternative numerical presentation, eight on additive or alternative pictorial representations, four on alternative media, and seven on a combination of alternative readability and document design. Additionally, one intervention focused on the effects of physician notification about patients' literacy status on health outcomes. A total of 21 studies involved mixed interventions; these included a combination of the strategies noted above and other strategies to promote improvements in patient knowledge, self-efficacy, behavior, adherence, disease, quality of life, and health care services use.

Interventions were tested in study populations with different proportions of individuals with low health literacy or low numeracy. Twenty-one studies examined the effect of interventions specifically in low-health-literacy subgroups, although many were underpowered for these analyses and/or failed to adequately control for confounding. Other studies examined intervention effects in populations that included both low- and high-health-literacy or -numeracy individuals; these studies provide only supportive evidence about the effect of interventions to mitigate the effects of low literacy.

## Effects of Health Literacy Interventions Using Single Strategies, by Intervention Type

### Intervention: Alternative Document Design

Two fair-quality randomized trials addressed the effects of alternative document design on outcomes, including comprehension and choice of higher quality options (Table 45).185,188 Both stratified analysis by health literacy subgroups. These studies examined the effects of specific design features including highlighting the common features of comparative information, presenting only essential information, and putting key information first.

Table 45 Single intervention strategies: alternative document design

Author, Date of Publication, Quality | Study design | Control Group | Intervention | Sample Size | % Population with Limited Literacy/ Numeracy | Outcomes | Difference
Greene et al., 2008^185^ Fair | RCT | 1. Side-by-side comparison of characteristics; 2. No framework | 1 Common/unique presentation of characteristics; 2a Short framework; 2b Long framework | 303 | 50% Low (score less than 10 on DR Numeracy Test) | Mean # responses to comprehension questions (range 0-6) | Common vs. Side to Side (unadjusted) High Numeracy Subgroup: Comprehension: -0.3, NS Low Numeracy Subgroup: Comprehension: -0.3, NS Short framework vs. No (unadjusted) High Numeracy Subgroup: Comprehension: +0.7, (P < 0.05) Low Numeracy Subgroup: Comprehension: +0.3, (P < 0.05) Long framework vs. No (unadjusted) High Numeracy Subgroup: Comprehension: +0.5, (P < 0.05) Low Numeracy Subgroup: Comprehension: -0.5, (P < 0.05)
Peters et al., 2007^188^ (Study 1) Fair | RCT | Non-ordered, non-essential info | 1. Ordered essential and non-essential info (= all); 2. Essential info only | 303 | 50% Low (score less than 10 on DR numeracy test) | Mean # correct responses to comprehension questions (range 0-3) % choosing higher quality hospital | Ordered, all vs. Control (unadjusted) High Literacy Subgroup: Comprehension: +0.1, NS Choice: +5%, NS Low Literacy Subgroup: Comprehension: +0.6, (P < 0.01) Plan Choice: +9%, NS P for literacy interaction: comprehension: (P < 0.05) Choice: NS Essential only, vs. control (unadjusted): Overall: Comprehension: +0.4, (P < 0.01) Choice: +21%, (P < 0.01) High Numeracy Subgroup: Comprehension: +0.3, (P < 0.01) Choice: +19%, NR Low Numeracy Subgroup: Comprehension: +0.7, (P < 0.01) Choice: +23%, NR P for interaction: comprehension: (P < 0.05) Choice: NS

Info=information; NR=not reported; NS=not significant; RCT=randomized controlled trial; vs.=versus.

One study tested simplifying design features in a convenience sample of 303 adults who were asked to examine comparative information about health plans.185 This study randomized individuals to six groups, which allowed two major comparisons: (1) the effects of presenting information on 13 features of health plans side by side in random order vs. with common features first, and (2) the effects of presenting a list of information about the plan (no framework) vs. presenting information about four advantages and four disadvantages of the plan (long framework) vs. presenting information about two advantages and two disadvantages of the plan (short framework). The investigators found that presenting common features first provided no improvements over the side-by-side presentation of information in either low- or high-numeracy participants. However, the short framework and the long framework (for high-numeracy participants only) provided small improvement in comprehension (ranging from 0.3-0.7 points on a comprehension scale with scores ranging from 0-6). The long framework provided significantly worse comprehension than no framework for those with low numeracy (-0.5 points on a comprehension scale with scores ranging from 0-6, P < 0.05).

In the other study in this category,188 which was done by the same group of investigators and appears to have used the same participants, the researchers investigated the effects of limiting and focusing information. In this study, participants received varying amounts of health plan information. Some participants received only the information investigators deemed essential to decisions about health plan use (i.e., information on cost and quality). Others, however, received both this essential information as well as other nonessential information (i.e., information on quality of hospital food and number of visiting hours per day). Both high- and low-numeracy participants who received only essential information had better comprehension (high numeracy 0.3 on a scale of 0-3, P < 0.01; low numeracy 0.7, P < 0.01) and chose higher quality options (high numeracy +19 percentage points, P < 0.01; low numeracy +23 percentage points, P < 0.01) than individuals who received both essential and nonessential information. When all information was presented, putting the essential information first further improved comprehension for low-numeracy individuals (+0.6 points on a scale of 0-3, P < 0.01), but not for high-numeracy individuals. Order had no effect on whether respondents chose higher quality options.

Considering this evidence in aggregate, our research team judged the overall strength of evidence for studies examining alternative document design to be insufficient (Table 46 and Appendix F), indicating that future studies would have a high likelihood of changing estimates of effect. Studies from our previous review did not change overall conclusions. In our previous review, we identified only one study focusing on alternative document design.232 This RCT compared illustrated narrative text to bulleted text on genital warts and cervical cancer screening and found no overall differences in comprehension among study arms receiving these presentations. Notably, however, low-literacy participants comprehended illustrated materials better than bulleted information.

### Intervention: Alternative Numerical Presentation

Three fair-quality randomized trials examined the effects of alternative numerical presentations (Table 47).188,217,219 Each examined a different strategy to improve numerical presentation. All stratified their analyses by participant numeracy level.

The first study188 was performed in the same population as the studies in the prior section. It examined the effects of presenting information on hospital quality so that the higher number (rather than the lower number) of any indicator indicated a better quality. In this study, listing information so that the higher number was better improved the mean number of correct responses to comprehension questions (+0.4 on a 0-4 scale, P < 0.001) and the proportion of individuals choosing a higher quality option (+13 percentage points, P < 0.01). Results varied by numeracy level, however; participants in the low- but not the high-numeracy subgroup achieved benefit from this approach. This study also investigated whether adding symbols to indicate the concepts of “more” or “less” would aid comprehension. We present these results in the next section about pictorial presentations.

The second study219 examined the effects of presenting information on the baseline risk of heart attack and treatment benefit for a hypothetical cholesterol drug using the same or different denominators. In this factorial randomized trial, a probabilistic sample of 1,047 American and German adults were randomly assigned first to information about the baseline risk of disease and risk following treatment presented alternately with four different sets of denominators (800/800, 100/800, 800/100, and 100/100). They were then secondarily randomized to either receive icon arrays or not. Presenting the numerical information using the same vs. different denominators resulted in appreciable improvements in understanding (P = 0.001), with a greater effect among those with low numeracy (+25 percentage points) vs. high numeracy (+16 percentage points, unadjusted P for numeracy effect = 0.001). The effect of adding icon arrays is discussed below in the section on additive pictorial representation.

The third study217 examined the effect of presenting information on the positive predictive value of genetic testing for diabetes and trisomy 21 (i.e., the likelihood of disease given a positive test for either of these diseases) in alternate numerical formats. In this study, a convenience sample of 162 adults was randomized to receive genetic testing information as either conditional probabilities or natural frequencies. In the conditional probabilities arm of the study, information on both the baseline rate of disease and the sensitivity and false positive rates of the genetic test was presented in percentages. Participants were then asked to calculate the likelihood of diabetes if genetic testing was positive. In the natural frequency arm, on the other hand, information on the baseline rate of disease was presented as x/10,000 people and sensitivity and false positive rates as y/x and z/10,000-x, respectively; these presentations preserve the base rate of disease and reduce the computations individuals must perform to estimate the likelihood of disease if genetic testing is positive. As hypothesized by investigators, natural frequencies improved the accuracy of participants' estimates of the positive predictive value of genetic testing (effect size not reported, P = 0.001) with similar effects for both high-(+24 percentage points) and low- (+27 percentage points) numeracy individuals. However, these results must be interpreted with caution due to the relatively small sample and lack of reporting of baseline group characteristics.

In considering this evidence, our research team felt that the overall strength of evidence was low (Table 46 and Appendix F), indicating that future research may change estimates of effect. Our prior review found no studies examining this outcome; therefore, it did not modify conclusions.

### Intervention: Additive and Alternative Pictorial Representation

Eight fair-quality studies133,186,188,189,195,216,219 (including two reported by Peters in the same article) investigated the effects of pictorial representation on outcomes, including comprehension, accurate perception of risk, and choice of higher quality options (Table 48). Six were RCTs and two were quasi-experimental studies. Six investigated the additive effects of pictorial information and two examined alternative pictorial representations. Five stratified their analysis by participant health literacy or numeracy level.

Of the six trials addressing the effects of adding pictorial information, two studies (performed by the same group and reported in one article) focused on the effect of adding symbols to numerical information.188 Both stratified their analyses by numeracy level. One study considered in the preceding section examined the effect of adding symbols to hospital quality information. Numerical information was presented alternately in two formats such that either the higher number indicated better quality (higher-number-better) or the lower number indicated better quality (lower-number-better).188 Symbols were then added to determine their effect on comprehension of hospital quality information and choice of higher quality hospitals. The symbols included a plus sign to indicate more patients per nurse, a minus sign to indicate fewer patients per nurse, and no symbol to indicate an average number of patients per nurse. These symbols had no effect on comprehension or hospital choice in the overall sample. However, adding symbols to the lower-number-better condition led to poorer choices (although not poorer comprehension) in high-numeracy participants (percentage choosing higher quality hospital -19 percentage points, P value not reported) and slightly better choices in the lower-numeracy participants (percentage choosing higher quality hospital +12 percentage points, P value not reported). In a similar study from this same group reported in the same article,188 participants were randomly assigned to one of five conditions to examine two main outcomes: (1) the effect of adding symbols to essential (with or without nonessential) hospital quality information, and (2) the effect of using black and white circles (i.e., all black, half-black half-white, all white) vs. colored traffic light symbols (i.e., green, yellow, red circles) to indicate relative quality. Symbols had no overall effect on comprehension but did increase the number of participants choosing high-quality options (+14 percentage points, P < 0.05). Effects varied by whether symbols accompanied only information essential to quality (i.e., death rates) or both essential and nonessential information (i.e., death rates and satisfaction). Adding symbols to both essential and nonessential information reduced the percentage of low-numeracy participants choosing high-quality hospitals, but it made no difference for high-numeracy participants. The effect of using black and white circles vs. colored traffic light symbols also differed by numeracy level. A higher number of high-numeracy participants chose high-quality hospitals with colored symbols (+16 percentage points, P < 0.05), while fewer low-numeracy participants chose high-quality hospitals, although the trend was not statistically significant (-11 percentage points, P not significant).

Two studies, including one already mentioned above, addressed the effects of adding icon arrays to numerical information about treatment benefit.216,219 Icon arrays (also known as pictographs) represent the benefits and/or harms of treatment using a series of dots, human figures, or faces that are shaded to represent the proportion of individuals affected by disease. Both studies stratified analyses by participant numeracy level. The first study examined the effects of adding icon arrays to numerical information in three hypothetical treatment scenarios (aspirin for cardiovascular disease, cholesterol drug for cardiovascular disease, and appendicitis screening).216 This factorial trial randomized a convenience sample of 171 students and older adults first to alternate numerical information (absolute risk reduction vs. relative risk reduction) and then to icon arrays or not. The study confirmed its a priori assumption that presenting treatment benefit information as absolute (rather than relative) risk reduction improved understanding for everyone (unadjusted difference +49 percentage points, adjusted P = 0.001). It then showed that adding icon arrays further aided understanding (unadjusted difference +23 percentage points, adjusted P = 0.002). However, improvements with icon arrays differed according to numeracy level, with greater improvements among those with low numeracy in unadjusted analyses. The second study, which was mentioned above in the “Alternative Numerical Presentation” section, examined the effects of adding icon arrays to numerical information in a single hypothetical treatment scenario (cholesterol drug for heart attack).219 In this factorial randomized trial, a probabilistic sample of 1,047 American and German adults were randomly assigned first to information about the baseline risk of disease and risk following treatment presented alternately with four different sets of denominators. They were then secondarily randomized to either receive icon arrays or not. The effects of icon arrays on accuracy of risk perception varied both by the denominators indicating treatment benefit and by participant numeracy. When denominators for the baseline risk and risk following treatment were different, icon arrays improved understanding for both low- (unadjusted difference +32 percentage points) and high- (unadjusted difference +11 percentage points) numeracy participants. However, when denominators for baseline risk and risk following treatment were the same, icon arrays provided a more modest benefit in the accuracy of risk perception for low-literacy participants (unadjusted difference +11 percentage points) and worsened risk perception in high-literacy participants (unadjusted difference -16 percentage points). P values for these differences were not reported.

Two other studies examined the effect of adding illustrations to prose.133,195 Neither of these studies stratified analysis by literacy level, although one reported that literacy predicted outcomes.133 This study, a randomized trial of 363 participants (only 4 percent of whom had Rapid Estimate of Adult Literacy in Medicine [REALM] scores below 45), found no overall effect of adding a mind map (a pictorial representation linking key concepts and ideas) to standard arthritis education materials.133 The other study, a quasi-experimental study enrolling a convenience sample of 130 adults from academic family medicine clinics, showed no effect of adding illustrations to the auxiliary prescription labels indicating “take with water,” “may cause drowsiness,” “take with food,” “no alcohol,” or “take on empty stomach.”195

The remaining studies examined alternative pictorial representations. Only one stratified analysis by numeracy. In this Internet study randomizing 140 adults (41 percent of whom were deemed to have low numeracy because they incorrectly answered the first numeracy question on the Lipkus numeracy scale) to six different conditions, the researchers could determine the effect of grouped vs. dispersed dot icon arrays for three risk magnitudes (3 percent, 6 percent, 50 percent).186 They determined that there was no overall effect on comprehension among those who received the grouped dot (rather than dispersed dot) icon arrays; however, those with higher numeracy had significantly greater improvements than those with lower numeracy. A different quasi-experimental study examined seven teratogen warning symbols in comparison with a standard symbol.189 The researchers found that participants' understanding that the medication should not be taken if pregnant and that the medication causes birth defects improved if these concepts were represented in separate complementary diagrams rather than single diagrams (P value not reported). They also found that adding text stating “causes birth defects” increased understanding of all tested symbols.

In aggregate, our research team considered the overall strength of evidence for alternative pictorial representations to be insufficient (Table 46 and Appendix F). Studies made disparate comparisons and found mixed results, precluding clear conclusions. Our prior review did not modify conclusions; although our prior review found one study of alternative pictorial representations, it was graded as poor quality.

### Intervention: Alternative Media

Four randomized trials assessed the effects of various types of media on comprehension and/or intent to seek health care (Table 49).184,200,212,213 Three focused on the effects of adding or substituting various media (e.g., video, computer, or slide show presentations) for printed materials.200,212,213 A fourth examined the effects of adding video to verbal narratives.184 Three of four studies stratified results by health literacy status.184,200,213

The first study examining the effects of various media compared to print materials randomized 233 parents or caretakers of children enrolled in Head Start Programs to one of four presentations of informed consent—standard, simplified print, video, computerized—for hypothetical high-risk and low-risk studies.200 Compared with standard informed consent, the video and computerized versions had little effect on freely remembered recall of information. However, the computerized version showed a trend toward improving prompted recall (percentage of total information remembered +4 percentage points, P = 0.08) with no difference by health literacy group. Whether such improvements are clinically meaningful is not clear. The comparison of the standard consent and simplified print version is presented below in the section “Alternative Design and Readability Document.”

The second study randomized a convenience sample of 232 men at two university hospitals to two different media for delivery of a symptom score assessment for benign prostatic hypertrophy: print or print plus video (which the authors called “multimedia”).213 The multimedia delivery included a computerized video with reading of the symptom score questions. Questions were shown on the computer screen during reading and color-coded to correspond to written symptom score sheets to be completed by participants. The efficacy of the multimedia version was assessed by two different measures of comprehension: the mean number of errors participants made and the proportion of participants understanding questions (compared to professionally completed scores). Overall, the multimedia version increased comprehension (mean difference in errors -1.51, P < 0.001; mean difference in percentage understanding +19 percentage points, P not reported), with larger effects among participants with low health literacy (defined as less than high school reading skills by the REALM; significance of interaction by health literacy status not reported). It also increased the accuracy of categorical classification of symptoms in the overall sample (+13 percentage points, P = 0.04).

The third study examining the effects of various media compared to print materials randomized 90 teenage patients and their parents (all of whom had median REALM and Wide Range Achievement Test [WRAT] scores, suggesting reading skill at the high school level) to one of three presentations of informed consent for orthodontic treatment—standard, simplified print, or simplified print plus a slide show that included images and audiovisual cues representing the elements of informed consent.212 As discussed under the section “Alternative Readability and Document Design” below, compared with standard informed consent (readability not reported), the simplified informed consent (which was written at the seventh-grade level and included large font, white space, active voice, and cues to action) did not improve recall or comprehension for patients or parents. The addition of a slide show, however, improved the proportion of information adequately recalled by patients (unadjusted absolute difference +11 percentage points, P < 0.05) and the proportion of information adequately recalled and comprehended by parents (unadjusted absolute differences for recall +9 percentage points, P < 0.05; for comprehension +12 percentage points, P < 0.001). Results should be interpreted with caution, however, because they did not adjust for potentially meaningful baseline differences between study arms. Furthermore, they were not stratified by literacy level.

A single study examined the effects of adding video to verbal narratives.184 This study randomized a convenience sample of 200 adults from four primary care practices in the United States to a verbal narrative about advanced dementia or a verbal narrative in combination with a 2-minute video.184 Participants who received the verbal narrative plus video had improved knowledge compared to the verbal narrative alone (unadjusted mean difference +0.9 on a scale ranging from 0-5, P < 0.001) Additionally, those who received the verbal narrative plus video had a greater preference (which we considered a proxy for intent) for comfort care as an end-of-life strategy (adjusted odds ratio [OR] 3.9, 95% confidence interval [CI], 1.8-8.6). Preference for comfort care varied by health literacy level, with those who had higher health literacy having higher preference for comfort care.

Based on findings from the studies above and their mixed results, our research team judged the strength of evidence to be insufficient (Table 46 and Appendix F). Three studies from our prior review contributed additional information, but didn't change overall conclusions.233-235 In our prior review, one RCT233 found that both a simple brochure written at the 5-6^th^ grade level and a video written at a similar level improved comprehension of colon cancer screening information more than usual care, although neither was superior to the other overall or in stratified analyses. Two additional nonrandomized trials234,235 found mixed results. One showed that a brochure plus video plus verbal recommendation about mammography improved mammography rates over either a verbal recommendation alone or a brochure plus verbal recommendation.234 The other confirmed no differences overall or in literacy subgroups in comprehension of information on sleep disorders with a 12-grade brochure vs. a video based on a script written at the 12th grade level.235

### Intervention: Alternative Readability and Document Design

We found seven studies examining the effects of interventions that combined simplification of readability with document redesign (Table 50). Six were fair-quality randomized trials (seven articles based on six studies)191,199,200,204,208,212,214 and one was a fair-quality quasi-experimental study.204 One focused on an advanced directive,204,208 one on simplified advice about head trauma,191 one on a simplified Medicaid health plan comparison chart,214 and four on simplified informed consent199,200,204,212 (although one of the latter provided only postintervention data, which limited conclusions204). Only three of the six with interpretable data stratified results by health literacy level.191,200,214

The first study stratifying results by health literacy level examined the effects of a simplified Medicaid health plan comparison chart.214 The chart had four key improvements: it listed only the differences between health plans, ordered plans from the most to the least generous, grouped or “chunked” cost-sharing and benefit information in rows to allow comparison across plans, and increased font size. Compared to a standard chart, the modified health plan comparison chart provided no significant improvements in comprehension overall or by health literacy group in a convenience sample of 122 Medicaid recipients in Florida. This might be attributable to the high residual document complexity, which was noted to be at a high school level for the simplified chart.

The second study stratifying results by health literacy level examined the effects of a simplified head trauma advice sheet.191 This simplified sheet included simplified language, a reduced number of words, grouping or chunking ideas, and the use of large font sizes and plenty of white space. Compared with a standard advice sheet, this simplified sheet resulted in a 1-point improvement on a comprehension scale with possible scores ranging from 0-10. There was no interaction by literacy level.

The third study stratifying results by health literacy level was mentioned above in the section “Alternative Media.” This RCT randomized 233 parents or caretakers of children enrolled in Head Start Programs to one of four presentations of informed consent—standard, simplified print, video, computerized—for hypothetical high-risk and low-risk studies.200 The simplified print version of informed consent included in this study employed simple language, chunking of ideas, and white space to improve participant understanding. Compared with standard informed consent, the simplified print version had little effect on freely remembered recall of information. However, it showed trends toward improving prompted recall in the low-literacy (less than an eighth-grade reading level on the WRAT) subgroup. Whether such improvements are meaningful is not clear.

Results from other studies, which did not stratify data by literacy level, were mixed. Three studies199,204,208,212 showed no effect on comprehension by three different combinations of reading and document simplification (see Table 44 and Table 50), although one of these showed changes in the proportion of participants completing advanced directives. Both studies had features limiting interpretation of findings.199,204,208 For instance, in one study,199 participants had a mean REALM score of 65 out of 66; this raises the possibility that the same intervention tested in a population with more low-literacy individuals might have appreciably different results. Additionally, in the other study,204,208 results about completion of advanced directives were confounded because of cross-over between study arms with lack of adjustment for relevant confounders.

Based on these findings, our research team judged the overall strength of evidence about alternative readability and document design to be insufficient (Table 46 and Appendix F). Studies found mixed results, which are likely attributable, at least in part, to the components of document redesign and methodological bias. Several studies from our prior review and prior sections of the current review similarly reported mixed results. In our prior review, one study focused on alternative readability alone236 and showed an association between low readability and improved comprehension. Three other studies focused on a combination of alternative readability and document design and reported mixed results.237-239 In prior sections of this review (see “Alternative Document Design” above), the benefits of document design varied by the components of redesign.

### Intervention: Physician Notification of Patient Literacy Status

One fair-quality cluster randomized trial examined the effects of physician notification of patient literacy status on health outcomes including self-efficacy and hemoglobin A1c (HgbA1c), (Table 51).181 Despite enrolling a population with a high proportion of low-literacy individuals (74 percent had a Test of Functional Health Literacy in Adults [TOFHLA] score below 16) and increasing physicians' use of more than three communication-enhancing strategies (adjusted OR 4.7, 95% CI, 1.4-16), neither patients' self-efficacy nor HgbA1c changed in any material way with physician notification. Based on this single study, our research team graded the overall strength of evidence as low (Table 46 and Appendix F). There were no studies from our prior review to modify this assessment.

### Summary of Interventions Using Single Intervention Design Strategies

In summary, the strength of evidence regarding the effect of specific intervention design features for low-health-literacy populations is low (Table 46 and Appendix F). This is attributable, in large part, to differences in the interventions (and subsequent results) for studies broadly grouped as follows: alternative document design, alternative numerical presentation, alternative pictorial representation, alternative media, alternative readability and document design, and physician notification of literacy status.

Looking closely within intervention categories, we noted that several specific design features resulted in improvements in comprehension for low-health-literacy populations in one or a few studies. These features, which bear further study in broader populations, include presenting essential information by itself (i.e., information on hospital death rates without other distracting information, such as information on consumer satisfaction); presenting essential information first (i.e., information on hospital death rates before information about consumer satisfaction); presenting information so that the higher number (rather than the lower number) indicates better quality; using the same denominators to present baseline risk and treatment benefit information; adding icon arrays to numerical presentations of treatment benefit; and adding video to verbal narratives. Additionally, in reexamining data from our 2004 review, we noted potential benefit from other design features tested individually in one or a few studies; these include using reduced reading level and illustrated narratives.

In contrast to the above design features, we noted that a few specific design features resulted in worse comprehension in one or a few studies; these design features also bear further study in broader populations. For instance, one study raised questions about whether colored traffic symbols to denote hospital quality may actually worsen health choices among those with low literacy. Similarly, one study raised questions about whether adding symbols to nonessential quality information (i.e., satisfaction information), may actually draw attention away from the essential information and worsen health choices among those with low health literacy.

## Effects of Mixed Strategy Interventions, by Analytic Framework

### KQ 2a Effect of Mixed Interventions on Use of Health Care Services

We found one good-quality study182 and five fair-quality studies194,196,202,203,207 addressing the effects of mixed strategy interventions on use of health care services (Table 52). Four were RCTs,182,194,202,203 one was a cluster randomized trial,196 and one used a quasi-experimental design.207 Two studies provided preventive service education and examined rates of preventive services utilization.196,203 Three others, one promoting adherence182 and two facilitating self-management,202,207 examined rates of visits to emergency rooms182,207 and hospitalizations.182,202,207 One additional study examined use of recommended services,194 but the authors did not describe this outcome in sufficient detail to allow interpretation; thus results are not presented here. Four of the six studies stratified analyses by literacy level.

Of two studies providing preventive service education, only one stratified analysis by health literacy level. This cluster randomized trial delivered interventions to both providers and patients. It provided providers with education on literacy and communication strategies and patients with education on colorectal cancer screening. With these interventions, this study showed increases in any colorectal cancer test completion over 18 months (absolute difference 8.9 percentage points, P = 0.003). The impact differed by health literacy level, with an absolute difference of 26 percentage points in the low-health-literacy subgroup (P = 0.002) and 3 percentage points in the high-health-literacy subgroup (P = 0.65) when adjusting only for the clustering of patients within providers.196 A second trial providing patients with education on prostate cancer screening also increased preventive service use,203 with significant increases in the number of prostate-specific antigen tests ordered after both low-readability patient education (adjusted OR, 7.62, 95% CI, 1.62-35.83) and cues encouraging patients to talk with their physician (adjusted OR, 5.86, 95% CI, 1.24-27.81). However, the health benefits of additional prostate cancer screening are questionable and the authors do not present information about whether results differed by health literacy level. Rates of digital rectal examinations documented by chart review did not change in this study.

Of two studies examining the effects of interventions on emergency room visits, only one stratified results by health literacy level. This fair-quality quasi-experimental study promoting asthma self-management by children (intervention directed at children) reported an overall reduction in emergency room visits (unadjusted mean difference -30 percentage points, P < 0.01), with a striking effect in those who showed improvements in reading compared to those who did not (adjusted OR, 0.34; 95% CI, 0.22-0.52).207 Smaller reductions in emergency room visits (incidence rate ratio, 0.82; 95% CI, 0.70-0.95) were noted in one good-quality RCT promoting medication adherence for congestive heart failure (CHF); this study was conducted in an undifferentiated population of individuals, 29 percent of whom were designated as “not literate” (not otherwise specified) on the S-TOFHLA.182

Of three studies examining the effects of interventions on hospitalizations, two stratified results by health literacy. The best of these two studies was a fair-quality randomized trial focused on CHF self-management.202 This study reported no overall reduction in hospitalizations but significant reductions in a subgroup of individuals of low health literacy (adjusted incidence rate ratio, 0.39; 95% CI, 0.16-0.91). A fair-quality quasi-experimental study of an asthma self-management intervention also reported reductions in hospitalizations (adjusted mean difference -15 percentage points, P < 0.001), although the effect did not differ by literacy level.207 A third good-quality RCT, which did not stratify results by health literacy, noted a trend toward reduced hospitalizations (incidence rate ratio, 0.39; 95% CI, 0.16-0.91) with a medication adherence for CHF.182

Based on these findings, our research team graded the strength of evidence for the effect of mixed interventions on emergency room visits and hospitalizations as moderate. This grade is based on consistent evidence from multiple fair- to good-quality studies that adherence and self-management interventions reduce emergency room visits and hospitalizations in low-literacy subgroups or populations that contain individuals with both low and high numeracy (Table 53 and Appendix F). Our prior review found no studies examining this outcome; it, therefore, did not modify our conclusions.

### KQ 2b Effect of Mixed Interventions on Health Outcomes

#### Knowledge

We identified 10- fair-quality studies addressing the effects of mixed strategy interventions on knowledge (Table 54).79,194,197,201,202,205,206,211,215,220 Three were RCTs194,201,202 and the remaining seven were quasi-experimental studies.79,197,205,206,211,215,220 Two quasi-experimental studies measured data about knowledge before or after the intervention only, limiting conclusions.79,206 Of studies with interpretable data, two focused on promoting adherence,201,220 six on promoting self-management of chronic illness,194,197,201,202,211,215 and one on promoting weight loss.205 Only one examined knowledge as the primary outcome.215 Five examined literacy as a moderator of intervention effect, testing whether the level of effectiveness of the intervention differed by health literacy level.194,197,211,215

In aggregate, studies found mixed results; findings did not seem to be related to study design, intervention or disease focus, health literacy level of included participants, or health literacy strategies employed as part of the intervention. Four of eight studies with interpretable data,202,205,215,220 including one RCT202 and one study215 that focused on knowledge as the primary outcome, found positive effects of their intervention on knowledge.202,205,215,220 However, which components of these interventions were the effective components remained unclear. Additionally, in the one study that found an effect and stratified results by health literacy level,215 results were greater in those with high health literacy; this may be in part because the small subgroups for low health literacy had insufficient power to detect differences. One additional quasi-experimental study showed positive effects for the high-health-literacy group but not the low-health-literacy group at 3-month followup.197

Given the mixed findings, our research team judged the overall strength of evidence to be insufficient (Table 53 and Appendix F). However, 14 studies from our prior review (including 12 that examined knowledge as their primary outcome) contributed additional information. Eight have been described above because they addressed specific alternative presentations of health information. One additional study is presented below under the effects of mixed interventions on skill. Five additional studies addressed the effect of mixed interventions on knowledge and are described here.240-245 Four of these five studies, including two RCTs,243,244 and one study that stratified results by literacy level,244 found improvements in knowledge with interventions as diverse as an interactive videodisc program about self-care of fatigue in cancer patients, low-literacy nutrition classes, a cholesterol education video, and a CD-ROM on prostate cancer screening. The remaining nonrandomized trial found no improvement in knowledge with the addition of a color medication schedule to verbal teaching. With continued mixed results (9 of 14 studies overall with knowledge improvements), the research team concluded that the overall strength of evidence was still insufficient (Table 53 and Appendix F), with effect estimates that are likely to change substantially with new results.

#### Self-Efficacy

We identified nine fair-quality studies addressing the effects of mixed strategy interventions on self-efficacy (Table 55). Four were RCTs187,194,202,209,210 and five were quasi-experimental studies.190,205,207,211,220 Two focused on promoting adherence,190,220 five on promoting self-management,187,194,202,207,210,211 one on arthritis treatment,209 and one on weight loss.205 None examined self-efficacy as its primary outcome; only two examined literacy as a moderator of effect.194,211 One reported self-efficacy results only postintervention, which limited conclusions.220

In aggregate, studies found mixed results, which may be related to differences in the intensity of the intervention. Two RCTs187,202,210 and one quasi-experimental study207 with intensive self-management interventions including frequent and prolonged participant contact showed improvements in self-efficacy. Additionally, one study that targeted both patients and providers (although with less intensive and less prolonged contact for each than other effective interventions) showed increases in self-efficacy.205 However, none of these studies stratified analyses by literacy level. Other studies with less intensive interventions, including two randomized trials, showed negative results190,194,209,211 and no differential effect by health literacy level in the one study that performed stratified analysis.194 Based on these studies, our research team judged the overall strength of evidence to be insufficient (Table 53 and Appendix F). No studies from our prior review addressed this outcome.

#### Behavioral Intent

We found no studies addressing the effects of mixed health literacy interventions on patients' intent to perform specific health behaviors. Similarly, our prior review found no studies addressing this outcome.

#### Skill

We found one study addressing the effects of mixed health literacy interventions on patients' skill (Table 56).218 This fair-quality randomized trial randomized a convenience sample of 56 individuals to either a standard nutrition label or a nutrition label information card and 8-minute video tutorial. Participants who received the information card and video tutorial correctly answered a higher proportion of questions on a 12-item food label quiz (adjusted absolute difference + 12 percentage points, P < 0.05), with a greater effect among those with adequate literacy on the s-TOFHLA in an adjusted analysis. Based on findings from this study, our research team judged the overall strength of evidence to be low (Table 53 and Appendix F). Two studies from our prior review245,246 addressed label-reading skills and found mixed results. This leaves the overall literature inconclusive.

#### Behavior

Three fair-quality studies addressed the effect of mixed strategy interventions on actual behaviors (Table 57).187,197,202,210 Two were RCTs; one was a quasi-experimental study. All involved individual or group counseling that taught self-management behaviors and measured aggregate self-management behaviors. Additionally, two studies measured individual self-management behaviors for diabetes (including diet, physical activity, foot care, medication adherence, and glucose self-monitoring).187,197,210 Only one analyzed these effects by health literacy level.197

In aggregate, these studies suggested that self-management interventions including individual and group counseling improved aggregate self-management behaviors. However, in the only study to examine effects by health literacy status,197 improvements were sometimes greater for those who had adequate health literacy and at other times greater for those with inadequate health literacy in adjusted analyses. Based on these studies, our research team judged the strength of evidence regarding the effects of self-management interventions on behavior as moderate (Table 53 and Appendix F).

Three studies in our prior review also addressed behavior, although their intervention focus was different.243,245,247 All three had special diet interventions and measured dietary change and/or caloric intake. These studies found mixed results, precluding definitive conclusions about the effects of low-health-literacy diet interventions on behavior.

#### Medication Adherence

We found one good-quality182 and four fair-quality studies79,197,201,209 addressing the effect of mixed literacy interventions on adherence to medication regimens (Table 58).Three were RCTs182,201,209 and two were quasi-experimental studies.79,197 Three included interventions that were designed specifically to promote adherence.182,197,201 A fourth79 was a self-management intervention that measured medication adherence only postintervention in a subset of patients, which limited drawing any conclusions. A fifth209 was designed to promote arthritis management. Of studies with interpretable data, only one stratified results by health literacy level.197

In the four studies contributing interpretable data,182,197,201,209 effects were mixed, which appeared to be related to both the intensity of the intervention and the measure of adherence. The good-quality RCT,182 which involved an intensive intervention focused at both patients and their providers, found improved adherence (+10.9 percent, 95% CI, 5-16.7) during the intervention period using Medication Event Monitoring Systems (MEMS) to assess adherence. The effect, however, attenuated at 3 months after completion of the intervention (+3.9 percent, 95% CI, -2.8-10.7). Three other studies,197,201,209 which used less intensive interventions and measured adherence by self-report, found no effect, although one showed a trend toward improved adherence among a subgroup of individuals who were initially nonadherent (+12 percent, P = 0.08, when counting as adherent those who disagreed that they missed medications for any of the four reasons on the Morisky questionnaire).201 In the study that stratified results by health literacy,197 results were similar by health literacy group in an adjusted analysis.

Based on the findings above, our research team judged the strength of evidence for the effects of mixed interventions on adherence to be insufficient (Table 53 and Appendix F). Only one study from our previous review measured adherence and found no effect of a color medication schedule.240 This nonrandomized trial did not change our conclusion about the overall strength of evidence for this outcome.

#### Disease Prevalence and Severity

We found one good-quality183 and six fair-quality studies79,187,193,194,197,198,210 addressing the effects of mixed strategy interventions on disease prevalence and severity (Table 59). Four were RCTs183,187,193,194,210 and three were quasi-experimental studies.79,197,198 Five measured biomarkers of disease183,187,194,197,198,210 and two measured symptoms.79,193 Five stratified results by level of health literacy. In general, studies reported mixed results, which may be attributable, at least in part, to intervention and study design.

Three studies addressed the effects of diabetes self-management interventions on disease biomarkers (including HgbA1c, blood pressure, and BMI).187,194,197,210 Two fair-quality RCTs found no effect on HgbA1c, blood pressure, or BMI in participants overall187,194,210 or in low-health-literacy subgroups in an adjusted analysis.194 By contrast, a fair-quality quasi-experimental study found a statistically significant decrease in HgbA1c with no difference in effect among health literacy subgroups in an adjusted analysis;197 without a control group, however, we cannot judge the importance of this finding.

Two other studies addressed the effects of diabetes disease management programs (i.e., self-management plus pharmacist adjustment of medication) on disease biomarkers.183,198 These studies appeared to test the same intervention in a quasi-experimental198 and a randomized design.183 The RCT showed a significant decrease in HgbA1c in the low-health-literacy group (adjusted absolute difference -1.4 percent, 95% CI, -2.3 to -0.6) but not in the high-health-literacy group (adjusted absolute difference -0.5 percent, 95% CI, -1.4 to 0.3), although it should be noted that the sample size may have been too small to detect small differences in the high-literacy subgroup. Systolic blood pressure was also significantly lowered among all participants (adjusted absolute difference -7.6 mmHg, 95% CI, -13 to -2.2 mmHg). Exactly which component of this intervention was efficacious remains unclear, although the lack of efficacy of other self-management interventions suggests that the pharmacist adjustment of medication may be the critical factor. Additionally, the self-management component in this study employed a wider variety of strategies to mitigate low health literacy (e.g., simple language, simple organizational structure, pictures, teach-back, repetition) than other studies.

Two studies addressed the effects of mixed strategy interventions on symptom control,79,193 although only one had adequate power to test its effects on disease severity and did not stratify results by health literacy level.193 This fair-quality randomized trial, which tested the effects of adult basic and literacy education as an adjunct to depression management, showed statistically significant reductions in scores on the PHQ-9 (the 9-item depression scale of the Patient Health Questionnaire) over multiple followups.

Based on the findings above, our research team judged the strength of evidence separately for self-management, disease management, and adult basic and literacy interventions. We concluded that the strength of evidence is insufficient for self-management interventions, moderate for disease management interventions, and low for adult basic and literacy education interventions (Table 53 and Appendix F). No studies from our prior review included these types of interventions. However, one RCT from our prior review found reduced depression with case management as an adjunct to a standard Head Start program.248 Furthermore, two RCTs from our prior review247,249 found no effect of special nutrition education programs on cholesterol (two studies) or blood pressure (one study).

#### Quality of Life

One good-quality182 and three fair-quality187,202,209,210 RCTs addressed the effects of mixed strategy interventions on quality of life (Table 60); however, none used quality of life as the primary outcome. Two focused on general quality of life187,209,210 and two focused on disease-specific quality of life.182,202 One measured quality of life only after the intervention in the intervention group,182 thereby limiting conclusions. Only one stratified results by health literacy level. 202

The three studies providing interpretable data yielded mixed results. Two studies reported no effects of self-management interventions on well-validated quality-of-life measures, including the mental and physical health subscales of the Medical Outcomes Study Short Form 12 (SF-12)187,210 and the Minnesota Living with Heart Failure scale (MLHF).202 One of the studies, however, reported reductions in the number of bed days in the past month (adjusted absolute difference -1.7 days per month, 95% CI, -3.3 to -0.1 days per month) for people assigned to an intensive telephone counseling intervention with 39 patient contacts.187,210 A third trial on arthritis management intervention reported mixed effects, with no effects on the Health Assessment Questionnaire (HAQ),209 but improvements on the mental health subscale of the SF-36.

Based on findings described above, our research team judged the strength of evidence for the effects of mixed interventions on quality of life to be insufficient (Table 53 and Appendix F). Our prior review found no studies examining this outcome; it, therefore, did not modify our conclusions.

### KQ 2c Effect of Mixed Interventions on Health Care Costs

We found two good-quality RCTs examining the health care costs of mixed health literacy interventions. One good-quality RCT examined the cost-effectiveness of its intervention to promote adherence to CHF medication182 (Table 61). This intensive pharmacist-led intervention, which included patient education and skill building, graphic medication labels, monitoring of adherence, and notification of providers, showed trends toward cost savings (-$2,960, 95% CI, -$7,603 to $1,338) compared with usual care when considering intervention, outpatient, and inpatient costs. Another good-quality RCT examined the labor and total costs (defined as labor plus indirect costs) of its diabetes disease management intervention. This study reported the labor costs for its disease management program, which employed both clinical pharmacists and diabetes care coordinators who provided more than 13 hours of education, skill building, and medication adjustment per patient, were $25.50 per patient per month (range in sensitivity analysis $12.01 to $55.35 per patient per month). Total costs were slightly higher at $36.97 per patient per month (range in sensitivity analysis $16.22 to $88.56 per patient per month).

Based on these studies and their mixed findings, our research team graded the strength of evidence for the effects of mixed interventions on health care costs as insufficient (Table 53 and Appendix F). Our prior review found no studies addressing this outcome and did not modify our conclusions.

### KQ 2d Effect of Mixed Interventions on Disparities

We found no studies addressing the effects of mixed health literacy interventions on patients' intent to perform specific health behaviors. Similarly, our prior review found no studies addressing this outcome.

## Summary of Interventions Using Mixed Intervention Strategies

The strength of evidence for studies combining multiple strategies to mitigate the effects of low health literacy on outcomes was more variable than for single-feature interventions. We found moderate strength of evidence that studied interventions change health care service use. Specifically, intensive self-management and adherence interventions appear to be effective in reducing emergency room visits and hospitalizations. Additionally, educational interventions and/or cues for screening increased colorectal cancer and prostate cancer screening. We note, however, that the health benefits of additional prostate cancer screening are questionable and that increased screening rates could be a marker for poor decision making.

Evidence of moderate strength indicates that some interventions change health outcomes. For instance, intensive disease-management programs appear to be effective at reducing disease prevalence. Furthermore, self-management interventions increased self-management behavior; however, in the only study that stratified its analysis by health literacy level, the effect was greater in the high-health-literacy subgroup than in the low-health-literacy subgroup in adjusted analyses. The effects of other interventions on other health outcomes, including knowledge, self-efficacy, adherence, health-related skills, quality of life, and cost, were mixed; thus, the strength of evidence was insufficient.

Too few studies addressed the effects of health literacy interventions on the outcomes of behavioral intent and disparities to draw any meaningful conclusions; the strength of evidence is insufficient.

## Cross-Cutting Observations About Interventions Designed To Mitigate Low Health Literacy

Looking at the common features of successful interventions can help illuminate features that may be important in making interventions effective at mitigating the effects of low health literacy. Common features across nearly all of the interventions that improved distal outcomes (e.g., self-management, hospitalizations, mortality) were their high intensity, theory basis, pilot-testing before full implementation, emphasis on skill building, and delivery of the intervention by a health professional (e.g., pharmacist, diabetes educator).182,183,202,207

Examining pathways of effect can also help illuminate factors that may be important in making interventions effective. Six studies in our update examined the impact of interventions on three or more outcomes79,182,187,194,197,202 (Table 44). In addition to changing distal outcomes, these studies reported changes in the following intermediate outcomes: knowledge,196,197,202 self-efficacy,187 or behavior.182,187,197,202 Although these studies did not perform formal mediation analyses, the change in these intermediate outcomes suggests that changing knowledge, increasing self-efficacy, and changing behavior may be important goals in mitigating the effects of low health literacy.