# Results: Relationship of Health Literacy to Outcomes and Disparities

This chapter presents the results of our literature search for the project, including results for key questions (KQ s) 1 and 2. It also reports our findings for KQ 1; we illustrated and discussed this KQ in Chapter 2 and Figures 1 and 2. Specifically, KQ 1 asked whether health literacy skills are related to (a) use of health care services, (b) health outcomes, (c) costs, and (d) disparities in outcomes or utilization according to race, ethnicity, culture, or age.

Table 5 Overview of health literacy studies

Source Design Quality Score | Population | Outcomes | Covariates Included in Multivariate Analyses
Bailey et al., 2009^77^ Cross-sectional Fair | 373 patients at 3 outpatient family medicine clinics serving low-income populations in Shreveport, LA; Chicago, IL; and Jackson, MI | Interpretation of a prescription label for amoxicillin Understanding of dosage measurement and frequency of use | Analysis 1 Race Age Sex Education Analysis 2 Race Age Sex Education Health literacy
Baker et al., 2004^62^ Cohort Good | 3,260 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Any ED visits 1 ED visit 2 or more ED visits Number of physician visits | Age Gender Race Physical and mental health Chronic diseases Smoking Alcohol use BMI Study site Months enrolled
Baker et al., 2007^65^ Prospective cohort Good | 3,260 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | All-cause mortality Cardiovascular mortality Cancer mortality Noncardiovascular, noncancer mortality Physical HRQoL (SF-12) Mental HRQoL (SF-12) IADL limitation ADL limitation Number of chronic conditions (unadjusted) BMI (unadjusted) | Age Sex Race/ethnicity Language Study site Income Social class Education Number of chronic conditions Physical health score Mental health score IADL limitation ADL limitation
Baker et al., 2008^67^ Prospective cohort Good | 3,260 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Mortality | Age Sex Race Language Income Education SF-36 physical functioning and mental health component scores Number of chronic diseases Number of impairments in ADLs Number of impairments in IADLs City of enrollment
Barragan et al., 2005^93^ Cross-sectional Fair | 372 patients at an inner-city public hospital urgent care center in Atlanta, GA | HIV test acceptance | Age Education
Bennett et al., 2007^132^ Cross-sectional Fair | 99 pregnant patients receiving prenatal care in clinics in Philadelphia, PA | Elevated depressive symptomatology | Mexican nativity Recent marijuana use
Bennett et al., 2009^85^ Cross-sectional Good | 2,668 US adults 65 years and older in a nationally representative sample | Mammography Influenza vaccine Health status | Age Race Gender Income Nativity
Chew et al., 2004^107^ Prospective cohort Fair | 332 patients at a preoperative clinic of the VA Puget Sound | Nonadherence to fasting instructions Nonadherence to preoperative medication instructions | Age Marital status Number of medications Cognitive functioning
Cho et al., 2008^81^ Cross-sectional Fair | 489 elderly outpatients at hospital and an FQHC in Chicago | ER visits Hospitalizations Preventive care FOBT Mammography Health status (self-report) Nonadherence Failed to fill prescriptions on time Health behavior measured through Health Promoting Lifestyle Profile | Race Ethnicity Gender Educational attainment
Coffman and Norton, 2010^135^ Cross-sectional Fair | 99 participants from 2 Latino service agencies | Depression | Demands of immigration
Davis et al., 2006^75^ Cross-sectional Fair | 395 adults in primary care clinics in Shreveport, LA; Jackson, MI; and Chicago, IL | Misunderstood ≥1 prescription label instructions Correct demonstration of number of pills | Age Sex Race Education Number of medications currently taken daily Site
DeWalt et al., 2007^80^ Retrospective cohort Fair | 150 patients at a general, asthma and allergy, and pulmonary clinic at children's hospital | Child ED visits Hospitalizations Albuterol use (unadjusted) Appropriate controller use (unadjusted) | Child age Household income Parental race Parental asthma knowledge Parental smoking Asthma severity classification Controller medication use Site of care
Estrada et al., 2004^126^ Prospective cohort Fair | 143 adults > 50 years old on warfarin ≥ 1 month in 2 anticoagulation management units | Warfarin control measured through INR variability and INR in the therapeutic range | Age
Fang et al., 2006^106^ Cross-sectional Fair | 179 patients at an anticoagulation clinic in San Francisco, CA | Adherence to medication as measured by self-report of missed doses over 3 time periods (last 3 days, last 2 weeks, > 3 months) No missed doses > past 3 months | Age Sex Race/ethnicity Education Cognitive impairment Years on warfarin
Garbers et al., 2004^91^ Cross-sectional Fair | 205 women recruited through their younger female relatives in 2 women's health centers in New York City | Ever had a Pap test Pap test within past 3 years | Having a source of care Having any health insurance Age Years in the US Education
Gatti et al., 2009^73^ Cross-sectional Fair | 275 participants recruited from 3 outpatient pharmacies at Grady Memorial Hospital, and from the DeKalb Grady Health Center pharmacy in Atlanta, GA | Self-reported medication adherence | Negative beliefs about medications Age Low self-efficacy Self-report of hyperlipidemia
Gazmararian et al., 2006^61^ Prospective cohort Fair | 1,549 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Nonadherence to cardiovascular medication refill adherence (1-year period) | Age Race Gender Education Regimen complexity
Graham et al., 2007^104^ Retrospective cohort Fair | 87 patients at an HIV clinic in Philadelphia, PA | < 95% adherence to HIV medication regimen (self-report of pill counts over past 3 months) | Individual's norm for acceptable adherence (investigator-conceptualized as mediator)
Grubbs et al., 2009^97^ Retrospective cohort Fair | 62 patients in 5 San Francisco Bay outpatient dialysis units | Time from dialysis date to transplant list referral date Time from transplant list referral date to waitlist date | Race Gender Income Age at start of dialysis Support Hypertension Diabetes Peripheral vascular disease Coronary artery disease HIV Hepatitis C Congestive heart failure Depression Drug abuse
Guerra et al., 2005^88^ Cross-sectional Fair | 136 patients at 4 community clinics, 2 university practices in Pennsylvania | FOBT Sigmoidoscopy or colonoscopy | Ethnicity Medicaid Education Income
Guerra et al., 2005^90^ Cross-sectional Fair | 97 patients at 3 community health plans in Philadelphia, PA | Mammography | Age Education Acculturation Insurance status
Hahn et al., 2007^163^ Cross-sectional Good | 415 adult cancer patients in 5 Chicago area cancer centers | Physical well-being, emotional well-being, and functional well-being (FACT-G) Physical functioning, role-physical, bodily pain, vitality, mental health, fair/poor health (SF-36) Standard Gamble utility score | Age Gender Race/ethnicity Work status Marital status Living arrangement Socioeconomic status Prior computer experience Cancer diagnosis Stage at diagnosis Months since diagnosis Current chemotherapy treatment Performance status
Hibbard et al., 2007^98^ Cross-sectional Fair | 303 community participants | Choosing a quality hospital | Age Gender Education Comprehension Activation
Hironaka et al., 2009^108^ Prospective cohort Fair | 110 caregivers of infants who receive care at 2 pediatric clinics | Days of adherence to giving vitamins to their infants in prior week | Race/ethnicity Caregiver education Caregiver concerns regarding multivitamins and possible side effects Randomized assignment to drops or sprinkle formulation
Hope et al., 2004^83^ Prospective cohort Fair | 61 control group RCT participants with CHF in Indianapolis, IN | ED visits | Race NYHA classification Medications Reading score
Howard, et al., 2005^68^ Prospective cohort Good | 3,260 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Use of inpatient, outpatient, ED, or pharmacy services Costs for 1-year period: overall, inpatient, outpatient, pharmacy Depression (unadjusted) Heart attack (unadjusted) Angina (unadjusted) Stroke (unadjusted) COPD (unadjusted) | Age Sex Race/Ethnicity Income Education Tobacco Alcohol Comorbidities
Howard, 2006^63^ Cohort Fair | 3,260 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Physical HRQoL (SF-12) Mental HRQoL (SF-12) IADL limitation ADL limitation Physical HRQoL Mental HRQoL Self-reported health good or higher Receipt of influenza vaccine Receipt of pneumococcal vaccine | Age Gender Race/ethnicity Education Income Site Morbidity Smoker
Huizinga et al. 2008^10^ Cross-sectional Fair | 160 patients at a primary care clinic at Vanderbilt University | BMI (unadjusted) | None
Johnston et al., 2005^162^ Cross-sectional Fair | 107 adult patients at spinal cord injury clinic in New Jersey | Physical morbidity Mental health morbidity Physical Component score (SF-12) Mental Component score (SF-12) Physical independence Mobility | Motor index Education
Johnson et al., 2010^74^ Cross-sectional Fair | 275 patients at 3 pharmacies at Grady Memorial Hospital in Atlanta, GA (intervention site) and a community-based satellite pharmacy in Decatur, GA (control site) | Adherence to medication regimens | Age Sex
Kalichman et al., 2008^103^ Prospective cohort Fair | 145 HIV-positive adults in Atlanta, GA | Antiretroviral therapy pill adherence (pill counts averaged over past 4 months) Depression (unadjusted) HIV symptoms (unadjusted) | Age Education Years since testing HIV positive HIV symptoms Depression Internalized stigma Social support Alcohol use
Kim, 2009^142^ Cross-sectional Fair | 103 community-dwelling older adults at a community-based senior welfare center in Daegu, Busan, and Kyungpook provinces in Korea | Chronic disease Functional health status Activity limitations | Age Education Income
Kripalani et al., 2006^123^ Cross-sectional Good | 152 patients with coronary heart disease at a clinic in Atlanta, GA | DRUGS: Requiring observed completion of 4 tasks: Identify appropriate medication Open container Select correct dose Report appropriate timing of doses | Age Education Cognitive functioning
Laramee et al., 2007^143^ Cross-sectional Fair | 998 adults with diabetes in primary care practices in Vermont, New Hampshire, and northern New York State | Heart failure | None
Lee, 2009^160^ Cross-sectional Fair | 489 seniors who are patients at 1 of 2 Chicago, IL clinics | General health (self-report) Physical health (SF-12) Mental health (SF-12) | Age Gender Race Education Marital status Income Social support level
LeVine et al., 2004^128^ Cross-sectional Fair | 167 mothers of kindergarten-age children in urban and rural Nepal | Comprehension of radio health messages Comprehension of visual print health message Ability to give an organized health-related narrative | Maternal schooling Childhood socioeconomic status Age Current socioeconomic status Husband's schooling Urban/rural
Lincoln et al., 2006^130^ Prospective cohort Fair | 390 adults in an inner-city short-term inpatient detoxification unit | Depressive symptomatology ASI-Alc ASI-Drug | Time Sex Age Race Education Income Primary language Primary substance of choice Randomization group Mini-mental status exam Outcome variables at baseline
Lindau et al., 2006^96^ Cohort Fair | 68 patients at clinics in a Chicago-area academic medical center | Patient followed up on time after abnormal Pap Patient followed up within 1 year | Age Race HIV status Cancer Unemployment Insurance
Mancuso, 2010^151^ Cross-sectional Good | 102 patients at 2 urban Midwestern US primary care clinics | HbA1c | Patient trust Depression Diabetes knowledge Performance of self-care activities
Mancuso et al., 2006^99,100^ Cross-sectional Fair | 175 patients at a primary care practice in New York City | Access to asthma care Access to care due to other conditions Asthma-related quality of life Physical health-related quality of life (SF-36) | Age Race/ethnicity Sex Comorbidity Language Asthma duration Asthma severity Asthma control
Marteleto, 2008^122^ Prospective cohort Fair | 4,751 individuals aged 14-22 years old at time of Wave 1 of study in Cape Town, South Africa | Sexual debut First pregnancy | Grades completed in 2002 Enrolled in 2002 Age Age squared Race Income Household shock Mother's education Father's education Living with mother Living with father
Mayben et al., 2007^145^ Cross-sectional Fair | 119 adults with HIV receiving care at 4 publicly funded clinics in Houston, TX | CD4 cell count: median (interquartile range) | Gender Reason for getting tested Marijuana use
Miller et al., 2007^89^ Cross-sectional Fair | 50 patients at a university community-based internal medicine clinic | Last time received colon screening | Age
Morris et al., 2006^134^ Cross-sectional Good | 1,002 adults with diabetes in primary care practices in Vermont | HbA1c level SBP DBP LDL-cholesterol Retinopathy Nephropathy Foot/leg problems Gastroparesis Cerebrovascular disease Coronary artery disease Depression (unadjusted) Depression, median Patient Health Questionnaire Score (unadjusted) | Age Sex Race Marital status Insurance Income Duration of diabetes Diabetes education Depression Alcohol use Medication use Physician practice
Muir et al., 2008^161^ Cross-sectional Fair | 110 glaucoma patients at a Duke eye clinic in Durham, NC | VRQoL Score (mean) Physical HRQoL (SF-12) Mental HRQoL (SF-12) | Age Race Visual acuity Visual field Education
Murphy et al., 2010^82^ Cross-sectional Fair | 186 patients at 5 US sites, primarily through the Adolescent Trials Network: Ft. Lauderdale, FL; Philadelphia, PA; Baltimore, MD; and Los Angeles, CA; 1 nonnetwork site was located in Detroit, MI | Medication adherence Viral load Self-efficacy to adherence to medication regimens Medical care received | Age Education level
Murray et al., 2009^78^ Cohort Fair | 192 patients at a university-based public clinic practice in Indianapolis, IN | ED use Hospitalizations | Age Race Insurance NYHA class LVEF Hematocrit CHF score Serum Na, Income Serum K, Cardiomyopathy questionnaire Comparison refill adherence prescription label reading Depression
Nokes et al., 2007^131^ Cross-sectional Fair | 489 HIV-positive adults receiving care in San Francisco, Fresno, Richmond, NYC, Corpus Christi | Depressive symptomatology Distress over body changes HIV symptom intensity Global physical health scale (unadjusted) | Hispanic
Osborn et al., 2007^69^ Cross-sectional Fair | 204 patients at 2 HIV clinics, 1 in Chicago, IL, and 1 in Shreveport, LA | Nonadherence to HIV medications in past 4 days (self-report) | Race Gender Age Income Number of medications in HIV regimen Non-HIV comorbid conditions Mental illness
Osborn et al., 2009^171^ Cross-sectional Good | 383 patients from 2 primary care and 2 diabetes specialty clinics located at 3 medical clinics | HbA1c: most recent in medical record | Analysis 1 Age Sex Years of education Annual income Insulin use Diabetes type Years of diagnosed diabetes Race Analysis 2 and 3 Age Years of diagnosed diabetes Insulin use African American race
Osborn et al., 2010^72^ Cross-sectional Fair | 204 patients at outpatient infectious disease clinics at Northwestern Memorial Hospital in Chicago, IL and Louisiana State University Health Sciences Center in Shreveport, LA | Adherence HIV knowledge and action | Age Insurance coverage Employment status Number of medications in HIV regimen Number of non-HIV prescription meds currently taken Presence of a comorbid chronic condition Treatment for a mental health condition in the past 6 months Treatment for alcohol or drug use in past 6 months
Paasche-Orlow et al., 2005^79^ Prospective cohort Fair | 73 patients at 2 inner-city hospitals for severe asthma | Mastery of metered dose inhaler technique Hospital visits (unadjusted) ED visits (unadjusted) | Age Sex Ethnicity Education Income History of near-fatal asthma Asthma Hospitalization in prior 12 months
Paasche-Orlow, 2005^121^ Cross-sectional Fair | 423 female inmates in Rhode Island adult correctional institute | HIV risk behavior in past 3 months (self-report of sex without a condom or shared injection drug equipment) | Age Race Problem drinking
Paasche-Orlow et al., 2006^105^ Retrospective cohort Fair | 235 patients with HIV and a history of alcohol problems in Boston, MA | 100% adherence to HIV medication regimen (self-report for 3-day period) Viral load suppressed | Gender Age Education Randomization group Ethnicity Homeless status Drank to intoxication past 30 days Injected drugs past 6 months Complexity of regimen
Pandit et al., 2009^155^ Cross-sectional Fair | 330 adults with hypertension receiving primary care from clinics in Grand Rapids, MI, Chicago, IL, and Shreveport, LA | Controlled blood pressure | Age Race Gender Marital status Employment status Insurance coverage Site location Number of comorbid conditions Years treated for hypertension Clinic site Education
Peterson et al., 2007^87^ Cross-sectional Fair | 99 patients at a community health clinic in Nashville, TN | Up-to-date colon screening Self-efficacy for FOBT Self-efficacy for colonoscopy | Age Sex Race Insurance
Powell et al., 2007^149^ Cross-sectional Fair | 68 patients with Type 2 diabetes treated in a general medicine clinic | Diabetes Health Belief Model scale score Most recent HbA1c level | Education Age Race Diabetes knowledge Most recent HbA1c
Powers et al., 2008^154^ Cross-sectional Fair | 1,224 patients with hypertension receiving primary care in the VA healthcare system and Duke University Healthcare system in Durham, NC | SBP | Age Race Marital status Education Adequacy of income Diabetic status Medication adherence Smoking Exercise Participatory decision-making score
Raehl et al., 2006^124^ Cross-sectional Fair | 57 seniors in Amarillo, TX | MedTake Test: ability to open and take own medications while observed by pharmacist | Age Number of OTC drugs Owned a car in last 10 years Received food assistance in last 10 years
Rothman et al., 2006^9^ Cross-sectional Fair | 200 adults in primary care clinic | Understanding nutrition labels Obese (BMI > 30) (unadjusted) Number with chronic illness (unadjusted) | Age Gender Race/ethnicity Income Education Insurance status Presence of chronic disease Status of being on a specific diet Label reading frequency
Schillinger et al., 2006^150^ Cross-sectional Good | 395 diabetes patients (> 30 years old) treated at 1 of 2 primary care clinics at San Francisco General Hospital | HbA1c | Age Primary language other than English Insurance Education
Sentell and Halpin, 2006^141^ Cross-sectional Fair | 23,889 adults in a national sample | Physical, mental, or other health condition that keeps respondent from working Long-term illness (> 6 months) | Race Education Understand English Born in US Unemployed Family income Income missing Sex Age Married Get food stamps Live in metropolitan statistical area Region
Sharif and Blank, 2010^119^ Cross-sectional Fair | 78 patients at a primary care pediatrics clinic in an inner-city academic community health center in the Bronx, NY | BMI-Z score | Age Parental BMI Child eating self-efficacy Parental eating self-efficacy Parental S-TOFHLA
Shone et al., 2009^84^ Cross-sectional Fair | 499 children in a New York school district, where over 40% of children live in poverty | Any urgent care use Child fair/poor health (adjusted) Asthma not under good control (unadjusted) | Ethnicity Race Child health Insurance Parent employment
Smith and Haggerty, 2003^159^ Cross-sectional Fair | 229 adults in university-affiliated family practice center in Montreal, Canada | Perceived general health status | Age Smoking status Maternal language
Sudore et al., 2006^167^ Prospective cohort, retrospective analysis Good | 2,512 well-functioning Medicare recipients living in the community in Memphis, TN and Pittsburgh, PA | Mortality rate | Demographics: age, race, gender, income, education Health status: self-rated health, cardiac disease, stroke, cancer, hypertension, diabetes, obesity Health-related behaviors: former or current smoker, drinking >1 alcoholic beverage per day Poor health care access: lack of a regular doc or clinic, no flu shot within past 12 months, no insurance for medications Psychosocial status: high depressive symptoms, poor personal mastery
Sudore et al., 2006^95^ Cross-sectional Fair | 2,512 well-functioning Medicare recipients living in the community in Memphis, TN, and Pittsburgh, PA | Influenza shot Access measures: No doctor/clinic No insurance for medication Composite of access measures Obesity (BMI >30) (unadjusted) Depression (unadjusted) Hypertension (unadjusted) Diabetes (unadjusted) | Age Race Sex Income Study site Health status Cardiac disease Stroke Cancer Hypertension Diabetes Obesity Depressive symptoms
Tang et al., 2008^148^ Cross-sectional survey and medical chart review Fair | 149 adults with diabetes in diabetes education management center of a public hospital in Hong Kong | HbA1c level | Gender Insurance Duration of diabetes Patient awareness score C-SDSCA (management of diabetes)
Torres et al., 2009^113^ Cross-sectional Fair | 106 women patients at a family health center in New York City | Self-efficacy for taking hormone therapy (unadjusted) | None
von Wagner, 2007^115^ Cross-sectional Fair | 719 individuals in a national sample of British adults | Don't smoke Fruit and vegetable intake > 5/day Any exercise in the last week | Age Education Gender Ethnicity Income
von Wagner et al., 2009^114^ Cross-sectional Fair | 96 adults in London, England between 50-69 years of age | Self-efficacy for participating in CRC screening | Age Ethnicity Employment Gender Number of computer links open Mean reading time CRC screening knowledge
Waite et al., 2008^71^ Cross-sectional Fair | 204 patients at 2 HIV clinics, 1 in Chicago, IL and 1 in Shreveport, LA | Nonadherence to HIV medications in past 4 days (self-report) | Stigma concerns related to HIV medications (self-report) (Investigator-conceptualized as mediator) Age Gender Site Employment status Number of medications in HIV regimen Number of non-HIV prescription medications taken Comorbid chronic condition Treatment for mental health condition Treatment for substance abuse
Waldrop-Valverde et al., 2009^47^ Cross-sectional Fair | 155 patients from an HIV clinic and participants in AIDS drug assistance program in Miami, FL | Medication Management Test (MMT) | Gender Education Time since HIV diagnosis
Walker et al., 2007^133^ Cross-sectional Fair | 363 patients at 3 rheumatology clinics in the United Kingdom | Hospital Anxiety and Depression scales (HAQ and HAD) | None
Weiss et al. 2004^168^ Retrospective cohort Fair | 74 Medicaid beneficiaries in Arizona | Total Medicaid costs, 1-year period | Age Ethnic group Health status
White et al., 2008^86^ Cross-sectional Fair | 18,100 participants in nationally representative US sample living in households | Colon cancer screening Mammography Had flu shot Vision checkup Dental checkup Prostate screening Osteoporosis screening | Age Gender Race Poverty level Insurance Health status Oral reading fluency
Wolf et al., 2005^66^ Cross-sectional Fair | 3,260 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Physical functioning (SF-36) Mental health functioning (SF-36) Hypertension Asthma Bronchitis or emphysema Heart failure Coronary artery disease Diabetes Arthritis Cancer IADL Activity limitations Limitations due to physical health Pain interfering with activities | Age Sex Race/ethnicity Income Education Tobacco Alcohol consumption Self-reported comorbid conditions
Wolf et al., 2007^76^ Cross-sectional Fair | 395 adults in primary care clinics in Shreveport LA; Jackson MI; and Chicago, IL | Correctly interpreted primary prescription label (unadjusted) Correctly attended to auxiliary label (unadjusted) | None
Wolf et al., 2006^157^ Cross-sectional Good | 308 patients with newly diagnosed prostate cancer in 4 outpatient oncology and urology clinics in Chicago area | PSA level > 20 ng/mL | Age Race Annual income Marital status
Wolf et al., 2006^120^ Cross-sectional Fair | 251 adults at a primary care clinic in Shreveport, LA | Read/looked at medication guides and consumer information included with prescription medications | Age Gender Race Education Number of prescriptions taken
Wolf et al., 2007^70^ Cross-sectional Fair | 204 patients at 2 HIV clinics, 1 in Chicago, IL, and 1 in Shreveport, LA | Nonadherence to HIV medications in past 4 days (self- report) Perception of self-efficacy to properly take and manage HIV medications | HIV treatment knowledge (investigator-conceptualized as mediator) HIV medication self-efficacy (investigator conceptualized as mediator) Age Insurance coverage Employment status Number of medications in HIV regimen Number of non-HIV prescription medications currently taking Presence of comorbid chronic conditions Treatment for mental health condition past 6 months Treatment for alcohol or drug use past 6 months
Wolf, 2007^64^ Cross-sectional Fair | 2,923 new Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) | Smoking (never, former, or current) Current alcohol use (none, light to moderate, or heavy) Level of physical activity per week Seat belt use (unadjusted) | Age Gender Race/ethnicity Language (English or Spanish) Site Education Annual income Occupation (white or blue collar)
Yin et al., 2007^125^ Cross-sectional Fair | 292 parents or caregivers of children at an ED in New York City | Self-reported use of nonstandardized dosing instrument | Experience of ever receiving a dosing instrument in a health care setting Child's age Child has regular health care provider Confounders with health literacy: caregiver's education, country of origin, language, socioeconomic status
Yin et al., 2009^102^ Cross-sectional Fair | 6,100 parents from US households | Parent's self-report of children's health insurance status and difficulty understanding OTC medication labels | Age Gender Number of children living in the home Educational attainment Race/ethnicity Country of birth English proficiency Income Region Metropolitan statistical area
Yin et al., 2010^127^ Cross-sectional survey Fair | 302 patients at a public hospital (Bellevue) pediatric clinic in New York, NY | Dosing accuracy | Parent's age Relationship to child Marital status Language Ethnicity US birth SES Presence of a child in the house < 8 years old Presence of a child in the house with a chronic medical condition

ADL= activities of daily living; AIDS=acquired immunodeficiency syndrome; ASI-Alc=Addiction Severity Index–Alcohol; ASI-Drug=Addiction Severity Index – Drugs; BMI=body mass index; CD4=cluster of differentiation 4; CHF=congestive heart failure; COPD=Chronic Obstructive Pulmonary Disease; CRC=colorectal cancer; C-SDSCA=Chinese version of the Summary of Diabetes Self-Care Activities measure; DBPdiastolic blood pressure; DRUGS=Drug Regimen Unassisted Grading Scale; ED=emergency department; ER=emergency room; FACT-G=Functional Assessment of Cancer Therapy-General; FOBT=fecal occult blood test; FQHC=federally qualified health center; HADS=hospital anxiety and depression scales; HAQ=health assessment questionnaire; HbA1c=glycosylated hemoglobin; HIV=human immunodeficiency virus; HRQoL=health-related quality of life; IADL=instrumental activities of daily living; INR=International Normalized Ratio; LDL=low density lipoproteins; LVEF=left ventricular ejection fraction; MMT=Medication Management Test; NYHA=New York Hospital Association; OTC=over-the-counter; Pap=Papanicolau test; SBP=systolic blood pressure; SES=socioeconomic status; Serum K=serum potassium; Serum Na=serum sodium; SF=short form; TOFHLA=Test of Functional Health Literacy in Adults; VA=Veteran's Administration; VRQoL=vision-related quality of life.

Table 6 Measurement tools and criteria used to measure health literacy or literacy in KQ 1 articles

Study | Measurement Tool | Measurement Levels (Continuous or Cutpoints)
Marteleto, 2008^122^ | Cape Area Panel Study Literacy and Numeracy Evaluation | Continuous
Weiss, 2004^168^ | Instrument for the Diagnosis of Reading (IDR- English/Spanish) | < 3rd grade, > 3rd grade
Hope, 2004^83^ | Medication Skills Assessment (Reading Score) | 0 = no correct answers, 1 = correctly answered some questions, 2 = correctly answered all questions
Sentell, 2006^141^ | National Adult Literacy Survey (NALS) literacy and numeracy | Continuous
Bennett, 2009,^85^ White, 2008^86^, Yin, 2009^102^ | National Assessment of Adult Literacy (NAAL) | Below basic, basic, intermediate, proficient
Yin, 2010^127^ | Newest Vital Sign | High likelihood of limited, possible limited, adequate
Levine, 2004^128^ | Reading comprehension and academic language proficiency (noun definitions) in Nepalese | No school, 1-4 years, 5-9 years, 10+ years
Barragan, 2005^93^ | Rapid Estimate of Adult Literacy in Medicine (REALM) | Low or < 6th grade, not low or > 6th grade
Graham, 2007,^104^ Huizinga, 2008,^10^ Lindau, 2006,^96^ Peterson, 2007,^87^ Powers, 2008,^154^ DeWalt, 2007,^80^ Lincoln, 2006,^130^ Muir, 2008,^161^ Shone, 2009,^84^ Sudore, 2006,^167^ Miller, 2007,^89^ Rothman, 2006,^9^ Walker, 2007^133^, Gatti, 2008,^73^ Johnson, 2010^74^ | Rapid Estimate of Adult Literacy in Medicine (REALM) | < 9th grade (score: 0-60), > 9th grade (score: 61-66)
Nokes, 2007,^131^ Raehl, 2006,^124^ Smith 2003^159^ | Rapid Estimate of Adult Literacy in Medicine (REALM) | Continuous
Paasche-Orlow, 2006,^105^ Paasche-Orlow, 2005,^121^ Davis, 2006,^75^ Kripalani, 2006,^123^ Wolf, 2006,^157^ Osborn, 2007,^69^ Wolf, 2006,^120^ Wolf, 2007,^70^ Sudore, 2006,^95^ Waite, 2008,^71^ Wolf, 2007,^76^ Osborn, 2010^72^ | Rapid Estimate of Adult Literacy in Medicine (REALM) | Low or < 6th grade (score: 0-44) Marginal or 7th-8th grade (score: 45-60) Adequate or > 9th grade (score: 61-66)
Powell, 2009,^149^ Estrada, 2004^126^ | Rapid Estimate of Adult Literacy in Medicine (REALM) | < 3rd grade, 4th-6th grade, 7th-8th grade, > 9th grade
Baker, 2004,^62^ Baker, 2007,^65^ Wolf, 2007,^64^ Baker, 2008,^67^ Howard, 2006,^63^ Wolf, 2005^66^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Inadequate (0-55), Marginal (56-66), Adequate (67-100)
Chew, 2004,^107^ Murray, 2009^78^ Torres, 2009,^113^ Raehl, 2006^124^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Inadequate (0-16), Marginal (17-22), Adequate (23-36)
Gazmararian, 2006,^61^ Howard, 2005^68^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Inadequate (0-53), Marginal (54-66), Adequate (67-100)
Grubbs, 2009,^97^ Cho, 2008,^81^ Guerra, 2005,^88^ Guerra, 2005,^90^ Hironaka, 2009,^108^ Laramee, 2007^143^ Lee, 2009^160^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Inadequate/Marginal (Limited) (0-22), Adequate (23-36)
Morris, 2006^134^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Inadequate (0-16), Marginal (17-22), Adequate (23-36) and continuous measurement
Paasche-Orlow, 2005^79^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Inadequate (0-16), Marginal/Adequate (17-36)
Pandit, 2009^155^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Category I: 0-30, Category II: 31-50, Category III: 51-70, Category IV: 71-90, Category V: 91-100
Schillinger, 2006,^150^ Raehl, 2006,^124^ von Wagner, 2007,^115^ Hibbard, 2007,^98^ Sharif, 2010^119^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) | Continuous
Tang, 2007^148^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) (Chinese) | Continuous
Fang, 2006^106^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) (English or Spanish) | Limited (inadequate/marginal, 0-22), Adequate (23-36)
Bennett, 2007^132^ | Short Test of Functional Health Literacy in Adults (S-TOFHLA) (Spanish) | Inadequate (0-55), Marginal (56-66), Adequate (67-100)
Waldrop-Valverde, 2009^47^ | Test of Functional Health Literacy in Adults (TOFHLA) | Continuous
Johnston, 2005,^162^ Mayben, 2007,^145^ Mancuso, 2006,^100^ Mancuso, 2006^99^ Murphy, 2010^82^ | Test of Functional Health Literacy in Adults (TOFHLA) | Inadequate/Marginal (combined; 0-74), Adequate (75-100)
Kalichman, 2008^103^ | Test of Functional Health Literacy in Adults (TOFHLA) | Higher literacy (90% correct or 45 of 50 questions correct), Lower literacy (<90% correct or < 45 correct)
Yin, 2007,^125^ (English or Spanish), Garbers, 2004^91^ (Spanish), Mancuso, 2010^151^ | Test of Functional Health Literacy in Adults (TOFHLA) | Inadequate (0-59), Marginal (60-74), Adequate (75-100)
Kim 2009^142^ | Korean Test of Functional Health Literacy in Adults (TOFHLA) | Higher, lower
Von Wagner, 2009^114^ | United Kingdom Test of Functional Health Literacy in Adults (TOFHLA) | Continuous
Hahn, 2007^163^ | Woodcock Language Proficiency Battery (passage comprehension subtest) | < 7th grade, > 7th grade

Table 8 KQ 1a health literacy studies: strength of evidence grades by health care service outcomes

Outcome for Health Literacy Studies | Number of Studies | Results | Overall Grade
Hospitalization | 6 | Low health literacy associated with increased hospitalization | Moderate
Emergency Care Visit | 9 | Low health literacy associated with greater emergency care use except in 1 study of urgent care visits (measured by self- report) | Moderate
Colon Screening | 5 | Larger studies found lower health literacy associated with lower probability of screening | Low
Pap Tests | 3 | Low health literacy associated with decreased probability of ever having a Pap test | Low
Mammogram | 4 | Low health literacy associated with less use of mammography; measures and populations differed across studies | Moderate
Sexually Transmitted Infection | 1 | Low health literacy associated with greater odds of accepting HIV testing | Low
Immunization: Influenza | 4 | Low health literacy associated with lower probability of receipt of influenza vaccine | Moderate
Immunization: Pneumococcal | 2 | Mixed results | Insufficient
Access to Care | 9 | Mixed results for association with number of physician visits, dental and vision visits | Insufficient
Access to Insurance | 1 | Parental low health literacy associated with having child without health insurance | Low

HIV=human immunodeficiency virus; Pap=Papanicolau.

Table 16 KQ 1b health literacy studies: strength of evidence grades by health outcomes

Outcome for Health Literacy Studies | Number of Studies | Results | Strength of Evidence Grade
Adherence | 11 | Mixed results depending on adherence measure, disease state, and adjustment for confounding | Insufficient
Self-efficacy | 5 | Mixed results in studies conducted within various sub-populations | Insufficient
Smoking | 2 | Mixed results | Insufficient
Alcohol and substance use | 2 | No effect on current alcohol consumption. Positive relationship between health literacy level and substance use in one study. | Insufficient
Healthy lifestyle (physical activity, eating habits, and seat belt use) | 3 | Mixed results from studies examining exercise, diet, a composite measure, and seatbelt use | Insufficient
Healthy lifestyle (obesity and weight) | 5 | Mixed results, 4 of 5 studies unadjusted | Insufficient
Review of prescription information | 1 | Low health literacy associated with being less likely to read prescription information | Low
HIV risk and sexual behaviors | 2 | Mixed results | Insufficient
Taking medications appropriately | 6 | Lower health literacy associated with poorer ability to demonstrate being able to take mediations appropriately | Moderate
Interpreting labels and health messages | 3 | Low health literacy associated with poorer ability to interpret labels and health messages; smaller likelihood of giving an organized health narrative | Moderate
Asthma self-care | 1 | Low literacy associated with poorer self-care skill in 1 study | Low
Mental health symptomatology | 10 | Results in 8 of 10 studies found association between lower health literacy and depression but control for confounding was limited | Low
Chronic disease outcomes | 7 | Mixed results: 3 studies on association with chronic diseases generally and 4 studies on association with specific diseases | Insufficient
HIV severity and symptoms | 5 | Results in 3 studies found no relationship but control for confounding was limited and sample sizes were small | Low
Asthma severity and control | 2 | Mixed results; only unadjusted analysis of asthma control | Insufficient
Diabetes control and related symptoms | 5: 5 glycemic control, 1 complications | Glycemic control: mixed results Complications: no relationship | Insufficient
Hypertension control | 2 | Mixed results | Insufficient
Prostate cancer control | 1 | More likely to have higher prostate-specific antigen (PSA) test results (worse levels) | Low
Health status: all adults | 1 | No relationship with global health status | Low
Health status and quality of life: seniors | 5 | Lower overall health status Mixed effects mental and physical functioning | Overall: Moderate Mental and physical: Insufficient
Health status and quality of life: individuals with specific diseases | 5 | Mixed results: mental and physical functioning by disease state and measure | Insufficient
Mortality: seniors | 2 | Higher risk of mortality in the lower literacy group; risk not elevated in the marginal literacy group (1 study) | High

Table 30 KQ 1c health literacy studies: strength of evidence grades by costs of health care

Outcome for Health Literacy Studies | Number of Studies | Results | Strength of Evidence Grade
Costs of health care | 2 | Mixed results across payment source and patient populations | Insufficient

Table 32 KQ 1d health literacy studies: strength of evidence grades by disparities across health outcomes

Outcome for Health Literacy Studies | Number of Studies | Results | Strength of Evidence Grade
Disparities across health outcomes | 8 | Health literacy mediates disparities in specific health outcomes between black and white race in selected outcomes. Health literacy not found to mediate the relationship between Hispanic and white race but little data available. Health literacy found to mediate the relationship between males and females in one, study, no other data available. | Black vs. white: Low Hispanic: Insufficient Sex: Insufficient

Table 7 Summary of studies of the relationship between health literacy and emergency department and hospitalization rates (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
Baker et al., 2004^62^ Cohort N = 3,260 Good | Enrollees in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 24.5% Marginal: 11.2% Adequate: 64.2% | Age Gender Race Physical and mental health Chronic diseases Smoking Alcohol use BMI Study site Months enrolled | Any ED visits Inadequate: 30.4% Marginal: 27.6% Adequate: 21.8% 1 ED visit Inadequate: 17.0% Marginal: 15.3% Adequate: 15.0% 2 or more ED visits Inadequate: 13.4% Marginal: 12.3% Adequate: 6.8% | Higher rate in inadequate or marginal compared with adequate Any ED visits Marginal: NR; P = 0.01 Inadequate: NR; P < 0.001 Higher rate in inadequate than adequate; no difference for marginal 1 ED visit Marginal: RR, 1.01; 95% CI, 0.76-1.33 Inadequate: RR, 1.07; 95% CI, 0.86-1.33 Higher rate in inadequate or marginal compared with adequate 2 or more ED visits Marginal: RR, 1.44; 95% CI, 1.01-2.02 Inadequate: RR, 1.34; 95% CI, 1.00-1.79
Howard, et al., 2005^68^ Cohort N = 3,260 Good | New Medicare managed-care enrollees in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 24.5% Marginal: 11.2% Adequate: 64.2% | Age Sex Race/ethnicity Income Education Tobacco Alcohol Comorbidities | Inpatient use Inadequate: 35% Marginal: 34% Adequate: 27% ED use Inadequate: 30% Marginal: 28% Adequate: 21% | Higher probability of inpatient and ED services in inadequate than adequate Mean differences in probability of inpatient use in inadequate vs. adequate: 0.05; 95% CI, 0.00-0.09 ED: 0.05; 95% CI, 0.01-0.10 Mean differences in probability of marginal vs. adequate inpatient use: 0.04; 95% CI, -0.01-0.09 ED: 0.04; 95% CI, -0.01-0.09 pharmacy: -0.04; 95% CI, -0.08-0.00
Hope et al., 2004^83^ Cohort N = 61 Fair | Control group RCT participants with CHF in Indianapolis, IN Ability to read standard prescription Literacy level: NR Mean reading score: 1.65 ± 0.56 | Race NYHA classification Medications Reading score | ED visits: Data NR | Higher cardiovascular-related ED visits in patients with worse prescription label reading skills NR; P = 0.002
Murray et al., 2009^78^ Cohort N = 192 Fair | University-based public clinic practice in Indianapolis Indiana S-TOFHLA Inadequate: 29.2% Adequate: 70.8% | Age Race Insurance NYHA class LVEF Hematocrit CHF score Serum Na, Income Serum K, Cardiomyopathy questionnaire Comparison refill adherence prescription label reading Depression | ED use: Data NR Hospitalization: Data NR | Adequate had a lower risk of hospitalization for heart failure than adequate All-cause ED visits (unadjusted) Prescription label reading score, 1-pt increment: IRR, 0.76; 95% CI, 0.59-0.97 Heart-failure-specific ED visits (unadjusted) Prescription label reading score: IRR, 0.36; 95% CI, 0.19-0.69 All-cause hospitalization (unadjusted) Prescription label reading score: IRR, 0.68; 95% CI, 0.54-0.86 Heart-failure-specific hospitalization (unadjusted): IRR, 0.34; 95% CI, 0.15-0.76
DeWalt et al., 2007^80^ Retrospective cohort N = 150 Fair | General, asthma and allergy, and pulmonary clinic at children's hospital REALM Low: 24% High:76% | Child age Household income Parental race Parental asthma knowledge Parental smoking Asthma severity classification Controller medication use Site of care | ED visits (per child) Inadequate: 1.53 Adequate: 1.08 Hospitalizations Inadequate: 0.39 Adequate: 0.12 | Children of parents with low HL had a greater incidence of ED visits than those with higher HL: IRR, 1.4; 95% CI, 0.97-2.0 Children of parents with low HL had a greater incidence of hospitalizations more than with higher HL: IRR, 4.6; 95%, CI 1.8-12
Cho et al., 2008^81^ Cross-sectional N = 489 Fair | Elderly outpatients at a hospital and an FQHC in Chicago S-TOFHLA Inadequate: 50.9% Adequate: 49.1% | Race Ethnicity Gender Educational attainment | ER visits: Data NR Hospitalizations: Data NR Preventive care: Data NR | More ER visits in lower HL group; P < 0.05 More hospitalizations in lower HL group; P < 0.05 Less preventive care in lower health literacy group; P < 0.05
Paasche-Orlow et al., 2005^79^ Prospective cohort N = 73 Fair | 2 inner-city hospitals S-TOFHLA Inadequate: 22% Adequate: 78% | None | Hospital visit past 12 months Inadequate: 81% Adequate: 52% ED visit past 12 months Inadequate: 88% Adequate: 75% | Inadequate HL associated with more hospitalization in past 12 mos.: (unadjusted) NR; P = 0.04 Inadequate HL not associated with ED visits in past 12 mos.; (unadjusted) P = 0.28
Shone et al., 2009^84^ Cross-sectional N = 499 Fair | New York school district, where > 40% of children live in poverty REALM Low: 33% Adequate: 67% | Ethnicity Race Child health Insurance Parent employment | Used any urgent care Low: 40.9% Adequate: 41.2% | Parent HL level not related to urgent care Used any urgent care; (unadjusted) P > 0.999
Murphy, 2010^82^ Cross-sectional N= 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit S-TOFHLA-modified Inadequate: 12% Marginal: 3% Adequate: 86% | Age Education | ER visits Data by HL: NR Overnight hospital stays Data by HL: NR | HL level not related to ER visits - > 1 compared to none (adjusted): OR, 0.98; 95% CI, 0.96-1.01 HL level not related to overnight hospital stay - > 1 compared to none (adjusted): OR, 0.97; 95% CI, 0.93-1.01

BMI=body mass index; CHF=congestive heart failure; CI=confidence interval; ED=emergency department; FQHC=Federally Qualified Health Center; HIV=human immunodeficiency virus; HL=health literacy; IRR=incidence rate ratio; LVEF=left ventricular ejection fraction; N=number; NR=not reported; NYHA=New York Heart Association; OR=odds ratio; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; RR=relative risk; Serum K=Serum K=serum potassium; S-TOFHLA=Short Test of Functional Health Literacy in Adults.

Table 9 Summary of studies of the relationship between health literacy and colon cancer screening (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
Miller et al., 2007^89^ Cross-sectional N= 50 Fair | University community-based internal medicine clinic REALM Limited: 48% Adequate: 52% | Age | Self-report of last time received colon screening Limited: 54% Adequate: 58% | No difference between limited and adequate groups: RR, 0.99; 95% CI, 0.64 -1.55
Cho et al., 2008^81^ Cross-sectional N = 489 Fair | Elderly outpatients at Hospital and an FQHC in Chicago S-TOFHLA Inadequate:50.9% Adequate: 49.1% | Race Ethnicity Gender Education | Self-report FOBT: NR | Decreased probability in inadequate compared with adequate group; P < 0.05
Peterson et al., 2007^87^ Cross-sectional N = 99 Fair | Community health clinic in Nashville, TN REALM Limited: 29.3% Adequate 70.7% | Age Sex Race Insurance | Self-report of colon screening Inadequate: 51.7% Adequate: 65.7% | No difference between limited and adequate groups: OR, 0.67; 95% CI, 0.24-1.83
Guerra et al., 2005^88^ Cross-sectional N = 136 Fair | 4 community clinics, 2 university practices in PA S-TOFHLA Inadequate:36% Marginal: 6% Adequate:58% | Ethnicity Medicaid Education Income | Self-report FOBT Inadequate/Marginal: 39% Adequate: 64% Sigmoidoscopy or Colonoscopy Inadequate/Marginal: 30% Adequate: 72% | No differences between inadequate/marginal and adequate groups: FOBT; P = 0.66 Sigmoidoscopy or Colonoscopy; P = 0.52
White et al., 2008^86^ Cross-sectional N = 18,100 Fair | Nationally representative US sample living in households NAAL Basic/below basic: 36% Intermediate: 56% Proficient: 12% | Age Gender Race Poverty level Insurance Health status Oral reading fluency | Self-report of colon screen Below basic: 38% Basic: 41% Intermediate: 41% Proficient: 36% | Adults over 65 years: Decreased probability of having colon cancer screening basic/below basic groups; P < 0.05

CI=confidence interval; FOBT=fecal occult blood test; FQHC=federally qualified health center; N=number; NAAL=national assessment of adult literacy; NR=not reported; OR=odds ratio; REALM=Rapid Estimate of Adult Literacy in Medicine; RR=relative risk; S-TOFHLA=Short Test of Functional Health Literacy in Adults.

Table 10 Summary of studies of the relationship between health literacy and Pap tests (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
Cho et al., 2008^81^ Cross-sectional N = 489 Fair | Elderly outpatients at Hospital and an FQHC in Chicago S-TOFHLA Inadequate: 51% Adequate: 49% | Race Ethnicity Gender Education | Pap: NR | Less Pap screening in inadequate group than adequate group; P < 0.05
White et al., 2008^86^ Cross-sectional NAAL N = 18,100 Fair | Nationally representative US sample living in households Basic or below basic: 36% Intermediate: 56% Proficient: 12% | Age Race Gender Poverty level Insurance Health status Oral reading fluency | Pap test (age 18-65) Below basic: 63% Basic: 67% Intermediate: 70% Proficient: 74% | Adults under 40 decreased probability of having a Pap test in basic/below basic than higher groups: P < 0.05 Adults 40-64 no differences by HL level; P > 0.05
Garbers et al., 2004^91^ Cross-sectional N = 205 S-TOFHLA Fair | Women recruited through their younger female relatives in 2 women's health centers in New York City Inadequate: 30% Marginal: 19% Adequate: 51% | Having a source of care Having any health insurance Age Years in the US Education | Ever had a Pap test Inadequate: 80% Adequate: 99% Marginal: 92.1% Pap test within past 3 years Inadequate: 62.3% Adequate: 82.9% Marginal: 82.1% | Less likely to ever have had a Pap test in inadequate compared to marginal and adequate Marginal: OR, 0.14; 95% CI, 0.01-1.41 Inadequate: OR, 0.06; 95% CI, 0.01-0.55 No differences in Pap test within past 3 years Marginal: OR, 1.31; 95% CI, 0.44-3.85 Inadequate: OR, 0.53; 95% CI, 0.21-1.35

CI=confidence interval; FQHC=federally qualified health center; HL=health literacy; N=number; NAAL=National Assessment of Adult Literacy; NR=not reported; OR=odds ratio; Pap=Papanicolau, S-TOFHLA=Short Test of Functional Health Literacy in Adults; US=United States.

Table 11 Summary of studies of the relationship between health literacy and mammography (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
Bennett et al., 2009^85^ Cross-sectional N = 2,668 Good | Nationally representative sample of US population 65 and older NAAL Below basic: 29.0% Basic: 29.5% Intermediate: 38.2 Proficient: 3.3% | Age Race Gender Income Nativity | Mammography: NR | Lower utilization of mammography in the below basic/basic group; P < 0.05
Cho et al., 2008^81^ Cross-sectional N = 489 Fair | Outpatients at hospital and an FQHC in Chicago S-TOFHLA Inadequate:50.9% Adequate: 49.1% | Race Ethnicity Gender Education | Mammography: NR | Less mammography in inadequate group than adequate group; P < 0.05
White et al., 2008^86^ Cross-sectional N = 18,100 Fair | Nationally representative US sample living in households NAAL Basic or below basic: 36% Intermediate:56% Proficient: 12% | Age Gender Race Poverty level Insurance status Self-reported health status, Oral reading fluency | Mammogram (age >40) Below basic:58% Basic: 61% Intermediate:62% Proficient: 62% | Adults >65: Decreased probability mammography in below basic or basic group; P < 0.05
Guerra et al., 2005^90^ Cross-sectional N = 97 Fair | 3 community health clinics in Philadelphia S-TOFHLA Inadequate: 70% Adequate: 30% | Age Education Acculturation Insurance status | Mammogram: NR | Inadequate HL associated with only lower odds of ever having a mammogram Ever had a mammogram: OR, 0.88; 95% CI, 0.79-0.98 Had last mammogram within 1 yr: OR, 0.99; 95% CI, 0.92-1.05 Had last mammogram within 2 yrs: OR, 1.02; 95% CI, 0.93- 1.09 Had mammogram as part of checkup: OR, 0.99; 95% CI, 0.92-1.06

CI=confidence interval; FQHC=federally qualified health center; HL=health literacy; N=number; NAAL=National Assessment of Adult Literacy; NR=not reported; OR=odds ratio; S-TOFHLA=Short Test of Functional Health Literacy in Adults; yr=year.

Table 12 Summary of studies of the relationship between health literacy and sexually transmitted infections testing (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
Barragan et al., 2005^93^ Cross-sectional N = 372 Fair | Inner city public hospital urgent care center, Atlanta, GA REALM Inadequate: 25% Adequate: 75% | Age Education | HIV Test Acceptance: NR | Inadequate HL positively associated with acceptance of HIV test compared with adequate group: OR, 2.017; 95% CI, 1.190-3.418

CI=confidence interval; HIV=human immunodeficiency virus; HL=health literacy; N=number; NR=not reported; OR=odds ratio; REALM=Rapid Estimate of Adult Literacy in Medicine.

Table 13 Summary of studies of the relationship between health literacy and immunizations (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
White et al., 2008^86^ Cross-sectional N = 18,100 Fair | Nationally representative US sample living in households NAAL Basic or below basic: 36% Intermediate: 56% Proficient: 12% | Age Gender Race Poverty level Insurance Health status, Oral reading fluency | Pneumonia shot Below basic: 39% Basic: 42% Intermediate: 38% Proficient: 27% Flu shot Below basic: 39% Basic: 37% Intermediate: 32% Proficient: 26% | Increased probability of having a flu shot in basic/below basic group Adults < 40; P < 0.05 Adults 40-64; P = NS Adults >65: Decreased probability of flu shot; not related to having a pneumonia shot (P < 0.05)
Howard et al., 2006^63^ Cohort N = 3260 Fair | Prudential Medicare managed care plan in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 24.4% Marginal: 11.5% Adequate: 64.4% | Age Gender Race/Ethnicity Education Income Site Morbidity Smoker | Influenza vaccine: NR Pneumococcal vaccine: NR | Influenza vaccine receipt lower in inadequate than adequate: OR, 0.76; P = 0.020 No differences in pneumococcal vaccine receipt between inadequate and adequate: OR, 0.85; P = 0.114 No difference between marginal and adequate groups Influenza vaccine: OR, 1.06; P = 0.707 Pneumococcal vaccine: OR, 0.91; P = 0.445
Sudore et al., 2006^95^ Cross-sectional N = 2,512 Fair | Well-functioning, Medicare recipients living in the community in Memphis and Pittsburgh REALM Limited: 24% Adequate: 76% | Age Race Sex Income Study site Health status Cardiac disease Stroke Cancer Hypertension Diabetes Obesity Depressive symptoms | Influenza shot: NR | Inadequate less likely to have influenza shot in 12 months: OR, 0.59; 95% CI, 0.41-0.83 Marginal less likely to have influenza shot in 12 months: OR, 0.94; 95% CI, 0.7-1.25
Bennett et al., 2009^85^ Cross-sectional N = 2668 Good | Nationally representative sample of US population 65 and older NAAL Below basic: 29.0% Basic: 29.5% Intermediate: 38.2 Proficient: 3.3% | Age Race Gender Income Nativity | Influenza vaccination: NR | Lower utilization of influenza vaccination in below basic and basic group; P < 0.05

CI=confidence interval; N=number; NAAL=national assessment of adult literacy; NR=not reported; NS=not significant; OR=odds ratio; REALM=Rapid Estimate of Adult Literacy in Medicine; S-TOFHLA=Short Test of Functional Health Literacy in Adults; US=United States.

Table 14 Summary of studies of the relationship between health literacy and access to care and access to insurance (KQ 1a)

Authors, Year, Study Design, Literacy tool, Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Results By Health Literacy Skill Level | Differences in Results Between Health Literacy Skill Levels
Baker et al., 2004^62^ Cohort N = 3,260 Good | Prudential Medicare managed care enrollees in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 24.5% Marginal: 11.2% Adequate: 64.2% | Age Gender Race Physical and Mental health Chronic-diseases Smoking Alcohol use BMI Study site Months enrolled | Number of physician visits Inadequate: 9.8% Marginal: 9.3% Adequate: 8.1% Total physician visits Inadequate: 13.7 Marginal: 13.5 Adequate: 14.3 Mean physician visits Inadequate: 2.2 Marginal: 2.2 Adequate: 2.2 | HL not associated with time to first physician visit, mean number of physician visits, or no physician visit in the first year Number of physician visits Marginal: OR,1.23; 95% CI, 0.82-1.85 Inadequate: OR, 1.23; 95% CI, 0.88-1.72 Time to first visit Marginal: HR, 0.89; 95% CI, 0.78-1.00 Inadequate: HR, 0.94; 95% CI, 0.84-1.04 Mean visits Marginal: NR; P = 0.34 Inadequate: NR; P = 0.38 Mean visits Marginal: NR; P = 0.27 Inadequate: NR; P = 0.62
Howard et al., 2005^68^ Cohort N = 3,260 Good | New Prudential Medicare managed-care enrollees in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 24.5% Marginal: 11.2% Adequate: 64.2% | Age Sex Race/Ethnicity Income Education Tobacco Alcohol Comorbidities | Overall use Inadequate: 95% Marginal: 96% Adequate: 97% Inpatient use Inadequate: 35% Marginal: 34% Adequate: 27% Outpatient use Inadequate: 90% Marginal: 90% Adequate: 91% ED use Inadequate: 30% Marginal: 28% Adequate: 21% Pharmacy use Inadequate: 85% Marginal: 85% Adequate: 88% | Inadequate HL not related to overall use, outpatient, or pharmacy use Marginal HL used more pharmacy services than those with adequate HL All other use comparisons not significant Mean differences in probability of use Inadequate vs. adequate Overall: 0.00; 95% CI, -0.02-0.02 Outpatient: -0.02; 95% CI, -0.05-0.01 Pharmacy: -0.03; 95% CI, -0.06-0.00 Mean differences in probability of use Marginal vs. adequate Overall: 0.00; 95% CI, -0.02-0.03 Outpatient: -0.01; 95% CI, -0.04-0.02 Pharmacy: -0.04; 95% CI, -0.08-0.00
Lindau et al., 2006^96^ Cohort N = 68 Fair | Clinics in Chicago area academic medical center REALM Inadequate: 35% Adequate: 65% | Age Race HIV status Cancer Unemployment Insurance | Patient followed up on time after abnormal Pap Inadequate: 33% Adequate: 66% Patient followed up within one year Inadequate: 67% Adequate: 80% | No differences on-time follow-up after an abnormal Pap smear between inadequate and adequate groups: OR, 2.05; 95% CI, 0.47-8.85 No differences in predicting women's follow-up within one year between inadequate and adequate groups: OR, 3.75; 95% CI, 0.81-17.4
Grubbs et al., 2009^97^ Retrospective cohort N = 62 Fair | 5 San Francisco bay outpatient dialysis units S-TOFHLA Inadequate: 32.3% Adequate: 67.7% | Race Gender Income Age at start of dialysis Support Hypertension Diabetes Peripheral vascular disease Coronary artery disease HIV Hepatitis C Congestive heart failure Depression Drug abuse | Time from dialysis date to transplant list referral date Inadequate: 23.5 mos Adequate: 15.3 mos Time from transplant list referral date to waitlist date Inadequate: 6.6 mos Adequate: 2.1 mos | Longer time from dialysis date to transplant referral list date in inadequate group than adequate group: HR 4.54; 95% CI, 1.67-12.5 No difference in time from transplant list referral date to Waitlist date by HL: HR 1.25; 95% CI, 0.62-3.45
Hibbard et al., 2007^98^ Cross-sectional N = 303 Fair | Community TOFHLA (passage B) Low: 45% High: 55% | Age Gender Education Comprehension Activation | Choosing a quality choice hospital: NR | No differences in predicting quality choice of a hospital between inadequate and adequate groups; P = NS
Sudore et al., 2006^95^ Cross-sectional N = 2,512 Fair | Well-functioning, Medicare recipients living in the community with multiple sources of medical care in Memphis and Pittsburgh REALM Limited: 24% (= 8.8%, 0-6th grade, + 15.2%, marginal/7-8th grade) Adequate: 76% | Age Race Sex Income, Study site Health status Cardiac disease Stroke Cancer Hypertension Diabetes Obesity Depressive symptoms | Doctor/clinic Insurance for meds Composite access measure: NR | Less access in 3 of 4 access measures between limited and adequate group. No doctor/clinic: OR, 0.79; 95% CI, 0.43-1.45 No insurance for medication: OR, 0.58; 95% CI, 0.41-0.81 Composite access measure: OR, 0.51; 95% CI, 0.35-0.75 Marginal group did not differ from adequate group in any access measures No doctor/clinic: OR, 0.90; 95% CI, 0.54-1.49 No insurance for medication: OR, 0.97; 95% CI, 0.75-1.25 Composite access measure: OR, 1.05; 95% CI, 0.81-1.35
Mancuso et al., 2006^99,100^ Cross-sectional N = 175 Fair | Primary care practice in New York City TOFHLA Inadequate: 10% Marginal: 8% Adequate: 82% | Age Race/ethnicity Sex Comorbidity Language Asthma duration Asthma severity Asthma control | Access to asthma care: NR Access to care due to other conditions: NR | No difference by HL level More difficult to access asthma care; P = 0.58 More difficult access to medical care for other medical conditions; P = 0.005
White, et al., 2008^86^ Cross-sectional N = 18,100 Fair | Nationally representative US sample living in households NAAL Basic or below basic: 36% Intermediate: 56% Proficient: 12% | Age, Gender Race Poverty level Insurance status Self-reported health status, Oral reading fluency | Dental checkup Below basic: 44% Basic: 59% Intermediate: 70% Proficient: 77% Vision checkup Below basic: 54% Basic: 58% Intermediate: 59% Proficient: 58% Prostate screen Below basic: 31% Basic: 34% Intermediate: 31% Proficient: 26% Osteoporosis screen Below basic: 17% Basic: 13% Intermediate: 11% Proficient: 7% | Adults under 40 Decreased probability of having a vision check-up for below basic/basic HL: NR; P < 0.05 No association with dental check-ups, P = NS Adults 40-64 Decreased probability of dental checkup for below basic/basic; P < 0.05 Adults > 65 Decreased probability of dental check-up, vision check-up, osteoporosis screening, and prostate cancer screening in below basic/basic HL group; P < 0.05 No differences by HL related to men's screening for osteoporosis: P = NS
Murphy, 2010^82^ Cross-sectional N= 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit TOFHLA-modified Inadequate: 12% Marginal: 3% Adequate: 86% | Age Education | Medical care received Data by HL level: NR | The likelihood of receiving medical care was related to higher HL level Medical care received 3 or more times (adjusted): OR, 1.09; 95% CI, 1.04-1.15 Medical care received once or twice (adjusted): OR, 1.06; 95% CI, 1.02-1.09
Yin, 2009^102^ Cross-sectional N = 6,100 Fair | Parents ≥ 16 years old living in a US household (nationally representative sample) NAAL Below basic: 11% Basic: 18% Intermediate: 56% Proficient: 15% | Age Gender Number of children living in the home Education Race/ethnicity Country of birth English proficiency Income Region Metropolitan statistical area | At least 1 child without health insurance Below basic: 24% Basic: 10% Intermediate: 6% Proficient 3% | In comparison to HL proficient group, odds are greater that at least 1 child is without health insurance (adjusted) Below basic: AOR, 2.4; 95% CI, 1.1-4.9 Basic: AOR, 1.7; 95% CI, 0.5-5.7 Intermediate: AOR, 1.4; 95% CI, 0.4-4.2

AOR=adjusted odds ratio; BMI=body mass index; CI=confidence interval; ED=emergency department; HIV=human immunodeficiency virus; HL=health literacy; HR=hazard ratio; mos=months; N=number; NAAL=National Assessment of Adult Literacy; NR=not reported; NS=not significant; OR=odds ratio; REALM=Rapid Estimate of Adult Literacy in Medicine; sig=significant; S-TOFHLA=Short Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; vs.=versus.

Table 15 Summary of studies of the relationship between health literacy and adherence (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables Used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | | | Differences in Outcomes Between Health Literacy Levels
Graham et al., 2007^104^ Retrospective cohort N = 87 Fair | Patients at an HIV clinic in Philadelphia, Pennsylvania REALM Low: 49% Adequate: 51% | Individual's norm for acceptable adherence (investigator controlled as mediator) | < 95% adherence to HIV medication regimen (self-report of pill counts over past 3 months) Low: 60% Adequate: 36% | | | Norms found to mediate the relationship between HL and nonadherence Difference between low and adequate groups (unadjusted): OR, 0.36; 95% CI, 0.16-0.88 No difference in nonadherence (adjusted): OR, 0.36; 95% CI, 0.17-1.02
Kalichman et al., 2008^103^ Prospective cohort N = 145 Fair | HIV positive adults in Atlanta, GA TOFHLA Lower: 49% Higher: 51% | Age Education Years since testing HIV positive HIV symptoms Depression Internalized stigma Social support Alcohol use | Antiretroviral therapy pill adherence < 85% (pills counts averaged over past 4 months) Lower: 84% Higher: 69% | | | Antiretroviral therapy pill nonadherence greater in lower health literacy group (adjusted): OR, 3.77; 95% CI, 1.46-9.93
Murphy et al., 2010^82^ Cross-sectional N = 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit TOFHLA-modified Inadequate/Marginal: 15% Adequate: 86% | Age Education | Self- reported medication adherence over past 3 days Inadequate/marginal ≥ 90%: 24% > 0 to < 90%: 41% 0%: 35% Adequate ≥ 90%: 36% > 0 to < 90%: 24% 0%: 41% | | | No difference in medication adherence level by HL (adjusted) ≥ 90% adherent: OR, 1.00; 95% CI, 0.96-1.05 > 0% and < 90% adherent: OR, 1.00; 95% CI, 0.95-1.04
Osborn et al., 2007^69^ (companions: Wolf et al., 2007;70 Waite et al., 2008^71^, Osborn et al., 2010^72^) Cross-sectional N = 204 Fair | Patients at 2 HIV clinics, 1 in Chicago, Illinois and 1 in Shreveport, Louisiana REALM Low: 11% Marginal: 20% Adequate: 69% | Race Gender Age Income Number of medications in HIV regimen Non-HIV comorbid conditions Mental illness | Nonadherence to HIV medications in past 4 days (self-report) Low: 52% Marginal: 19% Adequate: 30% | | | Nonadherence: Higher in low than adequate group (adjusted): OR, 2.12; 95% CI, 1.93-2.32 No difference between marginal and adequate groups (adjusted): OR, 1.55; 95% CI, 0.93-2.45
Osborn et al., 201072 (companions: Osborne et al., 2007;69 Wolf et al., 2007;70 Waite et al., 2008^71^ Cross-sectional N = 204 Fair | Patients at 2 HIV clinics, 1 in Chicago, Illinois and 1 in Shreveport, Louisiana REALM Low: 11% Marginal: 20% Adequate: 69% | Age Insurance coverage Employment status Number of medications in HIV regimen Number of non-HIV prescription meds currently taken Presence of a comorbid chronic condition Treatment for a mental health condition Treatment for alcohol or drug use | Nonadherence (<90%-95%) to HIV medications in past 4 days (self-report) Low: 89% Marginal: 80% Adequate: 31% | | | Nonadherence: Positively associated with being in the low compared to adequate group (adjusted): OR, 3.3; 95% CI, 1.3-8.7 No difference between marginal and adequate group (adjusted): OR, 2.1; 95% CI, 0.8-5.5
Paasche-Orlow et al., 2006^105^ Retrospective cohort N = 235 Fair | Patients with HIV and a history of alcohol problems in Boston, Massachusetts REALM: Low: 14% Marginal: 29% Adequate: 57% | Gender Age Education Randomization group Ethnicity Homeless status Drank to intoxication past 30 days Injected drugs past 6 months Complexity of regimen | 100% adherence to HIV medication regimen (self-report for 3 day period) Low: 69% Marginal: 63% Adequate: 64% | | | Total adherence: No difference between low and adequate group (adjusted): OR, 1.93; 95% CI, 0.86-4.31 No difference between marginal and adequate group (adjusted): OR, 1.29; 95% CI, 0.77-2.19
Waite et al., 2008^71^ (Companions: Osborn et al., 2007;69 Wolf et al., 2007^70^; Osborne et al., 2010^72^) Cross-sectional N = 204 Fair | Patients at 2 HIV clinics, 1 in Chicago, Illinois and 1 in Shreveport, Louisiana REALM Low: 11% Marginal: 20% Adequate: 69% | Stigma concerns related to HIV medications (self-report) (investigator controlled as mediator) Age Gender Site Employment status Number of medications in HIV regimen Number of non-HIV prescription medications taken Comorbid chronic condition Treatment for mental health condition Treatment for substance abuse | | Nonadherence to HIV medications in past 4 days (self-report) Low: 52% Marginal: 19% Adequate: 30% | Nonadherence (adjusted-not controlling for stigma) Positively related to being in the low compared to the adequate group: OR, 3.3; 95% CI, 1.3-8.7 No difference between marginal and adequate group: OR, 2.1; 95% CI, 0.8-5.5 Nonadherence (adjusted-controlling for stigma) No difference between low and adequate group: OR, 2.1; 95% CI, 0.7-6.5 No difference between low and adequate group: OR, 0.7; 95% CI, 0.2-1.8
Wolf et al., 2007^70^ (companions: Osborn et al., 2007;69 Waite et al., 200871; Osborne et al., 2010^72^) Cross-sectional N = 204 Fair | Patients at 2 HIV clinics, 1 in Chicago, Illinois and 1 in Shreveport, Louisiana REALM Low: 11% Marginal: 20% Adequate: 69% | HIV treatment knowledge (investigator controlled as mediator) HIV medication self-efficacy (investigator controlled as mediator) Age Insurance coverage Employment status Number of medications in HIV regimen Number of non-HIV prescription medications currently taking Presence of comorbid chronic conditions Treatment for mental health condition past 6 months Treatment alcohol or drug use past 6 months | | Nonadherence to HIV medications in past 4 days (self-report) Low: 52% Marginal: 19% Adequate: 30% | Nonadherence (adjusted-not controlling for knowledge and self-efficacy) Positively related to being in the low compared to the adequate group: OR, 3.3; 95% CI, 1.3-8.7 No difference between marginal and adequate group: OR, 2.1; 95% CI, 0.8-5.5 Nonadherence mediation analysis (adjusted-controlling for knowledge and self-efficacy) No difference between low and adequate groups: OR, 2.0; 95% CI, 0.8-5.3 No difference between marginal and adequate groups: OR, 1.6; 95% CI, 0.6-4.7
Chew et al., 2004^107^ Prospective cohort N = 332 Fair | Preoperative clinic of the VA Puget Sound S-TOFHLA Low (Inadequate/Marginal): 12% Adequate: 88% | Age Marital status Number of medications Cognitive functioning | | Nonadherence to fasting instructions Low: 9% Adequate: 8% Nonadherence to preoperative medication instructions: Low: 37% Adequate: 21% | No difference between groups in nonadherence to fasting instructions (unadjusted): P = 0.80 No difference between groups in nonadherence to preoperative medication instructions (adjusted): OR, 1.9; 95% CI, 0.8-4.8
Cho et al., 2008^81^ (companion: Lee et al., 2009^160^ Cross-sectional N = 489 Fair | Seniors who are patients at 1 of 2 Chicago, Illinois clinics S-TOFHLA Inadequate/marginal: 51% Adequate: 49% | Race/ethnicity Gender Education | | Nonadherence: failed to fill prescriptions on time (self-report) Inadequate/marginal: NR Adequate: NR | Using path analysis, HL level did not have a significant direct effect on nonadherence (adjusted): β = -0.17, P ≥ 0.05
Fang et al., 2006^106^ Cross-sectional N = 179 Fair | Patients at anticoagulation clinic in San Francisco, California S-TOFHLA Limited: 61% Adequate: 39% | Age Sex Race/ethnicity Education Cognitive impairment Years on warfarin | | Adherence to medication as measured by self-report of missed doses over 3 time periods (last 3 days, last 2 weeks, > 3 months) No missed doses > past 3 months: Limited: 61% Adequate: 51% | No difference in adherence between groups by any of the measures of missed doses (adjusted) Did not miss a dose in > 3 months (adjusted): OR, 0.9; 95% CI, 0.4-2.0
Gatti et al, 2008^73^ (companion Johnson et al., 2010^74^) Cross-sectional N = 275 Fair | Adults who used 3 pharmacies in hospitals in Atlanta REALM Inadequate/Marginal: 60% Adequate: 40% | Negative beliefs about medications Age Low self-efficacy Self-report of hyperlipidemia | | Self-reported low medication adherence - measured by Morisky 8-item Medication Adherence Scale (MMAS-8>2) REALM mean: low adherence group: 52.4 (16.8) high adherence group: 50.1 (17.4) | No difference in medication adherence (adjusted): OR, 0.96; 95% CI, 0.6-1.7
Gazmararian et al., 2006^61^ (companions: Wolf et al., 2007;64 Baker et al., 2007;65 Howard et al., 2006;63 Wolf et al., 2005;66 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Prospective cohort N = 1,549 Fair | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Inadequate: 24% Marginal: 12% Adequate: 64% | Age Race Gender Education Regimen complexity | | Nonadherence to cardiovascular medication refill adherence (1-year period) Low: 45% Marginal: 42% Adequate: 38% | Nonadherence: No difference between low and adequate groups (adjusted): OR, 1.23; 95% CI, 0.92-1.64 No difference between marginal and adequate groups (adjusted): OR, 1.15; 95% CI, 0.82-1.62
Hironaka et al., 2009^108^ Prospective cohort N = 110 Fair | Caregivers of infants who receive care at 2 pediatric clinics S-TOFHLA Inadequate/Marginal: 18% Adequate: 82% | Race/ethnicity Caregiver education Caregiver concerns regarding multivitamins and possible side effects Randomized assignment to drops or sprinkle formulation | | Caregivers' self-reported days of adherence to giving vitamins to their infants in prior week Inadequate/Marginal: 3.7 days Adequate: 2.4 days | Adherence positively related to being in the inadequate/marginal group compared to the adequate group (adjusted): OR, 2.4; 95% CI, 1.37-4.2
Johnson, 2010^74^ (companion: Gatti et al., 2008^73^) Cross-sectional N = 275 Fair | Adults who used 3 pharmacies in hospitals in Atlanta REALM Inadequate/Marginal: 60% Adequate: 40% | Potential moderator: social support Age Sex | | Self-reported medication adherence - measured by Morisky 8-item Medication Adherence Scale (MMAS-8): NR | No difference in adherence by HL level: β = 0.072; 95% CI, -0.350-0.494 After adjusting for interaction between HL and social support (moderator): lower HL related to better adherence at lower levels of social support, higher HL better adherence at higher levels of social support HL: β = -1.827; 95% CI, -3.389-0.265 HL × social support: β, 0.086; 95% CI, 0.018- 0.154

CD4=cluster of differentiation 4; CI=confidence interval; HIV=Human immunodeficiency virus; HL=health literacy; HR=hazard ratio; N=number; NR=not reported; OR=odds ratio; REALM=Rapid estimate of adult literacy in medicine; S-TOFHLA=Short Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; VA=veterans administration.

Table 17 Summary of studies of the relationship between health literacy and self-efficacy (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Results Between Health Literacy Levels
Murphy, 2010^82^ Cross-sectional N= 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit TOFHLA-modified Inadequate: 12% Marginal: 3% Adequate: 86% | Age Education | Outcomes by HL level: NR | No difference by HL in self-efficacy in taking HIV medication regimen score (adjusted): OR, 0.99; 95% CI, 0.95-1.03 No difference in self-efficacy in keeping medical appointment (adjusted): OR, 1.01; 95% CI, 0.95-1.06
Peterson et al., 2007^87^ Cross-sectional N = 99 Fair | Patients with public health care coverage at a community health clinic in Nashville, Tennessee REALM Limited: 29% Adequate: 71% | Age Sex Race Insurance status | Mean perception of self-efficacy score FOBT Limited: 3.87 Adequate: 3.93 Colonoscopy: Limited: 3.92 Adequate: 3.99 | No difference between groups in perception of self-efficacy for FOBT (adjusted): P = 0.44 No difference between groups in perception of self-efficacy or colonoscopy: P = 0.52
Torres et al., 2009^113^ Cross-sectional N = 106 Fair | Women patients at a family health center in New York City s-TOFHLA Inadequate: 46% Marginal: 18% Adequate: 36% | None | Self-efficacy for taking hormone therapy Self-efficacy by health literacy level: NR | Self-efficacy positively correlated with HL (unadjusted): r = 0.70; P < 0.01
von Wagner et al., 2009^114^ Cross-sectional N = 96 Fair | Adults in London, England between 50-69 years of age UK-TOFHLA Mean: 92.2 Range: 26-100 | Age Ethnicity Employment Gender Number of computer links open Mean reading time CRC screening knowledge | Self-efficacy for participating in CRC screening Self-efficacy by health literacy level: NR | Higher HL level associated with greater self-efficacy (adjusted): β = 0.061; 95% CI, 0.009-0.113
Wolf et al., 2007^70^ (companions: Osborn et al., 2007;69 Waite et al., 2008^71^ Osborne et al., 2010 72) Cross-sectional N = 204 Fair | Patients at 2 HIV clinics, 1 in Chicago, Illinois and 1 in Shreveport, Louisiana REALM Low: 11% Marginal: 20% Adequate: 69% | Age Insurance coverage Employment status Number of medications in HIV regimen Number of non-HIV prescription medications currently taking Presence of comorbid chronic conditions Treatment for mental health condition past 6 months Treatment alcohol or drug use past 6 months | Perception of self-efficacy to properly take and manage HIV medication Low: 61% Marginal: 20% Adequate: 24% | Higher HIV medication self-efficacy greater in adequate than low group (adjusted): OR, 5.8; 95% CI, 2.0-15.7 No difference HIV medication self-efficacy between adequate and marginal groups (adjusted): OR, 1.6; 95% CI, 0.3-3.2

CI=confidence interval; CRC=colorectal cancer; FOBT=fecal occult blood test; HL=health literacy; HIV=Human immunodeficiency virus; N=number; NR=not reported; OR=odds ratio; REALM=rapid estimate of adult literacy in medicine; TOFHLA=Test of Functional Health Literacy in Adults; S-TOFHLA=Short Test of Functional Health Literacy in Adults; UK-S-TOFHLA=British version of the Test of Functional Health Literacy in Adults.

Table 18 Summary of studies of the relationship between health literacy and health behaviors (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Results Between Health Literacy Levels
von Wagner, 2007^115^ Cross-sectional N = 719 Fair | National sample of British adults Modified TOFHLA Inadequate: 6% Marginal: 6% Adequate: 89% Continuous measure used in analysis | Age Education Gender Ethnicity Income | Don't smoke Inadequate: 29% Marginal: 32% Adequate: 70% Fruit and vegetable intake > 5/day Inadequate: 29% Marginal 39% Adequate: 47% Any exercise in the last week: Inadequate: 22% Marginal: 20% Adequate: 36.6% | Higher HL associated with greater likelihood of not smoking (adjusted): OR, 1.02; 95% CI, 1.003-1.03 Higher HL associated with greater likelihood of eating ≥ 5 fruit/vegetables a day (adjusted): OR, 1.02; 95% CI, 1.003-1.03 HL level not associated with likelihood of having exercised in the last week (adjusted): OR, 1.00; 95% CI, 0.98-1.02
Wolf, 2007^64^ (companions: Gazmararian, 2006;61 Baker et al., 2007;65 Howard et al., 2006;63 Wolf et al., 2005;66 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Cross-sectional N = 2,923 Fair | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Inadequate: 22% Marginal: 11% Adequate: 66% | Age Gender Race/ethnicity Language (English or Spanish) Site Education Annual income Occupation (white or blue collar) | Smoking (never): Inadequate: 47% Marginal: 42% Adequate: 39% Smoking (former) Inadequate: 42% Marginal: 45% Adequate: 49% Smoking (current) Inadequate: 12% Marginal: 13% Adequate: 12% Current alcohol use (none) Inadequate: 75.6% Marginal: 64.2% None: 57.9% Current alcohol use (light to moderate) Inadequate: 23% Marginal: 34% Adequate: 38% Current alcohol use (heavy) Inadequate: 2% Marginal: 2% Adequate: 4% Physical Activity per week (< 1 time) Inadequate: 38% Marginal: 25% Adequate: 22% Physical Activity per week (1-2 times) Inadequate: 15% Marginal: 16% Adequate: 15% Physical Activity per week (3 times) Inadequate: 14% Marginal: 18% Adequate: 15% Physical Activity per week (> 4 times) Inadequate: 33% Marginal: 41% Adequate: 48% Seat belt use (always) Inadequate: 72% Marginal: 78% Adequate: 78% Seat belt use (nearly always, sometimes, or seldom) Inadequate: 28% Marginal: 22% Adequate: 22% | Difference in smoking status (adjusted) No difference between groups in ever vs. never smoking Inadequate vs. adequate: OR, 0.9; 95% CI, 0.7-1.1 Marginal vs. adequate: OR, 0.9; 95% CI, 0.7-1.2 No difference between groups in ever vs. quit smoking Inadequate vs. adequate: OR, 0.9; 95% CI, 0.6-1.3 Marginal vs. adequate: OR, 0.7; 95% CI, 0.5-1.0 Difference in alcohol consumption (adjusted) No difference between groups in light/moderate vs. no alcohol consumption Inadequate vs. adequate: OR, 1.1; 95% CI, 0.5-2.5 Marginal vs. adequate: OR, 1.4; 95% CI, 0.6-3.3 No difference between groups in heavy vs. no alcohol consumption Inadequate vs. adequate: OR, 1.3; 95% CI, 0.6-3.0 Marginal vs. adequate: OR, 1.2; 95% CI, 0.5-2.8 Difference in physical activity (adjusted) No difference between groups in physical activity 1-2 times per week vs. < 1 time Inadequate vs. adequate: OR, 1.0; 95% CI, 0.7-1.4 Marginal vs. adequate: OR, 1.3; 95% CI, 0.9-1.8 No difference between groups in physical activity 3 times per week vs. < 1 time Inadequate vs. adequate: OR, 0.9; 95% CI, 0.7-1.3 Marginal vs. adequate: OR, 1.0; 95% CI, 0.7-1.5 No difference between groups in physical activity greater than 4 times per week vs. less than 1 time Inadequate vs. adequate: OR, 1.3; 95% CI, 0.9-1.7 Marginal vs. adequate: OR, 1.0; 95% CI, 0.7-1.4 No difference between groups in seat belt use (unadjusted): P = 0.13
Baker et al., 2007^65^ (companions: Gazmararian, 2006;61 Wolf et al., 2007;64 Howard et al., 2005;68 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Cohort N = 3,260 Good | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Inadequate: 24% Marginal: 11% Adequate: 64% | None | BMI < 18.5 Inadequate: 8% Marginal: 4% Adequate: 4% BMI 18.5-24.9 Inadequate: 59% Marginal: 60% Adequate: 58% BMI 25.0-29.9 Inadequate: 23% Marginal: 24% Adequate: 26% BMI > 30.0 Inadequate: 10% Marginal: 12% Adequate: 12% | Difference in BMI across groups (unadjusted): P < 0.005
Huizinga et al. 2008^10^ Cross-sectional N = 160 Fair | Patients at primary care clinic at Vanderbilt University REALM < 9th grade: 23% ≥ 9th grade: 77% | None | BMI < 9th: 31.7 (SD 9.9) ≥ 9th: 30.2 (SD 7.8) | No difference between groups in BMI level (unadjusted): P = 0.50
Sudore, 2006^95^ (companion: Sudore et al., 2006^167^) Cross-sectional N = 2,512 Fair | Seniors (70-79 year old) in Pittsburgh, Pennsylvania and Memphis, Tennessee REALM 0-6th grade: 8% 7-8th grade: 15% >9th grade: 76% | None | Obesity (BMI > 30) 0-6th grade: 29% 7th-8th grade: 32% > 9th grade: 23% | Difference in probability of obesity across groups (unadjusted): OR, 1.51; 95% CI, 1.23-1.85
Rothman, 2006^9^ Cross-sectional N = 200 Fair | Adults in a primary care clinic REALM < HS: 23% > HS: 77% | None | Obese (BMI ≥ 30): < HS: 53% > HS: 43% | No difference between groups in percent obese (unadjusted): P = 0.31
Sharif and Blank, 2010^119^ Cross-sectional N = 78 Good | Children ages 6-19 BMI ≥ 85th percentile for age and sex who received primary care at in an inner city academic community health center in the Bronx, NY S-TOFHLA Child Adequate: 52% Parent Adequate: 77% | Age Parental BMI Child Eating self-efficacy Parental eating self-efficacy Parental S-TOFHLA | Child BMI No data reported by HL | Higher HL significantly related to decrease in child BMI: B, -0.016; 95% CI, -0.025, -0.008
Cho et al., 2008^81^ (companion: Lee et al., 2009^160^) Cross-sectional N = 489 Fair | Seniors who are patients at 1 of 2 Chicago, Illinois clinics s-TOFHLA Inadequate/marginal: 51% adequate: 49% | Race/ethnicity Gender Education | Health Promoting Lifestyle Profile relating to exercise, nutrition, and health responsibility Data: NR | Using path analysis, HL level did not have a direct effect on health behavior (adjusted): P ≥ 0.05
Wolf et al., 2006^120^ Cross-sectional N = 251 Fair | Adults at a primary care clinic in Shreveport, Louisiana REALM Low: 30% Marginal: 31% Adequate: 40% | Age Gender Race Education Number of prescriptions taken | Read/looked at medication guides and consumer information included with prescription medications Low: 17% Marginal: 22% Adequate: 33% | Low HL group more likely than adequate group to not read/look at medication guides: OR, 2.5; 95% CI, 1.2-5.2 No difference between marginal and adequate groups in likelihood of reading/looking at medication guides: P = NS, data NR
Paasche-Orlow, 2005^121^ Cross-sectional N = 423 Fair | Female inmates in Rhode Island adult correctional institute REALM ≤ 6th grade: 10% 7th-8th grade: 19% ≥ 9th grade: 71% | Age Race Problem drinking | HIV Risk Behavior in past 3 months (self-report of sex without a condom or shared injection drug equipment) ≤ 6th grade: 9% 7th-8th grade: 19% ≥ 9th grade: 72% | No difference between groups in HIV risk behaviors (adjusted) ≤ 6th grade vs. ≥ 9th grade: OR, 2.02; 95% CI, 0.83-4.92 ≤ 6th grade vs. 7th-8th grade: OR, 1.89; 95% CI, 0.74-4.81
Marteleto, 2008^122^ Longitudinal N = 4,751 (wave 1) Fair | 14-22 years old at time of Wave 1 in Cape Town, South Africa Cape Area Panel Study Literacy evaluation scores: NR | Grades completed in 2002 Enrolled in 2002 Age Age squared Race Income Household shock Mother's education Father's education Living with mother Living with father | Sexual debut: NR First pregnancy: NR | An increase in literacy of one standard deviation associated with a 7.5% reduction in probability of sexual debut (adjusted): P < 0.05 Literacy level not related to first pregnancy in either females or males (adjusted) Probit coefficient Females: 0.41 Males: -0.030
Murphy et al., 2010^82^ Cross-sectional N= 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit TOFHLA-modified Inadequate: 12% Marginal: 3% Adequate: 86% | Age Education | Drug and alcohol use over past 3 months No data by HL | Higher HL positively associated with substance use (adjusted): P = 0.0181

BMI=Body Mass Index; CI=confidence interval; HL=health literacy; HIV=Human immunodeficiency virus; INR=International Normalized Ratio; N=number; NR=not reported; OH=Ohio; OR=odds ratio; REALM=rapid estimate of adult literacy in medicine; RR=risk ratio; S-TOFHLA=Short Test of Functional Health Literacy in Adults; TOFHLA=Test of Functional Health Literacy in Adults; TX=Texas.

Table 19 Summary of studies of the relationship between health literacy and the outcome of health care related skills (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Results By Health Literacy Level | Differences in Results Between Health Literacy Levels
Kripalani et al., 2006^123^ Cross-sectional N = 152 Good | Clinic population with coronary heart disease in Atlanta, GA REALM Inadequate: 52% Marginal: 29% Adequate: 20% | Age Education Cognitive functioning | DRUGS: Requiring observed completion of 4 tasks:; 1. Identify appropriate medication; 2. Open container; 3. Select correct dose; 4. Report appropriate timing of doses.; Mean score: Inadequate: 92.1 Marginal: 96.3 Adequate: 97.7 | Difference across groups in overall DRUGS score (unadjusted): P = 0.001 Inadequate more likely than adequate to not be able to identify all medications (adjusted): OR, 12.00; 95% CI, 2.57-56.08 No difference between marginal and adequate in ability to identify all medications (adjusted): OR, 4.75; 95% CI, 0.95-23.75
Raehl et al., 2006^124^ Cross-sectional N = 57 Fair | Seniors in Amarillo, Texas REALM mean: 55.4 | Age Number of over-the-counter drugs Owned a car in last 10 years Received food assistance in last 10 years | MedTake Test: ability to open and take own medications while observed by pharmacist MedTake Test outcomes: NR | A higher MedTake Test score was associated with a higher REALM score (adjusted): P < 0.01
Yin et al., 2007^125^ Cross-sectional N = 292 Fair | Parents/caregivers of children at an Emergency Department in New York City TOFHLA Inadequate: 10% Marginal: 16% Adequate: 74% | Experience of ever receiving a dosing instrument in a health care setting Child's age Child has regular health care provider Confounders with health literacy: Caregiver's education, country of origin, language, socio-economic status | Self-reported use of nonstandardized dosing instrument Inadequate/Marginal: 35% Adequate: 19% | No difference in use of dosing instrument between health literacy groups (adjusted for all control variables): OR, 1.5; 95% CI, 0.8-2.8 Marginal/inadequate greater use than adequate (adjusted for control variables except for confounders with HL): OR, 1.9; 95% CI, 1.0-3.5
Estrada et al., 2004^126^ Prospective cohort N = 143 Fair | Adults greater than 50 years old on warfarin ≥ 1 month in 2 anticoagulation management units REALM ≤ 3rd: 11% 4th-6th: 15% 7th-8th: 26% >8th: 48% | Age | Warfarin control measured through INR variability: NR Optimal intensity of anticoagulation (time in range): NR | No difference by HL level in INR variability (adjusted): P = 0.06 No difference by HL time INR in therapeutic range (adjusted): P = 0.71
Davis et al., 2006^75^ (Analysis 1) Wolf et al., 2007^76^ (Analysis 2) Cross-sectional N = 395 Fair | Adults in primary care clinics in Shreveport, LA; Jackson, MI; and Chicago, IL REALM Inadequate: 19% Marginal: 29% Adequate: 52% | Analysis 1 Age Sex Race Education Number of medications currently taken daily Site Analysis 2 None | Misunderstood one or more prescription label instructions: Inadequate: 63% Marginal: 51% Adequate: 38% Correct demonstration of number of pills: Inadequate: 35% Marginal: 63% Adequate: 80% | Analysis 1 Greater misunderstanding in inadequate compared to adequate group (adjusted): RR, 2.32; 95% CI, 1.26-4.28 Greater misunderstanding in marginal compared to adequate group (adjusted): RR, 1.94; 95% CI, 1.14-3.2 Greater demonstration of pills in adequate compared to inadequate group (adjusted): RR, 3.02; 95% CI, 1.70-4.89 No difference between marginal and adequate groups in demonstration of pills: RR = NS, data NR Analysis 2 Difference across literacy groups in correctly interpreting primary label (unadjusted) Amoxicillin: P < 0.001 Trimethoprim: P < 0.001 Guaifenesin: P < 0.001 Felodipine: P = 0.03 Furosemide: P = 0.09 Difference across literacy groups in correctly attending to auxiliary label (unadjusted) Amoxicillin: P = 0.13 Trimethoprim: P = 0.14 Guaifenesin: P < 0.001 Felodipine: P = 0.11 Furosemide: P = 0.01
Rothman et al., 2006^9^ Cross-sectional N = 200 Fair | Adults in primary care clinic REALM < HS: 23% > HS: 77% | Age Gender Race/ethnicity Income Education Insurance status Presence of chronic disease Status of being on a specific diet Label reading frequency | Understanding nutrition labels measured through Nutrition Label Survey Nutritional Label Survey score mean (SD): < HS: 51 (16) > HS: 75 (19) | Greater understanding of nutrition labels in higher HL group (adjusted): P < 0.001
Bailey et al, 2009^77^ (Companions: Davis et al., 2006^75^, Wolf et al., 2007^76^) Cross-sectional N = 373 Fair | Adults in Shreveport, La; Chicago, IL, and Jackson, Michigan REALM: Low: ≤ 6th grade: 20% Marginal: 7th-8th grade: 29% Adequate: ≥ 9th grade: 51% | Race Age Sex Education | Misinterpretation of medication label instructions: Low: 43% Marginal: 34% Adequate: 18% | In comparison to group with adequate HL (adjusted): Greater probability of marginal group misinterpreting medication instructions: AOR, 2.20; 95% CI, 1.19-3.97 Greater probability of low group misinterpreting medication instructions: AOR, 2.90; 95% CI, 1.41-6.00
Yin et al, 2010^127^ Cross-sectional N = 302 Good | English- and Spanish-speaking parents whose child received care at public pediatric clinic in NY Newest Vital Sign High likelihood of limited literacy: 40% Possible limited literacy: 38% Adequate literacy: 22% | Parent's age Relationship to child Marital status Language Ethnicity US birth SES Presence of a child in the house <8 years old Presence of child in the household with a chronic medical problem | Accuracy in measuring a dose of medicine using 6 different dosing instruments: NR | In comparison to group with adequate HL, the odds of making any dosing error (>20% deviation) was greater in those with a high likelihood of limited HL: AOR, 1.7; 95% CI, 1.1-2.8 and in those with possible limited HL: AOR, 1.6; 95% CI, 1.02-2.6 In comparison to group with adequate HL, odds of making a large dosing error (>40% deviation) was greater in those with a high likelihood of limited HL: AOR, 2.3; 95% CI, 1.2-4.6 but no difference in those with possible limited HL: AOR, 1.9; 95% CI, 0.95-3.7
LeVine et al., 2004^128^ Cross-sectional N = 167 Fair | Mothers of kindergarten age children in urban and rural Nepal Literacy measured as continuous, composite score of reading comprehension and noun definition (in Nepalese) Levels NR | Maternal schooling Childhood socioeconomic status Age Current socioeconomic status Husband's schooling Urban/rural | Comprehension of radio health messages: NR Comprehension of visual print health message: NR Ability to give an organized health-related narrative: NR | Higher literacy level associated with greater probability of giving an organized health narrative (adjusted): P < 0.05
Paasche-Orlow et al., 2005^79^ Cross-sectional N = 73 Fair | Inpatient adults hospitalized for severe asthma at 2 inner city hospitals s-TOFHLA Inadequate: 22% Adequate: 78% | Age Sex Ethnicity Education Income History of near fatal asthma Asthma hospitalization in prior 12 months Having a physician for asthma care Prior emergency department visit for asthma last 12 months (subset of confounders used in final model specification NR) | Mastery of metered dose inhaler technique Inadequate: 32% Adequate: 63% | Poorer probability of mastery of metered dose inhaler in inadequate than adequate group (adjusted): OR, 0.29; 95% CI, 0.08-1.00; P = 0.03
Waldrop-Valverde et al, 2009^47^ Cross-sectional N = 155 Fair | Adults with HIV in HIV clinics or AIDS drug assistance programs in Miami, FL TOFHLA (% correct) Men: 78% Women: 73% | Gender Education Time since HIV diagnosis Numeracy | Medication Management Test (MMT), a mock trial of medication-taking skills (interpretation of medication labels and a medication insert, counting a week's supply of medication and placing them in an organizer, and determining missed doses and refills) HL data NR | Higher HL related to better MMT score (adjusted): P < 0.05

AIDS=acquired immune deficiency syndrome; AOR=adjusted odds ratio; BMI=Body Mass Index; CI=confidence interval; DRUGS=Drug Regimen Unassisted Grading Scale; FL=Florida; GA=Georgia; HIV=Human immunodeficiency virus; HL=health literacy; HS=high school; IL=Illinois; INR=International Normalized Ratio; LA=Louisiana; MI=Michigan; N=number; NR=not reported; NY=New York; OR=odds ratio; REALM=rapid estimate of adult literacy in medicine; RR=risk ratio; SD=standard deviation; S-TOFHLA=Short Test of Functional Health Literacy in Adults; SES=socio-economic status; TOFHLA=Test of Functional Health Literacy in Adults; US=United States.

Table 20 Summary of studies of the relationship between health literacy and the outcome of prevalence of depression and other mental health outcomes (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Lincoln et al., 2006^130^ Prospective cohort N = 390 Fair | Adults in an inner-city short-term inpatient detoxification unit REALM Low: 46% Higher: 54% | Time Sex Age Race Education Income Primary language Primary substance of choice Randomization group Mini-mental status exam Baseline outcomes variable | Baseline CES-D: mean (SD) Low: 30.9 (11.3) Higher: 34.8 (13.32) ASI-Alc Low: 0.46 (0.34) High: 0.48 (0.34) ASI-Drug Low: 0.26 (0.13) High: 0.26 (0.15) | Depressive symptomatology No difference between groups (adjusted cross-sectional analysis): P = 0.09 Lower group greater (adjusted longitudinal analysis): P < 0.01 Alcohol addiction severity No difference between groups (adjusted cross-sectional analysis): P = 0.88 No difference between groups (adjusted longitudinal analysis): P = 0.86 Drug addiction severity No difference between groups (adjusted cross-sectional analysis: P = 0.11 No difference between groups (adjusted longitudinal analysis): P = 0.35
Nokes et al., 2007^131^ Cross-sectional N = 489 Fair | HIV positive adults receiving care in San Francisco, Fresno, Richmond, NYC, Corpus Christi REALM Mean = 59.1 (SD, 12.9) | Hispanic | Depressive symptomatology: NR Distress over body changes: NR | Depressive symptomatology worse in higher health literacy group (adjusted): P < 0.05 Distress over body changes greater in higher health literacy group (adjusted): β= 2.91, P < 0.05
Bennett et al., 2007^132^ Cross-sectional N = 99 Fair | Pregnant patients Receiving prenatal care in clinics in Philadelphia S-TOFHLA-Spanish Inadequate: 18% Marginal: 15% Adequate: 67% | Mexican nativity Recent marijuana use | Elevated depressive symptomatology (CES-D ≥ 16) Inadequate HL: 44% Marginal HL: 33% Adequate HL: 18% | Inadequate group more likely than adequate group to have depressive symptomatology (adjusted): PR, 2.39; 95% CI, 1.07-5.35 No difference in depressive symptomatology between marginal and adequate groups (adjusted): PR, 1.73; 95% CI, 0.75-4.02
Kalichman et al., 2008^103^ Cross-sectional N = 145 Fair | HIV positive adults in Atlanta, GA TOFHLA Lower: 49% Higher: 51% | None | Depression: Mean (SD) Lower: 10.9 (6.6) Higher: 8.7 (7.8) | No difference between groups in rate of depression (unadjusted): OR, 0.95; 95% CI, 0.91-1.00
Walker et al., 2007^133^ Cross-sectional N = 363 Fair | Patients at 3 rheumatology clinics in the United Kingdom REALM Lower (< 60): 15% Adequate (≥ 60): 85% | None | Hospital Anxiety and Depression scales (HAQ and HAD) Depression, mean Lower:8.1 Adequate: 6.5 Anxiety, mean Lower: 9.4 Adequate: 7.7 | Anxiety higher in lower group (unadjusted): P = 0.03 Depression higher in lower group (unadjusted): P = 0.01
Morris et al., 2006^134^ Cross-sectional N = 1,002 Good | Adults with diabetes in primary care practices in Vermont S-TOFHLA Inadequate: 10% Marginal: 7% Adequate: 83% | None | Depression, Patient Health Questionnaire (PHQ) > 5 Inadequate: 40% Marginal: 54% Adequate: 31% Depression, median Patient Health Questionnaire Score Inadequate: 3 Marginal: 5 Adequate: 2 | Difference across groups in depression (PHQ > 5) (unadjusted): P = 0.03 Difference across groups in median depression score (unadjusted): P = 0.04
Sudore et al., 2006^95^ (companion: Sudore et al., 2006167) Cross-sectional N = 2,512 Fair | Seniors (70-79 year old) in Pittsburgh, Pennsylvania and Memphis, Tennessee REALM 0-6th grade: 8% 7-8th grade: 15% >9th grade: 76% | None | Depression 0-6th grade: 6% 7th-8th grade: 3% > 9th grade: 2% | Difference in probability of depression across groups (unadjusted): OR, 2.54; 95% CI; 1.47-4.42
Howard et al., 2005^68^ (companion: Gazmararian, 2006^61^; Wolf et al., 2007^64^; Howard et al., 2006^63^; Wolf et al., 2005^66^; Baker et al., 2008^67^; Baker et al., 2004^62^) Cohort N = 3,260 Good | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Adequate: 64% Marginal: 11% Inadequate: 24% | None | Depression Inadequate: 19% Marginal: 14% Adequate: 12% | Difference between groups in rate of depression (unadjusted): P < 0.0001
Coffman, 2010^135^ Cross-sectional N=99 Fair | Spanish speaking adults who are recent immigrants recruited from two Latino service agencies SAHLSA Low HL: ≤ 39 Adequate HL: >39 | Demands of immigration | CES-D (mean score) Low HL: 13.9 (9.5) High HL: 9.7 (8.3) | Lower HL related to higher depression scores (adjusted): P = 0.048
Murphy, 2010^82^ Cross-sectional N= 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit TOFHLA-modified Inadequate: 12% Marginal: 3% Adequate: 86% | Age Education | Psychological distress as measured by BSI Global Severity Index No data reported by HL | No difference in BSI Global Severity Index by HL level (adjusted): P = 0531

ASI-Alc=Addiction Severity Index - Alcohol; ASI-Drug=Addiction Severity Index - Drugs; BSI=Brief Symptom Index; CES-D=Center for Epidemiology Studies – Depression Scale; COPD=chronic obstructive pulmonary disease; HIV=human immunodeficiency virus; N=number; NALS=national adult literacy survey; NR=not reported; NYC=New York City; OH=Ohio; OR=odds ratio; PHQ=Patient Health Questionnaire; PR=Poisson Regression coefficient; REALM=Rapid Estimate of Adult Literacy in Medicine; SAHSLA=Short Assessment of Health Literacy for Spanish-speaking Adults; S-TOFHLA=Short Test of Functional Health Literacy in Adults, TX=Texas.

Table 21 Summary of studies of the relationship between health literacy and the outcome of prevalence of chronic diseases (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Sentell and Halpin, 2006^141^ Cross-sectional N = 23,889 Fair | National sample of adults Total NALS score Level 1: 20% Level 2: 27% Level 3: 34% Level 4: 18% Level 5: 2% | Race Education Understand English Born in US Unemployed Family income Income missing Sex Age Married Get food stamps Live in Metropolitan Statistical Area Region | Self-report of physical, mental, or other health condition that keeps respondent from working: NR Long-term illness (> 6 months): NR | Lower health literacy associated with greater odds of having a condition that keeps respondent from working (adjusted): OR, 1.11; 95% CI, 1.08-1.14 Lower health literacy associated with greater odds of having a long-term illness (adjusted): OR, 1.04; 95% CI, 1.02-1.04
Baker et al., 2007^65^ (companion: Gazmararian, 2006;61 Wolf et al., 2007;64 Howard et al., 2006;63 Wolf et al., 2005;66 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Prospective cohort N = 3,260 Good | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Inadequate: 24% Marginal: 11% Adequate: 64% | None | Number of chronic conditions Inadequate: mean 1.7 (SD=1.2) Marginal: mean = 1.7 (SD=1.2) Adequate: mean = 1.5 (SD=1.2) | No difference between the groups in number of chronic conditions (unadjusted): P = 0.87
Rothman et al., 2006^9^ Cross-sectional N = 200 Fair | Adults in a primary care clinic REALM < HS: 23% > HS: 77% | None | Chronic illness (hypertension, coronary artery disease, high cholesterol, diabetes, or heart failure) < HS: 52% > HS: 38% | No difference between groups in percent with chronic illness (unadjusted): P = 0.08
Wolf et al., 2005^66^ (companion: Gazmararian, 2006;61 Wolf et al., 2007;64 Baker et al., 200;7^65^ Howard et al., 2006;63 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Cross-sectional N = 2,923 Fair | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Adequate: 67% Marginal: 11% Inadequate: 22% | Age Sex Race/ethnicity Income Education Tobacco Alcohol consumption Self-reported comorbid conditions | Hypertension Inadequate:50% Marginal: 46% Adequate: 43% Diabetes Inadequate: 19% Marginal: 15% Adequate: 13% Coronary artery disease Inadequate: 6% Marginal: 7% Adequate: 8% Heart failure Inadequate: 6% Marginal: 4% Adequate: 4% Bronchitis or emphysema Inadequate: 10% Marginal: 10% Adequate: 14% Asthma Inadequate: 7% Marginal: 8% Adequate: 7% Arthritis Inadequate: 57% Marginal: 57% Adequate: 50% Cancer Inadequate: 4% Marginal: 7% Adequate: 6% | Self-reported prevalence of chronic disease (adjusted) No difference in rates of hypertension between inadequate and adequate groups: OR, 1.20; 95% CI, 0.95-1.50 No difference in probability of hypertension between marginal and adequate groups: OR, 1.03; 95% CI, 0.80-1.34 Inadequate group had a significantly higher rate of diabetes than adequate group: OR, 1.48; 95% CI, 1.09-2.02 No difference in probability of diabetes between marginal and adequate groups: OR, 1.10; 95% CI, 0.75-1.59 No difference in coronary artery disease between inadequate and adequate groups: OR, 0.93; 95% CI, 0.59-1.47 No difference in coronary artery disease between marginal and adequate groups: OR, 0.85; 95% CI, 0.51-1.43 Inadequate group has a higher probability of heart failure than adequate group: OR, 1.69; 95% CI, 1.02-2.80 No difference in heart failure between marginal and adequate groups: OR, 0.97; 95% CI, 0.49-1.90 No difference in bronchitis or emphysema between inadequate and adequate groups: OR, 0.75; 95% CI 0.53-1.08 No difference in bronchitis or emphysema between marginal and adequate groups: OR, 0.81; 95% CI, 0.53-1.22 No difference in asthma between inadequate and adequate groups: OR, 0.96; 95% CI, 0.62-1.37 No difference in asthma between marginal and adequate groups: OR, 1.26; 95% CI, 0.79-2.01 No difference in arthritis between inadequate and adequate groups: OR, 0.98 95% CI, 0.78-1.23 No difference in arthritis between marginal and adequate groups: OR, 1.11; 95% CI, 0.85-1.44 No difference in cancer between inadequate and adequate groups: OR, 0.91; 95% CI, 0.54-1.52 No difference in cancer between marginal and adequate groups: OR, 1.38; 95% CI, 0.84-2.27
Howard et al., 2005^68^ (companion: Gazmararian, 2006;61 Wolf et al., 2007^64^ Baker et al., 2007;65 Howard et al., 2006;63 Wolf et al., 2005;66 Baker et al., 2008;67 Baker et al., 2004^62^) Cohort N = 3,260 Good | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Adequate: 64% Marginal: 11% Inadequate: 24% | None | Heart Attack Inadequate: 15% Marginal: 18% Adequate: 13% Angina Inadequate: 8% Marginal: 12% Adequate: 8% Stroke Inadequate: 13% Marginal: 9% Adequate: 7% COPD Inadequate: 14% Marginal: 16% Adequate: 18% | Difference between groups in heart attack rate (unadjusted): P = 0.01 No differences between groups in rate of angina (unadjusted): P = 0.06 Difference between groups in rate of stroke (unadjusted): P < 0.0001 No differences between groups in rate of COPD (unadjusted): P = 0.06
Sudore et al., 2006^95^ (companion: Sudore et al., 2006^167^) Cross-sectional N = 2,512 Fair | Seniors (70-79 year old) in Pittsburgh, Pennsylvania and Memphis, Tennessee REALM 0-6th grade: 8% 7-8th grade: 15% > 9th grade: 76% | None | Hypertension 0-6th grade: 62% 7th-8th grade: 63% > 9th grade: 55% Diabetes 0-6th grade: 25% 7th-8th grade: 26% >9th grade: 15% | Difference in probability of hypertension across groups (unadjusted): OR, 1.39; 95% CI, 1.25-1.68 Difference in probability of diabetes across groups (unadjusted): OR, 1.98; 95% CI, 1.58-2.48
Laramee et al., 2007^143^ Cross-sectional N = 998 Fair | Adults with diabetes in primary care practices in Vermont, New Hampshire, and northern New York State S-TOFHLA Limited: 17% Adequate: 83% | None | Heart failure Limited: 27% Adequate: 15% | Limited group higher rate of heart failure (unadjusted): OR, 2.05; 95% CI, 1.39-3.02
Kim, 2009^142^ Cross-sectional N= 103 Fair | Korean older adults (> 60 years) Korean Functional Health Literacy test (TOFHLA) High literacy (≥5): 58% Low literacy (<5): 42% | None | Self-report of chronic disease Arthritis Low HL: 51.2% High HL: 21.7% Hypertension Low HL: 44.2% High HL: 21.7% Sensory disease Low HL: 39.5% High HL: 23.3% Diabetes mellitus Low HL: 45.5% High HL: 54.5% Pulmonary disease Low HL: 16.3% High HL: 10.0% Heart disease Low HL: 8.3% High HL: 2.3% | Difference in probability of arthritis between groups (unadjusted): P = 0.003 Difference in probability of hypertension between groups (unadjusted): P = 0.018 Difference in probability of sensory disease between groups (unadjusted): P = 0.086 Difference in probability of diabetes mellitus between groups (unadjusted): P = 0.808 Difference in probability of pulmonary disease between groups (unadjusted): P = 0.380 Difference in probability of heart disease between groups (unadjusted): P = 0.397

ASI-Alc=Addiction Severity Index - Alcohol; ASI-Drug=Addiction Severity Index - Drugs; CES-D=Center for Epidemiology Studies – Depression Scale; CI=confidence interval; COPD=Chronic Obstructive Pulmonary Disease; HS=high school; N=number; NALS=National Adult Literacy Survey; NR=not reported; OH=Ohio; PR=Poisson Regression coefficient; REALM=Rapid Estimate of Adult Literacy in Medicine; S-TOFHLA=Short Test of Functional Health Literacy in Adults; SD=standard deviation; TOFHLA=Test of Functional Health Literacy in Adults; TX=Texas; US=United States.

Table 22 Summary of studies of the relationship between health literacy and HIV patient symptoms (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Paasche-Orlow et al., 2006^105^ Retrospective cohort N = 235 Fair | Patients with HIV and a history of alcohol problems in Boston, MA REALM Low: 14% Marginal: 29% Adequate: 57% | Gender Age Education Randomization group Ethnicity Homeless status Drank to intoxication past 30 days Injected drugs past 6 months Complexity of regimen Medication adherence | Viral load suppressed Low: 63% Marginal: 58% Adequate: 61% | Viral load (HIV-RNA) suppression No difference between low and adequate groups (adjusted): OR, 1.70; 95% CI, 0.79-3.65 No difference between marginal and adequate groups (adjusted): OR, 1.29; 95% CI, 0.77-2.18
Mayben et al., 2007^145^ Cross-sectional N = 119 Fair | Adults with HIV receiving care at 4 publicly funded clinics in Houston, TX TOFHLA Inadequate: 28% Adequate: 72% | Gender Reason for getting tested Marijuana use | CD4 cell count: median (interquartile range) Inadequate: 175 (69, 272) Adequate: 247(31, 517) | No difference in CD4 cell count between adequate and inadequate groups (adjusted): P = 0.35
Nokes et al., 2007^131^ Cross-sectional N = 489 Fair | HIV-positive adults receiving care in San Francisco, Fresno, Richmond, NYC, Corpus Christi REALM Mean = 59.1 (SD, 12.9) | Hispanic | HIV-symptom intensity: NR | HIV-symptom intensity greater in higher health literacy group (adjusted): β, 8.62; P < 0.05
Kalichman et al., 2008^103^ Cross-sectional N = 145 Fair | HIV-positive adults in Atlanta, GA TOFHLA Lower: 49% Higher: 51% | None | HIV symptoms: Mean (SD) Lower: 4.0 (3.2) Higher: 4.7 (3.9) | No difference between groups in number of HIV symptoms (unadjusted): OR, 1.05; 95% CI, 0.95-1.14
Murphy, 2010^82^ Cross-sectional N= 186 Fair | HIV-positive individuals ages 16-24 in Fort Lauderdale, Philadelphia, Baltimore, Los Angeles, and Detroit TOFHLA-modified Inadequate: 12% Marginal: 3% Adequate: 86% | Age Education | Viral load (plasma HIV-1 RNA): Mean (SD) Marginal/Inadequate: 3.82 (1.08) Adequate: 3.69 (1.19) CD4 measures Data NR | No relationship between viral load and HL (adjusted): P = 0.13 No relationship between CD4 count and HL (adjusted): P = 0.15

CD4=Classification of Disease, Version 4; CES-D=Center for Epidemiology Studies – Depression Scale; CI=confidence interval; COPD=Chronic Obstructive Pulmonary Disease; GA=Georgia; HIV=human immunodeficiency virus; N=number; NR=not reported; NYC=New York City; OR=odds ratio; PR=Poisson Regression coefficient; REALM=Rapid Estimate of Adult Literacy in Medicine; RNA=Ribonucleic Acid; S-TOFHLA=Short Test of Functional Health Literacy in Adults; SD=standard deviation; TOFHLA=Test of Functional Health Literacy in Adults; TX=Texas.

Table 23 Summary of studies of the relationship between health literacy and asthma patient symptoms (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Shone et al., 2009^84^ Cross-sectional N = 499 Fair | Parents of children with persistent asthma in Rochester New York School District REALM Low: 33% Adequate: 67% | Child health insurance Parent's employment, ethnicity, and race | Asthma is not under good control Low: 76% Adequate: 82% Child's health is fair/poor Low: 39% Adequate: 17% | No difference between groups in rate of asthma not under good control (unadjusted): P = 0.094 Parents' in low group more likely to have child with fair/poor health (adjusted): OR, 3.96; 95% CI, 2.4-6.4
DeWalt et al., 2007^80^ Cross-sectional N = 150 Fair | Parents of children with asthma receiving care at 3 clinics in North Carolina REALM Lower: 24% Higher: 76% | None | Albuterol Use (mean days per week) Lower: 2.7 Higher: 1.5 Albuterol Use (total mean use per week) Lower: 6 doses Higher: 3 doses Appropriate Controller Use Lower: 68% Higher: 82% | Greater Albuterol use in children of parents in lower compared to higher health literacy group (unadjusted): P = 0.01 Greater total weekly Albuterol use in children of parents in lower compared to higher health literacy group (unadjusted): P = 0.03 No difference between groups in appropriate controller use (unadjusted): P = 0.15

CI=confidence interval; N=number; OR=odds ratio; REALM=Rapid Estimate of Adult Literacy in Medicine.

Table 24 Summary of studies of the relationship between health literacy and diabetes control (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Morris et al., 2006^134^ Cross-sectional N = 1,002 Good | Adults with diabetes in primary care practices in Vermont S-TOFHLA Inadequate: 10% Marginal: 7% Adequate: 83% | Age Sex Race Marital status Insurance Income Duration of diabetes Diabetes education Depression Alcohol use Medication use Physician practice | HbA1c median Inadequate: 6.9% Marginal: 6.8% Adequate: 6.9% SBP median Inadequate:137 Marginal: 144 Adequate: 138 DBP median Inadequate: 76 Marginal: 77 Adequate: 79 LDL-cholesterol median Inadequate: 99 Marginal: 94 Adequate: 99 Retinopathy Inadequate: 30% Marginal: 34% Adequate: 18% Nephropathy Inadequate: 15% Marginal: 0 Adequate: 9% Gastroparesis Inadequate: 9% Marginal: 6% Adequate: 6% Foot/leg problems Inadequate: 30% Marginal: 30% Adequate: 30% Cerebrovascular disease Inadequate: 21% Marginal: 17% Adequate: 10% Coronary artery disease Inadequate: 30% Marginal: 27% Adequate: 17% | No difference in HbA1c levels across groups (adjusted, continuous TOFHLA scores used): P = 0.88 No difference in SBP across groups (adjusted, continuous TOFHLA scores used): P = 0.78 No difference in DBP across groups (adjusted, continuous TOFHLA scores used): P = 0.39 No difference in LDL-cholesterol across groups (adjusted, continuous TOFHLA scores used): P = 0.59 Retinopathy rates No difference between inadequate and adequate group (adjusted): OR, 1.88; 95% CI, 0.90-3.91 No difference between marginal and adequate groups (adjusted): OR, 2.30; 95% CI, 0.63-8.44 Nephropathy No difference between inadequate and adequate groups (adjusted): OR, 1.05; 95% CI, 0.39-2.80 No difference between marginal and adequate groups (adjusted): OR, 0.99; 95% CI, 0.95-1.03 Foot/leg problem rates No difference between inadequate and adequate groups (adjusted): OR, 0.52; 95% CI, 0.24-1.16 No difference between marginal and adequate groups (adjusted): OR, 1.39; 95% CI, 0.47-4.12 Gastroparesis No difference between inadequate and adequate groups (adjusted): OR, 1.92; 95% CI, 0.58-6.36 No difference between marginal and adequate groups (adjusted): OR, 1.98; 95% CI, 0.26-18.07 Cerebrovascular disease No difference between inadequate and adequate groups (adjusted): OR, 0.86; 95% CI, 0.39-1.91 No difference between marginal and adequate groups (adjusted): OR, 0.65; 95% CI, 1.66-2.57 Coronary artery disease No difference between inadequate and adequate groups (adjusted): OR, 0.76; 95% CI, 0.36-1.63 No difference between marginal and adequate groups (adjusted): OR, 1.12; 95% CI, 0.34-3.70
Tang et al., 2007^148^ Cross-sectional survey and medical chart review N = 149 Fair | Adults with diabetes in diabetes education management center of a public hospital in Hong Kong Chinese S-TOFHLA: Levels NR | Gender Insurance Duration of diabetes Patient awareness score C-SDSCA (management of diabetes) | HbA1c levels outcomes: NR | Higher HL associated with lower HbA1c levels (adjusted): P < 0.001
Powell et al., 2007^149^ Cross-sectional N = 68 Fair | Patients with Type 2 diabetes treated in general internal medicine clinic REALM < 4th grade: 13% 4th-6th grade: 25% 7th-8th grade: 19% High school: 43% | Education Age Race Gender Treatment regimen | HbA1c median <4th grade: 8% 4th-6th grade: 8% 7th-8th grade: 10% HS: Median: 7.9% | Difference in HbA1c level between groups (adjusted): P = 0.02
Schillinger et al., 2006^150^ Cross-sectional N = 395 Good | Adult diabetes patients (> 30 years old) treated at one of two primary care clinics at San Francisco General Hospital S-TOFHLA Mean = 20.6 (SD=12.1) | Age Primary language other than English Insurance Education | Log HbA1c: NR | HL mediated the direct relationship between education and HbA1c level in a partial mediation model (adjusted path analysis): P < 0.05 HL mediated the direct relationship between education and HbA1c level in a full mediation model (adjusted path analysis): P = 0.03
Mancuso et al, 2010^151^ Cross-sectional N=102 Good | Adults with a diagnosis of type 1 or 2 diabetes in 2 urban Midwestern US primary care clinics TOFHLA Inadequate: 16% Marginal: 21% Adequate: 63% | Patient trust depression diabetes knowledge performance of self-care activities | HbA1c by HL level: NR | No difference between HL groups in HbA1c (adjusted): P = 0.436

C-SDSCA=Chinese version of Summary of Diabetes Self-Care Activities; CI=confidence interval; DBP=diastolic blood pressure; Hb=hemoglobin; HL=health literacy; LDL=Low-density lipoprotein; N=number; OR=odds ratio; REALM=Rapid Estimate of Adult Literacy in Medicine; S-TOFHLA-Spanish=Short Test of Functional Health Literacy in Adults–Spanish; SBP=systolic blood pressure; TOFHLA=Test of Functional Health Literacy in Adults.

Table 25 Summary of studies of the relationship between health literacy and hypertension control (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Powers et al., 2008^154^ Cross-sectional N = 1,224 Fair | Patients with hypertension receiving primary care in the VA healthcare system and Duke University Healthcare system in Durham, NC. REALM VA Limited: 38% Adequate: 58% Duke Limited: 28% Adequate: 72% | Age Race Marital status Education Adequacy of income Diabetic status Medication Adherence Smoking Exercise Participatory decision-making score | SBP: mean (SD) VA Limited: 138.7 (17.8) Adequate: 138.4 (17.5) Duke Limited: 142 (24.9) Adequate: 133 (17.6) | The relationship between HL and blood pressure level differed in the two healthcare systems (adjusted) (moderator analysis) HL main effect: β = -1.2; 95% CI, -4.8-2.3 Interaction between HL and healthcare system: β = 7.4; 95% CI, 2.5-12.3
Pandit et al., 2009^155^ Cross-sectional N = 330 Fair | Adults with hypertension receiving primary care from clinics in Grand Rapids, Michigan, Chicago, Illinois, and Shreveport, Louisiana | Age Race Gender Marital status Employment status Insurance coverage Site location | Controlled Blood Pressure Category I: 34% Category II: 49% Category III: 45% Category IV: 61% Category V: 46% (highest) | Category V group has greater odds of having controlled BP than Category I group (adjusted): RR, 2.68; 95% CI, 1.54-4.70
Pandit et al., 2009^155^ (continued) | S-TOFHLA Category I: 17% Category II: 11% Category III: 16% Category IV: 26% Category V: 31% | Number of comorbid conditions Years treated for hypertension Clinic site Education | | No difference between Category II and Category V in odds of having controlled BP (adjusted): RR, 1.47; 95% CI, 0.53-4.05 Category V group has greater odds of having controlled BP than Category III group (adjusted): RR, 1.69; 95% CI, 1.08-2.63 No difference between Category IV and Category V in odds of having controlled BP (adjusted): RR, 1.10; 95% CI, 0.40-3.01

BP=blood pressure; CI=confidence interval; PSA=prostate-specific antigen; REALM=Rapid Estimate of Adult Literacy in Medicine; RR=relative risk; S-TOFHLA=Short Test of Functional Health Literacy in Adults; SD=standard deviation; SBP=systolic blood pressure; VA=veterans administration.

Table 26 Summary of studies of the relationship between health literacy and prostate cancer control (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Outcomes Between Health Literacy Levels
Wolf et al., 2006^157^ Cross-sectional N = 308 Good | Patients with newly diagnosed prostate cancer in 4 outpatient oncology and urology clinics in Chicago area REALM Low: 18% Marginal: 33% Functional: 50% | Age Race Annual income Marital status | PSA Level > 20 mg/mL Marginal: 24% Low: 33% Functional: 14% | Low group more likely to have elevated PSA than functional group (adjusted): OR, 2.5; 95% CI, 1.5-4.2 No difference in rates of elevated PSA between marginal and functional groups (adjusted): OR, 1.4; 95% CI, 0.9-2.2

CI=confidence interval; mg/mL=milligram/millileter; OR=odds ratio; PSA=prostate-specific antigen; REALM=Rapid Estimate of Adult Literacy in Medicine.

Table 27 Summary of studies of the relationship between health literacy and health status (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Results Between Health Literacy Levels
Smith and Haggerty, 2003^159^ Cross-sectional N = 229 Fair | Adults in University-affiliated family practice center in Montreal, Canada REALM Low: 6% Adequate: 94% | Age Smoking status Maternal language | Perceived overall health Low: mean = 3.3 Adequate: mean = 3.0 | No difference between groups in perceived general health (adjusted): β = -0.11; 95% CI, -0.25-0.03
Bennett et al., 2009^85^ (companion: White et al., 2008^86^) Cross-sectional N = 2,668 Good | Nationally representative sample of US population, 65 years and older NAAL Below basic: 29.0% Basic: 29.5% Intermediate: 38.2 Proficient: 3.3% | Race Income Gender Age Nativity | Health status levels by health literacy level: NR | Higher health literacy associated with better self-reported health status (adjusted): P < 0.05
Analysis 1 Cho et al., 2008^81^ Cross-sectional N = 489 Fair Analysis 2 Lee, 2009^160^ Cross-sectional N = 489 Fair | Seniors who are patients at 1 of 2 Chicago clinics S-TOFHLA Inadequate/marginal: 51% adequate: 49% | Analysis 1 Race/ethnicity Gender Education Analysis 2 Age Gender Race Education Marital status Income Social support level | Health status (self-report) Levels: NR General health (self-report) Levels: NR Physical health (SF-12) Levels: NR Mental health (SF-12) Levels: NR | Analysis 1 Using path analysis, higher health literacy level related to better health status (adjusted): P < 0.05 Analysis 2 Low health literacy associated with lower level of general health status(adjusted): P < 0.05 No difference between groups in physical health (adjusted): P = NS No difference between groups in mental health (adjusted): P = NS
Analysis 1 Howard, 2006^63^ Prospective cohort N = 3,260 Fair Analysis 2 Baker et al., 2007^65^ (companions: Gazmararian, 2006;61 Wolf et al., 2007;64 Wolf et al., 2005;66 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Prospective cohort N = 3,260 Good | New Prudential Medicare managed-care enrollees in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 25% Marginal: 11% Adequate: 64% | Analysis 1 Age Gender Race/ethnicity Education Income Site Morbidity Smoker Analysis 2 None | Physical HRQoL (SF-12) Inadequate: mean = 41.9 (SD=11.9) Marginal: mean = 43.6 (SD=11.7) Adequate: mean = 46.2 (SD=10.7) Mental HRQoL (SF-12) Inadequate: mean 52.1 (SD=10.7) Marginal: mean = 54.9 (SD=9.2) Adequate: mean 55.5 (SD=7.9) IADL limitation Inadequate: 46% Marginal: 37% Adequate: 24% ADL limitation Inadequate: 9% Marginal: 6% Adequate: 3% | Analysis 1 Inadequate group poorer physical HRQoL than adequate (adjusted): P < 0.001 Marginal group poorer physical HRQoL than adequate (adjusted): P =0.019 Inadequate group poorer mental HRQoL than adequate (adjusted): P < 0.001 No difference in mental HRQoL between marginal and adequate groups (adjusted): P = 0.304 Inadequate group less likely to self-report health status of good or better than adequate groups (adjusted): OR, 0.71; P = 0.004 No differences in self-reported health status of good or better between marginal and adequate groups (adjusted): OR, 0.77; P = 0.060 Analysis 2 Significant difference between 3 HL groups in IADL limitation (unadjusted): P < 0.001 Significant difference between 3 HL groups in ADL limitation (unadjusted): P < 0.001
Sudore et al., 2006^95^ (companion: Sudore, 2006^167^) Cross-sectional N = 2,512 Fair | Seniors (70-79 year old) in Pittsburgh, Pennsylvania and Memphis, Tennessee REALM 0-6th grade: 8% 7-8th grade: 15% ≥9th grade: 76% | None | Self-report poor health 0-6th grade: 33% 7th-8th grade: 28% ≥ 9th grade: 14% | Difference in probability of poor health across groups (unadjusted): OR, 2.60; 95% CI, 2.09-3.23
Wolf et al., 2005^66^ (companion: Gazmararian, 2006;61 Wolf et al., 2007;64 Baker et al., 2007;65 Howard et al., 2005;68 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Cross-sectional N = 2,923 Fair | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Inadequate: 22% Marginal: 11% Adequate: 67% | Age Sex Race/ethnicity Income Education Tobacco Alcohol consumption Self-reported comorbid conditions | Physical function (SF-36) mean (SD) Inadequate: 67.7 (9.7) Marginal: 73.7 (27.5) Adequate: 78.0 (24.6) Mental health functioning (SF-36) mean (SD) Inadequate: 76.2 (20.9) Marginal: 81.8 (18.6) Adequate: 84.0 (16.1) | Inadequate group lower physical function scores than adequate group (adjusted): β, -6; 95% CI, -8.4-3.5 Marginal lower physical function scores than adequate group (adjusted): β, -1.1; 95% CI, -3.9-1.8 Inadequate group lower mental health scores than adequate group (adjusted): β, -4.9; 95% CI, -6.7 to -3.1 Marginal group lower mental health score than adequate group (adjusted including education): β, -0.9; 95% CI, -2.9-1.2 Inadequate group has greater self-reported instrumental activity limitations than adequate group (adjusted including ed): OR, 2.25; 95% CI, 1.74-2.92 Marginal group has greater instrumental activity limitations than adequate group: OR, 1.65; 95% CI, 1.22-2.24 Inadequate group has greater self-reported activity limitations than adequate group (adjusted included): OR, 2.83; 95% CI, 1.62-4.96 Marginal group has greater activity limitations than adequate group (adjusted): OR, 2.05; 95% CI, 1.06-3.97 Inadequate group has greater limitations due to physical health than adequate group (adjusted): OR, 1.79; 95% CI, 1.39-2.32 No differences in limitations because of physical health between adequate and marginal groups (adjusted): OR, 1.35; 95% CI, 1.00-1.84 Inadequate group has fewer accomplishments due to physical health than adequate group (adjusted): OR, 1.90; 95% CI, 1.48-2.45 Marginal has fewer accomplishments than marginal group (adjusted): OR, 1.46; 95% CI, 1.08-1.97 Inadequate group has greater pain interfering with activities than adequate group (adjusted): OR, 2.01; 95% CI, 1.46-2.77 No difference in pain interfering with activities between marginal and adequate groups (adjusted): OR, 1.23; 95% CI, 0.83-1.82
Muir et al., 2008^161^ Cross-sectional N = 110 Fair | Glaucoma patients at a Duke eye clinic in Durham, NC REALM Low: 52% Adequate: 48% | Age Race Visual acuity Visual field Education | VRQoL score (mean) Low: 84 Adequate: 76 Physical HRQoL (SF-12): NR Mental HRQoL (SF-12): NR | No difference between groups in VRQoL (adjusted): P = 0.621 Low HL associated with poorer physical HRQoL (unadjusted): P = 0.002 No difference between groups in mental HRQoL (unadjusted): P = 0.068
Nokes et al., 2007^131^ Cross-sectional N = 489 Fair | HIV-positive adults receiving care in San Francisco, Fresno, Richmond, NYC, Corpus Christi REALM Mean = 59.1 (SD, 12.9) | Hispanic | Global physical health (scale developed by investigators): mean (SD) Lower: 7.21, (2.42) Higher: 6.68, (2.22) | Physical health rated lower in higher group (unadjusted): P = 0.02
Mancuso and Rincon, 2006^100^ Cross-sectional N = 175 Fair | Adults with asthma enrolled in a primary care practice in New York City TOFHLA Adequate: 82% Marginal: 8% Inadequate: 10% | Asthma severity asthma self-efficacy Age Education Depressive symptoms Asthma knowledge | Outcome data by health literacy level: NR | Lower HL related to poorer AQLQ (adjusting for asthma severity, asthma self-efficacy): P = 0.003 Lower HL related to poorer AQLQ (adjusting for asthma severity, asthma self-efficacy, age and education): P = 0.03 No difference in AQLQ by HL level (adjusting for asthma severity, asthma self-efficacy, age, education, depressive symptoms): P = 0.07 No difference in AQLQ by HL level (adjusting for asthma severity, asthma self-efficacy, age, education, depressive symptoms, asthma knowledge): P = 0.38 Lower HL related to poorer Physical HRQoL (SF-36) (adjusting for asthma severity and asthma self-efficacy): P = 0.0003 No difference in physical HRQoL (SF-36) by HL level (adjusting for asthma severity, asthma self-efficacy, age and education): P = 0.11 No difference in physical HRQoL (SF-36) by HL level (adjusting for asthma severity, asthma self-efficacy, age, education and depressive symptoms): P = 0.22 No difference in SF-36 by HL level (adjusting for asthma severity, asthma self-efficacy, age, education, depressive symptoms and asthma knowledge): P = 0.53
Johnston et al., 2005^162^ Cross-sectional N = 107 Fair | Adult patients at spinal cord injury clinic in New Jersey TOFHLA Inadequate: 6% Marginal: 8% Adequate: 86% | Motor index Education | Outcome data by health literacy level: NR | Having less than adequate HL associated with poorer physical morbidity (number of days physical health “not good”) (adjusted): P < = 0.05 No difference between groups in mental health morbidity (number of days mental health “not good”) (adjusted): P = 0.90 No difference between groups in SF-12 Physical Component score (adjusted): P = 0.49 No difference between groups in SF-12 Mental Component score (adjusted): P = 0.07 No difference between groups in physical independence (adjusted): P = 0.47 No difference between groups in mobility (adjusted): P = 0.93
Hahn et al., 2007^163^ Cross-sectional N = 415 Good | Adult cancer patients in 5 Chicago-area cancer centers Passage comprehension subtest of Woodcock Language Proficiency Battery Low: 52% High: 48% | Age Gender Race/ethnicity Work status Marital status Living arrangement Socioeconomic status Prior computer experience Cancer diagnosis Stage at diagnosis Months since diagnosis Current chemotherapy treatment Performance status | FACT-G mean (SD) Physical well-being Low: 17.9 (5.9) High: 18.4 (5.8) Emotional well-being Low: 17.6 (5.2) High:17.5 (4.7) Functional well-being Low: 15.7 (6.5) High: 16.0 (6.3) SF-36 mean (SD) Physical functioning Low: 48.7 (26.7) High: 57.2 (27.5) Role-physical Low: 29.7 (38.2) High: 34.8 (42.4) Bodily pain Low: 55.5 (26.9) High: 56.0 (24.9) General health Low: 49.9 (20.6) High: 53.2 (21.3) Vitality Low: 51.5 (21.4) High: 47.3 (20.5) Mental health Low: 65.5 (19.6) High: 66.9 (20.2) Fair/poor health Low: 53.3% High: 39% Standard Gamble utility score Low: mean = 0.87 (0.20) High: mean = 0.85 (0.23) | No difference between groups on any of the FACT-G scale items (adjusted) No difference between groups on SF-36 including and excluding biased scale items (adjusted) Difference standard Gamble utility score (unadjusted): P = 0.561
Kim, 2009^142^ Cross-sectional N= 103 Fair | Korean older adults (> 60 years) Korean Functional Health Literacy test (TOFHLA) High literacy (≥5): 58% Low literacy (<5): 42% | Age Education Income | Physical function (SF-12) Low HL: 40.34 (10.3) High HL: 46.71 (9.8) Limitations in activity Low HL: 51.11 (8.6) High HL: 44.64 (10.8) Pain that interfered with normal work Low HL: 47.08 (10.6) High HL: 40.37 (12.3) Subjective general health (SF-12) Low HL: 36.97 (11.5) High HL: 44.88 (12.0) Mental health status (SF-12) Low HL: 45.13 (9.82) High HL: 48.88 (6.53) | No difference in physical function by HL level (adjusted): P = 0.06 Limitations in activities worse in low HL group (adjusted): P = 0.025 Pain that interfered with normal work worse in low HL group (adjusted without education): P = 0.044 Subjective general health worse in low HL group (adjusted): P = 0.036 No difference in mental health status by HL level (adjusted): P =0.15

ADL=activities of daily living; AQLQ=Asthma Quality of Life Questionnaire; BMI=body mass index; FACT-G=Functional Assessment of Cancer Therapy-General; HR=hazard ratio; HRQoL=health-related quality of life; IADL=instrumental activities of daily living; N=number; NAAL=National Assessment of Adult Literacy; NALS=National Adult Literacy Survey; NR=not reported; OR=odds ratio; PCS=Physical Component Summary; REALM=Rapid Estimate of Adult Literacy in Medicine; SD=standard deviation; SF=short form; S-TOFHLA=Short Test of Functional Health Literacy in Adults; USUnited States; VRQoL=vision-related quality of life.

Table 28 Summary of studies on the relationship between health literacy and mortality (KQ 1b)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Results Between Health Literacy Levels
Baker et al., 2007^65^ (Analysis 1) Baker et al., 2008^67^ (Analysis 2) (companion: Gazmararian, 2006;61 Wolf et al., 2007;64 Howard et al., 2006;63 Wolf et al., 2005;66 Howard et al., 2005;68 Baker et al., 2004^62^) Prospective cohort N = 3,260 Good | New Prudential Medicare managed care enrollees in Cleveland, OH; Houston, TX; and Tampa and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA Inadequate: 24% Marginal: 11% Adequate: 64% | Baseline measures: Number of chronic conditions Physical health score Mental health score IADL limitation ADL limitation Smoking Alcohol use Vigorous physical activity BMI | All-cause mortality rate Inadequate: 39% Marginal: 29% Adequate: 19% Cardiovascular mortality rate Inadequate: 19% Marginal: 17% Adequate: 8% Cancer mortality rate Inadequate: 9% Marginal: 5% Adequate: 6% Noncardiovascular/noncancer mortality rate Inadequate: 11% Marginal: 7% Adequate: 5% | Analysis 1 All-cause mortality Inadequate group had a greater rate than adequate group (adjusted): HR,1.52; 95% CI, 1.26-1.83 No difference between marginal and adequate groups (adjusted): HR, 1.13; 95% CI, 0.90-1.41 Cardiovascular mortality Inadequate group had a greater rate than the adequate group (adjusted): HR, 1.52; 95% CI, 1.16-2.00 Marginal group had a greater rate than the adequate group (adjusted): HR, 1.39; 95% CI, 1.02-1.90 Cancer mortality No difference between inadequate and adequate groups (adjusted): HR, 1.18; 95% CI, 0.81-1.72 No difference between marginal and adequate groups (adjusted): HR, 0.65; 95% CI, 0.38-1.09 All other causes mortality Inadequate group has a greater rate than the: adequate group (adjusted): HR, 1.87; 95% CI, 1.32-2.67 No difference between marginal and adequate groups (adjusted): HR, 1.18; 95% CI, 0.76-1.85 Analysis 2 All-cause mortality (adjusted for all confounders and level of cognitive functioning) Inadequate group has a greater rate than adequate (adjusted): HR, 1.27; 95% CI, 1.03-1.57 No difference between marginal and adequate group (adjusted): HR, 1.08; 95% CI, 0.85-1.36
Sudore et al., 2006^167^ (companion: Sudore et al., 2006^95^) Prospective cohort, retrospective analysis N = 2,512 Good | Seniors (70-79 year old) in Pittsburgh, PA, and Memphis, TN REALM Limited: 24% Adequate: 76% | Demographics: age, race, gender, income, education Health status: self-rated health, cardiac disease, stroke, cancer, hypertension, diabetes, obesity Health-related behaviors: former or current smoker, drinking >1 alcoholic beverage per day Poor health care access: lack of a regular doc or clinic, no flu shot within past 12 months, no insurance for medications Psychosocial status: high depressive symptoms, poor personal mastery | Mortality rate Limited: 20% Adequate: 11% | Limited group greater odds of dying than adequate group (adjusted): HR, 1.75; 95% CI, 1.27-2.41 Limited group greater odds of dying than adequate group (adjusted, excluding participants with cognitive impairment): HR, 1.94; 95% CI, 1.37-2.74

ADL=activities of daily living; AQLQ=Asthma Quality of Life Questionnaire; BMI=body mass index; CI=confidence interval; HR=hazard ratio; HRQoL=health-related quality of life; IADL=Instrumental activities of daily living; N=number; OH=Ohio; OR=Odds ratio; TN=Tennessee; TX=Texas.

Table 29 Summary of studies of the relationship between health literacy and costs (KQ 1c)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Results Between Health Literacy Levels
Howard, et al., 2005^68^ (companion: Gazmararian, 2006;61 Wolf et al., 2007;64 Baker et al., 2007;65 Howard et al., 2006;63 Wolf et al., 2005;66 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Prospective cohort N = 3,260 S-TOFHLA Good | New Medicare managed-care enrollees in Cleveland, Houston, Tampa, and south Florida S-TOFHLA Inadequate: 25% Marginal: 11% Adequate: 64% | Age Sex Race/ethnicity Income Education Tobacco Alcohol consumption Self-reported comorbid conditions | Costs 1-year period Overall mean (SD) Inadequate: $9,614 ± $22,536 Marginal: $8,484 ± $16,646 Adequate: $7,246 ± $17,941 Inpatient mean (SD) Inadequate: $6,817 ± $21,049 Marginal: $5,857 ± $15,240 Adequate: $4,656 ± $16,428 Outpatient mean (SD) Inadequate: $1,970 ± $3,477 Marginal: $1,727 ± $2,954 Adequate: $1,805 ± $3,188 ED mean (SD) Inadequate: $189 ± $551 Marginal: $182 ± $593 Adequate: $100 ± $360 Pharmacy mean (SD) Inadequate: $638 ± $1,267 Marginal: $719 ± $998 Adequate: $684 ± $890 | Overall costs (adjusted) No difference between inadequate and adequate groups: β, $1,551; 95% CI, -$166-$3,267 No difference between marginal and adequate groups: β, $596; 95% CI, -$1,437-$2,630 Inpatient costs (adjusted) No difference between inadequate and adequate groups: β, $1,543; 95% CI, -$89-$3,175 No difference between marginal and adequate groups: β, $748; 95% CI, -$1,252-$2,748 Outpatient costs (adjusted) No difference between inadequate and adequate groups: β, -$213; 95% CI, -$481-$55 Costs lower in marginal group: β, -$350; 95% CI, -$679 to -$20 ED costs (adjusted) Higher costs in inadequate group: β, $108; 95% CI, $62- $154 Higher costs in marginal group: β, $80; 95% CI, $28- $132 Pharmacy costs (adjusted) No difference between inadequate and adequate group: β, $27; 95% CI, -$55-$110 No difference between marginal and adequate groups: β, $35; 95% CI, -$62-$132
Weiss et al. 2004^168^ Retrospective cohort N = 74 Fair | Medicaid beneficiaries in Arizona IDR Low: 24% Higher: 76% | Age Ethnic group Health status | Total costs, 1-year period, mean (range) Low: $10,688 ($0-$95,002) Higher: $2,890 ($0-38,957) | Medicaid costs over a 1-year period higher in low group (adjusted) (P = 0.037)

CI=-confidence interval; ED=-emergency department; IDR=Instrument for the Diagnosis of Reading; N=number; S-TOFHLA=Short Test of Functional Health Literacy in Adults; SD=standard deviation.

Table 31 Summary of studies of the relationship between health literacy and disparities (KQ 1d)

Authors, Year, Study Design, Analysis Sample Size, Quality | Population and Setting, Health Literacy Level | Variables used in Multivariate Analysis | Outcome Measure Outcomes By Health Literacy Level | Differences in Results Between Health Literacy Levels
Sentell and Halpin, 2006^141^ Cross-sectional N = 23,889 Fair | National sample of adults Total NALS score Level 1: 20% Level 2: 27% Level 3: 34% Level 4: 18% Level 5: 2% | Race Education Understand English Born in U.S.A. Unemployed Family income Income missing Sex Age Married Get food stamps Live in Metropolitan Statistical Area Region | Self report of physical, mental, or other health condition that keeps respondent from working Data: NR Long-term illness (greater than 6 months) Data: NR | Health literacy mediates the association of black race on having a condition that keeps you from work (adjusted): Odds associated with black race, not controlling for health literacy: OR 1.54, 95% CI, 1.29-1.84 Odds associated with black race, controlling for health literacy: OR 1.04; 95% CI, 0.85-1.26 Health literacy mediates the effect of black race on having long-term illness (adjusted) Odds associated with black race, not controlling for health literacy: OR 1.24; 95% CI, 1.03-1.49 Odds associated with black race, controlling for health literacy: OR, 1.07; 95% CI, 0.89-1.30
Howard, 2006^63^ (companion: Gazmararian, 2006;61 Wolf et al., 2007;64 Baker et al., 2007;65 Wolf et al., 2005;66 Baker et al., 2008;67 Howard et al., 2005;68 Baker et al., 2004^62^) Cohort N = 3,260 Fair | New Prudential Medicare managed care enrollees in Cleveland, Ohio, Houston, Texas, Tampa, and south Florida (including Ft. Lauderdale and Miami) S-TOFHLA By race: White: Adequate: 71% Marginal: 10% Inadequate: 19% Black: Adequate: 36% Marginal: 12% Inadequate: 52% | Age Gender Race/ethnicity Education Income Site Morbidity Smoker | Physical HRQoL mean (SF-12) White: 44.9 Black: 43.6 Mental HRQoL mean (SF-12) White: 55.7 Black: 53.0 Self-reported health good or higher White: 0.39 Black: 0.23 Receipt of influenza vaccine White: 0.826 Black: 0.701 Receipt of pneumococcal vaccine White: 0.48 Black: 0.29 | Physical HRQoL (difference in scores between white and black, adjusted) Not controlling for health literacy: 0.1 Controlling for health literacy: -0.5 Difference between models: (0.6, 95% CI, 0.3-0.9) Mental HRQoL (difference in scores between white and black, adjusted) Not controlling for health literacy: 0.5 Controlling for health literacy: 0.2 Difference between models: (0.3, 95% CI, 0.1-0.5) Self-reported health good or higher (difference in scores between white and black, adjusted) Not controlling for health literacy: 0.8 Controlling for health literacy: 0.6
Wolf et al., 2006^157^ Convenience N = 308 Good | Patients with newly diagnosed prostate cancer in 4 outpatient oncology and urology clinics in Chicago area REALM Low: 18% Marginal: 33% Functional: 50% | Age Race Annual income Marital status | PSA Level > 20 ng/mL Marginal: 24% Low: 33% Functional: 14% Outcomes by race: NR | Health literacy mediates the association between race (African American versus white) and PSA level (adjusted). Odds associated with African American, not controlling for health literacy (OR, 4.6; 95% CI, 2.0- 9.5) Odds associated with African American, controlling for health literacy (OR, 3.0; 95% CI, 0.8- 9.1)
Bailey, 2009^77^ Cross-sectional N = 373 Fair | Adults in Shreveport, LA; Chicago, IL; and Jackson, MI REALM Low: ≤ 6th grade: 20% Marginal: 7th-8th grade: 29% Adequate: ≥ 9th grade: 51% | Race Age Sex Education | Misinterpretation of medication label instructions Low: 43% Marginal: 34% Adequate: 18% | HL is a mediator between race and gender and misinterpretation of medication instructions Odds associated with being black vs. white (adjusted) Not controlling for HL: OR, 1.63; 95% CI, 1.02-2.61 Controlling for HL: OR, 1.22; 95% CI, 0.73-2.04 Odds associated with being male vs. female (adjusted) Not controlling for HL: OR, 1.67; 95% CI, 1.03-2.72 Controlling for HL: OR, 1.59; 95% CI, 0.97-2.60
Bennett et al., 2009^85^ (companion: White et al. 2008^86^) Cross-sectional N = 2,668 Good | Nationally representative sample of US population 65 years and older NAAL Below basic: 29.0% Basic: 29.5% Intermediate: 38.2 Proficient: 3.3% | Race Income Gender Age Nativity | NR | HL mediates the association between race (black vs. white) and self-reported health status (adjusted) Odds associated with being black Not controlling for HL: β, -0.34 (SE, 0.11) (P < 0.05) Controlling for HL: β, -0.24 (SE, 0.04) (P < 0.05) Odds associated with being Hispanic Not controlling for HL: β, 0.02 (SE, 0.14) (P = NS) Controlling for HL: β,0.21 (SE, 0.07) (P < 0.05) HL mediates the association between race (black vs. white) and receipt of influenza vaccine (adjusted) Odds associated with being black Not controlling for HL: β,-0.24 (SE, 0.10) (P < 0.05) Controlling for HL: β,-0.18 (SE, 0.04) (P < 0.05) Odds associated with being Hispanic Not controlling for HL: β, -0.04 (SE, 0.16) (P = NS) Controlling for HL: β, 0.08 (SE, 0.07) (P = NS) HL not found to mediate relationship between race/ethnicity and receipt of mammogram (adjusted, comparison is white) Odds associated with being black Not controlling for HL: β, 0.23 (SE, 0.15) (P =NS) Controlling for HL: β, 0.28 (SE, 0.06) (P < 0.05) Odds associated with being Hispanic Not controlling for HL: β, 0.57 (SE, 0.19) (P < 0.05) Controlling for HL: β, 0.70 (SE, 0.07) (P < 0.05) HL not found to mediate the relationship between race/ethnicity and dental checkup (adjusted, comparison is white) Odds associated with being black Not controlling for HL: β, -0.13 (SE, 0.11) (P =NS) Controlling for HL: β, -0.04 (SE, 0.04) (P = NS) Odds associated with being Hispanic Not controlling for HL: β, 0.19 (SE, 0.14) (P = NS) Controlling for HL (β. 0.35 (SE, 0.05) (P < 0.05))
Osborn, 2009^171^ Cross-sectional N= 383 Good | Adults with type I or II diabetes REALM < 9th grade = 31% ≥ 9th grade = 69% | Age Year of diagnosed diabetes Insulin use African American race | Data NR | HL not found to be a mediator of relationship between African American race and HbA1C through structural equation modeling
Sudore et al., 2006^167^ (companion: Sudore et al., 2006^95^) Prospective cohort, retrospective analysis N = 2,512 Good | Seniors (70-79 year old) in Pittsburgh, PA, and Memphis, TN REALM Limited: 24% Adequate: 76% | NR | Mortality rate Limited: 20% Adequate: 11% | Mortality within subgroups comparing limited group with adequate: Interaction between racial group and HL and sex and HL (P > 0.10 for all comparisons implying no moderator effect) White: HR 2.36; 95% CI, 1.63-3.42 Black: HR 1.66; 95% CI, 1.29-2.29 Male: HR 1.77; 95% CI, 1.20-2.62 Female: HR 2.27; 95% CI, 1.67-3.09
Osborn et al., 2007^69^ (companions: Wolf et al., 2007;70 Waite et al., 2008^71^) Cross-sectional N = 204 Fair | Patients at 2 HIV clinics: 1 in Chicago, IL, and 1 in Shreveport, LA REALM Low: 11% Marginal: 20% Adequate: 69% | Race Gender Age Income Number of medications in HIV regimen Non-HIV comorbid conditions Mental illness | Nonadherence to HIV medications in past 4 days Low: 52% Marginal: 19% Adequate: 30% | HL mediates association of black vs. white race on adherence (adjusted) Odds associated with being black, not controlling for HL: OR, 2.4; 95% CI, 1.14-5.08 Odds associated with being black, controlling for HL: OR, 1.8; 95% CI, 0.51-5.85
Yin, 2009^102^ Cross-sectional N = 6,100 Fair | Parents ≥ 16 years old living in a US household (nationally representative sample) NAAL Below basic: 11% Basic: 18% Intermediate: 56% Proficient: 15% | Age Gender Number of children living in the home Educational attainment Race/ethnicity Country of birth English proficiency Income Region Metropolitan statistical area | At least 1 child without health insurance Below basic: 24% Basic: 10% Intermediate: 6% Proficient: 3% Self-reported difficulty understanding OTC medication labels Below basic: 74% Basic: 43% Intermediate/proficient: 38% | HL is a mediator between race and health insurance coverage (adjusted) Race/ethnicity not controlling for HL: P = 0.03 Race/ethnicity controlling for HL: P = 0.08 HL is not a mediator between race and self-report of difficulty understanding of medication labels Race/ethnicity not controlling for HL: P = 0.04 Race/ethnicity controlling for HL: P = 0.05

CI=confidence interval; Hb=hemoglobin; HIV=human immunodeficiency virus; HL=health literacy; HR=hazard ratio; HRQoL=health related quality of life; N=number; NAAL=National Assessment of Adult Literacy; NALS=National Adult Literacy Survey; NR=not reported; NS=not sufficient; OR=odds ratio; OTC=over the counter; PSA=prostate-specific antigen; REALM=Rapid Estimate of Adult Literacy in Medicine; SE=standard error; SF-12=Short Form 12; S-TOFHLA=Short Test of Functional Health Literacy in Adults; US=United States.

Table 33 Overview of numeracy studies

Source Design Quality Score | Population | Population Numeracy Levels | Outcomes | Variables Used in Multivariate Analysis | Also examined literacy
Aggarwal et al., 2007^178^ Cross-sectional Fair | 264 patients at 4 ambulatory care clinics affiliated with an urban academic medical center in the US | 74% inadequate numeracy on 5-item numeracy test adapted from Black and Toteson | Knowledge Health care services | Age Race Education Primary care provider FH disease | No
Cavanaugh et al., 2008^174^ Cross-sectional Fair | 398 patients from 2 primary care clinics and 2 endocrinology clinics at 3 hospitals in the US | 69% < 9th grade WRAT-3, numeracy Diabetes Numeracy Test Quartile 1: 27% Quartile 2: 25% Quartile 3: 26% Quartile 4: 23% | Knowledge Self-efficacy Behavior Disease prevalence/severity | None | Yes
Davids et al., 2004^175^ Cross-sectional Fair | 254 patients in 2 academic general medicine clinics in the US | % correct on numeracy test adapted from Schwartz and Woloshin 0: 15% 1: 17% 2: 27% 3: 41% | Accuracy of risk perception | Age Race Education Income FH breast cancer Age at menses Age at first live birth Number of breast biopsies | No
Estrada et al., 2004^126^ Prospective cohort Fair | 143 patients in anticoagulation management clinics in 1 university and 1 VA-based hospital in the US | 6 items (including 3 adapted from Schwartz and Woloshin) 0 correct: 13.3% 1-2 correct: 35% 3-4 correct: 34.3% 5-6 correct: 17.5% | Medication skill | Age | No
Haggstrom and Schapira, 2006^176^ Cross-sectional Fair | 207 patients in a general medicine clinic at an academic medical center in the US | NR % with all correct on Schwartz and Woloshin numeracy test | Accuracy of risk perception | Age Race FH Family income Insurance Education | No
Hibbard et al., 2007^98^ RCT Relevant data analyzed cross-sectionally Fair | 303 community-dwelling adults in the US | 43% low numeracy (less than mean = 9 on 15-item scale adapted from Lipkus) | Skill Use of health care services | None | Yes
Huizinga et al., 2008^10^ Cross-sectional Fair | 169 patients in an academic primary care clinic in the US | 66% < 9th grade WRAT-3, numeracy | Disease prevalence/severity | Age Gender Race Income Education REALM | Yes
Lokker et al. 2009^179^ Cross-sectional Fair | 182 caregivers of patients at general pediatric clinics at 3 academic medical centers | < 6^th^ grade on WRAT-math: 36% 6^th^-8^th^ grade on WRAT-math: 47% | Medication skill | Age Gender Race Educational attainment | No
Osborn et al., 2009^171^ Cross-sectional Good | 383 patients at 2 primary care and 2 diabetes specialty clinics located at 3 medical centers | Diabetes Numeracy Test Quartile 1 = 27% Quartile 2 = 25% Quartile 3 = 26% Quartile 4 = 22% | Disease prevalence and severity (Numeracy as a mediator of relationship between race and HgbA1c) | Age Year of diagnosed Diabetes Insulin use African American race | Yes
Rothman et al., 2006^9^ Cross-sectional Fair | 200 patients at 1 academic primary care clinic in the US | 63% < HS on WRAT-3, numeracy | Skill Disease prevalence/severity | None | Yes
Schwartz et al., 1997^24^ RCT Relevant data analyzed cross-sectionally Fair | 287 patients at a Veterans hospital in the US who received a mailed survey | % correct on numeracy test from Schwartz and Woloshin 0: 30% 1: 28% 2: 26% 3: 16% | Accuracy of risk perception | Age Income Education Frame of information | No
Sheridan and Pignone, 2002^172^ RCT Relevant data analyzed cross-sectionally Fair | 62 medical students in 1 US medical school | % correct on numeracy test from Schwartz and Woloshin 0-1: 5% 2: 18% 3: 77% | Accuracy of risk perception | None | No
Sheridan et al., 2003^173^ RCT Relevant data analyzed cross-sectionally Fair | 357 patients in an academic general medicine clinic in the US | % correct on numeracy test from Schwartz and Woloshin 0: 41% 1: 30% 2: 27% 3: 2% | Accuracy of risk perception | None | No
Vavrus, 2006^177^ Cross-sectional Fair | 277 students from 4 school districts in the United Republic of Tanzania | 57% low numeracy (Correctly completed 0-1 of 3 calculations on numeracy test NOS) | Knowledge | Gender Literacy Household spending Parents' education Television in home Siblings Electricity Sewage | No
Waldrop-Vaverde et al., 2009^47^ Cross-sectional Fair | 155 individuals who are patients at HIV clinics or participants in AIDS drug assistance program in Miami, Florida | 57% correct on applied problems subtest of Woodcock-Johnson III Men: 63% correct Women: 50% correct | Medication skill (Numeracy as a mediator of the relationship between gender and medication management capacity) | Gender Time since HIV diagnosis Education Health literacy | Yes
Yin et al., 2007^125^ Cross-sectional Fair | 292 caregivers of young children at the pediatric emergency department in an urban academic medical center in the US | NR by TOFHLA, numeracy (split at median) | Knowledge, Medication skill | Caregiver education Country of origin Language SES Age of children Regular health care provider Experience in health care setting | No

AIDS=acquired immune deficiency syndrome; FH=family history; HgbA1c=glycosylated hemoglobin; HIV=human immunodeficiency virus; HS=high school; NOS=not otherwise specified; NR=not reported; RCT=randomized controlled trial; REALM=Rapid Estimate of Adult Literacy in Medicine; SES=socioeconomic status; TOFHLA=Test of Functional Health Literacy in Adults; VA=Veterans Administration; WRAT-3=Wide Range Achievement Test-3^rd^ edition.

Table 35 KQ 1 numeracy studies: strength of evidence grades by use of health care services and health outcomes

Outcome | Number of Studies | Results | Overall Grade
Use of Healthcare Services | 1 | Mixed results, no adjustment for confounding | Insufficient
Accuracy of Risk Perception | 5 | Perceived risk (n = 2): mixed results depending on length over which risk estimated Perceived treatment benefit (n = 4): mixed results depending on numeracy level categories, 3 of 4 studies suggested low numeracy reduced accuracy of perceived benefit. | Insufficient
Knowledge | 4 | Mixed results, partially dependent on type of knowledge, sample size, and adjustment for confounding | Insufficient
Self-Efficacy | 1 | Lower numeracy associated with lower self-efficacy in unadjusted analysis | Insufficient
Behavior | 1 | Lower numeracy not related to self-care behavior in unadjusted analysis | Insufficient
Skills | 6 | Mixed results depending on type of skill Skill in taking medication (n = 4): mixed results Skill in interpreting health information (n = 2) lower numeracy related to lower comprehension | Skill in taking medication: Insufficient Skill in interpreting health information: Low
Disease Prevalence and Severity | 3 | BMI (n = 2), HbA1c (n = 1), illness requiring dietary restriction (n = 1): Mixed results | Insufficient
Disparities | 2 | Numeracy appears to partially mediate the relationship between race and HgbA1c (n=1) and between gender and HIV medication management capacity (n=1) | Low

BMI=body mass index; HbA1c=glycosylated hemoglobin; HIV=human immunodeficiency virus

Table 34 The relationship between numeracy level and use of health care services (KQ 1a)

Author, Year, Study Design, Sample Size, Quality | % Low Numeracy | Outcome | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference
Aggarwal et al., 2007^178^ Cross-sectional survey N = 264 *Note: sample for actual colon screening 152 (women < age 50 who would not be eligible for screening were excluded) Fair | 74% inadequate numeracy on 5-item numeracy test adapted from Black and Toteson | % with up-to-date breast cancer screening % with up-to-date colon cancer screening | Age Race Education Primary care provider Familial hypercholes-terolemia disease | Up-to-date with screening for breast cancer Inadequate: 71% Adequate: 77% Up-to-date with colon cancer guidelines Inadequate: 46% Adequate: 51% | OR for up-to-date breast cancer screening (inadequate vs. adequate): OR, 1.43 (0.62-3.33)^a^ OR for up-to-date colon cancer screening (inadequate vs. adequate): OR, 0.91 (0.3-2.0)^a^

a Calculated by research team

OR=odds ratio; RCT=randomized controlled trial; vs.=versus.

Table 36 The relationship between numeracy level and accuracy of risk perception (KQ 1b)

Author, Year, Study Design, Sample Size, Quality | % Low Numeracy levels | Outcome | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference by Numeracy Level
Davids et al., 2004^175^ Cross-Sectional N = 254 Note: 18% of those invited Fair | % of questions correct on numeracy test adapted from Schwartz and Woloshin 0 correct: 15% 1 correct: 17% 2 correct: 27% 3 correct: 41% | Estimation error for breast cancer risk (Absolute difference between perceived and Gail model calculated breast cancer risks over lifetime and 5 years) | Age Race Education Income FH breast cancer Age at menses Age at first live birth Number of breast biopsies | Lifetime risk estimation error Numeracy 0 correct: 40.1 1 correct: 28.3 2 correct: 30.1 3 correct: 25.8 5-year estimation error Numeracy 0 correct: 32.2 1 correct: 24.0 2 correct: 27.8 3 correct: 20.5 | Lifetime risk estimation error (adjusted) Beta-coefficient for every additional numeracy question incorrect: 0.18; 95% CI, 0.05-0.30^a^ 5-year risk estimation error (adjusted): NR Note: unadjusted correlation NS
Haggstrom and Schapira, 2006^176^ Cross-Sectional N = 207 Note: 18% of those invited Fair | NR % with < 3 correct on Schwartz and Woloshin numeracy test | Accurate perception of breast cancer survival (compared with 5-year survival rates) Accurate perception of screening mammography benefit (compared with meta-analysis results) | Age, Race, FH, Family income, Insurance, Education | NR | Accurate perception of breast cancer survival over 5 years (0-2 questions vs. 3 correct; adjusted): OR, 1.19; 95% CI, 0.54–2.63^a^ Accurate perception of screening mammography benefit (0-2 correct vs. 3 correct; adjusted): OR, 1.33; 95% CI, 0.50– 3.57^a^
Sheridan and Pignone, 2002^172^ RCT Relevant data analyzed cross-sectionally N = 62 medical students Fair | % of questions correct on numeracy test from Schwartz and Woloshin 0-1 correct: 5% 2 correct: 18% 3 correct: 77% | Ability to correctly compare treatment benefit presented alternately as ARR, RRR, NNT, combination Ability to correctly calculate treatment benefit presented alternately as ARR, RRR, NNT, combination | None | Correctly stated which treatment provided more benefit 0-1 correct: 33% 2 correct: 91% 3 correct: 94% Correctly calculated treatment benefit 0-1 correct: 0% 2 correct: 36% 3 correct: 71% | Correctly stated which treatment provided more benefit 0-1 vs. 3 correct (unadjusted): - 61%^a^, P = 0.03 Correctly calculated treatment benefit (unadjusted) 0-1 vs. 3 correct: -71%^a^, P < 0.01
Sheridan et al., 2003^173^ RCT Relevant data analyzed cross-sectionally N = 357 Fair | % of questions correct on numeracy test from Schwartz and Woloshin 0 correct: 41% 1 correct: 30% 2 correct: 27% 3 correct: 2% | Ability to correctly compare treatment benefit presented alternately as ARR, RRR, NNT, combination Ability to correctly calculate treatment benefit presented alternately as ARR, RRR, NNT, combination | None | Correctly stated which treatment provided more benefit 0-1 correct: 35% 2 correct: 63% 3 correct: 88% Correctly calculated treatment benefit 0-1 correct: 5% 2 correct: 30% 3 correct: 50% | Correctly stated which treatment provided more benefit 0-1 vs. 3 correct (unadjusted): - 53%^a^; P< 0.001 Correctly calculated treatment benefit (unadjusted) 0-1 vs. 3 correct: -45%^a^; P< 0.001
Schwartz et al., 1997^24^ RCT Relevant data analyzed cross-sectionally N = 287 Fair | % of questions correct on numeracy test from Schwartz and Woloshin 0 correct: 30% 1 correct: 28% 2 correct: 26% 3 correct: 16% | Ability to correctly perceive treatment benefit presented alternately as ARR +/- baseline risk or as RRR +/- baseline risk | Age, Income, Education, Frame of information | Correctly perceived treatment benefit 0 correct: 5.8% 1 correct: 8.9% 2 correct: 23.7 % 3 correct: 40% | Correctly perceived treatment benefit 0 vs. 1 correct (adjusted) absolute difference: -3.1%a; OR, 0.77; 95% CI, 0.21–3.33a 0 vs. 2 correct (adjusted) absolute difference: -17.9% a; OR, 0.14; 95% CI, 0.04-0.45a 0 vs. 3 correct (adjusted) absolute difference: +34.2%a; OR, 0.08; 95% CI, 0.02-0.28a

a Calculated by research team

5-yr survival rate=5-year survival rates; ARR=absolute risk reduction; CI=confidence interval; FH=family history; NNT=number needed to treat; NR=not reported; NS=not significant; OR=odds ratio; RCT=randomized controlled trial; RRR=relative risk ratio; vs.=versus.

Table 37 Relationship between numeracy level and knowledge (KQ 1b)

Author, Year, Study Design, Sample Size, Quality | % Low Numeracy levels | Outcome | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference
Aggarwal et al., 2007^178^ Cross-sectional N = 264 *Note: sample for actual colon screening 152 (women < age 50 who would not be eligible for screening were excluded) Fair | 74% inadequate numeracy on 5-item numeracy test adapted from Black and Toteson | Knowledge of breast cancer and colorectal cancer screening guidelines | Age Race Education Primary care provider FH of disease | Knowledge of breast cancer guidelines Inadequate: 25% Adequate: 48% Knowledge of colon cancer guidelines Inadequate: 17% Adequate: 35% | Knowledge of breast cancer guidelines (inadequate vs. adequate, adjusted): 0.37 (0.19-0.71)^a^ Knowledge of colon cancer guidelines (inadequate vs. adequate, adjusted): 0.63 (0.29-1.25)^a^
Cavanaugh et al., 2008^174^ Cross-sectional N = 398 Fair | WRAT-3, numeracy < 9th grade: 69% ≥ 9th grade: 31% Diabetes Numeracy Test (DNT: median % correct) Overall: 65% Quartile 1: 27% Quartile 2: 25% Quartile 3: 26% Quartile 4: 23% | Median diabetes knowledge (range 0-100) | None | Median Diabetes knowledge DNT Quartile 1: 52 DNT Quartile 2: 65 DNT Quartile 3: 79 DNT Quartile 4: 86 | Median diabetes knowledge DNT Quartile 1 vs. 4 (unadjusted): -34^a^; P for trend: P < 0.001
Vavrus, 2006^177^ Cross-sectional N = 277 Fair | 57% Low Numeracy (correctly completed 0-1 of 3 calculations on numeracy test NOS) | % of 5 knowledge questions about general health correctly answered % of 5 knowledge questions about HIV/AIDS correctly answered | Gender Literacy Household spending Parents' education Television in home Siblings Electricity Sewage | NR | OR for high general health knowledge (low vs. high numeracy, adjusted): 0.66a; P > 0.05 OR for high HIV/AIDS knowledge (low vs. high numeracy, adjusted): 0.36a; P < 0.001
Yin et al., 2007^125^ Cross-sectional N = 292 caregivers of young children Fair | NR by TOFHLA, numeracy (split at median) | % of caregivers with poor knowledge of weight-based dosing | Caregiver education Country of origin Language SES Age of children Regular healthcare provider Experience in healthcare setting | Poor knowledge of weight based dosing Innumerate: 76% Numerate: 62% | Odds of poor knowledge of weight based dosing (innumerate vs. numerate, adjusted): 1.1; 95% CI, 0.6-2.2 Note: when education, acculturation, and SES are not included in model, result was significant (1.8; 95% CI, 1- 3.1)

a Calculated by research team

CI=confidence interval; DNT=Diabetes Numeracy Test; FH=family history; HIV/AIDS=acquired immunodeficiency syndrome/human immunodeficiency virus; NOS=not otherwise specified; NR=not reported; OR=odds ratio; SES=socioeconomic status; TOFHLA=Test of Functional Health Literacy in Adults; vs.=versus; WRAT-3=Wide Range Achievement Test-3^rd^ edition.

Table 38 Relationship between numeracy and self-efficacy (KQ 1b)

Author, Year, Study Design, Sample Size, Quality | % Low Numeracy | Outcome | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference
Cavanaugh et al., 2008^174^ Cross-sectional N = 398 Fair | WRAT-3, numeracy < 9^th^ grade: 69% ≥ 9^th^ grade: 31% Diabetes Numeracy Test (DNT: median % correct) Overall: 65% Quartile 1: 27% Quartile 2: 25% Quartile 3: 26% Quartile 4: 23% | Median self-efficacy for diabetes self-management Measured by Perceived Diabetes Self-Management Scale (range 8-40) | None | Median self-efficacy DNT Quartile 1: 28 DNT Quartile 2: 28 DNT Quartile 3: 31 DNT Quartile 4: 32 | Median Self-efficacy DNT Quartile 1 vs. 4: -4^a^, P for trend: (P = 0.003)

a Calculated by research team

DNT=Diabetes Numeracy Test; vs.=versus; WRAT-3=Wide Range Achievement Test-3^rd^ edition.

Table 39 Relationship between numeracy level and behavior (KQ 1b)

Author, Year, Study Design, Sample Size, Quality | % Low Numeracy | Outcome | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference
Cavanaugh et al., 2008^174^ Cross-sectional N = 398 Fair | WRAT-3, numeracy < 9th grade: 69% ≥ 9th grade: 31% Diabetes Numeracy Test (DNT: median % correct) Overall: 65% Quartile 1: 27% Quartile 2: 25% Quartile 3: 26% Quartile 4: 23% | Median reported use of self-management behaviors using the Summary of Diabetes Self-Care Activities scale (range 0-7) Includes the following behaviors General diet Specific diet Exercise Blood glucose level testing Foot care | None | Self-management behaviors General diet Quartile 1: 5 Quartile 4: 5 Specific diet Quartile 1: 3.5 Quartile 4: 3.5 Exercise Quartile 1: 3.5 Quartile 4: 2.75 Blood glucose level testing Quartile 1: 7 Quartile 4: 6.5 Foot care Quartile 1: 5.5 Quartile 4: 3.25 | Absolute difference in general diet behaviors (Quartile 1 vs. 4): 0^a^; P = 0.21 Absolute difference in specific diet behaviors (Quartile 1 vs. 4): 0^a^; P = 0.82 Absolute difference in exercise behavior (Quartile 1 vs. 4): +0.75^a^; P = 0.25 Absolute difference in blood glucose level testing (Quartile 1 vs. 4): 1.5^a^; P = 0.44 Absolute difference in foot care behavior (Quartile 1 vs. 4): 2.25^a^; P < 0.001

a Calculated by research team

DNT=Diabetes Numeracy Test; vs.=versus; WRAT-3=Wide Range Achievement Test- 3^rd^ edition.

Table 40 Relationship between numeracy level and skills (KQ 1b)

Author, Year, Study Design, Sample Size, Quality | % Low Numeracy | Outcomes | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference
Medication Taking Skills
Estrada et al., 2004^126^ Prospect cohort N = 143 Note: 11 were proxies for patients Fair | 6-items (including 3 adapted from Schwartz and Woloshin) 0 correct: 13.3% 1-2 correct: 35% 3-4 correct: 34.3% 5-6 correct: 17.5% | Correct medication dosing operationalized as: % INR tests within the therapeutic range INR variability (using sigma, a composite capturing number of measurements, time since previous measure, and therapeutic range; higher values are worse) | Age | % INR tests within range 0 correct: 56% 5-6 correct: 66% INR variability using mean sigma score 0 correct: 0.80 5-6 correct: 0.45 | Absolute difference in % INR tests within range (adjusted): NR; P = 0.35 Absolute difference in INR variability (adjusted): NR; P = 0.03
Lokker et al., 2009^179^ Cross-sectional N = 182 Fair | < 6^th^ grade on WRAT-math: 36% 6^th^-8^th^ grade on WRAT-math: 47% | Poor caregiver understanding of OTC cold medicine labels (i.e. say product suitable for < 24-month-old) Caregiver intent to use medication in 13-month-old | Age Gender Race Educational attainment | NR | Adjusted odds ratios for each decrease in numeracy grade level For caregivers with 2^nd^-8^th^ grade numeracy score Think suitable: 1.25 (0.99-1.58)^a^ Would use: 1.19 (1.01-1.41)* Adjusted odds ratios for each increase in numeracy grade level For caregivers with 9^th^-16^th^ grade numeracy score Think suitable: 1.28 (0.79-2.06) Would use: 1.78 (1.07-2.96)
Waldrop-Valverde et al., 2009^47^ Cross-sectional N = 155 Fair | 57% correct on applied problems subtest of Woodcock-Johnson III Men: 63% correct Women: 50% correct | % correct on Medication Management Test (MMT: range 2-16) | Gender Time since HIV diagnosis Education Health literacy | NR | Adjusted beta-coefficient for relationship between numeracy and MMT: 0.538; P < 0.01
Yin et al.,2007^125^ Cross-sectional N = 292 caregivers of young children Fair | NR by TOFHLA, numeracy (split at median) | % of caregivers with poor knowledge of correct medication dosing instrument (operationalized as reported use of nonstandardized instrument) | Caregiver education Country of origin Language SES Age of children Regular healthcare provider Experience in healthcare setting | Use of nonstandardized dosing instrument Innumerate: 34% numerate: 19% | Odds of use of nonstandardized dosing instrument (innumerate vs. numerate, fully adjusted): 1.4; 95% CI, 0.8-2.7 Note: when education, acculturation, and SES are not included in model, result was significant: 1.9; 95% CI, 1.1-3.4
Skills in Interpreting Health Information
Rothman et al., 2006^9^ Cross-Sectional N = 200 Fair | 63% < HS on WRAT-3, numeracy | % questions correct on 24-item Nutrition Label Survey after being given a nutrition label to read | Age Gender Race Insurance Income Education Clinical disease Specific diet Label reading frequency | Nutrition label comprehension < high school: 61% > high school: 84% | Absolute difference in NLS score (adjusted): NR; P < 0.001
Hibbard et al., 2007^98^ RCT However, results of interest in this paper are cross-sectional N = 303 Fair | 43% low numeracy (less than mean = 9 on 15-item scale adapted from Lipkus) | % questions correct on 13-item health plan knowledge questionnaire after being given health plan information to review % Choosing higher quality hospital | None | Health Plan Comprehension Low numeracy: 72%^a^ High numeracy: 90.5%^a^ Note: interaction by patient activation (i.e., motivation to engage with material) Low numeracy Low activation: 67.7% High activation: 76.3% P for interaction: P < 0.05 High numeracy Low activation: 90.2% High activation: 90.7% P for interaction: NS Choice of higher quality hospital Low numeracy: 59.9% High numeracy: 71.7% Note: interaction by patient activation (i.e., motivation to engage with material) Low numeracy Low activation: 53% High activation: 66.8% P for interaction: P < 0.05 High numeracy Low activation: 66.3% High activation: 77% P for interaction: P < 0.001 | Absolute difference in comprehension (low vs. high, unadjusted): -18.5%^a^; P < 0.05 Absolute difference in choice of higher quality hospital (low vs. high, unadjusted): -11.8%^a^; P < 0.01

a Calculated by research team

CI=confidence interval; HIV=human immunodeficiency virus; HS=high school; i.e., example; INR=international normalized ratio; NLS=Nutrition Label Survey; N=number; NR=not reported; NS=not significant; OTC=over-the-counter; RCT=randomized controlled trial; SES=socioeconomic status; TOFHLA=Test of Functional Health Literacy in Adults; vs.=versus; WRAT-3=Wide Range Achievement Test-3rd edition.

Table 41 Relationship between numeracy level and disease prevalence and severity (KQ 1b)

Author, Year, Study Design, Sample Size Quality | % Low Numeracy | Outcomes | Variables Used in Multivariate Analysis | Results by Numeracy Level | Difference
Cavanaugh et al., 2008^174^ Cross-sectional N = 398 Fair | WRAT-3, numeracy < 9th grade: 69% ≥ 9th grade: 31% Diabetes Numeracy Test (DNT: median % correct) Overall: 65% Quartile 1: 27% Quartile 2: 25% Quartile 3: 26% Quartile 4: 23% | Median HbA1c | Age Gender Race Income Type of diabetes Years since diagnosis of diabetes Clinic site | Median HbA1c Quartile 1: 7.6% Quartile 2: 7.1% Quartile 3: 7.1% Quartile 4: 7.1% | Absolute difference in Median HbA1c (quartile 1 vs. 4: +0.5%; P = 0.119) In adjusted analysis, every 10% decrease in % correct DNT questions resulted in an increase in HbA1c of 0.09%; 95% CI, 0.01%-0.16%
Huizinga et al., 2008^10^ Cross-sectional N = 169 Fair | WRAT-3, numeracy < 9th grade: 66% ≥ 9th grade: 34% | Mean BMI | Age Gender Race Income Education REALM | Mean BMI < 9th grade: 31.8 ≥ 9th grade: 27.9 | BMI (< 9th grade vs. ≥ 9th grade, unadjusted): +3.9^a^; P = 0.008 Effect of numeracy on BMI: (adjusted): β = -0.14; P = 0.01
Rothman et al., 2006^9^ Cross-sectional N = 200 Fair | 63% < HS on WRAT-3, numeracy | % with self-reported illness requiring dietary restriction % BMI > 30 | None | Illness requiring dietary restriction < HS: 44% ≥ HS: 35% % BMI > 30 < HS: 48% ≥ HS: 40% | Absolute difference in percent with illness requiring diet restriction (< HS vs. ≥ HS, unadjusted): +9%; P = 0.20 Absolute difference in % with BMI > 30 (< HS vs. ≥ HS, unadjusted): +8%; P = 0.30

a Calculated by research team

BMI=body mass index; CI=confidence interval; DNT=Diabetes Numeracy Test; HbA1c=glycosylated hemoglobin; HS=high school; REALM=Rapid Estimate of Adult Literacy in Medicine; vs.=versus;WRAT-3=Wide Range Achievement Test-3rd edition.

Table 42 Relationship between numeracy level and disparities (KQ 1d)

Author, Year, Study Design, Sample Size, Quality | % Population with Limited Literacy | Exposure, Outcome, Mediator | Results of Mediational Analysis
Osborn et al., 2009^171^ Cross-sectional N = 383 Good | Diabetes Numeracy Test Quartile 1 = 27% Quartile 2 = 25% Quartile 3 = 26% Quartile 4 = 22% | Exposure: race Outcome: HgbA1c Mediator: numeracy | Structural equation model results Correlation between African-American race and numeracy: -0.46 (P < 0.001) Correlation between numeracy and HgbA1c: -0.15 (P < 0.01) Correlation between African-American race and HgbA1c Without mediator: 0.12 (P < 0.01) With mediator: 0.10, NS
Waldrop-Valverde et al, 2009^47^ Cross-sectional N = 155 Fair | 57% correct on applied problems subtest of Woodcock-Johnson III Men: 63% correct Women: 50% correct | Exposure: gender Outcome: medication management capacity Mediator: numeracy | Path analysis results Correlation between female gender and numeracy: -0.428 (P < 0.01) Correlation between numeracy and medication management capacity: 0.644 (P < 0.01) Correlation between female gender and medication management capacity Without mediator: NR, significant With mediator: 0.073, NS

HgbA1c=glycosylated hemoglobin; NR=not reported; NS=not significant.

We report our results in three main sections: specific details about the yields of the literature searches and the number of studies meeting our inclusion criteria to answer KQ s 1 and 2, the effects of health literacy on health outcomes, and the effects of numeracy on health outcomes. In studies that measured health literacy, we compared the new results broadly with those found during the earlier review (Literacy and Health Outcomes, 2004^1^). All numeracy studies are discussed in this chapter are new; none had been included in the earlier review. We did not find any studies meeting our inclusion criteria addressing outcomes or interventions related to oral health literacy.

References for each study are provided in the summary and evidence tables. By convention, references are not given in tables presenting the strength of evidence. Chapter 2 describes the methods for arriving at strength of evidence grades; Appendix F gives the domain-specific scores used in deriving the overall grades.

## Results of Literature Search

Our literature search yielded 3,496 articles (Figure 3). We also conducted full text reviews of 73 articles identified by hand-searching articles and Web-based bibliographies and recommendations from our Technical Expert Panel (TEP). Of the 3,569 articles retrieved, we excluded 2,653 articles after reviewing the abstracts and pulled 916 articles for full text review. The full bibliography is included in Appendix I. Ultimately, for the two main questions, we included studies rated either good or fair quality: 81 studies addressed KQ 1 and 42 studies addressed KQ 2. KQ 1 results are presented separately in relation to health literacy (86 articles) and numeracy (16 articles). Of these, 7 articles address both health literacy and numeracy.

Figure 3 PRISMA tree: Flow diagram depicting review and disposition of articles

Figure 3. PRISMA tree: Flow diagram depicting review and disposition of articles. This flow diagram depicts the review of the literature; boxes going from top to bottom that are connected by arrows. The total number of titles and abstracts searched by electronic database and by hand were 3,569. This is shown in the first three boxes. There is an arrow pointing to a box labeled citations excluded that equals 2,653. There is an arrow pointing to a box below it labeled full-text articles retrieved that equals 916. There is an arrow pointing to a box on the right labeled full-text articles retrieved, with a total of 738 articles. There is an arrow pointing to the box below the full-text articles retrieved labeled articles included in this review of 178. There is an arrow that points to a box on the right labeled poor quality of 42. Finally, there is an arrow below the box labeled good and fair quality includes by key question (kq): There is a notation at the bottom of the box stating that some articles were included for more than on kq.

### Key Question 1 Relationship of Health Literacy to Various Outcomes and Disparities

We identified 86 good- or fair-quality articles reporting on 72 unique studies for this topic. Some studies report on more than one key question. These studies report results about the relationship between health literacy and use of health care services, health outcomes, and costs of health care and disparities between specific racial, ethnic, cultural, or age groups. Fourteen studies were of good quality and 72 of fair quality, according to the criteria described in Chapter 2. In addition, we identified 40 studies which were considered to be of poor quality and therefore not included in the analysis (poor-quality studies are listed in Appendix E; we do not discuss them further in this review.) In the text below, we identify only studies of good quality; all others for which quality is not specifically called out are fair quality. Most studies had a cross-sectional design (N = 64), but 22 were cohort designs (Table 5).

Multiple studies reported results using the same data. For instance, eight articles reported results collected during the “Prudential study.” This study was conducted with 3,260 new members in a Prudential Medicare managed care plan of enrollees in Cleveland, Ohio, Houston, Texas, and Tampa and south Florida.61-68 Other studies reported in multiple articles include four articles reporting on a sample of patients at Chicago, Illinois, and Shreveport, Louisiana, HIV clinics,69-72 two articles reporting on pharmacy patients in Atlanta, Georgia,73,74 and three articles reporting on patients in three primary care clinics in Chicago, Illinois; Shreveport, Louisiana; and Jackson, Michigan.75-77

Studies examined a variety of outcome measures including use of health care services (hospitalization and emergency department visits and screening and immunizations), access to care, and health outcomes (adherence, self-efficacy, health behaviors, health-care-related skills, disease prevalence and severity, health status, and mortality). Studies also examined differences in costs and disparities related to health literacy level (Table 5).

Table 6 groups KQ 1 health literacy studies based on the health literacy measurement tool used in the analysis and, further, the skill-level groupings used to distinguish study participants. We found that health literacy was mostly measured with the Rapid Estimate of Adult Literacy in Medicine (REALM; 33 articles) or the Test of Functional Health Literacy in Adults (TOFHLA) or Short Test of Functional Health Literacy in Adults (S-TOFHLA; 42 articles). Three articles used the National Assessments of Adult Literacy (NAAL), and, unlike our earlier review, no article used the Wide Range Achievement Test (WRAT; a general literacy measure that was commonly used in studies included in our earlier review Literacy and Health Outcomes1). Several other literacy measures (in contrast to health literacy measures intended to be used in a health care environment) were included in one study apiece: the Cape Area Panel Study Literacy and Numeracy Evaluation, a reading comprehension instrument in Nepalese, an instrument for the diagnosis of reading, and the Woodcock Language Proficiency Battery. Although the validity and reliability of the Woodcock battery42 is well known, information about these other literacy measures is quite limited. The health literacy levels used to compare study participants evaluated using the REALM, TOFHLA, or S-TOFHLA varied among studies, ranging from a continuous measure to two, three, or even more groups. In some studies, three groups were identified (i.e., inadequate, marginal, and adequate); in others, two of the three groups were combined in the statistical analysis. Studies varied concerning whether the two lower or the two higher groups were combined. Conceptually, an individual's health literacy level could change over time. However, the instruments included in the reviewed studies capture only static measures of health literacy or numeracy.

In contrast to our earlier review, studies reviewed in the update by and large include multivariate analyses (rather than just unadjusted bivariate analyses) (Table 5). However, the choice of variables controlled for in analyses varied greatly across studies. Potential confounders (related to health literacy and health outcomes) controlled for in many studies include education, age, race, gender, and income.

### KQ 1a Use of Health Care Services

We identified 24 articles reporting on 23 unique studies examining the relationship between health literacy skills and the use of health care services. Three studies were of good quality and 21 were of fair quality. Nine studies included cohort designs; the rest were cross-sectional. These studies focused on emergency department admissions or hospitalizations, general preventive screenings (mammogram, colon, Papanicolau [Pap], sexually transmitted infection testing, and influenza and pneumococcal vaccination), and access to office visits and insurance.

Hospitalization and emergency department rates. Six studies—one good-quality prospective cohort study (hereafter, the Prudential study),68 two fair-quality prospective cohort study,78,79 one retrospective cohort study,80 and two cross-sectional studies81,82—examined the risk of hospitalization by health literacy level (Table 7). All but one study showed a statistically significant association of increased hospitalization and use of inpatient services with lower health literacy level. Populations included the elderly,68,81 patients with asthma,79,80 and patients with congestive heart failure.78 The one study that did not find an association with hospitalizations included a cross-sectional subpopulation of HIV-positive adolescents, which may be a healthier population compared to the other studies.82 One of the larger cohort studies, the Prudential study, examined the impact of low health literacy on medical care use among 3,260 Prudential Medicare managed care enrollees.68 Patients with low health literacy had higher probabilities of using inpatient services than those with adequate health literacy (mean differences in probability of use, 0.05; 95% confidence interval [CI], 0.00-0.09). Enrollees with marginal and adequate health literacy did not differ in use of inpatient services. The strength of evidence is moderate (Table 8 and Appendix F). These findings are consistent with previous findings in our 2004 systematic review.1

Nine studies, including two good-quality prospective analyses from the Prudential study,62,68 three other prospective cohorts,78,79,83 one retrospective cohort,80 and three cross-sectional studies,81,82,84 examined emergency and urgent care visits by literacy level (Table 7). All but two studies82,84 showed an association of greater emergency department use and low health literacy. The Prudential study62 examined the association of emergency department visits with health literacy level. After controlling for multiple confounders, both the inadequate health literacy and the marginal health literacy groups had a higher rate of two or more emergency department visits when compared with those with adequate health literacy (marginal literacy relative risk [RR], 1.44; 95% CI, 1.01-2.02; inadequate literacy RR, 1.34; 95% CI, 1.00-1.79).

The two studies that did not find an association with health literacy examined associations of parent health literacy and child asthma care among children with persistent asthma84 and the HIV-positive adolescents described above.82 The other study, a cross sectional study of 499 children with persistent asthma, examined parental health literacy and multiple aspects of asthma care (preventive medicine use, acute care, unmet needs, parental worry, and parental quality of life). Parental health literacy was not associated with children's use of any urgent care. This particular outcome was limited because the outcome of urgent care visits was measured by parental self-report. The strength of evidence is moderate (Table 8 and Appendix F). No studies of emergency department use were reported in our earlier report.

General screening. We found one good85 and seven fair studies81,86-91 examining the association of health literacy with general screening services. These services included colon screening (Table 9), Pap testing (Table 10), mammography (Table 11), and testing for sexually transmitted diseases (Table 12).

Colon screening. Five cross-sectional studies found mixed results for the probability of having received colon screening by health literacy level (Table 9).81,86-89 Of note, the two larger studies found a lower probability of colon screening in patients with lower health literacy.81,86 The largest study86 found a decreased probability of colon cancer screening among those 65 years of age and older with below-basic health literacy compared with those with proficient skills in a nationally representative US cross-sectional study of 18,100 individuals examining multiple self-reported preventive services (data not reported [NR]; P < 0.05). The three studies not finding an association with health literacy were smaller in size (samples of 50 to 136) and limited to one geographic area.87-89 The strength of evidence is low (Table 8 and Appendix F). No studies of colon screening use were reported in the earlier 2004 report.1

Pap tests. Three cross-sectional studies found that women with lower health literacy had a lower probability of ever having had a Pap test (Table 10).81,86,91 However, this result was present only in certain age cohorts. In a nationally representative sample, researchers found that women less than 40 years of age with below-basic health literacy had a lower probability of having a Pap test than women in the same age group with proficient health literacy (NR; P < 0.05), but the probabilities did not differ by literacy level in women 40 to 64 years of age.86 Results also seemed to differ by degree of lower health literacy (inadequate vs. marginal). One study examined Pap screening in 205 low-income Spanish-speaking Latinas in New York City.91 In adjusted analyses, controlling for age, years in the United States, education, and having a source of care and health insurance, these investigators found that women with inadequate health literacy were less likely to have ever had a Pap test than women with adequate literacy (odds ratio [OR], 0.06; 95% CI, 0.01-0.55). However, the marginal and adequate health literacy groups did not differ significantly (OR, 0.14; 95% CI, 0.01-1.41). This discrepancy in findings between inadequate and marginal groups is consistent with an earlier study92 in the 2004 report.1 Thus, the overall strength of evidence is low (Table 8 and Appendix F).

Mammography. Four cross-sectional studies examined use of mammography by health literacy group (Table 11).81,85,86,90 All studies found a lower use of mammography in the lower health literacy group compared with the adequate group. However, one study found a difference in receipt of mammograms among older women86 and another found differences between groups by frequency of mammograms.90 In the Prudential study, women ages 65 and older with low health literacy had a lower probability of having a mammogram than those with adequate health literacy (NR; P < 0.05); health literacy was not associated with the probability of having mammography among women ages 40 to 64.^86^ Another study evaluated mammography rates in 97 women in three community health clinics in Philadelphia; inadequate health literacy was associated only with significantly lower odds of ever having a mammogram (OR, 0.88; 95% CI, 0.79-0.98), but not with having a mammogram in the past year, past 3 years, or as part of a check-up.90 The strength of evidence is moderate (Table 8 and Appendix F). These results are consistent with the 2004 report.

Sexually transmitted infection testing. Researchers conducted a cross-sectional study (N = 372) of HIV test acceptors in an inner-city urgent care hospital (Table 12).93 Subjects with inadequate health literacy had greater odds of accepting an HIV test result than those with adequate health literacy (OR, 2.02; 95% CI, 1.19-3.42). In the 2004 report, the one study about this type of service showed a lower probability of having received a gonorrhea test in the past year among those in the low-literacy group.94 The strength of evidence is low (Table 8 and Appendix F).

Immunizations. One good cohort63 and three cross-sectional studies85,86,95 found inadequate health literacy associated with lower receipt of influenza vaccine (Table 13). In a Prudential study analysis, controlling for age, sex, race, ethnicity, education, income, site, morbidity, and smoking, researchers found lower odds of receiving an influenza vaccine in the inadequate health literacy group than in the adequate group (OR, 0.76; P = 0.020), but no significant differences in the marginal health literacy group compared with the adequate health literacy group.63 These findings are similar to those in our 2004 report. Age also appears to be a factor in a study86 that found a lower receipt of influenza vaccine by health literacy level among adults under 40 years of age and 65 or older (NR; P < 0.05), but no differences by health literacy level in adults 40 to 64 years of age (NR; P = nonsignificant [NS]). The strength of evidence is moderate (Table 8 and Appendix F).

Pneumococcal vaccine did not follow a pattern similar to influenza vaccine (Table 13). In the two studies that examined pneumococcal vaccine,63,86 no significant association between pneumococcal vaccine and health literacy level was found. The strength of evidence is insufficient (Table 8 and Appendix F).

Access to care. Four cohort62,68,96,97 and five cross-sectional studies82,86,95,98-100 examined various measures of access to office visits and general care; these types of services included pharmacy visits, dental visits, and vision checkups as well as hospital choice and transplant waitlists (Table 14). Two good cohort analyses from the Prudential study did not find an association of inadequate health literacy level with number of physician visits62 or pharmacy services used.68 These results are consistent with the one study101 described in the 2004 report. Similarly, one prospective cohort of 68 individuals did not find differences in time to follow up after an abnormal Pap test by health literacy level.96 However, results were mixed for dental and vision visits in one Prudential study analysis.86 Another large study (N =2,512) of Medicare recipients found less access to medical care by lower health literacy groups.95

One interesting retrospective cohort study involved 62 patients in five outpatient dialysis units in San Francisco, California.97 After controlling for multiple confounders, the investigators found a significantly longer time from start of dialysis to referral to a transplant list in patients with inadequate health literacy (hazard ratio [HR], 4.54; 95% CI, 1.67-12.5). However, they saw no subsequent differences in time from being on a transplant list to making the waitlist for transplant. The strength of evidence is insufficient given the variation among studies (Table 8 and Appendix F).

Access to insurance. One nationally representative cross-sectional study102 of 6,100 parents examined parental health literacy and their children's access to health insurance. After controlling for multiple confounders, the odds of having at least one child without health insurance in their household was higher among parents with below-basic literacy compared to parents with proficient health literacy (OR, 2.4; 95% CI, 1.1-4.9). The strength of evidence is low because there is only one study and there are biases associated with using self-reported measures as the outcome (Table 8 and Appendix F).

## Summary of Outcomes on Use of Health Care Services

Differences in health literacy level were associated with use of some health care services (Table 5). Specifically, lower literacy was associated with increased emergency department and hospital use, less screening for cervical cancer (through a Pap test) and breast cancer (mammography), lower influenza immunization, and less access to insurance. Evidence was mixed for pneumococcal immunization and access to office visits. The strength of evidence to support these findings was moderate for hospitalizations, emergency department visits, mammography, and influenza immunization. Evidence for other health care service use was low or insufficient because of inconsistent findings and outcomes.

### KQ 1b Health Outcomes

We identified 72 articles reporting on 60 unique studies examining the relationship between literacy skills and health outcomes. Of these, 13 articles were of good quality and 59 were fair quality.

Adherence. Eleven studies, reported in 15 articles, evaluated the relationship between health literacy level and adherence in adjusted analyses (Table 15).61,69-74,81,82,103-108

Five studies reported in 8 articles examined nonadherence in taking HIV medication and found mixed evidence of a direct relationship.69-72,82,103-105 Studies found no relationship examining 100 percent adherence to medications over 3 days among patients with a history of alcohol problems,105 90 percent adherence over the past 3 days among adolescents,82 and less than 95 percent adherence over the past 3 months among a small sample (N = 87) of clinic patients.104 In the last study, the relationship between health literacy level and nonadherence was examined, comparing the unadjusted relationship with an adjusted model, controlling only for the potential mediation of a patient's norms about an acceptable level of adherence and no potential confounding variables. Norms were found to mediate the relationship.

In contrast, in study using self-reported pill counts and controlling for education and other variables, researchers found a positive relationship between lower health literacy level (measured as a TOFHLA score of less than 90 percent correct rather than more commonly used categories) and probability of nonadherence (OR, 3.77; 95% CI, 1.46-9.93).103 Similarly, based on findings from a study of 204 patients in clinics in Shreveport, Louisiana, and Chicago, Illinois, researchers found a positive relationship: nonadherence to HIV regimen was higher among those with low health literacy than those with adequate health literacy (OR, 2.12; 95% CI, 1.93-2.32).69,72 However, this study found no difference between the marginal and adequate groups. In subsequent analyses of this sample, the researchers conducted formal mediation analyses and found that the relationship between low health literacy and nonadherence to HIV medications was mediated by the combination of HIV treatment knowledge and medication self-efficacy in one analysis69 and by stigma related to taking HIV medications in another.71

Medication-taking adherence, refill adherence, and adherence to procedural instructions were examined in various other patient populations with mixed results. Among 110 caregivers of infants in pediatric clinics, a combined group of those with low or marginal health literacy were significantly more likely to be adherent in providing vitamins to their infants than those with adequate health literacy (OR, 2.4; 95% CI, 1.37-4.2).108 However, no significant differences by health literacy level emerged in other patient populations for medication-taking, refill adherence, or adherence to procedural instructions. Studies included patients at an anticoagulation clinic missing doses of warfarin,106 seniors at two clinics filling any medication prescriptions on time,81 seniors refilling medications for cardiovascular disease,61 preoperative clinic patients following fasting and preoperative medication instructions,107 and adults reporting adherence at hospital pharmacies in Atlanta, Georgia.74 However, in the Atlanta study, researchers found that the relationship between health literacy and adherence was moderated by social support; at the highest levels of social support, patients with adequate health literacy reported better adherence, and, at the lowest levels of social support, patients with lower health literacy reported better adherence.74

Three studies examining the relationship between health literacy level and adherence assessed outcome differences between individuals in the marginal- and adequate-health-literacy groups but found no significant difference.61,69-72,105

Our research team found mixed evidence of a relationship between health literacy and health outcomes resulting in a strength of evidence grade of insufficient, which may be the result of differences in adherence measure, disease state, and adjustment for relevant confounders (Table 16 and Appendix F). Our earlier review also found mixed results across studies. One study reported a significant relationship between lower literacy and poorer self-reported adherence; three found no significant relationship.109-112

Self-efficacy. Five studies examined the relationship between participant health literacy level and self-efficacy for a variety of behaviors70,82,87,113,114 (Table 17). One study found greater self-efficacy for taking HIV medications in the adequate-health-literacy group than in the low-health-literacy group, but no difference between the adequate and marginal groups.70 A second study found greater self-efficacy for colorectal cancer screening among individuals with higher health literacy levels (measured by the UK TOFHLA).114 In contrast, another study found no difference between groups in relation to self-efficacy for taking medications or keeping appointments among adolescent HIV patients.82 Furthermore, self-efficacy for obtaining a fecal occult blood test or colonoscopy was not related to limited health literacy level (low and marginal groups combined) compared with a group with adequate literacy in a small, potentially underpowered adjusted analysis of 99 patients at one clinic.87 Finally, although higher self-efficacy for taking hormone therapy among postmenopausal women was correlated with higher health literacy level, this was in an unadjusted analysis.113

Based on the mixed results in these studies, our research team graded the strength of evidence as insufficient (Table 16 and Appendix F). Our earlier review included no self-efficacy studies.

Health Behaviors. We identified studies reporting on a variety of health behaviors including smoking, alcohol and drug use, healthy lifestyle, review of prescription information, HIV risk behaviors, and sexual activity.

Smoking. Two large studies evaluated the relationship between health literacy level and self-report of smoking in adjusted analyses (Table 18); results were statistically different even though odds ratios were fairly similar.64,115 A study examining current smoking status in a national sample of British adults (N = 719) found that higher health literacy, measured as a continuous variable, was associated with a small increased likelihood of not smoking (OR, 1.02; 95% CI, 1.003-1.03).115 In contrast, among the Prudential sample of American seniors (N = 2,923), researchers found no relationship between health literacy level and participants' smoking status (never, former, or current).64 Due to these mixed results, the strength of evidence was graded as insufficient (Table 16 and Appendix F). We reported mixed results in our earlier review through one adjusted analysis of adolescents (boys and girls reported separately) and two unadjusted analyses examining outcomes of smoking in adults; therefore, these studies do not modify our evaluation of the strength of evidence.116-118

Alcohol and drug use. The Prudential study also examined the relationship between health literacy level and current alcohol consumption; they found no relationship.64 Among adolescents with HIV, higher health literacy was associated with greater substance use.82 Neither study adjusted for comorbid depression. With only one study concerning alcohol consumption and one concerning substance use, strength of evidence was graded as insufficient (Table 16 and Appendix F). In our earlier review, we included one study of alcohol consumption among adolescents and no significant relationship with health literacy was found.118

Healthy lifestyle. Eight studies addressed the relationship between health literacy level and various measures of healthy lifestyle, including level of physical activity, eating habits, seat belt use, and weight9,10,64,65,81,95,115,119 (Table 18).

Two studies, discussed above for smoking outcomes, measured level of physical activity. Neither study found significant differences by health literacy level.64,115

Healthy eating, overall healthy lifestyle, and seat belt use were examined in one study each. In a sample of British adults, higher health literacy level was associated with a small but significantly higher probability of eating five or more servings of fruits or vegetables per day (OR, 1.02; 95% CI, 1.003-1.03).115 Among 489 seniors receiving care at two clinics in Chicago, health literacy level did not have a direct effect on a composite measure, the Health-Promoting Lifestyle Profile, which assesses a combination of exercise, nutrition, and health responsibility.81 Only one unadjusted analysis examined the relationship between health literacy level and seat belt use. The researchers found no significant differences.64

Among obese children, body mass index (BMI) was inversely related to the child's health literacy level, controlling for their parent's health literacy level and other confounders.119 Four additional studies examined differences in rates of obesity or BMI by health literacy level in unadjusted analyses.9,10,65,95 Results were mixed.

The research team judged the strength of evidence as insufficient (Table 16 and Appendix F) for the relationship between health literacy and physical activity, eating habits, and seat belt use as a group based on mixed findings. The strength of evidence concerning weight or obesity was also insufficient (Table 16 and Appendix F). Our earlier review included no studies with any healthy lifestyle outcomes.

Review of prescription information. One adjusted analysis examined the relationship between health literacy and review of prescription information (Table 18). Clinic patients (N = 251) in Shreveport, Louisiana, were asked to report on whether they ever looked at the consumer information included with their prescriptions.120 After controlling for potential confounders, including the number of prescriptions taken, those with low health literacy were less likely to look at the material than persons of adequate health literacy (OR, 2.5; 95% CI, 1.2-5.2). The marginal- and adequate-health-literacy groups did not differ. The strength of evidence was low (Table 16 and Appendix F).

HIV risk behaviors and sexual activity. Two adjusted analyses examined the relationship between health literacy and sexual behaviors (Table 18). One study of female inmates did not find a relationship between health literacy level and HIV risk behaviors (sex without a condom or sharing injecting equipment), controlling for age, race, and problem drinking.121 A large study of adolescents and young adults (N = 4,751) in Cape Town, South Africa, found that higher literacy level (measured using the Cape Area Panel Study Literacy and Numeracy Evaluation) was associated with a lower probability of sexual debut but not first pregnancy, controlling for socioeconomic variables.122 The research team judged the strength of evidence to be insufficient based on mixed findings (Table 16 and Appendix F). Our earlier review included no studies with these outcomes.

Health care-related skills. Eleven studies reported in 13 articles included outcomes concerning a variety of health care-related skills (Table 19). Among these were appropriate medication use;47,123-127 interpreting prescription medication, nutritional labels, and health messages;9,75-77,102,128 and asthma self-care skills.79

Taking medications appropriately. Three studies directly observed whether participants could take prescription medications appropriately; their results generally found a relationship with health literacy level. In one study we rated good quality, researchers required 152 coronary heart disease patients to perform four tasks relating to their medication: identify the appropriate medication, open the container, select the correct dose, and report the appropriate timing of doses.123 The researchers found no difference across health literacy levels in patients' scores from completing all four tasks in an unadjusted analysis. However, after controlling for age, education, and cognitive functioning, low health literacy (but not marginal health literacy) was associated with poorer performance on one of the tasks—being less likely to identify all of one's medications (OR, 12.00; 95% CI, 2.57-56.08). Using a similar approach, a second team of researchers conducted a mock exercise concerning successful medication management (Medication Management Test) among HIV-positive patients.47 Patients with higher health literacy scored significantly higher in an adjusted analysis. Similarly, in a small sample of seniors in Texas (N = 57), researchers found that lower health literacy (measured continuously) was associated with poorer ability to open and take one's own medications, in adjusted analysis.124

Three additional adjusted analyses examined other measures of whether patients take medications properly, the first through self-report, the second through direct observation, and the third through biologic test results, and found limited evidence of a relationship with health literacy level.125-127 One study examined whether health literacy level was associated with parents' use of nonstandardized dosing instruments (such as kitchen spoons) when providing medications to their children; they found no relationship in an analysis adjusting for all identified potential confounding variables.125 However, after removing from the adjusted analysis only the variables in the analysis that were confounded with health literacy level (caregiver's education, country of origin, language, and socio-economic status), participants with marginal/inadequate health literacy (combined into one group) were more likely to use nonstandardized instruments than those with adequate health literacy (OR, 1.9; 95% CI, 1.0-3.5). In a second study, researchers tested parents' health literacy level using the Newest Vital Sign and evaluated whether they made dosing errors using common dosing instruments (i.e., dosing cups, droppers, dosing spoons, and syringes).127 Parents with a high likelihood of limited health literacy and those with possible limited health literacy were significantly more likely to make a dosing error (greater than 20 percent deviation) than parents with adequate health literacy, in adjusted analyses; parents with a high likelihood of limited health literacy were significantly more likely to make a large dosing error (greater than 40 percent deviation). One study examined warfarin control measured by international normalized ratio (INR) variability. Results did not differ by health literacy level, controlling only for age, in a population of adults 50 years of age and older.126

Interpreting labels and health messages. Two studies examined participants' ability to interpret labels (prescription medications and nutrition); both found a positive relationship with health literacy level. One study among 395 adult patients in three primary care clinics in Shreveport, Louisiana, Jackson, Michigan, and Chicago, Illinois, examined interpretation of prescription medication labels.75-77 Participants demonstrated their ability to understand prescription label instructions by describing to physicians how they would take five medications in adjusted analyses, those with inadequate health literacy (RR, 2.32; 95% CI, 1.26-4.28) as well as those with marginal health literacy (RR, 1.94; 95% CI, 1.14-3.27) had a greater probability of misunderstanding one or more label instructions than those with adequate health literacy.75 A further (unadjusted) examination of participants' correct interpretation of each of the five primary labels found significant differences in interpretation of four of five primary medication labels. They also found differences in whether participants attended to auxiliary labels in two of five comparisons.76 Lastly, researchers found in an adjusted analysis that those with lower health literacy (less than high school level) were less likely to understand nutrition labels.9

One study examined health literacy and the ability to give an organized oral health narrative. Among a community sample of mothers of young children in Nepal, higher literacy level was associated with greater ability to give an organized health narrative (a skill associated with higher oral health literacy) in an adjusted analysis.128

Asthma self-care. One study examined self-care skills relating to asthma among hospitalized adults.79 In adjusted analysis, those with inadequate health literacy, compared with those with adequate literacy, were less likely to have mastery of their dose inhaler (OR, 0.29; 95% CI, 0.08-1.00). We had found a similar result in our earlier review.129

Health care-related skills strength of evidence. The research team separately determined that the strength of evidence concerning taking medications appropriately and interpreting labels and health messages was moderate and the strength of evidence concerning asthma self-care was low (Table 16 and Appendix F). Our earlier review included one health-care-related skills study concerning asthma self-care. 129

Disease prevalence and severity. We found multiple studies examining the relationship between health literacy level and disease prevalence (specifically, mental health diagnoses and chronic conditions) or disease severity (specifically, HIV, asthma, diabetes, hypertension, and prostate cancer).

Mental health outcomes. Eight of ten studies evaluating the relationship between depression and health literacy level found that patients with lower health literacy were more likely to have symptoms of depression or to be considered depressed; however, the majority of studies controlled for a limited number or no potential confounders.68,95,103,130-135 One additional study examined the relationship between health literacy level and psychological distress82 (Table 20). In the most rigorous study of depression (a prospective cohort conducted among 390 patients receiving inpatient detoxification from alcohol and substance abuse), depression symptomatology did not differ between health literacy groups at baseline, but was higher among those with lower health literacy at 2-year followup, controlling for a number of potential confounders including sociodemographic characteristics, primary substance of choice, and mental state.130 Other analyses were conducted among subpopulations with limited adjustments for potential confounders. One reported that depression was greater in the lower-health-literacy group among HIV-positive adults in five urban clinics, controlling for Hispanic nationality.131 A second reported that depression was also greater among pregnant patients with lower (but not marginal) health literacy, controlling for Mexican nativity and marijuana use.132 Finally, a third that depression scores were higher among recent Spanish-speaking immigrants in the low-health-literacy groups, controlling for a scale measuring the demands of immigration.135 In unadjusted analyses, lower health literacy was also related to depression among rheumatology and diabetes patients133,134 and among seniors in two community samples.68,95 However, no difference by health literacy level was found among HIV-positive patients in Atlanta.103 In relation to psychological distress, differences were not found by health literacy level among HIV-positive adolescents.82

The research team judged the strength of evidence to be low because, although studies generally found consistent results, only one rigorously controlled for potential confounders (Table 16 and Appendix F). Results of studies evaluating differences in depression across different levels of health literacy in our earlier review were mixed, including among the two studies that controlled for potential confounders.136-140

Chronic disease outcomes and prevalence. Three studies examined differences in rates of chronic disease (defined in a group as any long-term illnesses) by health literacy level (Table 21).9,65,141Four additional studies examined differences in rates of specific diseases by health literacy level.66,68,95,142,143

Using the large, nationally representative NALS (N = 23,889), researchers found that lower health literacy was associated with higher odds of having a long-term illness (one lasting more than 6 months) and greater odds of having a condition that would keep the individual from working after controlling for various sociodemographic characteristics including education.141 In other studies with unadjusted analyses, the number of chronic conditions among seniors and the percentage with a chronic disease among adults in a clinic population did not differ by health literacy level.9,65

Three studies, discussed in four articles, examined differences in rates of specific diseases by health literacy level; one used a well-designed adjusted analysis and the others used unadjusted analyses.66,68,95,142 All analyses were limited to senior citizens. In adjusted good-quality analyses of the Prudential sample, inadequate compared with adequate health literacy was associated with significantly higher rates of diabetes and heart failure, but not with higher rates of hypertension, coronary heart disease, bronchitis, asthma, arthritis, or cancer.66 In contrast, the investigators found no differences in rates of specific diseases between those with marginal and adequate health literacy. Potential limitations of this analysis are that respondents' outcomes are self-reported shortly after joining the health plan and differences in prior access to care may have resulted in differences in knowledge concerning their disease state. Also, by testing multiple outcomes, significant differences were more likely to be found in at least some of the comparisons. Two unadjusted analyses measured the probability of differences in prevalence of chronic disease across three health literacy levels; however, their design was insufficient to determine if differences existed between any two groups (inadequate compared with adequate or marginal compared with adequate).68,95 A third unadjusted analysis among seniors in Korea found that health literacy was associated with significantly higher rates of arthritis and hypertension, but not sensory disease, diabetes, or pulmonary or heart disease.142

Among individuals with diabetes, heart failure rates were higher in the limited health literacy group in one bivariate comparison.143

Overall, the body of evidence found mixed results and was limited by differences in outcomes across studies with the majority of studies not controlling for potential confounders. Given these issues, the strength of evidence was graded insufficient (Table 16 and Appendix F). Our earlier review found one study of children with migraines and no relationship was found.144

HIV infection severity and symptoms. Three adjusted and one unadjusted analyses of individuals with HIV did not find differences in severity of HIV (measured by viral load suppression, CD4 cell counts, and number of HIV symptoms) by health literacy level (Table 22).82,103,105,145 In contrast, higher health literacy was associated with greater symptom intensity in one study controlling only for Hispanic ethnicity.131 In this study, health literacy was measured as a continuous variable among a population with relatively high health literacy (REALM mean score = 59.1). Even though four of five studies found no relationship, the research team evaluated the strength of evidence as low because these studies included limited control for confounding and had small sample sizes (Table 16 and Appendix F). Our earlier review was limited to unadjusted analyses and found mixed results.138,146,147

Asthma severity and control. The relationship between health literacy and asthma severity of children was examined in two studies reporting a mix of adjusted and unadjusted analyses (Table 23).80,84 Both studies measured asthma severity by parent report. In one, an adjusted analysis concluded that lower-health-literacy parents of children with asthma were more likely to report that their children were in fair or poor health; however, in an unadjusted comparison, these same parents' reports of their children's asthma control did not differ by health literacy level.84 In a different unadjusted analysis, parents with lower health literacy reported greater use of albuterol (a bronchodilator) by their children, indicating poorer asthma control.80 Overall, the strength of evidence was insufficient (Table 16 and Appendix F).

Diabetes control, complications, and related outcomes. Five adjusted studies examined the relationship between glycosylated hemoglobin (HbA1c) level and health literacy level and found mixed results (Table 24).134,148-151 One good-quality study measuring the HbA1c levels in 1,002 diabetic adults in Vermont found no relationship with health literacy level after measuring health literacy as a continuous variable using the TOFHLA and controlling for demographic characteristics and several factors related to successful diabetes control, such as duration, diabetes education, medication, and alcohol use.134 Similarly, a second good-quality study conducted with diabetic patients in the Midwest also found no relationship between HbA1c and health literacy levels after controlling for different factors related to successful diabetes control including patient trust, depression, diabetes knowledge, and performance of self-care activities. The lack of a finding of association between health literacy and the outcome may be due to over-adjustment given that researchers controlled for potentially mediating variables in this analysis.151 In contrast, a very small study (N = 68) from one general internal medicine clinic found significant differences in HbA1c between the four health literacy levels; each increasingly higher level of health literacy, however, was not associated with better control.149 In a good-quality study, using a path analysis statistical technique and controlling for potential confounders, researchers found that higher health literacy was related to better glycemic control and that health literacy mediated the direct relationship between education and HbA1c level.150 Also, in a study conducted in Hong Kong, higher-health-literacy diabetic patients had better glycemic control.148

The large study of diabetic patients in Vermont, did not find health literacy level to be related to blood pressure, cholesterol level, or the probability of having other potential side effects of poor diabetes control (retinopathy, nephropathy, foot or leg problems, gastroparesis, cerebrovascular disease, or coronary artery disease) after adjusting for confounders.134

The strength of evidence relating to diabetes outcomes from this review was insufficient (Table 16 and Appendix F). In our earlier review, diabetes-related results were mixed.129,152,153

Hypertension control. Two studies examined blood pressure control among patients diagnosed with hypertension; results were mixed (Table 25).154,155 The larger study (N = 1,224), measuring health literacy using the REALM, did not find a significant main effect between systolic blood pressure and health literacy level (limited compared to adequate), controlling for education level, diabetes status, medication adherence, smoking, exercise, and participatory decisionmaking.154 However, the interaction between health literacy and health care system was significant, indicating that the relationship between blood pressure and health literacy differed in the Veterans Administration vs. the private health care system. A second analysis (N = 330) measured health literacy using the S-TOFHLA subdivided into five categories and found that those in the lowest category were less likely than those in the highest category to have controlled blood pressure (less than 140 mmHg systolic and less than 90 mmHg diastolic [or less than 130 mm Hg systolic and less than 80 mm Hg diastolic among those with diabetes] RR, 2.68; 95% CI, 1.54-4.70) after controlling for sociodemographic characteristics, education level, insurance status, number of comorbid conditions, and years treated for hypertension.155 In this study, the percentage of patients with controlled blood pressure was not consistently larger with every category of increasingly higher health literacy, and only some comparisons between various other health-literacy-level groups were significantly different. Based on mixed results, the research team judged the strength of evidence to be insufficient (Table 16 and Appendix F). Our earlier review did not find a relationship in hypertensive patients between blood pressure control and health literacy level in an adjusted analysis from the one study reviewed with this outcome.156

Prostate cancer control. Prostate cancer patients with low health literacy (sixth grade or less) were more likely than those with adequate health literacy (ninth grade or higher) to have an elevated prostate-specific antigen (PSA) level in an adjusted good-quality study (OR, 2.5; 95% CI, 1.5-4.2) (Table 26).157 In contrast, the marginal-health-literacy (seventh or eighth grade) group and the functional-health-literacy group did not differ. With only a single study, the strength of evidence was low (Table 16 and Appendix F). In our earlier review, stage of presentation of prostate cancer did not differ by health literacy level, in an adjusted analysis.158

Global health status measures. Twelve studies reported in 14 articles examined health status differences by health literacy level among a variety of populations, including all adults, seniors, and adults with various specific disease states (Table 27).63,65,66,81,85,95,100,131,142,159-163 Health status was measured using an assortment of measures, including self-report of overall health status (excellent/very good/good/fair/poor) and physical and mental health subscales of the 12-Item Short Form Health Survey (SF-12) and SF-36, among others.

Only one study measured self-reported health status among all adults (ages 18 to 85).159 Limited to one clinic population in Canada, this work indicated that self-reported health status was not related to health literacy level after adjustment for confounders. With only a single study, the strength of evidence was low (Table 16 and Appendix F). Our earlier review found similar results in two adjusted analyses.101,164

In studies limited to senior citizens, five studies, reported in six articles, all found differences in self-reported health status by health literacy level.63,81,85,95,142,160 Within a nationally representative sample (N = 2,668), one good-quality study reported that lower health literacy level measured through the NAAL was related to poorer self-reported health status, after adjusting for potential confounders.85 Self-reported health status was also poorer in lower health literacy groups in three additional adjusted analyses: among Medicare patients in Chicago, Illinois,81,160 in the Prudential study comparing differences between the low- and adequate-literacy groups (but not marginal- and adequate-literacy groups),63,65 and among older Korean adults.142 The relationship was also found in one unadjusted analysis of 2,512 seniors in Pittsburgh, Pennsylvania, and Memphis, Tennessee.95 The research team judged the strength of evidence to be moderate (Table 16 and Appendix F). In our earlier review, one unadjusted analysis from the Prudential study also found poorer overall health status among those with lower health literacy.165

Three of the studies limited to seniors reported additional health status measures and results were mixed. In adjusted analyses, the Prudential study found lower health literacy to be associated with poorer physical- and mental-health-related quality of life and physical functioning in both the inadequate- and the marginal-literacy groups (SF-36) compared with the adequate group.63,65,66 In contrast, a sample of Medicare beneficiaries in Chicago, Illinois, was not found to differ in physical or mental functioning by health literacy level.160 One of these two studies, the Prudential study, also found that persons with inadequate health literacy had higher probabilities of having activity limitations, fewer accomplishments, and greater pain related to physical health than those with adequate health literacy.66 Among Korean seniors, physical functioning (SF-12) did not differ by health literacy level in adjusted analyses, but significant differences were found in limitations in activities and pain that interfered with normal work.142 Given mixed results, the research team judged the strength of evidence to be insufficient (Table 16 and Appendix F).

Five studies examined differences in a variety of health status measures in adult populations with various diseases, including persons who were HIV-positive131 and patients with glaucoma,161 asthma,100 spinal cord injuries,162 and cancer.163 No more than one study examined each disease state, and results were mixed by disease state and outcome measure (e.g., general health, physical health, mental health, disease-specific quality of life). In HIV patients, better global physical health (using a scale developed by the researchers) was related to lower health literacy.131 In glaucoma patients, those with lower health literacy had poorer physical, but not vision or mental, quality of life based on quality-of-life scores.161 Among patients with spinal cord injuries, lower health literacy was associated with poorer physical morbidity, but not with mental health morbidity, physical health, or mental health status (SF-12).162 In cancer patients of all types, Functional Assessment of Cancer Therapy scores (related to physical and emotional functioning) and general health scores measured by the SF-36 showed no difference by health literacy level.163 In asthma patients, lower health literacy was associated with poorer asthma quality of life (Asthma Quality of Life Quotient) and physical health status (SF-36), adjusting for asthma severity and asthma self-sufficiency.100 However, the relationship with both outcomes was no longer significant after the investigators added age, education, depressive symptoms, and knowledge confounders to their analyses. Based on mixed results, the research team judged the strength of evidence as insufficient (Table 16 and Appendix F). In our earlier review of studies of global health measures, two unadjusted studies found no significant relationship.139,166

Mortality. Differences in all-cause mortality rates of seniors were related to health literacy in adjusted analyses in two good-quality studies reported in three articles (Table 28).65,67,167 The Prudential study reported higher mortality rates in the inadequate health literacy group than in the adequate health literacy group—first in an analysis controlling for cognitive functioning67 and second in an analysis not controlling for cognitive functioning but instead controlling for baseline measures of disease, physical functioning, and healthy lifestyle.65 Both analyses did not find significant differences between the marginal- and the adequate-health-literacy groups. In a population of seniors in Pittsburgh, Pennsylvania, and Memphis, Tennessee, those with limited health literacy had a higher all-cause mortality rate than those with adequate health literacy.167 The Prudential study also reported, in adjusted analyses, higher cardiovascular-related mortality in the inadequate- and marginal-health-literacy groups than in the adequate group, but no differences in cancer-related mortality across health literacy levels.65 The research team graded the strength of evidence as high (Table 16 and Appendix F). No studies examining the association between health literacy and mortality were included in our earlier review.

## Summary of Outcomes and Strength of Evidence on Health Outcomes

The effect of health literacy on health outcomes was variable (Table 16). The risk of mortality for seniors was clearly higher with lower health literacy. The strength of evidence to support this finding was high. There was also moderate strength of evidence to support a relationship between lower health literacy and poorer ability to take medications properly, poorer ability to interpret labels and health messages, and poorer overall health status among seniors. In these studies, the evidence consists of all observational studies generally having a medium risk of bias and results generally in a consistent direction. The strength of evidence for all other outcomes was either low or insufficient because the literature consisted of a small number of studies, poorly designed studies, and/or inconsistent results. Strength of evidence evaluations focused on the relationship between the lowest health-literacy group and the highest. The evidence was sparse for evaluating differences between those with marginal (a middle category) health literacy and adequate (the highest category) health literacy. In unreplicated studies, evidence is beginning to emerge that the effect of health literacy on health outcomes may be moderated by social support or the characteristics of the health care system and that it may be mediated by knowledge, patient self-efficacy, and stigma. In addition, health literacy may mediate the effect of education, income, and urbanicity.

### KQ 1c Costs of Health Care

KQ 1c concerns differences in health literacy level and costs of health care (Table 29). The Prudential study of new Medicare managed care enrollees examined costs over a 1-year period. In adjusted analyses, inadequate- and marginal-health-literacy groups had higher emergency department costs; however, no other patterns of differences were uncovered in relation to overall, inpatient, outpatient, or pharmacy costs.68 In contrast, total Medicaid costs were higher in the lower literacy group (less than third grade) among a small sample of beneficiaries in Arizona (N = 74).168 Our earlier review found no relationship between literacy and Medicaid costs.169

In summary, the strength of evidence concerning differences by health literacy level in costs of health care (KQ 1c) was insufficient (Table 30 and Appendix F). The two relevant studies examined different payment sources (Medicaid and Medicare), found inconsistent results, and included different patient populations. No studies examined differences in costs among those with private health insurance coverage or no coverage.

### KQ 1d Disparities in Health Outcomes or Health Care Service Use

Eight studies examined whether health literacy mediates the relationship between race/ethnicity and health outcomes or use of health care services, and one study examined whether health literacy moderates the effect between race/ethnicity and health outcomes (Table 31). As described in more detail in Chapter 2, health literacy would be considered a mediator of racial differences in health outcomes, if differences in health literacy level between racial groups explain all or a portion of the outcome differences observed by race. Analytically, health literacy level is determined to be a mediator when health literacy is related to race or ethnicity and an outcome and when the coefficient for the race or ethnicity variable is smaller or becomes statistically insignificant after health literacy is added to the analytic model. Alternatively, the relationships can be observed through a path analysis.170 Health literacy was found to mediate the effect of race on a variety of health outcomes in a variety of populations: on health conditions that keeps respondents from working and having a long-term illness in a nationally representative sample of adults included in the NALS,141 on self-reported health status and receipt of an influenza vaccine among seniors included in the nationally representative NAAL sample,85 on physical and mental-health-related quality of life and self-reported health among seniors included in the Prudential study,63 PSA levels among newly diagnosed prostate cancer patients in Chicago,157 on nonadherence to HIV medications in a population of HIV patients,69 on child health insurance among parents included in the NAAL sample,102 and misinterpretation of medication label instructions among adults.77 The relationship was not found in relation to receipt of a mammogram or a dental checkup or parents' difficulty understanding over-the-counter medication labels in the NAAL study,85,102 rate of receipt of vaccines in the Prudential study,63 or glycemic control in diabetic adults.171

Only the NAAL study examined whether health literacy mediated the effect of ethnicity (Hispanic vs. white) on a health outcome, and this relationship was not found.85 In contrast, only the study examining misinterpretation of medication label instructions in adults investigated whether health literacy was also a potential mediator of the relationship between gender and the outcome, as well as race; the relationship was found in this comparison as well.77

Health literacy is determined to be a moderator of the relationship between race/ethnicity and health outcomes when the relationship is different in magnitude or direction between the two race/ethnicity groups. Only one study examined moderation and found no differences in the relationship between mortality and health literacy level in blacks and whites or males and females.167

The strength of evidence was low in relation to health literacy level explaining racial differences in health outcomes based on findings of effect in some outcomes (Table 32 and Appendix F). The strength of evidence was low in relation to health literacy level explaining differences in health outcomes between Hispanics and whites and between males and females (Table 32 and Appendix F). Data were not available to examine disparities related to cultural or age group differences. In our earlier review, only one study was available to examine this issue, and it did not find that health literacy was a mediator of differences between black and white patients in late-stage prostate cancer diagnosis.158

In summary, our research team found that health literacy mediates or partially explains disparities in health outcomes between white and black participants for a variety of outcomes; the strength of evidence for this conclusion is low because only one study examined each outcome (Table 32 and Appendix F). Health literacy was found to mediate outcome differences between blacks and whites in relation to the following outcomes: a health condition that keeps respondents from working or having a long-term illness, self-reported health status, receipt of an influenza vaccine, physical and mental-health-related quality of life, self-reported health among seniors, prostate-specific antigen levels among newly diagnosed prostate cancer patients, nonadherence to HIV medications, children's lack of health insurance, and misinterpretation of medication labels. We cannot know whether health literacy level would also mediate racial disparities for other health outcomes that have not been tested. Only one study examined whether health literacy level mediated the relationship between race and health outcomes for persons of Hispanic ethnicity and whites, and one study examined the relationship between males and females. The strength of evidence for these relationships was low. We found no studies that evaluated disparities related to differences in age, cultural group, or other sociodemographic characteristics.

### Key Question 1 Relationship of Numeracy to Various Outcomes and Disparities

We identified 16 unique studies of the relationship between numeracy and outcomes of interest (Table 33). Nearly all studies examining the relationship of numeracy to health outcomes were cross-sectional in design.9,10,24,47,98,125,171-179 Four studies were randomized controlled trials (RCTs) that analyzed their data in a cross-sectional manner for this analysis,24,98,172,173 and one used a prospective cohort design.126 Fifteen studies were of fair quality; only one was of good quality.171

Studies employed a wide variety of numeracy measures. These included the WRAT-3, the Lipkus numeracy test, the Schwartz and Woloshin numeracy test (or adaptations thereof), the Diabetes Numeracy Test, the Black and Toteson numeracy test (or adaptations thereof), and the TOFHLA numeracy test. Using these measures, populations studied had a varying proportion of individuals with low numeracy (ranging from 5 percent to 74 percent).

Studies also examined a wide variety of outcome measures. Among them were the accuracy of the use of health care services, accuracy of risk perception, knowledge, self-efficacy, actual behaviors, skills, disease prevalence and severity, and disparities. No studies measured intent for behavior, adherence, quality of life, or costs.

Six studies measured both literacy and numeracy.9,47,98,125,126,171 This allowed assessment of whether these exposures affect health outcomes differently.

### KQ 1a Use of Health Care Services

One cross-sectional study178 examined the effect of numeracy on use of health care services (Table 34). This study178 focused on the effects of numeracy on use of screening services.

Screening services. In adjusted analyses, researchers reported no effect of numeracy level on up-to-date screening for either breast or colon cancer in women presenting for primary care.178 However, the sample for colon cancer screening was small (N = 152; 58 percent of the total sample due to age ineligibility for screening for colon, but not breast cancer), and the authors provided no power calculations for either analysis.

Summary. In summary, only one study addressed the relationship between numeracy and use of health care services and reported no effect, possibly due to inadequate power. Based on this study, our research team judged the strength of the evidence for the relationship between numeracy and use of health care services to be low (Table 35 and Appendix F).

### KQ 1b Health Outcomes

Accuracy of risk perception. Five studies addressed the effects of numeracy level on accuracy of risk perception (i.e., whether individuals correctly perceived their health risks and treatment benefits) (Table 36). Three were RCTs24,172,173 and two were cross-sectional studies,173,176 although all analyzed their data in cross-sectional fashion to answer this question. Two examined the effects of numeracy on the accuracy of perceived risk175,176 and four on the accuracy of perceived treatment benefit.24,172,173,176 All used the Schwarz and Woloshin 3-item numeracy test to assess numeracy level.

The two studies examining perceived risk found no effect of numeracy level on the accuracy of perceived risk of breast cancer or breast cancer survival over 5 years.175,176 One study, however, reported that for every additional numeracy question answered incorrectly (scale range 0-3), participants' error in estimating lifetime risk increased by 18 percent (95% CI, 5-30%).175

Four studies examined the effect of numeracy on the accuracy of perceived treatment benefit and found mixed results. Three studies reported lower accuracy of perceived treatment benefit at lower levels of numeracy (0-1 questions correct vs. 3 questions correct).24,172,173 Notably, the size of the effect was smaller in the one study that adjusted for covariates including age, income, education, and the framing of information about treatment benefit (e.g., relative risk reduction or absolute risk reduction).24 The fourth study, which also performed adjusted analysis, reported no significant difference between groups,176 but the authors dichotomized their numeracy exposure variable differently (0-2 questions correct vs. 3 of 3 questions correct).

Interestingly, results varied across studies by how the investigators assessed accuracy. The differences in accuracy of perceived treatment benefit were greater between low- and high-numeracy participants who were asked to calculate an exact treatment benefit than between those who were asked merely to say which of two treatments provided more benefit.172,173

Considering all of these studies in aggregate, our research team judged the overall strength of evidence about the relationship between numeracy and accuracy of risk perception to be insufficient due to mixed results by task and study (Table 35 and Appendix F).

Knowledge. We found four cross-sectional studies addressing the effect of numeracy level on knowledge (Table 37).125,174,177,178 These focused on different types of knowledge as well as different health topics and conditions, including diabetes,174 general health and HIV,177 breast and colorectal cancer screening guidelines,178 and medication dosing.125 Results were mixed.

Three studies,174,177,178 including two that adjusted for relevant covariates,177,178 showed significantly lower knowledge about diabetes, HIV, and breast cancer screening with lower numeracy. These same studies, however, showed no effect of numeracy on general health knowledge or colorectal cancer screening, although nearly half of the sample queried about colorectal cancer screening included individuals who were too young to be eligible for screening. A fourth study showed lower numeracy to be related to lower knowledge about medication dosing in an analysis controlling for some confounders;125 however, results became nonsignificant after additional adjustment for education, acculturation, and socioeconomic status.

Considering these studies in aggregate, our research team judged the overall strength of evidence regarding the relationship between numeracy and knowledge to be insufficient (Table 35 and Appendix F).

Self-efficacy. One cross-sectional study examined the effects of numeracy level on self-efficacy (Table 38).174 In an unadjusted analysis, this study found significant reductions in self-efficacy (a 4-point reduction on the Perceived Diabetes Self-management scale ranging from 8 to 40) among those who scored in the lowest vs. the highest quartile of the Diabetes Numeracy Test. Based on this single unadjusted analysis, the overall strength of evidence about the relationship between numeracy and self-efficacy was insufficient (Table 35 and Appendix F).

Intent for behavior. We found no studies that examined the effect of numeracy on intent for behavior.

Behavior. One cross-sectional study examined the effects of numeracy level on behavior (Table 39).174 In unadjusted analysis, this study found no significant differences in diabetes self-management behaviors in four of five domains of the Diabetes Self-Care Activities Scale, including general diet behavior, specific diet behavior, exercise behavior, or blood glucose testing. However, there were small increases in foot care behavior (+2.25 on a scale of 0-7; P < 0.001) among those in the lowest vs. highest quartile of numeracy; these unexpected results (as well as the negative results for analyses of other self-care behaviors) may be the result of confounding. Based on this single unadjusted analysis, our research team judged the overall strength of evidence about the relationship between numeracy and self-efficacy to be insufficient (Table 35 and Appendix F).

Health-related skills. Six studies examined the effects of numeracy level on health-related skills (Table 40). One was a cohort study,126 four were cross-sectional studies,9,47,125,179 and one was an RCT that analyzed data in cross-sectional fashion.98 The skills included taking medication, reading nutrition labels, and assessing health plan materials.

The four studies that focused on skills in taking medication found mixed results. In analyses adjusted for age, one found mixed effects of numeracy on two different but related variables denoting medication-taking skill: the proportion of INR tests within range (adjusted absolute difference, NR; P = 0.35) and INR variability (adjusted absolute difference, NR; P = 0.03).126 Other studies measured medication-taking skill more directly and still found mixed effects. One study found a relationship between numeracy and HIV medication management capacity after adjusting for gender, education, health literacy, and time since HIV diagnosis (0.5-point increase in Medication Management skill [range 2-16] for every 1-point increase in the Applied Problems subtest of the Woodcock Johnson Test; P < 0.01).47 Another study reported that, after adjustment for some confounders, poor caregiver numeracy resulted in use of nonstandardized dosing instruments for administering medications to children.125 Additional adjustment for education, acculturation, and socioeconomic status, however, led to nonsignificant differences between groups, based on TOFHLA numeracy scores split at the median. Finally, a third study found that poor caregiver numeracy (second through eighth grade on the WRAT-math) was associated with (1) an increased likelihood of thinking a potentially harmful over-the-counter medication to be suitable (adjusted OR, 1.25; 95% CI, 0.99-1.58), although results were not statistically significant, and (2) increased intent to use potentially harmful over-the-counter cold medicines in a 13-month-old (adjusted OR for each decrease in numeracy skill level, 1.19; 95% CI, 1.01-1.41). This study also reported that, paradoxically, for caregivers with higher numeracy (9th-16th grade), each increase in numeracy grade level made them more likely to intend to use over-the-counter cold medicines (adjusted OR for each increase in numeracy skill level, 1.78; 95% CI, 1.07-2.96). Investigators attributed this finding to heavier reliance on independent judgment. Importantly, however, analyses were not adjusted for potentially relevant confounders, such as prior physician prescriptions for these medications. Based on these studies, our research team judged the overall strength of evidence regarding the relationship between numeracy and skills in taking medication to be insufficient (Table 35 and Appendix F).

The studies assessing other outcomes—skill at reading nutrition labels9 and at reviewing health plan materials98—found lower comprehension of reviewed materials in participants with lower numeracy. However, only the nutrition label study adjusted for potential confounders. Additionally, the health plan study found fewer participants choosing a higher quality hospital among those with lower numeracy.98 Interestingly, this result was moderated by patient activation; subjects who were more motivated to process information were also more likely to make higher quality choices, regardless of their numeracy level.

Based on these studies, our research team judged the overall strength of evidence regarding the relationship between numeracy and skill in interpreting health information as insufficient (Table 35 and Appendix F).

Disease prevalence and severity. Three cross-sectional studies examined the effect of numeracy level on disease prevalence and severity (Table 41).9,10,174 These studies addressed the effects of numeracy on BMI,9,10 HbA1c,174 and illness requiring dietary restriction.9

The two studies addressing the effect of numeracy (measured by the WRAT-3 numeracy test) on BMI found mixed results in patients drawn from the same academic medicine practice. In one study, those scoring below the ninth-grade level on the WRAT-3 had higher mean BMIs (adjusted beta coefficient, 0.14; P = 0.01).10 By contrast, the other study reported no effect of differential WRAT-3 scores on obesity (BMI greater than 30) in unadjusted analysis.9 The differences in findings may be attributable to a combination of differences in recruiting (physician referral in the Huizinga study), handling of the outcome variable (continuous in the Huizinga study, categorical in the Rothman study), and adjustment in analysis (adjusted in the Huizinga study, unadjusted in the Rothman study).

Findings on other health outcomes were also mixed. One study reported modest effects of numeracy on HgbA1c (adjusted beta coefficient 0.09 for every 10-percentage-point decrease in the proportion of correct responses on the Diabetes Numeracy Test).174 A second study, however, reported no effects of numeracy on the proportion of individuals with illness requiring diet restriction in unadjusted analysis.9

Given the mixed nature of results, our research team judged the overall strength of evidence regarding the relationship between numeracy and disease prevalence to be insufficient (Table 35 and Appendix F).

Summary. In summary, studies of the relationship between numeracy skill level and many health outcomes (including accuracy of risk perception, knowledge, skills taking medication, and disease prevalence and severity) found mixed results. Based on these findings, we judged overall strength of evidence for its relationship to these outcomes to be insufficient.

The relationship between numeracy skill level and other outcomes is also uncertain. One study suggests a possible relationship between numeracy skill level and label-reading skill. Additionally, only one study each addressed the relationships between numeracy and self-efficacy or behavior (both with unadjusted analyses), making conclusions impossible.

### KQ 1c Costs

We found no study that examined the effect of numeracy level on costs.

### KQ 1d Potential Mediator of Disparities

We found two studies that addressed the effects of numeracy as a potential mediator of disparities in health outcomes.47,171 One examined numeracy as a potential mediator of the relationship between race and HgbA1c.171 The other examined numeracy as a potential mediator of the relationship between gender and HIV medication management capacity.47 Both used formal mediational analyses.

In the study examining numeracy as a potential mediator of the relationship between race and HgbA1c, investigators used path analysis and structural equation models to examine the relationships between race, numeracy, and HgbA1c in a cross-sectional sample of 383 diabetic patients who received care at primary care and diabetes specialty clinics at three medical centers. Investigators demonstrated significant negative relationships between both African-American race and numeracy (standardized path coefficient, -0.46; P < 0.001) and numeracy and HgbA1c (standardized path coefficient, -0.15; P < 0.01). They additionally demonstrated that the relationship between African-American race and HgbA1c (standardized path coefficient, 0.12; P < 0.01) lessens and becomes nonsignificant with the addition of numeracy (standardized path coefficient, 0.10; P = NS), suggesting partial mediation of racial disparities by numeracy.

In the study examining numeracy as a potential mediator of the relationship between gender and HIV medication management capacity, investigators also used path analysis to examine the relationships between gender, numeracy, and HIV medication management capacity in a cross-sectional sample of 155 HIV-positive patients recruited from clinics or drug assistance programs in Miami, Florida. In this study, investigators demonstrated a significant negative relationship between female gender and numeracy (path coefficient, -0.428; P < 0.01) and a significant positive relationship between numeracy and medication management capacity (path coefficient, 0.644; P < 0.01). They additionally demonstrated that the correlation between female gender and medication management capacity (path coefficient = NR) lessened and became nonsignificant (path coefficient, 0.073; P = NS) with the addition of numeracy to the model. These findings suggest partial mediation of gender disparities in medication management capacity by numeracy. Our research team judged the overall strength of evidence to be low (Table 35 and Appendix F).