# References

1 Berkman ND, Dewalt DA, Pignone MP, et al. Literacy and health outcomes. Evid Rep Technol Assess. (Summ). Jan. 2004;(87):1-8.
2 Ratzan SC, Parker RM. National library of medicine current bibliographies in medicine: health literacy. Selden CR, Zorn M, Ratzan SC, et al., editors. Bethesda, M. National Institutes of Health, US Department of Health and Human Services. 2000.
3 US Department of Health and Human Services. 11: Health Communication, Healthy People 2010: Objectives for Improving Health. 2nd edition. [Available at: http://www.healthypeople.gov/Document/pdf/uih/2010uih.pdf. 2008 July 19.
4 Institute of Medicine. Health literacy: a prescription to end confusion - executive summary. Available at: http://www.nap.edu/catalog/10883.html. 2008 November 26.
5 American Medical Association. Health literacy: report of the Council on Scientific Affairs. J Am Med Assoc. 1999;281(6):552-7.
6 Baker DW. The meaning and the measure of health literacy. J Gen Intern Med. Aug. 2006;21(8):878-83. [pmid: 16881951].
7 Nutbeam D. Health literacy as a public health goal: a challenge for contemporary health education and communication strategies into the 21st century. Health Promot Intl. 2000;15:259-67.
8 Milne E, Royle JA, Miller M, et al. Maternal folate and other vitamin supplementation during pregnancy and risk of acute lymphoblastic leukemia in the offspring. Int J Cancer. Jun. 1. 2010;126(11):2690-9. [pmid: 19839053].
9 Rothman RL, Housam R, Weiss H, et al. Patient understanding of food labels: the role of literacy and numeracy. Am J Prev Med. Nov. 2006;31(5):391-8. [pmid: 17046410].
10 Huizinga MM, Beech BM, Cavanaugh KL, et al. Low numeracy skills are associated with higher BMI. Obesity (Silver Spring). Aug. 2008;16(8):1966-8. [pmid: 18535541].
11 Kirsch IS, Jungeblut A, Jenkins L, et al. Adult literacy in America: a first look at the findings of the National Adult Literacy Survey. (NCES 1993-275). 3rd ed. Washington, DC. US Department of Education Office of Educational Research and Improvement. Available from: http://nces.ed.gov/pubs93/93275.pdf. 2002.
12 Kutner M, Greenberg E, Jin Y, et al. The health literacy of America's adults: results from the 2003 National Assessment of Adult Literacy. (NCES 2006-483). Available at: http://eric.ed.gov/PDFS/ED493284.pdf. November 17, 2008.
13 Rudd RE. Health literacy skills of U.S. adults. Am J Health Behav. Sep-Oct. 31. 1. 2007:S8-18.
14 Rothman RL, Montori VM, Cherrington A, et al. Perspective: the role of numeracy in health care. J Health Commun. Sep. 2008;13(6):583-95. [pmid: 18726814].
15 Baker DW, Gazmararian JA, Sudano J, et al. The association between age and health literacy among elderly persons. J Gerontol B Psychol Sci Soc Sci. November. 1. 2000. 2000;55(6):S368-74. [pmid: 11078114].
16 Davis T, Crouch M, Wills G, et al. The gap between patient reading comprehension and the readability of patient education materials. J Fam Pract. 1990;31:533-8. [pmid: 2230677].
17 Martin LT, Ruder T, Escarce JJ, et al. Developing predictive models of health literacy. Journal of General Internal Medicine. 2009;24(11):1211-6. [pmid: 19760299].
18 Mohadjer L, Kalton G, Krenzke T, et al. National Assessment of Adult Literacy: Indirect County and State Estimates of the Percentage of Adults at the Lowest Level of Literacy for 1992 and 2003. (NCES 2009-482). Washington, D.C. 2009.
19 Prevalence Calculator. Available at: http://www.pfizerhealthliteracy.com/physicians-providers/prevalence-calculator.html. 2010.
20 National assessment of adult literacy: state and county estimate of low literacy. Available at: http://nces.ed.gov/naal/estimates/StateEstimates.aspx. 2010.
21 Davis T, Long S, Jackson R, et al. Rapid Estimate of Adult Literacy in Medicine: a shortened screening instrument. Family Medicine. June. 1993;25(6):391-5. [pmid: 8349060].
22 Parker R, Baker D, Williams M, et al. The Test of Functional Health Literacy in Adults. Journal of General Internal Medicine. 1995;10(10):537-41. [pmid: 8576769].
23 Baker DW, Williams MV, Parker RM, et al. Development of a brief test to measure functional health literacy. Patient Educ Couns. Sep. 1999;38(1):33-42. [pmid: 14528569].
24 Schwartz LM, Woloshin S, Black WC, et al. The role of numeracy in understanding the benefit of screening mammography. Ann Intern Med. Dec. 1. 1997;127(11):966-72. [pmid: 9412301].
25 Jastak S, Wilkinson G. Wide Range Achievement Test-Revised (WRAT-R). San Antonio, TX. The Psychological Corporation. 1984.
26 Meeting 7: Rountable on health literacy. Workshop on measures of health literacy Available at: http://www.iom.edu/Activities/PublicHealth/HealthLiteracy/2009-FEB-26.aspx September 22, 2010
27 Chew LD, Griffin JM, Partin MR, et al. Validation of screening questions for limited health literacy in a large VA outpatient population. J Gen Intern Med. May. 2008;23(5):561-6. [pmid: 18335281].
28 Hanchate AD, Ash AS, Gazmararian JA, et al. The Demographic Assessment for Health Literacy (DAHL): a new tool for estimating associations between health literacy and outcomes in surveys. J Gen Intern Med. 2008. 2008;23(10):1561-6. [pmid: 18618197].
29 Baron-Epel O, Balin L, Daniely Z, et al. Validation of a Hebrew health literacy test. Patient Educ Couns. Jul. 2007;67(1-2):235-9. [pmid: 17386994].
30 Nath CR, Sylvester ST, Yasek V, et al. Development and validation of a literacy assessment tool for persons with diabetes. Diabetes Educator. 2001;27(6):857-64. [pmid: 12211925].
31 Hanson-Divers EC. Developing a medical achievement reading test to evaluate patient literacy skills: a preliminary study. Journal of Health Care for the Poor and Underserved. Feb. 1997;8(1):56-69. [pmid: 9019026].
32 Weiss BD, Mays MZ, Martz W, et al. Quick assessment of literacy in primary care: the newest vital sign. Ann Fam Med. Nov-Dec. 2005;3(6):514-22. [pmid: 16338915].
33 Diamond JJ. Development of a reliable and construct valid measure of nutritional literacy in adults. Nutr J. 2007;6:5. [pmid: 17300716].
34 Bass PF 3rd, Wilson JF, Griffith CH. A shortened instrument for literacy screening. J Gen Intern Med. Dec. 2003;18(12):1036-8. [pmid: 14687263].
35 Arozullah AM, Yarnold PR, Bennett CL, et al. Development and validation of a short-form, rapid estimate of adult literacy in medicine. Med Care. Nov. 2007;45(11):1026-33. [pmid: 18049342].
36 Lee JY, Rozier RG, Lee SY, et al. Development of a word recognition instrument to test health literacy in dentistry: the REALD-30—a brief communication. J Public Health Dent. Spring. 2007;67(2):94-8. [pmid: 17557680].
37 Davis TC, Wolf MS, Arnold CL, et al. Development and validation of the Rapid Estimate of Adolescent Literacy in Medicine (REALM-Teen): a tool to screen adolescents for below-grade reading in health care settings. Pediatrics. Dec. 2006;118(6):e1707-14. [pmid: 17142495].
38 Lee SY, Bender DE, Ruiz RE, et al. Development of an easy-to-use Spanish health literacy test. Health Serv Res. Aug. 2006;41(4 Pt 1):1392-412. [pmid: 16899014].
39 Morris NS, MacLean CD, Chew LD, et al. The Single Item Literacy Screener: evaluation of a brief instrument to identify limited reading ability. BMC Fam Pract. 2006;7:21. [pmid: 16563164].
40 Gong DA, Lee JY, Rozier RG, et al. Development and testing of the Test of Functional Health Literacy in Dentistry (TOFHLiD). J Public Health Dent. Spring. 2007;67(2):105-12. [pmid: 17557682].
41 Wilkinson G. Wide Range Achievement Test 3—Administration Manual. Wilmington, DE. Jastak Associates, Inc. 1993.
42 Woodcock RW, Mather N. WJ-R tests of achievement: examiner's manual. 1989, 1990.
43 Rothman RL, Malone R, Bryant B, et al. The Spoken Knowledge in Low Literacy in Diabetes scale: a diabetes knowledge scale for vulnerable patients. Diabetes Educ. Mar-Apr. 2005;31(2):215-24. [pmid: 15797850].
44 Lipkus IM, Samsa G, Rimer BK. General performance on a numeracy scale among highly educated samples. Med Decis Making. Jan-Feb. 2001;21(1):37-44. [pmid: 11206945].
45 Zikmund-Fisher BJ, Smith DM, Ubel PA, et al. Validation of the Subjective Numeracy Scale: effects of low numeracy on comprehension of risk communications and utility elicitations. Med Decis Making. Sep-Oct. 2007;27(5):663-71. [pmid: 17652180].
46 Fagerlin A, Zikmund-Fisher BJ, Ubel PA, et al. Measuring numeracy without a math test: development of the Subjective Numeracy Scale. Med Decis Making. Sep-Oct. 2007;27(5):672-80. [pmid: 17641137].
47 Waldrop-Valverde D, Jones DL, Jayaweera D, et al. Gender differences in medication management capacity in HIV infection: The role of health literacy and numeracy. AIDS and Behavior. 2009;13(1):46-52. [pmid: 18618237].
48 DeWalt DA, Pignone MP. Reading is fundamental: the relationship between literacy and health. Arch Intern Med. 2005;165(17):143-4.
49 Berkman ND, DeWalt DA, Pignone MP, et al. Summary, Evidence Report/Technology Assessment No. 87. Available at: http://www.ahrq.gov/clinic/epcsums/litsum.pdf. 2008 July 19.
50 Dewalt DA, Berkman ND, Sheridan S, et al. Literacy and health outcomes: a systematic review of the literature. J Gen Intern Med. Dec. 2004;19(12):1228-39. [pmid: 15610334].
51 Pignone M, DeWalt DA, Sheridan S, et al. Interventions to improve health outcomes for patients with low literacy. A systematic review. J Gen Intern Med. Feb. 2005;20(2):185-92. [pmid: 15836553].
52 National action plan to improve health literacy. Available at: http://www.health.gov/communication/HLActionPlan/. 2010.
53 Institute of Medicine. Report Brief - Health Literacy: A Prescription To End Confusion. Available at: http://www.iom.edu/Object.File/Master/19/726/health%20literacy%20final.pdf. 2008 July 19.
54 Health literacy universal precautions toolkits. Available at: http://www.ahrq.gov/qual/literacy/. 2010.
55 Fishbein M. The role of theory in HIV prevention. AIDS Care. Jun. 2000;12(3):273-8. [pmid: 10928203].
56 Paasche-Orlow MK, Wolf MS. The causal pathways linking health literacy to health outcomes. Am J Health Behav. Sep-Oct. 1. 2007;31:S19-26. [pmid: 17931132].
57 MacKinnon DP. Introduction to statistical mediation analysis. New York. Taylor & Francis Group, LLC. 2008.
58 Moher D, Tricco AC. Issues related to the conduct of systematic reviews: a focus on the nutrition field. Am J Clin Nutr. 2008;88:1191-9. [pmid: 18996852].
59 Berkman ND, Viswanathan M. , , n/a. Development of a tool to evaluate the quality of observational studies. (Abstract). Zeitschrift für Evidenz, Fortbildung, und Qualität im Gesundheitswesen. (German Journal for Evidence and Quality in Health Care). 2008;102(Supple V):S.19.
60 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
61 Gazmararian JA, Kripalani S, Miller MJ, et al. Factors associated with medication refill adherence in cardiovascular-related diseases: a focus on health literacy. J Gen Intern Med. Dec. 2006;21(12):1215-21. [pmid: 17105519].
62 Baker DW, Gazmararian JA, Williams MV, et al. Health literacy and use of outpatient physician services by Medicare managed care enrollees. J Gen Intern Med. Mar. 2004;19(3):215-20. [pmid: 15009775].
63 Howard DH, Sentell T, Gazmararian JA. Impact of health literacy on socioeconomic and racial differences in health in an elderly population. J Gen Intern Med. Aug. 2006;21(8):857-61. [pmid: 16881947].
64 Wolf MS, Gazmararian JA, Baker DW. Health literacy and health risk behaviors among older adults. Am J Prev Med. Jan. 2007;32(1):19-24. [pmid: 17184964].
65 Baker DW, Wolf MS, Feinglass J, et al. Health literacy and mortality among elderly persons. Arch Intern Med. Jul. 23. 2007;167(14):1503-9. [pmid: 17646604].
66 Wolf MS, Gazmararian JA, Baker DW. Health literacy and functional health status among older adults. Arch Intern Med. Sep. 26. 2005;165(17):1946-52. [pmid: 16186463].
67 Baker DW, Wolf MS, Feinglass J, et al. Health literacy, cognitive abilities, and mortality among elderly persons. J Gen Intern Med. Jun. 2008;23(6):723-6. [pmid: 18330654].
68 Howard DH, Gazmararian J, Parker RM. The impact of low health literacy on the medical costs of Medicare managed care enrollees. Am J Med. Apr. 2005;118(4):371-7. [pmid: 15808134].
69 Osborn CY, Paasche-Orlow MK, Davis TC, et al. Health literacy: an overlooked factor in understanding HIV health disparities. Am J Prev Med. Nov. 2007;33(5):374-8. [pmid: 17950402].
70 Wolf MS, Davis TC, Osborn CY, et al. Literacy, self-efficacy, and HIV medication adherence. Patient Educ Couns. Feb. 2007;65(2):253-60. [pmid: 17118617].
71 Waite KR, Paasche-Orlow M, Rintamaki LS, et al. Literacy, social stigma, and HIV medication adherence. J Gen Intern Med. Sep. 2008;23(9):1367-72. [pmid: 18563494].
72 Osborn CY, Davis TC, Bailey SC, et al. Health literacy in the context of HIV treatment: Introducing the Brief Estimate of Health Knowledge and Action (BEHKA)—HIV version. AIDS and Behavior. 2010;14(1):181-8. [pmid: 19023653].
73 Gatti ME, Jacobson KL, Gazmararian JA, et al. Relationships between beliefs about medications and adherence. Am J Health Syst Pharm. Apr. 1. 2009;66(7):657-64. [pmid: 19299373].
74 Johnson VR, Jacobson KL, Gazmararian JA, et al. Does social support help limited-literacy patients with medication adherence?: A mixed methods study of patients in the pharmacy intervention for limited literacy (PILL) study. Patient Education and Counseling. 2010;79(1):14-24. [pmid: 19647967].
75 Davis TC, Wolf MS, Bass PF 3rd, et al. Literacy and misunderstanding prescription drug labels. Ann Intern Med. Dec. 19. 2006;145(12):887-94. [pmid: 17135578].
76 Wolf MS, Davis TC, Shrank W, et al. To err is human: patient misinterpretations of prescription drug label instructions. Patient Educ Couns. Aug. 2007;67(3):293-300. [pmid: 17587533].
77 Bailey SC, Pandit AU, Yin S, et al. Predictors of misunderstanding pediatric liquid medication instructions. Fam Med. Nov-Dec. 2009;41(10):715-21. [pmid: 19882395].
78 Murray MD, Tu W, Wu J, et al. Factors associated with exacerbation of heart failure include treatment adherence and health literacy skills. Clin Pharmacol Ther. Jun. 2009;85(6):651-8. [pmid: 19262464].
79 Paasche-Orlow MK, Riekert KA, Bilderback A, et al. Tailored education may reduce health literacy disparities in asthma self-management. Am J Respir Crit Care Med. Oct. 15. 2005;172(8):980-6. [pmid: 16081544].
80 DeWalt DA, Dilling MH, Rosenthal MS, et al. Low parental literacy is associated with worse asthma care measures in children. Ambul Pediatr. Jan-Feb. 2007;7(1):25-31. [pmid: 17261479].
81 Cho YI, Lee SY, Arozullah AM, et al. Effects of health literacy on health status and health service utilization amongst the elderly. Soc Sci Med. Apr. 2008;66(8):1809-16. [pmid: 18295949].
82 Murphy DA, Lam P, Naar-King S, et al. Health literacy and antiretroviral adherence among HIV-infected adolescents. Patient Education and Counseling. 2010;79(1):25-9. [pmid: 19665860].
83 Hope CJ, Wu J, Tu W, et al. Association of medication adherence, knowledge, and skills with emergency department visits by adults 50 years or older with congestive heart failure. Am J Health Syst Pharm. Oct. 1. 2004;61(19):2043-9. [pmid: 15509127].
84 Shone LP, Conn KM, Sanders L, et al. The role of parent health literacy among urban children with persistent asthma. Patient Educ Couns. Jun. 2009;75(3):368-75. [pmid: 19233588].
85 Bennett IM, Chen J, Soroui JS, et al. The contribution of health literacy to disparities in self-rated health status and preventive health behaviors in older adults. Ann Fam Med. May-Jun. 2009;7(3):204-11. [pmid: 19433837].
86 White S, Chen J, Atchison R. Relationship of preventive health practices and health literacy: a national study. Am J Health Behav. May-Jun. 2008;32(3):227-42. [pmid: 18067463].
87 Peterson NB, Dwyer KA, Mulvaney SA, et al. The influence of health literacy on colorectal cancer screening knowledge, beliefs and behavior. J Natl Med Assoc. Oct. 2007;99(10):1105-12. [pmid: 17987913].
88 Guerra CE, Dominguez F, Shea JA. Literacy and knowledge, attitudes, and behavior about colorectal cancer screening. J Health Commun. Oct-Nov. 2005;10(7):651-63. [pmid: 16278201].
89 Miller DP Jr, Brownlee CD, McCoy TP, et al. The effect of health literacy on knowledge and receipt of colorectal cancer screening: a survey study. BMC Fam Pract. 2007;8:16. [pmid: 17394668].
90 Guerra CE, Krumholz M, Shea JA. Literacy and knowledge, attitudes and behavior about mammography in Latinas. J Health Care Poor Underserved. Feb. 2005;16(1):152-66. [pmid: 15741716].
91 Garbers S, Chiasson MA. Inadequate functional health literacy in Spanish as a barrier to cervical cancer screening among immigrant Latinas in New York City. Prev Chronic Dis. Oct. 2004;1(4):A07. [pmid: 15670438].
92 Scott TL, Gazmararian JA, Williams MV, et al. Health Literacy and Preventive Health Care Use Among Medicare Enrollees in a Managed Care Organization. Medical Care. May. 2002;40(5):395-404. [pmid: 11961474].
93 Barragan M, Hicks G, Williams MV, et al. Low health literacy is associated with HIV test acceptance. J Gen Intern Med. May. 2005;20(5):422-5. [pmid: 15963165].
94 Fortenberry JD, McFarlane MM, Hennessy M, et al. Relation of health literacy to gonorrhoea related care. Sex Transm Infect. Jun. 2001;77(3):206-11. [pmid: 11402232].
95 Sudore RL, Mehta KM, Simonsick EM, et al. Limited literacy in older people and disparities in health and healthcare access. J Am Geriatr Soc. May. 2006;54(5):770-6. [pmid: 16696742].
96 Lindau ST, Basu A, Leitsch SA. Health literacy as a predictor of follow-up after an abnormal Pap smear: a prospective study. J Gen Intern Med. Aug. 2006;21(8):829-34. [pmid: 16881942].
97 Grubbs V, Gregorich SE, Perez-Stable EJ, et al. Health literacy and access to kidney transplantation. Clin J Am Soc Nephrol. Jan. 2009;4(1):195-200. [pmid: 19056617].
98 Hibbard JH, Peters E, Dixon A, et al. Consumer competencies and the use of comparative quality information: it isn't just about literacy. Med Care Res Rev. Aug. 2007;64(4):379-94. [pmid: 17684108].
99 Mancuso CA, Rincon M. Asthma patients' assessments of health care and medical decision making: the role of health literacy. J Asthma. Jan-Feb. 2006;43(1):41-4. [pmid: 16448964].
100 Mancuso CA, Rincon M. Impact of health literacy on longitudinal asthma outcomes. J Gen Intern Med. Aug. 2006;21(8):813-7. [pmid: 16881939].
101 Baker DW, Parker RM, Williams MV, et al. The relationship of patient reading ability to self-reported health and use of health services. Am J Public Health. June. 1. 1997. 1997;87(6):1027-30. [pmid: 9224190].
102 Yin HS, Johnson M, Mendelsohn AL, et al. The health literacy of parents in the United States: a nationally representative study. Pediatrics. Nov. 3. 2009;124:S289-98. [pmid: 19861483].
103 Kalichman SC, Pope H, White D, et al. Association between health literacy and HIV treatment adherence: further evidence from objectively measured medication adherence. J Int Assoc Physicians AIDS Care (Chic Ill). Nov-Dec. 2008;7(6):317-23.
104 Graham J, Bennett IM, Holmes WC, et al. Medication beliefs as mediators of the health literacy-antiretroviral adherence relationship in HIV-infected individuals. AIDS Behav. May. 2007;11(3):385-92. [pmid: 17053858].
105 Paasche-Orlow MK, Cheng DM, Palepu A, et al. Health literacy, antiretroviral adherence, and HIV-RNA suppression: a longitudinal perspective. J Gen Intern Med. Aug. 2006;21(8):835-40. [pmid: 16881943].
106 Fang MC, Machtinger EL, Wang F, et al. Health literacy and anticoagulation-related outcomes among patients taking warfarin. J Gen Intern Med. Aug. 2006;21(8):841-6. [pmid: 16881944].
107 Chew LD, Bradley KA, Flum DR, et al. The impact of low health literacy on surgical practice. Am J Surg. Sep. 2004;188(3):250-3. [pmid: 15450829].
108 Hironaka LK, Paasche-Orlow MK, Young RL, et al. Caregiver health literacy and adherence to a daily multi-vitamin with iron regimen in infants. Patient Educ Couns. Jun. 2009;75(3):376-80. [pmid: 19395227].
109 Frack SA, Woodruff SI, Candelaria J, et al. Correlates of compliance with measurement protocols in a Latino nutrition-intervention study. American Journal of Preventive Medicine. Mar-Apr. 1997;13(2):131-6. [pmid: 9088450].
110 Golin CE, Liu H, Hays RD, et al. A prospective study of predictors of adherence to combination antiretroviral medication. Journal of General Internal Medicine. Oct. 2002;17(10):756-65. [pmid: 12390551].
111 Kalichman SC, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. Journal of General Internal Medicine. May. 1999;14(5):267-73. [pmid: 10337035].
112 Li BD, Brown WA, Ampil FL, et al. Patient compliance is critical for equivalent clinical outcomes for breast cancer treated by breast-conservation therapy. Annals of Surgery. Jun. 2000;231(6):883-9. [pmid: 10816632].
113 Torres RY, Marks R. Relationships among health literacy, knowledge about hormone therapy, self-efficacy, and decision-making among postmenopausal health. J Health Commun. Jan-Feb. 2009;14(1):43-55. [pmid: 19180370].
114 von Wagner C, Semmler C, Good A, et al. Health literacy and self-efficacy for participating in colorectal cancer screening: The role of information processing. Patient Educ Couns. Jun. 2009;75(3):352-7. [pmid: 19386461].
115 von Wagner C, Knight K, Steptoe A, et al. Functional health literacy and health-promoting behaviour in a national sample of British adults. J Epidemiol Community Health. Dec. 2007;61(12):1086-90. [pmid: 18000132].
116 Davis TC, Fredrickson DD, Arnold C, et al. A polio immunization pamphlet with increased appeal and simplified language does not improve comprehension to an acceptable level. Patient Educat Counsel. 1998. Jan. 1998;33(1):25-37.
117 Fredrickson DD, Washington RL, Pham N, et al. Reading grade levels and health behaviors of parents at child clinics. Kans Med. Fall. 1995;96(3):127-9. [pmid: 8583738].
118 Hawthorne G. Preteenage drug use in Australia: the key predictors and school-based drug education. J Adolesc Health. 1996. May. 1996;20(5):384-95. [pmid: 9168386].
119 Sharif I, Blank AE. Relationship between child health literacy and body mass index in overweight children. Patient Education and Counseling. 2010;79(1):43-8. [pmid: 19716255].
120 Wolf MS, Davis TC, Shrank WH, et al. A critical review of FDA-approved Medication Guides. Patient Educ Couns. Sep. 2006;62(3):316-22. [pmid: 16884888].
121 Paasche-Orlow MK, Clarke JG, Hebert MR, et al. Educational attainment but not literacy is associated with HIV risk behavior among incarcerated women. J Womens Health (Larchmt). Nov. 2005;14(9):852-9. [pmid: 16313213].
122 Marteleto L, Lam D, Ranchhod V. Sexual behavior, pregnancy, and schooling among young people in urban South Africa. Stud Fam Plann. Dec. 2008;39(4):351-68. [pmid: 19248720].
123 Kripalani S, Henderson LE, Chiu EY, et al. Predictors of medication self-management skill in a low-literacy population. J Gen Intern Med. Aug. 2006;21(8):852-6. [pmid: 16881946].
124 Raehl CL, Bond CA, Woods TJ, et al. Screening tests for intended medication adherence among the elderly. Ann Pharmacother. May. 2006;40(5):888-93. [pmid: 16595567].
125 Yin HS, Dreyer BP, Foltin G, et al. Association of low caregiver health literacy with reported use of nonstandardized dosing instruments and lack of knowledge of weight-based dosing. Ambul Pediatr. Jul-Aug. 2007;7(4):292-8. [pmid: 17660100].
126 Estrada CA, Martin-Hryniewicz M, Peek BT, et al. Literacy and numeracy skills and anticoagulation control. Am J Med Sci. Aug. 2004;328(2):88-93. [pmid: 15311167].
127 Yin HS, Mendelsohn AL, Wolf MS, et al. Parents' medication administration errors: role of dosing instruments and health literacy. Arch Pediatr Adolesc Med. Feb. 2010;164(2):181-6. [pmid: 20124148].
128 LeVine RA, LeVine SE, Rowe ML, et al. Maternal literacy and health behavior: a Nepalese case study. Soc Sci Med. Feb. 2004;58(4):863-77. [pmid: 14672599].
129 Williams MV, Baker DW, Honig EG, et al. Inadequate literacy is a barrier to asthma knowledge and self-care. Chest. 1998. Oct. 1998;114(4):1008-15. [pmid: 9792569].
130 Lincoln A, Paasche-Orlow MK, Cheng DM, et al. Impact of health literacy on depressive symptoms and mental health-related: quality of life among adults with addiction. J Gen Intern Med. Aug. 2006;21(8):818-22. [pmid: 16881940].
131 Nokes KM, Coleman CL, Cashen M, et al. Health literacy and health outcomes in HIV seropositive persons. Res Nurs Health. Dec. 2007;30(6):620-7. [pmid: 18022832].
132 Bennett IM, Culhane JF, McCollum KF, et al. Literacy and depressive symptomatology among pregnant Latinas with limited English proficiency. Am J Orthopsychiatry. Apr. 2007;77(2):243-8. [pmid: 17535122].
133 Walker D, Adebajo A, Heslop P, et al. Patient education in rheumatoid arthritis: the effectiveness of the ARC booklet and the mind map. Rheumatology (Oxford). Oct. 2007;46(10):1593-6. [pmid: 17767002].
134 Morris NS, MacLean CD, Littenberg B. Literacy and health outcomes: a cross-sectional study in 1002 adults with diabetes. BMC Fam Pract. 2006;7:49. [pmid: 16907968].
135 Coffman MJ, Norton CK. Demands of immigration, health literacy, and depression in recent Latino immigrants. Home Health Care Management & Practice. 2010;22(2):116-22.
136 Gazmararian J, Baker D, Parker R, et al. A multivariate analysis of factors associated with depression: evaluating the role of health literacy as a potential contributor. Arch Intern Med. Nov. 27. 2000;160(21):3307-14. [pmid: 11088094].
137 TenHave TR, Van Horn B, Kumanyika S, et al. Literacy assessment in a cardiovascular nutrition education setting. Patient Educ Couns. Jun. 1997;31(2):139-50. [pmid: 9216355].
138 Kalichman SC, Rompa D. Emotional reactions to health status changes and emotional well-being among HIV-positive persons with limited reading literacy. J Clin Psychol Med Set. 2000;7(4):203-11.
139 Gordon MM, Hampson R, Capell HA, et al. Illiteracy in rheumatoid arthritis patients as determined by the Rapid Estimate of Adult Literacy in Medicine (REALM) score. Rheumatology (Oxford). Jul. 2002;41(7):750-4. [pmid: 12096223].
140 Zaslow MJ, Hair EC, Dion MR, et al. Maternal depressive symptoms and low literacy as potential barriers to employment in a sample of families receiving welfare: are there two-generational implications?. Women Health. 2001;32(3):211-51. [pmid: 11480894].
141 Sentell TL, Halpin HA. Importance of adult literacy in understanding health disparities. J Gen Intern Med. Aug. 2006;21(8):862-6. [pmid: 16881948].
142 Kim SH. Health literacy and functional health status in Korean older adults. J Clin Nurs. Aug. 2009;18(16):2337-43. [pmid: 19583664].
143 Laramee AS, Morris N, Littenberg B. Relationship of literacy and heart failure in adults with diabetes. BMC Health Serv Res. 2007;7:98. [pmid: 17605784].
144 Andrasik F, Kabela E, Quinn S, et al. Psychological functioning of children who have recurrent migraine. Pain. Jul. 1988;34(1):43-52. [pmid: 3405619].
145 Mayben JK, Kramer JR, Kallen MA, et al. Predictors of delayed HIV diagnosis in a recently diagnosed cohort. AIDS Patient Care STDS. Mar. 2007;21(3):195-204. [pmid: 17428187].
146 Kalichman SC, Rompa D. Functional health literacy is associated with health status and health-related knowledge in people living with HIV-AIDS. J Acquir Immune Defic Syndr. Dec. 1. 2000;25(4):337-44. [pmid: 11114834].
147 Kalichman SC, Benotsch E, Suarez T, et al. Health literacy and health-related knowledge among persons living with HIV/AIDS. Am J Prev Med. May. 2000;18(4):325-31. [pmid: 10788736].
148 Tang YH, Pang SM, Chan MF, et al. Health literacy, complication awareness, and diabetic control in patients with type 2 diabetes mellitus. J Adv Nurs. Apr. 2008;62(1):74-83. [pmid: 18352966].
149 Powell CK, Hill EG, Clancy DE. The relationship between health literacy and diabetes knowledge and readiness to take health actions. Diabetes Educ. Jan-Feb. 2007;33(1):144-51. [pmid: 17272800].
150 Schillinger D, Barton LR, Karter AJ, et al. Does literacy mediate the relationship between education and health outcomes? A study of a low-income population with diabetes. Public Health Rep. May-Jun. 2006;121(3):245-54. [pmid: 16640146].
151 Mancuso JM. Impact of health literacy and patient trust on glycemic control in an urban USA population. Nursing & Health Sciences. 2010;12(1):94-104. [pmid: 20487332].
152 Ross LA, Frier BM, Kelnar CJ, et al. Child and parental mental ability and glycaemic control in children with Type 1 diabetes. Diabet Med. May. 2001;18(5):364-9. [pmid: 11472446].
153 Schillinger D, Grumbach K, Piette J, et al. Association of health literacy with diabetes outcomes. JAMA. Jul. 24-31. 2002;288(4):475-82. [pmid: 12132978].
154 Powers BJ, Olsen MK, Oddone EZ, et al. Literacy and blood pressure--do healthcare systems influence this relationship? A cross-sectional study. BMC Health Serv Res. 2008;8:219. [pmid: 18947408].
155 Pandit AU, Tang JW, Bailey SC, et al. Education, literacy, and health: Mediating effects on hypertension knowledge and control. Patient Educ Couns. Jun. 2009;75(3):381-5. [pmid: 19442477].
156 Williams MV, Baker DW, Parker RM, et al. Relationship of functional health literacy to patients' knowledge of their chronic disease. A study of patients with hypertension and diabetes. Arch Intern Med. Jan. 26. 1998;158(2):166-72. [pmid: 9448555].
157 Wolf MS, Knight SJ, Lyons EA, et al. Literacy, race, and PSA level among low-income men newly diagnosed with prostate cancer. Urology. Jul. 2006;68(1):89-93. [pmid: 16844451].
158 Bennett CL, Ferreira MR, Davis TC, et al. Relation between literacy, race, and stage of presentation among low-income patients with prostate cancer. J Clin Oncol. Sep. 1998;16(9):3101-4. [pmid: 9738581].
159 Smith JL, Haggerty J. Literacy in primary care populations: is it a problem. Can J Public Health. Nov-Dec. 2003;94(6):408-12. [pmid: 14700237].
160 Lee SYD, Arozullah AM, Cho YI, et al. Health literacy, social support, and health status among older adults. Educational Gerontology. 03. 2009;35(3):191-201.
161 Muir KW, Santiago-Turla C, Stinnett SS, et al. Health literacy and vision-related quality of life. Br J Ophthalmol. Jun. 2008;92(6):779-82. [pmid: 18460538].
162 Johnston MV, Diab ME, Kim SS, et al. Health literacy, morbidity, and quality of life among individuals with spinal cord injury. J Spinal Cord Med. 2005;28(3):230-40. [pmid: 16048141].
163 Hahn EA, Cella D, Dobrez DG, et al. The impact of literacy on health-related quality of life measurement and outcomes in cancer outpatients. Qual Life Res. Apr. 2007;16(3):495-507. [pmid: 17091362].
164 Weiss BD, Hart G, McGee DL, et al. Health status of illiterate adults: relation between literacy and health status among persons with low literacy skills. J Am Board Fam Pract. 1992;5(3):257-64. [pmid: 1580173].
165 Gazmararian JA, Baker DW, Williams MV, et al. Health Literacy Among Medicare Enrollees in a Managed Care Organization. JAMA. February. 10. 1999. 1999;281(6):545-51. [pmid: 10022111].
166 Sullivan LM, Dukes KA, Harris L, et al. A comparison of various methods of collecting self-reported health outcomes data among low-income and minority patients. Med Care. Apr. 1995;33(4 Suppl):AS183-94. [pmid: 7723446].
167 Sudore RL, Yaffe K, Satterfield S, et al. Limited literacy and mortality in the elderly: the health, aging, and body composition study. J Gen Intern Med. Aug. 2006;21(8):806-12. [pmid: 16881938].
168 Weiss BD, Palmer R. Relationship between health care costs and very low literacy skills in a medically needy and indigent Medicaid population. J Am Board Fam Pract. Jan-Feb. 2004;17(1):44-7. [pmid: 15014052].
169 Weiss BD, Blanchard JS, McGee DL, et al. Illiteracy among Medicaid recipients and its relationship to health care costs. J Health Care Poor Underserved. 1994;5(2):99-111. [pmid: 8043732].
170 Baron RM, Kenny DA. The moderator-mediator variable distinction in social psychological research: conceptual, strategic, and statistical considerations. J Pers Soc Psychol. Dec. 1986;51(6):1173-82. [pmid: 3806354].
171 Osborn CY, Cavanaugh K, Wallston KA, et al. Diabetes numeracy: an overlooked factor in understanding racial disparities in glycemic control. Diabetes Care. Sep. 2009;32(9):1614-9. [pmid: 19401443].
172 Sheridan SL, Pignone M. Numeracy and the medical student's ability to interpret data. Eff Clin Pract. Jan-Feb. 2002;5(1):35-40. [pmid: 11874195].
173 Sheridan SL, Pignone MP, Lewis CL. A randomized comparison of patients' understanding of number needed to treat and other common risk reduction formats. J Gen Intern Med. Nov. 2003;18(11):884-92. [pmid: 14687273].
174 Cavanaugh K, Huizinga MM, Wallston KA, et al. Association of numeracy and diabetes control. Ann Intern Med. May. 20. 2008;148(10):737-46. [pmid: 18490687].
175 Davids SL, Schapira MM, McAuliffe TL, et al. Predictors of pessimistic breast cancer risk perceptions in a primary care population. J Gen Intern Med. Apr. 2004;19(4):310-5. [pmid: 15061739].
176 Haggstrom DA, Schapira MM. Black-white differences in risk perceptions of breast cancer survival and screening mammography benefit. J Gen Intern Med. Apr. 2006;21(4):371-7. [pmid: 16686816].
177 Vavrus F. Girls' schooling in Tanzania: the key to HIV/AIDS prevention?. AIDS Care. Nov. 2006;18(8):863-71. [pmid: 17012074].
178 Aggarwal A, Speckman JL, Paasche-Orlow MK, et al. The role of numeracy on cancer screening among urban women. Am J Health Behav. Sep-Oct. 1. 2007;31:S57-68. [pmid: 17931137].
179 Lokker N, Sanders L, Perrin EM, et al. Parental misinterpretations of over-the-counter pediatric cough and cold medication labels. Pediatrics. Jun. 2009;123(6):1464-71. [pmid: 19482755].
180 Peters E, Hibbard J, Slovic P, et al. Numeracy skill and the communication, comprehension, and use of risk-benefit information. Health Aff (Millwood). May-Jun. 2007;26(3):741-8. [pmid: 17485752].
181 Seligman HK, Wang FF, Palacios JL, et al. Physician notification of their diabetes patients' limited health literacy. A randomized, controlled trial. J Gen Intern Med. Nov. 2005;20(11):1001-7. [pmid: 16307624].
182 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
183 Rothman RL, DeWalt DA, Malone R, et al. Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program. J Am Med Assoc. Oct. 13. 2004;292(14):1711-6.
184 Volandes AE, Paasche-Orlow MK, Barry MJ, et al. Video decision support tool for advance care planning in dementia: randomised controlled trial. Br Med J. 2009;338:b2159. [pmid: 19477893].
185 Greene J, Peters E, Mertz CK, et al. Comprehension and choice of a consumer-directed health plan: an experimental study. Am J Manag Care. Jun. 2008;14(6):369-76. [pmid: 18554075].
186 Wright AJ, Whitwell SC, Takeichi C, et al. The impact of numeracy on reactions to different graphic risk presentation formats: an experimental analogue study. Br J Health Psychol. Feb. 2009;14(Pt 1):107-25. [pmid: 18442447].
187 Schillinger D, Hammer H, Wang F, et al. Seeing in 3-D: examining the reach of diabetes self-management support strategies in a public health care system. Health Educ Behav. Oct. 2008;35(5):664-82. [pmid: 17513690].
188 Peters E, Dieckmann N, Dixon A, et al. Less is more in presenting quality information to consumers. Med Care Res Rev. Apr. 2007;64(2):169-90. [pmid: 17406019].
189 Mayhorn CB, Goldsworthy RC. Refining teratogen warning symbols for diverse populations. Birth Defects Res A Clin Mol Teratol. Jun. 2007;79(6):494-506. [pmid: 17358036].
190 Kripalani S, Robertson R, Love-Ghaffari MH, et al. Development of an illustrated medication schedule as a low-literacy patient education tool. Patient Educ Couns. Jun. 2007;66(3):368-77. [pmid: 17344015].
191 Yates K, Pena A. Comprehension of discharge information for minor head injury: a randomised controlled trial in New Zealand. N Z Med J. 2006;119(1239):U2101. [pmid: 16912719].
192 Sudore RL, Landefeld CS, Williams BA, et al. Use of a modified informed consent process among vulnerable patients: a descriptive study. J Gen Intern Med. Aug. 2006;21(8):867-73. [pmid: 16881949].
193 Weiss BD, Francis L, Senf JH, et al. Literacy education as treatment for depression in patients with limited literacy and depression: a randomized controlled trial. J Gen Intern Med. Aug. 2006;21(8):823-8. [pmid: 16881941].
194 Gerber BS, Brodsky IG, Lawless KA, et al. Implementation and evaluation of a low-literacy diabetes education computer multimedia application. Diabetes Care. Jul. 2005;28(7):1574-80. [pmid: 15983303].
195 Hwang SW, Tram CQ, Knarr N. The effect of illustrations on patient comprehension of medication instruction labels. BMC Fam Pract. Jun. 16. 2005;6(1):26. [pmid: 15960849].
196 Ferreira MR, Dolan NC, Fitzgibbon ML, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
197 Kim S, Love F, Quistberg DA, et al. Association of health literacy with self-management behavior in patients with diabetes. Diabetes Care. Dec. 2004;27(12):2980-2. [pmid: 15562219].
198 Rothman R, Malone R, Bryant B, et al. The relationship between literacy and glycemic control in a diabetes disease-management program. Diabetes Educ. Mar-Apr. 2004;30(2):263-73. [pmid: 15095516].
199 Coyne CA, Xu R, Raich P, et al. Randomized, controlled trial of an easy-to-read informed consent statement for clinical trial participation: a study of the Eastern Cooperative Oncology Group. J Clin Oncol. Mar. 1. 2003;21(5):836-42. [pmid: 12610182].
200 Campbell FA, Goldman BD, Boccia ML, et al. The effect of format modifications and reading comprehension on recall of informed consent information by low-income parents: a comparison of print, video, and computer-based presentations. Patient Educ Couns. May. 2004;53(2):205-16. [pmid: 15140461].
201 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
202 DeWalt DA, Malone RM, Bryant ME, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. 2006;6:30. [pmid: 16533388].
203 Kripalani S, Sharma J, Justice E, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. Am J Prev Med. Aug. 2007;33(2):83-90. [pmid: 17673094].
204 Sudore RL, Landefeld CS, Barnes DE, et al. An advance directive redesigned to meet the literacy level of most adults: a randomized trial. Patient Educ Couns. Dec. 2007;69(1-3):165-95. [pmid: 17942272].
205 Davis TC, Wolf MS, Bass PF, et al. Provider and patient intervention to improve weight loss: a pilot study in a public hospital clinic. Patient Educ Couns. Jul. 2008;72(1):56-62. [pmid: 18346861].
206 Kripalani S, Bengtzen R, Henderson LE, et al. Clinical research in low-literacy populations: using teach-back to assess comprehension of informed consent and privacy information. IRB. Mar-Apr. 2008;30(2):13-9. [pmid: 18512655].
207 Robinson LD Jr, Calmes DP, Bazargan M. The impact of literacy enhancement on asthma-related outcomes among underserved children. J Natl Med Assoc. Aug. 2008;100(8):892-6. [pmid: 18717138].
208 Sudore RL, Schickedanz AD, Landefeld CS, et al. Engagement in multiple steps of the advance care planning process: a descriptive study of diverse older adults. J Am Geriatr Soc. Jun. 2008;56(6):1006-13. [pmid: 18410324].
209 Rudd RE, Blanch DC, Gall V, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
210 Schillinger D, Handley M, Wang F, et al. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. Apr. 2009;32(4):559-66. [pmid: 19131469].
211 Wallace AS, Seligman HK, Davis TC, et al. Literacy-appropriate educational materials and brief counseling improve diabetes self-management. Patient Educ Couns. Jun. 2009;75(3):328-33. [pmid: 19167857].
212 Kang EY, Fields HW, Kiyak A, et al. Informed consent recall and comprehension in orthodontics: traditional vs improved readability and processability methods. Am J Orthod Dentofacial Orthop. Oct. 2009;136(4):488 e1-13. discussion -9. [pmid: 19815144].
213 Bryant MD, Schoenberg ED, Johnson TV, et al. Multimedia version of a standard medical questionnaire improves patient understanding across all literacy levels. J Urol. Sep. 2009;182(3):1120-5. [pmid: 19625036].
214 Greene J, Peters E. Medicaid consumers and informed decisionmaking. Health Care Financ Rev. Spring. 2009;30(3):25-40. [pmid: 19544933].
215 Sobel RM, Paasche-Orlow MK, Waite KR, et al. Asthma 1-2-3: a low literacy multimedia tool to educate African American adults about asthma. J Community Health. Aug. 2009;34(4):321-7. [pmid: 19353250].
216 Galesic M, Garcia-Retamero R, Gigerenzer G. Using icon arrays to communicate medical risks: overcoming low numeracy. Health Psychol. Mar. 2009;28(2):210-6. [pmid: 19290713].
217 Galesic M, Gigerenzer G, Straubinger N. Natural frequencies help older adults and people with low numeracy to evaluate medical screening tests. Med Decis Making. May-Jun. 2009;29(3):368-71. [pmid: 19129155].
218 Jay M, Adams J, Herring SJ, et al. A randomized trial of a brief multimedia intervention to improve comprehension of food labels. Preventive Medicine. 2009;(1):25-31. [pmid: 19022282].
219 Garcia-Retamero R, Galesic M. Communicating treatment risk reduction to people with low numeracy skills: a cross-cultural comparison. Am J Public Health. Dec. 2009;99(12):2196-202. [pmid: 19833983].
220 Brock TP, Smith SR. Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings. Int J Med Inform. Nov-Dec. 2007;76(11-12):829-35. [pmid: 17113345].
221 Kalichman SC, Cherry J, Cain D. Nurse-delivered antiretroviral treatment adherence intervention for people with low literacy skills and living with HIV/AIDS. J Assoc Nurses AIDS Care. Sep-Oct. 2005;16(5):3-15. [pmid: 16433105].
222 van Servellen G, Nyamathi A, Carpio F, et al. Effects of a treatment adherence enhancement program on health literacy, patient-provider relationships, and adherence to HAART among low-income HIV-positive Spanish-speaking Latinos. AIDS Patient Care STDS. Nov. 2005;19(11):745-59. [pmid: 16283835].
223 van Servellen G, Carpio F, Lopez M, et al. Program to enhance health literacy and treatment adherence in low-income HIV-infected Latino men and women. AIDS Patient Care STDS. Nov. 2003;17(11):581-94. [pmid: 14746666].
224 DeWalt DA, Pignone M, Malone R, et al. Development and pilot testing of a disease management program for low literacy patients with heart failure. Patient Educ Couns. Oct. 2004;55(1):78-86. [pmid: 15476993].
225 Carbone ET, Lennon KM, Torres MI, et al. Testing the feasibility of an interactive learning styles measure for U.S. Latino adults with type 2 diabetes and low literacy. International Quarterly of Community Health Education. 2006;25(4):315-35. [pmid: 17686705].
226 Kandula NR, Nsiah-Kumi PA, Makoul G, et al. The relationship between health literacy and knowledge improvement after a multimedia type 2 diabetes education program. Patient Educ Couns. Jun. 2009;75(3):321-7. [pmid: 19395223].
227 Bickmore TW, Pfeifer LM, Paasche-Orlow MK. Using computer agents to explain medical documents to patients with low health literacy. Patient Educ Couns. Jun. 2009;75(3):315-20. [pmid: 19297116].
228 Ntiri DW, Stewart M. Transformative learning intervention: effect on functional health literacy and diabetes knowledge in older African Americans. Gerontol Geriatr Educ. 2009;30(2):100-13. [pmid: 19440898].
229 Garcia-Retamero R, Galesic M. Who profits from visual aids: overcoming challenges in people's understanding of risks [corrected]. Soc Sci Med. Apr. 2010;70(7):1019-25. [pmid: 20116159].
230 Gazmararian J, Jacobson KL, Pan Y, et al. Effect of a pharmacy-based health literacy intervention and patient characteristics on medication refill adherence in an urban health system. Ann Pharmacother. Jan. 2010;44(1):80-7. [pmid: 20028960].
231 Cordasco KM, Asch SM, Bell DS, et al. A low-literacy medication education tool for safety-net hospital patients. Am J Prev Med. Dec. 2009;37(6 Suppl 1):S209-16. [pmid: 19896021].
232 Michielutte R, Bahnson J, Dignan MB, et al. The use of illustrations and narrative text style to improve readability of a health education brochure. J Cancer Educ. 1992;7(3):251-60. [pmid: 1419592].
233 Meade CD, McKinney WP, Barnas GP. Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer. Am J Public Health. Jan. 1994;84(1):119-21. [pmid: 8279598].
234 Davis TC, Berkel HJ, Arnold CL, et al. Intervention to increase mammography utilization in a public hospital. J Gen Intern Med. Apr. 1998;13(4):230-3. [pmid: 9565385].
235 Murphy PW, Chesson AL, Walker L, et al. Comparing the effectiveness of video and written material for improving knowledge among sleep disorders clinic patients with limited literacy skills. South Med J. Mar. 2000;93(3):297-304. [pmid: 10728518].
236 Eaton ML, Holloway RL. Patient comprehension of written drug information. Am J Hosp Pharm. Feb. 1980;37(2):240-3. [pmid: 7361799].
237 Davis TC, Bocchini JA Jr, Fredrickson D, et al. Parent comprehension of polio vaccine information pamphlets. Pediatrics. Jun. 1996;97(6 Pt 1):804-10. [pmid: 8657518].
238 Davis TC, Holcombe RF, Berkel HJ, et al. Informed consent for clinical trials: a comparative study of standard versus simplified forms. J Natl Cancer Inst. May. 6. 1998;90(9):668-74. [pmid: 9586663].
239 Hayes KS. Randomized trial of geragogy-based medication instruction in the emergency department. Nurs Res. Jul-Aug. 1998;47(4):211-8. [pmid: 9683116].
240 Hussey LC. Minimizing effects of low literacy on medication knowledge and compliance among the elderly. Clin Nurs Res. May. 1994;3(2):132-45. [pmid: 7513587].
241 Kim SP, Knight SJ, Tomori C, et al. Health literacy and shared decision making for prostate cancer patients with low socioeconomic status. Cancer Invest. 2001;19(7):684-91. [pmid: 11577809].
242 Pepe M, Chodzko-Zajko WJ. Impact of older adults' reading ability on the comprehension and recall of cholesterol information. J Health Educat. 1997;28(1):21-7.
243 Howard-Pitney B, Winkleby MA, Albright CL, et al. The Stanford Nutrition Action Program: a dietary fat intervention for low-literacy adults. Am J Public Health. Dec. 1997;87(12):1971-6. [pmid: 9431286].
244 Wydra EW. The effectiveness of a self-care management interactive multimedia module. Oncol Nurs Forum. Oct. 2001;28(9):1399-407. [pmid: 11683310].
245 Murphy PW, Davis TC, Mayeaux EJ, et al. Teaching nutrition education in adult learning centers: linking literacy, health care, and the community. J Community Health Nurs. 1996;13(3):149-58. [pmid: 8916604].
246 Raymond EG, Dalebout SM, Camp SI. Comprehension of a prototype over-the-counter label for an emergency contraceptive pill product. Obstet Gynecol. Aug. 2002;100(2):342-9. [pmid: 12151161].
247 Hartman TJ, McCarthy PR, Park RJ, et al. Results of a community-based low-literacy nutrition education program. J Community Health. Oct. 1997;22(5):325-41. [pmid: 9353681].
248 Poresky RH, Daniels AM. Two-year comparison of income, education, and depression among parents participating in regular Head Start or supplementary Family Service Center Services. Psychol Rep. Jun. 2001;88(3 Pt 1):787-96. [pmid: 11508020].
249 Kumanyika SK, Adams-Campbell L, Van Horn B, et al. Outcomes of a cardiovascular nutrition counseling program in African-Americans with elevated blood pressure or cholesterol level. J Am Diet Assoc. Nov. 1999;99(11):1380-91. [pmid: 10570675].
250 Rothman RL, So SA, Shin J, et al. Labor characteristics and program costs of a successful diabetes management program. Am J Manag Care. 2006;12(5):277-83. [pmid: 16686585].
251 Schroder FH, Hugosson J, Roobol MJ, et al. Screening and prostate-cancer mortality in a randomized European study. N Engl J Med. Mar. 26. 2009;360(13):1320-8. [pmid: 19297566].
252 Andriole GL, Crawford ED, Grubb RL 3rd, et al. Mortality results from a randomized prostate-cancer screening trial. N Engl J Med. Mar. 26. 2009;360(13):1310-9. [pmid: 19297565].
253 Wolf MS, Feinglass J, Thompson J, et al. In search of ‘low health literacy’: threshold vs. gradient effect of literacy on health status and mortality. Soc Sci Med. 2010;70(9):1335-41. [pmid: 20167411].
254 Roter DL, Erby LH, Larson S, et al. Assessing oral literacy demand in genetic counseling dialogue: preliminary test of a conceptual framework. Soc Sci Med. Oct. 2007;65(7):1442-57. [pmid: 17614177].
255 Miller MJ, Abrams MA, McClintock B, et al. Promoting health communication between the community-dwelling well-elderly and pharmacists: the Ask Me 3 program. J Am Pharm Assoc. (2003). Nov-Dec. 2008;48(6):784-92.
256 Schillinger D, Bindman A, Wang F, et al. Functional health literacy and the quality of physician-patient communication among diabetes patients. Patient Educ Couns. Mar. 2004;52(3):315-23. [pmid: 14998602].
257 Schillinger D, Wang F, Palacios J, et al. Language, Literacy, and Communication Regarding Medication in an Anticoagulation Clinic: A Comparison of Verbal vs. Visual Assessment. Journal of Health Communication. 10. 2006;11(7):651-64. [pmid: 17074733].
258 Katz MG, Jacobson TA, Veledar E, et al. Patient literacy and question-asking behavior during the medical encounter: a mixed-methods analysis. J Gen Intern Med. Jun. 2007;22(6):782-6. [pmid: 17431697].
259 Sudore RL, Landefeld CS, Perez-Stable EJ, et al. Unraveling the relationship between literacy, language proficiency, and patient-physician communication. Patient Educ Couns. Jun. 2009;75(3):398-402. [pmid: 19442478].
260 Arthur SA, Geiser HR, Arriola KR, et al. Health literacy and control in the medical encounter: a mixed-methods analysis. J Natl Med Assoc. Jul. 2009;101(7):677-83. [pmid: 19634588].
261 Institute of Medicine. Measures of health litearcy, workshop summary. Available at: http://books.nap.edu/openbook.php?record_id=12690. Accessed.
262 Doak CC, Leonard G. Doak, Jane H. Root. Teaching Patients With Low Literacy Skills. 2nd ed. Philadelphia. Lippincott Co. 1996.
263 Snow CE. Reading for understanding: toward a research and development program in reading comprehension. 2002. Report No.: ISBN 0-8330-3105-8.
264 Petty RE, Barden J, Wheeler SJ. The Elaboration likelihood model of persuasion: Health Promtion that yield sustained behavior change. San Francisco. Jossey-Bass. 2002.
265 Cappella JN. Integrating message effects and behavioral change theories: organizing comments and unanswered questions. J Communicat. 2006;56(Suppl 1):S265-79.
266 Fagerlin A, Ubel PA, Smith DM, et al. Making numbers matter: present and future research in risk communication. Am J Health Behav. Sep-Oct. 31. 1. 2007:S47-56.
267 Lipkus IM. Numeric, verbal, and visual formats of conveying health risks: suggested best practices and future recommendations. Med Decis Making. Sep-Oct. 2007;27(5):696-713. [pmid: 17873259].
268 McGettigan P, Sly K, O'Connell D, et al. The effects of information framing on the practices of physicians. J Gen Intern Med. Oct. 1999;14(10):633-42. [pmid: 10571710].
269 Edwards A, Elwyn G, Covey J, et al. Presenting risk information--a review of the effects of “framing” and other manipulations on patient outcomes. J Health Commun. Jan-Mar. 2001;6(1):61-82. [pmid: 11317424].
270 Moxey A, O'Connell D, McGettigan P, et al. Describing treatment effects to patients. J Gen Intern Med. Nov. 2003;18(11):948-59. [pmid: 14687282].
271 Covey J. A meta-analysis of the effects of presenting treatment benefits in different formats. Med Decis Making. Sep-Oct. 2007;27(5):638-54. [pmid: 17873250].