# Conclusions

Our systematic review update confirms that lower health literacy as measured by poorer reading skills is associated with a range of adverse health outcomes. Evidence is beginning to emerge concerning the relationship between poorer numeracy skills and health outcomes but the evidence is still too weak to be confident of an association. We found no evidence evaluating oral (verbal) health literacy and health outcomes.

Rigorous, well-designed studies of interventions to mitigate the effects of low health literacy have been conducted since our earlier review. Future studies isolating one measurable and replicable component of an intervention will, however, be particularly helpful in building this body of evidence. Many studies have now been conducted with a variety of clinic populations. Future research could enhance our confidence in the more universal applicability of results by including more broadly based and representative samples.

Table 62 Health outcome study results (KQ1): summary and comparison of 2004 and 2010 systematic reviews

Outcome | Study design | Number of articles: 2004 (Number controlling for confounding) | Number of articles: 2010 (Number controlling for confounding) | Low Health Literacy Related Results: 2004 | Low Health Literacy Related Results: 2010 | Strength of Evidence: 2010
Hospitalization | Cohort | 2 (2) | 4 (3) | Increase | Increase | Moderate
Hospitalization | Cross-sectional | 0 | 2 (2) | Increase | Increase | Moderate
Emergency care visits | Cohort | 0 | 4 (3) | NA: no studies | Increase | Moderate
Emergency care visits | Cross-sectional | 0 | 3 (3) | NA: no studies | Increase | Moderate
Colon screening | Cross-sectional | 0 | 5(5) | NA: no studies | Decrease | Insufficient
Pap tests | Cross-sectional | 1(1) | 3(3) | Decrease | Decrease | Low
Mammogram | Cross-sectional | 1(1) | 4(4) | Decrease | Decrease | Moderate
STI (testing) | Cross-sectional | 1(1) | 1(1) | Increase | Increase | Low
Immunization: Influenza | Cohort | 0 | 1(1) | Decrease | Decrease | Moderate
Immunization: Influenza | Cross-sectional | 1(1) | 3(3) | Decrease | Decrease | Moderate
Immunization: Pneumococcal | Cohort | 0 | 1(1) | Decrease | Mixed | Insufficient
Immunization: Pneumococcal | Cross-sectional | 1(1) | 1(1) | Decrease | Mixed | Insufficient
Access to care | Cohort | 0 | 4(4) | No difference | Mixed | Insufficient
Access to care | Cross-sectional | 1(1) | 5(5) | No difference | Mixed | Insufficient
Access to insurance | Cross-sectional | 0 | 1(1) | NA: no studies | Decrease | Low
Knowledge | Cohort | 1 (0) | NA | Decrease | NA: analysis not repeated | Not re-evaluated
Knowledge | Cross-sectional | 9 (7) | NA | Decrease | NA: analysis not repeated | Not re-evaluated
Adherence | Cohort | 2 (0) | 6 (6) | Mixed | Mixed | Insufficient
Adherence | Cross-sectional | 2 (1) | 9 (9) | Mixed | Mixed | Insufficient
Self-efficacy | Cross-sectional | 0 | 5 (4) | NA: no studies | Mixed | Insufficient
Smoking | Cross-sectional | 3 (1) | 2 (2) | Mixed | Mixed | Insufficient
Alcohol and drug use | Cross-sectional | 1 (1) | 2 (2) | No difference | Mixed | Insufficient
Healthy lifestyle (physical activity, eating habits, and seat belt use) | Cross-sectional | 0 | 3 (3-for some outcomes) | NA: no studies | Mixed | Insufficient
Obesity and weight | Cohort | 0 | 1 (0) | NA: no studies | Mixed | Insufficient
Obesity and weight | Cross-sectional | 0 | 4 (1) | NA: no studies | Mixed | Insufficient
Review of prescription information | Cross-sectional | 0 | 1 (1) | NA: no studies | Decrease | Low
HIV risk and sexual behavior | Cohort | 0 | 1 (1) | NA: no studies | Mixed | Insufficient
HIV risk and sexual behavior | Cross-sectional | 0 | 1 (1) | NA: no studies | Mixed | Insufficient
Taking medications appropriately | Cohort | 0 | 1 (1) | NA: no studies | Decrease | Moderate
Taking medications appropriately | Cross-sectional | 0 | 4 (4) | NA: no studies | Decrease | Moderate
Interpreting labels and health messages | Cross-sectional | 0 | 5 (4) | NA: no studies | Decrease | Moderate
Asthma self care | Cross-sectional | 1 (1) | 1 (1) | Decrease | Decrease | Low
Mental health symptomatology | Cohort | 1 (0) | 2 (1) | Decrease | Greater in 8 studies | Low
Mental health symptomatology | Cross-sectional | 4 (2) | 8 (4) | Decrease | Greater in 8 studies | Low
Chronic disease | Cohort | 1 (1) | 2 (0) | No difference | Mixed | Insufficient
Chronic disease | Cross-sectional | 1 (1) | 5 (3) | No difference | Mixed | Insufficient
HIV severity and symptoms | Cohort | | 1 (1) | Mixed | No difference in 4 studies | Low
HIV severity and symptoms | Cross-sectional | 3 (0) | 4 (3) | Mixed | No difference in 4 studies | Low
Asthma severity and control | Cross-sectional | 0 | 2 (1) | NA: no studies | Mixed | Insufficient
Diabetes control and related symptoms | Cross-sectional | 3 (2) | 6 (5) | Mixed | Mixed | Insufficient
Hypertension control | Cross-sectional | 1 (1) | 2 (2) | No difference | Mixed | Insufficient
Prostate cancer control | Cross-sectional | 1 (1) | 1 (1) | No difference | Decrease | Low
Health status: all adults | Cross-sectional | 2 (2) | 1 (1) | Decrease | No difference | Low
Health status and QoL seniors: Mental & physical functioning: seniors | Cohort | 0 | 1 (1) | Decrease | Decrease | Moderate
Health status and QoL seniors: Mental & physical functioning: seniors | Cross-sectional | 1 (0) | 5 (4) | Decrease | Decrease | Moderate
Health status and QoL seniors: Mental & physical functioning: seniors | Cohort | | 3 (2) | NA: no studies | Mixed | Insufficient
Health status and QoL seniors: Mental & physical functioning: seniors | Cross-sectional | 0 | 2 (2) | NA: no studies | Mixed | Insufficient
Health status and QoL: specific diseases | Cross-sectional | 2 (0) | 5 (5) | No difference | Mixed | Insufficient
Mortality: seniors | Cohort | 0 | 3 (3) | NA: no studies | Greater | High
Costs | Cohort | 1 (1) | 2(2) | No difference | Mixed | Insufficient
Disparities | Cohort | 0 | 1 (1) | HL mediates racial disparity in 1 study | HL partially mediates: racial disparities in some outcomes, no differences in Hispanic ethnicity, sex differences for 1 outcome | Race: Low Hispanic ethnicity: Low Sex: Low
Disparities | Cross-sectional | 1 (1) | 5 (5) | HL mediates racial disparity in 1 study | HL partially mediates: racial disparities in some outcomes, no differences in Hispanic ethnicity, sex differences for 1 outcome | Race: Low Hispanic ethnicity: Low Sex: Low

HL=health literacy; NA=not applicable; QoL=quality of life; STI=sexually transmitted infection

Table 63 Numeracy outcome study results (KQ 1): summary of 2010 systematic review^*^

Outcome | Study design | Number of articles: 2010 (Number controlling for confounding) | Low Numeracy Literacy Related Results: 2010 | Strength of Evidence: 2010
Use of health care services | Cross-sectional | 1(1) | No effect | Low
Accuracy of risk perception | Cross-sectional | 5(3) | Mixed | Insufficient
Knowledge | Cross-sectional | 4(3) | Mixed | Insufficient
Self-efficacy | Cross-sectional | 1(0) | Decrease | Insufficient
Behavior | Cross-sectional | 1(0) | No effect | Insufficient
Skills | Cohort | 1(1) | Taking medication (n=4): Mixed Interpreting health information (n=2): Decrease | Taking medication: Insufficient Interpreting health information: Low
Skills | Cross-sectional | 5(4) | Taking medication (n=4): Mixed Interpreting health information (n=2): Decrease | Taking medication: Insufficient Interpreting health information: Low
Disease prevalence and severity | Cross-sectional | 3(2) | Mixed | Insufficient
Disparities | Cross-sectional | 2(2) | Numeracy partially mediates the relationship between race and 1 outcome and between gender and 1 outcome | Low

* Numeracy studies were not included in the 2004 review

n=number

Table 64 Results of intervention studies with single design strategies (KQ 2): summary and comparison of 2004 and 2010 systematic reviews *

Design Strategy | Study design | Number of articles (Number stratifying results by HL level): 2004 | Number of articles (Number stratifying results by HL level): 2010 | Low Health Literacy Related Results: 2004 | Low Health Literacy Related Results: 2010 | Strength of Evidence: 2010
Alternative Document Design | RCT | 1(1) | 2(2) | Increased | Increased | Low
Alternative Numerical Presentation | RCT | 0 | 3(3) | NA | Increased | Low
Additive and Alternative Pictorial Representation | RCT | 0 | 8(5) | NA | Mixed | Insufficient
Additive and Alternative Pictorial Representation | Quasi (pre/post) | 0 | 8(5) | NA | Mixed | Insufficient
Alternative Media | RCT | 1(1) | 4(3) | Mixed | Mixed | Insufficient
Alternative Media | NRCT | 2(1) | 4(3) | Mixed | Mixed | Insufficient
Alternative Readability and Document Design | RCT | 2(0) | 6(3) | Mixed | Mixed | Insufficient
Alternative Readability and Document Design | Quasi (post) | 0 | 1(1) | Mixed | Mixed | Insufficient
Alternative Readability and Document Design | NRCT | 3(3) | 1(1) | Mixed | Mixed | Insufficient
Physician Notification of HL Level | cRCT | 0 | 1(1) | NA | No effect (patient outcomes) | Low

* Studies in 2004 report reorganized into 2010 framework (e.g. single vs. multiple design strategy interventions) for reporting cRCT=cluster randomized controlled trial; HL=health literacy; NA=not applicable; NRCT=non-randomized controlled trial; quasi=quasi-experimental study; RCT=randomized controlled trial

Table 65 Results of interventions with multiple design strategies: summary and comparison of 2004 and 2010 systematic reviews^*^

Outcome | Study design | Number of articles (Number stratifying results by HL level): 2004 | Number of articles (Number stratifying results by HL level): 2010 | Low Health Literacy Related Results: 2004 | Low Health Literacy Related Results: 2010 | Strength of Evidence: 2010
Knowledge | RCT | 2(1) | 3(1) | Mixed | Mixed | Insufficient
Knowledge | Quasi (pre/post) | 1(0) | 5(2) | Mixed | Mixed | Insufficient
Knowledge | Quasi (post) | 1(0) | 2(2) | Mixed | Mixed | Insufficient
Knowledge | NRCT | 1(0) | 0 | Mixed | Mixed | Insufficient
Self-efficacy | RCT | 0 | 4(1) | NA | Mixed | Insufficient
Self-efficacy | Quasi (pre/post) | 0 | 4(0) | NA | Mixed | Insufficient
Self-efficacy | Quasi (post) | 0 | 1(0) | NA | Mixed | Insufficient
Behavioral Intent | | 0 | 0 | NA | NA | NA
Skill | RCT | 0 | 1(1) | Mixed | Increased | Insufficient^*^
Skill | Quasi (pre/post) | 1(1) | 0 | Mixed | Increased | Insufficient^*^
Skill | NRCT | 1(0) | 0 | Mixed | Increased | Insufficient^*^
Behavior | RCT | 2 (0) | 2(0) | Nutrition interventions: Mixed | Self-management interventions: Increased | Self-management interventions: Moderate Nutrition interventions: Insufficient
Behavior | Quasi (pre/post) | 0 | 1(1) | Nutrition interventions: Mixed | Self-management interventions: Increased | Self-management interventions: Moderate Nutrition interventions: Insufficient
Behavior | NRCT | 1 | 0 | Nutrition interventions: Mixed | Self-management interventions: Increased | Self-management interventions: Moderate Nutrition interventions: Insufficient
Adherence | RCT | 0 | 2(0) | No effect | Mixed | Insufficient
Adherence | Quasi (pre/post) | 0 | 1(1) | No effect | Mixed | Insufficient
Adherence | Quasi (post) | 0 | 1(1) | No effect | Mixed | Insufficient
Adherence | NRCT | 1 (0) | 0 | No effect | Mixed | Insufficient
Disease Prevalence and Severity | RCT | 3(0) | 4(2) | No effect | Self-management: Insufficient Disease management: Moderate Adult basic and Lit. Education: Low | Self-management: Insufficient Disease management: Moderate Adult Basic and Education: Low
Disease Prevalence and Severity | Quasi | 0 | 3(3) | No effect | Self-management: Insufficient Disease management: Moderate Adult basic and Lit. Education: Low | Self-management: Insufficient Disease management: Moderate Adult Basic and Education: Low
Quality of Life | RCT | 0 | 4(0) | NA | Mixed | Insufficient
Preventive service use | RCT | 0 | 1(0) | NA | Increased | Moderate
Preventive service use | cRCT | 0 | 1(1) | NA | Increased | Moderate
Emergency Room Visits | RCT | 0 | 1(0) | NA | Reduced | Moderate
Emergency Room Visits | Quasi (pre/post) | 0 | 1(1) | NA | Reduced | Moderate
Hospitalization | RCT | 0 | 2(1) | NA | Reduced | Moderate
Hospitalization | Quasi (pre/post) | 0 | 1(1) | NA | Reduced | Moderate
Cost | RCT | 0 | 2(0) | NA | Mixed | Insufficient
Disparities | | 0 | 0 | NA | NA | Insufficient

* Studies in 2004 report reorganized into 2010 framework (e.g. single vs. multiple design strategy interventions) for reporting cRCT=cluster randomized controlled trial; NA=not applicable; NRCT=non-randomized controlled trial; quasi=quasi-experimental study; RCT=randomized controlled trial