# Summary of KQ 1 Findings from Literacy and Health Outcomes Report

Table 5 Summary of studies of relationship between health services, outcomes, costs, or disparities and literacy (KQ 1)

Study | Design | Health Measure | Literacy Measure | Results
Use of Health Care Services
Knowledge of Health Care Services
Davis et al., 1996^1^ | Cross-sectional | Knowledge and attitudes regarding mammography screening | REALM | Higher literacy level was associated with reasons why women get mammograms.
Lindau et al., 2002^2^ | Cross-sectional | Cervical cancer screening practices | REALM | Higher literacy was associated with being more knowledgeable of the purpose of Pap test.
Miller et al., 1996 3 | Cross-sectional | Adequacy of clinical trials information (informed consent) | WRAT | Higher literacy level was moderately correlated with understanding informed consent.
Moon et al., 1998^4^ | Prospective cohort | Understanding of medical information and ability to follow therapy prescribed for child | REALM | No correlation between literacy and parental knowledge of health maintenance procedures or child health measures.
Spandorfer et al., 1995^5^ | Prospective observational cohort | Emergency department discharge instructions | WRAT | Higher literacy level was associated with comprehension of instructions.
TenHave et al., 1997^6^ | Cross-sectional | Heart health knowledge | CARDES | Higher literacy level was associated with greater knowledge of matters relating to use of these health services.
Risk of Hospitalization
Baker et al., 2002^7^ | Prospective cohort | Hospitalization | S-TOFHLA | Patients with inadequate literacy were more likely than patients with adequate literacy to be hospitalized.
Baker et al., 1998^8^ | Prospective cohort | Hospitalization | TOFHLA | Patients with inadequate literacy were more likely than patients with adequate literacy to be hospitalized.
Physician Visits
Baker et al., 1997^9^ | Cross-sectional | Self-reported health and use of health services | TOFHLA | There was no association between literacy status and self-reported access to physician visits after adjusting for age, health status, and economic indicators.
Screening and Prevention
Fortenbury et al., 2001^10^ | Cross-sectional | Receipt of a screening for gonorrhea in the past year | REALM | Higher literacy was associated with an increase in the probability of having a gonorrhea test in the past year.
Scott et al., 2002^11^ | Cross-sectional | New Medicare enrollees in a national managed care organization preventive care utilization | S-TOFHLA | Patients with inadequate literacy were more likely to have never had a Pap smear or a mammogram in the past 2 years. Patients with inadequate literacy were less likely to have had either an influenza or pneumococcal immunization.
Health Outcomes
Knowledge or Comprehension of Outcomes
Arnold et al., 2001^12^ | Cross-sectional | Knowledge, attitudes, and practice of tobacco use among pregnant women | REALM | Literacy was a predictor for knowledge of effects of smoking and secondhand smoke.
Conlin and Schumann, 2002^13^ | Cross-sectional | Analysis of standard discharge instructions and forms for open heart surgery after recovery from open heart surgery | REALM | Literacy level was correlated with understanding standard discharge instructions and forms.
Gazmararian et al., 1999^14^ | Cross-sectional | Family planning knowledge and practices among Medicaid managed care enrollees | S-TOFHLA | Women wanting to know more about birth control were more likely to have low reading skills. Incorrect knowledge of “time of month most likely to get pregnant” was higher among women with low reading skills.
Kalichman et al., 2000^15^ | Cross-sectional | HIV-infected patients' knowledge and understanding of their status and perceptions of treatment effects on transmission risks | Modified TOFHLA | Lower literacy was associated with not understanding CD4 counts or meaning of viral load. Lower literacy was associated with incorrect beliefs about HIV treatments and transmission risks.
Kalichman and Rompa, 2000^16^ | Cross-sectional | Health status awareness and understanding of HIV infection status, disease, and treatment-related knowledge | Modified TOFHLA | Lower literacy was associated with lack of knowledge and understanding of HIV-related health markers. Higher literacy group had higher knowledge of HIV disease and treatment than lower literacy group. Lower literacy group had more negative perceptions and experiences related to HIV-AIDS.
Kalichman et al., 2000^17^ | Cross-sectional | Reliability and validity of self-reported HIV-related health markers in HIV-infected adults | Modified TOFHLA | Lower literacy was more likely to have discrepant self-reported CD4 counts or viral loads.
Miller et al., 2003^18^ | Prospective cohort | Dosing and compliance of HIV-infected individuals taking antiretroviral medication | S-TOFHLA | Lower medication knowledge was significantly associated with lower literacy.
Williams et al., 1998^19^ | Cross-sectional | Chronic disease and treatment among patients with diabetes or hypertension | TOFHLA | Patients with low literacy had less knowledge about diabetes and hypertension.
Williams et al., 1998^20^ | Cross-sectional | Knowledge about asthma | REALM | Knowledge increased with literacy.
Wilson and McLemore, 1997^21^ | Cross-sectional | Patients hospitalized for knee or hip surgery “self-care” knowledge after education with written discharge instructions | REALM | The relationship between literacy and self-care knowledge after written education materials was not significant.
Health Behaviors and Adherence
Arnold et al., 2001^12^ | Cross-sectional | Knowledge, attitude, and practices of tobacco use among pregnant women | REALM | No difference in the unadjusted rates of smoking according to literacy status.
Davis et al., 1999^22^ | Cross-sectional | Violent behavior in adolescents | Slosson Oral Reading Test | Youth who were more than two grades behind expected reading level were more likely than others to carry a weapon including a gun, take a weapon to school, miss school because it was unsafe, and be in a physical fight that required medical treatment.
Frack et al., 1997^23^ | Cross-sectional | Compliance with research protocols in a clinical trial | Cloze procedure | Patients who followed up as directed had a higher average literacy score than those who never followed up.
Fredrickson et al., 1995^24^ | Cross-sectional | Breast-feeding | WRAT | An association was found between low reading ability and never breast-feeding.
Fredrickson et al., 1995^24^ | Cross-sectional | Smoking | WRAT | An association between low reading ability and smoking.
Golin et al, 2002^25^ | Prospective cohort | Adherence among HIV-infected patients taking antiretrovirals | S-TOFHLA | No relationship between literacy and adherence was found.
Hawthorne, 1996^26^ | Cross-sectional | Tobacco use among 11 and 12 year olds | NR | A relationship between literacy and ever having used tobacco among boys but not among girls. The relationship between literacy and using tobacco in the past month was strong among both boys and girls.
Hawthorne, 1996^26^ | Cross-sectional | Alcohol use in adolescence | NR | Odds of having misused alcohol were higher among boys with lower literacy levels than among boys with higher literacy levels. No significant relationship emerged for girls by literacy level.
Kalichman et al., 1999^27^ | Cross-sectional | Adherence to treatment for HIV and AIDS | Modified TOFHLA | Lower literacy was associated with greater odds of poor adherence.
Kaufman et al., 2001^28^ | Cross-sectional | Breast-feeding | REALM | Women with literacy levels at or above 9th grade were more likely to breast-feed for at least 2 months than mothers with literacy at the 7th or 8th grade level.
Li et al., 2000 29 | Retrospective case study | Adherence to breast conservation therapy in women with early-stage breast cancer | REALM | Literacy did not ignore predict adherence to radiation, chemotherapy, or clinical appointments.
Stanton et al., 1990^30^ | Prospective cohort | Problem behavior in children | Burt Word Reading Test | Reading ability was an independent predictor of teacher-reported problem behavior.
Williams et al., 1998^20^ | Cross-sectional | Correct use of metered dose inhaler by patients with asthma | REALM | Patients with higher literacy had better metered dose inhaler technique.
Biochemical and Biometric Health Outcomes
Battersby et al., 1993^31^ | Case-control | Diagnosis of hypertension | Schonell Graded Word Reading Test | No difference in reading ability between patients with or without hypertension was found.
Kalichman and Rompa, 2000^32^ | Cross-sectional | HIV infection | Modified TOFHLA | No significant association between reading comprehension and undetectable viral load.
Kalichman et al., 2000^15^ | Cross-sectional | HIV infection, optimism, and perceptions of care | Modified TOFHLA | Patients with better reading comprehension had greater odds of having an undetectable viral load than those with worse reading comprehension. No significant association between reading comprehension and undetectable viral load was found. Patients with lower literacy tended to be more optimistic about their future living with HIV.
Kalichman and Rompa, 2000^16^ | Cross-sectional | HIV infection, optimism, and perceptions of care | Modified TOFHLA | Better readers had greater odds of having an undetectable viral load than worse readers. Worse readers had greater odds of having a CD4 count less than 300 than did better readers. Patients with lower literacy had more distrust of providers and were less likely to believe that treatment helps.
Ross et al., 2001^33^ | Cross-sectional | Glycemic control in children with type 1 diabetes | WRAT3, children; NART, mothers | No significant correlation between literacy in children aged 5 to 17 and glycemic control. Parent's literacy was correlated with the child's glycemic control.
Schillinger et al., 2002^34^ | Cross-sectional | Glycemic control in adults with type 2 diabetes | S-TOFHLA | Patients with lower literacy had worse glycemic control. The glycemic level was found to be inversely related to literacy.
Williams et al., 1998^19^ | Cross-sectional | Glycemic control in adults with type 2 diabetes | TOFHLA | Knowledge of diabetes was lower for patients with a low literacy status. No differences were found in the control of diabetes according to literacy status.
Williams et al., 1998^19^ | Cross-sectional | Patients diagnosed with hypertension | TOFHLA | Knowledge of hypertension was lower for patients with low literacy status. No differences were found in the control of hypertension according to literacy status.
Measures of Disease Prevalence, Incidence, or Morbidity
Andrasik et al., 1988^35^ | Case-control | Children with and without migraines | WRAT | No significant difference in literacy scores between the two groups was found.
Bennett et al., 1998^36^ | Cross-sectional | Stage of presentation of prostate cancer | REALM | Men with lower literacy were more likely to present with late-stage prostate cancer than those with higher literacy. After adjusting for race, age, and location of care, the investigators found that the relationship between literacy and stage of presentation was smaller and no longer statistically significant.
Fisch et al., 1998^37^ | Cross-sectional | Emotional balance after receiving informed consent materials for a bone marrow transplant | WRAT | No significant relationship between the patterns of affects changes and literacy.
Gazmararian et al., 2000^38^ | Cross-sectional | Self-reports of depression in a Medicare population | S-TOFHLA | The odds of being depressed were greater for those people with inadequate literacy compared to those with adequate literacy. After adjusting for demographic, social support, health behavior, and health status factors, the correlation was no longer statistically significant. A significant relationship between literacy and depression could not be observed. No significant relationship was found after adjusting for age and health status.
Gordon et al., 2002^39^ | Cross-sectional | Arthritis and functional status of patients with rheumatoid arthritis | REALM | Health activity did not differ according to literacy dichotomized at the 9th grade level.
Gordon et al., 2002^39^ | Cross-sectional | Self-report of depression in patients with rheumatoid arthritis | REALM | Patients with more anxiety and depression were greater among those who read below the 9th grade level than among those who read at or above the 9th grade level.
Kalichman and Rompa, 2000^32^ | Cross-sectional | Self-reported depression in HIV-infected patients | Modified TOFHLA | Total scores on the depression scales did not differ by literacy status. Some depression subscales were higher (representing more depression) for participants with lower literacy.
TenHave et al., 1997^6^ | Cross-sectional | Self-reports of depression in adults participating in a cardio-vascular dietary education program | CARDES | Lower scores on the literacy assessment were statistically significantly associated with higher scores on the depression assessment after adjusting for age, suggesting a greater propensity for depression among those with lower literacy.
Zaslow et al., 2001^40^ | Cohort | Mothers' reports of child's depression and antisocial behavior | Test of Applied Literary Skills | Risk of depression was higher among mothers who had lower literacy skills. No relationship was detected between maternal literacy and depression or antisocial behavior among their children.
Global Health Status Measures
Baker et al., 1997^9^ | Cross-sectional | Overall health status | TOFHLA | Patients with inadequate literacy had about twice the odds of reporting poor health than patients with adequate literacy.
Gazmararian, et al., 1999^41^ | Cross-sectional | Medicare managed care health plan | S-TOFHLA | Patients with inadequate literacy were significantly more likely to self-report fair or poor health than patients with adequate literacy.
Sullivan et al., 1995^42^ | Cross-sectional | General health status of patients with type 2 diabetes | QLS | No difference in scores on the SF-36 according to whether the subject “passed” or “failed” the QLS.
Weiss et al., 1992^43^ | Cross-sectional | Health status | Tests of Adult Basic Education and Mott Basic Language Skills Program | People with lower literacy scored worse than those with higher literacy on both the physical and psychosocial subcomponents.
Cost of Health Care
Weiss et al., 1994^44^ | Retrospective cohort | Costs of health care in Medicaid patients | Instrument for the Diagnosis of Reading | No relationship between literacy and Medicaid charges.
Disparities in Health Outcomes or Use of Health Services
Bennett et al., 1998^36^ | Cross-sectional | Men who presented with late-stage prostate cancer | REALM | Black patients were significantly more likely than white patients to present with late-stage cancer. After adjusting for literacy, age, and location of care, the odds ratio was smaller and no longer statistically significant.

Note: REALM=Rapid Estimate of Adult Literacy in Medicine; WRAT=Wide Range Achievement Test; CARDES=Cardiovascular Education Dietary System; TOFHLA=Test of Functional Health Literacy in Adults; S-TOFHLA=Short-TOFHLA; NR=not reported.

Table 8 Studies of knowledge or comprehension of health service use (KQ 1a)

Study | Population | Results
Davis et al., 1996^1^ | Low-income women at an ambulatory clinic at Louisiana State University at Shreveport | Lower literacy correlated with lower knowledge about mammograms (adjusted)
Lindau et al., 2002^2^ | Women in women's health clinics at an academic medical center in Chicago, predominantly Medicaid insurance | Higher literacy associated with more knowledge about cervical cancer screening (adjusted)
Miller et al., 1996^3^ | Participants enrolling in anti-infective clinical trials | Moderate correlation between literacy and understanding of informed consent (unadjusted)
Moon et al., 1998^4^ | Parents of children in urban and suburban pediatric practices in Washington, DC | No correlation between literacy and parental knowledge of health maintenance procedures or child health measures (adjusted)
Spandorfer et al., 1995^5^ | Impoverished inner-city patients at an emergency department in Philadelphia | Reading ability was best predictor of knowledge of discharge instructions (adjusted)
TenHave et al., 1997^6^ | Community members coming to a cholesterol screening at a local supermarket | Higher literacy associated with more “Heart Healthy Knowledge” (P value not reported) (unadjusted)

Table 9 Studies of knowledge or comprehension of health outcomes (KQ 1b)

Study | Population | Results
Arnold et al., 2001^12^ | Predominantly Medicaid or uninsured pregnant women | Low literacy predicted lower knowledge about smoking effects (adjusted)
Conlin and Schumann, 2002^13^ | Patients recovering from open heart surgery at a teaching hospital | Lower literacy correlated with lower score on knowledge test of discharge instructions (unadjusted)
Gazmararian et al., 1999^14^ | Female Medicaid managed care enrollees in Memphis, Tennessee | Lower literacy associated with less knowledge of time most likely to get pregnant during menstrual cycle (adjusted)
Kalichman et al., 2000^15^ | HIV-infected individuals living in Atlanta, Georgia | Higher literacy associated with higher likelihood of understanding the meaning of the CD4 count or viral load (adjusted)
Kalichman and Rompa, 2000^16^ | HIV-infected individuals living in Atlanta, Georgia | Lower literacy associated with less understanding of meaning of CD4 counts and viral load; lower literacy associated with less knowledge of disease and treatment based on 14-item questionnaire (adjusted)
Kalichman et al., 2000^17^ | HIV-infected individuals living in Atlanta, Georgia | Higher literacy associated with knowledge of CD4 counts and viral load (adjusted)
Miller et al., 2003^18^ | HIV-infected patients in a public hospital affiliated clinic | Literacy associated with knowledge of antiretroviral medication (unadjusted)
Williams et al., 1998^19^ | Patients with diabetes or hypertension attending a primary care clinic at a public hospital in Los Angeles or Atlanta | Higher literacy associated with more knowledge about hypertension and diabetes (adjusted)
Williams et al., 1998^20^ | Adult asthma patients in the emergency department at Grady Memorial Hospital | Higher literacy associated with more asthma knowledge (adjusted)
Wilson and McLemore, 1997^21^ | Patients hospitalized for knee or hip surgery | No correlation between literacy level and patients' level of knowledge about self-care after receiving written education materials (unadjusted)

Table 10 Studies of the relationship between literacy and depression (KQ 1b)

Study | Population | Results
Gazmararian et al., 2000^38^ | Elderly persons without dementia in a Medicare health plan | Marginal literacy associated with lower rate of depression (adjusted)
TenHave et al., 1997^6^ | Mostly black middle-aged and elderly persons attending a supermarket cholesterol screening | Lower literacy associated with higher depression scores (adjusted)
Kalichman and Rompa, 2000^32^ | Mostly black middle-aged HIV-positive patients | Lower literacy associated with more symptoms of depression (unadjusted)
Gordon et al., 2002^39^ | Mostly white middle-aged rheumatoid arthritis patients | Lower literacy associated with higher rate of depression (unadjusted)
Zaslow et al., 2001^40^ | Black young adult mothers who qualified for Aid to Families with Dependent Children | Lower literacy associated with higher rate of depression (unadjusted)

Table 11 Studies of the relationship between literacy and global health status (KQ 1b)

Study | Population | Results
Weiss et al., 1992^43^ | Young English-speaking adult students in an adult education class | Lower literacy associated with poorer health status score (adjusted)
Baker et al., 1997^9^ | Middle-aged English- and Spanish-speaking patients of hospital walk-in clinics or emergency departments | Lower literacy associated with poorer health status rating (adjusted)
Sullivan et al., 1995^42^ | Middle-aged and elderly patients with type 2 diabetes | No difference in physical functioning and literacy
Gazmararian et al., 1999^41^ | Elderly Spanish- and English-speaking Medicare beneficiaries without dementia | Lower literacy associated with poorer health status rating (unadjusted)

## References

1 Davis T, Arnold C, Berkel H, et al. Knowledge and attitude on screening mammography among low-literate, low-income women. Cancer. 1996;78(9):1912-20. [pmid: 8909311].
2 Lindau ST, Tomori C, Lyons T, Langseth L, Bennett CL, Garcia P. The association of health literacy with cervical cancer prevention knowledge and health behaviors in a multiethnic cohort of women. Am J Obstet Gynecol. 2002;186(5):938-43. [pmid: 12015518].
3 Miller CK, O'Donnell DC, Searight HR, Barbarash RA. The Deaconess Informed Consent Comprehension Test: an assessment tool for clinical research subjects. Pharmacotherapy. 1996;16(5):872-8. [pmid: 8888082].
4 Moon RY, Cheng TL, Patel KM, Baumhaft K, Scheidt PC. Parental literacy level and understanding of medical information. Pediatrics. 1998;102(2):e25. [pmid: 9685471].
5 Spandorfer JM, Karras DJ, Hughes LA, Caputo C. Comprehension of discharge instructions by patients in an urban emergency department. Ann Emerg Med. 1995;25(1):71-4. [pmid: 7802373].
6 TenHave TR, Van Horn B, Kumanyika S, Askov E, Matthews Y, Adams-Campbell LL. Literacy assessment in a cardiovascular nutrition education setting. Patient Educat Counsel. 1997;31(2):139-50.
7 Baker D, Gazmararian J, Williams M, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. Am J Pub Health. 2002;92(8):1278-83. [pmid: 12144984].
8 Baker DW, Parker RM, Williams MV, Clark WS. Health literacy and the risk of hospital admission. J Gen Int Med. 1998;13(12):791-8.
9 Baker DW, Parker RM, Williams MV, Clark WS, Nurss J. The relationship of patient reading ability to self-reported health and use of health services. Am J Pub Health. 1997;87(6):1027-30. [pmid: 9224190].
10 Fortenberry J, McFarlane M, Hennessy M, et al. Relation of health literacy to gonorrhoea related care. Sex Trans Infect. 2001;77(3):206-11.
11 Scott TL, Gazmararian JA, Williams MV, Baker DW. Health literacy and preventive health care use among Medicare enrollees in a managed care organization. Med Care. 2002;40(5):395-404. [pmid: 11961474].
12 Arnold C, Davis T, Berkel H, Jackson R, Nandy I, London S. Smoking status, reading level, and knowledge of tobacco effects among low-income pregnant women. Prevent Med. 2001;32(4):313-20.
13 Conlin K, Schumann L. Research. Literacy in the health care system: a study on open heart surgery patients. J Am Acad Nurse Pract. 2002;14(1):38-42. [pmid: 11845640].
14 Gazmararian JA, Parker RM, Baker DW. Reading skills and family planning knowledge and practices in a low-income managed-care population. Obstet Gynecol. 1999;93(2):239-44. [pmid: 9932563].
15 Kalichman SC, Benotsch E, Suarez T, Catz S, Miller J, Rompa D. Health literacy and health-related knowledge among persons living with HIV/AIDS. Am J Prev Med. 2000;18(4):325-31. [pmid: 10788736].
16 Kalichman SC, Rompa D. Functional health literacy is associated with health status and health-related knowledge in people living with HIV-AIDS. J Acq Immune Def Synd Hum Retrovirol. 2000;25(4):337-44.
17 Kalichman SC, Rompa D, Cage M. Reliability and validity of self-reported CD4 lymphocyte count and viral load test results in people living with HIV/AIDS. Int J STD & AIDS. 2000;11(9):579-85. [pmid: 10997499].
18 Miller LG, Liu H, Hays RD, et al. Knowledge of antiretroviral regimen dosing and adherence: a longitudinal study. Clin Infect Dis. 2003;36(4):514-8. [pmid: 12567311].
19 Williams MV, Baker DW, Parker RM, Nurss JR. Relationship of functional health literacy to patients' knowledge of their chronic disease. A study of patients with hypertension and diabetes. Arch Int Med. 1998;158(2):166-72. [pmid: 9448555].
20 Williams MV, Baker DW, Honig EG, Lee TM, Nowlan A. Inadequate literacy is a barrier to asthma knowledge and self-care. Chest. 1998;114(4):1008-15. [pmid: 9792569].
21 Wilson FL, McLemore R. Patient literacy levels: a consideration when designing patient education programs. Rehab Nursing. 1997;22(6):311-7.
22 Davis TC, Byrd RS, Arnold CL, Auinger P, Bocchini JAJ. Low literacy and violence among adolescents in a summer sports program. J Adolesc Health. 1999;24(6):403-11. [pmid: 10401968].
23 Frack S, Woodruff S, Candelaria J, Elder J. Correlates of compliance with measurement protocols in a Latino nutrition-intervention study. Am J Prevent Med. 1997;13(2):131-6.
24 Fredrickson DD, Washington RL, Pham N, Jackson T, Wiltshire J, Jecha LD. Reading grade levels and health behaviors of parents at child clinics. Kansas Med. 1995;96(3):127-9.
25 Golin CE, Liu H, Hays RD, et al. A prospective study of predictors of adherence to combination antiretroviral medication. J Gen Intern Med. 2002;17(10):756-65. [pmid: 12390551].
26 Hawthorne G. Preteenage drug use in Australia: the key predictors and school-based drug education. J Adolesc Health. 1996;20(5):384-95. [pmid: 9168386].
27 Kalichman SC, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. J Gen Int Med. 1999;14(5):267-73.
28 Kaufman H, Skipper B, Small L, Terry T, McGrew M. Effect of literacy on breast-feeding outcomes. South Med J. 2001;94(3):293-6. [pmid: 11284516].
29 Li B, Brown W, Ampil F, Burton G, Yu H, McDonald J. Patient compliance is critical for equivalent clinical outcomes for breast cancer treated by breast-conservation therapy. Ann Surg. 2000;231(6):883-9. [pmid: 10816632].
30 Stanton WR, Feehan M, McGee R, Silva PA. The relative value of reading ability and IQ as predictors of teacher-reported behavior problems. J Learn Disabil. 1990;23(8):514-7. [pmid: 2246604].
31 Battersby C, Hartley K, Fletcher A, et al. Cognitive function in hypertension: a community based study. J Hum Hyperten. 1993;7(2):117-23.
32 Kalichman SC, Rompa D. Emotional reactions to health status changes and emotional well-being among HIV-positive persons with limited reading literacy. J Clin Psychol Med Set. 2000;7(4):203-11.
33 Ross LA, Frier BM, Kelnar CJ, Deary IJ. Child and parental mental ability and glycaemic control in children with Type 1 diabetes. Diabetic Med. 2001;18(5):364-9. [pmid: 11472446].
34 Schillinger D, Grumbach K, Piette J, et al. Association of health literacy with diabetes outcomes. J Am Med Assoc. 2002;288(4):475-82.
35 Andrasik F, Kabela E, Quinn S, Attanasio V, Blanchard EB, Rosenblum EL. Psychological functioning of children who have recurrent migraine. Pain. 1988;34(1):43-52. [pmid: 3405619].
36 Bennett C, Ferreira M, Davis T, et al. Relation between literacy, race, and stage of presentation among low-income patients with prostate cancer. J Clin Oncol. 1998;16(9):3101-4. [pmid: 9738581].
37 Fisch M, Unverzagt F, Hanna M, Bledsoe P, Menke C, Cornetta K. Information preferences, reading ability, and emotional changes in outpatients during the process of obtaining informed consent for autologous bone-marrow transplantation. J Cancer Educat. 1998;13(2):71-5.
38 Gazmararian J, Baker D, Parker R, Blazer D. A multivariate analysis of factors associated with depression: evaluating the role of health literacy as a potential contributor. Arch Int Med. 2000;160(21):3307-14. [pmid: 11088094].
39 Gordon MM, Hampson R, Capell HA, Madhok R. Illiteracy in rheumatoid arthritis patients as determined by the Rapid Estimate of Adult Literacy in Medicine (REALM) score. Rheumatol. 2002;41(7):750-4.
40 Zaslow MJ, Hair EC, Dion MR, Ahluwalia SK, Sargent J. Maternal depressive symptoms and low literacy as potential barriers to employment in a sample of families receiving welfare: are there two-generational implications?. Women Health. 2001;32(3):211-51. [pmid: 11480894].
41 Gazmararian J, Baker D, Williams M, et al. Health literacy among Medicare enrollees in a managed care organization. J Am Med Assn. 1999;281(6):545-51.
42 Sullivan LM, Dukes KA, Harris L, Dittus RS, Greenfield S, Kaplan SH. A comparison of various methods of collecting self-reported health outcomes data among low-income and minority patients. Med Care. 1995;33(4 Suppl):AS183-94. [pmid: 7723446].
43 Weiss BD, Hart G, McGee DL, D'Estelle S. Health status of illiterate adults: relation between literacy and health status among persons with low literacy skills. J Am Board Fam Pract. 1992;5(3):257-64. [pmid: 1580173].
44 Weiss BD, Blanchard JS, McGee DL, et al. Illiteracy among Medicaid recipients and its relationship to health care costs. J Health Care Poor Underserved. 1994;5(2):99-111. [pmid: 8043732].