# Articles by Database Search

## CINAHL = 93 (excluding duplicates)

1 Bridging the gulf between health care providers and back pain sufferers: understanding health literacy. Bone & Joint. 09. 2004;10(8):94.
2 Understanding how health literacy impacts patient safety. Briefings on Patient Safety. 07. 2004;5(7):1-8.
3 Health care literacy gap is addressed. Same Day Surg. 04. 02. 2007:4.
4 The library column. Health literacy: why should dental hygienists be concerned about literacy?. Canadian Journal of Dental Hygiene. 07. 2007;41(4):202.
5 Making the message clear… Fyalka T. Uncovering the secret nearly 50% of your patients may be keeping. Ill Dent News. Sept. Dent Abstr. 2007 03. 2006;52(2):4-5. 80.
6 Patient confusion over health info. World of Irish Nursing & Midwifery. 12. 2007;15(11):53.
7 Strategies for improving health literacy. Joint Commission Perspectives on Patient Safety. 03. 2008;8(3):8-9.
8 AHRQ introduces new Pharmacy Health Literacy Center. AHRQ Research Activities. 2009;(352):21.
9 Better educational materials are needed to boost the health literacy of individuals who are deaf. AHRQ Research Activities. 2009;(352):8.
10 Bulletin board AHRQ launches health literacy measurement tools. J AHIMA. 2009;80(3):12.
11 Concept Analysis of Health Literacy. Journal of Nursing. 2009;56(5):93-7.
12 Family council can help make materials readable: revamping written handout distribution. Patient Education Management. 2009;16(4):42.
13 For best results, create systemwide plan for overcoming literacy barriers: organized committee tackles specific projects along the lines of members' expertise. Patient Education Management. 2009;16(11):121-3.
14 A health literacy example: revising a HIPAA privacy notice. ASHA Leader. 2009;14(2):29.
15 Health literacy is linked to personal happiness. AHRQ Research Activities. 2009;(350):12.
16 Health literacy: one pillar of patient education. Briefings on Patient Safety. 2009;10(6):6-8.
17 Iowa Health System addresses health literacy within state facilities by adopting patient-centered approaches. Briefings on Patient Safety. 2009;10(3):5-6.
18 It takes two to improve health communication: both consumers and health care providers have a role. Patient Education Management. 2009;16(12):137-8.
19 Lack of compliance may mean patients don't understand. Case Management Advisor. 2009;20(8):85-7.
20 Lack of compliance may mean patients misunderstand: low health literacy contributes to readmissions. Patient Education Management. 2009;16(9):103-5.
21 Local beat. Nursing Spectrum New York & New Jersey Edition. 2009;21(21):2-3.
22 Log on for health literacy materials. American Dental Association News. 2009;40(2):11.
23 To improve health literacy, follow Ql model: goal is to create a culture change. Patient Education Management. 2009;16(11):124-5.
24 Volunteers address low health literacy: provide someone to teach tasks. Patient Education Management. 2009;16(5):54-5.
25 AHRQ releases a new health literacy tool. AHRQ Research Activities. 2010;(354):18.
26 Awards aim to promote health literacy. World of Irish Nursing & Midwifery. 2010;18(1). [39].
27 Health literacy competencies staff should have. Patient Education Management. 2010;17(3):29.
28 Knowledge of health literacy vital for role of patient education manager: it impacts almost every task required in job description. Patient Education Management. 2010;17(3):25-8.
29 TJC: time is now to examine communication with LEP patients: new Joint Commission standards link with requirements of U.S. law. Patient Education Management. 2010;17(2):13-5.
30 To improve health literacy, follow QI model: goal is to create a culture change. Healthcare Benchmarks & Quality Improvement. 2010;17(1):10. [pmid: 20121010].
31 Banas J. A tailored approach to identifying and addressing college students' online health information literacy. American Journal of Health Education. 07. 2008;39(4):228-36.
32 Beales DL. Health literacy: the medical librarian's role. Journal of Hospital Librarianship. 09. 2005;5(3):17-27.
33 Campbell S, Duddle M. Health literacy in chronic kidney disease education. Renal Society of Australasia Journal. 2010;6(1):26-31.
34 Cecchino NJ, Morgan SE. Use of urban adolescent natural language to access sexual health information and education. Journal of Consumer Health on the Internet. 2009;13(1):31-41.
35 Chau PH, Mak B, Choy SY, Chan KC, Cheung SH, Woo J. Raising health literacy and promoting empowerment to meet the challenges of aging in Hong Kong. Educational Gerontology. 2010;36(1):12-25.
36 Chiarella D. Health literacy: using Web 2.0 to create an autism resource. Journal of Consumer Health on the Internet. 2009;13(3):281-6.
37 Coffman MJ. Development and testing of the Spanish Nutritional Literacy Scale 2009 Southern Nursing Research Society Conference. Southern Online Journal of Nursing Research. 2009;9:2.
38 Coffman MJ, Norton CK. Demands of immigration, health literacy, and depression in recent Latino immigrants. Home Health Care Management & Practice. 2010;22(2):116-22.
39 Connor E. Taking the pulse of health information seeking. Journal of Electronic Resources in Medical Libraries. 2009;6(3):230-5.
40 Costa DM. Facilitating health literacy. OT Practice. 08. 25. 2008. Aug. 25. 2008;13(15):13.
41 Crozier S. House directs continued action on health literacy in dentistry. American Dental Association News. 2009;40(22):24-5.
42 Dunn DJ. The nurse role in health literacy. Fla Nurse. 2010;58(1):14.
43 Esparza JM, Hahn GO. Symposium shines spotlight on health literacy. MLA News. 2006;09(389):1.
44 Fleming J. Health literacy. RDH. 03. 2007;27(3):48.
45 Flewelling KW. Health literacy. Refugee health: information needs of health professionals. Journal of Consumer Health on the Internet. 2010. Jan-Mar. 2010;14(1):69-74.
46 Fraser E, Pakenham KI. Resilience in children of parents with mental illness: relations between mental health literacy, social connectedness and coping, and both adjustment and caregiving. Psychology, Health & Medicine. 2009;14(5):573-84.
47 Glover C. Have you thought about your patients' health literacy today?. AAACN Viewpoint. 2010. Jan-Feb. 2010;32(1):3-4.
48 Harrington S. Thinking about the daily realities of diversity and health literacy. AORN Connections. 2009;7(12):2p.
49 Hasman L, Chiarella DT. Health literacy An introduction to the new health literacy column. Journal of Consumer Health on the Internet. 2009;13(1):90-2.
50 Hasselkus A. Health literacy in clinical practice first in a three-part series. ASHA Leader. 2009;14(1):28-9.
51 Hasselkus A, Moxley A. Health literacy at the intersection of cultures Last in a three-part series. ASHA Leader. 2009;14(4):30-1.
52 Hester EJ. An investigation of the relationship between health literacy and social communication skills in older adults. Communication Disorders Quarterly. 2009;30(2):112-9.
53 Hossain D, Gorman D, Eley R, Coutts J. Farm Advisors' reflections on Mental Health First Aid training. Australian e Journal for the Advancement of Mental Health. 2009;8(1):1-7.
54 Jones CM. Internet resources: health literacy. MLA News. 2009;416:11.
55 Kaye M. Health literacy and informatics in the geriatric population: the challenges and opportunities. Online Journal of Nursing Informatics. 2009;13(3):1-19.
56 Khan TM, Sulaiman SA, Hassali MA, Tahir H. Attitude toward depression, its complications, prevention and barriers to seeking help among ethnic groups in Penang, Malaysia. Mental Health in Family Medicine. 2009;6(4):219-27.
57 Kobylarz FA, Pomidor A, Pleasant A. Health literacy as a tool to improve the public understanding of Alzheimer's disease. Annals of Long Term Care. 2010;18(1):34-40.
58 Kohler D. Health literacy: improving comprehension and adherence of written patient instructions by simplifying educational materials at or below a sixth-grade reading level. Gastroenterol Nurs. 2009;32(2):143.
59 Kouame G. Reflections on rural communities. Journal of Hospital Librarianship. 2010;10(2):165-9.
60 Kurashige EM. Health literacy: what are the organizational barriers and concerns?. AAACN Viewpoint. 05. 2008;30(3):3-4.
61 LaValley S. Health literacy Delaware Health Source: consumer health libraries and health literacy outreach. Journal of Consumer Health on the Internet. 2009;13(2):180-6.
62 Leighton S. Adolescents' understanding of mental health problems: conceptual confusion. Journal of Public Mental Health. 2009;8(2):4-14.
63 Levoy B. Patient compliance and health literacy: these steps can improve your treatment results. Podiatry Management. 2010;29(4):71.
64 Mancuso JM. Impact of health literacy and patient trust on glycemic control in an urban USA population. Nursing & Health Sciences. 2010;12(1):94-104. [pmid: 20487332].
65 McCann TV, Clark E. Australian Bachelor of Midwifery students' mental health literacy: an exploratory study. Nursing & Health Sciences. 2010;12(1):14-20. [pmid: 20487320].
66 McCord S. The Medical Library Association guide to health literacy. Journal of the Medical Library Association. 2009;97(2):155-6.
67 Medlen JG. Health literacy for individuals with special needs. Exceptional Parent. 2009;39(2):24-7.
68 Meehan D. Building a stronger foundation: raising health literacy awareness. Med Surg Matters. 2009;18(4):16-8.
69 Ntiri DW, Stewart M. Recruitment challenges: lessons from senior centers and older African-American participants in a literacy study. Educational Gerontology. 2010;36(2):148-54.
70 O'Connell R, Hughes M, Kilonzo B. Tackling health illiteracy. World of Irish Nursing & Midwifery. 2010;18(2):40-1.
71 Ogunsola LA. Health information literacy: a road map for poverty alleviation in the developing countries. Journal of Hospital Librarianship. 2009;9(1):59-72.
72 O'Kelly S. Spell it out. World of Irish Nursing & Midwifery. 09. 2008;16(8):56.
73 Osborne H. In other words… Building healthy literacy programs one step at a time. On Call. 08. 2004;7(6):16-7.
74 Owens J. OJIN tackles health literacy. Am Nurse. 2009;41(5):6. [pmid: 19731571].
75 Pizur-Barnekow K, Doering J, Cashin S, Patrick T, Rhyner P. Functional health literacy and mental health in urban and rural mothers of children enrolled in early intervention programs Infants & Young Children. An Interdisciplinary Journal of Special Care Practices. 2010. Jan-Mar. 2010;23(1):42-51.
76 Powell M. Improving low health literacy: key resources. AAACN Viewpoint. 09. 2008;30(5):12.
77 Powell M. Perspectives in ambulatory care Health literacy: implications for ambulatory care. Nursing Economic$. 2009;27(5):343-7. [pmid: 19927453].
78 Retzlaff K. Overcoming barriers. AORN Connections. 2009;7(11):1.
79 Rowlands G. Health literacy and long-term conditions. Primary Health Care. 2009;19(7):16-20.
80 Scheckel M, Emery N, Nosek C. Addressing health literacy: the experiences of undergraduate nursing students. J Clin Nurs. 2010;19(5-6):794-802. [pmid: 20500323].
81 Schutten M, McFarland A. Readability levels of health-based websites: from content to comprehension. International Electronic Journal of Health Education. 2009;12:99-107.
82 Sudore RL, Schillinger D. Interventions to improve care for patients with limited health literacy. Journal of Clinical Outcomes Management. 2009;16(1):20-9. [pmid: 20046798].
83 Sullivan CH. Partnering with community agencies to provide nursing students with cultural awareness experiences and refugee health promotion access. J Nurs Educ. 2009;48(9):519-22. [pmid: 19645368].
84 Susic J. Health literacy. NIHSeniorHealth classes for senior citizens at a public library in Louisiana. Journal of Consumer Health on the Internet. 2009;13(4):417-9.
85 Thobaben M. Health literacy and elderly home health clients. Home Health Care Management & Practice. 10. 2007;19(6):478-9.
86 Villaire M, Mayer G. Health literacy: the low-hanging fruit in health care reform. J Health Care Finance. 2009;36(2):55-9. [pmid: 20499721].
87 Wardle J. Make sure your patients understand discharge plan: low health literacy contributes to readmissions. Patient Education Management. 04. 2006;13(4):45-8.
88 Wessling MN. Success stories in health literacy. AMWA Journal: American Medical Writers Association Journal. 2010;25(1):17-8.
89 Wicklund K, Ramos K. Plain language: effective communication in the health care setting. Journal of Hospital Librarianship. 2009;9(2):177-85.
90 Witry MJ, Doucette WR, Daly JM, Levy BT, Chrischilles EA. Family physician perceptions of personal health records. Perspectives in Health Information Management. 2010. Winter. 2010;7:21p.
91 Wolf MS, Davis TC, Parker RM. Editorial: the emerging field of health literacy research. American Journal of Health Behavior. 09. 02. 2007. Sep-Oct. 2007;31:S3-5. [pmid: 17931134].
92 Woodson D, Adams MK, Timm DF, Jones D. Online resources for teaching seniors to find health information on the internet: from basic computer skills to consumer health. Journal of Hospital Librarianship. 2009;9(4):391-8.
93 X1Lurie N, Parker R. Editorial: moving health literacy from the individual to the community. American Journal of Health Behavior. 09. 02. 2007. Sep-Oct. 2007;31:S6-7. [pmid: 17931138].

## Cochrane Library = 42 (excluding duplicates)

1 Chan R, Webster J, Hall J. Information interventions for orienting patients and their carers to cancer care facilities. Cochrane Database of Systematic Reviews. 2010;(1).
2 Christensen H. Beyond Ageing Project: A Randomized Controlled Trial to Assess the Benefit of Improving Mental Health Literacy in Depression as Well as the Effect of Folate and B12, and Physical Activity, in Preventing Major Depression and Cognitive Impairment Among Australians Aged 65-74 Years. ClinicalTrialsgov. 2005.
3 Ciciriello S, Johnston Renea V, Osborne Richard H, Wicks I, deKroo T, Clerehan R, et al. Multimedia educational interventions for consumers about prescribed and over the counter medications. Cochrane Database of Systematic Reviews. 2010;(3).
4 Clasen Thomas F, Roberts Ian G, Rabie T, Schmidt WP, Cairncross S. Interventions to improve water quality for preventing diarrhoea. Cochrane Database of Systematic Reviews. 2006;(3).
5 Clement S, Ibrahim S, Crichton N, Wolf M, Rowlands G. Complex interventions to improve the health of people with limited literacy: a systematic review (Structured abstract). Patient Educ Couns. 2009;(3):340-51. [pmid: 19261426].
6 Cohan D, Gomez E, Greenberg M, Washington S, Charlebois ED. Patient perspectives with abbreviated versus standard pre-test HIV counseling in the prenatal setting: a randomized-controlled, non-inferiority trial. PloS one. 2009;(4):e5166. [pmid: 19367335].
7 Dale J, Caramlau Isabela O, Lindenmeyer A, Williams Susan M. Peer support telephone calls for improving health. Cochrane Database of Systematic Reviews. 2008;(4).
8 Dapp U, Anders J, Meier-Baumgartner HP, v Renteln-Kruse W. [Geriatric health promotion and prevention for independently living senior citizens: programmes and target groups]. Zeitschrift für Gerontologie und Geriatrie : Organ der Deutschen Gesellschaft für Gerontologie und Geriatrie. 2007:226-40.
9 DeWalt DA, Broucksou KA, Hawk V, Baker DW, Schillinger D, Ruo B, et al. Comparison of a one-time educational intervention to a teach-to-goal educational intervention for self-management of heart failure: design of a randomized controlled trial. BMC health services research. 2009:99.
10 Dowling S, Gardner F. Parenting programmes for improving the parenting skills and outcomes for incarcerated parents and their children. Cochrane Database of Systematic Reviews. 2005;(4).
11 Duke Sally-Anne S, Colagiuri S, Colagiuri R. Individual patient education for people with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2009;(1).
12 Ejemot Regina I, Ehiri John E, Meremikwu Martin M, Critchley Julia A. Hand washing for preventing diarrhoea. Cochrane Database of Systematic Reviews. 2008;(1).
13 Eunice Kennedy Shriver National Institute of Child H, Human D. Early Ootitis and literacy and attention at 9 to 11 years. [completed]. mRCT. 31 Oct 2009. 2009. Id:.
14 Forbes Carol A, Jepson Ruth G, Martin-Hirsch Pierre PL. Interventions targeted at women to encourage the uptake of cervical screening. Cochrane Database of Systematic Reviews. 2002;(3).
15 Glasgow RE, Gaglio B, Estabrooks PA, Marcus AC, Ritzwoller DP, Smith TL, et al. Long-term results of a smoking reduction program. Med Care. 2009:115-20.
16 Greenfield S. Medication error reduction and the use of PDA technology. The Journal of nursing education. 2007:127-31.
17 Hodnett Ellen D, Gates S, Hofmeyr GJ, Sakala C. Continuous support for women during childbirth. Cochrane Database of Systematic Reviews. 2007;(3).
18 Jay M, Adams J, Herring SJ, Gillespie C, Ark T, Feldman H, et al. A randomized trial of a brief multimedia intervention to improve comprehension of food labels. Prev Med. 2009;(1):25-31. [pmid: 19022282].
19 Kairaluoma L, Närhi V, Ahonen T, Westerholm J, Aro M. Do fatty acids help in overcoming reading difficulties? A double-blind, placebo-controlled study of the effects of eicosapentaenoic acid and carnosine supplementation on children with dyslexia. Child Care Health Dev. 2009;(1):112-9. [pmid: 18991979].
20 Khare MM, Huber R, Carpenter RA, Balmer PW, Bates NJ, Nolen KN, et al. A lifestyle approach to reducing cardiovascular risk factors in underserved women: design and methods of the Illinois WISEWOMAN Program. Journal of women's health (2002). 2009;(3):409-19.
21 Macpherson R, Edwards Thomas R, Chilvers R, David C, Elliott Helen J. Twenty-four hour care for schizophrenia. Cochrane Database of Systematic Reviews. 2009;(2).
22 Maratos A, Gold C, Wang X, Crawford M. Music therapy for depression. Cochrane Database of Systematic Reviews. 2008;(1).
23 Montgomery P, Bjornstad Gretchen J, Dennis Jane A. Media-based behavioural treatments for behavioural problems in children. Cochrane Database of Systematic Reviews. 2006;(1).
24 Morgan Angela T, Vogel Adam P. Intervention for childhood apraxia of speech. Cochrane Database of Systematic Reviews. 2008;(3).
25 Murthy GV, Vashist P, John N, Pokharel G, Ellwein LB. Prevalence and vision-related outcomes of cataract surgery in Gujarat. India Ophthalmic Epidemiol. 2009;(6):400-9.
26 O'Connor Annette M, Bennett Carol L, Stacey D, Barry M, Col Nananda F, Eden Karen B, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database of Systematic Reviews. 2009;(3).
27 O'Kearney R, Kang K, Christensen H, Griffiths K. A controlled trial of a school-based Internet program for reducing depressive symptoms in adolescent girls. Depress Anxiety. 2009;(1):65-72. [pmid: 18828141].
28 Pratt Belinda M, Woolfenden S. Interventions for preventing eating disorders in children and adolescents. Cochrane Database of Systematic Reviews. 2002;(2).
29 Primack BA, Fine D, Yang CK, Wickett D, Zickmund S. Adolescents' impressions of antismoking media literacy education: qualitative results from a randomized controlled trial. Health Educ Res. 2009;(4):608-21. [pmid: 19052155].
30 Puertas G, Patel V, Marshall T. Are visual measures of mood superior to questionnaire measures in non-Western settings?. Soc Psychiatry Psychiatr Epidemiol. 2004;(8):662-6. [pmid: 15300377].
31 Ramos HR, Atalah SE, Urteaga RC, Castañeda LR, Orozco LM, Avila L, et al. [Effect of the consumption of a food supplement on plasma zinc concentrations of free-living Chilean elderly adults]. Rev Med Chil. 2007:1015-24.
32 Rana AK, Wahlin A, Lundborg CS, Kabir ZN. Impact of health education on health-related quality of life among elderly persons: results from a community-based intervention study in rural Bangladesh. Health promotion international. 2009;(1):36-45. [pmid: 19136677].
33 Reveiz L, Gyte Gillian ML, Cuervo Luis G. Treatments for iron-deficiency anaemia in pregnancy. Cochrane Database of Systematic Reviews. 2007;(2).
34 Rosal MC, Olendzki B, Reed GW, Gumieniak O, Scavron J, Ockene I. Diabetes self-management among low-income Spanish-speaking patients: a pilot study. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2005;(3):225-35. [pmid: 15946117].
35 Rosal MC, White MJ, Restrepo A, Olendzki B, Scavron J, Sinagra E, et al. Design and methods for a randomized clinical trial of a diabetes self-management intervention for low-income Latinos: Latinos en Control. BMC medical research methodology. 2009:81.
36 Ryan R, Prictor M, McLaughlin Kristin J, Hill S. Audio-visual presentation of information for informed consent for participation in clinical trials. Cochrane Database of Systematic Reviews. 2008;(1).
37 Ryan R, Santesso N, Hill S, Kaufman C, Grimshaw J. Consumer-oriented interventions for evidence-based prescribing and medicine use: an overview of Cochrane reviews, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
38 Samal L, Yeh HC, Gary-Webb TL, Jackson CL, Brancati FL. Computer and internet use of urban african americans with type 2 diabetes in relation to glycemic control, emergency department use, diabetes-related knowledge, and health literacy. Diabetes care. 2010;(1):e9. [pmid: 20040672].
39 Sloat E, Letourneau N, Brannen Cyndi L, Thompson K, Uhrig E, Veldhuyzen van Zanten Stephanie CM, et al. Parent mediated reading interventions for children aged birth to 48 months. Cochrane Database of Systematic Reviews. 2009;(2).
40 Steckelberg A, Hülfenhaus C, Kasper J, Mühlhauser I. Ebm@school--a curriculum of critical health literacy for secondary school students: results of a pilot study. International journal of public health. 2009;(3):158-65. [pmid: 19183847].
41 Virgili G, Acosta R. Reading aids for adults with low vision. Cochrane Database of Systematic Reviews. 2006;(4).
42 Wilksch SM, Wade TD. Reduction of shape and weight concern in young adolescents: a 30-month controlled evaluation of a media literacy program. J Am Acad Child Adolesc Psychiatry. 2009;(6):652-61. [pmid: 19454921].

## ERIC = 41 (excluding duplicates)

1 SuccessMaker[R] WWC Intervention Report. What Works Clearinghouse. 2009:24.
2 Alati R, Gunnell D, Najman J, Williams G, Lawlor D. Is IQ in childhood associated with suicidal thoughts and attempts? Findings from the Mater University study of pregnancy and its outcomes. Suicide Life Threat Behav. 2009;39(3):282-93. [pmid: 19606920].
3 Bahr D, Monroe EE, Balzotti M, Eggett D. Crossing the Barriers between Preservice and Inservice Mathematics Teacher Education: An Evaluation of the Grant School Professional Development Program. School of Science and Mathematics. 2009;109(4):223-37.
4 Baldi S, Kutner M, Greenberg E, Jin Y, Baer J, Moore E, et al. Technical Report and Data File User's Manual: For the 2003 National Assessment of Adult Literacy NCES 2009-476. National Center for Education Statistics. 2009:628.
5 Bitz M. The Comic Book Project: forging alternative pathways to literacy. Journal of Adolescent & Adult Literacy. 2004;47(7):574-86.
6 Burgess J, Fleet A. Frameworks for change: four recurrent themes for quality in early childhood curriculum initiatives. Asia-Pacific Journal of Teacher Education. 2009;37(1):45-61.
7 Chatterji M. Applying the Joint Committee's 1994 standards in international contexts: a case study of education evaluations in Bangladesh. Teachers College Record. 2005;107(10):2372-400.
8 Colker L, National Association for the Education of Young Children WDC. The Cooking Book: Fostering Young Children's Learning and Delight: National Association for the Education of Young Children. 2005. Report No.: 1-9288-9620-0.
9 Diehl S. Life Skills to Life Saving: Health Literacy in Adult Education. Adult Learning. 2004;15:26-9.
10 Flood J, Anders PL. Literacy Development of Students in Urban Schools: Research and Policy. International Reading Association. 2005.
11 Gallagher J. Literacy Assistance C. Literacy Update. 2009;19(1).
12 Gillis DE. A Community-Based Approach to Health Literacy Using Participatory Research. Adult Learning. 2004;15:14-7.
13 Golbeck AL, LaBonty J, Paschal AM, Harris M, Ryan KE, Molgaard CA. Promoting Health Literacy through GED Testing. Adult Basic Education and Literacy Journal. 2010;4(1):13-23.
14 Grace C, Shores EF, Zaslow M, Brown B, Aufseeser D. New Clues to Reaching Very Young Children and Families in Rural America. Zero to Three. 2006;26(4):7-13.
15 Harkavy I. University-Assisted Community School Program of West Philadelphia: Democratic Partnerships that Make a Difference. New Directions for Youth Development. 2005;(107):35-43. [pmid: 16315515].
16 Hart SA, Petrill SA, Thompson LA, Plomin R. The ABCs of Math: A Genetic Analysis of Mathematics and Its Links with Reading Ability and General Cognitive Ability. Journal of Educational Psychology. May. 2009;101(2):388-402. 2009;101(2):15. [pmid: 20157630].
17 Higgins C. Discursive Enactments of the World Health Organization's Policies: Competing Cultural Models in Tanzanian HIV/AIDS Prevention. Language Policy. 2010;9(1):65-85.
18 Hill LH. Health Literacy Is a Social Justice Issue that Affects Us All. Adult Learning. 2004;15(1):4-6.
19 Holland JW. Reading Aloud with Infants: The Controversy, the Myth, and a Case Study. Early Childhood Education Journal. 2008;35(4):383-5.
20 Hubbard B, Rainey J. Health Literacy Instruction and Evaluation among Secondary School Students. American Journal of Health Education. 2007;38:332-7.
21 Ickes MJ, Cottrell R. Health Literacy in College Students. J Am Coll Health. 2010;58(5):491-8. [pmid: 20304761].
22 Kim P, Miranda T, Olaciregui C. Pocket School: Exploring Mobile Technology as a Sustainable Literacy Education Option for Underserved Indigenous Children in Latin America. International Journal of Educational Development. 2008;28(4):435-45.
23 Ladd GW, Dinella LM. Continuity and Change in Early School Engagement: Predictive of Children's Achievement Trajectories from First to Eighth Grade?. Journal of Educational Psychology. Feb. 2009;101(1):190-206. 2009;101(1):17.
24 McCardle P, Leung CYY. English Language Learners: Development and Intervention--An Introduction. Topics in Language Disorders. 2006;26(4):302.
25 McIntyre S, Dale H, Gabler C. Building Successful Partnerships in Health Literacy. Adult Basic Education and Literacy Journal. 2010;4(1):43-6.
26 Mikulecky L, Smith-Burke T, Beatty J. Adult Literacy Research in 2006: Where Did It Appear, What Methodologies Were Used, and What Did It Say?. Adult Basic Education and Literacy Journal. Sum. 2009;3(2):67-76. 2009;3(2):10.
27 Mond JM, Marks P, Hay PJ, Rodgers B, Kelly C, Owen C, et al. Mental Health Literacy and Eating-Disordered Behavior: Beliefs of Adolescent Girls Concerning the Treatment of and Treatment-Seeking for Bulimia Nervosa. Journal of Youth and Adolescence. 2007;36(6):753-62.
28 Nebraska State Dept of Education L. Nebraska Early Learning Guidelines for Ages Birth to 3: Nurturing the Development and Learning of Infants and Toddlers through Responsive Caregiving. Nebraska Department of Education. 2006.
29 Nordtveit BH. Poverty Alleviation and Integrated Service Delivery: Literacy, Early Child Development and Health. International Journal of Educational Development. 2008;28(4):405-18.
30 Olateju MA. Reading Kiosks: Literacy Empowerment for the Girl-Child. Language, Culture and Curriculum. 2007;20(2):155-63.
31 Platt JS, Casey RE, Faessel RT. The Need for a Paradigmatic Change in Juvenile Correctional Education. Preventing School Failure. 2006;51(1):31-8.
32 Prendiville F, Toye N. Speaking and Listening through Drama 7 - 11. Paul Chapman Publishing. 2007.
33 Rose D, Rose M, Farrington S, Page S. Scaffolding Academic Literacy with Indigenous Health Sciences Students: An Evaluative Study. Journal of English for Academic Purposes. 2008;7(3):165-79.
34 Saunders CM. Insuring the Uninsured: Reducing the Barriers to Public Insurance. Qualitative Report. 2006;11(3):499-515.
35 Schnell-Anzola B, Rowe ML, LeVine RA. Literacy as a Pathway between Schooling and Health-Related Communication Skills: A Study of Venezuelan Mothers. International Journal of Educational Development. 2005;25(1):19-37.
36 Severeide R. Early Childhood Strategies POR, Washington County Commission on Children and Families HOR. Revisiting School Readiness. Washington County, Orego. Summer. 2007. Online Submission; 2007.
37 Vahabi M. The Impact of Health Communication on Health-Related Decision Making: A Review of Evidence. Health Educ. 2007;107(1):27-41.
38 Vamos CA, Vamos SD. Dimensions of Women's Health across the Lifespan. American Journal of Health Education. 2008;39:370-3.
39 Vanderstaay SL. Learning from Longitudinal Research in Criminology and the Health Sciences. Reading Research Quarterly. 2006;41(3):328-50.
40 von Wagner C, Steptoe A, Wolf MS, Wardle J. Health Literacy and Health Actions: A Review and a Framework from Health Psychology. Health Education & Behavior. 2009;36(5):860-877. 2009;36(5):18. [pmid: 18728119].
41 Witte PG. Health Literacy: Can We Live without It?. Adult Basic Education and Literacy Journal. 2010;4(1):3-12.

## ISI = 4 (excluding duplicates)

1 Hibbard JH, Peters E. Supporting informed consumer health care decisions: Data presentation approaches that facilitate the use of information in choice. Annu Rev Public Health. 2003;24:413-33. [pmid: 12428034].
2 Parrott R, Silk K, Dorgan K, Condit C, Harris T. Risk comprehension and judgments of statistical evidentiary appeals -When a picture is not worth a thousand words. Human Communication Research. Jul. 2005;31(3):423-52.
3 Rich M. Health literacy via media literacy -Video intervention/prevention assessment. _m Behav Sci. Oct. 2004;48(2):165-88.
4 Wolf MS, Feinglass JM, Carrion V, Gazmararian J, Baker D. Literacy and mortality among medicare enrollees. J Gen Intern Med. Apr. 2006;21:81.

## Other = 247 (excluding duplicates)

1 National assessment of adult literacy: state and county estimate of low literacy. [cited. 2010. Available from: http://nces.ed.gov/naal/estimates/StateEstimates.aspx.
2 The Joint Commission “What did the doctor say”?. Improving health literacy to protect patient safety. 2007:1-64.
3 Prevalence Calculator. 2008. [cited 2010; Available from:http://www.pfizerhealthliteracy.com/physicians-providers/prevalence-calculator.html.
4 Meeting 7: Rountable on health literacy Workshop on measures of health literacy. 2009. [citedSeptember 22, 2010]; Available from: http://www.iom.edu/Activities/PublicHealth/HealthLiteracy/2009-FEB-26.aspx.
5 Health literacy universal precautions toolkits. 2010. [cited 2010; Available from: http://www.ahrq.gov/qual/literacy/.
6 National action plan to improve health literacy. 2010. [cited 2010; Available from: http://www.health.gov/communication/HLActionPlan/.
7 Adams RJ, Appleton SL, Hill CL, Dodd M, Findlay C, Wilson DH. Risks associated with low functional health literacy in an Australian population. Med J Aust. Nov. 16. 2009;191(10):530-4. [pmid: 19912083].
8 Agency for Healthcare Research and Quality. Methods reference guide for effectiveness and comparative effectiveness reviews, version 1.0. [Draft postedOct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. 2007.
9 Aikens JE, Piette JD. Diabetic patients' medication underuse, illness outcomes, and beliefs about antihyperglycemic and antihypertensive treatments. Diabetes Care. Jan. 2009;32(1):19-24. [pmid: 18852334].
10 American Medical Association. Health literacy: report of the Council on Scientific Affairs. J Am Med Assoc. 1999;281(6):552-7.
11 American Medical Association. 2008. AMA Medicare physician payment action kit. 2008 [cited 2008 July 10]; Available from: http://www.ama-assn.org/ama/pub/category/14332.html.
12 American Medical Association. Medicare Advantage: the facts. 2008. [cited 2008 July 10]; Available from: http://www.ama-assn.org/ama1/pub/upload/mm/399/nac_mafacts.pdf.
13 American Medical Association. Myth vs Fact: Medicare Advantage in HR 6331. 2008. [cited 2008 July 10]; Available from: http://www.ama-assn.org/ama1/pub/upload/mm/399/ma_myths.pdf.
14 American Medical Association. National Legislative Activities -- Medicare. 2008. [cited 2008 July 10]; Available from: http://www.ama-assn.org/ama/pub/category/6583.html.
15 American Medical Association. Strategies to improve Medicare. 2008. [cited 2008 July 10]; Available from:http://www.ama-assn.org/ama1/pub/upload/mm/399/nac_strategies.pdf.
16 Andreasen AR. Marketing Social Marketing in the Social Change Marketplace. J Pub Pol Market. Spring. 2002;21(1):3-13.
17 Andriole GL, Crawford ED, Grubb RL 3rd, Buys SS, Chia D, Church TR, et al. Mortality results from a randomized prostate-cancer screening trial. N Engl J Med. Mar. 26. 2009;360(13):1310-9. [pmid: 19297565].
18 Asbury LD, Wong FL, Price SM, Nolin MJ. The VERB(TM) Campaign: Applying a Branding Strategy in Public Health. Am J Prev Med. 2008;34(6, Supplement 1):S183-S7. [pmid: 18471598].
19 Baker D, Parker R, Williams M, Clark W. Health literacy and the risk of hospital admission. J Gen Intern Med. 1998;13(12):791-8. [pmid: 9844076].
20 Baker DW, Gazmararian JA, Sudano J, Patterson M. The association between age and health literacy among elderly persons. J Gerontol B Psychol Sci Soc Sci. November. 1. 2000. 2000;55(6):S368-74. [pmid: 11078114].
21 Baker DW, Gazmararian JA, Williams MV, Scott T, Parker RM, Green D, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. Am J Public Health. August. 1. 2002. 2002;92(8):1278-83. [pmid: 12144984].
22 Baker DW, Parker RM, Williams MV, Clark WS, Nurss J. The relationship of patient reading ability to self-reported health and use of health services. Am J Public Health. June. 1. 1997. 1997;87(6):1027-30. [pmid: 9224190].
23 Bautista RE, Glen ET, Shetty NK, Wludyka P. The association between health literacy and outcomes of care among epilepsy patients. Seizure. Jul. 2009;18(6):400-4. [pmid: 19324575].
24 Beaudoin CE, Fernandez C, Wall JL, Farley TA. Promoting healthy eating and physical activity: short-term effects of a mass media campaign. Am J Prev Med. 2007;32(3):217-23. [pmid: 17236742].
25 Bennett IM, Chen J, Soroui JS, White S. The contribution of health literacy to disparities in self-rated health status and preventive health behaviors in older adults. Ann Fam Med. May-Jun. 2009;7(3):204-11. [pmid: 19433837].
26 Berenson RA. Medicare+Choice: doubling or disappearing?. Health Aff. 2001. November. 28. 2001:hlthaff.w1.65.
27 Berenson RA. Medicare disadvantaged and the search for the elusive 'level playing field'. Health Aff. 2004. December. 15. 2004:hlthaff.w4.572.
28 Berk ML, Monheit AC. The concentration of health care expenditures, revisited. Health Aff. March. 1. 2001. 2001;20(2):9-18.
29 Berkman ND, Viswanathan M. n/a. Development of a tool to evaluate the quality of observational studies. (Abstract). Zeitschrift für Evidenz, Fortbildung, und Qualität im Gesundheitswesen. (German Journal for Evidence and Quality in Health Care). 2008;102(Supple V):S.19.
30 Berkman ND, DeWalt DA, Pignone MP, Sheridan SL, Lohr KN, Lux L, et al. Summary, Evidence Report/Technology Assessment No. 87. 2004. [cited 2008 July 19 ]; Available from: http://www.ahrq.gov/clinic/epcsums/litsum.pdf.
31 Berkowitz SA, Gerstenblith G, Anderson GF. Medicare prescription drug coverage gap: navigating the “doughnut hole” with patients. J Am Med Assoc. February. 28. 2007. 2007;297(8):868-70.
32 Bickmore TW, Pfeifer LM, Paasche-Orlow MK. Using computer agents to explain medical documents to patients with low health literacy. Patient Educ Couns. Jun. 2009;75(3):315-20. [pmid: 19297116].
33 Biles B, Dallek G, Nicholas LH. Medicare Advantage: Deja Vu All Over Again?. Health Aff. 2004. December. 15. 2004:hlthaff.w4.586.
34 Birkland TA. An introduction to the policy process: theories, concepts, and models of public policy making. Second Edition ed. Armonk, New York. Sharpe, M.E. 2005.
35 Blair J, Spreen O. Predicting premorbid IQ: a revision of the National Adult Reading Test Clinical Neuropsychologist. 1989;3:129-36.
36 Blendon RJ, Brodie M, Benson JM, Altman DE, Levitt L, Hoff T, et al. Understanding the managed care backlash. Health Aff. July. 1. 1998. 1998;17(4):80-94.
37 Bosworth HB, Olsen MK, Grubber JM, Neary AM, Orr MM, Powers BJ, et al. Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009. Oct. 5.
38 Boulware LE, Carson KA, Troll MU, Powe NR, Cooper LA. Perceived susceptibility to chronic kidney disease among high-risk patients seen in primary care practices. J Gen Intern Med. Oct. 2009;24(10):1123-9. [pmid: 19711135].
39 Brill JV. Trends in the prescription drug plans delivering the Medicare Part D Prescription Drug Benefit. Am J Health Syst Pharm. August. 1. 2007. 2007;64(15_Supplement_10):S3-6. [pmid: 17646551].
40 Brown KM, Bryant CA, Forthofer MS, Perrin KM, Quinn GP, Wolper M, et al. Florida cares for women: social marketing campaign: a case study. American Journal of Health Behavior. 2000;24(1):44.
41 Bugeja G, Kumar A, Banerjee AK. Exclusion of elderly people from clinical research: a descriptive study of published reports. BMJ. October. 25. 1997. 1997;315(7115):1059. [pmid: 9366735].
42 Campbell JR, Nolfi AD. Teaching elderly adults to use the internet to access health care information: Before-After Study. J Med Internet Res. 2005;7(2):e19. [pmid: 15998610].
43 Campbell MK, Hudson MA, Resnicow K, Blakeney N, Paxton A, Baskin M. Church-based health promotion interventions: evidence and lessons learned. Annu Rev Public Health. 2007;28(1):213-34. [pmid: 17155879].
44 Cappella JN. Integrating message effects and behavioral change theories: organizing comments and unanswered questions. J Communicat. 2006;56(Suppl 1):S265-79.
45 Centers for Medicare & Medicaid Services. CMS Legislative Summary: Medicare Prescription Drug, Improvement, and Modernization Act of 2003, Public Law 108-173. 2004. [cited 2008 July 11]; Available from: http://www.cms.hhs.gov/MMAUpdate/downloads/PL108-173summary.pdf.
46 Centers for Medicare & Medicaid Services. Medicare & You 2008. 2008. [cited 2008 July 11]; Available from: http://www.medicare.gov/Publications/Pubs/pdf/10050.pdf.
47 Centers for Medicare & Medicaid Services. Prescription Drug Coverage - General Information. 2008. January. [cited 2008 July 11]; Available from: http://www.cms.hhs.gov/PrescriptionDrugCovGenIn/.
48 Clarke C, Friedman SM, Shi K, Arenovich A, Culligan C. Emergency department discharge instructions comprehension and compliance study. Cjem. Jan. 2005;7(1):5-11. [pmid: 17355647].
49 Committee on Oversight and Government Reform - U.S. House of Representatives, Private Medicare Drug Plans: High Expenses and Low Rebates Increase the Costs of Medicare Drug Coverage. 2007. [cited2008 July 28]; Available from: http://oversight.house.gov/documents/20071015093754.pdf.
50 Committee on Oversight and Government Reform - U.S. House of Representatives, Medicare Part D: Drug Pricing and Manufacturer Windfalls. 2008. [cited2008 July 28]; Available from: http://oversight.house.gov/documents/20080724101850.pdf.
51 Cormier CM, Kotrlik JW. Health literacy knowledge and experiences of senior baccalaureate nursing students. J Nurs Educ. May. 2009;48(5):237-48. [pmid: 19476028].
52 Covey J. A meta-analysis of the effects of presenting treatment benefits in different formats. Med Decis Making. Sep-Oct. 2007;27(5):638-54. [pmid: 17873250].
53 Davis T, Crouch M, Wills G, et al. The gap between patient reading comprehension and the readability of patient education materials. J Fam Pract. 1990;31:533-8. [pmid: 2230677].
54 Davis T, Long S, Jackson R, Mayeaux E, George R, Murphy P, et al. Rapid Estimate of Adult Literacy in Medicine: a shortened screening instrument. Fam Med. June. 1993;25(6):391-5. [pmid: 8349060].
55 Davis TC, Berkel HJ, Arnold CL, Nandy I, Jackson RH, Murphy PW. Intervention to increase mammography utilization in a public hospital. J Gen Intern Med. Apr. 1998;13(4):230-3. [pmid: 9565385].
56 Davis TC, Bocchini JA Jr, Fredrickson D, Arnold C, Mayeaux EJ, Murphy PW, et al. Parent comprehension of polio vaccine information pamphlets. Pediatrics. Jun. 1996;97(6 Pt 1):804-10. [pmid: 8657518].
57 Davis TC, Fredrickson DD, Arnold C, Murphy PW, Herbst M, Bocchini JA. A polio immunization pamphlet with increased appeal and simplified language does not improve comprehension to an acceptable level. Patient Educ Couns. Jan. 1998;33(1):25-37. [pmid: 9481346].
58 Davis TC, Holcombe RF, Berkel HJ, Pramanik S, Divers SG. Informed consent for clinical trials: a comparative study of standard versus simplified forms. J Natl Cancer Inst. May. 6. 1998;90(9):668-74. [pmid: 9586663].
59 Dewalt DA, Davis TC, Wallace AS, Seligman HK, Bryant-Shilliday B, Arnold CL, et al. Goal setting in diabetes self-management: Taking the baby steps to success. Patient Educ Couns. 2009. Apr. 7.
60 DeWalt DA, Oberlander J, Carey TS, Roper WL. Significance of Medicare and Medicaid Programs for the Practice of Medicine. Health Care Financ Rev. 2005-2006;27(2):79-90. [pmid: 17290639].
61 DeWalt DA, Pignone MP. Reading is fundamental: the relationship between literacy and health. Arch Intern Med. 2005;165(17):143-4.
62 Doak CC, Doak Leonard G, Root Jane H. Teaching Patients With Low Literacy Skills. 2d ed. Philadelphia. Lippincott Co. 1996.
63 Donelle L, Hoffman-Goetz L, Gatobu S, Arocha JF. Comprehension of Internet-based numeric cancer information by older adults. Inform Health Soc Care. Dec. 2009;34(4):209-24. [pmid: 19919298].
64 Eaton ML, Holloway RL. Patient comprehension of written drug information. Am J Hosp Pharm. Feb. 1980;37(2):240-3. [pmid: 7361799].
65 Edwards A, Elwyn G, Covey J, Matthews E, Pill R. Presenting risk information--a review of the effects of “framing” and other manipulations on patient outcomes. J Health Commun. Jan-Mar. 2001;6(1):61-82. [pmid: 11317424].
66 Eichler K, Wieser S, Brugger U. The costs of limited health literacy: a systematic review. Int J Public Health. 2009;54(5):313-24. [pmid: 19644651].
67 Fang MC, Panguluri P, Machtinger EL, Schillinger D. Language, literacy, and characterization of stroke among patients taking warfarin for stroke prevention: Implications for health communication. Patient Educ Couns. Jun. 2009;75(3):403-10. [pmid: 19171448].
68 Federman AD, Safran DG, Keyhani S, Cole H, Halm EA, Siu AL. Awareness of pharmaceutical cost-assistance programs among inner-city seniors. Am J Geriatr Pharmacother. Apr. 2009;7(2):117-29. [pmid: 19447364].
69 Fishbein M. The role of theory in HIV prevention. AIDS Care. Jun. 2000;12(3):273-8. [pmid: 10928203].
70 Foote SB, Halaas GW. Defining A Future For Fee-For-Service Medicare. Health Aff. May. 1. 2006. 2006;25(3):864-8.
71 Fortenberry JD, McFarlane MM, Hennessy M, Bull SS, Grimley DM, St Lawrence J, et al. Relation of health literacy to gonorrhoea related care. Sex Transm Infect. Jun. 2001;77(3):206-11. [pmid: 11402232].
72 Fox S. Older Americans and the Internet. 2005. [cited 2009 March 6]; Available from: http://www.pewinternet.org/pdfs/PIP_Seniors_Online_2004.pdf.
73 Fox S, Rainie L, Larsen E, Horrigan J, Lenhart A, Spooner T, et al. Wired Seniors. 2001. September. 9. 2001 [cited 2009 March 6 ]; Available from: http://www.pewinternet.org/pdfs/PIP_Wired_Seniors_Report.pdf.
74 Frakt AB, Pizer SD. A First Look At The New Medicare Prescription Drug Plans. Health Aff. July. 1. 2006. 2006;25(4):W252-61.
75 Frank RG. Prescription-Drug Prices. N Engl J Med. September. 30. 2004. 2004;351(14):1375-7. [pmid: 15459294].
76 Frank RG, Newhouse JP. Should Drug Prices Be Negotiated Under Part D Of Medicare? And If So, How?. Health Aff. January. 1. 2008. 2008;27(1):33-43.
77 Friedman DB, Corwin SJ, Dominick GM, Rose ID. African American men's understanding and perceptions about prostate cancer: why multiple dimensions of health literacy are important in cancer communication. J Community Health. Oct. 2009;34(5):449-60. [pmid: 19517223].
78 Gazmararian JA, Baker DW, Williams MV, Parker RM, Scott TL, Green DC, et al. Health Literacy Among Medicare Enrollees in a Managed Care Organization. JAMA. February. 10. 1999. 1999;281(6):545-51. [pmid: 10022111].
79 Gold M. Private Plans In Medicare: Another Look. Health Aff. September. 1. 2005. 2005;24(5):1302-10.
80 Gold M. Medicare Advantage In 2006-2007: What Congress Intended?. Health Aff. July. 1. 2007. 2007;26(4):w445-55.
81 Goldstein E. CMS's Consumer Information Efforts. Health Care Financ Rev. Fall. 2001;23(1):1-4. [pmid: 12500358].
82 Goldstein E, Crawley B, Gaumer G, Joseph C, Reardon L, Teichman L. Lessons learned from the national Medicare & You education program. Health Care Financ Rev. Fall. 2001;23(1):5-20. [pmid: 12500359].
83 Gordon R, McDermott L, Stead M, Angus K. The effectiveness of social marketing interventions for health improvement: What's the evidence?. Public Health. 2006;120:1133-9. [pmid: 17095026].
84 GovTrack.us. H.R. 6331: Medicare Improvement for Patients and Providers Act of 2008. 2008. [cited 2008 July 14]; Available from: http://www.govtrack.us/congress/bill.xpd?bill=h110-6331.
85 Greenwald L, McCormack L, Uhrig J, West N. Measures and Predictors of Medicare Knowledge: A Review of the Literature. Health Care Financ Rev. Summer. 2006;27(4):1-12. [pmid: 17290654].
86 Hanchate AD, Ash AS, Gazmararian JA, Wolf MS, Paasche-Orlow MK. The Demographic Assessment for Health Literacy (DAHL): a new tool for estimating associations between health literacy and outcomes in surveys. J Gen Intern Med. 2008. 2008;23(10):1561-6. [pmid: 18618197].
87 Harrington P. Perspective: Quality As A System Property: Section 646 Of The Medicare Modernization Act. Health Aff. 2004. October. 7. 2004:hlthaff.var.136.
88 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3, Supplement 1):21-35. [pmid: 11306229].
89 Hartman TJ, McCarthy PR, Park RJ, Schuster E, Kushi LH. Results of a community-based low-literacy nutrition education program. J Community Health. Oct. 1997;22(5):325-41. [pmid: 9353681].
90 Hayes KS. Randomized trial of geragogy-based medication instruction in the emergency department. Nurs Res. Jul-Aug. 1998;47(4):211-8. [pmid: 9683116].
91 Headley AJ, Harrigan J. Using the Pregnancy Perception of Risk Questionnaire to assess health care literacy gaps in maternal perception of prenatal risk. J Natl Med Assoc. Oct. 2009;101(10):1041-5. [pmid: 19860304].
92 Heitzler CD, Asbury LD, Kusner SL. Bringing “Play” to Life: The Use of Experiential Marketing in the VERB(TM) Campaign. Am J Prev Med. 2008;34(6, Supplement 1):S188-S93. [pmid: 18471599].
93 Herman A, Young KD, Espitia D, Fu N, Farshidi A. Impact of a health literacy intervention on pediatric emergency department use. Pediatr Emerg Care. Jul. 2009;25(7):434-8. [pmid: 19564810].
94 Hibbard J, Slovic P, Jewett J. Informing Consumer Decisions in Health Care: Implications from Decision-Making Research. The Milbank Quarterly. 1997;75(3):395-414. [pmid: 9290635].
95 Hibbard JH, Jewett JJ, Engelmann S, Tusler M. Can Medicare beneficiaries make informed choices?. Health Aff. November. 1. 1998. 1998;17(6):181-93.
96 Hibbard JH, Slovic P, Peters E, Finucane ML, Tusler M. Is The Informed-Choice Policy Approach Appropriate For Medicare Beneficiaries?. Health Aff. May. 1. 2001. 2001;20(3):199-203.
97 Hironaka LK, Paasche-Orlow MK, Young RL, Bauchner H, Geltman PL. Caregiver health literacy and adherence to a daily multi-vitamin with iron regimen in infants. Patient Educ Couns. Jun. 2009;75(3):376-80. [pmid: 19395227].
98 Howard-Pitney B, Winkleby MA, Albright CL, Bruce B, Fortmann SP. The Stanford Nutrition Action Program: a dietary fat intervention for low-literacy adults. Am J Public Health. Dec. 1997;87(12):1971-6. [pmid: 9431286].
99 Huhman M, Berkowitz JM, Wong FL, Prosper E, Gray M, Prince D, et al. The VERB(TM) Campaign's Strategy for Reaching African-American, Hispanic, Asian, and American Indian Children and Parents. Am J Prev Med. 2008;34(6, Supplement 1):S194-S209. [pmid: 18471600].
100 Hussey LC. Minimizing effects of low literacy on medication knowledge and compliance among the elderly. Clin Nurs Res. May. 1994;3(2):132-45. [pmid: 7513587].
101 Iglehart JK. The New Medicare Prescription-Drug Benefit -- A Pure Power Play. N Engl J Med. February. 19. 2004. 2004;350(8):826-33. [pmid: 14973209].
102 Institute of Medicine. ed. Health literacy: a prescription to end confusion. Washington, D.C. National Academies Press. 2004.
103 Institute of Medicine. Health literacy: a prescription to end confusion - executive summary. 2004. [cited 2008 November 26 ]; Available from: http://www.nap.edu/catalog/10883.html.
104 Institute of Medicine. Report Brief - Health Literacy: A Prescription To End Confusion. 2004. [cited 2008 July 19 ]; Available from: http://www.iom.edu/Object.File/Master/19/726/health%20literacy%20final.pdf.
105 Institute of Medicine. Measures of health litearcy, workshop summary. 2009. [cited; Available from: http://books.nap.edu/openbook.php?record_id=12690.
106 Institute of Medicin - Committee on Monitoring Access to Personal Health Care Servicese. Executive Summary. Millman M, editor. Access to health Care In America. 1993:1-18.
107 IRS. Publication 15: Employer's Tax Guide. 2008. [cited 2008 July 10 ]; Available from: www.irs.gov/publications/p15/ar02.html.
108 Jastak S, Wilkinson G. Wide Range Achievement Test-Revised (WRAT-R). San Antonio, TX. The Psychological Corporation. 1984.
109 Jones S, Fox S. Generations Online in 2009. 2009. January. 28. 2009 [cited 2009 March 6 ]; Available from: http://www.pewinternet.org/pdfs/PIP_Generations_2009.pdf.
110 Jovic-Vranes A, Bjegovic-Mikanovic V, Marinkovic J. Functional health literacy among primary health-care patients: data from the Belgrade pilot study. J Public Health (Oxf). Dec. 2009;31(4):490-5. [pmid: 19454605].
111 Joyce GF, Keeler EB, Shang B, Goldman DP. The Lifetime Burden Of Chronic Disease Among The Elderly. Health Aff. R18. 2005;24(Supplement 2):W5-29.
112 Joyner-Grantham J, Mount DL, McCorkle OD, Simmons DR, Ferrario CM, Cline DM. Self-reported influences of hopelessness, health literacy, lifestyle action, and patient inertia on blood pressure control in a hypertensive emergency department population. Am J Med Sci. Nov. 2009;338(5):368-72. [pmid: 19838100].
113 Kandula NR, Nsiah-Kumi PA, Makoul G, Sager J, Zei CP, Glass S, et al. The relationship between health literacy and knowledge improvement after a multimedia type 2 diabetes education program. Patient Educ Couns. Jun. 2009;75(3):321-7. [pmid: 19395223].
114 Keehan S, Sisko A, Truffer C, Smith S, Cowan C, Poisal J, et al. Health Spending Projections Through 2017: The Baby-Boom Generation Is Coming To Medicare. Health Aff. March. 1. 2008. 2008;27(2):w145-55.
115 Keenan TA. Prescription Drugs and Medicare Part D: A Report on Access, Satisfaction, and Cost. 2007. [cited 2008 July 30 ]; Available from: http://assets.aarp.org/rgcenter/health/rx_medicared.pdf.
116 Kim EH, Stolyar A, Lober WB, Herbaugh AL, Shinstrom SE, Zierler BK, et al. Challenges to using an electronic personal health record by a low-income elderly population. J Med Internet Res. 2009;11(4):e44. [pmid: 19861298].
117 Kim SP, Knight SJ, Tomori C, Colella KM, Schoor RA, Shih L, et al. Health literacy and shared decision making for prostate cancer patients with low socioeconomic status. Cancer Invest. 2001;19(7):684-91. [pmid: 11577809].
118 Kingdon JW. Agendas, Alternatives, and Public Policies. Second ed. New York. HarperCollins College Publishers. 1995.
119 Kintsch W, Welsch D, Schmalhofer F, Zimny S. Sentence memory: A theoretical analysis. Journal of Memory and Language. 1990;29(2):133-59.
120 Kirsch IS, Jungeblut A, Jenkins L, Kolstad A. Adult literacy in America: a first look at the findings of the National Adult Literacy Survey (NCES 1993-275). 3rd ed. Washington, DC. US Department of Education, Office of Educational Research and Improvement. Available from: http://nces.ed.gov/pubs93/93275.pdf. 2002.
121 Krugman P. Kennedy's Big Day. The New York Times. 2008. July. 11.
122 Kumanyika SK, Adams-Campbell L, Van Horn B, Ten Have TR, Treu JA, Askov E, et al. Outcomes of a cardiovascular nutrition counseling program in African-Americans with elevated blood pressure or cholesterol level. J Am Diet Assoc. Nov. 1999;99(11):1380-91. [pmid: 10570675].
123 Kutner M, Greenberg E, Jin Y, Paulsen C. The health literacy of America's adults: results from the 2003 National Assessment of Adult Literacy (NCES 2006-483). 2006. [cited November 17, 2008]; Available from: http://eric.ed.gov/PDFS/ED493284.pdf.
124 Lee TW, Kang SJ, Lee HJ, Hyun SI. Testing health literacy skills in older Korean adults. Patient Educ Couns. Jun. 2009;75(3):302-7. [pmid: 19394184].
125 Lefebvre RC, Flora JA. Social Marketing and Public Health Intervention. Health Educ Q. Fall. 1988;15(3):299-315. [pmid: 3056876].
126 Lefebvre RC, Harden EA, Rakowski W, Lasater TM, Carleton RA. Characteristics of Participants in Community Health Promotion Programs: Four-Year Results. Am J Public Health. October. 1987;77(10):1342-4. [pmid: 3631372].
127 Lenhart A, Fox S, Horrigan J, Spooner T. Who's not online: 57% of those without Internet access say they do not plan to log on. 2000. September. 21. 2000 [cited 2009 March 6]; Available from: http://www.pewinternet.org/pdfs/Pew_Those_Not_Online_Report.pdf.
128 Levesque D, Cummins C, Miranda D, Prochaska J, Terrell S. Assessing Medicare beneficiaries' readiness to make informed health plan choices. Health Care Financ Rev. Fall. 2001;23(1):87-104. [pmid: 12500365].
129 Lewis CL, Pignone MP, Sheridan SL, Downs SM, Kinsinger LS. A randomized trial of three videos that differ in the framing of information about mammography in women 40 to 49 years old. J Gen Intern Med. Nov. 2003;18(11):875-83. [pmid: 14687272].
130 Lipkus IM. Numeric, verbal, and visual formats of conveying health risks: suggested best practices and future recommendations. Med Decis Making. Sep-Oct. 2007;27(5):696-713. [pmid: 17873259].
131 MacKinnon DP. Introduction to statistical mediation analysis. New York. Taylor & Francis Group, LLC. 2008.
132 Mayeaux EJ Jr, Murphy PW, Arnold C, Davis TC, Jackson RH, Sentell T. Improving patient education for patients with low literacy skills. Am Fam Physician. Jan. 1996;53(1):205-11. [pmid: 8546047].
133 McCormack L, Garfinkel S, Hibbard J, Kalsbeek W, Kilpatrick K. Beneficiary survey-based feedback on new Medicare information materials. Health Care Financ Rev. Fall. 2001;23(1):37-46. [pmid: 12500361].
134 McCormack L, Garfinkel S, Hibbard J, Keller S, Kilpatrick K, Kosiak B. Health insurance knowledge among Medicare beneficiaries. Health Serv Res. February. 2002;37(1):43-63. [pmid: 11949925].
135 McCormack L, Garfinkel S, Hibbard JH, Norton E, Bayen U. Health plan decision making with new medicare information materials. Health Serv Res. July. 2001;36(3):531-54. [pmid: 11482588].
136 McDonald PW. A Practical, Cost-effective Method for Recruiting People Into Healthy Eating Behavior Programs. Preventing Chronic Disease. April. 2007;4(2):A26. [pmid: 17362617].
137 McGettigan P, Sly K, O'Connell D, Hill S, Henry D. The effects of information framing on the practices of physicians. J Gen Intern Med. Oct. 1999;14(10):633-42. [pmid: 10571710].
138 McKellar AT, Rutland-Brown W. Using community medical auxiliary trainees to improve dose understanding among illiterate hospital outpatients in rural. Nepal Trop Doct. 2005;(35):17-8.
139 McNamara DS, Kintsch E, Songer NB, Kintsch W. Are Good Texts Always Better? Interactions of Text Coherence, Background Knowledge, and Levels of Understanding in Learning From Text. Cognition & Instruction. 03. 1996;14(1):1.
140 Meade CD, McKinney WP, Barnas GP. Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer. Am J Public Health. Jan. 1994;84(1):119-21. [pmid: 8279598].
141 Medicare Rights Center. Truth Is The Best Medicine. 2007. [cited 2008 July 29 ]; Available from: http://www.medicarerights.org/Truth_Best_Medicine.pdf.
142 MedPAC. Report To The Congress: Medicare Payment Policy. 2007. [cited 2008 July 10 ]; March:[Available from: http://www.medpac.gov/documents/Mar07_EntireReport.pdf.
143 MedPAC. Report To The Congress: Promoting Greater Efficiency In Medicine. 2007. [cited 2008 July 10 ]; June:[Available from: http://www.medpac.gov/documents/Jun07_EntireReport.pdf.
144 MedPAC. Report To The Congress: Medicare Payment Policy. 2008. [cited 2008 July 10 ]; March:[Available from: http://www.medpac.gov/documents/Mar08_EntireReport.pdf.
145 MedPAC. Report To The Congress: Reforming The Delivery System. 2008. [cited 2008 July 10 ]. June. [Available from: http://www.medpac.gov/documents/Jun08_EntireReport.pdf.
146 Michielutte R, Bahnson J, Dignan MB, Schroeder EM. The use of illustrations and narrative text style to improve readability of a health education brochure. J Cancer Educ. 1992;7(3):251-60. [pmid: 1419592].
147 Mitka M. Medicare Advantage Attacked. JAMA. August. 8. 2007. 2007;298(6):618-b.
148 Mitka M. Medicare (Dis)Advantage?. JAMA. April. 9. 2008. 2008;299(14):1657-b.
149 Mobley L, McCormack L, Wang J, Squire C, Kenyon A, Lynch J, et al. Voluntary Disenrollment From Medicare Advantage Plans: Valuable Signals Of Market Performance. Am J Manag Care. 2007;13(12):677-84. [pmid: 18069911].
150 Mohadjer L, Kalton G, Krenzke T, Liu B, Van de Kerckhove W, Li L, et al. National Assessment of Adult Literacy: Indirect County and State Estimates of the Percentage of Adults at the Lowest Level of Literacy for 1992 and 2003 (NCES 2009-482). Washington, D.C. 2009.
151 Moher D, Tricco AC. Issues related to the conduct of systematic reviews: a focus on the nutrition field. Am J Clin Nutr. 2008;88:1191-9. [pmid: 18996852].
152 Mosenthal PB, Kirsch IS. A new measure for assessing document complexity: The PMOSE/IKIRSCH document readability formula. Journal of Adolescent & Adult Literacy. 05. 1998;41(8):638.
153 Moxey A, O'Connell D, McGettigan P, Henry D. Describing treatment effects to patients. J Gen Intern Med. Nov. 2003;18(11):948-59. [pmid: 14687282].
154 Murphy PW, Chesson AL, Walker L, Arnold CL, Chesson LM. Comparing the effectiveness of video and written material for improving knowledge among sleep disorders clinic patients with limited literacy skills. South Med J. Mar. 2000;93(3):297-304. [pmid: 10728518].
155 Murphy PW, Davis TC, Mayeaux EJ, Sentell T, Arnold C, Rebouche C. Teaching nutrition education in adult learning centers: linking literacy, health care, and the community. J Community Health Nurs. 1996;13(3):149-58. [pmid: 8916604].
156 Murray MD, Tu W, Wu J, Morrow D, Smith F, Brater DC. Factors associated with exacerbation of heart failure include treatment adherence and health literacy skills. Clin Pharmacol Ther. Jun. 2009;85(6):651-8. [pmid: 19262464].
157 Nath CR, Sylvester ST, Yasek V, Gunel E. Development and validation of a literacy assessment tool for persons with diabetes. Diabetes Educ. 2001;27(6):857-64. [pmid: 12211925].
158 National Health Service Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in health care. 2009. [cited 2010 February 7th]; Available from: http://www.york.ac.uk/inst/crd/systematic_reviews_book.htm.
159 Nelson L, Brown R, Gold M, Ciemnecki A, Docteur E. Access to care in Medicare HMOs, 1996. Health Aff. March. 1. 1997. 1997;16(2):148-56.
160 Newhouse JP. How Much Should Medicare Pay For Drugs?. Health Aff. January. 1. 2004. 2004;23(1):89-102.
161 North Carolina Institute of Medicine. Issue Brief: Just What Did the Doctor Order? Addressing Low Health Literacy in North Carolina. 2007. [cited 2008 November 30 ]; Available from: http://www.nciom.org/projects/health_literacy/IssueBrief.pdf.
162 North Carolina Institute of Medicine. Just What Did the Doctor Order? Addressing Low Health Literacy in North Carolina. 2007. [cited 2008 November 30 ]; Available from: http://www.nciom.org/projects/health_literacy/HealthLiteracyReport.pdf.
163 NPR. Medicare Reform Efforts. The Diane Rehm Show: WAMU. 2008.
164 Ntiri DW, Stewart M. Transformative learning intervention: effect on functional health literacy and diabetes knowledge in older African Americans. Gerontol Geriatr Educ. 2009;30(2):100-13. [pmid: 19440898].
165 Nutbeam D. Health literacy as a public health goal: a challenge for contemporary health education and communication strategies into the 21st century. Health Promot Intl. 2000;15:259-67.
166 Oberlander J. Through the Looking Glass: The Politics of the Medicare Prescription Drug, Improvement, and Modernization Act. Journal of Health Politics Policy and Law. April. 1. 2007. 2007;32(2):187-219.
167 Oettinger MD, Finkle JP, Esserman D, Whitehead L, Spain TK, Pattishall SR, et al. Color-coding improves parental understanding of body mass index charting. Acad Pediatr. Sep-Oct. 2009;9(5):330-8. [pmid: 19679524].
168 Owens DK, Lohr KN, Atkins D, Treadwell JR, Reston JT, Bass EB, et al. Grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. In Press, Corrected Proof.
169 Owens DK, Lohr KN, Atkins D, Treadwell JR, Reston JT, Bass EB, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventionsAgency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
170 Paasche-Orlow MK, McCaffery K, Wolf MS. Bridging the international divide for health literacy research. Patient Educ Couns. Jun. 2009;75(3):293-4. [pmid: 19497492].
171 Pandit AU, Tang JW, Bailey SC, Davis TC, Bocchini MV, Persell SD, et al. Education, literacy, and health: Mediating effects on hypertension knowledge and control. Patient Educ Couns. Jun. 2009;75(3):381-5. [pmid: 19442477].
172 Parker R, Baker D, Williams M, Nurss J. The Test of Functional Health Literacy in Adults. J Gen Intern Med. 1995;10(10):537-41. [pmid: 8576769].
173 Pear R. AMA Says Government Should Negotiate On Drugs. The New York Times. 2004.
174 Pear R. Doctors Press Senate to Undo Medicare Cuts. The New York Times. 2008. July. 7.
175 Pear R, Herszenhorn DM. White House Predicts $482 Billion Deficit. The New York Times. 2008. July. 29.
176 Peck LE, Sharpe PA, Burroughs EL, Granner ML. Recruitment Strategies and Costs for a Community-Based Physical Activity Program. Health Promot Pract. April. 1. 2008. 2008;9(2):191-8. [pmid: 17494948].
177 Pepe M, Chodzko-Zajko WJ. . Impact of older adults' reading ability on the comprehension and recall of cholesterol information. J Health Educat. 1997;28(1):21-7.
178 Petty RE, Barden J, Wheeler SJ. The Elaboration likelihood model of persuasion: Health Promtion that yield sustained behavior change. San Francisco. Jossey-Bass. 2002.
179 Pharmaceutical Research and Manufacturers of America (PhRMA). The Truth is the Best Medicine: Get the Facts on Prescription Drug Costs. 2008. [cited 2008 July 29 ]; Available from: http://www.phrma.org/files/Truth%20is%20the%20Best%20Medicine--Facts.pdf.
180 Pirisi A. Low health literacy prevents equal access to care. The Lancet. 2000;356(9244):1828.
181 Pizer SD, Feldman R, Frakt AB. Defective Design: Regional Competition In Medicare. Health Aff. 2005. August. 23. 2005:hlthaff.w5.399.
182 Pollard RQ, Barnett S. Health-related vocabulary knowledge among deaf adults. Rehabil Psychol. May. 2009;54(2):182-5. [pmid: 19469608].
183 Pollard RQ, Dean RK, O'Hearn A, Haynes SL. Adapting health education material for deaf audiences. Rehabil Psychol. May. 2009;54(2):232-8. [pmid: 19469615].
184 Protheroe J, Wallace LS, Rowlands G, DeVoe JE. Health literacy: setting an international collaborative research agenda. BMC Fam Pract. 2009;10:51. [pmid: 19589176].
185 Radvinsky G. Aging Memory and Comprehension. Current Directions in Psych Science. 1999;8(2):49-53.
186 Raymond EG, Dalebout SM, Camp SI. Comprehension of a prototype over-the-counter label for an emergency contraceptive pill product. Obstet Gynecol. Aug. 2002;100(2):342-9. [pmid: 12151161].
187 Redelmeier DA, Shafir E. Medical decision making in situations that offer multiple alternatives. JAMA. January. 25. 1995. 1995;273(4):302-5. [pmid: 7815657].
188 Regan J, Petroski C. Prescription Drug Coverage Among Medicare Beneficiaries. Health Care Financ Rev. Fall. 2007;29(1):119-26. [pmid: 18624084].
189 Reinhardt UE. Perspectives On The Pharmaceutical Industry. Health Aff. September. 1. 2001. 2001;20(5):136-49.
190 Reinhardt UE. An Information Infrastructure For The Pharmaceutical Market. Health Aff. January. 1. 2004. 2004;23(1):107-12.
191 Rhodes SD, Bowie DA, Hergenrather KC. Collecting behavioural data using the world wide web: considerations for researchers. J Epidemiol Community Health. Jan. 2003;57(1):68-73. [pmid: 12490652].
192 Rogers EM, Ratzan SC, Payne JG. Health Literacy: A Nonissue in the 2000 Presidential Election. _m Behav Sci. August. 1. 2001. 2001;44(12):2172-95.
193 Rosenthal MB. Doughnut-Hole Economics. Health Aff. November. 1. 2004. 2004;23(6):129-35.
194 Rothman RL, So SA, Shin J, Malone RM, Bryant B, DeWalt DA, et al. Labor characteristics and program costs of a successful diabetes management program. Am J Manag Care. 2006;12(5):277-83. [pmid: 16686585].
195 RTI International-University of North Carolina Evidence-Based Practice Center. Research Protocol - Health Literacy Interventions and Outcomes: An Update of the Literacy and Health Outcomes Systematic Review of the Literature. 2010. [cited 2010 February 11 ]; Available from: http://www.effectivehealthcare.ahrq.gov/ehc/products/151/392/Health%20Literacy%20Protocol%20(2-9-2010).pdf.
196 Rudd RE, Blanch DC, Gall V, Chibnik LB, Wright EA, Reichmann W, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
197 Saul S. Strategies to Avoid Medicare's Big Hole. The New York Times. 2007.
198 Sawaya GF, Guirguis-Blake J, LeFevre M, Harris R, Petitti D. Update on the Methods of the U.S. Preventive Services Task Force: Estimating Certainty and Magnitude of Net Benefit. Ann Intern Med. December. 18. 2007. 2007;147(12):871-5. [pmid: 18087058].
199 Schillinger D, Handley M, Wang F, Hammer H. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. Apr. 2009;32(4):559-66. [pmid: 19131469].
200 Schlesinger M, Hacker JS. Secret Weapon: The “New” Medicare as a Route to Health Security. Journal of Health Politics Policy and Law. April. 1. 2007. 2007;32(2):247-91.
201 Schroder FH, Hugosson J, Roobol MJ, Tammela TL, Ciatto S, Nelen V, et al. Screening and prostate-cancer mortality in a randomized European study. N Engl J Med. Mar. 26. 2009;360(13):1320-8. [pmid: 19297566].
202 Scott TL, Gazmararian JA, Williams MV, Baker DW. Health Literacy and Preventive Health Care Use Among Medicare Enrollees in a Managed Care Organization. Med Care. May. 2002;40(5):395-404. [pmid: 11961474].
203 Shearer G. Confusing Inequitable Medicare Prescription Drug Benefit. J Gen Intern Med. 2007;22(2):286-8. [pmid: 17357002].
204 Sheridan SL, Pignone MP, Lewis CL. A randomized comparison of patients' understanding of number needed to treat and other common risk reduction formats. J Gen Intern Med. Nov. 2003;18(11):884-92. [pmid: 14687273].
205 Shieh C, Mays R, McDaniel A, Yu J. Health literacy and its association with the use of information sources and with barriers to information seeking in clinic-based pregnant women. Health Care Women Int. Nov. 2009;30(11):971-88. [pmid: 19809901].
206 Shone LP, Conn KM, Sanders L, Halterman JS. The role of parent health literacy among urban children with persistent asthma. Patient Educ Couns. Jun. 2009;75(3):368-75. [pmid: 19233588].
207 Slaughter LM. Medicare Part D -- The Product of a Broken Process. N Engl J Med. June. 1. 2006. 2006;354(22):2314-5. [pmid: 16738267].
208 Smith SK, Dixon A, Trevena L, Nutbeam D, McCaffery KJ. Exploring patient involvement in healthcare decision making across different education and functional health literacy groups. Soc Sci Med. Dec. 2009;69(12):1805-12. [pmid: 19846245].
209 Smith WA. Social Marketing: An Evolving Definition. American Journal of Health Behavior. 2000;24(1):11.
210 Snow CE. Reading for understanding: toward a research and development program in reading comprehension. 2002. Report No.: ISBN 0-8330-3105-8.
211 Social Security Administration. Social Security & Medicare Tax Rates. 2007. [cited 2008 July 10 ]; Available from: http://www.ssa.gov/OACT/ProgData/taxRates.html.
212 Stone D. Policy Paradox: The Art of Political Decision Making. New York. WW Norton & Company. 1997.
213 Stout D. Kennedy Casts Key Vote as Medicare Bill Passes. The New York Times. 2008. July. 10.
214 Stuart B, Briesacher BA, Shea DG, Cooper B, Baysac FS, Limcangco MR. Riding The Rollercoaster: The Ups And Downs In Out-Of-Pocket Spending Under The Standard Medicare Drug Benefit. Health Aff. July. 1. 2005. 2005;24(4):1022-31.
215 Sudore R, Yaffe K, Satterfield S, Harris T, Mehta K, Simonsick E, et al. Limited literacy and mortality in the elderly. J Gen Intern Med. 2006;21(8):806-12. [pmid: 16881938].
216 Sudore RL, Landefeld CS, Perez-Stable EJ, Bibbins-Domingo K, Williams BA, Schillinger D. Unraveling the relationship between literacy, language proficiency, and patient-physician communication. Patient Educ Couns. Jun. 2009;75(3):398-402. [pmid: 19442478].
217 Sutton SM, Balch GI, Lefebvre RC. Strategic Questions for Consumer-Based Health Communications. Public Health Rep. November/December. 1995;110:725. [pmid: 8570827].
218 Tan R. Medicare Beneficiaries' Use of Computers and Internet: 1998-2005. Health Care Financ Rev. Winter. 2006;28(2):45-52. [pmid: 17427844].
219 Teal C, Paterniti D, Murphy C, John D, Morgan R. Medicare Beneficiary Knowledge: Measurement Implications from a Qualitative Study. Health Care Financ Rev. Summer. 2006;27(4):13-23. [pmid: 17290655].
220 Thabit H, Shah S, Nash M, Brema I, Nolan JJ, Martin G. Globalization, immigration and diabetes self-management: an empirical study amongst immigrants with type 2 diabetes mellitus in Ireland. QJM. Oct. 2009;102(10):713-20. [pmid: 19736289].
221 The Kaiser Family Foundation/Harvard School of Public Health. The Public's Health Care Agenda for the New Congress and Presidential Campaign. 2006. [cited 2008 July 18 ]; Available from: http://www.kff.org/kaiserpolls/upload/7598.pdf.
222 Thorpe KE, Atherly A. Reforming Medicare: Impacts On Federal Spending And Choice Of Health Plans. Health Aff. 2001. October. 10. 2001:hlthaff.w1.51.
223 Tokuda Y, Doba N, Butler JP, Paasche-Orlow MK. Health literacy and physical and psychological wellbeing in Japanese adults. Patient Educ Couns. Jun. 2009;75(3):411-7. [pmid: 19403259].
224 Tversky A, Kahneman D. Judgment under Uncertainty: Heuristics and Biases. Science. 1974;185:1124. [pmid: 17835457].
225 Tversky A, Shafir E. CHOICE UNDER CONFLICT: The Dynamics of Deferred Decision. Psychological Science. 1992;3(6):358-61.
226 U.S. Census Bureau. Older Adults In 2005. 2006. [cited 2008 November 17 ]; Available from: http://www.census.gov/population/www/pop-profile/files/dynamic/OLDER.pdf.
227 U.S. Census Bureau. 2007. American Community Survey 1-Year Estimates. 2008 [cited 2008 November 17 ]; Available from: http://factfinder.census.gov/servlet/IPGeoSearchByListServlet?ds_name=ACS_2007_1YR_G00_&_lang=en&_ts=244997629375.
228 U.S. Census Bureau. Population Profile of the United States. 2008. [cited 2008 November 17 ]; Available from: http://www.census.gov/population/www/pop-profile/elderpop.html.
229 U.S. Census Bureau. U.S. Population Projections. 2008. [cited 2008 November 17 ]; Available from: http://www.census.gov/population/www/projections/summarytables.html.
230 United States Government Accountability Office (GAO). Medicare Advantage: Increased Spending Relative to Medicare Fee-For-Service May Not Always Reduce Beneficiary Out-of-Pocket Costs. Washington, DC. 2008.
231 US Department of Health and Human Services. 11: Health Communication, Healthy People 2010: Objectives for Improving Health. 2000. [cited 2008 July 19];. 2nd edition. [Available from: http://www.healthypeople.gov/Document/pdf/uih/2010uih.pdf.
232 US Department of Health and Human Services. Medicare Prescription Drug Plan Finder. 2008. [cited 2008 July 20 ]; Available from: http://www.medicare.gov/MPDPF/Shared/Include/DataSection/Results/Overview.asp.
233 von Wagner C, Semmler C, Good A, Wardle J. Health literacy and self-efficacy for participating in colorectal cancer screening: The role of information processing. Patient Educ Couns. Jun. 2009;75(3):352-7. [pmid: 19386461].
234 Wallace AS, Seligman HK, Davis TC, Schillinger D, Arnold CL, Bryant-Shilliday B, et al. Literacy-appropriate educational materials and brief counseling improve diabetes self-management. Patient Educ Couns. Jun. 2009;75(3):328-33. [pmid: 19167857].
235 Warren-Findlow J, Prohaska TR, Freedman D. Challenges and Opportunities in Recruiting and Retaining Underrepresented Populations Into Health Promotion Research. Gerontologist. March. 1. 2003. 2003;43(90001):37-46. [pmid: 12637688].
236 Wilkinson G. Wide Range Achievement Test 3—Administration Manual. Wilmington, DE. Jastak Associates, Inc. 1993.
237 Woloshin S, Schwartz LM, Welch HG. Patients and medical statistics: interest, confidence, and ability. J Gen Intern Med. April. 2005. 2005;20(11):996-1000. [pmid: 16307623].
238 Wong FL, Greenwell M, Gates S, Berkowitz JM. It's What You Do!: Reflections on the VERB(TM) Campaign. Am J Prev Med. 2008;34(6, Supplement 1):S175-S82. [pmid: 18471597].
239 Woodcock RW, Mather N. WJ-R tests of achievement: examiner's manual. 1989. 1990.
240 Wydra EW. The effectiveness of a self-care management interactive multimedia module. Oncol Nurs Forum. Oct. 2001;28(9):1399-407. [pmid: 11683310].
241 Xiao L, Ma Y, Hu JF, Cheng YL, Chen GY, Yang C, et al. [Study on indicator system for evaluating the adult health literacy in China]. Zhonghua Yu Fang Yi Xue Za Zhi. Mar. 2009;43(3):227-31. [pmid: 19534930].
242 Yancey AK, Jordan A, Bradford J, Voas J, Eller TJ, Buzzard M, et al. Engaging High-Risk Populations in Community-Level Fitness Promotion: ROCK! Richmond. Health Promot Pract. April. 1. 2003. 2003;4(2):180-8. [pmid: 14610988].
243 Yancey AK, Kumanyika SK, Ponce NA, McCarthy WJ, Fielding JE, Leslie JP, et al. Population-based Interventions Engaging Communities of Color in Healthy Eating and Active Living: A Review. Preventing Chronic Disease. January. 2004;1(1).
244 Yancey AK, Ory MG, Davis SM. Dissemination of Physical Activity Promotion Interventions in Underserved Populations. Am J Prev Med. 2006;31(4S):S82-S91. [pmid: 16979472].
245 Yin W, Basu A, Zhang JX, Rabbani A, Meltzer DO, Alexander GC. The Effect of the Medicare Part D Prescription Benefit on Drug Utilization and Expenditures. Ann Intern Med. February. 5. 2008. 2008;148(3):169-77. [pmid: 18180465].
246 Yost KJ, Webster K, Baker DW, Choi SW, Bode RK, Hahn EA. Bilingual health literacy assessment using the Talking Touchscreen/la Pantalla Parlanchina: Development and pilot testing. Patient Educ Couns. Jun. 2009;75(3):295-301. [pmid: 19386462].
247 Zhang Y, Donohue JM, Newhouse JP, Lave JR. The Effects Of The Coverage Gap On Drug Spending: A Closer Look At Medicare Part D. Health Aff. 2009. February. 3. 2009:hlthaff.28.2.w317.

## PsycINFO = 98 (excluding duplicates)

1 Akre C, Michaud PA, Berchtold A, Suris JC. Cannabis and tobacco use: Where are the boundaries? A qualitative study on cannabis consumption modes among adolescents. Health Educ Res. 2010;25(1):74-82. [pmid: 19515745].
2 Angner E, Miller MJ, Ray MN, Saag KG, Allison JJ. Health literacy and happiness: A community-based study. Social Indicators Research. 2010;95(2):325-38.
3 Ashworth JA. A case study of comprehensive schoolwide improvement at a high needs elementary school. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2009. 2009;69(10):3862.
4 Balfour L, Kowal J, Corace KM, Tasca GA, Krysanski V, Cooper CL, et al. Increasing public awareness about hepatitis C: Development and validation of the brief hepatitis c knowledge scale. Scand J Caring Sci. 2009;23(4):801-8. [pmid: 19500309].
5 Bogen K, Biener L, Garrett CA, Allen J, Cummings KM, Hartman A, et al. Surveillance indicators for potential reduced exposure products (PREPs): Developing survey items to measure awareness. Harm Reduction Journal. 2009:6.
6 Bouwman LI, te Molder H, Koelen MM, van Woerkum CMJ. I eat healthfully but I am not a freak. Consumers’ everyday life perspective on healthful eating. Appetite. 2009;53(3):390-8. [pmid: 19698753].
7 Britigan DH, Murnan J, Rojas-Guyler L. A qualitative study examining Latino functional health literacy levels and sources of health information. J Community Health. 06. 2009;34(3):222-30. [pmid: 19127413].
8 Caballero Schillaci P. Postpartum depression and its treatment: Knowledge, attitudes, and preferences among new and expecting mothers in a hispanic population. 2010:70.
9 Callaly T, Berk M, Dodd S. Suicidality: the challenge for public mental health services. Acta Neuropsychiatrica. Feb. 2009. 2009;21(1):41-3.
10 Campbell M. Access to healthcare among Hispanic immigrants in Memphis, Tennessee: Consensus and contention in cultural models. 2010:70.
11 Carbone ET, Lennon KM, Torres MI, Rosal MC. Testing the feasibility of an interactive learning styles measure for U.S. Latino adults with type 2 diabetes and low literacy. International Quarterly of Community Health Education. 2006;25(4):315-35. [pmid: 17686705].
12 Chen A, Mond JM, Kumar R. Eating disorders mental health literacy in Singapore: Beliefs of young adult women concerning treatment and outcome of bulimia nervosa. Early Intervention in Psychiatry. 2010;4(1):39-46. [pmid: 20199479].
13 Compton MT, Broussard B. The first episode of psychosis: A guide for patients and their families. New York, NY,US. Oxford University Press. 2009.
14 Davis TC, Gazmararian J, Kennen EM. Approaches to Improving Health Literacy: Lessons From the Field. Journal of Health Communication. 09. 2006;11(6):551-4. [pmid: 16950727].
15 Denham SA. Diabetes: A family matter. Journal of Family Nursing. Aug. 2009. 2009;15(3):400-1. [pmid: 19622843].
16 Dunbar-Jacob J, Gemmell LA, Schlenk EA, editors. Predictors of patient adherence: Patient characteristics. New York, NY,US. Springer Publishing Co. 2009.
17 Dunford MD. Provider recognition of patient health literacy. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;70(1):210.
18 Dwamena FC, Mavis B, Holmes-Rovner M, Walsh KB, Loyson AC. Teaching medical interviewing to patients: The other side of the encounter. Patient Educ Couns. Sep. 2009. 2009;76(3):380-4. [pmid: 19674860].
19 Edwards M, Davies M, Edwards A. What are the external influences on information exchange and shared decision-making in healthcare consultations: A meta-synthesis of the literature. Patient Educ Couns. Apr. 2009. 2009;75(1):37-52. [pmid: 19036550].
20 Eysenck W. Personality, intelligence, and longevity: A cross-cultural perspective. Social Behavior and Personality. 2009. 2009;37(2):149-54.
21 Finset A, Lie HC. Health literacy and communication explored from different angles. Patient Educ Couns. 2010;79(1):1-2. [pmid: 20226340].
22 Furnham A, Daoud Y, Swami V. ‘How to spot a psychopath’: Lay theories of psychopathy. Soc Psychiatry Psychiatr Epidemiol. Jun. 2009. 2009;44(6):464-72. [pmid: 18982232].
23 Garrett DM. Parental perceptions of overweight in toddlers and preschool children. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;70(2):939.
24 Garside R, Pearson M, Moxham T. What influences the uptake of information to prevent skin cancer? A systematic review and synthesis of qualitative research. Health Educ Res. 2010;25(1):162-82. [pmid: 19858077].
25 Giarelli E, Bernhardt BA, Pyeritz RE. Self-surveillance by adolescents and young adults transitioning to self-management of a chronic genetic disorder. Health Educ Behav. 2010;37(1):133-50. [pmid: 19349431].
26 Gonzalez JS, Hendriksen ES, Collins EM, DurÃ¡n RE, Safren SA. Latinos and HIV/AIDS: Examining factors related to disparity and identifying opportunities for psychosocial intervention research. AIDS and Behavior. Jun. 2009. 2009;13(3):582-602. [pmid: 18498050].
27 Hagglund KJ, Shigaki CL, McCall JG, editors. New media: A third force in health care. New York, NY,US. Springer Publishing Co. 2009.
28 Halbert CH, Kumanyika S, Bowman M, Bellamy SL, Briggs V, Brown S, et al. Participation rates and representativeness of African Americans recruited to a health promotion program. Health Educ Res. 2010;25(1):6-13. [pmid: 19875730].
29 Han HR, Lee H, Kim MT, Kim KB. Tailored lay health worker intervention improves breast cancer screening outcomes in nonadherent Korean-American women. Health Educ Res. Apr. 2009. 2009;24(2):318-29. [pmid: 18463411].
30 Hargreaves J, Hatcher A, Strange V, Phetla G, Busza J, Kim J, et al. Process evaluation of the Intervention with Microfinance for AIDS and Gender Equity (IMAGE) in rural South Africa. Health Educ Res. 2010;25(1):27-39. [pmid: 19797337].
31 Haun J. Health literacy assessment. Rehabilitation and health assessment: Applying ICF guidelines. 2010:673-95.
32 Hay PJ, de Angelis C, Millar H, Mond J. Bulimia nervosa mental health literacy of general practitioners. Primary Care & Community Psychiatry. 2005;10(3):103-8.
33 Hoffman-Goetz L, Meissner HI, Thomson MD. Literacy and cancer anxiety as predictors of health status: An exploratory study. J Cancer Educ. Jul. 2009. 2009;24(3):218-24. [pmid: 19526411].
34 Honore HH. Perception of genetic risk in sexual and reproductive decision-making (pgrid) by college students. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;69(10):6048.
35 Huang YW, Hung CH. The effect of health education through the internet on university female students hepatitis B knowledge and cognition. J Clin Nurs. 2009;18(23):3342-8. [pmid: 19732240].
36 Hurd NM, Valerio MA, Garcia NM, Scott AA. Adapting an HIV prevention intervention for high-risk, incarcerated adolescents. Health Educ Behav. 2010;37(1):37-50. [pmid: 19494058].
37 Isaacs AN, Pyett P, Oakley-Browne MA, Gruis H, Waples-Crowe P. Barriers and facilitators to the utilization of adult mental health services by Australia's indigenous people: Seeking a way forward. International Journal of Mental Health Nursing. 2010;19(2):75-82. [pmid: 20367644].
38 Jayasundara DS. Reproductive health of women in developing countries and human development: A test of Sen's theory. 2010:70.
39 Jensen JD, King AJ, Guntzviller LM, Davis LA. Patient–provider communication and low-income adults: Age, race, literacy, and optimism predict communication satisfaction. Patient Educ Couns. 2010;79(1):30-5. [pmid: 19879093].
40 John H, Treharne GJ, Hale ED, Panoulas VF, Carroll D, Kitas GD. Development and initial validation of a heart disease knowledge questionnaire for people with rheumatoid arthritis. Patient Educ Couns. Oct. 2009. 2009;77(1):136-43. [pmid: 19395226].
41 Johnson VR, Jacobson KL, Gazmararian JA, Blake SC. Does social support help limited-literacy patients with medication adherence?: A mixed methods study of patients in the pharmacy intervention for limited literacy (PILL) study. Patient Educ Couns. 2010;79(1):14-24. [pmid: 19647967].
42 Jordan JE, Buchbinder R, Osborne RH. Conceptualising health literacy from the patient perspective. Patient Educ Couns. 2010;79(1):36-42. [pmid: 19896320].
43 Kermode M, Bowen K, Arole S, Pathare S, Jorm AF. Attitudes to people with mental disorders: A mental health literacy survey in a rural area of Maharashtra, India. Soc Psychiatry Psychiatr Epidemiol. 2009;44(12):1087-96. [pmid: 19305937].
44 Kirkcaldy B, Furnham A, Siefen G. The Relationship Between Health Efficacy, Educational Attainment, and Well-Being Among 30 Nations. European Psychologist. 06. 2004;9(2):107-19.
45 Koyama T, Tachimori H, Sawamura K, Koyama A, Naganuma Y, Makino H, et al. Mental health literacy of autism spectrum disorders in the Japanese general population. Soc Psychiatry Psychiatr Epidemiol. Aug. 2009. 2009;44(8):651-7. [pmid: 19096742].
46 LaHousse SF. Factors associated with mammography screening utilization among latinas: A revision of the behavioral model of health services use. 2010:70.
47 Latimer AE, Green KE, Schmid K, Tomasone J, Abrams S, Cummings KM, et al. The identification of framed messages in the New York State Smokers’ Quitline materials. Health Educ Res. 2010;25(1):54-60. [pmid: 19656799].
48 Lee JP, Battle RS, Lipton R, Soller B. ‘Smoking’: Use of cigarettes, cigars and blunts among Southeast Asian American youth and young adults. Health Educ Res. 2010;25(1):83-96. [pmid: 19959564].
49 Lee SYD, Arozullah AM, Cho YI, Crittenden K, Vicencio D. Health literacy, social support, and health status among older adults. Educational Gerontology. 03. 2009;35(3):191-201.
50 Lesaux NK, Vukovic RK, Hertzman C, Siegel LS. Context matters: The interrelatedness of early literacy skills, developmental health, and community demographics. Early Education and Development. 2007;18(3):497-518.
51 Levinthal BR, Morrow DG, Tu W, Wu J, Murray MD. Cognition and health literacy in patients with hypertension. J Gen Intern Med. 08. 2008;23(8):1172-6. [pmid: 18459011].
52 Lipscomb M, Ishmael A. Humanistic educational theory and the socialization of preregistration mental health nursing students. International Journal of Mental Health Nursing. Jun. 2009. 2009;18(3):173-8. [pmid: 19490227].
53 Liu Cj, Kemper S, McDowd J. The use of illustration to improve older adultsâ€™ comprehension of health-related information: Is it helpful?. Patient Educ Couns. Aug. 2009. 2009;76(2):283-8. [pmid: 19286343].
54 Lohse B, Rifkin R, Krall JS. Digital photo receivers deliver herbal education for low-income persons. Journal of Nutrition Education and Behavior. 2009;41(6):438-40. [pmid: 19879502].
55 Lonigan GS. The relationship between performance on the WRAML2 and WRAT4 for school age children. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;70(2):1349.
56 López SR, Lara MC, Kopelowicz A, Solano S, Foncerrada H, Aguilera A. La CLAve to increase psychosis literacy of Spanish-speaking community residents and family caregivers. J Consult Clin Psychol. Aug. 2009. 2009;77(4):763-74. [pmid: 19634968].
57 Low LF, Anstey KJ. Authors' response to: Commentary on Low and Anstey: Cross-cultural findings and insights. Alzheimer's & Dementia. May. 2009. 2009;5(3):282.
58 Marks JR, Schectman JM, Groninger H, Plews-Ogan ML. The association of health literacy and socio-demographic factors with medication knowledge. Patient Educ Couns. 2010;78(3):372-6. [pmid: 19773144].
59 Martin LT, Ruder T, Escarce JJ, Ghosh-Dastidar B, Sherman D, Elliott M, et al. Developing predictive models of health literacy. J Gen Intern Med. 2009;24(11):1211-6. [pmid: 19760299].
60 Matsaganis MD. Rediscovering the communication engine of neighborhood effects: How the interaction of residents and community institutions impacts health literacy and how it can be leveraged to improve health care access. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;70(1):239.
61 McCann TV, Lu S, Berryman C. Mental health literacy of Australian Bachelor of Nursing students: A longitudinal study. J Psychiatr Ment Health Nurs. 02. 2009;16(1):61-7. [pmid: 19192087].
62 Mond JM, Myers TC, Crosby RD, Hay PJ, Mitchell JE. Bulimic eating disorders in primary care: Hidden morbidity still?. Journal of Clinical Psychology in Medical Settings. 2010;17(1):56-63. [pmid: 20039194].
63 Murdaugh CL, Insel K, editors. Problems with adherence in the elderly. New York, NY,US. Springer Publishing Co. 2009.
64 Murphy DA, Lam P, Naar-King S, Harris DR, Parsons JT, Muenz LR. Health literacy and antiretroviral adherence among HIV-infected adolescents. Patient Educ Couns. 2010;79(1):25-9. [pmid: 19665860].
65 Nieves-Khouw F, Welton R, Muchow N. Bariatric surgery: Beyond informed consent. Bariatric Nursing and Surgical Patient Care. 2009;4(3):191-202.
66 Oh E, Jorm AF, Wright A. Perceived helpfulness of websites for mental health information: A national survey of young Australians. Soc Psychiatry Psychiatr Epidemiol. Apr. 2009. 2009;44(4):293-9. [pmid: 18830552].
67 Orenstein M. Social emotional and cognitive functioning of obese and non-obese minority, low SES children. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;69(7):4460.
68 Osborn CY, Davis TC, Bailey SC, Wolf MS. Health literacy in the context of HIV treatment: Introducing the Brief Estimate of Health Knowledge and Action (BEHKA)— HIV version. AIDS and Behavior. 2010;14(1):181-8. [pmid: 19023653].
69 Park S. The effects of acculturation and education upon intelligence test performances in Korean Americans. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009. 2009;69(8):5046.
70 Parker JC, Thorson E, editors. Health communication in the new media landscape. New York, NY,US. Springer Publishing Co. 2009.
71 Patwardhan V. Decision making and reasoning of rural and urban illiterate women in India. Gender & Behaviour. 2005;3:361-72.
72 Peek ME, Wilson SC, Gorawara-Bhat R, Odoms-Young A, Quinn MT, Chin MH. Barriers and facilitators to shared decision-making among African-Americans with diabetes. J Gen Intern Med. 2009;24(10):1135-9. [pmid: 19578818].
73 Peerson A, Saunders M. Health literacy revisited: What do we mean and why does it matter?. Health promotion international. 2009;24(3):285-96. [pmid: 19372101].
74 Peters E, Dieckmann NF, VÃ¤stfjÃ¤ll D, Mertz CK, Slovic P, Hibbard JH. Bringing meaning to numbers: The impact of evaluative categories on decisions. Journal of Experimental Psychology: Applied. Sep. 2009. 2009;15(3):213-27. [pmid: 19751072].
75 Pickard AS, Lin H-W, Knight SJ, Sharifi R, Wu Z, Hung SY, et al. ‘Proxy assessment of health-related quality of life in African American and White respondents with prostate cancer: Perspective matters’: Erratum. Med Care. Apr. 2009. 2009;47(4):491.
76 Pieterse AH, Berkers F, Baas-Thijssen MCM, Marijnen CAM, Stiggelbout AM. Adaptive conjoint analysis as individual preference assessment tool: Feasibility through the internet and reliability of preferences. Patient Educ Couns. 2010;78(2):224-33. [pmid: 19581069].
77 Ranahan P. Mental health literacy: A conceptual framework for future inquiry into child and youth care professionals' practice with suicidal adolescents. Child & Youth Care Forum. 2010;39(1):11-25.
78 Reyna VF, Nelson WL, Han PK, Dieckmann NF. How numeracy influences risk comprehension and medical decision making. Psychol Bull. Nov. 2009. 2009;135(6):943-73. [pmid: 19883143].
79 Roman SP. Illiteracy and older adults: Individual and societal implications. Educational Gerontology. 02. 2004;30(2):79-93.
80 Schillinger D, Wang F, Palacios J, Rodriguez M, Machtinger EL, Bindman A. Language, Literacy, and Communication Regarding Medication in an Anticoagulation Clinic: A Comparison of Verbal vs. Visual Assessment. Journal of Health Communication. 10. 2006;11(7):651-64. [pmid: 17074733].
81 Sharif I, Blank AE. Relationship between child health literacy and body mass index in overweight children. Patient Educ Couns. 2010;79(1):43-8. [pmid: 19716255].
82 Shaw A, Ibrahim S, Reid F, Ussher M, Rowlands G. Patients' perspectives of the doctor-patient relationship and information giving across a range of literacy levels. Patient Educ Couns. Apr. 2009. 2009;75(1):114-20. [pmid: 19041210].
83 Shaw SJ, Huebner C, Armin J, Orzech K, Vivian J. The role of culture in health literacy and chronic disease screening and management. Journal of Immigrant and Minority Health. 2009;11(6):460-7. [pmid: 18379877].
84 Shevil E, Finlayson M. Pilot study of a cognitive intervention program for persons with multiple sclerosis. Health Educ Res. 2010;25(1):41-53. [pmid: 19651639].
85 Shieh C, Mays R, McDaniel A, Yu J. Health literacy and its association with the use of information sources with barriers to information seeking in clinic-based pregnant women. Health Care Women Int. 2009;30(11):971-88. [pmid: 19809901].
86 Small LFF. Corrigendum of ‘What older adults know about HIV/AIDS: Lessons from an HIV/AIDS education program‘. Educational Gerontology. 2010;36(5):449-50.
87 Small LFF. What older adults know about HIV/AIDS: Lessons from an HIV/AIDS education program. Educational Gerontology. 2010;36(1):26-45.
88 Steckelberg A, HÃ¼lfenhaus C, Kasper Jr, Rost Jr, MÃ¼hlhauser I. How to measure critical health competences: Development and validation of the Critical Health Competence Test (CHC test). Advances in Health Sciences Education. Mar. 2009. 2009;14(1):11-22. [pmid: 17902033].
89 Stewart S, Riecken T, Scott T, Tanaka M, Riecken J. Expanding health literacy: Indigenous youth creating videos. Journal of Health Psychology. 03. 2008;13(2):180-9. [pmid: 18375624].
90 Storrs D. Critical literacy among the working poor: Individualism and pseudostructural interpretive narratives of health inequalities. Sociological Perspectives. 03. 2007;50(1):79-100.
91 Waldrop-Valverde D, Jones DL, Jayaweera D, Gonzalez P, Romero J, Ownby RL. Gender differences in medication management capacity in HIV infection: The role of health literacy and numeracy. AIDS and Behavior. 2009;13(1):46-52. [pmid: 18618237].
92 Wallace LS, Rogers ES, Roskos SE, Holiday DB, Weiss BD. Screening Items to Identify Patients with Limited Health Literacy Skills. J Gen Intern Med. 08. 2006;21(8):874-7. [pmid: 16881950].
93 Wangberg S, Andreassen H, Kummervold P, Wynn R, Sørensen T. Use of the internet for health purposes: Trends in Norway 2000-2010. Scand J Caring Sci. 2009;23(4):691-6. [pmid: 19473317].
94 Werner P. Commentary on Low and Anstey: Cross-cultural findings and insights. Alzheimer's & Dementia. May. 2009. 2009;5(3):280-1.
95 Wong FKD, Lam YKA, Poon A. Depression literacy among Australians of Chinese-speaking background in Melbourne, Australia. BMC Psychiatry. 2010:10.
96 Wright JA, Stackhouse J, Wood J. Promoting language and literacy skills in the early years: Lessons from interdisciplinary teaching and learning. Child Language Teaching & Therapy. 06. 2008;24(2):155-71.
97 Zarcadoolas C, Pleasant A, editors. Health literacy in the digital world. New York, NY,US. Springer Publishing Co. 2009.
98 Zebrack BJ, Donohue JE, Gurney JG, Chesler MA, Bhatia S, Landier W. Psychometric evaluation of the impact of cancer (IOC-CS) scale for young adult survivors of childhood cancer. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2010;19(2):207-18.

## PubMed = 3044 (excluding duplicates)

1 Numeracy skills. Paediatr Nurs. Jul. 1998;10(6):26-30. quiz 1-2. [pmid: 9782969].
2 Low literacy levels can limit effectiveness of DM programs. Dis Manag Advis. May. 2003;9(5):65-9. [pmid: 12825392].
3 Putting the spotlight on health literacy to improve quality care. Qual Lett Healthc Lead. Jul. 2003;15(7):2-11. 1.
4 Accessible Web design. J Audiov Media Med. Sep. 2004;27(3):131-4. [pmid: 15799590].
5 ACOG Committee Opinion No. 30. Informed refusal6. Obstet Gynecol. Dec. 2004;104(6):1465-6. [pmid: 15572515].
6 AHRQ. IOM weigh in on developing a health-literate America. Qual Lett Healthc Lead. May. 2004;16(5):6-8.
7 Institute of Medicine report calls for national effort to improve health literacy. N Y State Dent J. Apr. 2004;70(4):36-7.
8 Intensive approach pays off in diabetics with low literacy skills. Dis Manag Advis. Dec. 2004;10(12):133-7. [pmid: 15673127].
9 Medical literacy becoming a bigger challenge. Interventions aimed at disadvantaged populations. AIDS Alert. Apr. 2004;19(4):43-5. [pmid: 15074294].
10 Health literacy and understanding medical information. Prairie Rose. 2005 Nov-2006 Jan. 74(4):17. [pmid: 16594184].
11 The invisible barrier: literacy and its relationship with oral health. A report of a workgroup sponsored by the National Institute of Dental and Craniofacial Research, National Institute of Health, U.S. Public Health Service, Department of Health and Human Services. J Public Health Dent. Summer. 2005;65(3):174-82. [pmid: 16171263].
12 NQF looks to improve informed consent for individuals with limited health literacy. Qual Lett Healthc Lead. Oct. 2005;17(10):13-4.
13 What is health literacy?. Prairie Rose. 2005 Nov-2006 Jan. 74(4):16.
14 Health literacy: the most important vital sign?. Dis Manag Advis. Jan. 2006;12(1):6-8. 1. [pmid: 16502814].
15 Literacy and health practice resources. Can J Public Health. May-Jun. 2. 2006;97:S14-5. [pmid: 16805155].
16 Ten common mistakes that keep patients from using your hospital's Web site--and 10 solutions. Hosp Health Netw. Nov. 2006;80(11):92-4. [pmid: 17216798].
17 ACOG Committee Opinion No. 391, December 2007. Health literacy. Obstet Gynecol. Dec. 2007;110(6):1489-91. [pmid: 18055753].
18 Don't overlook patients with low health literacy. Hosp Peer Rev. Jun. 2007;32(6):86-8. [pmid: 17624021].
19 An emerging giant: nursing informatics. Nurs Manage. Mar. 2007;38(3):38-42.
20 The feasibility of audio computer-assisted self-interviewing in international settings. AIDS. Apr. 2. 2007;21:S49-58.
21 The Joint Commission calls for comprehensive action on poor health literacy. Dis Manag Advis. Mar. 2007;13(3):34-5. 25. [pmid: 17427546].
22 The Joint Commission releases white paper on health literacy. Jt Comm Perspect. May. 2007;27(5):13.
23 Low health literacy puts patients at risk. Bull Am Coll Surg. Jul. 2007;92(7):94-5. [pmid: 17849633].
24 Maintaining evidence-based practice. J Vis Commun Med. Sep. 2007;30(3):132-4. [pmid: 17968727].
25 White paper underscores patient health literacy. ED Manag. May. 2007;19(5):3-4.
26 eHealth Blueprint outlines health information technology implementation in the United States. Optometry. Feb. 2008;79(2):107-10. [pmid: 18286742].
27 Health literacy problem affecting the bottom line. Many in healthcare unaware of the issue. Dis Manag Advis. Sep. 2008;14(9):5-6. 1.
28 Medication therapy management in pharmacy practice: core elements of an MTM service model (version 2.0). J Am Pharm Assoc (2003). May-Jun. 2008;48(3):341-53. [pmid: 18595820].
29 Screening for prostate cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Aug. 5. 2008;149(3):185-91. [pmid: 18678845].
30 Summaries for patients. Association of numeracy and diabetes control. Ann Intern Med. May. 20. 2008;148(10):I53. [pmid: 18490670].
31 Educational advantage. J Empir Res Hum Res Ethics. Dec. 2009;4(4):79-80. [pmid: 19919321].
32 Racial disparities in total knee replacement among Medicare enrollees--United States, 2000-2006. MMWR Morb Mortal Wkly Rep. Feb. 20. 2009;58(6):133-8. [pmid: 19229164].
33 Andrulis DP, Brach C. Integrating literacy, culture, and language to improve health care quality for diverse populations. Am J Health Behav. Sep-Oct. 31. 1. 2007:S122-33.
34 Aarnoudse-Moens CS, Weisglas-Kuperus N, van Goudoever JB, Oosterlaan J. Meta-analysis of neurobehavioral outcomes in very preterm and/or very low birth weight children. Pediatrics. Aug. 2009;124(2):717-28. [pmid: 19651588].
35 Abbeduto L, Warren SF, Conners FA. Language development in Down syndrome: from the prelinguistic period to the acquisition of literacy. Ment Retard Dev Disabil Res Rev. 2007;13(3):247-61. [pmid: 17910087].
36 Abbey A, Saenz C, Buck PO, Parkhill MR, Hayman LW Jr. The effects of acute alcohol consumption, cognitive reserve, partner risk, and gender on sexual decision making. J Stud Alcohol. Jan. 2006;67(1):113-21. [pmid: 16536135].
37 Abbot JM, Thomson CA, Ranger-Moore J, Teixeira PJ, Lohman TG, Taren DL, et al. Psychosocial and behavioral profile and predictors of self-reported energy underreporting in obese middle-aged women. J Am Diet Assoc. Jan. 2008;108(1):114-9. [pmid: 18155996].
38 Abdrbo AA, Hudak CA, Anthony MK, Douglas SL. Moderating and mediating roles of nurses' beliefs: information systems use among Ohio nurses. West J Nurs Res. Feb. 2009;31(1):110-27. [pmid: 19028922].
39 Abdullah L, Margolis S, Townsend T. Primary health care patients' knowledge about diabetes in the United Arab Emirates. East Mediterr Health J. Jul-Sep. 2001;7(4-5):662-70. [pmid: 15332764].
40 Abebe Y, Schaap A, Mamo G, Negussie A, Darimo B, Wolday D, et al. HIV prevalence in 72 000 urban and rural male army recruits, Ethiopia. AIDS. Aug. 15. 2003;17(12):1835-40. [pmid: 12891070].
41 Abed H, Rogers R, Helitzer D, Warner TD. Informed consent in gynecologic surgery. Am J Obstet Gynecol. Dec. 2007;197(6):674 e1-5. [pmid: 18060978].
42 Abel E, Hopson L, Delville C. Health promotion for women with human immunodeficiency virus or acquired immunodeficiency syndrome. J Am Acad Nurse Pract. Nov. 2006;18(11):534-43. [pmid: 17064331].
43 Abernethy AP, Currow DC, Hunt R, Williams H, Roder-Allen G, Rowett D, et al. A pragmatic 2 × 2 × 2 factorial cluster randomized controlled trial of educational outreach visiting and case conferencing in palliative care-methodology of the Palliative Care Trial [ISRCTN 81117481]. Contemp Clin Trials. Feb. 2006;27(1):83-100. [pmid: 16290094].
44 Abolfotouh MA, Daffallah AA, Khan MY, Khattab MS, Abdulmoneim I. Psychosocial assessment of geriatric subjects in Abha City, Saudi Arabia. East Mediterr Health J. May. 2001;7(3):481-91. [pmid: 12690770].
45 Abrams MA, Klass P, Dreyer BP. Health literacy and children: introduction. Pediatrics. Nov. 3. 2009;124:S262-4. [pmid: 19861479].
46 Abrams MA, Klass P, Dreyer BP. Health literacy and children: recommendations for action. Pediatrics. Nov. 3. 2009;124:S327-31. [pmid: 19861487].
47 Abutalebi J, Keim R, Brambati SM, Tettamanti M, Cappa SF, De Bleser R, et al. Late acquisition of literacy in a native language. Hum Brain Mapp. Jan. 2007;28(1):19-33. [pmid: 16639742].
48 Achmat Z, Simcock J. Combining prevention, treatment and care: lessons from South Africa. AIDS. Jul. 4. 2007;21:S11-20. [pmid: 17620746].
49 Ackerson LK, Kawachi I, Barbeau EM, Subramanian SV. Effects of individual and proximate educational context on intimate partner violence: a population-based study of women in India. Am J Public Health. Mar. 2008;98(3):507-14. [pmid: 18235066].
50 Acosta-Mendez M, Mariscal-Servitje L, Santos-Burgoa C. The present and future of Mexican health promotion. Promot Educ. 2007;14(4):224-7. [pmid: 18372873].
51 Adam JE. Transcultural nursing courses online: implications for culturally competent care. Nurs Clin North Am. Dec. 2008;43(4):567-74. vi. [pmid: 18940413].
52 Adams A, Adams R, Thorogood M, Buckingham C. Barriers to the use of ehealth technology in nurse practitioner-patient consultations. Inform Prim Care. 2007;15(2):103-9. [pmid: 17877872].
53 Adams A, Duffield C. The value of drills in developing and maintaining numeracy skills in an undergraduate nursing programme. Nurse Educ Today. Jun. 1991;11(3):213-9. [pmid: 2062280].
54 Adams RJ, Stocks NP, Wilson DH, Hill CL, Gravier S, Kickbusch I, et al. Health literacy˜a new concept for general practice?. Aust Fam Physician. Mar. 2009;38(3):144-7. [pmid: 19283256].
55 Adelson N. The embodiment of inequity: health disparities in aboriginal Canada. Can J Public Health. Mar-Apr. 2. 2005;96:S45-61. [pmid: 16078555].
56 Adelsward V, Sachs L. The meaning of 6.8: numeracy and normality in health information talks. Soc Sci Med. Oct. 1996;43(8):1179-87. [pmid: 8903121].
57 Adesiyun AG. Female sterilization by tubal ligation: a re-appraisal of factors influencing decision making in a tropical setting. Arch Gynecol Obstet. Apr. 2007;275(4):241-4. [pmid: 17021769].
58 Adily A, Westbrook J, Coiera E, Ward J. Use of on-line evidence databases by Australian public health practitioners. Med Inform Internet Med. Jun. 2004;29(2):127-36. [pmid: 15370993].
59 Adnams CM, Sorour P, Kalberg WO, Kodituwakku P, Perold MD, Kotze A, et al. Language and literacy outcomes from a pilot intervention study for children with fetal alcohol spectrum disorders in South Africa. Alcohol. Sep. 2007;41(6):403-14. [pmid: 17936509].
60 Advocat J, Lindsay J. Internet-based trials and the creation of health consumers. Soc Sci Med. Feb. 2010;70(3):485-92. [pmid: 19926185].
61 Afolabi AO. Factors influencing the pattern of self-medication in an adult Nigerian population. Ann Afr Med. Sep. 2008;7(3):120-7. [pmid: 19253521].
62 Agardh EE, Ahlbom A, Andersson T, Efendic S, Grill V, Hallqvist J, et al. Socioeconomic position at three points in life in association with type 2 diabetes and impaired glucose tolerance in middle-aged Swedish men and women. Int J Epidemiol. Feb. 2007;36(1):84-92. [pmid: 17510076].
63 Agarwal KN, Agarwal DK, Sharma A, Sharma K, Prasad K, Kalita MC, et al. Prevalence of anaemia in pregnant and lactating women in India. Indian J Med Res. Aug. 2006;124(2):173-84. [pmid: 17015931].
64 Agarwal S, Raman R, Paul PG, Rani PK, Uthra S, Gayathree R, et al. Sankara Nethralaya-Diabetic Retinopathy Epidemiology and Molecular Genetic Study (SN-DREAMS 1): study design and research methodology. Ophthalmic Epidemiol. Apr. 2005;12(2):143-53. [pmid: 16019696].
65 Agbaje EO, Babatunde EO. A KAP study of the attitude and practice of traditional medicine in a contemporary Nigerian community. Cent Afr J Med. May-Jun. 2005;51(5-6):58-62. [pmid: 17432433].
66 Aggarwal A, Speckman JL, Paasche-Orlow MK, Roloff KS, Battaglia TA. The role of numeracy on cancer screening among urban women. Am J Health Behav. Sep-Oct. 1. 2007;31:S57-68. [pmid: 17931137].
67 Agness C, Murrell E, Nkansah N, Martin CM. Poor health literacy as a barrier to patient care. Consult Pharm. May. 2008;23(5):378-82. 85. 6. [pmid: 18540791].
68 Agre P, Stieglitz E, Milstein G. The case for development of a new test of health literacy. Oncol Nurs Forum. Mar. 2006;33(2):283-9. [pmid: 16518444].
69 Aguirre AC, Ebrahim N, Shea JA. Performance of the English and Spanish S-TOFHLA among publicly insured Medicaid and Medicare patients. Patient Educ Couns. Mar. 2005;56(3):332-9. [pmid: 15721976].
70 Ahern NR. Using the Internet to conduct research. Nurse Res. 2005;13(2):55-70. [pmid: 16416980].
71 Ahlers-Schmidt CR, Golbeck AL, Paschal AM, Zackula R, Taylor NT. Breast cancer counts: numeracy in breast cancer information on the Web. J Cancer Educ. Summer. 2006;21(2):95-8. [pmid: 17020522].
72 Ahmad K, Jafary F, Jehan I, Hatcher J, Khan AQ, Chaturvedi N, et al. Prevalence and predictors of smoking in Pakistan: results of the National Health Survey of Pakistan. Eur J Cardiovasc Prev Rehabil. Jun. 2005;12(3):203-8. [pmid: 15942416].
73 Ahmadian L, Massof R. Does functional vision behave differently in low-vision patients with diabetic retinopathy? A case-matched study. Invest Ophthalmol Vis Sci. Sep. 2008;49(9):4051-7. [pmid: 18552389].
74 Ahmed AM, Yousif E, Abdalla ME. Use of the Internet by Sudanese doctors and medical students. East Mediterr Health J. Jan-Feb. 2008;14(1):134-41. [pmid: 18557461].
75 Ahmed NU, Alam MM, Sultana F, Sayeed SN, Pressman AM, Powers MB. Reaching the unreachable: barriers of the poorest to accessing NGO healthcare services in Bangladesh. J Health Popul Nutr. Dec. 2006;24(4):456-66. [pmid: 17591342].
76 Ahmed S, Nahar S. Contraceptive prevalence among adolescent married women in rural Bangladesh. Mymensingh Med J. Jan. 2008;17(1):42-5. [pmid: 18285730].
77 Akamatsu CT, Mayer C, Farrelly S. An investigation of two-way text messaging use with deaf students at the secondary level. J Deaf Stud Deaf Educ. Winter. 2006;11(1):120-31. [pmid: 16237186].
78 Akeel R. Attitudes of Saudi male patients toward the replacement of teeth. J Prosthet Dent. Dec. 2003;90(6):571-7. [pmid: 14668758].
79 Akhtar M, Jamil K, Ahmed S, Mushtaq S. Brain death and related issues. J Coll Physicians Surg Pak. Jul. 2003;13(7):423-7. [pmid: 12887850].
80 Akoijam BS, Thangjam ND, Singh KT, Devi SR, Devi RK. Birth weight pattern in the only referral teaching hospital in Manipur. Indian J Public Health. Oct-Dec. 2006;50(4):220-4. [pmid: 17444050].
81 al Mannai H, Everatt J. Phonological processing skills as predictors of literacy amongst Arabic speaking Bahraini children. Dyslexia. Nov. 2005;11(4):269-91. [pmid: 16355748].
82 Al Otaiba S, Fuchs D. Who are the young children for whom best practices in reading are ineffective? An experimental and longitudinal study. J Learn Disabil. Sep-Oct. 2006;39(5):414-31. [pmid: 17004674].
83 Alant E, Life H, Harty M. Comparison of the learnability and retention between Blissymbols and CyberGlyphs. Int J Lang Commun Disord. Apr-Jun. 2005;40(2):151-69. [pmid: 16101272].
84 Al-Harazi AH. Obstructed labor. A real problem in Yemeni s rural areas. Saudi Med J. Sep. 2006;27(9):1435-6. [pmid: 16951795].
85 Ali SS, Karim N, Billoo AG, Haider SS. Association of literacy of mothers with malnutrition among children under three years of age in rural area of district Malir, Karachi. J Pak Med Assoc. Dec. 2005;55(12):550-3. [pmid: 16438277].
86 Aliu O, Chung KC. Readability of ASPS and ASAPS educational web sites: an analysis of consumer impact. Plast Reconstr Surg. Apr. 2010;125(4):1271-8. [pmid: 20072085].
87 Allen D. You're never too old for a Wii. Nurs Older People. Oct. 2007;19(8):8.
88 Allen D, Coombes L, Foxcroft DR. Cultural accommodation of the Strengthening Families Programme 10-14: UK Phase I study. Health Educ Res. Aug. 2007;22(4):547-60. [pmid: 17041022].
89 Allen DN, Donohue B, Sutton G, Haderlie M, Lapota H. Application of a standardized assessment methodology within the context of an evidence-based treatment for substance abuse and its associated problems. Behav Modif. Sep. 2009;33(5):618-54. [pmid: 19864319].
90 Allen MP, Jacobs SK, Levy J, Pierce S, Pravikoff DS, Tanner A. Continuing education as a catalyst for inter-professional collaboration. Med Ref Serv Q. Fall. 2005;24(3):93-102. [pmid: 15982958].
91 Allen RH. The role of family planning in poverty reduction. Obstet Gynecol. Nov. 2007;110(5):999-1002. [pmid: 17978110].
92 Allen RS, Phillips LL, Roff LL, Cavanaugh R, Day L. Religiousness/spirituality and mental health among older male inmates. Gerontologist. Oct. 2008;48(5):692-7. [pmid: 18981285].
93 Allhusen V, Belsky J, Booth-LaForce CL, Bradley R, Brownwell CA, Burchinal M, et al. Does class size in first grade relate to children's academic and social performance or observed classroom processes?. Dev Psychol. Sep. 2004;40(5):651-64. [pmid: 15355156].
94 Alloway TP, Archibald L. Working memory and learning in children with developmental coordination disorder and specific language impairment. J Learn Disabil. May-Jun. 2008;41(3):251-62. [pmid: 18434291].
95 Al-Mahroos FT. Child abuse and neglect in the Arab Peninsula. Saudi Med J. Feb. 2007;28(2):241-8. [pmid: 17268704].
96 Al-Maskari F, El-Sadig M. Prevalence of risk factors for diabetic foot complications. BMC Fam Pract. 2007;8:59. [pmid: 17927826].
97 Almeida ND, Loucks EB, Kubzansky L, Pruessner J, Maselko J, Meaney MJ, et al. Quality of parental emotional care and calculated risk for coronary heart disease. Psychosom Med. Feb. 2010;72(2):148-55. [pmid: 20064905].
98 Alnasir FA, Skerman JH. Schoolteachers' knowledge of common health problems in Bahrain. East Mediterr Health J. Jul-Sep. 2004;10(4-5):537-46. [pmid: 16335644].
99 Alonso P, Menchon JM, Segalas C, Jaurrieta N, Jimenez-Murcia S, Cardoner N, et al. Clinical implications of insight assessment in obsessive-compulsive disorder. Compr Psychiatry. May-Jun. 2008;49(3):305-12. [pmid: 18396191].
100 Alper Z, Ergin N, Selimoglu K, Bilgel N. Domestic violence: a study among a group of Turkish women. Eur J Gen Pract. Jun. 2005;11(2):48-54. [pmid: 16392776].
101 Al-Saeedi M, Elzubier AG, Bahnassi AA, Al-Dawood KM. Patterns of belief and use of traditional remedies by diabetic patients in Mecca, Saudi Arabia. East Mediterr Health J. Jan-Mar. 2003;9(1-2):99-107. [pmid: 15562738].
102 Al-Safi SA, Alkofahi AS, El-Eid HS. Public response to chest pain in Jordan. Eur J Cardiovasc Nurs. Jun. 2005;4(2):139-44. [pmid: 15904884].
103 Altemeier LE, Abbott RD, Berninger VW. Executive functions for reading and writing in typical literacy development and dyslexia. J Clin Exp Neuropsychol. Jul. 2008;30(5):588-606. [pmid: 18569253].
104 Alter DA, Iron K, Austin PC, Naylor CD. Influence of education and income on atherogenic risk factor profiles among patients hospitalized with acute myocardial infarction. Can J Cardiol. Oct. 2004;20(12):1219-28. [pmid: 15494774].
105 Alzate MM, Moxley DP, Bohon SA, Nackerud L. The influence of perceived health status on poor women's confidence in leaving welfare: implications for social work. Soc Work Health Care. Jan. 2009;48(1):57-75. [pmid: 19197766].
106 Amalraj S, Starkweather C, Nguyen C, Naeim A. Health literacy, communication, and treatment decision-making in older cancer patients. Oncology (Williston Park). Apr. 15. 2009;23(4):369-75. [pmid: 19476267].
107 Amin Z, Hoon Eng K, Gwee M, Dow Rhoon K, Chay Hoon T. Medical education in Southeast Asia: emerging issues, challenges and opportunities. Med Educ. Aug. 2005;39(8):829-32. [pmid: 16048625].
108 Aminu MB, Ameh EA, Mai A. Computer technology and the surgeon: what the resident needs to know. Niger J Med. Apr-Jun. 2006;15(2):119-23. [pmid: 16805165].
109 Amzel A, Ghosh C. National newspaper coverage of minority health disparities. J Natl Med Assoc. Oct. 2007;99(10):1120-5. [pmid: 17987915].
110 Anand S, Barnighausen T. Human resources and health outcomes: cross-country econometric study. Lancet. 2004 Oct 30-Nov 5. 364(9445):1603-9. [pmid: 15519630].
111 Anand S, Barnighausen T. Health workers and vaccination coverage in developing countries: an econometric analysis. Lancet. Apr. 14. 2007;369(9569):1277-85. [pmid: 17434403].
112 Ancker JS, Kaufman D. Rethinking health numeracy: a multidisciplinary literature review. J Am Med Inform Assoc. Nov-Dec. 2007;14(6):713-21. [pmid: 17712082].
113 Ancker JS, Senathirajah Y, Kukafka R, Starren JB. Design features of graphs in health risk communication: a systematic review. J Am Med Inform Assoc. Nov-Dec. 2006;13(6):608-18. [pmid: 16929039].
114 Anderson AS, Klemm P. The Internet: friend or foe when providing patient education?. Clin J Oncol Nurs. Feb. 2008;12(1):55-63. [pmid: 18258575].
115 Anderson CJ, Krajci KA, Vogel LC. Community integration among adults with spinal cord injuries sustained as children or adolescents. Dev Med Child Neurol. Feb. 2003;45(2):129-34. [pmid: 12578239].
116 Anderson CJ, Vogel LC. Domain-specific satisfaction in adults with pediatric-onset spinal cord injuries. Spinal Cord. Dec. 2003;41(12):684-91. [pmid: 14639448].
117 Anderson DM, Asher LM, Wilson EA. Physician computer skills: a prerequisite to the future in healthcare services. J Ky Med Assoc. Feb. 2007;105(2):67-71. [pmid: 17390734].
118 Anderson JM, Murphy AA, Boyle KB, Yaeger KA, Halamek LP. Simulating extracorporeal membrane oxygenation emergencies to improve human performance. Part II: Assessment of technical and behavioral skills. Simul Healthc. Winter. 2006;1(4):228-32. [pmid: 19088594].
119 Andrade LO, Bareta IC, Gomes CF, Canuto OM. Public health policies as guides for local public policies: the experience of Sobral-Ceara, Brazil. Promot Educ. 2005;. 3. 28-31.
120 Andretta S. Promoting reflective information literacy practice through Facilitating Information Literacy Education (FILE). Health Info Libr J. Jun. 2008;25(2):150-3. [pmid: 18494650].
121 Andrzejewski CS, Reed HE, White MJ. Does where you live influence what you know? Community effects on health knowledge in Ghana. Health Place. Mar. 2009;15(1):228-38. [pmid: 18603464].
122 Angelini A, Bendini C, Neviani F, Neri M. Behavioral and psychological symptoms of dementia (BPSD) in elderly demented subjects: is the long lasting use of atypical antipsychotic drugs useful and safe?. Arch Gerontol Geriatr. 1. 2007;44:35-43. [pmid: 17317431].
123 Angermeyer MC, Holzinger A, Matschinger H. Mental health literacy and attitude towards people with mental illness: a trend analysis based on population surveys in the eastern part of Germany. Eur Psychiatry. May. 2009;24(4):225-32. [pmid: 19361961].
124 Angermeyer MC, Matschinger H. Causal beliefs and attitudes to people with schizophrenia. Trend analysis based on data from two population surveys in Germany. Br J Psychiatry. Apr. 2005;186:331-4. [pmid: 15802691].
125 Angermeyer MC, Matschinger H. The stigma of mental illness in Germany: a trend analysis. Int J Soc Psychiatry. Sep. 2005;51(3):276-84. [pmid: 16252795].
126 Angus J, Evans S, Lapum J, Rukholm E, St Onge R, Nolan R, et al. “Sneaky disease”: the body and health knowledge for people at risk for coronary heart disease in Ontario, Canada. Soc Sci Med. May. 2005;60(9):2117-28. [pmid: 15743659].
127 Ansani NT, Vogt M, Henderson BA, McKaveney TP, Weber RJ, Smith RB, et al. Quality of arthritis information on the Internet. Am J Health Syst Pharm. Jun. 1. 2005;62(11):1184-9. [pmid: 15984050].
128 Anthony D, Lawson G, Crawford D. The theory-practice gap: ECMO research example. Paediatr Nurs. Feb. 2008;20(1):41-5. [pmid: 18335905].
129 Anthony JL, Williams JM, McDonald R, Corbitt-Shindler D, Carlson CD, Francis DJ. Phonological processing and emergent literacy in Spanish-speaking preschool children. Ann Dyslexia. Dec. 2006;56(2):239-70. [pmid: 17849200].
130 Anthony JL, Williams JM, McDonald R, Francis DJ. Phonological processing and emergent literacy in younger and older preschool children. Ann Dyslexia. Dec. 2007;57(2):113-37. [pmid: 18058023].
131 Anton B, Nelson R. Literacy, consumer informatics, and health care outcomes: Interrelations and implications. Stud Health Technol Inform. 2006;122:49-53. [pmid: 17102216].
132 Antony GM, Rao KV. A composite index to explain variations in poverty, health, nutritional status and standard of living: use of multivariate statistical methods. Public Health. Aug. 2007;121(8):578-87. [pmid: 17467017].
133 Apold J, Daniels T, Sonneborn M. Promoting collaboration and transparency in patient safety. Jt Comm J Qual Patient Saf. Dec. 2006;32(12):672-5. [pmid: 17220155].
134 Applegate KE, Crewson PE. Statistical literacy. Radiology. Mar. 2004;230(3):613-4. [pmid: 14990828].
135 Apter AJ, Cheng J, Small D, Bennett IM, Albert C, Fein DG, et al. Asthma numeracy skill and health literacy. J Asthma. Nov. 2006;43(9):705-10. [pmid: 17092853].
136 Apter AJ, Paasche-Orlow MK, Remillard JT, Bennett IM, Ben-Joseph EP, Batista RM, et al. Numeracy and communication with patients: they are counting on us. J Gen Intern Med. Dec. 2008;23(12):2117-24. [pmid: 18830764].
137 Aqeel M, Shafquat A, Salahuddin N. Pacemaker patients' perception of unsafe activities: a survey. BMC Cardiovasc Disord. 2008;8:31. [pmid: 19014563].
138 Aram D, Most T, Mayafit H. Contributions of mother-child storybook telling and joint writing to literacy development in kindergartners with hearing loss. Lang Speech Hear Serv Sch. Jul. 2006;37(3):209-23. [pmid: 16837444].
139 Arango-Lasprilla JC, Rosenthal M, Deluca J, Cifu DX, Hanks R, Komaroff E. Functional outcomes from inpatient rehabilitation after traumatic brain injury: how do Hispanics fare?. Arch Phys Med Rehabil. Jan. 2007;88(1):11-8. [pmid: 17207669].
140 Araujo MB, Mazza CS. Assessment of risk factors of poor metabolic control in type 1 diabetic children assisted in a public hospital in Argentina. Pediatr Diabetes. Oct. 2008;9(5):480-7. [pmid: 18761645].
141 Arffa S. The relationship of intelligence to executive function and non-executive function measures in a sample of average, above average, and gifted youth. Arch Clin Neuropsychol. Nov. 2007;22(8):969-78. [pmid: 17920807].
142 Arhan E, Serdaroglu A, Soysal S, Ozcelik A, Gucuyener K, Demir E. Assessment of mothers' knowledge and perceptions of electroencephalography and determination of the short-term effect of an informational leaflet. Epilepsy Behav. Aug. 2009;15(4):491-5. [pmid: 19616483].
143 Arkkila E, Rasanen P, Roine RP, Vilkman E. Specific language impairment in childhood is associated with impaired mental and social well-being in adulthood. Logoped Phoniatr Vocol. 2008;33(4):179-89. [pmid: 18608878].
144 Arlt S, Lindner R, Rosler A, von Renteln-Kruse W. Adherence to medication in patients with dementia: predictors and strategies for improvement. Drugs Aging. 2008;25(12):1033-47. [pmid: 19021302].
145 Armand F, Lefrancois P, Baron A, Gomez MC, Nuckle S. Improving reading and writing learning in underprivileged pluri-ethnic settings. Br J Educ Psychol. Sep. 2004;74(Pt 3):437-59. [pmid: 15296549].
146 Armistead-Jehle P, Cifu DX, Wetzel R, Carne W, Klanchar LA. Health literacy among patients diagnosed with movement disorders: a pilot study. PM R. Jan. 2010;2(1):43-7. [pmid: 20129512].
147 Armstrong K, Weber B, Ubel PA, Peters N, Holmes J, Schwartz JS. Individualized survival curves improve satisfaction with cancer risk management decisions in women with BRCA1/2 mutations. J Clin Oncol. Dec. 20. 2005;23(36):9319-28. [pmid: 16361631].
148 Armstrong KJ, Weidner TG, Walker SE. Athletic training approved clinical instructors' reports of real-time opportunities for evaluating clinical proficiencies. J Athl Train. Nov-Dec. 2009;44(6):630-8. [pmid: 19911090].
149 Armstrong MB, Nettleton SK. Attention deficit hyperactivity disorder and preschool children. Semin Speech Lang. Aug. 2004;25(3):225-32. [pmid: 15359366].
150 Arnesen K, Enerstvedt RT, Engen EA, Engen T, Hoie G, Vonen AM. The linguistic milieu of Norwegian children with hearing loss. Am Ann Deaf. Spring. 2008;153(1):65-77. [pmid: 18619070].
151 Arogundade FA, Barsoum RS. CKD prevention in Sub-Saharan Africa: a call for governmental, nongovernmental, and community support. Am J Kidney Dis. Mar. 2008;51(3):515-23. [pmid: 18295068].
152 Arora RS, Eden T, Pizer B. The problem of treatment abandonment in children from developing countries with cancer. Pediatr Blood Cancer. Dec. 2007;49(7):941-6. [pmid: 17252565].
153 Arowojolu MO, Dosumu EB, Onyeaso CO, Lawoyin JO. Effects of some risk factors and immunodeficiencies on the periodontium--a review. Afr J Med Med Sci. Sep. 2002;31(3):195-9. [pmid: 12751556].
154 Arozullah AM, Lee SY, Khan T, Kurup S, Ryan J, Bonner M, et al. The roles of low literacy and social support in predicting the preventability of hospital admission. J Gen Intern Med. Feb. 2006;21(2):140-5. [pmid: 16336616].
155 Arozullah AM, Yarnold PR, Bennett CL, Soltysik RC, Wolf MS, Ferreira RM, et al. Development and validation of a short-form, rapid estimate of adult literacy in medicine. Med Care. Nov. 2007;45(11):1026-33. [pmid: 18049342].
156 Arshad F, Thompson B. The Midwifery Interactive Learning Environment (MILE). RCM Midwives. Feb. 2003;6(2):76-8. [pmid: 12630309].
157 Arthur SA, Geiser HR, Arriola KR, Kripalani S. Health literacy and control in the medical encounter: a mixed-methods analysis. J Natl Med Assoc. Jul. 2009;101(7):677-83. [pmid: 19634588].
158 Asekun-Olarinmoye EO, Amusan OA. The impact of health education on attitudes towards female genital mutilation (FGM) in a rural Nigerian community. Eur J Contracept Reprod Health Care. Sep. 2008;13(3):289-97. [pmid: 18609348].
159 Ashtari M, Cottone J, Ardekani BA, Cervellione K, Szeszko PR, Wu J, et al. Disruption of white matter integrity in the inferior longitudinal fasciculus in adolescents with schizophrenia as revealed by fiber tractography. Arch Gen Psychiatry. Nov. 2007;64(11):1270-80. [pmid: 17984396].
160 Atasoylu G, Evci ED, Kaya E, Ergin F, Tikir D, Beser E. The household garbage in the western coast region of Turkey and its relationship with the socio-economic characterstics. J Environ Biol. Apr. 2007;28(2):225-9. [pmid: 17915755].
161 Atchison KA, Black EE, Leathers R, Belin TR, Abrego M, Gironda MW, et al. A qualitative report of patient problems and postoperative instructions. J Oral Maxillofac Surg. Apr. 2005;63(4):449-56. [pmid: 15789315].
162 Atreja A, Mehta NB, Jain AK, Harris C, Ishwaran H, Avital M, et al. Satisfaction with web-based training in an integrated healthcare delivery network: do age, education, computer skills and attitudes matter?. BMC Med Educ. 2008;8:48. [pmid: 18922178].
163 August GJ, Egan EA, Realmuto GM, Hektner JM. Parceling component effects of a multifaceted prevention program for disruptive elementary school children. J Abnorm Child Psychol. Oct. 2003;31(5):515-27. [pmid: 14561059].
164 August GJ, Lee SS, Bloomquist ML, Realmuto GM, Hektner JM. Dissemination of an evidence-based prevention innovation for aggressive children living in culturally diverse, urban neighborhoods: the Early Risers effectiveness study. Prev Sci. Dec. 2003;4(4):271-86. [pmid: 14598999].
165 Aunio P, Hautamaki J, Heiskari P, Van Luit JE. The Early Numeracy Test in Finnish: children's norms. Scand J Psychol. Oct. 2006;47(5):369-78. [pmid: 16987206].
166 Austin EW, Chen YC, Pinkleton BE, Quintero Johnson J. Benefits and costs of Channel One in a middle school setting and the role of media-literacy training. Pediatrics. Mar. 2006;117(3):e423-33. [pmid: 16510621].
167 Austin EW, Pinkleton BE, Hust SJ, Cohen M. Evaluation of an American Legacy Foundation/Washington State Department Of Health Media Literacy Pilot Study. Health Commun. 2005;18(1):75-95. [pmid: 15918791].
168 Austin JW, Evans EL, Hoerr HR Jr. Distributed perfusion educational model: a shift in perfusion economic realities. J Extra Corpor Technol. Dec. 2005;37(4):360-3. [pmid: 16524152].
169 Auyeung TW, Kwok T, Lee J, Leung PC, Leung J, Woo J. Functional decline in cognitive impairmeñtthe relationship between physical and cognitive function. Neuroepidemiology. 2008;31(3):167-73. [pmid: 18784415].
170 Avery AJ, Savelyich BS, Teasdale S. Improving the safety features of general practice computer systems. Inform Prim Care. 2003;11(4):203-6. [pmid: 14980059].
171 Aydog E, Bal A, Aydog ST, Cakci A. Evaluation of dynamic postural balance using the Biodex Stability System in rheumatoid arthritis patients. Clin Rheumatol. Jul. 2006;25(4):462-7. [pmid: 16247584].
172 Aziz NA, Norzila MZ, Hamid MZ, Noorlaili MT. Skills amongst parents of children with asthma: a pilot interventional study in primary care setting. Med J Malaysia. Dec. 2006;61(5):534-9. [pmid: 17623952].
173 Aziz Z, Sana S, Akram M, Saeed A. Socioeconomic status and breast cancer survival in Pakistani women. J Pak Med Assoc. Sep. 2004;54(9):448-53. [pmid: 15518365].
174 Babar TF, Khan MT, Marwat MZ, Shah SA, Murad Y, Khan MD. Patterns of ocular trauma. J Coll Physicians Surg Pak. Mar. 2007;17(3):148-53. [pmid: 17374300].
175 Bade E, Evertsen J, Smiley S, Banerjee I. Navigating the health care system: a view from the urban medically underserved. Wis Med J. Dec. 2008;107(8):374-9.
176 Baerlocher MO. Adult literacy rates in African and Eastern Mediterranean countries. Can Med Assoc J. Nov. 20. 2007;177(11):1347. [pmid: 18025423].
177 Bahadur A, Mittal S, Sharma JB, Sehgal R. Socio-demographic profile of women undergoing abortion in a tertiary centre. Arch Gynecol Obstet. Oct. 2008;278(4):329-32. [pmid: 18274767].
178 Baig SM, Azhar A, Hassan H, Baig JM, Aslam M, Ud Din MA, et al. Prenatal diagnosis of beta-thalassemia in Southern Punjab, Pakistan. Prenat Diagn. Oct. 2006;26(10):903-5. [pmid: 16821247].
179 Bailey P, Derbyshire J, Harding A, Middleton A, Rayson K, Syson L. Assessing the impact of a study skills programme on the academic development of nursing diploma students at Northumbria University, UK. Health Info Libr J. Dec. 1. 2007;24:77-85. [pmid: 18005297].
180 Bailey R, Rhee KB. Reach Out and Read: promoting pediatric literacy guidance through a transdisciplinary team. J Health Care Poor Underserved. May. 2005;16(2):225-30. [pmid: 15937385].
181 Bailey SC, Pandit AU, Curtis L, Wolf MS. Availability of Spanish prescription labels: a multi-state pharmacy survey. Med Care. Jun. 2009;47(6):707-10. [pmid: 19433992].
182 Bailey SC, Pandit AU, Yin S, Federman A, Davis TC, Parker RM, et al. Predictors of misunderstanding pediatric liquid medication instructions. Fam Med. Nov-Dec. 2009;41(10):715-21. [pmid: 19882395].
183 Baird AD, Ford M, Podell K. Ethnic differences in functional and neuropsychological test performance in older adults. Arch Clin Neuropsychol. Mar. 2007;22(3):309-18. [pmid: 17317093].
184 Baiyewu O, Unverzagt FW, Lane KA, Gureje O, Ogunniyi A, Musick B, et al. The Stick Design test: a new measure of visuoconstructional ability. J Int Neuropsychol Soc. Sep. 2005;11(5):598-605. [pmid: 16212687].
185 Baker DW. The meaning and the measure of health literacy. J Gen Intern Med. Aug. 2006;21(8):878-83. [pmid: 16881951].
186 Baker DW, Gazmararian JA, Williams MV, Scott T, Parker RM, Green D, et al. Health literacy and use of outpatient physician services by Medicare managed care enrollees. J Gen Intern Med. Mar. 2004;19(3):215-20. [pmid: 15009775].
187 Baker DW, Williams MV, Parker RM, Gazmararian JA, Nurss J. Development of a brief test to measure functional health literacy. Patient Educ Couns. Sep. 1999;38(1):33-42. [pmid: 14528569].
188 Baker DW, Wolf MS, Feinglass J, Thompson JA. Health literacy, cognitive abilities, and mortality among elderly persons. J Gen Intern Med. Jun. 2008;23(6):723-6. [pmid: 18330654].
189 Baker DW, Wolf MS, Feinglass J, Thompson JA, Gazmararian JA, Huang J. Health literacy and mortality among elderly persons. Arch Intern Med. Jul. 23. 2007;167(14):1503-9. [pmid: 17646604].
190 Baker GA, Hargis E, Hsih MM, Mounfield H, Arzimanoglou A, Glauser T, et al. Perceived impact of epilepsy in teenagers and young adults: an international survey. Epilepsy Behav. Apr. 2008;12(3):395-401. [pmid: 18164251].
191 Baker LM, Wilson FL, Nordstrom CK, Legwand C. Mothers' knowledge and information needs relating to childhood immunizations. Issues Compr Pediatr Nurs. Jan-Jun. 2007;30(1-2):39-53. [pmid: 17613141].
192 Baker LM, Wilson FL, Winebarger A. An exploratory study of the health problems, stigmatization, life satisfaction, and literacy skills of urban, street-level sex workers. Women Health. 2004;39(2):83-96. [pmid: 15130863].
193 Baker-Henningham H, Meeks-Gardner J, Chang S, Walker S. Experiences of violence and deficits in academic achievement among urban primary school children in Jamaica. Child Abuse Negl. May. 2009;33(5):296-306. [pmid: 19481803].
194 Bakhshandeh S, Murtomaa H, Mofid R, Vehkalahti MM, Suomalainen K. Periodontal treatment needs of diabetic adults. J Clin Periodontol. Jan. 2007;34(1):53-7. [pmid: 17243996].
195 Bakken S. Informatics for patient safety: a nursing research perspective. Annu Rev Nurs Res. 2006;24:219-54. [pmid: 17078416].
196 Bakken S, Grullon-Figueroa L, Izquierdo R, Lee NJ, Morin P, Palmas W, et al. Development, validation, and use of English and Spanish versions of the telemedicine satisfaction and usefulness questionnaire. J Am Med Inform Assoc. Nov-Dec. 2006;13(6):660-7. [pmid: 16929036].
197 Bakken S, Sheets Cook S, Curtis L, Soupios M, Curran C. Informatics competencies pre-and post-implementation of a Palm-based student clinical log and informatics for evidence-based practice curriculum. AMIA Annu Symp Proc. 2003:41-5.
198 Baldwin CD, Niebuhr VN, Sullivan B. Meeting the computer technology needs of community faculty: building new models for faculty development. Ambul Pediatr. Jan-Feb. 2004;4(1 Suppl):113-6. [pmid: 14731082].
199 Balen RM, Jewesson PJ. Pharmacist computer skills and needs assessment survey. J Med Internet Res. Mar. 29. 2004;6(1):e11. [pmid: 15111277].
200 Balevre P. Professional nursing burnout and irrational thinking. J Nurses Staff Dev. Sep-Oct. 2001;17(5):264-71. [pmid: 12759997].
201 Balka E, Reidl C, Wagner I. Using fieldwork in analyzing ethical issues related to IT in health care. Stud Health Technol Inform. 2007;129(Pt 1):237-41. [pmid: 17911714].
202 Ball JD, Hart RP, Stutts ML, Turf E, Barth JT. Comparative utility of Barona Formulae, Wtar demographic algorithms, and WRAT-3 reading for estimating premorbid ability in a diverse research sample. Clin Neuropsychol. May. 2007;21(3):422-33. [pmid: 17455028].
203 Ball MJ. Nursing informatics of tomorrow. One of nurses' new roles will be agents of change in the healthcare revolution. Healthc Inform. Feb. 2005;22(2):74. 6. 8. [pmid: 15759776].
204 Ballantine L. Computer-assisted learning. Cannt J. Jan-Mar. 2004;14(1):51-2. [pmid: 15544174].
205 Ballard EC. Exploration of nurses' information environment. Nurse Res. 2006;13(4):50-65. [pmid: 16897940].
206 Ballard EC. Improving information management in ward nurses' practice. Nurs Stand. Aug. 23-29. 2006;20(50):43-8. [pmid: 16964775].
207 Balter M, Ernst P, Watson W, Kim H, Cicutto L, Beauchesne MF, et al. Asthma worsenings: approaches to prevention and management from the Asthma Worsenings Working Group. Can Respir J. Nov-Dec. B. 2008;15:1B-19B.
208 Banai K, Abrams D, Kraus N. Sensory-based learning disability: Insights from brainstem processing of speech sounds. Int J Audiol. Sep. 2007;46(9):524-32. [pmid: 17828668].
209 Banai K, Nicol T, Zecker SG, Kraus N. Brainstem timing: implications for cortical processing and literacy. J Neurosci. Oct. 26. 2005;25(43):9850-7. [pmid: 16251432].
210 Banerjee D, Perry M, Tran D, Arafat R. Self-reported health, functional status and chronic disease in community dwelling older adults: untangling the role of demographics. J Community Health. Apr. 2010;35(2):135-41. [pmid: 20033835].
211 Banerjee SC, Greene K. Antismoking initiatives: effects of analysis versus production media literacy interventions on smoking-related attitude, norm, and behavioral intention. Health Commun. 2007;22(1):37-48. [pmid: 17617012].
212 Bankson HL. Health literacy: an exploratory bibliometric analysis, 1997-2007. J Med Libr Assoc. Apr. 2009;97(2):148-50. [pmid: 19404510].
213 Bara AC, van den Heuvel WJ, Maarse JA, van Dijk J, de Witte LP. Opinions on changes in the Romanian health care system from people's point of view: a descriptive study. Health Policy. Nov. 2003;66(2):123-34. [pmid: 14585512].
214 Barakzai MD, Fraser D. The effect of demographic variables on achievement in and satisfaction with online coursework. J Nurs Educ. Aug. 2005;44(8):373-80. [pmid: 16130344].
215 Baral N, Paudel BH, Das BK, Aryal M, Das BP, Jha N, et al. An evaluation of training of teachers in medical education in four medical schools of Nepal. Nepal Med Coll J. Sep. 2007;9(3):157-61. [pmid: 18092430].
216 Barbarin O, Bryant D, McCandies T, Burchinal M, Early D, Clifford R, et al. Children enrolled in public pre-K: the relation of family life, neighborhood quality, and socioeconomic resources to early competence. Am J Orthopsychiatry. Apr. 2006;76(2):265-76. [pmid: 16719646].
217 Bardia A, Loprinzi C, Grothey A, Nelson G, Alberts S, Menon S, et al. Adjuvant chemotherapy for resected stage II and III colon cancer: comparison of two widely used prognostic calculators. Semin Oncol. Feb. 2010;37(1):39-46. [pmid: 20172363].
218 Barkataki P, Kumar S, Rao PS. Knowledge of and attitudes to leprosy among patients and community members: a comparative study in Uttar Pradesh, India. Lepr Rev. Mar. 2006;77(1):62-8. [pmid: 16715691].
219 Barkin SL, Finch SA, Ip EH, Scheindlin B, Craig JA, Steffes J, et al. Is office-based counseling about media use, timeouts, and firearm storage effective? Results from a cluster-randomized, controlled trial. Pediatrics. Jul. 2008;122(1):e15-25. [pmid: 18595960].
220 Barnard A, Nash R, O'Brien M. Information literacy: developing lifelong skills through nursing education. J Nurs Educ. Nov. 2005;44(11):505-10. [pmid: 16342632].
221 Barnes DE, Tager IB, Satariano WA, Yaffe K. The relationship between literacy and cognition in well-educated elders. J Gerontol A Biol Sci Med Sci. Apr. 2004;59(4):390-5. [pmid: 15071084].
222 Barnes J. Implementing a perinatal clinical information system: a work in progress. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2006;35(1):134-40.
223 Barnhart KT. The challenge and enjoyment of the interpretation of epidemiologic data. Fertil Steril. Sep. 2006;86(3):527-8. discussion 34. [pmid: 16952502].
224 Barnholtz-Sloan J, Patel N, Rollison D, Kortepeter K, MacKinnon J, Giuliano A. Incidence trends of invasive cervical cancer in the United States by combined race and ethnicity. Cancer Causes Control. Sep. 2009;20(7):1129-38. [pmid: 19253025].
225 Barnoy S, Volfin-Pruss D, Ehrenfeld M, Kushnir T. Factors affecting nurses' attitudes in Israel toward patients who present them with Internet medical information. Nurs Outlook. Nov-Dec. 2008;56(6):314-21. [pmid: 19041453].
226 Baron-Epel O, Balin L, Daniely Z, Eidelman S. Validation of a Hebrew health literacy test. Patient Educ Couns. Jul. 2007;67(1-2):235-9. [pmid: 17386994].
227 Barragan M, Hicks G, Williams MV, Franco-Paredes C, Duffus W, del Rio C. Low health literacy is associated with HIV test acceptance. J Gen Intern Med. May. 2005;20(5):422-5. [pmid: 15963165].
228 Barrett SE, Puryear JS. Health literacy: improving quality of care in primary care settings. J Health Care Poor Underserved. Nov. 2006;17(4):690-7. [pmid: 17242524].
229 Barry JG, Yasin I, Bishop DV. Heritable risk factors associated with language impairments. Genes Brain Behav. Feb. 2007;6(1):66-76. [pmid: 17233642].
230 Bartlett H, Travers C, Cartwright C, Smith N. Mental health literacy in rural Queensland: results of a community survey. Aust N Z J Psychiatry. Sep. 2006;40(9):783-9. [pmid: 16911754].
231 Barton AJ. Cultivating informatics competencies in a community of practice. Nurs Adm Q. Oct-Dec. 2005;29(4):323-8. [pmid: 16260996].
232 Bass L. Health literacy: implications for teaching the adult patient. J Infus Nurs. Jan-Feb. 2005;28(1):15-22. [pmid: 15684900].
233 Bass PF 3rd, Wilson JF, Griffith CH. A shortened instrument for literacy screening. J Gen Intern Med. Dec. 2003;18(12):1036-8. [pmid: 14687263].
234 Bastian H. Health literacy and patient information: developing the methodology for a national evidence-based health website. Patient Educ Couns. Dec. 2008;73(3):551-6. [pmid: 18963722].
235 Basu P, Sarkar S, Mukherjee S, Ghoshal M, Mittal S, Biswas S, et al. Women's perceptions and social barriers determine compliance to cervical screening: results from a population based study in India. Cancer Detect Prev. 2006;30(4):369-74. [pmid: 16963194].
236 Basu S, Paul DK, Ganguly S, Chandra PK. Risk factors for mortality from neonatal tetanus: 7 years experience in North Bengal, India. Ann Trop Paediatr. Sep. 2006;26(3):233-9. [pmid: 16925961].
237 Bateson K, Delaney J, Pybus R. Meeting expectations: the pilot evaluation of the Solihull Approach Parenting Group. Community Pract. May. 2008;81(5):28-31. [pmid: 18549120].
238 Battaglioli-DeNero AM. Strategies for improving patient adherence to therapy and long-term patient outcomes. J Assoc Nurses AIDS Care. Jan-Feb. 2007;18(1 Suppl):S17-22. [pmid: 17275718].
239 Battistoni A, Pignatti M, Giovannini M. A Web site service for plastic surgeons: new ideas for patients' records. Plast Reconstr Surg. Sep. 15. 2004;114(4):947-9. [pmid: 15468403].
240 Batty GD, Der G, Deary IJ. Effect of maternal smoking during pregnancy on offspring's cognitive ability: empirical evidence for complete confounding in the US national longitudinal survey of youth. Pediatrics. Sep. 2006;118(3):943-50. [pmid: 16950984].
241 Bauldoff GS, Kirkpatrick B, Sheets DJ, Mays B, Curran CR. Implementation of handheld devices. Nurse Educ. Nov-Dec. 2008;33(6):244-8. [pmid: 18981902].
242 Bawdekar M, Ladusingh L. Contextual correlates of child malnutrition in rural Maharashtra. J Biosoc Sci. Sep. 2008;40(5):771-86. [pmid: 18241523].
243 Baykal U, Sokmen S, Korkmaz S, Akgun E. Determining student satisfaction in a nursing college. Nurse Educ Today. May. 2005;25(4):255-62. [pmid: 15885856].
244 Bazata DD, Robinson JG, Fox KM, Grandy S. Affecting behavior change in individuals with diabetes: findings from the Study to Help Improve Early Evaluation and Management of Risk Factors Leading to Diabetes (SHIELD). Diabetes Educ. Nov-Dec. 2008;34(6):1025-36. [pmid: 19075084].
245 Beech JR, Beauvois MW. Early experience of sex hormones as a predictor of reading, phonology, and auditory perception. Brain Lang. Jan. 2006;96(1):49-58. [pmid: 16203032].
246 Begoray DL, Wharf-Higgins J, Macdonald M. High school health curriculum and health literacy: Canadian student voices. Glob Health Promot. Dec. 2009;16(4):35-42. [pmid: 20028667].
247 Begum S, Haque MM, Nasreen SA. Contraceptive prevalence: experience from rural areas of Mymensingh. Mymensingh Med J. Jul. 2006;15(2):124-7. [pmid: 16878089].
248 Beitler JJ, Chen AY, Jacobson K, Owens A, Edwards M, Johnstone PA. Health literacy and health care in an inner-city, total laryngectomy population. Am J Otolaryngol. Jan-Feb. 2010;31(1):29-31. [pmid: 19944896].
249 Bell JA, Patel B, Malasanos T. Knowledge improvement with web-based diabetes education program: brainfood. Diabetes Technol Ther. Aug. 2006;8(4):444-8. [pmid: 16939369].
250 Bell ML, Kelley-Baker T, Rider R, Ringwalt C. Protecting you/protecting me: effects of an alcohol prevention and vehicle safety program on elementary students. J Sch Health. May. 2005;75(5):171-7. [pmid: 15989086].
251 Bello IS, Arogundade FA, Sanusi AA, Ezeoma IT, Abioye-Kuteyi EA, Akinsola A. Knowledge and utilization of Information Technology among health care professionals and students in Ile-Ife, Nigeria: a case study of a university teaching hospital. J Med Internet Res. Dec. 17. 2004;6(4):e45. [pmid: 15631969].
252 Beloosesky Y, Weiss A, Grinblat J, Brill S, Hershkovitz A. Can functional status, after rehabilitation, independently predict long-term mortality of hip-fractured elderly patients?. Aging Clin Exp Res. Feb. 2004;16(1):44-8. [pmid: 15132291].
253 Bendycki NA. Health literacy. Mark Health Serv. Fall. 2008;28(3):32-7. [pmid: 19062445].
254 Benedict RE. Disparities in use of and unmet need for therapeutic and supportive services among school-age children with functional limitations: a comparison across settings. Health Serv Res. Feb. 2006;41(1):103-24. [pmid: 16430603].
255 Bennett I, Switzer J, Aguirre A, Evans K, Barg F. ‘Breaking it down’: patient-clinician communication and prenatal care among African American women of low and higher literacy. Ann Fam Med. Jul-Aug. 2006;4(4):334-40. [pmid: 16868237].
256 Bennett IM, Culhane JF, McCollum KF, Mathew L, Elo IT. Literacy and depressive symptomatology among pregnant Latinas with limited English proficiency. Am J Orthopsychiatry. Apr. 2007;77(2):243-8. [pmid: 17535122].
257 Bennett IM, Kripalani S, Weiss BD, Coyne CA. Combining cancer control information with adult literacy education: opportunities to reach adults with limited literacy skills. Cancer Control. Sep-Oct. 2003;10(5 Suppl):81-3. [pmid: 14581908].
258 Bennett IM, Robbins S, Al-Shamali N, Haecker T. Screening for low literacy among adult caregivers of pediatric patients. Fam Med. Sep. 2003;35(8):585-90. [pmid: 12947522].
259 Bennett JH, Bennett ER, Lowry J, Derry J. Defining the educational needs of recent dental graduates preparing for the membership of the faculty of dental surgery examination. Br Dent J. Sep. 2005;(Suppl):21-5. [pmid: 16192933].
260 Bennett Johnson S, Baughcum AE, Carmichael SK, She JX, Schatz DA. Maternal anxiety associated with newborn genetic screening for type 1 diabetes. Diabetes Care. Feb. 2004;27(2):392-7. [pmid: 14747219].
261 Bennett NL, Casebeer LL, Zheng S, Kristofco R. Information-seeking behaviors and reflective practice. J Contin Educ Health Prof. Spring. 2006;26(2):120-7. [pmid: 16802313].
262 Benotsch EG, Kalichman S, Weinhardt LS. HIV-AIDS patients' evaluation of health information on the internet: the digital divide and vulnerability to fraudulent claims. J Consult Clin Psychol. Dec. 2004;72(6):1004-11. [pmid: 15612847].
263 Ben-Shlomo Y, Fallon U, Sterne J, Brookes S. Do medical students with A-level mathematics have a better understanding of the principles behind evidence-based medicine?. Med Teach. Dec. 2004;26(8):731-3. [pmid: 15763879].
264 Benson J. Concordance--An alternative term to ‘compliance’ in the Aboriginal population. Aust Fam Physician. Oct. 2005;34(10):831-5. [pmid: 16217567].
265 Beranova E, Sykes C. A systematic review of computer-based softwares for educating patients with coronary heart disease. Patient Educ Couns. Apr. 2007;66(1):21-8. [pmid: 17084058].
266 Bergsma LJ, Carney ME. Effectiveness of health-promoting media literacy education: a systematic review. Health Educ Res. Jun. 2008;23(3):522-42. [pmid: 18203680].
267 Berhane Y, Wall S, Fantahun M, Emmelin A, Mekonnen W, Hogberg U, et al. A rural Ethiopian population undergoing epidemiological transition over a generation: Butajira from 1987 to 2004. Scand J Public Health. Jun. 2008;36(4):436-41. [pmid: 18539699].
268 Berkman ND, Dewalt DA, Pignone MP, Sheridan SL, Lohr KN, Lux L, et al. Literacy and health outcomes. Evid Rep Technol Assess (Summ). Jan. 2004;(87):1-8. [pmid: 15819598].
269 Berkule SB, Dreyer BP, Klass PE, Huberman HS, Yin HS, Mendelsohn AL. Mothers' expectations for shared reading after delivery: implications for reading activities at 6 months. Ambul Pediatr. May-Jun. 2008;8(3):169-74. [pmid: 18501863].
270 Berle JO, Mykletun A, Daltveit AK, Rasmussen S, Dahl AA. Outcomes in adulthood for children with foetal growth retardation. A linkage study from the Nord-Trondelag Health Study (HUNT) and the Medical Birth Registry of Norway. Acta Psychiatr Scand. Jun. 2006;113(6):501-9. [pmid: 16677227].
271 Berman RA, Nir-Sagiv B. Linguistic indicators of inter-genre differentiation in later language development. J Child Lang. May. 2004;31(2):339-80. [pmid: 15495844].
272 Bermejo MJ, Perez IR. Physicians and the prescription of hormone replacement therapy in Spain. Health Policy. Jul. 2005;73(1):58-65. [pmid: 15911057].
273 Bernhardt B, Major E. Speech, language and literacy skills 3 years later: a follow-up study of early phonological and metaphonological intervention. Int J Lang Commun Disord. Jan-Mar. 2005;40(1):1-27. [pmid: 15832523].
274 Berninger VW, Dunn A, Lin SJ, Shimada S. School evolution: scientist-practitioner educators creating optimal learning environments for all students. J Learn Disabil. Nov-Dec. 2004;37(6):500-8. [pmid: 15586468].
275 Berry DL, Trigg LJ, Lober WB, Karras BT, Galligan ML, Austin-Seymour M, et al. Computerized symptom and quality-of-life assessment for patients with cancer part I: development and pilot testing. Oncol Nurs Forum. Sep. 2004;31(5):E75-83. [pmid: 15378104].
276 Berteau-Pavy F, Park B, Raber J. Effects of sex and APOE epsilon4 on object recognition and spatial navigation in the elderly. Neuroscience. Jun. 15. 2007;147(1):6-17. [pmid: 17509769].
277 Bertollo DN, Alexander MJ, Shinn M, Aybar JB. Innovations: clinical computing: an audio computer-assisted self-interviewing system for research and screening in public mental health settings. Psychiatr Serv. Jun. 2007;58(6):743-5. [pmid: 17535933].
278 Besdine R, Boult C, Brangman S, Coleman EA, Fried LP, Gerety M, et al. Caring for older Americans: the future of geriatric medicine. J Am Geriatr Soc. Jun. 2005;53(6 Suppl):S245-56. [pmid: 15963180].
279 Betz CL, Ruccione K, Meeske K, Smith K, Chang N. Health literacy: a pediatric nursing concern. Pediatr Nurs. May-Jun. 2008;34(3):231-9. [pmid: 18649813].
280 Bevan JL, Pecchioni LL. Understanding the impact of family caregiver cancer literacy on patient health outcomes. Patient Educ Couns. Jun. 2008;71(3):356-64. [pmid: 18372142].
281 Bharati S, Pal M, Bharati P. Obstetric care practice in Birbhum District, West Bengal, India. Int J Qual Health Care. Aug. 2007;19(4):244-9. [pmid: 17569683].
282 Bharati S, Pal M, Bharati P. Determinants of nutritional status of pre-school children in India. J Biosoc Sci. Nov. 2008;40(6):801-14. [pmid: 18442431].
283 Bhurgri Y. Cancer of the oral cavity - trends in Karachi South (1995-2002). Asian Pac J Cancer Prev. Jan-Mar. 2005;6(1):22-6. [pmid: 15780026].
284 Bierman AS, Lawrence WF, Haffer SC, Clancy CM. Functional health outcomes as a measure of health care quality for Medicare beneficiaries. Health Serv Res. Dec. 2001;36(6 Pt 2):90-109. [pmid: 16148963].
285 Bierman KL, Domitrovich CE, Nix RL, Gest SD, Welsh JA, Greenberg MT, et al. Promoting academic and social-emotional school readiness: the head start REDI program. Child Dev. Nov-Dec. 2008;79(6):1802-17. [pmid: 19037951].
286 Bigler RS, Liben LS. A developmental intergroup theory of social stereotypes and prejudice. Adv Child Dev Behav. 2006;34:39-89. [pmid: 17120802].
287 Birru M, Steinman RA. Online health information and low-literacy African Americans. J Med Internet Res. Sep. 3. 2004;6(3):e26. [pmid: 15471752].
288 Birru MS, Monaco VM, Charles L, Drew H, Njie V, Bierria T, et al. Internet usage by low-literacy adults seeking health information: an observational analysis. J Med Internet Res. Sep. 3. 2004;6(3):e25. [pmid: 15471751].
289 Birtwistle GE, Brodie DA. Children's attitudes towards activity and perceptions of physical education. Health Educ Res. Dec. 1991;6(4):465-78. [pmid: 10148703].
290 Bishop DV. Curing dyslexia and attention-deficit hyperactivity disorder by training motor co-ordination: miracle or myth?. J Paediatr Child Health. Oct. 2007;43(10):653-5. [pmid: 17854448].
291 Bishop DV. Using mismatch negativity to study central auditory processing in developmental language and literacy impairments: where are we, and where should we be going?. Psychol Bull. Jul. 2007;133(4):651-72. [pmid: 17592960].
292 Bishop DV, Adams CV, Norbury CF. Using nonword repetition to distinguish genetic and environmental influences on early literacy development: a study of 6-year-old twins. Am J Med Genet B Neuropsychiatr Genet. Aug. 15. 2004;129B(1):94-6. [pmid: 15274048].
293 Bishop DV, Maybery M, Wong D, Maley A, Hill W, Hallmayer J. Are phonological processing deficits part of the broad autism phenotype?. Am J Med Genet B Neuropsychiatr Genet. Jul. 1. 2004;128B(1):54-60. [pmid: 15211632].
294 Bishop DV, Watt H, Papadatou-Pastou M. An efficient and reliable method for measuring cerebral lateralization during speech with functional transcranial Doppler ultrasound. Neuropsychologia. Jan. 2009;47(2):587-90. [pmid: 18929586].
295 Bissonnette J, Logan J, Davies B, Graham ID. Methodological issues encountered in a study of hospitalized COPD patients. Clin Nurs Res. Feb. 2005;14(1):81-97. [pmid: 15604229].
296 Bizzozero I, Ferrari F, Pozzoli S, Saetti MC, Spinnler H. Who is who: Italian norms for visual recognition and identification of celebrities. Neurol Sci. Jun. 2005;26(2):95-107. [pmid: 15995826].
297 Bjelland I, Krokstad S, Mykletun A, Dahl AA, Tell GS, Tambs K. Does a higher educational level protect against anxiety and depression? The HUNT study. Soc Sci Med. Mar. 2008;66(6):1334-45. [pmid: 18234406].
298 Bjerkeset O, Dahl AA, Stordal E, Dahl NH, Kruger MB, Linaker O. Feasibility of mental health screening and intervention in the HUNT population study. Soc Psychiatry Psychiatr Epidemiol. Mar. 2006;41(3):191-8. [pmid: 16424970].
299 Bjerkeset O, Nordahl HM, Larsson S, Dahl AA, Linaker O. A 4-year follow-up study of syndromal and sub-syndromal anxiety and depression symptoms in the general population: the HUNT study. Soc Psychiatry Psychiatr Epidemiol. Mar. 2008;43(3):192-9. [pmid: 18064394].
300 Bjerkeset O, Nordahl HM, Mykletun A, Holmen J, Dahl AA. Anxiety and depression following myocardial infarction: gender differences in a 5-year prospective study. J Psychosom Res. Feb. 2005;58(2):153-61. [pmid: 15820843].
301 Black CD, Watties-Daniels AD. Cutting edge technology to enhance nursing classroom instruction at Coppin State University. ABNF J. Summer. 2006;17(3):103-6. [pmid: 16948362].
302 Black MM, Dubowitz H, Krishnakumar A, Starr RH Jr. Early intervention and recovery among children with failure to thrive: follow-up at age 8. Pediatrics. Jul. 2007;120(1):59-69. [pmid: 17606562].
303 Blair C, Razza RP. Relating effortful control, executive function, and false belief understanding to emerging math and literacy ability in kindergarten. Child Dev. Mar-Apr. 2007;78(2):647-63. [pmid: 17381795].
304 Blair J. Assessing the value of the internet in health improvement. Nurs Times. Aug. 31. Sep. 6. 2004;100(35):28-30. [pmid: 15471268].
305 Blanch DC, Rudd RE, Wright E, Gall V, Katz JN. Predictors of refusal during a multi-step recruitment process for a randomized controlled trial of arthritis education. Patient Educ Couns. Nov. 2008;73(2):280-5. [pmid: 18715740].
306 Blanson Henkemans OA, Rogers WA, Fisk AD, Neerincx MA, Lindenberg J, van der Mast CA. Usability of an adaptive computer assistant that improves self-care and health literacy of older adults. Methods Inf Med. 2008;47(1):82-8. [pmid: 18213433].
307 Blazer DG, Fillenbaum GG, Gold DT, Burchett BM, Hays JC. APOE epsilon4 as a predictor of subjective quality of life in a biracial older person community sample. J Aging Health. Nov. 2003;15(4):645-60. [pmid: 14594022].
308 Bleakley A, Merzel CR, VanDevanter NL, Messeri P. Computer access and Internet use among urban youths. Am J Public Health. May. 2004;94(5):744-6. [pmid: 15117693].
309 Bleecker ML, Ford DP, Celio MA, Vaughan CG, Lindgren KN. Impact of cognitive reserve on the relationship of lead exposure and neurobehavioral performance. Neurology. Jul. 31. 2007;69(5):470-6. [pmid: 17664406].
310 Blignault I, Ponzio V, Rong Y, Eisenbruch M. A qualitative study of barriers to mental health services utilisation among migrants from mainland China in south-east Sydney. Int J Soc Psychiatry. Mar. 2008;54(2):180-90. [pmid: 18488410].
311 Blignault I, Woodland L, Ponzio V, Ristevski D, Kirov S. Using a multifaceted community intervention to reduce stigma about mental illness in an Australian Macedonian community. Health Promot J Austr. Dec. 2009;20(3):227-33. [pmid: 19951244].
312 Blitstein JL, Evans WD. Use of nutrition facts panels among adults who make household food purchasing decisions. J Nutr Educ Behav. Nov-Dec. 2006;38(6):360-4. [pmid: 17142192].
313 Blood GW, Ridenour VJ, Qualls CD, Hammer CS. Co-occurring disorders in children who stutter. J Commun Disord. Nov-Dec. 2003;36(6):427-48. [pmid: 12967738].
314 Bloom KC, Hough MC. Student satisfaction with technology-enhanced learning. Comput Inform Nurs. Sep-Oct. 2003;21(5):241-6. quiz 7-8. [pmid: 14504600].
315 Boateng J, Flanagan C. Women's access to health care in Ghana: effects of education, residence, lineage and self-determination. Biodemography Soc Biol. Spring. 2008;54(1):56-73. [pmid: 19350761].
316 Bochner JH, Walter GG. Evaluating deaf students' readiness to meet the English language and literacy demands of postsecondary educational programs. J Deaf Stud Deaf Educ. Summer. 2005;10(3):232-43. [pmid: 15843509].
317 Bodie GD, Dutta MJ. Understanding health literacy for strategic health marketing: eHealth literacy, health disparities, and the digital divide. Health Mark Q. 2008;25(1-2):175-203. [pmid: 18935884].
318 Bodstein R. The complexity of the discussion on effectiveness and evidence in health promotion practices. Promot Educ. 1. 2007:16-20.
319 Boehl T. Linguistic issues and literacy barriers in nutrition. J Am Diet Assoc. Mar. 2007;107(3):380-3. [pmid: 17415943].
320 Boets B, Wouters J, van Wieringen A, De Smedt B, Ghesquiere P. Modelling relations between sensory processing, speech perception, orthographic and phonological ability, and literacy achievement. Brain Lang. Jul. 2008;106(1):29-40. [pmid: 18207564].
321 Boets B, Wouters J, van Wieringen A, Ghesquiere P. Auditory temporal information processing in preschool children at family risk for dyslexia: relations with phonological abilities and developing literacy skills. Brain Lang. Apr. 2006;97(1):64-79. [pmid: 16112723].
322 Boets B, Wouters J, van Wieringen A, Ghesquiere P. Auditory processing, speech perception and phonological ability in preschool children at high-risk for dyslexia: a longitudinal study of the auditory temporal processing theory. Neuropsychologia. Apr. 9. 2007;45(8):1608-20. [pmid: 17303197].
323 Boiko P, Katon W, Guerra JC, Mazzoni S. An audiotaped mental health evaluation tool for Hispanic immigrants with a range of literacy levels. J Immigr Health. Jan. 2005;7(1):33-6. [pmid: 15744475].
324 Boissy P, Briere S, Tousignant M, Rousseau E. The eSMAF: a software for the assessment and follow-up of functional autonomy in geriatrics. BMC Geriatr. 2007;7:2. [pmid: 17298673].
325 Bond CS, Fevyer D, Pitt C. Learning to use the Internet as a study tool: a review of available resources and exploration of students' priorities. Health Info Libr J. Sep. 2006;23(3):189-96. [pmid: 16911125].
326 Bond GE. Lessons learned from the implementation of a Web-based nursing intervention. Comput Inform Nurs. Mar-Apr. 2006;24(2):66-74. [pmid: 16554689].
327 Bond L, Giddens A, Cosentino A, Cook M, Hoban P, Haynes A, et al. Changing cultures: enhancing mental health and wellbeing of refugee young people through education and training. Promot Educ. 2007;14(3):143-9. [pmid: 18154223].
328 Boone KB, Lu P, Wen J. Comparison of various RAVLT scores in the detection of noncredible memory performance. Arch Clin Neuropsychol. May. 2005;20(3):301-19. [pmid: 15797167].
329 Booth A. In search of the information literacy training ‘half-life’. Health Info Libr J. Jun. 2007;24(2):145-9. [pmid: 17584219].
330 Booth RG. Educating the future eHealth professional nurse. Int J Nurs Educ Scholarsh. 2006:3. Article 13.
331 Borooah VK. On the incidence of diarrhoea among young Indian children. Econ Hum Biol. Mar. 2004;2(1):119-38. [pmid: 15463998].
332 Borrayo EA. Where's Maria? A video to increase awareness about breast cancer and mammography screening among low-literacy Latinas. Prev Med. Jul. 2004;39(1):99-110. [pmid: 15207991].
333 Borson S, Scanlan JM, Watanabe J, Tu SP, Lessig M. Simplifying detection of cognitive impairment: comparison of the Mini-Cog and Mini-Mental State Examination in a multiethnic sample. J Am Geriatr Soc. May. 2005;53(5):871-4. [pmid: 15877567].
334 Borson S, Scanlan JM, Watanabe J, Tu SP, Lessig M. Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. Apr. 2006;21(4):349-55. [pmid: 16534774].
335 Borycki EM, Lemieux-Charles L. Does a hybrid electronic-paper environment impact on health professional information seeking?. Stud Health Technol Inform. 2008;136:505-10. [pmid: 18487781].
336 Borzekowski DL. Adolescents' use of the Internet: a controversial, coming-of-age resource. Adolesc Med Clin. Feb. 2006;17(1):205-16. [pmid: 16473301].
337 Borzekowski DL. Considering children and health literacy: a theoretical approach. Pediatrics. Nov. 3. 2009;124:S282-8. [pmid: 19861482].
338 Bose S, Trent K. Socio-demographic determinants of abortion in India: a north-South comparison. J Biosoc Sci. Mar. 2006;38(2):261-82. [pmid: 16202178].
339 Boswell C, Cannon S, Aung K, Eldridge J. An application of health literacy research. Appl Nurs Res. Feb. 2004;17(1):61-4. [pmid: 14991557].
340 Bosworth HB, Olsen MK, Gentry P, Orr M, Dudley T, McCant F, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
341 Bot M, Milder IE, Bemelmans WJ. Nationwide implementation of Hello World: a Dutch email-based health promotion program for pregnant women. J Med Internet Res. 2009;11(3):e24. [pmid: 19674957].
342 Botden SM, Buzink SN, Schijven MP, Jakimowicz JJ. ProMIS augmented reality training of laparoscopic procedures face validity. Simul Healthc. Summer. 2008;3(2):97-102. [pmid: 19088648].
343 Bouchard C. Literacy and hazard communication: ensuring workers understand the information they receive. AAOHN J. Jan. 2007;55(1):18-25. [pmid: 17260677].
344 Boudreau D. Use of a parent questionnaire in emergent and early literacy assessment of preschool children. Lang Speech Hear Serv Sch. Jan. 2005;36(1):33-47. [pmid: 15801506].
345 Boudreau JD, Cassell EJ, Fuks A. Preparing medical students to become skilled at clinical observation. Med Teach. 2008;30(9-10):857-62. [pmid: 18825545].
346 Bourne RR, Dineen BP, Ali SM, Noorul Huq DM, Johnson GJ. Prevalence of refractive error in Bangladeshi adults: results of the National Blindness and Low Vision Survey of Bangladesh. Ophthalmology. Jun. 2004;111(6):1150-60. [pmid: 15177965].
347 Bousamra M, Kloecker G, Herbig S. Drive cancer out: a physician-led anti-smoking program directed at teens and adolescents. J Ky Med Assoc. Dec. 2008;106(12):561-5. [pmid: 19130873].
348 Boutayeb A, Serghini M. Health indicators and human development in the Arab region. Int J Health Geogr. 2006;5:61. [pmid: 17194309].
349 Bova C, Fennie KP, Watrous E, Dieckhaus K, Williams AB. The health care relationship (HCR) trust scale: development and psychometric evaluation. Res Nurs Health. Oct. 2006;29(5):477-88. [pmid: 16977644].
350 Bowd AD. Otitis media: health and social consequences for aboriginal youth in Canada's north. Int J Circumpolar Health. Feb. 2005;64(1):5-15. [pmid: 15776988].
351 Bowen D. Predictors of women's Internet access and Internet health seeking. Health Care Women Int. Dec. 2003;24(10):940-51. [pmid: 14742131].
352 Bowling BV, Acra EE, Wang L, Myers MF, Dean GE, Markle GC, et al. Development and evaluation of a genetics literacy assessment instrument for undergraduates. Genetics. Jan. 2008;178(1):15-22. [pmid: 18202354].
353 Bowman NA, Kitayama S, Nisbett RE. Social class differences in self, attribution, and attention: socially expansive individualism of middle-class Americans. Pers Soc Psychol Bull. Jul. 2009;35(7):880-93. [pmid: 19398590].
354 Bowyer-Crane C, Snowling MJ, Duff FJ, Fieldsend E, Carroll JM, Miles J, et al. Improving early language and literacy skills: differential effects of an oral language versus a phonology with reading intervention. J Child Psychol Psychiatry. Apr. 2008;49(4):422-32. [pmid: 18081756].
355 Box JM. Twenty-first century learning after school: the case of Junior Achievement Worldwide. New Dir Youth Dev. Summer. 2006;(110):141-7. 20. 1. [pmid: 17017264].
356 Boyer C. Education and consumer informatics: improvements in existing systems. Findings from the Yearbook 2008 Section on. Education and Consumer Informatics Yearb Med Inform. 2008:88-90.
357 Bracken SS. The role of oral language revisited: a comment on the NICHD Early Child Care Research Network (2005). Dev Psychol. Nov. 2005;41(6):998-9. discussion 1000-2. [pmid: 16351344].
358 Brackis-Cott E, Kang E, Dolezal C, Abrams EJ, Mellins CA. Brief report: language ability and school functioning of youth perinatally infected with HIV. J Pediatr Health Care. May-Jun. 2009;23(3):158-64. [pmid: 19401248].
359 Brackis-Cott E, Kang E, Dolezal C, Abrams EJ, Mellins CA. The impact of perinatal HIV infection on older school-aged children's and adolescents' receptive language and word recognition skills. AIDS Patient Care STDS. Jun. 2009;23(6):415-21. [pmid: 19415986].
360 Bradman A, Whitaker D, Quiros L, Castorina R, Henn BC, Nishioka M, et al. Pesticides and their metabolites in the homes and urine of farmworker children living in the Salinas Valley, CA. J Expo Sci Environ Epidemiol. Jul. 2007;17(4):331-49. [pmid: 16736054].
361 Brajkovic L, Godan A, Godan L. Quality of life after stroke in old age: comparison of persons living in nursing home and those living in their own home. Croat Med J. Apr. 2009;50(2):182-8. [pmid: 19399952].
362 Bramao I, Mendonca A, Faisca L, Ingvar M, Petersson KM, Reis A. The impact of reading and writing skills on a visuo-motor integration task: a comparison between illiterate and literate subjects. J Int Neuropsychol Soc. Mar. 2007;13(2):359-64. [pmid: 17286893].
363 Bravender T. School performance: the pediatrician's role. Clin Pediatr (Phila). Jul. 2008;47(6):535-45. [pmid: 18566352].
364 Brayne C, Gao L, Dewey M, Matthews FE. Dementia before death in ageing societies--the promise of prevention and the reality. PLoS Med. Oct. 2006;3(10):e397. [pmid: 17076551].
365 Braze D, Tabor W, Shankweiler DP, Mencl WE. Speaking up for vocabulary: reading skill differences in young adults. J Learn Disabil. May-Jun. 2007;40(3):226-43. [pmid: 17518215].
366 Brehaut JC, Stiell IG, Visentin L, Graham ID. Clinical decision rules “in the real world”: how a widely disseminated rule is used in everyday practice. Acad Emerg Med. Oct. 2005;12(10):948-56. [pmid: 16166599].
367 Brettle A. Evaluating information skills training in health libraries: a systematic review. Health Info Libr J. Dec. 1. 2007;24:18-37. [pmid: 18005292].
368 Brey RA, Clark SE, Wantz MS. Enhancing health literacy through accessing health information, products, and services: an exercise for children and adolescents. J Sch Health. Nov. 2007;77(9):640-4. [pmid: 17970869].
369 Brey RA, Clark SE, Wantz MS. This is your future: a case study approach to foster health literacy. J Sch Health. Jun. 2008;78(6):351-5. [pmid: 18489469].
370 Brice JH, Travers D, Cowden CS, Young MD, Sanhueza A, Dunston Y. Health literacy among Spanish-speaking patients in the emergency department. J Natl Med Assoc. Nov. 2008;100(11):1326-32. [pmid: 19024230].
371 Brito GN, de Onis M. Growth status and academic performance in Brazilian school age children: growth retardation impairs mathematical, but not reading and spelling abilities. Arq Neuropsiquiatr. Dec. 2006;64(4):921-5. [pmid: 17220996].
372 Britto MC, Freire EF, Bezerra PG, Brito Rde C, Rego Jda C. Low income as a protective factor against asthma in children and adolescents treated via the Brazilian Unified Health System. J Bras Pneumol. May. 2008;34(5):251-5. [pmid: 18545819].
373 Brock TP, Smith SR. Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings. Int J Med Inform. Nov-Dec. 2007;76(11-12):829-35. [pmid: 17113345].
374 Brooks F, Scott P. Knowledge work in nursing and midwifery: an evaluation through computer-mediated communication. Int J Nurs Stud. Jan. 2006;43(1):83-97. [pmid: 16326164].
375 Brooks-Gunn J, Markman LB. The contribution of parenting to ethnic and racial gaps in school readiness. Future Child. Spring. 2005;15(1):139-68. [pmid: 16130545].
376 Broos A. Gender and information and communication technologies (ICT) anxiety: male self-assurance and female hesitation. Cyberpsychol Behav. Feb. 2005;8(1):21-31. [pmid: 15738690].
377 Brosnan MJ. Effect of perceiving computing to be an acquirable skill upon a computer-mediated serial recall task. Percept Mot Skills. Apr. 2005;100(2):354-6. [pmid: 15974343].
378 Brosnan MJ. Digit ratio as an indicator of numeracy relative to literacy in 7-year-old British schoolchildren. Br J Psychol. Feb. 2008;99(Pt 1):75-85. [pmid: 17535470].
379 Brown DR, Ludwig R, Buck GA, Durham D, Shumard T, Graham SS. Health literacy: universal precautions needed. J Allied Health. Summer. 2004;33(2):150-5. [pmid: 15239414].
380 Brown GT. Student information literacy: psychometric validation of a self-efficacy report. Psychol Rep. Jun. 2005;96(3 Pt 2):1044-8. [pmid: 16173376].
381 Brown J, Wheatley F, Holyoake DD, Clarkson D, Szczepanska S. Use IT or lose it?. Nurs Stand. Jul. 12-18. 2006;20(44):28-9. [pmid: 16872114].
382 Brown JF, Nelson JL. Integration of information literacy into a revised medical school curriculum. Med Ref Serv Q. Fall. 2003;22(3):63-74. [pmid: 14527141].
383 Brown KJ, Kilbride HW, Turnbull W, Lemanek K. Functional outcome at adolescence for infants less than 801 g birth weight: perceptions of children and parents. J Perinatol. Jan. 2003;23(1):41-7. [pmid: 12556926].
384 Brown L, Upchurch G, Frank SK. Low health literacy: what pharmacists can do to help. J Am Pharm Assoc (2003). Jan-Feb. 2006;46(1):4-11. [pmid: 16529335].
385 Brown SL, Teufel JA, Birch DA. Early adolescents perceptions of health and health literacy. J Sch Health. Jan. 2007;77(1):7-15. [pmid: 17212754].
386 Brown ST, Kirkpatrick MK, Mangum D, Avery J. A review of narrative pedagogy strategies to transform traditional nursing education. J Nurs Educ. Jun. 2008;47(6):283-6. [pmid: 18557318].
387 Brown T. Literacy and healthcare: the challenge of communication in home healthcare and hospice. Home Healthc Nurse. Jan. 2009;27(1):55-9. [pmid: 19114788].
388 Brownhill S, Wilhelm K, Eliovson G, Waterhouse M. ‘For men only’. A mental health prompt list in primary care. Aust Fam Physician. Jun. 2003;32(6):443-50. [pmid: 12833772].
389 Bruce B, Thernlund G, Nettelbladt U. ADHD and language impairment: A study of the parent questionnaire FTF (Five to Fifteen). Eur Child Adolesc Psychiatry. Feb. 2006;15(1):52-60. [pmid: 16514510].
390 Bruce DG, Davis WA, Casey GP, Starkstein SE, Clarnette RM, Almeida OP, et al. Predictors of cognitive decline in older individuals with diabetes. Diabetes Care. Nov. 2008;31(11):2103-7. [pmid: 18650375].
391 Brucki SM, Nitrini R. Cancellation task in very low educated people. Arch Clin Neuropsychol. Mar. 2008;23(2):139-47. [pmid: 18178373].
392 Bruett K. Why American business demands twenty-first century skills: an industry perspective. New Dir Youth Dev. Summer. 2006;110:25-30. 9. 10. [pmid: 17017253].
393 Brug J, Wammes B, Kremers S, Giskes K, Oenema A. Underestimation and overestimation of personal weight status: associations with socio-demographic characteristics and weight maintenance intentions. J Hum Nutr Diet. Aug. 2006;19(4):253-62. [pmid: 16911237].
394 Brugge D, Bagley J, Hyde J. Environmental management of asthma at top-ranked U.S. managed care organizations. J Asthma. Sep. 2003;40(6):605-14. [pmid: 14579991].
395 Brugge D, Rivera-Carrasco E, Zotter J, Leung A. Community-based participatory research in Boston's neighborhoods: A review of asthma case examples. Arch Environ Occup Health. Jan-Mar. 1. 2010;65(1):38-44. [pmid: 20147002].
396 Brumby SA, Willder SJ, Martin J. The sustainable farm families project: changing attitudes to health. Rural Remote Health. Jan-Mar. 2009;9(1):1012. [pmid: 19292570].
397 Bryan C. Provider and policy response to reverse the consequences of low health literacy. J Healthc Manag. Jul-Aug. 2008;53(4):230-41. [pmid: 18720685].
398 Bryan K, Freer J, Furlong C. Language and communication difficulties in juvenile offenders. Int J Lang Commun Disord. Sep-Oct. 2007;42(5):505-20. [pmid: 17729143].
399 Bryant MD, Schoenberg ED, Johnson TV, Goodman M, Owen-Smith A, Master VA. Multimedia version of a standard medical questionnaire improves patient understanding across all literacy levels. J Urol. Sep. 2009;182(3):1120-5. [pmid: 19625036].
400 Bryson M, Tidy N, Smith M, Levy S. An online survey of nurses' perceptions, knowledge and expectations of the National Health Service modernization programme. J Telemed Telecare. 1. 2005;11:64-6. [pmid: 16035999].
401 Buchbinder R, Hall S, Youd JM. Functional health literacy of patients with rheumatoid arthritis attending a community-based rheumatology practice. J Rheumatol. May. 2006;33(5):879-86. [pmid: 16511936].
402 Buckley PF, Madaan V. Leadership and professional workforce development. Psychiatr Clin North Am. Mar. 2008;31(1):105-22. [pmid: 18295042].
403 Buckley S. Teaching numeracy. Downs Syndr Res Pract. Jul. 2007;12(1):11-4. [pmid: 17692181].
404 Buckley S, Bird G, Sacks B, Archer T. A comparison of mainstream and special education for teenagers with Down syndrome: implications for parents and teachers. Downs Syndr Res Pract. Jun. 2006;9(3):54-67. [pmid: 16869376].
405 Budgen S. “We need to be savvy in computer literacy and in managing information”. Nurs Times. Dec. 5-11. 2006;102(49):12. [pmid: 17175761].
406 Buescher PA, White AE, DeWalt DA. Seleted data related to health literacy in North Carolina. N C Med J. Sep-Oct. 2007;68(5):377-8. [pmid: 18183768].
407 Buetow S, Jutel A, Hoare K. Shrinking social space in the doctor-modern patient relationship: a review of forces for, and implications of, homologisation. Patient Educ Couns. Jan. 2009;74(1):97-103. [pmid: 18789627].
408 Buist A, Speelman C, Hayes B, Reay R, Milgrom J, Meyer D, et al. Impact of education on women with perinatal depression. J Psychosom Obstet Gynaecol. Mar. 2007;28(1):49-54. [pmid: 17454513].
409 Bulgiba AM, Noran MH. IT usage, perceptions and literacy of medical students. Asia Pac J Public Health. 2003;15(2):127-34. [pmid: 15038688].
410 Bulik RJ. Perspectives on the patient-provider relationship in primary-care telemedicine. Telemed J E Health. Winter. 2004;10(4):466-8. [pmid: 15689652].
411 Bull L. Sunflower therapy for children with specific learning difficulties (dyslexia): a randomised, controlled trial. Complement Ther Clin Pract. Feb. 2007;13(1):15-24. [pmid: 17210507].
412 Bunn T. The effectiveness of Additional Literacy Support (ALS) in Years 3 and 4. Dyslexia. Aug. 2008;14(3):214-27. [pmid: 18697191].
413 Burdick DJ, Rosenblatt A, Samus QM, Steele C, Baker A, Harper M, et al. Predictors of functional impairment in residents of assisted-living facilities: the Maryland Assisted Living Study. J Gerontol A Biol Sci Med Sci. Feb. 2005;60(2):258-64. [pmid: 15814872].
414 Burke MS. The incidence of technological stress among baccalaureate nurse educators using technology during course preparation and delivery. Nurse Educ Today. Jan. 2009;29(1):57-64. [pmid: 18694615].
415 Burnett N. Education for all: an imperative for reducing poverty. Ann N Y Acad Sci. 2008;1136:269-75. [pmid: 17954673].
416 Burns JR, Rapee RM. Adolescent mental health literacy: young people's knowledge of depression and help seeking. J Adolesc. Apr. 2006;29(2):225-39. [pmid: 15996727].
417 Burton H, McLaren DG. Visual cortex activation in late-onset, Braille naive blind individuals: an fMRI study during semantic and phonological tasks with heard words. Neurosci Lett. Jan. 9. 2006;392(1-2):38-42. [pmid: 16198053].
418 Bury R, Martin L, Roberts S. Achieving change through mutual development: supported online learning and the evolving roles of health and information professionals. Health Info Libr J. Dec. 1. 2006;23:22-31. [pmid: 17206993].
419 Bushko RG. Situated, strategic, and AI-Enhanced technology introduction to healthcare. Stud Health Technol Inform. 2005;118:273-7. [pmid: 16301786].
420 Bushnell J, McLeod D, Dowell A, Salmond C, Ramage S, Collings S, et al. Do patients want to disclose psychological problems to GPs?. Fam Pract. Dec. 2005;22(6):631-7. [pmid: 16055471].
421 Butterbaugh G, Olejniczak P, Roques B, Costa R, Rose M, Fisch B, et al. Lateralization of temporal lobe epilepsy and learning disabilities, as defined by disability-related civil rights law. Epilepsia. Aug. 2004;45(8):963-70. [pmid: 15270764].
422 Butters MA, Whyte EM, Nebes RD, Begley AE, Dew MA, Mulsant BH, et al. The nature and determinants of neuropsychological functioning in late-life depression. Arch Gen Psychiatry. Jun. 2004;61(6):587-95. [pmid: 15184238].
423 Byrd DA, Jacobs DM, Hilton HJ, Stern Y, Manly JJ. Sources of errors on visuoperceptual tasks: role of education, literacy, and search strategy. Brain Cogn. Aug. 2005;58(3):251-7. [pmid: 15963375].
424 Byrd DA, Touradji P, Tang MX, Manly JJ. Cancellation test performance in African American, Hispanic, and White elderly. J Int Neuropsychol Soc. May. 2004;10(3):401-11. [pmid: 15147598].
425 Byrd DR, Katcher ML, Peppard P, Durkin M, Remington PL. Infant mortality: explaining black/white disparities in Wisconsin. Matern Child Health J. Jul. 2007;11(4):319-26. [pmid: 17473986].
426 Cabell SQ, Justice LM, Zucker TA, McGinty AS. Emergent name-writing abilities of preschool-age children with language impairment. Lang Speech Hear Serv Sch. Jan. 2009;40(1):53-66. [pmid: 18840675].
427 Cadmus E, Van Wynen EA, Chamberlain B, Steingall P, Kilgallen ME, Holly C, et al. Nurses' skill level and access to evidence-based practice. J Nurs Adm. Nov. 2008;38(11):494-503. [pmid: 18997555].
428 Cain J, Bird ER, Jones M. Mobile computing initiatives within pharmacy education. Am J Pharm Educ. Aug. 15. 2008;72(4):76. [pmid: 19002276].
429 Calderon JL, Fleming E, Gannon MR, Chen SC, Vassalotti JA, Norris KC. Applying an expanded set of cognitive design principles to formatting the Kidney Early Evaluation Program (KEEP) longitudinal survey. Am J Kidney Dis. Apr. 2008;51(4 Suppl 2):S83-92. [pmid: 18359412].
430 Calderon JL, Zadshir A, Norris K. Structure and content of chronic kidney disease information on the World Wide Web: barriers to public understanding of a pandemic. Nephrol News Issues. Oct. 8. 2004;18(11):76-9. 81. 4. [pmid: 15551616].
431 Calderon JL, Zadshir A, Norris K. A survey of kidney disease and risk-factor information on the World Wide Web. MedGenMed. 2004;6(4):3. [pmid: 15775830].
432 Caliskan D, Ozdemir O, Ocaktan E, Idil A. Evaluation of awareness of diabetes mellitus and associated factors in four health center areas. Patient Educ Couns. Jul. 2006;62(1):142-7. [pmid: 16139985].
433 Callen JL, Alderton M, McIntosh J. Evaluation of electronic discharge summaries: a comparison of documentation in electronic and handwritten discharge summaries. Int J Med Inform. Sep. 2008;77(9):613-20. [pmid: 18294904].
434 Callingham R, Watson JM. Measuring statistical literacy. J Appl Meas. 2005;6(1):19-47. [pmid: 15701942].
435 Callister LC. Improving literacy in women and girls globally. MCN Am J Matern Child Nurs. May-Jun. 2007;32(3):194. [pmid: 17479059].
436 Calza S, Specchia C, Frasca G, Tumino R, Sacerdote C, Fiorini L, et al. EPIC-Italy cohorts and multipurpose national surveys. A comparison of some socio-demographic and life-style characteristics. Tumori. Nov-Dec. 2003;89(6):615-23. [pmid: 14870826].
437 Cambanis A, Ramsay A, Yassin MA, Cuevas LE. Duration and associated factors of patient delay during tuberculosis screening in rural Cameroon. Trop Med Int Health. Nov. 2007;12(11):1309-14. [pmid: 17949400].
438 Cameron CE, Connor CM, Morrison FJ, Jewkes AM. Effects of classroom organization on letter-word reading in first grade. J Sch Psychol. Apr. 2008;46(2):173-92. [pmid: 19083356].
439 Campbell FA, Goldman BD, Boccia ML, Skinner M. The effect of format modifications and reading comprehension on recall of informed consent information by low-income parents: a comparison of print, video, and computer-based presentations. Patient Educ Couns. May. 2004;53(2):205-16. [pmid: 15140461].
440 Campbell MJ, Edwards MJ, Ward KS, Weatherby N. Developing a parsimonious model for predicting completion of advance directives. J Nurs Scholarsh. 2007;39(2):165-71. [pmid: 17535317].
441 Campos C. Addressing cultural barriers to the successful use of insulin in Hispanics with type 2 diabetes. South Med J. Aug. 2007;100(8):812-20. [pmid: 17713308].
442 Campus G, Solinas G, Strohmenger L, Cagetti MG, Senna A, Minelli L, et al. National pathfinder survey on children's oral health in Italy: pattern and severity of caries disease in 4-year-olds. Caries Res. 2009;43(2):155-62. [pmid: 19365120].
443 Canada RE, Turner B. Talking to patients about screening colonoscopy˜where conversations fall short. J Fam Pract. Aug. 2007;56(8):E1-9. [pmid: 17669281].
444 Candela L, Bowles C. Recent RN graduate perceptions of educational preparation. Nurs Educ Perspect. Sep-Oct. 2008;29(5):266-71. [pmid: 18834055].
445 Candilis PJ, Fletcher KE, Geppert CM, Lidz CW, Appelbaum PS. A direct comparison of research decision-making capacity: schizophrenia/schizoaffective, medically ill, and non-ill subjects. Schizophr Res. Feb. 2008;99(1-3):350-8. [pmid: 18164593].
446 Canino G, McQuaid EL, Rand CS. Addressing asthma health disparities: a multilevel challenge. J Allergy Clin Immunol. Jun. 2009;123(6):1209-17. quiz 18-9. [pmid: 19447484].
447 Cannon S, Boswell C. Filling gaps in knowledge: educating nurses to provide appropriate patient materials. J Contin Educ Nurs. Apr. 2009;40(4):148-9. [pmid: 19418751].
448 Cantrell SW, O'Leary P, Ward KS. Strategies for success in online learning. Nurs Clin North Am. Dec. 2008;43(4):547-55. vi. [pmid: 18940411].
449 Capella-McDonnall ME. The effects of single and dual sensory loss on symptoms of depression in the elderly. Int J Geriatr Psychiatry. Sep. 2005;20(9):855-61. [pmid: 16116571].
450 Capuano M, Knoderer T. Twenty-first century learning in school systems: the case of the Metropolitan School District of Lawrence Township, Indianapolis, Indiana. New Dir Youth Dev. Summer. 2006;(110):113-25. 17. 8. [pmid: 17017261].
451 Caravolas M, Volin J, Hulme C. Phoneme awareness is a key component of alphabetic literacy skills in consistent and inconsistent orthographies: evidence from Czech and English children. J Exp Child Psychol. Oct. 2005;92(2):107-39. [pmid: 16038927].
452 Carcaise-Edinboro P, McClish D, Kracen AC, Bowen D, Fries E. Fruit and vegetable dietary behavior in response to a low-intensity dietary intervention: the rural physician cancer prevention project. J Rural Health. Summer. 2008;24(3):299-305. [pmid: 18643808].
453 Carden CP, Jefford M, Rosenthal MA. Information about cancer clinical trials: an analysis of Internet resources. Eur J Cancer. Jul. 2007;43(10):1574-80. [pmid: 17544266].
454 Cardenas-Hagan E, Carlson CD, Pollard-Durodola SD. The cross-linguistic transfer of early literacy skills: the role of initial L1 and L2 skills and language of instruction. Lang Speech Hear Serv Sch. Jul. 2007;38(3):249-59. [pmid: 17625051].
455 Carlesimo GA, Bonanni R, Caltagirone C. Memory for the perceptual and semantic attributes of information in pure amnesic and severe closed-head injured patients. J Clin Exp Neuropsychol. May. 2003;25(3):391-406. [pmid: 12916652].
456 Carlock D, Anderson J. Teaching and assessing the database searching skills of student nurses. Nurse Educ. Nov-Dec. 2007;32(6):251-5. [pmid: 17998852].
457 Carlson BA, Neal D, Magwood G, Jenkins C, King MG, Hossler CL. A community-based participatory health information needs assessment to help eliminate diabetes information disparities. Health Promot Pract. Jul. 2006;7(3 Suppl):213S-22S. [pmid: 16760247].
458 Carmona RH. Improving Americans' health literacy. J Am Diet Assoc. Sep. 2005;105(9):1345. [pmid: 16129071].
459 Carney PA, Poor DA, Schifferdecker KE, Gephart DS, Brooks WB, Nierenberg DW. Computer use among community-based primary care physician preceptors. Acad Med. Jun. 2004;79(6):580-90. [pmid: 15165980].
460 Carod-Artal FJ, Ferreira Coral L, Trizotto DS, Menezes Moreira C. Poststroke depression: prevalence and determinants in Brazilian stroke patients. Cerebrovasc Dis. 2009;28(2):157-65. [pmid: 19556768].
461 Carolan M. Health literacy and the information needs and dilemmas of first-time mothers over 35 years. J Clin Nurs. Jun. 2007;16(6):1162-72. [pmid: 17518891].
462 Caron J, Latimer E, Tousignant M. Predictors of psychological distress in low-income populations of Montreal. Can J Public Health. Jul-Aug. 1. 2007;98:S35-44. [pmid: 18047159].
463 Carr AB, Beebe TJ, Jenkins SM. An assessment of oral health importance: results of a statewide survey. J Am Dent Assoc. May. 2009;140(5):580-6. [pmid: 19411529].
464 Carroll J, Epstein R, Fiscella K, Gipson T, Volpe E, Jean-Pierre P. Caring for Somali women: implications for clinician-patient communication. Patient Educ Couns. Jun. 2007;66(3):337-45. [pmid: 17337152].
465 Carroll JM, Maughan B, Goodman R, Meltzer H. Literacy difficulties and psychiatric disorders: evidence for comorbidity. J Child Psychol Psychiatry. May. 2005;46(5):524-32. [pmid: 15845132].
466 Carroll JM, Snowling MJ. Language and phonological skills in children at high risk of reading difficulties. J Child Psychol Psychiatry. Mar. 2004;45(3):631-40. [pmid: 15055381].
467 Carthery-Goulart MT, Anghinah R, Areza-Fegyveres R, Bahia VS, Brucki SM, Damin A, et al. Performance of a Brazilian population on the test of functional health literacy in adults. Rev Saude Publica. Aug. 2009;43(4):631-8. [pmid: 19488667].
468 Cartwright M. Numeracy needs of the beginning registered nurse. Nurse Educ Today. Apr. 1996;16(2):137-43. [pmid: 8716545].
469 Carty B, Kenney K. Consumer informatics in primary care. Stud Health Technol Inform. 2006;122:36-7. [pmid: 17102213].
470 Carvalho KM, Monteiro GB, Isaac CR, Shiroma LO, Amaral MS. Causes of low vision and use of optical aids in the elderly. Rev Hosp Clin Fac Med Sao Paulo. Aug. 2004;59(4):157-60. [pmid: 15361978].
471 Carvalho Sde A, Barreto SM, Guerra HL, Gama AC. Oral language comprehension assessment among elderly: a population based study in Brazil. Prev Med. Dec. 2009;49(6):541-5. [pmid: 19800364].
472 Case A, Ardington C. The impact of parental death on school outcomes: longitudinal evidence from South Africa. Demography. Aug. 2006;43(3):401-20. [pmid: 17051820].
473 Cashman SB, Seifer SD. Service-learning: an integral part of undergraduate public health. Am J Prev Med. Sep. 2008;35(3):273-8. [pmid: 18692742].
474 Cassey MZ. Building a case for using technology: health literacy and patient education. Nurs Econ. May-Jun. 2007;25(3):186-8. [pmid: 17803006].
475 Castle S. “The tongue is venomous”: perception, verbalisation and manipulation of mortality and fertility regimes in rural Mali. Soc Sci Med. Jun. 2001;52(12):1827-41. [pmid: 11352409].
476 Castles A, Coltheart M. Is there a causal link from phonological awareness to success in learning to read?. Cognition. Feb. 2004;91(1):77-111. [pmid: 14711492].
477 Castro CM, Wilson C, Wang F, Schillinger D. Babel babble: physicians' use of unclarified medical jargon with patients. Am J Health Behav. Sep-Oct. 1. 2007;31:S85-95. [pmid: 17931142].
478 Catroppa C, Anderson V. Recovery and predictors of language skills two years following pediatric traumatic brain injury. Brain Lang. Jan. 2004;88(1):68-78. [pmid: 14698732].
479 Cavaco S, Anderson SW, Allen JS, Castro-Caldas A, Damasio H. The scope of preserved procedural memory in amnesia. Brain. Aug. 2004;127(Pt 8):1853-67. [pmid: 15215216].
480 Cavanaugh K, Huizinga MM, Wallston KA, Gebretsadik T, Shintani A, Davis D, et al. Association of numeracy and diabetes control. Ann Intern Med. May. 20. 2008;148(10):737-46. [pmid: 18490687].
481 Chachamovich E, Fleck MP, Power M. Literacy affected ability to adequately discriminate among categories in multipoint Likert Scales. J Clin Epidemiol. Jan. 2009;62(1):37-46. [pmid: 18619806].
482 Chaffin AJ, Maddux CD. Accessibility accommodations for older adults seeking ehealth information. J Gerontol Nurs. Mar. 2007;33(3):6-12. [pmid: 17378186].
483 Chandhiok N, Dhillon BS, Datey S, Mathur A, Saxena NC. Oral misoprostol for prevention of postpartum hemorrhage by paramedical workers in India. Int J_Gynaecol Obstet. Feb. 2006;92(2):170-5. [pmid: 16371228].
484 Chang C. Increasing mental health literacy via narrative advertising. J Health Commun. Jan-Feb. 2008;13(1):37-55. [pmid: 18307135].
485 Chang CH, Sharp LK, Kimmel LG, Grammer LC, Kee R, Shannon JJ. A 6-item brief measure for assessing perceived control of asthma in culturally diverse patients. Ann Allergy Asthma Immunol. Aug. 2007;99(2):130-5. [pmid: 17718100].
486 Chang CS. Development and validation of the computer technology literacy self-assessment scale for Taiwanese elementary school students. Adolescence. Fall. 2008;43(171):623-34. [pmid: 19086674].
487 Changrani J, Gany F. Online cancer education and immigrants: effecting culturally appropriate websites. J Cancer Educ. Fall. 2005;20(3):183-6. [pmid: 16122368].
488 Chapman JW, Tunmer WE, Allen R. Findings from the International Adult Literacy Survey on the incidence and correlates of learning disabilities in New Zealand: is something rotten in the state of New Zealand?. Dyslexia. May. 2003;9(2):75-98. [pmid: 12775082].
489 Chapman L. Effective teamwork. Nurs Manag (Harrow). Oct. 2008;15(6):18-21. [pmid: 18982881].
490 Charles M, Bradley K. Indulging our gendered selves? Sex segregation by field of study in 44 countries. Ajs. Jan. 2009;114(4):924-76. [pmid: 19824299].
491 Charman SC, Howes A. The adaptive user: an investigation into the cognitive and task constraints on the generation of new methods. J Exp Psychol Appl. Dec. 2003;9(4):236-48. [pmid: 14664675].
492 Charman T, Baird G, Simonoff E, Loucas T, Chandler S, Meldrum D, et al. Efficacy of three screening instruments in the identification of autistic-spectrum disorders. Br J Psychiatry. Dec. 2007;191:554-9. [pmid: 18055961].
493 Chaudhari S, Otiv M, Chitale A, Hoge M, Pandit A, Mote A. Biology versus environment in low birth weight children. Indian Pediatr. Aug. 2005;42(8):763-70. [pmid: 16141477].
494 Chaudhari S, Otiv M, Chitale A, Pandit A, Hoge M. Pune low birth weight studycognitive abilities and educational performance at twelve years. Indian Pediatr. Feb. 2004;41(2):121-8. [pmid: 15004297].
495 Chauhan M, Bala R, Nandan D, Misra SK. Complementary feeding practices in rural area of district Agra. Indian J Public Health. Jan-Mar. 2007;51(1):66-7. [pmid: 18232150].
496 Chaves PH, Carlson MC, Ferrucci L, Guralnik JM, Semba R, Fried LP. Association between mild anemia and executive function impairment in community-dwelling older women: The Women's Health and Aging Study II. J Am Geriatr Soc. Sep. 2006;54(9):1429-35. [pmid: 16970654].
497 Chen CP. Transcultural expression of subcortical vascular disease. J Neurol Sci. Nov. 15. 2004;226(1-2):45-7. [pmid: 15537518].
498 Chen FC, Lin MC. Effects of a nursing literature reading course on promoting critical thinking in two-year nursing program students. J Nurs Res. Jun. 2003;11(2):137-47. [pmid: 12820077].
499 Chen JW, Zhang J. Comparing text-based and graphic user interfaces for novice and expert users. AMIA Annu Symp Proc. 2007:125-9.
500 Cheng TL, Dreyer BP, Jenkins RR. Introduction: Child health disparities and health literacy. Pediatrics. Nov. 3. 2009;124:S161-2. [pmid: 19861466].
501 Chepesiuk R. Environmental literacy: knowledge for a healthier public. Environ Health Perspect. Oct. 2007;115(10):A494-9. [pmid: 17938718].
502 Cherner M, Suarez P, Lazzaretto D, Fortuny LA, Mindt MR, Dawes S, et al. Demographically corrected norms for the brief visuospatial memory test-revised and Hopkins verbal learning test-revised in monolingual Spanish speakers from the U.S.-Mexico border region. Arch Clin Neuropsychol. Mar. 2007;22(3):343-53. [pmid: 17293078].
503 Cheung EY, Sachs J. Test of the technology acceptance model for a web-based information system in a Hong Kong Chinese sample. Psychol Rep. Dec. 2006;99(3):691-703. [pmid: 17305184].
504 Cheung YB, Thumboo J. Developing health-related quality-of-life instruments for use in Asia: the issues. Pharmacoeconomics. 2006;24(7):643-50. [pmid: 16802840].
505 Chew F, Grant W, Tote R. Doctors on-line: using diffusion of innovations theory to understand internet use. Fam Med. Oct. 2004;36(9):645-50. [pmid: 15467942].
506 Chew LD, Bradley KA, Boyko EJ. Brief questions to identify patients with inadequate health literacy. Fam Med. Sep. 2004;36(8):588-94. [pmid: 15343421].
507 Chew LD, Bradley KA, Flum DR, Cornia PB, Koepsell TD. The impact of low health literacy on surgical practice. Am J Surg. Sep. 2004;188(3):250-3. [pmid: 15450829].
508 Chew LD, Griffin JM, Partin MR, Noorbaloochi S, Grill JP, Snyder A, et al. Validation of screening questions for limited health literacy in a large VA outpatient population. J Gen Intern Med. May. 2008;23(5):561-6. [pmid: 18335281].
509 Chiang KJ, Lu RB, Chu H, Chang YC, Chou KR. Evaluation of the effect of a life review group program on self-esteem and life satisfaction in the elderly. Int J Geriatr Psychiatry. Jan. 2008;23(1):7-10. [pmid: 17477451].
510 Chiarelli L, Edwards P. Building healthy public policy. Can J Public Health. May-Jun. 2. 2006;97:S37-42. [pmid: 16805160].
511 Chiou WB, Wan CS. The dynamic change of self-efficacy in information searching on the Internet: influence of valence of experience and prior self-efficacy. J Psychol. Nov. 2007;141(6):589-603. [pmid: 18044273].
512 Chiovetti A. Bridging the gap between health literacy and patient education for people with multiple sclerosis. J Neurosci Nurs. Oct. 2006;38(5):374-8. [pmid: 17069267].
513 Chisholm JF. Cyberspace violence against girls and adolescent females. Ann N Y Acad Sci. Nov. 2006;1087:74-89. [pmid: 17189499].
514 Chisholm MA, Fair J, Spivey CA. Health literacy and transplant patients and practitioners. Public Health. Oct. 2007;121(10):800-3. [pmid: 17574640].
515 Chisolm DJ, Buchanan L. Measuring adolescent functional health literacy: a pilot validation of the Test of Functional Health Literacy in Adults. J Adolesc Health. Sep. 2007;41(3):312-4. [pmid: 17707303].
516 Cho RN, Plunkett BA, Wolf MS, Simon CE, Grobman WA. Health literacy and patient understanding of screening tests for aneuploidy and neural tube defects. Prenat Diagn. May. 2007;27(5):463-7. [pmid: 17345585].
517 Cho YI, Lee SY, Arozullah AM, Crittenden KS. Effects of health literacy on health status and health service utilization amongst the elderly. Soc Sci Med. Apr. 2008;66(8):1809-16. [pmid: 18295949].
518 Choi J, Bakken S. Heuristic evaluation of a Web-based Educational Resource for low literacy NICU parents. Stud Health Technol Inform. 2006;122:194-9. [pmid: 17102247].
519 Choi J, Starren JB, Bakken S. Web-based educational resources for low literacy families in the NICU. AMIA Annu Symp Proc. 2005:922.
520 Chou KL. Psychological distress in migrants in Australia over 50 years old: a longitudinal investigation. J Affect Disord. Feb. 2007;98(1-2):99-108. [pmid: 16890296].
521 Chou MH, Lin MF, Hsu MC, Wang YH, Hu HF. Exploring the self-learning experiences of patients with depression participating in a multimedia education program. J Nurs Res. Dec. 2004;12(4):297-306. [pmid: 15619180].
522 Chow BW, McBride-Chang C, Cheung H, Chow CS. Dialogic reading and morphology training in Chinese children: effects on language and literacy. Dev Psychol. Jan. 2008;44(1):233-44. [pmid: 18194022].
523 Chowdhary N, Patel V. The effect of spousal violence on women's health: findings from the Stree Arogya Shodh in Goa, India. J Postgrad Med. Oct-Dec. 2008;54(4):306-12. [pmid: 18953151].
524 Christensen H, Griffiths KM, Jorm AF. Delivering interventions for depression by using the internet: randomised controlled trial. BMJ. Jan. 31. 2004;328(7434):265. [pmid: 14742346].
525 Christian P, Khatry SK, LeClerq SC, Roess AA, Wu L, Yuenger JD, et al. Prevalence and risk factors of chlamydia and gonorrhea among rural Nepali women. Sex Transm Infect. Jun. 2005;81(3):254-8. [pmid: 15923297].
526 Chuansumrit A. Treatment of haemophilia in the developing countries. Haemophilia. Jul. 2003;9(4):387-90. [pmid: 12828673].
527 Chugh A, Williams MV, Grigsby J, Coleman EA. Better transitions: improving comprehension of discharge instructions. Front Health Serv Manage. Spring. 2009;25(3):11-32. [pmid: 19382514].
528 Chumley HS, Dobbie AE, Delzell JE Jr. Case-based exercises fail to improve medical students' information management skills: a controlled trial. BMC Med Educ. 2006;6:14. [pmid: 16509977].
529 Chung JH, Voss KJ, Caughey AB, Wing DA, Henderson EJ, Major CA. Role of patient education level in predicting macrosomia among women with gestational diabetes mellitus. J Perinatol. Jun. 2006;26(6):328-32. [pmid: 16642026].
530 Chung WK. Implementation of genetics to personalize medicine. Gend Med. Sep. 2007;4(3):248-65. [pmid: 18022591].
531 Chur-Hansen A, Taverner R, Barrett RJ, Hugo M. Mental health nurses' and psychiatrists' views on the prognosis of schizophrenia and depression: an exploratory, qualitative investigation. J Psychiatr Ment Health Nurs. Oct. 2005;12(5):607-13. [pmid: 16164513].
532 Clamp PJ, Virdi P, Vats A, Pothier DD. Information technology in ENT: are we ready to be ‘Connected For Health’?. J Laryngol Otol. Jul. 2007;121(7):687-91. [pmid: 17052372].
533 Clancy C. PAs, health literacy, and medication safety. Jaapa. Oct. 2008;21(10):51. [pmid: 19024637].
534 Clancy TR, Effken JA, Pesut D. Applications of complex systems theory in nursing education, research, and practice. Nurs Outlook. Sep-Oct. 2008;56(5):248-56. e3. [pmid: 18922279].
535 Clark DO, Frankel RM, Morgan DL, Ricketts G, Bair MJ, Nyland KA, et al. The meaning and significance of self-management among socioeconomically vulnerable older adults. J Gerontol B Psychol Sci Soc Sci. Sep. 2008;63(5):S312-9. [pmid: 18818452].
536 Clarke JR, Lerner JC, Marella W. The role for leaders of health care organizations in patient safety. Am J Med Qual. Sep-Oct. 2007;22(5):311-8. [pmid: 17804390].
537 Clarke MT, Donlan C, Lister C, Wright J, Newton C, Cherguit J. The provision of communication aids to children in England: an analysis of applications to the Communication Aids Project. Child Care Health Dev. Sep. 2007;33(5):569-75. [pmid: 17725779].
538 Cleary M, Walter G, Matheson S. What is the role of e-technology in mental health services and psychiatric research?. J Psychosoc Nurs Ment Health Serv. Apr. 2008;46(4):42-8. [pmid: 18478808].
539 Clegg J, Hollis C, Mawhood L, Rutter M. Developmental language disorders--a follow-up in later adult life. Cognitive, language and psychosocial outcomes. J Child Psychol Psychiatry. Feb. 2005;46(2):128-49. [pmid: 15679523].
540 Clendon SA, Erickson KA. The vocabulary of beginning writers: implications for children with complex communication needs. Augment Altern Commun. Dec. 2008;24(4):281-93. [pmid: 19023750].
541 Cobb SC. Comparison of oncology nurse and physician use of the Internet for continuing education. J Contin Educ Nurs. Jul-Aug. 2003;34(4):184-8. [pmid: 12887230].
542 Cobban SJ, Seale LN. A collaborative approach for improving information literacy skills of dental hygiene students. Int J Dent Hyg. Feb. 2003;1(1):49-56. [pmid: 16451546].
543 Cobus L. Integrating information literacy into the education of public health professionals: roles for librarians and the library. J Med Libr Assoc. Jan. 2008;96(1):28-33. [pmid: 18219378].
544 Cochran G, Hardy J, Harpending H. Natural history of Ashkenazi intelligence. J Biosoc Sci. Sep. 2006;38(5):659-93. [pmid: 16867211].
545 Cochran J, Conn VS. Meta-analysis of quality of life outcomes following diabetes self-management training. Diabetes Educ. Sep-Oct. 2008;34(5):815-23. [pmid: 18832286].
546 Coelho M, Ferreira JJ, Dias B, Sampaio C, Pavao Martins I, Castro-Caldas A. Assessment of time perception: the effect of aging. J Int Neuropsychol Soc. May. 2004;10(3):332-41. [pmid: 15147591].
547 Cohall A, Nshom M, Nye A. One chip at a time: using technology to enhance youth development. Adolesc Med State Art Rev. Aug. 2007;18(2):415-24. xiv. [pmid: 18605656].
548 Cohen F, Kemeny ME, Zegans LS, Johnson P, Kearney KA, Stites DP. Immune function declines with unemployment and recovers after stressor termination. Psychosom Med. Apr. 2007;69(3):225-34. [pmid: 17401058].
549 Cohen GL, Garcia J, Apfel N, Master A. Reducing the racial achievement gap: a social-psychological intervention. Science. Sep. 1. 2006;313(5791):1307-10. [pmid: 16946074].
550 Cohen LA, Bonito AJ, Akin DR, Manski RJ, Macek MD, Edwards RR, et al. Toothache pain: a comparison of visits to physicians, emergency departments and dentists. J Am Dent Assoc. Sep. 2008;139(9):1205-16. [pmid: 18762631].
551 Cohen S, Doyle WJ, Turner RB, Alper CM, Skoner DP. Childhood socioeconomic status and host resistance to infectious illness in adulthood. Psychosom Med. Jul-Aug. 2004;66(4):553-8. [pmid: 15272102].
552 Cohen T, Blatter B, Almeida C, Shortliffe E, Patel V. A cognitive blueprint of collaboration in context: distributed cognition in the psychiatric emergency department. Artif Intell Med. Jun. 2006;37(2):73-83. [pmid: 16730960].
553 Cohen-Mansfield J, Marx MS, Biddison JR, Guralnik JM. Socio-environmental exercise preferences among older adults. Prev Med. Jun. 2004;38(6):804-11. [pmid: 15193902].
554 Coldren RL, Prosser T, Ogolla F, Ofula VO, Adungo N. Literacy and recent history of diarrhoea are predictive of Plasmodium falciparum parasitaemia in Kenyan adults. Malar J. 2006;5:96. [pmid: 17076908].
555 Coleman EA, Lord J, Heard J, Coon S, Cantrell M, Mohrmann C, et al. The Delta project: increasing breast cancer screening among rural minority and older women by targeting rural healthcare providers. Oncol Nurs Forum. Jul-Aug. 2003;30(4):669-77. [pmid: 12861326].
556 Coles ME, Coleman SL. Barriers to treatment seeking for anxiety disorders: initial data on the role of mental health literacy. Depress Anxiety. 2010;27(1):63-71. [pmid: 19960488].
557 Collier EJ, Harrington C. Discharge planning, nursing home placement, and the Internet. Nurs Outlook. Mar-Apr. 2005;53(2):95-103. [pmid: 15858528].
558 Collins M, Crowley R, Karlawish JH, Casarett DJ. Are depressed patients more likely to share health care decisions with others?. J Palliat Med. Aug. 2004;7(4):527-32. [pmid: 15353096].
559 Colom R, Garcia-Lopez O. Secular gains in fluid intelligence: evidence from the Culture-Fair intelligence test. J Biosoc Sci. Jan. 2003;35(1):33-9. [pmid: 12537154].
560 Colombatti R, Coin A, Bestagini P, Vieira CS, Schiavon L, Ambrosini V, et al. A short-term intervention for the treatment of severe malnutrition in a post-conflict country: results of a survey in Guinea Bissau. Public Health Nutr. Dec. 2008;11(12):1357-64. [pmid: 18652716].
561 Comer JS, Furr JM, Beidas RS, Weiner CL, Kendall PC. Children and terrorism-related news: training parents in Coping and Media Literacy. J Consult Clin Psychol. Aug. 2008;76(4):568-78. [pmid: 18665686].
562 Connelly J, Chell S, Tennant A, Rigby AS, Airey CM. Modelling 5-year functional outcome in a major traumatic injury survivor cohort. Disabil Rehabil. May. 30. 2006;28(10):629-36. [pmid: 16690576].
563 Connor CM, Craig HK. African American preschoolers' language, emergent literacy skills, and use of African American English: a complex relation. J Speech Lang Hear Res. Aug. 2006;49(4):771-92. [pmid: 16908874].
564 Connors H, Warren J, Weaver C. HIT plants SEEDS in healthcare education. Nurs Adm Q. Apr-Jun. 2007;31(2):129-33. [pmid: 17413506].
565 Conti-Ramsden G, Durkin K. Phonological short-term memory, language and literacy: developmental relationships in early adolescence in young people with SLI. J Child Psychol Psychiatry. Feb. 2007;48(2):147-56. [pmid: 17300553].
566 Conti-Ramsden G, Durkin K. Language and independence in adolescents with and without a history of specific language impairment (SLI). J Speech Lang Hear Res. Feb. 2008;51(1):70-83. [pmid: 18230856].
567 Conti-Ramsden G, Falcaro M, Simkin Z, Pickles A. Familial loading in specific language impairment: patterns of differences across proband characteristics, gender and relative type. Genes Brain Behav. Apr. 2007;6(3):216-28. [pmid: 16827920].
568 Conti-Ramsden G, Simkin Z, Pickles A. Estimating familial loading in SLI: a comparison of direct assessment versus parental interview. J Speech Lang Hear Res. Feb. 2006;49(1):88-101. [pmid: 16533075].
569 Conwell LS, O'Callaghan MJ, Andersen MJ, Bor W, Najman JM, Williams GM. Early adolescent smoking and a web of personal and social disadvantage. J Paediatr Child Health. Nov. 2003;39(8):580-5. [pmid: 14629522].
570 Cook JA. Employment barriers for persons with psychiatric disabilities: update of a report for the President's Commission. Psychiatr Serv. Oct. 2006;57(10):1391-405. [pmid: 17035556].
571 Cordasco KM, Asch SM, Bell DS, Guterman JJ, Gross-Schulman S, Ramer L, et al. A low-literacy medication education tool for safety-net hospital patients. Am J Prev Med. Dec. 2009;37(6 Suppl 1):S209-16. [pmid: 19896021].
572 Cordasco KM, Asch SM, Franco I, Mangione CM. Health literacy and English language comprehension among elderly inpatients at an urban safety-net hospital. J Health Hum Serv Adm. Summer. 2009;32(1):30-50. [pmid: 19558032].
573 Cordery RJ, Alner K, Cipolotti L, Ron M, Kennedy A, Collinge J, et al. The neuropsychology of variant CJD: a comparative study with inherited and sporadic forms of prion disease. J Neurol Neurosurg Psychiatry. Mar. 2005;76(3):330-6. [pmid: 15716521].
574 Corraini P, Baelum V, Pannuti CM, Pustiglioni AN, Romito GA, Pustiglioni FE. Risk indicators for increased probing depth in an isolated population in Brazil. J Periodontol. Sep. 2008;79(9):1726-34. [pmid: 18771375].
575 Correia HR. Higher male educational hypergamy: evidence from Portugal. J Biosoc Sci. Apr. 2003;35(2):303-13. [pmid: 12664964].
576 Corriveau K, Pasquini E, Goswami U. Basic auditory processing skills and specific language impairment: a new look at an old hypothesis. J Speech Lang Hear Res. Jun. 2007;50(3):647-66. [pmid: 17538107].
577 Corriveau KH, Goswami U. Rhythmic motor entrainment in children with speech and language impairments: tapping to the beat. Cortex. Jan. 2009;45(1):119-30. [pmid: 19046744].
578 Cosgrove L, Riddle B. Constructions of femininity and experiences of menstrual distress. Women Health. 2003;38(3):37-58. [pmid: 14664304].
579 Costantini L, Beanlands H, McCay E, Cattran D, Hladunewich M, Francis D. The self-management experience of people with mild to moderate chronic kidney disease. Nephrol Nurs J. Mar-Apr. 2008;35(2):147-55. quiz 56. [pmid: 18472683].
580 Costello T, Coyne I. Nurses' knowledge of mouth care practices. Br J Nurs. Feb. 28. Mar. 12. 2008;17(4):264-8. [pmid: 18414273].
581 Cote MJ, Van Enyde DF, DelliFraine JL, Tucker SL. Computer skills for the next generation of healthcare executives. J Health Adm Educ. Winter. 2005;22(1):29-48. [pmid: 15887847].
582 Cotton SM, Wright A, Harris MG, Jorm AF, McGorry PD. Influence of gender on mental health literacy in young Australians. Aust N Z J Psychiatry. Sep. 2006;40(9):790-6. [pmid: 16911755].
583 Cotugna N, Vickery CE. Health literacy education and training: a student-professional collaboration. J Am Diet Assoc. Jul. 2003;103(7):878-80. [pmid: 12830028].
584 Cotugna N, Vickery CE, Carpenter-Haefele KM. Evaluation of literacy level of patient education pages in health-related journals. J Community Health. Jun. 2005;30(3):213-9. [pmid: 15847246].
585 Coughlin SS, Costanza ME, Fernandez ME, Glanz K, Lee JW, Smith SA, et al. CDC-funded intervention research aimed at promoting colorectal cancer screening in communities. Cancer. Sep. 1. 2006;107(5 Suppl):1196-204. [pmid: 16802326].
586 Couper MP, Singer E. The role of numeracy in informed consent for surveys. J Empir Res Hum Res Ethics. Dec. 2009;4(4):17-26. [pmid: 19919316].
587 Courey T, Benson-Soros J, Deemer K, Zeller RA. The missing link: information literacy and evidence-based practice as a new challenge for nurse educators. Nurs Educ Perspect. Nov-Dec. 2006;27(6):320-3. [pmid: 17256657].
588 Courouble G, Rouet F, Herrmann-Storck C, Nicolas M, Candolfi E, Deloumeaux J, et al. Epidemiologic study of the association between human T-cell lymphotropic virus type 1 and Strongyloides stercoralis infection in female blood donors (Guadeloupe, French West Indies). West Indian Med J. Jan. 2004;53(1):3-6. [pmid: 15114885].
589 Courtney KL, Alexander GL, Demiris G. Information technology from novice to expert: implementation implications. J Nurs Manag. Sep. 2008;16(6):692-9. [pmid: 18808463].
590 Couser GP. Challenges and opportunities for preventing depression in the workplace: a review of the evidence supporting workplace factors and interventions. J Occup Environ Med. Apr. 2008;50(4):411-27. [pmid: 18404014].
591 Covvey HD, Fenton S, Mulholland D, Young K. Making health informatics competencies useful: an applied health informatics competency self-assessment system. Stud Health Technol Inform. 2007;129(Pt 2):1357-61. [pmid: 17911935].
592 Cox CL, Rai SN, Rosenthal D, Phipps S, Hudson MM. Subclinical late cardiac toxicity in childhood cancer survivors: impact on self-reported health. Cancer. Apr. 15. 2008;112(8):1835-44. [pmid: 18311782].
593 Coyne CA, Xu R, Raich P, Plomer K, Dignan M, Wenzel LB, et al. Randomized, controlled trial of an easy-to-read informed consent statement for clinical trial participation: a study of the Eastern Cooperative Oncology Group. J Clin Oncol. Mar. 1. 2003;21(5):836-42. [pmid: 12610182].
594 Cragg CE, Edwards N, Yue Z, Xin SL, Hui ZD. Integrating Web-based technology into distance education for nurses in China: computer and Internet access and attitudes. Comput Inform Nurs. Sep-Oct. 2003;21(5):265-74. [pmid: 14504603].
595 Cragg CE, Humbert J, Doucette S. A toolbox of technical supports for nurses new to Web learning. Comput Inform Nurs. Jan-Feb. 2004;22(1):19-23. quiz 4-5. [pmid: 15069845].
596 Craig A, Blumgart E, Tran Y. The impact of stuttering on the quality of life in adults who stutter. J Fluency Disord. Jun. 2009;34(2):61-71. [pmid: 19686883].
597 Craig A, Corrall S. Making a difference? Measuring the impact of an information literacy programme for pre-registration nursing students in the UK. Health Info Libr J. Jun. 2007;24(2):118-27. [pmid: 17584215].
598 Craig E. Better informed for better health and better care: an information literacy framework to support health care in Scotland. Health Info Libr J. Mar. 2009;26(1):77-80. [pmid: 19245647].
599 Crane PK, Gibbons LE, Jolley L, van Belle G, Selleri R, Dalmonte E, et al. Differential item functioning related to education and age in the Italian version of the Mini-mental State Examination. Int Psychogeriatr. Sep. 2006;18(3):505-15. [pmid: 16478571].
600 Crawford MA. The elimination of child poverty and the pivotal significance of the mother. Nutr Health. 2008;19(3):175-86. [pmid: 19009739].
601 Creedy DK, Mitchell M, Seaton-Sykes P, Cooke M, Patterson E, Purcell C, et al. Evaluating a Web-enhanced bachelor of nursing curriculum: perspectives of third-year students. J Nurs Educ. Oct. 2007;46(10):460-7. [pmid: 17955743].
602 Crisp KM, Jensen M, Moore R. Pros and cons of a group webpage design project in a freshman anatomy and physiology course. Adv Physiol Educ. Dec. 2007;31(4):343-6. [pmid: 18057407].
603 Cross RK, Finkelstein J. Feasibility and acceptance of a home telemanagement system in patients with inflammatory bowel disease: a 6-month pilot study. Dig Dis Sci. Feb. 2007;52(2):357-64. [pmid: 17211702].
604 Cua YM, Kripalani S. Medication use in the transition from hospital to home. Ann Acad Med Singapore. Feb. 2008;37(2):136-6. [pmid: 18327350].
605 Culatta B, Kovarsky D, Theadore G, Franklin A, Timler G. Quantitative and qualitative documentation of early literacy instruction. Am J Speech Lang Pathol. May. 2003;12(2):172-88. [pmid: 12828531].
606 Cunningham AE, Perry KE, Stanovich KE, Stanovich PJ. Disciplinary knowledge of K-3 teachers and their knowledge calibration in the domain of early literacy. Ann Dyslexia. Jun. 2004;54(1):139-67. [pmid: 15765007].
607 Cunningham DJ, Ascher MT, Viola D, Visintainer PF. Baseline assessment of public health informatics competencies in two Hudson Valley health departments. Public Health Rep. May-Jun. 2007;122(3):302-10. [pmid: 17518301].
608 Cunningham-Burley S. Public knowledge and public trust. Community Genet. 2006;9(3):204-10. [pmid: 16741351].
609 Curran C, Sheets D, Kirkpatrick B, Bauldoff GS. Virtual patients support point-of-care nursing education. Nurs Manage. Dec. 2007;38(12):27-33. [pmid: 18188006].
610 Curran CR. Faculty development initiatives for the integration of informatics competencies and point-of-care technologies in undergraduate nursing education. Nurs Clin North Am. Dec. 2008;43(4):523-33. v. [pmid: 18940409].
611 Curtin L. It takes a whole nation … to create a health care system. Nurs Adm Q. Apr-Jun. 2003;27(2):120-7. [pmid: 12765103].
612 Cutilli CC. Do your patients understand? Determining your patients' health literacy skills. Orthop Nurs. Sep-Oct. 2005;24(5):372-7. quiz 8-9. [pmid: 16272918].
613 Cutilli CC. Health literacy: what you need to know. Orthop Nurs. May-Jun. 2005;24(3):227-31. quiz 32-3. [pmid: 15928534].
614 Cutilli CC. Health literacy in geriatric patients: An integrative review of the literature. Orthop Nurs. Jan-Feb. 2007;26(1):43-8. [pmid: 17273109].
615 Cutilli CC, Bennett IM. Understanding the health literacy of America: results of the National Assessment of Adult Literacy. Orthop Nurs. Jan-Feb. 2009;28(1):27-32. quiz 3-4. [pmid: 19190475].
616 Cyhlarova E, Bell JG, Dick JR, Mackinlay EE, Stein JF, Richardson AJ. Membrane fatty acids, reading and spelling in dyslexic and non-dyslexic adults. Eur Neuropsychopharmacol. Jan. 15. 2007;17(2):116-21. [pmid: 16997534].
617 Cykert S. Risk acceptance and risk aversion: patients' perspectives on lung surgery. Thorac Surg Clin. Aug. 2004;14(3):287-93. [pmid: 15382760].
618 Czubek TA. Blue listerine, parochialism, and ASL literacy. J Deaf Stud Deaf Educ. Summer. 2006;11(3):373-81. [pmid: 16556898].
619 Czubek TA, Greenwald J. Understanding Harry Potter: parallels to the deaf world. J Deaf Stud Deaf Educ. Fall. 2005;10(4):442-50. [pmid: 16000691].
620 da Silva CG, Petersson KM, Faisca L, Ingvar M, Reis A. The effects of literacy and education on the quantitative and qualitative aspects of semantic verbal fluency. J Clin Exp Neuropsychol. Apr. 2004;26(2):266-77. [pmid: 15202546].
621 Dabelko HI. A comparative analysis of short stays versus long stays in adult day health care programs. Soc Work Health Care. 2005;42(1):57-71. [pmid: 16236649].
622 Dahl E, Ivar Elstad J, Hofoss D, Martin-Mollard M. For whom is income inequality most harmful? A multi-level analysis of income inequality and mortality in Norway. Soc Sci Med. Nov. 2006;63(10):2562-74. [pmid: 16934916].
623 Dahl LB, Kaaresen PI, Tunby J, Handegard BH, Kvernmo S, Ronning JA. Emotional, behavioral, social, and academic outcomes in adolescents born with very low birth weight. Pediatrics. Aug. 2006;118(2):e449-59. [pmid: 16882786].
624 Dahl M, Kamper J. Physical outcome and school performance of very-low-birthweight infants treated with minimal handling and early nasal CPAP. Acta Paediatr. Sep. 2006;95(9):1099-103. [pmid: 16938757].
625 Dahlberg KM, Waern M, Runeson B. Mental health literacy and attitudes in a Swedish community sample - investigating the role of personal experience of mental health care. BMC Public Health. 2008;8:8. [pmid: 18184424].
626 Dahlgren Sandberg A. Reading and spelling abilities in children with severe speech impairments and cerebral palsy at 6, 9, and 12 years of age in relation to cognitive development: a longitudinal study. Dev Med Child Neurol. Aug. 2006;48(8):629-34. [pmid: 16836773].
627 Dailey R, Schwartz KL, Binienda J, Moorman J, Neale AV. Challenges in making therapeutic lifestyle changes among hypercholesterolemic African-American patients and their physicians. J Natl Med Assoc. Dec. 2006;98(12):1895-903. [pmid: 17225831].
628 D'Alessandro DM. Challenges and options for patient education in the office setting. Pediatr Ann. Feb. 2010;39(2):78-83. [pmid: 20166636].
629 Daley TC, Whaley SE, Sigman MD, Espinosa MP, Neumann C. IQ on the rise: the Flynn effect in rural Kenyan children. Psychol Sci. May. 2003;14(3):215-9. [pmid: 12741743].
630 Daliento L, Mapelli D, Russo G, Scarso P, Limongi F, Iannizzi P, et al. Health related quality of life in adults with repaired tetralogy of Fallot: psychosocial and cognitive outcomes. Heart. Feb. 2005;91(2):213-8. [pmid: 15657236].
631 Dallongeville J, Bringer J, Bruckert E, Charbonnel B, Dievart F, Komajda M, et al. Abdominal obesity is associated with ineffective control of cardiovascular risk factors in primary care in France. Diabetes Metab. Dec. 2008;34(6 Pt 1):606-11. [pmid: 19019717].
632 Dalziel SR, Lim VK, Lambert A, McCarthy D, Parag V, Rodgers A, et al. Psychological functioning and health-related quality of life in adulthood after preterm birth. Dev Med Child Neurol. Aug. 2007;49(8):597-602. [pmid: 17635205].
633 Damus K. Prevention of preterm birth: a renewed national priority. Curr Opin Obstet Gynecol. Dec. 2008;20(6):590-6. [pmid: 18989136].
634 Dangour AD, Allen E, Elbourne D, Fletcher A, Richards M, Uauy R. Fish consumption and cognitive function among older people in the UK: baseline data from the OPAL study. J Nutr Health Aging. Mar. 2009;13(3):198-202. [pmid: 19262951].
635 Dani KA, Stobo DB, Capell HA, Madhok R. Audit of literacy of medical patients in north Glasgow. Scott Med J. May. 2007;52(2):21-4. [pmid: 17536637].
636 Daniel AB, Nagaraj K, Kamath R. Prevalence and determinants of tobacco use in a highly literate rural community in southern India. Natl Med J India. Jul-Aug. 2008;21(4):163-5. [pmid: 19267035].
637 Darbyshire P. ‘Rage against the machine?’: nurses' and midwives' experiences of using Computerized Patient Information Systems for clinical information. J Clin Nurs. Jan. 2004;13(1):17-25. [pmid: 14687289].
638 Darmstadt GL, Kumar V, Shearer JC, Misra R, Mohanty S, Baqui AH, et al. Validation of accuracy and community acceptance of the BIRTHweigh III scale for categorizing newborn weight in rural India. J Perinatol. Oct. 2007;27(10):602-8. [pmid: 17717522].
639 Das DK, Biswas R. Nutritional status of adolescent girls in a rural area of North 24 Parganas district, West Bengal. Indian J Public Health. Jan-Mar. 2005;49(1):18-21. [pmid: 15989155].
640 Das SK, Bose P, Biswas A, Dutt A, Banerjee TK, Hazra AM, et al. An epidemiologic study of mild cognitive impairment in Kolkata, India. Neurology. Jun. 5. 2007;68(23):2019-26. [pmid: 17548552].
641 Date J, Okita K. Gender and literacy: factors related to diagnostic delay and unsuccessful treatment of tuberculosis in the mountainous area of Yemen. Int J Tuberc Lung Dis. Jun. 2005;9(6):680-5. [pmid: 15971397].
642 Dauz E, Moore J, Smith CE, Puno F, Schaag H. Installing computers in older adults' homes and teaching them to access a patient education web site: a systematic approach. Comput Inform Nurs. Sep-Oct. 2004;22(5):266-72. quiz 73-4. [pmid: 15520595].
643 Davids SL, Schapira MM, McAuliffe TL, Nattinger AB. Predictors of pessimistic breast cancer risk perceptions in a primary care population. J Gen Intern Med. Apr. 2004;19(4):310-5. [pmid: 15061739].
644 Davidson DA. Health literacy: adverse implications for patients and physicians. J Med Pract Manage. Jan-Feb. 2004;19(4):207-10. [pmid: 15018369].
645 Davidson JA, Moreno PR, Badimon JJ, Lopez-Candales A, Maisonet Giachello AL, Ovalle F, et al. Cardiovascular disease prevention and care in Latino and Hispanic subjects. Endocr Pract. Jan-Feb. 2007;13(1):77-85. [pmid: 17360307].
646 Davies K. Job hunting in the UK using the Internet: finding your next information professional role in the health care sector and the skills employers require. Health Info Libr J. Jun. 2008;25(2):106-15. [pmid: 18494645].
647 Davis FD, Yi MY. Improving computer skill training: behavior modeling, symbolic mental rehearsal, and the role of knowledge structures. J Appl Psychol. Jun. 2004;89(3):509-23. [pmid: 15161409].
648 Davis J. Occupational therapy students' metaphors for helping. Am J Occup Ther. Mar-Apr. 2008;62(2):242-50. [pmid: 18390018].
649 Davis LJ. Life, death, and biocultural literacy. Chron High Educ. Jan. 6. 2006;52(18):B9-10. [pmid: 16459383].
650 Davis RE, Armstrong DK, Dignan M, Norling GR, Redmond J. Evaluation of educational materials on colorectal cancer screening in Appalachian Kentucky. Prev Chronic Dis. Apr. 2006;3(2):A43. [pmid: 16539784].
651 Davis TC, Fredrickson DD, Potter L, Brouillette R, Bocchini AC, Williams MV, et al. Patient understanding and use of oral contraceptive pills in a southern public health family planning clinic. South Med J. Jul. 2006;99(7):713-8. [pmid: 16866052].
652 Davis TC, Wolf MS, Arnold CL, Byrd RS, Long SW, Springer T, et al. Development and validation of the Rapid Estimate of Adolescent Literacy in Medicine (REALM-Teen): a tool to screen adolescents for below-grade reading in health care settings. Pediatrics. Dec. 2006;118(6):e1707-14. [pmid: 17142495].
653 Davis TC, Wolf MS, Bass PF, Arnold CL, Huang J, Kennen EM, et al. Provider and patient intervention to improve weight loss: a pilot study in a public hospital clinic. Patient Educ Couns. Jul. 2008;72(1):56-62. [pmid: 18346861].
654 Davis TC, Wolf MS, Bass PF 3rd, Middlebrooks M, Kennen E, Baker DW, et al. Low literacy impairs comprehension of prescription drug warning labels. J Gen Intern Med. Aug. 2006;21(8):847-51. [pmid: 16881945].
655 Davis TC, Wolf MS, Bass PF 3rd, Thompson JA, Tilson HH, Neuberger M, et al. Literacy and misunderstanding prescription drug labels. Ann Intern Med. Dec. 19. 2006;145(12):887-94. [pmid: 17135578].
656 Dawn A, Biswas R. Reproductive tract infection: an experience in rural West Bengal. Indian J Public Health. Apr-Jun. 2005;49(2):102-3. [pmid: 16457102].
657 de Albuquerque Mde F, Ximenes RA, Lucena-Silva N, de Souza WV, Dantas AT, Dantas OM, et al. Factors associated with treatment failure, dropout, and death in a cohort of tuberculosis patients in Recife, Pernambuco State, Brazil. Cad Saude Publica. Jul. 2007;23(7):1573-82. [pmid: 17572806].
658 de Amorim Garcia CA, Orefice F, de Oliveira Lyra C, Gomes AB, Franca M, de Amorim Garcia Filho CA. Socioeconomic conditions as determining factors in the prevalence of systemic and ocular toxoplasmosis in Northeastern Brazil. Ophthalmic Epidemiol. Oct. 2004;11(4):301-17. [pmid: 15512992].
659 de Boer MJ, Versteegen GJ, van Wijhe M. Patients' use of the Internet for pain-related medical information. Patient Educ Couns. Sep. 2007;68(1):86-97. [pmid: 17590563].
660 de Cespedes C, Saborio M, Trejos R, Abarca G, Sanchez A, Rojas L. Evolution and innovations of the National Neonatal and High Risk Screening Program in Costa Rica. Rev Biol Trop. Sep. 2004;52(3):451-66. [pmid: 17361538].
661 de Graaff S, Verhoeven L, Bosman AM, Hasselman F. Integrated pictorial mnemonics and stimulus fading: Teaching kindergartners letter sounds. Br J Educ Psychol. Sep. 2007;77(Pt 3):519-39. [pmid: 17908373].
662 De Groote SL, Doranski M. The use of personal digital assistants in the health sciences: results of a survey. J Med Libr Assoc. Jul. 2004;92(3):341-8. [pmid: 15243640].
663 De Groote SL, Dorsch JL. Measuring use patterns of online journals and databases. J Med Libr Assoc. Apr. 2003;91(2):231-40. [pmid: 12883574].
664 de Guia NA, Cohen JE, Ashley MJ, Pederson L, Ferrence R, Bull S, et al. Support for tobacco control policies: how congruent are the attitudes of legislators and the public?. Can J Public Health. Jan-Feb. 2003;94(1):36-40. [pmid: 12583669].
665 de Guise E, Feyz M, LeBlanc J, Richard SL, Lamoureux J. Overview of traumatic brain injury patients at a tertiary trauma centre. Can J Neurol Sci. May. 2005;32(2):186-93. [pmid: 16018153].
666 de Oliveira DF, Arieta CE, Temporini ER, Kara-Jose N. Quality of health care: patient satisfaction in a university hospital. Arq Bras Oftalmol. Sep-Oct. 2006;69(5):731-6. [pmid: 17187144].
667 de Oliveira EA, Hoga LA. The process of seeking and undergoing surgical contraception: an ethnographic study in a Brazilian community. J Transcult Nurs. Jan. 2005;16(1):5-14. [pmid: 15608094].
668 de Vries H. Comment on “Modifiable family and school environmental factors associated with smoking status among adolescents in Guangzhou, China”. Prev Med. Aug-Sep. 2007;45(2-3):119-20. [pmid: 17640722].
669 De Yebenes MJ, Otero A, Zunzunegui MV, Rodriguez-Laso A, Sanchez-Sanchez F, Del Ser T. Validation of a short cognitive tool for the screening of dementia in elderly people with low educational level. Int J Geriatr Psychiatry. Oct. 2003;18(10):925-36. [pmid: 14533125].
670 Deacon SH, Wade-Woolley L, Kirby J. Crossover: the role of morphological awareness in French immersion children's reading. Dev Psychol. May. 2007;43(3):732-46. [pmid: 17484584].
671 Dearnley C, Dunn G, Watson S. An exploration of on-line access by non-traditional students in higher education: a case study. Nurse Educ Today. Jul. 2006;26(5):409-15. [pmid: 16406621].
672 Deater-Deckard K, Petrill SA, Thompson LA. Anger/frustration, task persistence, and conduct problems in childhood: a behavioral genetic analysis. J Child Psychol Psychiatry. Jan. 2007;48(1):80-7. [pmid: 17244273].
673 Debevc M, Peljhan Z. The role of video technology in on-line lectures for the deaf. Disabil Rehabil. Sep. 2. 2004;26(17):1048-59. [pmid: 15371041].
674 Debourgh GA. Predictors of student satisfaction in distance-delivered graduate nursing courses: what matters most?. J Prof Nurs. May-Jun. 2003;19(3):149-63. [pmid: 12836145].
675 Decarlo D, Collingridge DS, Grant C, Ventre KM. Factors influencing nurses' attitudes toward simulation-based education. Simul Healthc. Summer. 2008;3(2):90-6. [pmid: 19088647].
676 DeCastro J, Stone B. Improving therapeutic outcomes in BPH through diagnosis, treatment and patient compliance. Am J Med. Aug. 2008;121(8 Suppl 2):S27-33. [pmid: 18675614].
677 Declau F, Doyen A, Robillard T, de Varebeke SJ. Universal newborn hearing screening. B-Ent. 1. 2005:16-21. quiz 2-3.
678 Dee C, Stanley EE. Information-seeking behavior of nursing students and clinical nurses: implications for health sciences librarians. J Med Libr Assoc. Apr. 2005;93(2):213-22. [pmid: 15858624].
679 Dees RH. Health literacy and autonomy. Am J Bioeth. Nov. 2007;7(11):22-3. discussion W1-2. [pmid: 18027294].
680 Del Prado-Lu JL. Organizational work factors among workers and supervisors in export processing zones which support global markets. Ind Health. Oct. 2008;46(5):435-42. [pmid: 18840932].
681 Delaney C. Nursing and informatics for the 21st century: a conversation with Connie Delaney, PhD, RN, FAAN, FACMI. Interview by Joan Karnas. Creat Nurs. 2007;13(2):4-6. [pmid: 18232581].
682 Delaney C. Facilitating cultural competence and computer literacy in RN-to-BSN. J Nurs Educ. May. 2008;47(5):240. [pmid: 18522158].
683 Dellatolas G, Willadino Braga L, Souza Ldo N, Filho GN, Queiroz E, Deloche G. Cognitive consequences of early phase of literacy. J Int Neuropsychol Soc. Jul. 2003;9(5):771-82. [pmid: 12901783].
684 Delnevo CD, Hrywna M, Foulds J, Steinberg MB. Cigar use before and after a cigarette excise tax increase in New Jersey. Addict Behav. Dec. 2004;29(9):1799-807. [pmid: 15530722].
685 Demiris G, Parker Oliver DR, Courtney KL, Porock D. Use of technology as a support mechanism for caregivers of hospice patients. J Palliat Care. Winter. 2005;21(4):303-9. [pmid: 16483101].
686 Demirkaya E, Ozen S, Turker T, Kuis W, Saurenmann RK. Current educational status of paediatric rheumatology in Europe: the results of PReS survey. Clin Exp Rheumatol. Jul-Aug. 2009;27(4):685-90. [pmid: 19772807].
687 Denne M, Langdown N, Pring T, Roy P. Treating children with expressive phonological disorders: does phonological awareness therapy work in the clinic?. Int J Lang Commun Disord. Oct-Dec. 2005;40(4):493-504. [pmid: 16195202].
688 Dennis M, Barnes M. Math and numeracy in young adults with spina bifida and hydrocephalus. Dev Neuropsychol. 2002;21(2):141-55. [pmid: 12139196].
689 Depp CA, Davis CE, Mittal D, Patterson TL, Jeste DV. Health-related quality of life and functioning of middle-aged and elderly adults with bipolar disorder. J Clin Psychiatry. Feb. 2006;67(2):215-21. [pmid: 16566616].
690 Depp CA, Jeste DV. Definitions and predictors of successful aging: a comprehensive review of larger quantitative studies. Am J Geriatr Psychiatry. Jan. 2006;14(1):6-20. [pmid: 16407577].
691 Derrick CG, Miller JS, Andrews JM. A fish consumption study of anglers in an at-risk community: a community-based participatory approach to risk reduction. Public Health Nurs. Jul-Aug. 2008;25(4):312-8. [pmid: 18666936].
692 Descheemaeker MJ, Ghesquiere P, Symons H, Fryns JP, Legius E. Behavioural, academic and neuropsychological profile of normally gifted Neurofibromatosis type 1 children. J Intellect Disabil Res. Jan. 2005;49(Pt 1):33-46. [pmid: 15634310].
693 DesJardin JL, Ambrose SE, Eisenberg LS. Literacy skills in children with cochlear implants: the importance of early oral language and joint storybook reading. J Deaf Stud Deaf Educ. Winter. 2009;14(1):22-43. [pmid: 18417463].
694 Devaney A, Outhwaite H. Learning resource needs of UK NHS support staff. Health Info Libr J. Dec. 2005;22(4):253-61. [pmid: 16293167].
695 Devereux J. Nursing. Low health literacy: a covert barrier to patient self-management. HIV Clin. Winter. 2004;16(1):12-4. [pmid: 15052990].
696 Devieux JG, Malow RM, Rosenberg R, Jean-Gilles M, Samuels D, Ergon-Perez E, et al. Cultural adaptation in translational research: field experiences. J Urban Health. Jun. 2005;82(2 Suppl 3):iii82-91. [pmid: 15933334].
697 Devitt N, Murphy J. A survey of the information management and technology training needs of doctors in an acute NHS trust in the United Kingdom. Health Info Libr J. Sep. 2004;21(3):164-72. [pmid: 15318914].
698 Devraj R, Gordon EJ. Health literacy and kidney disease: toward a new line of research. Am J Kidney Dis. May. 2009;53(5):884-9. [pmid: 19324481].
699 DeWalt DA. Low health literacy: epidemiology and interventions. N C Med J. Sep-Oct. 2007;68(5):327-30. [pmid: 18183751].
700 Dewalt DA, Berkman ND, Sheridan S, Lohr KN, Pignone MP. Literacy and health outcomes: a systematic review of the literature. J Gen Intern Med. Dec. 2004;19(12):1228-39. [pmid: 15610334].
701 DeWalt DA, Boone RS, Pignone MP. Literacy and its relationship with self-efficacy, trust, and participation in medical decision making. Am J Health Behav. Sep-Oct. 1. 2007;31:S27-35. [pmid: 17931133].
702 DeWalt DA, Dilling MH, Rosenthal MS, Pignone MP. Low parental literacy is associated with worse asthma care measures in children. Ambul Pediatr. Jan-Feb. 2007;7(1):25-31. [pmid: 17261479].
703 DeWalt DA, Hink A. Health literacy and child health outcomes: a systematic review of the literature. Pediatrics. Nov. 3. 2009;124:S265-74. [pmid: 19861480].
704 DeWalt DA, Malone RM, Bryant ME, Kosnar MC, Corr KE, Rothman RL, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. 2006;6:30. [pmid: 16533388].
705 DeWalt DA, Pignone M, Malone R, Rawls C, Kosnar MC, George G, et al. Development and pilot testing of a disease management program for low literacy patients with heart failure. Patient Educ Couns. Oct. 2004;55(1):78-86. [pmid: 15476993].
706 Dhaliwal G, Chou CL. A brief educational intervention in personal finance for medical residents. J Gen Intern Med. Mar. 2007;22(3):374-7. [pmid: 17356971].
707 Di Mario S, Say L, Lincetto O. Risk factors for stillbirth in developing countries: a systematic review of the literature. Sex Transm Dis. Jul. 2007;34(7 Suppl):S11-21. [pmid: 17592385].
708 Diamond F. Docs and insurers work to advance health literacy. Manag Care. Oct. 2009;18(10):39-40. [pmid: 19902688].
709 Diamond JJ. Development of a reliable and construct valid measure of nutritional literacy in adults. Nutr J. 2007;6:5. [pmid: 17300716].
710 Dibartolo MC, McCrone S. Recruitment of rural community-dwelling older adults: barriers, challenges, and strategies. Aging Ment Health. Mar. 2003;7(2):75-82. [pmid: 12745386].
711 Dickerson SS. Women's use of the Internet: what nurses need to know. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2006;35(1):151-6.
712 Dickerson SS, Boehmke M, Ogle C, Brown JK. Out of necessity: oncology nurses' experiences integrating the internet into practice. Oncol Nurs Forum. Mar. 2005;32(2):355-62. [pmid: 15759072].
713 Dieckmann P, Gaba D, Rall M. Deepening the theoretical foundations of patient simulation as social practice. Simul Healthc. Fall. 2007;2(3):183-93. [pmid: 19088622].
714 Diefenbach MA, Butz BP. A multimedia interactive education system for prostate cancer patients: development and preliminary evaluation. J Med Internet Res. Jan. 21. 2004;6(1):e3. [pmid: 15111269].
715 Diehl SJ. Incorporating health literacy into adult basic education: from life skills to life saving. N C Med J. Sep-Oct. 2007;68(5):336-9. [pmid: 18183754].
716 Dike N, Onwujekwe O, Ojukwu J, Ikeme A, Uzochukwu B, Shu E. Influence of education and knowledge on perceptions and practices to control malaria in Southeast Nigeria. Soc Sci Med. Jul. 2006;63(1):103-6. [pmid: 16448735].
717 Dillon TW, Blankenship R, Crews T Jr. Nursing attitudes and images of electronic patient record systems. Comput Inform Nurs. May-Jun. 2005;23(3):139-45. [pmid: 15900171].
718 Dillon TW, Lending D, Crews TR 2nd, Blankenship R. Nursing self-efficacy of an integrated clinical and administrative information system. Comput Inform Nurs. Jul-Aug. 2003;21(4):198-205. [pmid: 12869873].
719 Dilworth TJ, Mott D, Young H. Pharmacists' communication with Spanish-speaking patients: a review of the literature to establish an agenda for future research. Res Social Adm Pharm. Jun. 2009;5(2):108-20. [pmid: 19524859].
720 Dimarco C, Bray P, Covvey HD, Cowan DD, Diciccio V, Hovy E, et al. Authoring and generation of individualized patient education materials. AMIA Annu Symp Proc. 2006:195-9.
721 DiMaria-Ghalili RA, Ostrow L, Rodney K. Webcasting: a new instructional technology in distance graduate nursing education. J Nurs Educ. Jan. 2005;44(1):11-8. [pmid: 15673169].
722 DiMatteo MR. Variations in patients' adherence to medical recommendations: a quantitative review of 50 years of research. Med Care. Mar. 2004;42(3):200-9. [pmid: 15076819].
723 Divaris K, Polychronopoulou A, Mattheos N. An investigation of computer literacy and attitudes amongst Greek post-graduate dental students. Eur J Dent Educ. Aug. 2007;11(3):144-7. [pmid: 17640257].
724 Dodani S, Mistry R, Khwaja A, Farooqi M, Qureshi R, Kazmi K. Prevalence and awareness of risk factors and behaviours of coronary heart disease in an urban population of Karachi, the largest city of Pakistan: a community survey. J Public Health (Oxf). Sep. 2004;26(3):245-9. [pmid: 15454591].
725 Dodge KA. Risk and protection in the perpetration of child abuse. N C Med J. Sep-Oct. 2005;66(5):364-6. [pmid: 16323584].
726 Dogan MC, Seydaoglu G, Uguz S, Inanc BY. The effect of age, gender and socioeconomic factors on perceived dental anxiety determined by a modified scale in children. Oral Health Prev Dent. 2006;4(4):235-41. [pmid: 17153645].
727 Dolan NC, Ferreira MR, Davis TC, Fitzgibbon ML, Rademaker A, Liu D, et al. Colorectal cancer screening knowledge, attitudes, and beliefs among veterans: does literacy make a difference?. J Clin Oncol. Jul. 1. 2004;22(13):2617-22. [pmid: 15226329].
728 Donelle L, Arocha JF, Hoffman-Goetz L. Health literacy and numeracy: key factors in cancer risk comprehension. Chronic Dis Can. 2008;29(1):1-8. [pmid: 19036218].
729 Donelle L, Hoffman-Goetz L. An exploratory study of canadian aboriginal online health care forums. Health Commun. 2008;23(3):270-81. [pmid: 18569056].
730 Donelle L, Hoffman-Goetz L. Health literacy and online health discussions of North American Black women. Women Health. 2008;47(4):71-90. [pmid: 18843941].
731 Donelle L, Hoffman-Goetz L. Functional health literacy and cancer care conversations in online forums for retired persons. Inform Health Soc Care. Jan. 2009;34(1):59-72. [pmid: 19306200].
732 Donelle L, Hoffman-Goetz L, Arocha JF. Assessing health numeracy among community-dwelling older adults. J Health Commun. Oct-Nov. 2007;12(7):651-65. [pmid: 17934942].
733 Donelle L, Hoffman-Goetz L, Clarke JN. Portrayal of genetic risk for breast cancer in ethnic and non-ethnic newspapers. Women Health. 2004;40(4):93-111. [pmid: 15911512].
734 Donlan C, Bishop DV, Hitch GJ. Magnitude comparisons by children with specific language impairments: evidence of unimpaired symbolic processing. Int J Lang Commun Disord. Apr-Jun. 1998;33(2):149-60. [pmid: 9709434].
735 Donnelly G. A budget model to determine the financial health of nursing education programs in academic institutions. Nurs Leadersh Forum. Summer. 2005;9(4):143-7. [pmid: 16259099].
736 Donovan OM. The Carbohydrate Quandary: achieving health literacy through an interdisciplinary WebQuest. J Sch Health. Nov. 2005;75(9):359-62. [pmid: 16255722].
737 Dore MP, Maragkoudakis E, Fraley K, Pedroni A, Tadeu V, Realdi G, et al. Diet, lifestyle and gender in gastro-esophageal reflux disease. Dig Dis Sci. Aug. 2008;53(8):2027-32. [pmid: 18030622].
738 Dormandy E, Tsui EY, Marteau TM. Development of a measure of informed choice suitable for use in low literacy populations. Patient Educ Couns. Jun. 2007;66(3):278-95. [pmid: 17300913].
739 Dotson VM, Kitner-Triolo M, Evans MK, Zonderman AB. Literacy-based normative data for low socioeconomic status African Americans. Clin Neuropsychol. Dec. 2008;22(6):989-1017. [pmid: 18609322].
740 Dougall A, Fiske J. Access to special care dentistry, part 3. Consent and capacity. Br Dent J. Jul. 26. 2008;205(2):71-81. [pmid: 18660768].
741 Douglas GP, Killam WP, Hochgesang MS, Deula RA, Limbe W, Davis MK. Improving completeness, accuracy & timeliness of HIV voluntary counseling & testing client data in Malawi using touchscreen computers. AMIA Annu Symp Proc. 2005:942.
742 Downey LV, Zun L. Testing of a verbal assessment tool of English proficiency for use in the healthcare setting. J Natl Med Assoc. Jul. 2007;99(7):795-8. [pmid: 17668646].
743 Downey LV, Zun LS. Assessing adult health literacy in urban healthcare settings. J Natl Med Assoc. Nov. 2008;100(11):1304-8. [pmid: 19024227].
744 Dowrick PW. Community-driven learning activities, creating futures: 30,000 people can't be wrong - can they?. Am J Community Psychol. Mar. 2007;39(1-2):13-9. [pmid: 17437187].
745 Dowrick PW, Yuen JW. Literacy for the community, by the community. J Prev Interv Community. 2006;32(1-2):81-96. [pmid: 17000603].
746 Doyle AE, Wilens TE, Kwon A, Seidman LJ, Faraone SV, Fried R, et al. Neuropsychological functioning in youth with bipolar disorder. Biol Psychiatry. Oct. 1. 2005;58(7):540-8. [pmid: 16199011].
747 Dragon N. Leaving the paper trail behind. Aust Nurs J. Jul. 2008;16(1):22-5. [pmid: 18727263].
748 Dragovic M, Waters FA, Jablensky A. Estimating premorbid intelligence in schizophrenia patients: demographically based approach. Aust N Z J Psychiatry. Sep. 2008;42(9):814-8. [pmid: 18696286].
749 Drainoni ML, Rajabiun S, Rumptz M, Welles SL, Relf M, Rebholz C, et al. Health literacy of HIV-positive individuals enrolled in an outreach intervention: results of a cross-site analysis. J Health Commun. Apr-May. 2008;13(3):287-302. [pmid: 18569359].
750 Drake BE, Keane TE, Mosley CM, Adams SA, Elder KT, Modayil MV, et al. Prostate cancer disparities in South Carolina: early detection, special programs, and descriptive epidemiology. J S C Med Assoc. Aug. 2006;102(7):241-9. [pmid: 17319238].
751 Drewnowski A. The real contribution of added sugars and fats to obesity. Epidemiol Rev. 2007;29:160-71. [pmid: 17591599].
752 Driscoll A, Davidson P, Clark R, Huang N, Aho Z. Tailoring consumer resources to enhance self-care in chronic heart failure. Aust Crit Care. Aug. 2009;22(3):133-40. [pmid: 19581110].
753 Du H, Valenzuela V, Diaz P, Cella D, Hahn EA. Factors affecting enrollment in literacy studies for English- and Spanish-speaking cancer patients. Stat Med. Sep. 10. 2008;27(20):4119-31. [pmid: 18381706].
754 Dubow J. Adequate literacy and health literacy: prerequisites for informed health care decision making. Issue Brief (Public Policy Inst (Am Assoc Retired Pers)). Jun. 2004;(IB70):1-11. [pmid: 15243980].
755 Duggan A. Understanding interpersonal communication processes across health contexts: advances in the last decade and challenges for the next decade. J Health Commun. 2006;11(1):93-108. [pmid: 16546921].
756 Duke R. Easy as ABC? Low literacy rates in Arkansas are causing problems with health care. J Ark Med Soc. Apr. 2004;100(10):345-7. [pmid: 15080274].
757 Dumitru RC, Burkle T, Potapov S, Lausen B, Wiese B, Prokosch HU. Use and perception of internet for health related purposes in Germany: results of a national survey. Int J Public Health. 2007;52(5):275-85. [pmid: 18030943].
758 Dumont S, Turgeon J, Allard P, Gagnon P, Charbonneau C, Vezina L. Caring for a loved one with advanced cancer: determinants of psychological distress in family caregivers. J Palliat Med. Aug. 2006;9(4):912-21. [pmid: 16910806].
759 Duncan LG, Cole P, Seymour PH, Magnan A. Differing sequences of metaphonological development in French and English. J Child Lang. May. 2006;33(2):369-99. [pmid: 16826831].
760 Duncan P, Aref-Adib G, Venn A, Britton J, Davey G. Use and misuse of aspirin in rural Ethiopia. East Afr Med J. Jan. 2006;83(1):31-6. [pmid: 16642748].
761 Dunckley M, Hkughes R, Addington-Hall JM, Higginson IJ. Translating clinical tools in nursing practice. J Adv Nurs. Nov. 2003;44(4):420-6. [pmid: 14651714].
762 Dussault M, Deaudelin C, Brodeur M. Teachers' instructional efficacy and teachers' efficacy toward integration of information technologies in the classroom. Psychol Rep. Jun. 2004;94(3 Pt 2):1375-81. [pmid: 15362419].
763 Dutta-Bergman M. Trusted online sources of health information: differences in demographics, health beliefs, and health-information orientation. J Med Internet Res. Jul-Sep. 2003;5(3):e21. [pmid: 14517112].
764 Dwight-Johnson M, Lagomasino IT, Aisenberg E, Hay J. Using conjoint analysis to assess depression treatment preferences among low-income Latinos. Psychiatr Serv. Aug. 2004;55(8):934-6. [pmid: 15292545].
765 Dykstra BA. What is your excuse (for not implementing digital technologies into your practice)?. Dent Today. May. 118. 2006;25(5):20-1.
766 Easterbrooks SR, Stephenson B. An examination of twenty literacy, science, and mathematics practices used to educate students who are deaf or hard of hearing. Am Ann Deaf. Fall. 2006;151(4):385-97. [pmid: 17225633].
767 Easterbrooks SR, Stephenson B, Mertens D. Master teachers' responses to twenty literacy and science/mathematics practices in deaf education. Am Ann Deaf. Fall. 2006;151(4):398-409. [pmid: 17225634].
768 Echebarria-Echabe A, Guede EF. Extending the theory of realistic conflict to competition in institutional settings: intergroup status and outcome. J Soc Psychol. Dec. 2003;143(6):763-82. [pmid: 14658750].
769 Echeverry D, Dike M, Jovanovic L, Wollitzer AO, Westphal S, Mudaliar S, et al. Efforts to improve subsequent treatment of cardiovascular risk factors in older patients with diabetes hospitalized for a cardiac event. Am J Manag Care. Dec. 2005;11(12):758-64. [pmid: 16336059].
770 Echeverry DM, Dike MR, Washington C, Davidson MB. The impact of using a low-literacy patient education tool on process measures of diabetes care in a minority population. J Natl Med Assoc. Nov. 2003;95(11):1074-81. [pmid: 14651374].
771 Echouffo-Tcheugui JB, Simmons RK, Williams KM, Barling RS, Prevost AT, Kinmonth AL, et al. The ADDITION-Cambridge trial protocol: a cluster --randomised controlled trial of screening for type 2 diabetes and intensive treatment for screen-detected patients. BMC Public Health. 2009;9:136. [pmid: 19435491].
772 Eden A, Pizov R, Toderis L, Kantor G, Perel A. The impact of an electronic reminder on the use of alarms after separation from cardiopulmonary bypass. Anesth Analg. Apr. 2009;108(4):1203-8. [pmid: 19299787].
773 Edwards PD, Bonilla ZE. The use of Spanish language educational materials by American cleft palate-craniofacial association teams. Cleft Palate Craniofac J. Nov. 2004;41(6):655-60. [pmid: 15516171].
774 Edwards S, Nebel S, Heinrich M. Questionnaire surveys: methodological and epistemological problems for field-based ethnopharmacologists. J Ethnopharmacol. Aug. 22. 2005;100(1-2):30-6. [pmid: 16009518].
775 Egri M, Gunay O. Association between some educational indicators and dental caries experience of 12-year-old children in developing countries: an ecological approach. Community Dent Health. Sep. 2004;21(3):227-9. [pmid: 15470834].
776 Eikemo TA, Bambra C, Joyce K, Dahl E. Welfare state regimes and income-related health inequalities: a comparison of 23 European countries. Eur J Public Health. Dec. 2008;18(6):593-9. [pmid: 18927186].
777 Eiser AR, Ellis G. Viewpoint: Cultural competence and the African American experience with health care: The case for specific content in cross-cultural education. Acad Med. Feb. 2007;82(2):176-83. [pmid: 17264697].
778 Eke N, Nkananginieme KE. Neologisms in medical practice: their potential to be ‘useful’, ‘useless’ or ‘misleading’. Niger J Med. Jul-Sep. 2005;14(3):311-4. [pmid: 16350705].
779 El Tantawi MM, Saleh SM. Attitudes of dental students towards using computers in education--a mixed design study. East Mediterr Health J. May-Jun. 2008;14(3):675-85. [pmid: 18720632].
780 El-Ibiary SY, Youmans SL. Health literacy and contraception: a readability evaluation of contraceptive instructions for condoms, spermicides and emergency contraception in the USA. Eur J Contracept Reprod Health Care. Mar. 2007;12(1):58-62. [pmid: 17455046].
781 Elkins J. Learning disabilities: bringing fields and nations together. J Learn Disabil. Sep-Oct. 2007;40(5):392-9. [pmid: 17915493].
782 Elliott C, Farmer K. Immunization status of children under 7 years in the Vikas Nagar area, North India. Child Care Health Dev. Jul. 2006;32(4):415-21. [pmid: 16784497].
783 Elliott JO, Charyton C, Long L. A health literacy assessment of the National Epilepsy Foundation Web site. Epilepsy Behav. Dec. 2007;11(4):525-32. [pmid: 17923440].
784 Elliott JO, Shneker BF. A health literacy assessment of the epilepsy.com website. Seizure. Jul. 2009;18(6):434-9. [pmid: 19419887].
785 Ellis-Danquah LV. Addressing health disparities: African American consumer information resources on the web. Med Ref Serv Q. Winter. 2004;23(4):61-73. [pmid: 15778183].
786 Eloundou-Enyegue PM. Pregnancy-related dropouts and gender inequality in education: a life-table approach and application to Cameroon. Demography. Aug. 2004;41(3):509-28. [pmid: 15461012].
787 Elstad JI, Dahl E, Hofoss D. Associations between relative income and mortality in Norway: a register-based study. Eur J Public Health. Dec. 2006;16(6):640-4. [pmid: 16476681].
788 Elwyn G, Edwards A, Hood K, Robling M, Atwell C, Russell I, et al. Achieving involvement: process outcomes from a cluster randomized trial of shared decision making skill development and use of risk communication aids in general practice. Fam Pract. Aug. 2004;21(4):337-46. [pmid: 15249520].
789 Enders SR, Paterniti DA, Meyers FJ. An approach to develop effective health care decision making for women in prison. J Palliat Med. Apr. 2005;8(2):432-9. [pmid: 15890054].
790 Endres LK, Sharp LK, Haney E, Dooley SL. Health literacy and pregnancy preparedness in pregestational diabetes. Diabetes Care. Feb. 2004;27(2):331-4. [pmid: 14747209].
791 Erath AS, Larkin VM. Making distance education accessible for students who are deaf and hard-of-hearing. Assist Technol. Winter. 2004;16(2):116-23. [pmid: 15566044].
792 Erby LH, Roter D, Larson S, Cho J. The rapid estimate of adult literacy in genetics (REAL-G): a means to assess literacy deficits in the context of genetics. Am J Med Genet A. Jan. 15. 2008;146A(2):174-81. [pmid: 18076116].
793 Erickson KA, Hatton D. Literacy and visual impairment. Semin Speech Lang. Feb. 2007;28(1):58-68. [pmid: 17340383].
794 Erlen JA. Functional health illiteracy. Ethical concerns. Orthop Nurs. Mar-Apr. 2004;23(2):150-3. [pmid: 15103803].
795 Escobar-Chaves SL, Tortolero SR, Markham CM, Low BJ, Eitel P, Thickstun P. Impact of the media on adolescent sexual attitudes and behaviors. Pediatrics. Jul. 2005;116(1):303-26. [pmid: 16001458].
796 Eser E, Dinc G, Oral AM, Ozcan C. Contrasting children and women's health and the determinants of health in a small-sized city. J Urban Health. Dec. 2005;82(4):666-81. [pmid: 16195473].
797 Esgate A, Flynn M. The brain-sex theory of occupational choice: a counterexample. Percept Mot Skills. Feb. 2005;100(1):25-37. [pmid: 15773689].
798 Eshet-Alkali Y, Amichai-Hamburger Y. Experiments in digital literacy. Cyberpsychol Behav. Aug. 2004;7(4):421-9. [pmid: 15331029].
799 Esperat MC, Feng D, Zhang Y, Masten Y, Allcorn S, Velten L, et al. Transformation for health: a framework for conceptualizing health behaviors in vulnerable populations. Nurs Clin North Am. Sep. 2008;43(3):381-95. viii. ix. [pmid: 18674671].
800 Estape T, Estape J, Grau JJ, Ferrer C. Cancer knowledge among Spanish women participating in literacy schemes. Psychooncology. Mar. 2003;12(2):194-7. [pmid: 12619151].
801 Estrada CA, Martin-Hryniewicz M, Peek BT, Collins C, Byrd JC. Literacy and numeracy skills and anticoagulation control. Am J Med Sci. Aug. 2004;328(2):88-93. [pmid: 15311167].
802 Evangelista LS, Shinnick MA. What do we know about adherence and self-care?. J Cardiovasc Nurs. May-Jun. 2008;23(3):250-7. [pmid: 18437067].
803 Evangelista LS, Stromberg A, Westlake C, Ter-Galstanyan A, Anderson N, Dracup K. Developing a Web-based education and counseling program for heart failure patients. Prog Cardiovasc Nurs. Fall. 2006;21(4):196-201. [pmid: 17170595].
804 Evans AE, Dave J, Tanner A, Duhe S, Condrasky M, Wilson D, et al. Changing the home nutrition environment: effects of a nutrition and media literacy pilot intervention. Fam Community Health. Jan-Mar. 2006;29(1):43-54. [pmid: 16340677].
805 Evans CE, Kemish K, Turnbull OH. Paradoxical effects of education on the Iowa Gambling Task. Brain Cogn. Apr. 2004;54(3):240-4. [pmid: 15050783].
806 Evans CJ. Literacy development in deaf students: case studies in bilingual teaching and learning. Am Ann Deaf. Spring. 2004;149(1):17-27. [pmid: 15332463].
807 Evans T. Why health literacy matters. Iowa Med. Nov-Dec. 2003;93(6):6.
808 Everatt J, Weeks S, Brooks P. Profiles of strengths and weaknesses in dyslexia and other learning difficulties. Dyslexia. Feb. 2008;14(1):16-41. [pmid: 17659648].
809 Extermann M, Chen H, Booth-Jones M, Meyer J, Balducci L, Jacobsen P. Pilot testing of the computerized cognitive test Microcog in chemotherapy-treated older cancer patients. Crit Rev Oncol Hematol. May. 2005;54(2):137-43. [pmid: 15843096].
810 Fageeh NA. Prospective study of hearing loss in schools for deaf children in Assir region, Saudi Arabia. West Afr J Med. Dec. 2003;22(4):321-3. [pmid: 15008297].
811 Fagerlin A, Ubel PA, Smith DM, Zikmund-Fisher BJ. Making numbers matter: present and future research in risk communication. Am J Health Behav. Sep-Oct. 1. 2007;31:S47-56. [pmid: 17931136].
812 Fagerlin A, Wang C, Ubel PA. Reducing the influence of anecdotal reasoning on people's health care decisions: is a picture worth a thousand statistics?. Med Decis Making. Jul-Aug. 2005;25(4):398-405. [pmid: 16061891].
813 Fagerlin A, Zikmund-Fisher BJ, Ubel PA, Jankovic A, Derry HA, Smith DM. Measuring numeracy without a math test: development of the Subjective Numeracy Scale. Med Decis Making. Sep-Oct. 2007;27(5):672-80. [pmid: 17641137].
814 Faguy K. Health literacy. Radiol Technol. Nov-Dec. 2004;76(2):139-46. quiz 47-9. [pmid: 15587616].
815 Fajewonyomi BA, Orji EO, Adeyemo AO. Sexual dysfunction among female patients of reproductive age in a hospital setting in Nigeria. J Health Popul Nutr. Mar. 2007;25(1):101-6. [pmid: 17615910].
816 Fallon KA, Katz LA. Augmentative and alternative communication and literacy teams: facing the challenges, forging ahead. Semin Speech Lang. May. 2008;29(2):112-9. [pmid: 18645913].
817 Familoni OB, Ariba AJ. Ability of Nigerian hypertensive patients to perceive changes in their blood pressure. Cardiovasc J S Afr. Jul-Aug. 2003;14(4):195-8. [pmid: 14532961].
818 Fang MC, Machtinger EL, Wang F, Schillinger D. Health literacy and anticoagulation-related outcomes among patients taking warfarin. J Gen Intern Med. Aug. 2006;21(8):841-6. [pmid: 16881944].
819 Fantahun M, Berhane Y, Hogberg U, Wall S, Byass P. Young adult and middle age mortality in Butajira demographic surveillance site, Ethiopia: lifestyle, gender and household economy. BMC Public Health. 2008;8:268. [pmid: 18671854].
820 Faragher R, Brown RI. Numeracy for adults with Down syndrome: it's a matter of quality of life. J Intellect Disabil Res. Oct. 2005;49(Pt 10):761-5. [pmid: 16162123].
821 Farrell MH, Kuruvilla P. Assessment of parental understanding by pediatric residents during counseling after newborn genetic screening. Arch Pediatr Adolesc Med. Mar. 2008;162(3):199-204. [pmid: 18316655].
822 Farrell MJ, Rose L. Use of mobile handheld computers in clinical nursing education. J Nurs Educ. Jan. 2008;47(1):13-9. [pmid: 18232610].
823 Farrer L, Leach L, Griffiths KM, Christensen H, Jorm AF. Age differences in mental health literacy. BMC Public Health. 2008;8:125. [pmid: 18423049].
824 Farris KB, Phillips BB. Instruments assessing capacity to manage medications. Ann Pharmacother. Jul. 2008;42(7):1026-36. [pmid: 18594054].
825 Farver JM, Nakamoto J, Lonigan CJ. Assessing preschoolers' emergent literacy skills in English and Spanish with the Get Ready to Read! screening tool. Ann Dyslexia. Dec. 2007;57(2):161-78. [pmid: 18008165].
826 Favre R, Duchange N, Vayssiere C, Kohler M, Bouffard N, Hunsinger MC, et al. How important is consent in maternal serum screening for Down syndrome in France? Information and consent evaluation in maternal serum screening for Down syndrome: a French study. Prenat Diagn. Mar. 2007;27(3):197-205. [pmid: 17238219].
827 Fawcett AJ. The International Adult Literacy Survey in Britain: impact on policy and practice. Dyslexia. May. 2003;9(2):99-121. [pmid: 12775083].
828 Federman AD, Sano M, Wolf MS, Siu AL, Halm EA. Health literacy and cognitive performance in older adults. J Am Geriatr Soc. Aug. 2009;57(8):1475-80. [pmid: 19515101].
829 Fei M, Qu YC, Wang T, Yin J, Bai JX, Ding QH. Prevalence and distribution of cognitive impairment no dementia (CIND) among the aged population and the analysis of socio-demographic characteristics: the community-based cross-sectional study. Alzheimer Dis Assoc Disord. Apr-Jun. 2009;23(2):130-8. [pmid: 19474570].
830 Feifer R. How a few simple words improve patients' health. Manag Care Q. Spring. 2003;11(2):29-31. [pmid: 12968440].
831 Feinberg E, Smith MV, Morales MJ, Claussen AH, Smith DC, Perou R. Improving women's health during internatal periods: developing an evidenced-based approach to addressing maternal depression in pediatric settings. J Womens Health (Larchmt). Jul-Aug. 2006;15(6):692-703. [pmid: 16910901].
832 Fekede B, GM A. Antenatal care services utilization and factors associated in Jimma Town (south west Ethiopia). Ethiop Med J. Apr. 2007;45(2):123-33. [pmid: 17642168].
833 Feldblum I, German L, Castel H, Harman-Boehm I, Bilenko N, Eisinger M, et al. Characteristics of undernourished older medical patients and the identification of predictors for undernutrition status. Nutr J. 2007;6:37. [pmid: 17980023].
834 Feldman-Stewart D, Brundage MD, Siemens R, Skarsgard D. A randomized controlled trial comparing two educational booklets on prostate cancer. The Canadian journal of urology. Dec. 2006;13(6):3321-6. [pmid: 17187695].
835 Ferguson B. Health literacy and health disparities: the role they play in maternal and child health. Nurs Womens Health. Aug. 2008;12(4):286-98. [pmid: 18715376].
836 Fernandes N, Bastos MG, Cassi HV, Machado NL, Ribeiro JA, Martins G, et al. The Brazilian Peritoneal Dialysis Multicenter Study (BRAZPD) : characterization of the cohort. Kidney Int Suppl. Apr. 2008;(108):S145-51. [pmid: 18379538].
837 Ferreira MR, Dolan NC, Fitzgibbon ML, Davis TC, Gorby N, Ladewski L, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
838 Ferrell DK, DeBord CL. Make computer-based training user-friendly. Nurs Manage. Oct. 2003;(Suppl):30-1. [pmid: 14574185].
839 Fetter MS. Curriculum strategies to improve baccalaureate nursing information technology outcomes. J Nurs Educ. Feb. 2009;48(2):78-85. [pmid: 19260399].
840 Fetter MS. Graduating nurses' self-evaluation of information technology competencies. J Nurs Educ. Feb. 2009;48(2):86-90. [pmid: 19260400].
841 Fetter MS. Health information literacy and mental health nursing. Issues Ment Health Nurs. Jan. 2009;30(1):64-5. [pmid: 19148825].
842 Fetter MS. Improving information technology competencies: implications for psychiatric mental health nursing. Issues Ment Health Nurs. Jan. 2009;30(1):3-13. [pmid: 19148816].
843 Fetter MS. Promoting health literacy with vulnerable behavioral health clients. Issues Ment Health Nurs. Dec. 2009;30(12):798-802. [pmid: 19916815].
844 Findling RL, Short EJ, Leskovec T, Townsend LD, Demeter CA, McNamara NK, et al. Aripiprazole in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. Aug. 2008;18(4):347-54. [pmid: 18759644].
845 Finger RP. Cataracts in India: current situation, access, and barriers to services over time. Ophthalmic Epidemiol. May-Jun. 2007;14(3):112-8. [pmid: 17613845].
846 Firestone DN, Jimenez-Briceno L, Reimann JO, Talavera GA, Polonsky WH, Edelman SV. Predictors of diabetes-specific knowledge and treatment satisfaction among Costa Ricans. Diabetes Educ. Mar-Apr. 2004;30(2):281-92. [pmid: 15095518].
847 Fisberg RM, Morimoto JM, Slater B, Barros MB, Carandina L, Goldbaum M, et al. Dietary quality and associated factors among adults living in the state of Sao Paulo, Brazil. J Am Diet Assoc. Dec. 2006;106(12):2067-72. [pmid: 17126640].
848 Fish TR, Rabidoux P, Ober J, Graff VL. Community literacy and friendship model for people with intellectual disabilities. Ment Retard. Dec. 2006;44(6):443-6. [pmid: 17132040].
849 Fisher JR, Hammarberg K, Baker GH. Antenatal mood and fetal attachment after assisted conception. Fertil Steril. May. 2008;89(5):1103-12. [pmid: 17706213].
850 Fisher KM, Copenhaver V. Assessing the mental health of rural older adults in public housing facilities: a comparison of screening tools. J Gerontol Nurs. Sep. 2006;32(9):26-33. [pmid: 16972606].
851 Fiske A, Gatz M. The Apartment Test: validity of a memory measure. Neuropsychol Dev Cogn B Aging Neuropsychol Cogn. Sep. 2007;14(5):441-61. [pmid: 17828623].
852 Fitzgerald N. Health literacy and your practice. Mich Med. Jan-Feb. 2005;104(1):22. [pmid: 15751381].
853 Fivush R, Haden CA, Reese E. Elaborating on elaborations: role of maternal reminiscing style in cognitive and socioemotional development. Child Dev. Nov-Dec. 2006;77(6):1568-88. [pmid: 17107447].
854 Flaming D. Orality to literacy: effects on nursing knowledge. Nurs Outlook. Sep-Oct. 2003;51(5):233-8. [pmid: 14569230].
855 Fleischer NL, Diez Roux AV, Alazraqui M, Spinelli H. Social patterning of chronic disease risk factors in a Latin American city. J Urban Health. Nov. 2008;85(6):923-37. [pmid: 18830819].
856 Florence MD, Asbridge M, Veugelers PJ. Diet quality and academic performance. J Sch Health. Apr. 2008;78(4):209-15. quiz 39-41. [pmid: 18336680].
857 Flynn KJ, Powell LH, Mendes de Leon CF, Munoz R, Eaton CB, Downs DL, et al. Increasing self-management skills in heart failure patients: a pilot study. Congest Heart Fail. Nov-Dec. 2005;11(6):297-302. [pmid: 16330904].
858 Fogel J. Internet use for cancer information among racial/ethnic populations and low literacy groups. Cancer Control. Sep-Oct. 2003;10(5 Suppl):45-51. [pmid: 14581904].
859 Fogelholm M, Malmberg J, Suni J, Santtila M, Kyrolainen H, Mantysaari M. Waist circumference and BMI are independently associated with the variation of cardiorespiratory and neuromuscular fitness in young adult men. Int J Obes (Lond). Jun. 2006;30(6):962-9. [pmid: 16432537].
860 Fogelholm M, Valve R, Absetz P, Heinonen H, Uutela A, Patja K, et al. Rural-urban differences in health and health behaviour: a baseline description of a community health-promotion programme for the elderly. Scand J Public Health. 2006;34(6):632-40. [pmid: 17132597].
861 Foggs MB. Guidelines management of asthma in a busy urban practice. Curr Opin Pulm Med. Jan. 2008;14(1):46-56. [pmid: 18043275].
862 Fok MS, Wong TK. What does health literacy mean to children?. Contemp Nurse. Oct. 2002;13(2-3):249-58. [pmid: 16116781].
863 Folk LC, March JZ, Hurst RD. A comparison of linear, fixed-form computer-based testing versus traditional paper-and-pencil-format testing in veterinary medical education. J Vet Med Educ. Fall. 2006;33(3):455-64. [pmid: 17035224].
864 Fomous C, Miller N. The role of National Library of Medicine web sites in newborn screening education. Ment Retard Dev Disabil Res Rev. 2006;12(4):305-12. [pmid: 17183579].
865 Ford ES, Mokdad AH, Li C, McGuire LC, Strine TW, Okoro CA, et al. Gender differences in coronary heart disease and health-related quality of life: findings from 10 states from the 2004 behavioral risk factor surveillance system. J Womens Health (Larchmt). Jun. 2008;17(5):757-68. [pmid: 18537479].
866 Ford PJ, Foxlee N, Green W. Developing information literacy with first year oral health students. Eur J Dent Educ. Feb. 2009;13(1):46-51. [pmid: 19196293].
867 Forjuoh SN. Traffic-related injury prevention interventions for low-income countries. Inj Control Saf Promot. Mar-Jun. 2003;10(1-2):109-18. [pmid: 12772494].
868 Fornes NS, Stringhini ML, Elias BM. Reproducibility and validity of a food-frequency questionnaire for use among low-income Brazilian workers. Public Health Nutr. Dec. 2003;6(8):821-7. [pmid: 14641954].
869 Fortman KK, Fisch RO, Phinney MY, Defor TA. Books and babies: clinical-based literacy programs. J Pediatr Health Care. Nov-Dec. 2003;17(6):295-300. [pmid: 14610443].
870 Fortner KB, Zite NB, Wallace LS. In my own words: misunderstanding of Pap smears and colposcopy among Appalachian women. J Low Genit Tract Dis. Oct. 2007;11(4):251-7. [pmid: 17917569].
871 Foschi R. Science and culture around the Montessori's first “Children's Houses” in Rome (1907-1915). J Hist Behav Sci. Summer. 2008;44(3):238-57. [pmid: 18649376].
872 Foster EM, Porter MM, Ayers TS, Kaplan DL, Sandler I. Estimating the costs of preventive interventions. Eval Rev. Jun. 2007;31(3):261-86. [pmid: 17478629].
873 Foster HE, Marshall N, Myers A, Dunkley P, Griffiths ID. Outcome in adults with juvenile idiopathic arthritis: a quality of life study. Arthritis Rheum. Mar. 2003;48(3):767-75. [pmid: 12632431].
874 Foster WA, Miller M. Development of the literacy achievement gap: a longitudinal study of kindergarten through third grade. Lang Speech Hear Serv Sch. Jul. 2007;38(3):173-81. [pmid: 17625043].
875 Fotenos S, Rohatgi D. Amplifying youth voices in the developing world. New Dir Youth Dev. Winter. 2007;(116):117-26. 12. 3. [pmid: 18271053].
876 Fottrell E, Byass P, Berhane Y. Demonstrating the robustness of population surveillance data: implications of error rates on demographic and mortality estimates. BMC Med Res Methodol. 2008;8:13. [pmid: 18366742].
877 Fourney AM, Williams ML. Formative evaluation of an intervention to increase compliance to HIV therapies: the ALP project. Health Promot Pract. Apr. 2003;4(2):165-70. [pmid: 14610986].
878 Fox JP. Stochastic EM for estimating the parameters of a multilevel IRT model. Br J Math Stat Psychol. May. 2003;56(Pt 1):65-81. [pmid: 12803822].
879 Foy JG, Feldman M, Lin E, Mahoney M, Sjoblom C. Neuroscience workshops for fifth-grade school children by undergraduate students: a university-school partnership. CBE Life Sci Educ. Summer. 2006;5(2):128-36. [pmid: 17012203].
880 Frack SA, Woodruff SI, Candelaria J, Elder JP. Correlates of compliance with measurement protocols in a Latino nutrition-intervention study. Am J Prev Med. Mar-Apr. 1997;13(2):131-6. [pmid: 9088450].
881 Frade IC, Fonseca I, Dias L, Henriques AC, Martins LS, Santos J, et al. Impact assessment in living kidney donation: psychosocial aspects in the donor. Transplant Proc. Apr. 2008;40(3):677-81. [pmid: 18454984].
882 Francis C, Pirkis JE, Blood RW, Burgess PM, Dunt DR. Media reporting of specific mental illnesses in the context of crime: implications for mental health literacy. Med J Aust. Dec. 1-15. 2003;179(11-12):638. [pmid: 14636140].
883 Francis L, Weiss BD, Senf JH, Heist K, Hargraves R. Does literacy education improve symptoms of depression and self-efficacy in individuals with low literacy and depressive symptoms? A preliminary investigation. J Am Board Fam Med. Jan-Feb. 2007;20(1):23-7. [pmid: 17204731].
884 Frankel A. Health literacy and harm: who is at risk? What is the fix?. CMAJ. Jun. 3. 2008;178(12):1573-4. [pmid: 18519906].
885 Franks H, McAlonan C. Establishing library 'key skill' confidence levels amongst a cohort of nursing students at an English university. Nurse Educ Pract. Jul. 2007;7(4):258-65. [pmid: 17689451].
886 Franks-Meeks S. Nurses and computer competency. J Nurses Staff Dev. Sep-Oct. 2008;24(5):248-51. [pmid: 18838908].
887 Fraser E, Pakenham KI. Evaluation of a resilience-based intervention for children of parents with mental illness. Aust N Z J Psychiatry. Dec. 2008;42(12):1041-50. [pmid: 19016092].
888 Fratiglioni L, Wang HX. Brain reserve hypothesis in dementia. J Alzheimers Dis. Aug. 2007;12(1):11-22. [pmid: 17851191].
889 Fratiglioni L, Winblad B, von Strauss E. Prevention of Alzheimer's disease and dementia. Major findings from the Kungsholmen Project. Physiol Behav. Sep. 10. 2007;92(1-2):98-104. [pmid: 17588621].
890 Fredrickson DD, Jones TL, Molgaard CA, Carman CG, Schukman J, Dismuke SE, et al. Optimal design features for surveying low-income populations. J Health Care Poor Underserved. Nov. 2005;16(4):677-90. [pmid: 16311492].
891 Freedman DA, Bess KD, Tucker HA, Boyd DL, Tuchman AM, Wallston KA. Public health literacy defined. Am J Prev Med. May. 2009;36(5):446-51. [pmid: 19362698].
892 Frew PM, del Rio C, Lu L, Clifton S, Mulligan MJ. Understanding differences in enrollment outcomes among high-risk populations recruited to a phase IIb HIV vaccine trial. J Acquir Immune Defic Syndr. Mar. 1. 2009;50(3):314-9. [pmid: 19194310].
893 Friedl R, Hoppler H, Ecard K, Scholz W, Hannekum A, Ochsner W, et al. Multimedia-driven teaching significantly improves students' performance when compared with a print medium. Ann Thorac Surg. May. 2006;81(5):1760-6. [pmid: 16631668].
894 Friedman DB, Hoffman-Goetz L. A systematic review of readability and comprehension instruments used for print and web-based cancer information. Health Educ Behav. Jun. 2006;33(3):352-73. [pmid: 16699125].
895 Friedman DB, Hoffman-Goetz L. An exploratory study of older adults' comprehension of printed cancer information: is readability a key factor?. J Health Commun. Jul-Aug. 2007;12(5):423-37. [pmid: 17710594].
896 Friedman DB, Hoffman-Goetz L, Arocha JF. Readability of cancer information on the internet. J Cancer Educ. Summer. 2004;19(2):117-22. [pmid: 15456669].
897 Friedman DB, Hoffman-Goetz L, Arocha JF. Health literacy and the World Wide Web: comparing the readability of leading incident cancers on the Internet. Med Inform Internet Med. Mar. 2006;31(1):67-87. [pmid: 16754369].
898 Friedman DB, Tanwar M, Richter JV. Evaluation of online disaster and emergency preparedness resources. Prehosp Disaster Med. Sep-Oct. 2008;23(5):438-46. [pmid: 19189613].
899 Friel S, McMichael AJ, Kjellstrom T, Prapamontol T. Housing and health transition in Thailand. Rev Environ Health. Jul-Dec. 2004;19(3-4):311-27. [pmid: 15742676].
900 Fries E, Edinboro P, McClish D, Manion L, Bowen D, Beresford SA, et al. Randomized trial of a low-intensity dietary intervention in rural residents: the Rural Physician Cancer Prevention Project. Am J Prev Med. Feb. 2005;28(2):162-8. [pmid: 15710271].
901 Frijling BD, Lobo CM, Keus IM, Jenks KM, Akkermans RP, Hulscher ME, et al. Perceptions of cardiovascular risk among patients with hypertension or diabetes. Patient Educ Couns. Jan. 2004;52(1):47-53. [pmid: 14729290].
902 Fritschi J, Raddatz-Muller P, Schmid P, Wuillemin WA. Patient self-management of long-term oral anticoagulation in Switzerland. Swiss Med Wkly. May. 5. 2007;137(17-18):252-8. [pmid: 17557215].
903 Fritzsche K, Ratz U, Zeeck A, Braune S, Burger T, Wirsching M. Need and use of psychotherapeutic interventions within a psychosomatic liaison service in neurology. Acta Neurol Scand. Apr. 2003;107(4):285-92. [pmid: 12675703].
904 Fuchs FD, Chambless LE, Folsom AR, Eigenbrodt ML, Duncan BB, Gilbert A, et al. Association between alcoholic beverage consumption and incidence of coronary heart disease in whites and blacks: the Atherosclerosis Risk in Communities Study. Am J Epidemiol. Sep. 1. 2004;160(5):466-74. [pmid: 15321844].
905 Fulton L, Starnes LW, Caouette M, Whittaker D, Ivanitskaya L. Explaining and forecasting attrition in the Army pharmacy technician course. Mil Med. Dec. 2008;173(12):1219-24. [pmid: 19149343].
906 Fung SM, Gilmour C, McCracken D, Shane K, Matsuura G. Nontraditional roles for certified pharmacy technicians in a pharmaceutical company. J Am Pharm Assoc (2003). Jul-Aug. 2006;46(4):507-10. [pmid: 16913395].
907 Furnham A, Chan E. Lay theories of schizophrenia. A cross-cultural comparison of British and Hong Kong Chinese attitudes, attributions and beliefs. Soc Psychiatry Psychiatr Epidemiol. Jul. 2004;39(7):543-52. [pmid: 15243692].
908 Fusar-Poli P, Martinelli V, Klersy C, Campana C, Callegari A, Barale F, et al. Depression and quality of life in patients living 10 to 18 years beyond heart transplantation. J Heart Lung Transplant. Dec. 2005;24(12):2269-78. [pmid: 16364881].
909 Gadoury MA, Schwartzman K, Rouleau M, Maltais F, Julien M, Beaupre A, et al. Self-management reduces both short- and long-term hospitalisation in COPD. Eur Respir J. Nov. 2005;26(5):853-7. [pmid: 16264046].
910 Gage H, Storey L. Rehabilitation for Parkinson's disease: a systematic review of available evidence. Clin Rehabil. Aug. 2004;18(5):463-82. [pmid: 15293481].
911 Galesic M, Garcia-Retamero R. Statistical numeracy for health: a cross-cultural comparison with probabilistic national samples. Arch Intern Med. Mar. 8. 2010;170(5):462-8. [pmid: 20212183].
912 Galesic M, Garcia-Retamero R, Gigerenzer G. Using icon arrays to communicate medical risks: overcoming low numeracy. Health Psychol. Mar. 2009;28(2):210-6. [pmid: 19290713].
913 Galesic M, Gigerenzer G, Straubinger N. Natural frequencies help older adults and people with low numeracy to evaluate medical screening tests. Med Decis Making. May-Jun. 2009;29(3):368-71. [pmid: 19129155].
914 Gallagher JE, Dobrosielski-Vergona KA, Wingard RG, Williams TM. Web-based vs. traditional classroom instruction in gerontology: a pilot study. J Dent Hyg. Summer. 2005;79(3):7. [pmid: 16197772].
915 Gallagher R, McKinley S. Stressors and anxiety in patients undergoing coronary artery bypass surgery. Am J Crit Care. May. 2007;16(3):248-57. [pmid: 17460316].
916 Galloway G, Murphy P, Chesson AL, Martinez K. MDA and AAEM informational brochures: can patients read them?. J Neurosci Nurs. Jun. 2003;35(3):171-4. [pmid: 12830665].
917 Galvin WF. Associate in science degree education programs: organization, structure, and curriculum. Respir Care Clin N Am. Sep. 2005;11(3):383-400. [pmid: 16168909].
918 Ganesh B, Talole SD, Dikshit R, Badwe RA, Dinshaw KA. Estimation of survival rates of breast cancer patients--a hospital-based study from Mumbai. Asian Pac J Cancer Prev. Jan-Mar. 2008;9(1):53-7. [pmid: 18439074].
919 Gansler T, Henley SJ, Stein K, Nehl EJ, Smigal C, Slaughter E. Sociodemographic determinants of cancer treatment health literacy. Cancer. Aug. 1. 2005;104(3):653-60. [pmid: 15983986].
920 Garbers S, Chiasson MA. Inadequate functional health literacy in Spanish as a barrier to cervical cancer screening among immigrant Latinas in New York City. Prev Chronic Dis. Oct. 2004;1(4):A07. [pmid: 15670438].
921 Garcia GN, McCardle P, Nixon SM. Prologue: development of english literacy in Spanish-speaking children: transforming research into practice. Lang Speech Hear Serv Sch. Jul. 2007;38(3):213-5. [pmid: 17625047].
922 Garcia RI, Cadoret CA, Henshaw M. Multicultural issues in oral health. Dent Clin North Am. Apr. 2008;52(2):319-32. vi. [pmid: 18329446].
923 Garcia-Retamero R, Galesic M. Communicating treatment risk reduction to people with low numeracy skills: a cross-cultural comparison. Am J Public Health. Dec. 2009;99(12):2196-202. [pmid: 19833983].
924 Garcia-Retamero R, Galesic M. Who profits from visual aids: overcoming challenges in people's understanding of risks [corrected]. Soc Sci Med. Apr. 2010;70(7):1019-25. [pmid: 20116159].
925 Garcia-Sanchez R. The patient's perspective of computerised records: a questionnaire survey in primary care. Inform Prim Care. 2008;16(2):93-9. [pmid: 18713525].
926 Gardette V, Bongard V, Dallongeville J, Arveiler D, Bingham A, Ruidavets JB, et al. Ten-year all-cause mortality in presumably healthy subjects on lipid-lowering drugs (from the Prospective Epidemiological Study of Myocardial Infarction [PRIME] prospective cohort). Am J Cardiol. Feb. 1. 2009;103(3):381-6. [pmid: 19166693].
927 Gardner H, Froud K, McClelland A, van der Lely HK. Development of the Grammar and Phonology Screening (GAPS) test to assess key markers of specific language and literacy difficulties in young children. Int J Lang Commun Disord. Sep-Oct. 2006;41(5):513-40. [pmid: 17050469].
928 Garland AF, Kruse M, Aarons GA. Clinicians and outcome measurement: what's the use?. J Behav Health Serv Res. Oct-Dec. 2003;30(4):393-405. [pmid: 14593663].
929 Garrett B, Klein G. Value of wireless personal digital assistants for practice: perceptions of advanced practice nurses. J Clin Nurs. Aug. 2008;17(16):2146-54. [pmid: 18705736].
930 Garson A Jr. The uninsured: problems, solutions, and the role of academic medicine. Acad Med. Sep. 2006;81(9):798-801. [pmid: 16936484].
931 Gassert CA. Technology and informatics competencies. Nurs Clin North Am. Dec. 2008;43(4):507-21. v. [pmid: 18940408].
932 Gassert CA, Sward KA. Phase I implementation of an academic medical record for integrating information management competencies into a nursing curriculum. Stud Health Technol Inform. 2007;129(Pt 2):1392-5. [pmid: 17911942].
933 Gates EA. Communicating risk in prenatal genetic testing. J Midwifery Womens Health. May-Jun. 2004;49(3):220-7. [pmid: 15134675].
934 Gathercole SE, Tiffany C, Briscoe J, Thorn A. Developmental consequences of poor phonological short-term memory function in childhood: a longitudinal study. J Child Psychol Psychiatry. Jun. 2005;46(6):598-611. [pmid: 15877766].
935 Gathwala G, Yadav OP, Sangwan K, Singh I, Yadav J. A study on plasma selenium level among pregnant women at Rohtak, Haryana. Indian J Public Health. Apr-Jun. 2003;47(2):45-8. [pmid: 15129852].
936 Gatti ME, Jacobson KL, Gazmararian JA, Schmotzer B, Kripalani S. Relationships between beliefs about medications and adherence. Am J Health Syst Pharm. Apr. 1. 2009;66(7):657-64. [pmid: 19299373].
937 Gattuso S, Fullagar S, Young I. Speaking of women's 'nameless misery': the everyday construction of depression in Australian women's magazines. Soc Sci Med. Oct. 2005;61(8):1640-8. [pmid: 16029771].
938 Gautam RK. Biosocial covariates of adult male body mass index in Central India. J Biosoc Sci. Nov. 2007;39(6):875-93. [pmid: 17349067].
939 Gazmararian J, Jacobson KL, Pan Y, Schmotzer B, Kripalani S. Effect of a pharmacy-based health literacy intervention and patient characteristics on medication refill adherence in an urban health system. Ann Pharmacother. Jan. 2010;44(1):80-7. [pmid: 20028960].
940 Gazmararian JA, Curran JW, Parker RM, Bernhardt JM, DeBuono BA. Public health literacy in America: an ethical imperative. Am J Prev Med. Apr. 2005;28(3):317-22. [pmid: 15766622].
941 Gazmararian JA, Kripalani S, Miller MJ, Echt KV, Ren J, Rask K. Factors associated with medication refill adherence in cardiovascular-related diseases: a focus on health literacy. J Gen Intern Med. Dec. 2006;21(12):1215-21. [pmid: 17105519].
942 Gazmararian JA, Williams MV, Peel J, Baker DW. Health literacy and knowledge of chronic disease. Patient Educ Couns. Nov. 2003;51(3):267-75. [pmid: 14630383].
943 Geers AE. Predictors of reading skill development in children with early cochlear implantation. Ear Hear. Feb. 2003;24(1 Suppl):59S-68S. [pmid: 12612481].
944 Gehring K, Sitskoorn MM, Gundy CM, Sikkes SA, Klein M, Postma TJ, et al. Cognitive rehabilitation in patients with gliomas: a randomized, controlled trial. J Clin Oncol. Aug. 1. 2009;27(22):3712-22. [pmid: 19470928].
945 Gehring KM, Eastman DA. Information fluency for undergraduate biology majors: applications of inquiry-based learning in a developmental biology course. CBE Life Sci Educ. Spring. 2008;7(1):54-63. [pmid: 18316808].
946 Geller BM, Skelly JM, Dorwaldt AL, Howe KD, Dana GS, Flynn BS. Increasing patient/physician communications about colorectal cancer screening in rural primary care practices. Med Care. Sep. 2008;46(9 Suppl 1):S36-43. [pmid: 18725831].
947 Geller J, Swetter SM, Leyson J, Miller DR, Brooks K, Geller AC. Crafting a melanoma educational campaign to reach middle-aged and older men. J Cutan Med Surg. Nov-Dec. 2006;10(6):259-68. [pmid: 17241595].
948 Gellis ZD, McGinty J, Horowitz A, Bruce ML, Misener E. Problem-solving therapy for late-life depression in home care: a randomized field trial. Am J Geriatr Psychiatry. Nov. 2007;15(11):968-78. [pmid: 17846101].
949 Gendle MH, Spaeth AM, Dollard SM, Novak CA. Functional relationships between serum total cholesterol levels, executive control, and sustained attention. Nutr Neurosci. Apr. 2008;11(2):84-94. [pmid: 18510808].
950 Gennetian LA, Magnuson K, Morris PA. From statistical associations to causation: what developmentalists can learn from instrumental variables techniques coupled with experimental data. Dev Psychol. Mar. 2008;44(2):381-94. [pmid: 18331130].
951 George AC, Hoshing A, Joshi NV. A study of the reasons for irregular dental attendance in a private dental college in a rural setup. Indian J Dent Res. Apr-Jun. 2007;18(2):78-81. [pmid: 17502713].
952 George JT, Warriner DA, Anthony J, Rozario KS, Xavier S, Jude EB, et al. Training tomorrow's doctors in diabetes: self-reported confidence levels, practice and perceived training needs of post-graduate trainee doctors in the UK. A multi-centre survey. BMC Med Educ. 2008;8:22. [pmid: 18419804].
953 Georges CA, Bolton LB, Bennett C. Functional health literacy: an issue in African-American and other ethnic and racial communities. J Natl Black Nurses Assoc. Jul. 2004;15(1):1-4. [pmid: 15712814].
954 Gerber BS, Brodsky IG, Lawless KA, Smolin LI, Arozullah AM, Smith EV, et al. Implementation and evaluation of a low-literacy diabetes education computer multimedia application. Diabetes Care. Jul. 2005;28(7):1574-80. [pmid: 15983303].
955 Gerber BS, Cano AI, Caceres ML, Smith DE, Wilken LA, Michaud JB, et al. A pharmacist and health promoter team to improve medication adherence among Latinos with diabetes. Ann Pharmacother. Jan. 2010;44(1):70-9. [pmid: 20028957].
956 Gerber BS, Pagcatipunan M, Smith EV Jr, Basu SS, Lawless KA, Smolin LI, et al. The assessment of diabetes knowledge and self-efficacy in a diverse population using Rasch measurement. J Appl Meas. 2006;7(1):55-73. [pmid: 16385151].
957 Gerber Y, Benyamini Y, Goldbourt U, Drory Y. Prognostic importance and long-term determinants of self-rated health after initial acute myocardial infarction. Med Care. Mar. 2009;47(3):342-9. [pmid: 19194331].
958 Ghanbari A, Yekta ZP, Roushan ZA, Lakeh NM. Assessment of factors affecting quality of life in diabetic patients in Iran. Public Health Nurs. Jul-Aug. 2005;22(4):311-22. [pmid: 16150012].
959 Ghosh AK, Ghosh K. Translating evidence-based information into effective risk communication: current challenges and opportunities. J Lab Clin Med. Apr. 2005;145(4):171-80. [pmid: 15962835].
960 Ghosh R, Bharati P. Haemoglobin status of adult women of two ethnic groups living in a peri-urban area of Kolkata city, India: a micro-level study. Asia Pac J Clin Nutr. 2003;12(4):451-9. [pmid: 14672870].
961 Ghosh R, Bharati P. Women's status and health of two ethnic groups inhabiting a periurban habitat of Kolkata City, India: a micro-level study. Health Care Women Int. Mar. 2005;26(3):194-211. [pmid: 15804693].
962 Gibson J, Jack K, Rennie JS. Computer literacy, skills and knowledge among dentists and dental care professionals (DCPs) within primary care in Scotland. Inform Prim Care. 2006;14(1):17-28. [pmid: 16848963].
963 Gibson J, Jack K, Rennie JS. Computer literacy, skills and knowledge among dentists and professionals complementary to dentistry in Scotland. Health Informatics J. Dec. 2007;13(4):267-82. [pmid: 18029404].
964 Gibson M, Meem DT. Performing transformation: reflections of a lesbian academic couple. J Lesbian Stud. 2005;9(4):107-28. [pmid: 17548298].
965 Gigerenzer G. Collective statistical illiteracy: a cross-cultural comparison with probabilistic national samples: comment on “Statistical numeracy for health”. Arch Intern Med. Mar. 8. 2010;170(5):468. [pmid: 20212184].
966 Gil KM, Gibbons HE, Jenison EL, Hopkins MP, von Gruenigen VE. Baseline characteristics influencing quality of life in women undergoing gynecologic oncology surgery. Health Qual Life Outcomes. 2007;5:25. [pmid: 17509145].
967 Gillis DE, MacIsaac A, Quigley Allan B, Shively J. Health literacy: expanding practitioners' horizons through collaborative research. J Interprof Care. Nov. 2004;18(4):449-51. [pmid: 15801563].
968 Gillon GT. Facilitating phoneme awareness development in 3- and 4-year-old children with speech impairment. Lang Speech Hear Serv Sch. Oct. 2005;36(4):308-24. [pmid: 16389703].
969 Gillon GT, Moriarty BC. Childhood apraxia of speech: children at risk for persistent reading and spelling disorder. Semin Speech Lang. Feb. 2007;28(1):48-57. [pmid: 17340382].
970 Gilmour C, Hall H, McIntyre M, Gillies L, Harrison B. Factors associated with early breastfeeding cessation in Frankston, Victoria: a descriptive study. Breastfeed Rev. Jul. 2009;17(2):13-9. [pmid: 19685854].
971 Gilmour JA. Reducing disparities in the access and use of Internet health information. a discussion paper. Int J Nurs Stud. Sep. 2007;44(7):1270-8. [pmid: 16828775].
972 Gilmour JA, Scott SD, Huntington N. Nurses and Internet health information: a questionnaire survey. J Adv Nurs. Jan. 2008;61(1):19-28. [pmid: 18034820].
973 Ginde AA, Clark S, Goldstein JN, Camargo CA Jr. Demographic disparities in numeracy among emergency department patients: evidence from two multicenter studies. Patient Educ Couns. Aug. 2008;72(2):350-6. [pmid: 18462915].
974 Ginde AA, Weiner SG, Pallin DJ, Camargo CA Jr. Multicenter study of limited health literacy in emergency department patients. Acad Emerg Med. Jun. 2008;15(6):577-80. [pmid: 18616448].
975 Giordano L, Webster P, Anthony C, Szarewski A, Davies P, Arbyn M, et al. Improving the quality of communication in organised cervical cancer screening programmes. Patient Educ Couns. Jul. 2008;72(1):130-6. [pmid: 18538725].
976 Girolametto L, Weitzman E, Lefebvre P, Greenberg J. The effects of in-service education to promote emergent literacy in child care centers: a feasibility study. Lang Speech Hear Serv Sch. Jan. 2007;38(1):72-83. [pmid: 17218537].
977 Giskes K, Kunst AE, Benach J, Borrell C, Costa G, Dahl E, et al. Trends in smoking behaviour between 1985 and 2000 in nine European countries by education. J Epidemiol Community Health. May. 2005;59(5):395-401. [pmid: 15831689].
978 Gjerde CL, Pipas CF, Russell M. Teaching of medical informatics in UME-21 medical schools: best practices and useful resources. Fam Med. Jan. 2004;36(Suppl):S68-73. [pmid: 14961406].
979 Glaister K. The presence of mathematics and computer anxiety in nursing students and their effects on medication dosage calculations. Nurse Educ Today. May. 2007;27(4):341-7. [pmid: 16857301].
980 Glasgow NJ, Jeon YH, Kraus SG, Pearce-Brown CL. Chronic disease self-management support: the way forward for Australia. Med J Aust. Nov. 17. 2008;189(10 Suppl):S14-6. [pmid: 19143579].
981 Glasgow RE, Estabrooks PA, Marcus AC, Smith TL, Gaglio B, Levinson AH, et al. Evaluating initial reach and robustness of a practical randomized trial of smoking reduction. Health Psychol. Nov. 2008;27(6):780-8. [pmid: 19025274].
982 Glasgow RE, Gaglio B, Estabrooks PA, Marcus AC, Ritzwoller DP, Smith TL, et al. Long-term results of a smoking reduction program. Med Care. Jan. 2009;47(1):115-20. [pmid: 19106739].
983 Glass AP, Butler DQ. Health literacy and older adults. J Am Geriatr Soc. Jan. 2010;58(1):152-3. [pmid: 20122046].
984 Glogowska M, Roulstone S, Peters TJ, Enderby P. Early speech- and language-impaired children: linguistic, literacy, and social outcomes. Dev Med Child Neurol. Jun. 2006;48(6):489-94. [pmid: 16700942].
985 Gnich W, Sheehy C, Amos A, Bitel M, Platt S. A Scotland-wide pilot programme of smoking cessation services for young people: process and outcome evaluation. Addiction. Nov. 2008;103(11):1866-74. [pmid: 18705682].
986 Godbole S, Mehendale S. HIV/AIDS epidemic in India: risk factors, risk behaviour & strategies for prevention & control. Indian J Med Res. Apr. 2005;121(4):356-68. [pmid: 15817949].
987 Godbout L, Grenier MC, Braun CM, Gagnon S. Cognitive structure of executive deficits in patients with frontal lesions performing activities of daily living. Brain Inj. May. 2005;19(5):337-48. [pmid: 16094781].
988 Goel V, Tierney M, Sheesley L, Bartolo A, Vartanian O, Grafman J. Hemispheric specialization in human prefrontal cortex for resolving certain and uncertain inferences. Cereb Cortex. Oct. 2007;17(10):2245-50. [pmid: 17158186].
989 Golbeck AL, Ahlers-Schmidt CR, Paschal AM, Dismuke SE. A definition and operational framework for health numeracy. Am J Prev Med. Nov. 2005;29(4):375-6. [pmid: 16242604].
990 Goldberg DS. Justice, health literacy and social epidemiology. Am J Bioeth. Nov. 2007;7(11):18-20. discussion W1-2. [pmid: 18027292].
991 Goldman LE, Handley M, Rundall TG, Schillinger D. Current and future directions in Medi-Cal chronic disease care management: a view from the top. Am J Manag Care. May. 2007;13(5):263-8. [pmid: 17488192].
992 Goldney RD, Dunn KI, Dal Grande E, Crabb S, Taylor A. Tracking depression-related mental health literacy across South Australia: a decade of change. Aust N Z J Psychiatry. May. 2009;43(5):476-83. [pmid: 19373710].
993 Goldney RD, Fisher LJ. Have broad-based community and professional education programs influenced mental health literacy and treatment seeking of those with major depression and suicidal ideation?. Suicide Life Threat Behav. Apr. 2008;38(2):129-42. [pmid: 18444772].
994 Goldney RD, Fisher LJ, Dal Grande E, Taylor AW. Changes in mental health literacy about depression: South Australia, 1998 to 2004. Med J Aust. Aug. 1. 2005;183(3):134-7. [pmid: 16053415].
995 Goldney RD, Taylor AW, Bain MA. Depression and remoteness from health services in South Australia. Aust J Rural Health. Jun. 2007;15(3):201-10. [pmid: 17542794].
996 Goldschmidt L, Richardson GA, Cornelius MD, Day NL. Prenatal marijuana and alcohol exposure and academic achievement at age 10. Neurotoxicol Teratol. Jul-Aug. 2004;26(4):521-32. [pmid: 15203174].
997 Goldsworthy S, Lawrence N, Goodman W. The use of personal digital assistants at the point of care in an undergraduate nursing program. Comput Inform Nurs. May-Jun. 2006;24(3):138-43. [pmid: 16707943].
998 Goldsworthy SJ, Goodman B, Muirhead B. Goal orientation and its relationship to academic success in a laptop-based BScN program. Int J Nurs Educ Scholarsh. 2005:2. Article 22.
999 Golin CE, Liu H, Hays RD, Miller LG, Beck CK, Ickovics J, et al. A prospective study of predictors of adherence to combination antiretroviral medication. J Gen Intern Med. Oct. 2002;17(10):756-65. [pmid: 12390551].
1000 Gome JJ, Paltridge D, Inder WJ. Review of intern preparedness and education experiences in General Medicine. Intern Med J. Apr. 2008;38(4):249-53. [pmid: 18298561].
1001 Gomez E. Web-based tools can help to improve health literacy. ONS News. Sep. 2004;19(9):6. [pmid: 15473214].
1002 Gong DA, Lee JY, Rozier RG, Pahel BT, Richman JA, Vann WF Jr. Development and testing of the Test of Functional Health Literacy in Dentistry (TOFHLiD). J Public Health Dent. Spring. 2007;67(2):105-12. [pmid: 17557682].
1003 Gong G, Kosoko-Lasaki S, Haynatzki G, Cook C, O'Brien RL, Houtz LE. Ethical, legal and social issues of genetic studies with African immigrants as research subjects. J Natl Med Assoc. Sep. 2008;100(9):1073-7. [pmid: 18807438].
1004 Gonnella JS, Erdmann JB, Hojat M. An empirical study of the predictive validity of number grades in medical school using 3 decades of longitudinal data: implications for a grading system. Med Educ. Apr. 2004;38(4):425-34. [pmid: 15025644].
1005 Gonzalez YM, Lozier EB. Oral cancer screening, dental needs assessment and risk factors literacy in Hispanic population of western New York. N Y State Dent J. Nov. 2007;73(6):32-5. [pmid: 18265766].
1006 Goodfellow GW, Trachimowicz R, Steele G. Patient literacy levels within an inner-city optometry clinic. Optometry. Feb. 2008;79(2):98-103. [pmid: 18215800].
1007 Gordon EJ, Wolf MS. Beyond the basics: designing a comprehensive response to low health literacy. Am J Bioeth. Nov. 2007;7(11):11-3. discussion W1-2. [pmid: 18027289].
1008 Gordon EJ, Wolf MS. Health literacy skills of kidney transplant recipients. Prog Transplant. Mar. 2009;19(1):25-34. [pmid: 19341060].
1009 Gordon JA, Oriol NE. Perspective: fostering biomedical literacy among America's youth: how medical simulation reshapes the strategy. Acad Med. May. 2008;83(5):521-3. [pmid: 18448913].
1010 Gore JL, Danovitch GM, Litwin MS, Pham PT, Singer JS. Disparities in the utilization of live donor renal transplantation. Am J Transplant. May. 2009;9(5):1124-33. [pmid: 19422338].
1011 Goske MJ, Bulas D. Improving health literacy: informed decision-making rather than informed consent for CT scans in children. Pediatr Radiol. Sep. 2009;39(9):901-3. [pmid: 19557404].
1012 Gosline MB. Leadership in nursing education: voices from the past. Nurs Leadersh Forum. Winter. 2004;9(2):51-9. [pmid: 16033044].
1013 Goswami U, Ziegler JC, Richardson U. The effects of spelling consistency on phonological awareness: a comparison of English and German. J Exp Child Psychol. Dec. 2005;92(4):345-65. [pmid: 16087187].
1014 Goto R, Nishimura S, Ida T. Discrete choice experiment of smoking cessation behaviour in Japan. Tob Control. Oct. 2007;16(5):336-43. [pmid: 17897993].
1015 Gould DJ, Terrell MA, Fleming J. A usability study of users' perceptions toward a multimedia computer-assisted learning tool for neuroanatomy. Anat Sci Educ. Jul. 2008;1(4):175-83. [pmid: 19177405].
1016 Gouvea MV, Werneck GL, Costa CH, de Amorim Carvalho FA. Factors associated to Montenegro skin test positivity in Teresina, Brazil. Acta Trop. Nov-Dec. 2007;104(2-3):99-107. [pmid: 17825238].
1017 Goytia EJ, Rapkin B, Weiss ES, Golub D, Guzman V, O'Connor M. Readiness and capacity of librarians in public libraries to implement a breast cancer outreach and screening campaign in medically underserved communities. Cancer Control. Nov. 2. 2005;12:13-20. [pmid: 16327746].
1018 Goz F, Karaoz S, Goz M, Ekiz S, Cetin I. Effects of the diabetic patients' perceived social support on their quality-of-life. J Clin Nurs. Jul. 2007;16(7):1353-60. [pmid: 17584354].
1019 Grady JL, Schlachta-Fairchild L. Report of the 2004-2005 International Telenursing Survey. Comput Inform Nurs. Sep-Oct. 2007;25(5):266-72. [pmid: 17827989].
1020 Graesser AC, Lu S, Jackson GT, Mitchell HH, Ventura M, Olney A, et al. AutoTutor: a tutor with dialogue in natural language. Behav Res Methods Instrum Comput. May. 2004;36(2):180-92. [pmid: 15354683].
1021 Graham J, Bennett IM, Holmes WC, Gross R. Medication beliefs as mediators of the health literacy-antiretroviral adherence relationship in HIV-infected individuals. AIDS Behav. May. 2007;11(3):385-92. [pmid: 17053858].
1022 Gramling R, Irvin JE, Nash J, Sciamanna C, Culpepper L. Numeracy and medicine: key family physician attitudes about communicating probability with patients. J Am Board Fam Pract. Nov-Dec. 2004;17(6):473. [pmid: 15575041].
1023 Grassi G, Arenare F, Dell'oro R, Quarti-Trevano F, Brambilla G, Carugo S, et al. Prevalence of cardiovascular risk factors in an unselected italian population. Results of the Cardiolab Project 2004-2008. Acta Cardiol. Dec. 2009;64(6):771-8. [pmid: 20128154].
1024 Gray K, Sim J. Building ICT capabilities for clinical work in a sustainable healthcare system: approaches to bridging the higher education learning and teaching gap. Stud Health Technol Inform. 2007;129(Pt 2):1428-31. [pmid: 17911950].
1025 Gray NJ. Adolescents, the Internet, and health literacy. Adolesc Med State Art Rev. Aug. 2007;18(2):370-82. xiii. [pmid: 18605652].
1026 Gray NJ, Klein JD. Adolescents and the internet: health and sexuality information. Curr Opin Obstet Gynecol. Oct. 2006;18(5):519-24. [pmid: 16932046].
1027 Gray NJ, Klein JD, Noyce PR, Sesselberg TS, Cantrill JA. The Internet: a window on adolescent health literacy. J Adolesc Health. Sep. 2005;37(3):243. [pmid: 16109345].
1028 Gray PH, O'Callaghan MJ, Rogers YM. Psychoeducational outcome at school age of preterm infants with bronchopulmonary dysplasia. J Paediatr Child Health. Mar. 2004;40(3):114-20. [pmid: 15009575].
1029 Greebe P, Rinkel GJ. Feasibility of follow-up through e-mail in patients discharged after subarachnoid hemorrhage. Cerebrovasc Dis. 2006;21(5-6):363-6. [pmid: 16490948].
1030 Green JB, Duncan RE, Barnes GL, Oberklaid F. Putting the ‘informed’ into ‘consent’: a matter of plain language. J Paediatr Child Health. Dec. 2003;39(9):700-3. [pmid: 14629504].
1031 Green MJ, Peterson SK, Baker MW, Harper GR, Friedman LC, Rubinstein WS, et al. Effect of a computer-based decision aid on knowledge, perceptions, and intentions about genetic testing for breast cancer susceptibility: a randomized controlled trial. JAMA. Jul. 28. 2004;292(4):442-52. [pmid: 15280342].
1032 Green SM, Weaver M, Voegeli D, Fitzsimmons D, Knowles J, Harrison M, et al. The development and evaluation of the use of a virtual learning environment (Blackboard 5) to support the learning of pre-qualifying nursing students undertaking a human anatomy and physiology module. Nurse Educ Today. Jul. 2006;26(5):388-95. [pmid: 16414156].
1033 Greenberg BJ, Kumar JV, Stevenson H. Dental case management: increasing access to oral health care for families and children with low incomes. J Am Dent Assoc. Aug. 2008;139(8):1114-21. [pmid: 18682626].
1034 Greenberg D, Lackey J. The importance of adult literacy issues in social work practice. Soc Work. Apr. 2006;51(2):177-9. [pmid: 16858924].
1035 Greene BL, Miller JD, Brown TM, Harshman RS, Richerson GT, Doyle JJ. Economic impact of the BP DownShift Program on blood pressure control among commercial driver license employees. J Occup Environ Med. May. 2009;51(5):542-53. [pmid: 19365286].
1036 Greene J. RN to CIO. High-tech nurses bridge hospitals' cultural divide. Hosp Health Netw. Feb. 2004;78(2):40-6. 2. [pmid: 14999877].
1037 Greene J, Peters E. Medicaid consumers and informed decisionmaking. Health Care Financ Rev. Spring. 2009;30(3):25-40. [pmid: 19544933].
1038 Greene J, Peters E, Mertz CK, Hibbard JH. Comprehension and choice of a consumer-directed health plan: an experimental study. Am J Manag Care. Jun. 2008;14(6):369-76. [pmid: 18554075].
1039 Greenfield SF, Sugarman DE, Nargiso J, Weiss RD. Readability of patient handout materials in a nationwide sample of alcohol and drug abuse treatment programs. Am J Addict. Jul-Sep. 2005;14(4):339-45. [pmid: 16188714].
1040 Greenhalgh T, Wood GW, Bratan T, Stramer K, Hinder S. Patients' attitudes to the summary care record and HealthSpace: qualitative study. BMJ. Jun. 7. 2008;336(7656):1290-5. [pmid: 18511764].
1041 Greenlund KJ, Keenan NL, Giles WH, Zheng ZJ, Neff LJ, Croft JB, et al. Public recognition of major signs and symptoms of heart attack: seventeen states and the US Virgin Islands, 2001. Am Heart J. Jun. 2004;147(6):1010-6. [pmid: 15199349].
1042 Greenlund KJ, Zheng ZJ, Keenan NL, Giles WH, Casper ML, Mensah GA, et al. Trends in self-reported multiple cardiovascular disease risk factors among adults in the United States, 1991-1999. Arch Intern Med. Jan. 26. 2004;164(2):181-8. [pmid: 14744842].
1043 Gregorio DI, DeChello LM, Segal J. Service learning within the University of Connecticut Master of Public Health Program. Public Health Rep. 2008;123(Suppl 2):44-52. [pmid: 18773522].
1044 Gregory CO, Blanck HM, Gillespie C, Maynard LM, Serdula MK. Health perceptions and demographic characteristics associated with underassessment of body weight. Obesity (Silver Spring). May. 2008;16(5):979-86. [pmid: 18309300].
1045 Gregory KD, Johnson CT, Johnson TR, Entman SS. The content of prenatal care. Update 2005. Womens Health Issues. Jul-Aug. 2006;16(4):198-215. [pmid: 16920524].
1046 Gresty K, Skirton H, Evenden A. Addressing the issue of e-learning and online genetics for health professionals. Nurs Health Sci. Mar. 2007;9(1):14-22. [pmid: 17300540].
1047 Griffin J, McKenna K, Tooth L. Discrepancy between older clients' ability to read and comprehend and the reading level of written educational materials used by occupational therapists. Am J Occup Ther. Jan-Feb. 2006;60(1):70-80. [pmid: 16541986].
1048 Griffiths KM, Christensen H. Internet-based mental health programs: a powerful tool in the rural medical kit. Aust J Rural Health. Apr. 2007;15(2):81-7. [pmid: 17441815].
1049 Griffiths KM, Christensen H, Jorm AF. Predictors of depression stigma. BMC Psychiatry. 2008;8:25. [pmid: 18423003].
1050 Griffiths KM, Christensen H, Jorm AF. Mental health literacy as a function of remoteness of residence: an Australian national study. BMC Public Health. 2009;9:92. [pmid: 19327161].
1051 Griffiths KM, Christensen H, Jorm AF, Evans K, Groves C. Effect of web-based depression literacy and cognitive-behavioural therapy interventions on stigmatising attitudes to depression: randomised controlled trial. Br J Psychiatry. Oct. 2004;185:342-9. [pmid: 15458995].
1052 Grigg-Saito D, Och S, Liang S, Toof R, Silka L. Building on the strengths of a Cambodian refugee community through community-based outreach. Health Promot Pract. Oct. 2008;9(4):415-25. [pmid: 17494947].
1053 Grissinger MC, Globus NJ, Fricker MP Jr. The role of managed care pharmacy in reducing medication errors. J Manag Care Pharm. Jan-Feb. 2003;9(1):62-5. [pmid: 14613363].
1054 Grizenko N, Bhat M, Schwartz G, Ter-Stepanian M, Joober R. Efficacy of methylphenidate in children with attention-deficit hyperactivity disorder and learning disabilities: a randomized crossover trial. J Psychiatry Neurosci. Jan. 2006;31(1):46-51. [pmid: 16496035].
1055 Groce NE, Yousafzai AK, van der Maas F. HIV/AIDS and disability: differences in HIV/AIDS knowledge between deaf and hearing people in Nigeria. Disabil Rehabil. Mar. 15. 2007;29(5):367-71. [pmid: 17364788].
1056 Groeneveld PW, Kwoh CK, Mor MK, Appelt CJ, Geng M, Gutierrez JC, et al. Racial differences in expectations of joint replacement surgery outcomes. Arthritis Rheum. May. 15. 2008;59(5):730-7. [pmid: 18438917].
1057 Grubbs V, Gregorich SE, Perez-Stable EJ, Hsu CY. Health literacy and access to kidney transplantation. Clin J Am Soc Nephrol. Jan. 2009;4(1):195-200. [pmid: 19056617].
1058 Grunau RE, Whitfield MF, Fay TB. Psychosocial and academic characteristics of extremely low birth weight (< or =800 g) adolescents who are free of major impairment compared with term-born control subjects. Pediatrics. Dec. 2004;114(6):e725-32. [pmid: 15576337].
1059 Gucciardi E, Smith PL, DeMelo M. Use of diabetes resources in adults attending a self-management education program. Patient Educ Couns. Dec. 2006;64(1-3):322-30. [pmid: 16859862].
1060 Guerra CE, Dominguez F, Shea JA. Literacy and knowledge, attitudes, and behavior about colorectal cancer screening. J Health Commun. Oct-Nov. 2005;10(7):651-63. [pmid: 16278201].
1061 Guerra CE, Jacobs SE, Holmes JH, Shea JA. Are physicians discussing prostate cancer screening with their patients and why or why not? A pilot study. J Gen Intern Med. Jul. 2007;22(7):901-7. [pmid: 17549576].
1062 Guerra CE, Krumholz M, Shea JA. Literacy and knowledge, attitudes and behavior about mammography in Latinas. J Health Care Poor Underserved. Feb. 2005;16(1):152-66. [pmid: 15741716].
1063 Guerra CE, McDonald VJ, Ravenell KL, Asch DA, Shea JA. Effect of race on patient expectations regarding their primary care physicians. Fam Pract. Feb. 2008;25(1):49-55. [pmid: 18304974].
1064 Guerra CE, Shea JA. Health literacy and perceived health status in Latinos and African Americans. Ethn Dis. Spring. 2007;17(2):305-12. [pmid: 17682363].
1065 Guerrero AD, Chen J, Inkelas M, Rodriguez HP, Ortega AN. Racial and ethnic disparities in pediatric experiences of family-centered care. Med Care. Apr. 2010;48(4):388-93. [pmid: 20220533].
1066 Guillausseau PJ. Influence of oral antidiabetic drugs compliance on metabolic control in type 2 diabetes. A survey in general practice. Diabetes Metab. Feb. 2003;29(1):79-81. [pmid: 12629452].
1067 Guillot L, Stahr B, Plaisance L. Dedicated online virtual reference instruction. Nurse Educ. Nov-Dec. 2005;30(6):242-6. [pmid: 16292145].
1068 Gul S, Ghaffar H, Mirza S, Fizza Tauqir S, Murad F, Ali Q, et al. Multitasking a telemedicine training unit in earthquake disaster response: paraplegic rehabilitation assessment. Telemed J E Health. Apr. 2008;14(3):280-3. [pmid: 18570553].
1069 Gulliford MC, Mahabir D, Rocke B. Diabetes-related inequalities in health status and financial barriers to health care access in a population-based study. Diabet Med. Jan. 2004;21(1):45-51. [pmid: 14706053].
1070 Gupta DN, Mondal SK, Sarkar BL, Mukherjee S, Bhattacharya SK. An el tor cholera outbreak amongst tribal population in Tripura. J Commun Dis. Dec. 2004;36(4):271-6. [pmid: 16506550].
1071 Gupta M, Thakur JS, Kumar R. Reproductive and child health inequities in Chandigarh Union Territory of India. J Urban Health. Mar. 2008;85(2):291-9. [pmid: 18197478].
1072 Gupta PC, Ray CS. Tobacco, education & health. Indian J Med Res. Oct. 2007;126(4):289-99. [pmid: 18032804].
1073 Gupta R, Misra A, Pais P, Rastogi P, Gupta VP. Correlation of regional cardiovascular disease mortality in India with lifestyle and nutritional factors. Int J Cardiol. Apr. 14. 2006;108(3):291-300. [pmid: 15978684].
1074 Gupta U, Sharma S, Sheth PD, Jha J, Chaudhury RR. Improving medicine usage through patient information leaflets in India. Trop Doct. Jul. 2005;35(3):164-6. [pmid: 16105344].
1075 Gureje O, Akinpelu AO, Uwakwe R, Udofia O, Wakil A. Comorbidity and impact of chronic spinal pain in Nigeria. Spine. Aug. 1. 2007;32(17):E495-500. [pmid: 17762283].
1076 Gurmankin AD, Baron J, Armstrong K. The effect of numerical statements of risk on trust and comfort with hypothetical physician risk communication. Med Decis Making. May-Jun. 2004;24(3):265-71. [pmid: 15155015].
1077 Guttmacher AE, Porteous ME, McInerney JD. Educating health-care professionals about genetics and genomics. Nat Rev Genet. Feb. 2007;8(2):151-7. [pmid: 17230201].
1078 Guzick DS, Swan S. The decline of infertility: apparent or real?. Fertil Steril. Sep. 2006;86(3):524-6. discussion 34. [pmid: 16952501].
1079 Habil E, Faris R, Magid A, Rady M. Predictive model of coronary heart disease in Egypt (a disease with multiple risk factors). J Egypt Public Health Assoc. 1999;74(3-4):297-312. [pmid: 17219872].
1080 Hack M, Taylor HG, Drotar D, Schluchter M, Cartar L, Andreias L, et al. Chronic conditions, functional limitations, and special health care needs of school-aged children born with extremely low-birth-weight in the 1990s. JAMA. Jul. 20. 2005;294(3):318-25. [pmid: 16030276].
1081 Hackney JE, Weaver TE, Pack AI. Health literacy and sleep disorders: a review. Sleep Med Rev. Apr. 2008;12(2):143-51. [pmid: 18222098].
1082 Haggstrom DA, Schapira MM. Black-white differences in risk perceptions of breast cancer survival and screening mammography benefit. J Gen Intern Med. Apr. 2006;21(4):371-7. [pmid: 16686816].
1083 Hahn EA, Cella D. Health outcomes assessment in vulnerable populations: measurement challenges and recommendations. Arch Phys Med Rehabil. Apr. 2003;84(4 Suppl 2):S35-42. [pmid: 12692770].
1084 Hahn EA, Cella D, Dobrez D, Shiomoto G, Marcus E, Taylor SG, et al. The talking touchscreen: a new approach to outcomes assessment in low literacy. Psychooncology. Feb. 2004;13(2):86-95. [pmid: 14872527].
1085 Hahn EA, Cella D, Dobrez DG, Weiss BD, Du H, Lai JS, et al. The impact of literacy on health-related quality of life measurement and outcomes in cancer outpatients. Qual Life Res. Apr. 2007;16(3):495-507. [pmid: 17091362].
1086 Hahn EA, Cellal D, Dobrez DG, Shiomoto G, Taylor SG, Galvez AG, et al. Quality of life assessment for low literacy Latinos: a new multimedia program for self-administration. J Oncol Manag. Sep-Oct. 2003;12(5):9-12. [pmid: 14619989].
1087 Hahn EA, Rao D, Cella D, Choi SW. Comparability of interview- and self-administration of the Functional Assessment of Cancer Therapy-General (FACT-G) in English- and Spanish-speaking ambulatory cancer patients. Med Care. Apr. 2008;46(4):423-31. [pmid: 18362823].
1088 Haigh J. Information technology in health professional education: why IT matters. Nurse Educ Today. Oct. 2004;24(7):547-52. [pmid: 15465170].
1089 Halberg F, Cornelissen G, Schack B, Wendt HW, Minne H, Sothern RB, et al. Blood pressure self-surveillance for health also reflects 1.3-year Richardson solar wind variation: spin-off from chronomics. Biomed Pharmacother. Oct. 1. 2003;57:58s-76s. [pmid: 14572679].
1090 Haldar A, Gupta UD, Majumdar KK, Laskar K, Ghosh S, Sen S. Community perception of Dengue in slum areas of metropolitan city of West Bengal. J Commun Dis. Sep. 2008;40(3):205-10. [pmid: 19245159].
1091 Haldar A, Mundle M, Ray A, Haldar S. Acute lower respiratory tract infection among under- fives in urban eastern India--an appraisal of risk factors. J Commun Dis. Sep. 2005;37(3):203-8. [pmid: 17080704].
1092 Haldar A, Saha S, Mandal S, Haldar S, Mundle M, Mitra SP. Life events as risk factors for myocardial infarction: a pilot case-control study in Kolkata, India. J Health Popul Nutr. Jun. 2005;23(2):131-6. [pmid: 16117364].
1093 Hall CD, Fabayo AO. Nursing students' adjustment to a new phenomenon. J Natl Black Nurses Assoc. Dec. 2006;17(2):24-9. [pmid: 17410756].
1094 Hall J, Donelle L. Research with women serving court-mandated probation or parole orders. Can J Nurs Res. Jun. 2009;41(2):37-53. [pmid: 19650512].
1095 Hall KM, Culatta B, Black S. Curriculum-based emergent literacy assessment in early childhood. Semin Speech Lang. Feb. 2007;28(1):3-13. [pmid: 17340378].
1096 Haller DM, Sanci LA, Sawyer SM, Patton GC. The identification of young people's emotional distress: a study in primary care. Br J Gen Pract. Mar. 2009;59(560):e61-70. [pmid: 19275825].
1097 Halliday LF, Bishop DV. Frequency discrimination and literacy skills in children with mild to moderate sensorineural hearing loss. J Speech Lang Hear Res. Oct. 2005;48(5):1187-203. [pmid: 16411805].
1098 Halliday LF, Bishop DV. Is poor frequency modulation detection linked to literacy problems? A comparison of specific reading disability and mild to moderate sensorineural hearing loss. Brain Lang. May. 2006;97(2):200-13. [pmid: 16330093].
1099 Halling A, Fridh G, Ovhed I. Validating the Johns Hopkins ACG Case-Mix System of the elderly in Swedish primary health care. BMC Public Health. 2006;6:171. [pmid: 16805909].
1100 Halter MJ, Kleiner C, Hess RF. The experience of nursing students in an online doctoral program in nursing: a phenomenological study. Int J Nurs Stud. Jan. 2006;43(1):99-105. [pmid: 16326165].
1101 Hamdan JM, Amayreh MM. Consonant profile of Arabic-speaking school-age children in Jordan. Folia Phoniatr Logop. 2007;59(2):55-64. [pmid: 17337895].
1102 Hamer B. A capacity-building model for implementing a nursing best practice. J Nurses Staff Dev. Jan-Feb. 2008;24(1):36-42. [pmid: 18349769].
1103 Hamilton AS, Hofer TP, Hawley ST, Morrell D, Leventhal M, Deapen D, et al. Latinas and breast cancer outcomes: population-based sampling, ethnic identity, and acculturation assessment. Cancer Epidemiol Biomarkers Prev. Jul. 2009;18(7):2022-9. [pmid: 19549806].
1104 Hamilton S. How do we assess the learning style of our patients?. Rehabil Nurs. Jul-Aug. 2005;30(4):129-31. [pmid: 15999856].
1105 Hamilton SS, Glascoe FP. Evaluation of children with reading difficulties. Am Fam Physician. Dec. 15. 2006;74(12):2079-84. [pmid: 17186715].
1106 Hammer CS, Rodriguez BL, Lawrence FR, Miccio AW. Puerto Rican mothers' beliefs and home literacy practices. Lang Speech Hear Serv Sch. Jul. 2007;38(3):216-24. [pmid: 17625048].
1107 Hammerschlag R, Lasater K, Salanti S, Fleishman S. Research scholars program: a faculty development initiative at the Oregon College of Oriental Medicine. J Altern Complement Med. May. 2008;14(4):437-43. [pmid: 18447630].
1108 Hammond A, Freeman K. The long-term outcomes from a randomized controlled trial of an educational-behavioural joint protection programme for people with rheumatoid arthritis. Clin Rehabil. Aug. 2004;18(5):520-8. [pmid: 15293486].
1109 Hamner J, Wilder B. Knowledge and risk of cardiovascular disease in rural Alabama women. J Am Acad Nurse Pract. Jun. 2008;20(6):333-8. [pmid: 18588661].
1110 Hamra M, Ross MW, Orrs M, D'Agostino A. Relationship between expressed HIV/AIDS-related stigma and HIV-beliefs/knowledge and behaviour in families of HIV infected children in Kenya. Trop Med Int Health. Apr. 2006;11(4):513-27. [pmid: 16553935].
1111 Hamrosi K, Taylor SJ, Aslani P. Issues with prescribed medications in Aboriginal communities: Aboriginal health workers' perspectives. Rural Remote Health. Apr-Jun. 2006;6(2):557. [pmid: 16683907].
1112 Han PK, Lehman TC, Massett H, Lee SJ, Klein WM, Freedman AN. Conceptual problems in laypersons' understanding of individualized cancer risk: a qualitative study. Health Expect. Mar. 2009;12(1):4-17. [pmid: 19250148].
1113 Hanck SE, Blankenship KM, Irwin KS, West BS, Kershaw T. Assessment of self-reported sexual behavior and condom use among female sex workers in India using a polling box approach: a preliminary report. Sex Transm Dis. May. 2008;35(5):489-94. [pmid: 18356771].
1114 Handley MA, Hammer H, Schillinger D. Navigating the terrain between research and practice: a Collaborative Research Network (CRN) case study in diabetes research. J Am Board Fam Med. Jan-Feb. 2006;19(1):85-92. [pmid: 16492010].
1115 Hanley E. Computer literacy: Where are nurse educators on the continuum?. Stud Health Technol Inform. 2006;122:505-9. [pmid: 17102309].
1116 Hansen DL, Derry HA, Resnick PJ, Richardson CR. Adolescents searching for health information on the Internet: an observational study. J Med Internet Res. Oct. 17. 2003;5(4):e25. [pmid: 14713653].
1117 Hanson-Divers EC. Developing a medical achievement reading test to evaluate patient literacy skills: a preliminary study. J Health Care Poor Underserved. Feb. 1997;8(1):56-69. [pmid: 9019026].
1118 Harbarth S, Albrich W, Pittet D. Semmelweis' legacy: insights from an international survey among 265,000 students in 32 countries. Int J Hyg Environ Health. Oct. 2004;207(5):481-5. [pmid: 15575564].
1119 Hardin LR. Counseling patients with low health literacy. Am J Health Syst Pharm. Feb. 15. 2005;62(4):364-5. [pmid: 15745888].
1120 Hardyman R, Hardy P, Brodie J, Stephens R. It's good to talk: comparison of a telephone helpline and website for cancer information. Patient Educ Couns. Jun. 2005;57(3):315-20. [pmid: 15893214].
1121 Harper W, Cook S, Makoul G. Teaching medical students about health literacy: 2 Chicago initiatives. Am J Health Behav. Sep-Oct. 1. 2007;31:S111-4. [pmid: 17931129].
1122 Harrington S. Overweight in Latino/Hispanic adolescents: scope of the problem and nursing implications. Pediatr Nurs. Sep-Oct. 2008;34(5):389-94. [pmid: 19051842].
1123 Harris JR, Brown PK, Coughlin S, Fernandez ME, Hebert JR, Kerner J, et al. The cancer prevention and control research network. Prev Chronic Dis. Jan. 2005;2(1):A21. [pmid: 15670474].
1124 Harrison TC, Mackert M, Watkins C. Health literacy issues among women with visual impairments. Res Gerontol Nurs. Jan. 2010;3(1):49-60. [pmid: 20128543].
1125 Hart A, Henwood F, Wyatt S. The role of the Internet in patient-practitioner relationships: findings from a qualitative research study. J Med Internet Res. Sep. 30. 2004;6(3):e36. [pmid: 15471762].
1126 Hart LM, Jorm AF, Kanowski LG, Kelly CM, Langlands RL. Mental health first aid for Indigenous Australians: using Delphi consensus studies to develop guidelines for culturally appropriate responses to mental health problems. BMC Psychiatry. 2009;9:47. [pmid: 19646284].
1127 Hart P, Scherz J, Apel K, Hodson B. Analysis of spelling error patterns of individuals with complex communication needs and physical impairments. Augment Altern Commun. Mar. 2007;23(1):16-29. [pmid: 17364485].
1128 Harvard-Hinchberger PA. Using innovative strategies to enhance health promotion critical literacy. Nurs Forum. Jan-Mar. 2006;41(1):25-9. [pmid: 16512870].
1129 Harwell TS, Law DG, Ander JL, Helgerson SD. Increasing state public health professionals' proficiency in using PubMed. J Med Libr Assoc. Apr. 2008;96(2):134-7. [pmid: 18379668].
1130 Haslum MN, Miles TR. Motor performance and dyslexia in a national cohort of 10-year-old children. Dyslexia. Nov. 2007;13(4):257-75. [pmid: 17948879].
1131 Hatcher PJ. Reading intervention: a 'conventional' and successful approach to helping dyslexic children acquire literacy. Dyslexia. Aug. 2003;9(3):140-5. discussion 67-76. [pmid: 12940296].
1132 Hatcher PJ, Goetz K, Snowling MJ, Hulme C, Gibbs S, Smith G. Evidence for the effectiveness of the Early Literacy Support programme. Br J Educ Psychol. Jun. 2006;76(Pt 2):351-67. [pmid: 16719968].
1133 Hatcher PJ, Hulme C, Miles JN, Carroll JM, Hatcher J, Gibbs S, et al. Efficacy of small group reading intervention for beginning readers with reading-delay: a randomised controlled trial. J Child Psychol Psychiatry. Aug. 2006;47(8):820-7. [pmid: 16898996].
1134 Haveman R, Smeeding T. The role of higher education in social mobility. Future Child. Fall. 2006;16(2):125-50. [pmid: 17036549].
1135 Hawley ST, Janz NK, Hamilton A, Griggs JJ, Alderman AK, Mujahid M, et al. Latina patient perspectives about informed treatment decision making for breast cancer. Patient Educ Couns. Nov. 2008;73(2):363-70. [pmid: 18786799].
1136 Hawley ST, Zikmund-Fisher B, Ubel P, Jancovic A, Lucas T, Fagerlin A. The impact of the format of graphical presentation on health-related knowledge and treatment choices. Patient Educ Couns. Dec. 2008;73(3):448-55. [pmid: 18755566].
1137 Hay DA, O'Brien PJ, Johnston CJ, Prior M. The high incidence of reading disability in twin boys and its implications for genetic analyses. Acta Genet Med Gemellol (Roma). 1984;33(2):223-36. [pmid: 6540955].
1138 Hayes H, Luchok K, Martin AB, McKeown RE, Evans A. Short birth intervals and the risk of school unreadiness among a Medicaid population in South Carolina. Child Care Health Dev. Jul. 2006;32(4):423-30. [pmid: 16784498].
1139 Hayes K. Designing written medication instructions: effective ways to help older adults self-medicate. J Gerontol Nurs. May. 2005;31(5):5-10. [pmid: 15916198].
1140 Hayes M, Ross IE, Gasher M, Gutstein D, Dunn JR, Hackett RA. Telling stories: news media, health literacy and public policy in Canada. Soc Sci Med. May. 2007;64(9):1842-52. [pmid: 17337317].
1141 Hayiou-Thomas ME. Genetic and environmental influences on early speech, language and literacy development. J Commun Disord. Sep-Oct. 2008;41(5):397-408. [pmid: 18538338].
1142 Hayward S. Networks: better language required. Healthc Pap. 2006;7(2):62-6. discussion 8-75. [pmid: 17167321].
1143 Haywood K, Marshall S, Fitzpatrick R. Patient participation in the consultation process: a structured review of intervention strategies. Patient Educ Couns. Oct. 2006;63(1-2):12-23. [pmid: 16406464].
1144 Hazarey VK, Erlewad DM, Mundhe KA, Ughade SN. Oral submucous fibrosis: study of 1000 cases from central India. J Oral Pathol Med. Jan. 2007;36(1):12-7. [pmid: 17181736].
1145 He M, Chan V, Baruwa E, Gilbert D, Frick KD, Congdon N. Willingness to pay for cataract surgery in rural Southern China. Ophthalmology. Mar. 2007;114(3):411-6. [pmid: 17197026].
1146 He N, Detels R, Chen Z, Jiang Q, Zhu J, Dai Y, et al. Sexual behavior among employed male rural migrants in Shanghai, China. AIDS Educ Prev. Apr. 2006;18(2):176-86. [pmid: 16649962].
1147 He N, Detels R, Zhu J, Jiang Q, Chen Z, Fang Y, et al. Characteristics and sexually transmitted diseases of male rural migrants in a metropolitan area of Eastern China. Sex Transm Dis. May. 2005;32(5):286-92. [pmid: 15849529].
1148 Heath SM, Hogben JH. The reliability and validity of tasks measuring perception of rapid sequences in children with dyslexia. J Child Psychol Psychiatry. Oct. 2004;45(7):1275-87. [pmid: 15335347].
1149 Hecker R. Participatory action research as a strategy for empowering aboriginal health workers. Aust N Z J Public Health. Dec. 1997;21(7):784-8. [pmid: 9489200].
1150 Heimburger DC. Training and certifying Physician Nutrition Specialists: the American Board of Physician Nutrition Specialists (ABPNS). Am J Clin Nutr. Apr. 2006;83(4):985S-7S. [pmid: 16600961].
1151 Heisler M, Piette JD, Spencer M, Kieffer E, Vijan S. The relationship between knowledge of recent HbA1c values and diabetes care understanding and self-management. Diabetes Care. Apr. 2005;28(4):816-22. [pmid: 15793179].
1152 Hejaili FF, Assad L, Shaheen FA, Moussa DH, Karkar A, AlRukhaimi M, et al. Culture-related service expectations: a comparative study using the Kano model. Qual Manag Health Care. Jan-Mar. 2009;18(1):48-58. [pmid: 19148029].
1153 Helitzer D, Hollis C, Cotner J, Oestreicher N. Health literacy demands of written health information materials: an assessment of cervical cancer prevention materials. Cancer Control. Jan. 2009;16(1):70-8. [pmid: 19078933].
1154 Helland T. Dyslexia at a behavioural and a cognitive level. Dyslexia. Feb. 2007;13(1):25-41. [pmid: 17330734].
1155 Helland T, Asbjornsen AE, Hushovd AE, Hugdahl K. Dichotic listening and school performance in dyslexia. Dyslexia. Feb. 2008;14(1):42-53. [pmid: 17676714].
1156 Helland T, Kaasa R. Dyslexia in English as a second language. Dyslexia. Feb. 2005;11(1):41-60. [pmid: 15747806].
1157 Hellems MA, Gurka MJ, Hayden GF. Statistical literacy for readers of Pediatrics: a moving target. Pediatrics. Jun. 2007;119(6):1083-8. [pmid: 17545374].
1158 Hemming HE, Langille L. Building knowledge in literacy and health. Can J Public Health. May-Jun. 2. 2006;97:S31-6. [pmid: 16805159].
1159 Hendrickson SG. Video recruitment of non-English-speaking participants. West J Nurs Res. Mar. 2007;29(2):232-42. [pmid: 17337624].
1160 Henquet C, Krabbendam L, de Graaf R, ten Have M, van Os J. Cannabis use and expression of mania in the general population. J Affect Disord. Oct. 2006;95(1-3):103-10. [pmid: 16793142].
1161 Hepworth N, Paxton SJ. Pathways to help-seeking in bulimia nervosa and binge eating problems: a concept mapping approach. Int J Eat Disord. Sep. 2007;40(6):493-504. [pmid: 17573682].
1162 Hepworth NS, Paxton SJ, Williams B. Predictors of attitudes towards treatments for bulimia nervosa. Aust N Z J Psychiatry. Mar. 2007;41(3):247-56. [pmid: 17464706].
1163 Herenda S, Tahirovic H, Zildzic M. Impact of education on metabolic control in type 2 diabetic patients in family practice. Med Arh. 2007;61(4):236-9. [pmid: 18297999].
1164 Herlitz A, Kabir ZN. Sex differences in cognition among illiterate Bangladeshis: a comparison with literate Bangladeshis and Swedes. Scand J Psychol. Dec. 2006;47(6):441-7. [pmid: 17107492].
1165 Hernandez Hernandez P, Rodriguez Mateo H. Success in chess mediated by mental molds. Psicothema. Nov. 2006;18(4):704-10. [pmid: 17296106].
1166 Herrera AP, Snipes SA, King DW, Torres-Vigil I, Goldberg DS, Weinberg AD. Disparate inclusion of older adults in clinical trials: priorities and opportunities for policy and practice change. Am J Public Health. Apr. 1. 1. 2010;100:S105-12. [pmid: 20147682].
1167 Herrmann E, Call J, Hernandez-Lloreda MV, Hare B, Tomasello M. Humans have evolved specialized skills of social cognition: the cultural intelligence hypothesis. Science. Sep. 7. 2007;317(5843):1360-6. [pmid: 17823346].
1168 Herzberger S. Nursing media-educated patients. J Nurses Staff Dev. May-Jun. 2008;24(3):101-4. [pmid: 18525409].
1169 Heshka JT, Palleschi C, Howley H, Wilson B, Wells PS. A systematic review of perceived risks, psychological and behavioral impacts of genetic testing. Genet Med. Jan. 2008;10(1):19-32. [pmid: 18197053].
1170 Hesketh A. Early literacy achievement of children with a history of speech problems. Int J Lang Commun Disord. Oct-Dec. 2004;39(4):453-68. [pmid: 15691075].
1171 Hesketh A, Dima E, Nelson V. Teaching phoneme awareness to pre-literate children with speech disorder: a randomized controlled trial. Int J Lang Commun Disord. May-Jun. 2007;42(3):251-71. [pmid: 17514541].
1172 Hess J, Whelan JS. Making health literacy real: adult literacy and medical students teach each other. J Med Libr Assoc. Jul. 2009;97(3):221-4. [pmid: 19626149].
1173 Hess RF, McKinney D. Fatalism and HIV/AIDS beliefs in rural Mali, West Africa. J Nurs Scholarsh. 2007;39(2):113-8. [pmid: 17535310].
1174 Hessari H, Vehkalahti MM, Eghbal MJ, Murtomaa H. Tooth loss and prosthodontic rehabilitation among 35- to 44-year-old Iranians. J Oral Rehabil. Apr. 2008;35(4):245-51. [pmid: 18321259].
1175 Hester EJ, Stevens-Ratchford R. Health literacy and the role of the speech-language pathologist. Am J Speech Lang Pathol. May. 2009;18(2):180-91. [pmid: 19332527].
1176 Hetherington R, Dennis M, Barnes M, Drake J, Gentili F. Functional outcome in young adults with spina bifida and hydrocephalus. Childs Nerv Syst. Feb. 2006;22(2):117-24. [pmid: 16170574].
1177 Hetzroni OE. AAC and literacy. Disabil Rehabil. Nov. 4-18. 2004;26(21-22):1305-12. [pmid: 15513730].
1178 Hewer LA, Whyatt D. Improving the implementation of an early literacy program by child health nurses through addressing local training and cultural needs. Contemp Nurse. Oct. 2006;23(1):111-9. [pmid: 17083324].
1179 Hewison A. Evidence-based policy: implications for nursing and policy involvement. Policy Polit Nurs Pract. Nov. 2008;9(4):288-98. [pmid: 18981059].
1180 Hibbard JH, Peters E, Dixon A, Tusler M. Consumer competencies and the use of comparative quality information: it isn't just about literacy. Med Care Res Rev. Aug. 2007;64(4):379-94. [pmid: 17684108].
1181 Hickie AMI, Davenport TA, Luscombe GM, Rong Y, Hickie ML, Bell MI. The assessment of depression awareness and help-seeking behaviour: experiences with the International Depression Literacy Survey. BMC Psychiatry. 2007;7:48. [pmid: 17850674].
1182 Hicks G, Barragan M, Franco-Paredes C, Williams MV, del Rio C. Health literacy is a predictor of HIV/AIDS knowledge. Fam Med. Nov-Dec. 2006;38(10):717-23. [pmid: 17075745].
1183 Hijazi ZM, Marshall JJ. Seconds-Count.org offers enhanced tools for patients and physicians. Catheter Cardiovasc Interv. Dec. 1. 2008;72(7):1027-9. [pmid: 19031412].
1184 Hildrum B, Mykletun A, Midthjell K, Ismail K, Dahl AA. No association of depression and anxiety with the metabolic syndrome: the Norwegian HUNT study. Acta Psychiatr Scand. Jul. 2009;120(1):14-22. [pmid: 19120047].
1185 Hill AJ. Motivation for eating behaviour in adolescent girls: the body beautiful. Proc Nutr Soc. Nov. 2006;65(4):376-84. [pmid: 17181904].
1186 Hill SC, Lindsay GB. Using health infomercials to develop media literacy skills. J Sch Health. Aug. 2003;73(6):239-41. [pmid: 12899106].
1187 Hill W, Weinert C, Cudney S. Influence of a computer intervention on the psychological status of chronically ill rural women: preliminary results. Nurs Res. Jan-Feb. 2006;55(1):34-42. [pmid: 16439927].
1188 Hill WG, Weinert C. An evaluation of an online intervention to provide social support and health education. Comput Inform Nurs. Sep-Oct. 2004;22(5):282-8. [pmid: 15520598].
1189 Hill-Briggs F, Renosky R, Lazo M, Bone L, Hill M, Levine D, et al. Development and pilot evaluation of literacy-adapted diabetes and CVD education in urban, diabetic African Americans. J Gen Intern Med. Sep. 2008;23(9):1491-4. [pmid: 18521688].
1190 Hill-Briggs F, Smith AS. Evaluation of diabetes and cardiovascular disease print patient education materials for use with low-health literate populations. Diabetes Care. Apr. 2008;31(4):667-71. [pmid: 18202245].
1191 Hillman CH, Pontifex MB, Raine LB, Castelli DM, Hall EE, Kramer AF. The effect of acute treadmill walking on cognitive control and academic achievement in preadolescent children. Neuroscience. Mar. 31. 2009;159(3):1044-54. [pmid: 19356688].
1192 Hiltunen LA. Are there associations between socio-economic status and known diabetes in an elderly Finnish population?. Cent Eur J Public Health. Dec. 2005;13(4):187-90. [pmid: 16419383].
1193 Hilty DM, Hales DJ, Briscoe G, Benjamin S, Boland RJ, Luo JS, et al. APA Summit on Medical Student Education Task Force on Informatics and Technology: learning about computers and applying computer technology to education and practice. Acad Psychiatry. Jan-Feb. 2006;30(1):29-35. [pmid: 16473991].
1194 Hindin TJ, Contento IR, Gussow JD. A media literacy nutrition education curriculum for head start parents about the effects of television advertising on their children's food requests. J Am Diet Assoc. Feb. 2004;104(2):192-8. [pmid: 14760566].
1195 Hironaka LK, Paasche-Orlow MK. The implications of health literacy on patient-provider communication. Arch Dis Child. May. 2008;93(5):428-32. [pmid: 17916588].
1196 Hiscock H, Canterford L, Ukoumunne OC, Wake M. Adverse associations of sleep problems in Australian preschoolers: national population study. Pediatrics. Jan. 2007;119(1):86-93. [pmid: 17200274].
1197 Hixon AL. Functional health literacy: improving health outcomes. Am Fam Physician. May. 1. 2004;69(9):2077-8. [pmid: 15152955].
1198 Ho CS, Chan DW, Lee SH, Tsang SM, Luan VH. Cognitive profiling and preliminary subtyping in Chinese developmental dyslexia. Cognition. Feb. 2004;91(1):43-75. [pmid: 14711491].
1199 Ho JE, Paultre F, Mosca L. Is diabetes mellitus a cardiovascular disease risk equivalent for fatal stroke in women? Data from the Women's Pooling Project. Stroke. Dec. 2003;34(12):2812-6. [pmid: 14657546].
1200 Hobbs BB, Farr LA. Assessing internet survey data collection methods with ethnic nurse shift workers. Chronobiol Int. 2004;21(6):1003-13. [pmid: 15646245].
1201 Hobbs R, Broder S, Pope H, Rowe J. How adolescent girls interpret weight-loss advertising. Health Educ Res. Oct. 2006;21(5):719-30. [pmid: 16880220].
1202 Hochhauser M. The continuing critical issue is health literacy. Manag Care Interface. Aug. 2003;16(8):23-4. 9. [pmid: 12964549].
1203 Hochhauser M. In other words … clearing a path … helping patients understand medical-legal information. Interview by Helen Osborne. Prairie Rose. May-Jul. 2006;75(2):15-6. [pmid: 19264080].
1204 Hodge T, Downie J. Together we are heard: effectiveness of daily ‘language’ groups in a community preschool. Nurs Health Sci. Jun. 2004;6(2):101-7. [pmid: 15130095].
1205 Hodgins W. Distance education but beyond: “meLearning”--what if the impossible isn't?. J Vet Med Educ. Summer. 2007;34(3):325-9. [pmid: 17673792].
1206 Hoffman-Goetz L, Donelle L, Thomson MD. Clinical guidelines about diabetes and the accuracy of peer information in an unmoderated online health forum for retired persons. Inform Health Soc Care. Mar. 2009;34(2):91-9. [pmid: 19412842].
1207 Hoffmann T, McKenna K. Analysis of stroke patients' and carers' reading ability and the content and design of written materials: recommendations for improving written stroke information. Patient Educ Couns. Mar. 2006;60(3):286-93. [pmid: 16098708].
1208 Hohenadel J, Kaegi E, Laidlaw J, Kovacik G, Cortinois A, Kang R, et al. Leveling the playing field: the personal coach program as an innovative approach to assess and address the supportive care needs of underserved cancer patients. J Support Oncol. Apr. 2007;5(4):185-93. [pmid: 17500506].
1209 Holdsworth M, Delpeuch F, Landais E, Gartner A, Eymard-Duvernay S, Maire B. Knowledge of dietary and behaviour-related determinants of non-communicable disease in urban Senegalese women. Public Health Nutr. Dec. 2006;9(8):975-81. [pmid: 17125559].
1210 Hollis V, Madill H. Online learning: the potential for occupational therapy education. Occup Ther Int. 2006;13(2):61-78. [pmid: 16862957].
1211 Holm A, Farrier F, Dodd B. Phonological awareness, reading accuracy and spelling ability of children with inconsistent phonological disorder. Int J Lang Commun Disord. May-Jun. 2008;43(3):300-22. [pmid: 17852519].
1212 Holmes B, Dick K, Nelson M. A comparison of four dietary assessment methods in materially deprived households in England. Public Health Nutr. May. 2008;11(5):444-56. [pmid: 17672921].
1213 Holmes M, Bacon TJ, Dobson LA, McGorty EK, Silberman P, DeWalt D, et al. Addressing health literacy through improved patient-practitioner communication. N C Med J. Sep-Oct. 2007;68(5):319-26. [pmid: 18183750].
1214 Holmes-Rovner M, Price C, Rovner DR, Kelly-Blake K, Lillie J, Wills C, et al. Men's theories about benign prostatic hyperplasia and prostate cancer following a benign prostatic hyperplasia decision aid. J Gen Intern Med. Jan. 2006;21(1):56-60. [pmid: 16423124].
1215 Holmes-Rovner M, Stableford S, Fagerlin A, Wei JT, Dunn RL, Ohene-Frempong J, et al. Evidence-based patient choice: a prostate cancer decision aid in plain language. BMC Med Inform Decis Mak. 2005;5:16. [pmid: 15963238].
1216 Holmstrom I. Decision aid software programs in telenursing: not used as intended? Experiences of Swedish telenurses. Nurs Health Sci. Mar. 2007;9(1):23-8. [pmid: 17300541].
1217 Holzemer WL, Bakken S, Portillo CJ, Grimes R, Welch J, Wantland D, et al. Testing a nurse-tailored HIV medication adherence intervention. Nurs Res. May-Jun. 2006;55(3):189-97. [pmid: 16708043].
1218 Honey M. Flexible learning for postgraduate nurses: a basis for planning. Nurse Educ Today. May. 2004;24(4):319-25. [pmid: 15110442].
1219 Honey M, North N, Gunn C. Improving library services for graduate nurse students in New Zealand. Health Info Libr J. Jun. 2006;23(2):102-9. [pmid: 16706865].
1220 Honeybourne C, Sutton S, Ward L. Knowledge in the Palm of your hands: PDAs in the clinical setting. Health Info Libr J. Mar. 2006;23(1):51-9. [pmid: 16466499].
1221 Hood KK, Bennett Johnson S, Carmichael SK, Laffel LM, She JX, Schatz DA. Depressive symptoms in mothers of infants identified as genetically at risk for type 1 diabetes. Diabetes Care. Aug. 2005;28(8):1898-903. [pmid: 16043729].
1222 Hooli RS. Computers in nursing. Nurs J India. Feb. 2003;94(2):26-8. [pmid: 14520808].
1223 Hope CJ, Wu J, Tu W, Young J, Murray MD. Association of medication adherence, knowledge, and skills with emergency department visits by adults 50 years or older with congestive heart failure. Am J Health Syst Pharm. Oct. 1. 2004;61(19):2043-9. [pmid: 15509127].
1224 Hopkins DD. The emergence of online learning in PN Education. J Pract Nurs. Winter. 2008;58(4):4-7. [pmid: 19260361].
1225 Hopkins RB, Paradis J, Roshankar T, Bowen J, Tarride JE, Blackhouse G, et al. Universal or targeted screening for fetal alcohol exposure: a cost-effectiveness analysis. J Stud Alcohol Drugs. Jul. 2008;69(4):510-9. [pmid: 18612566].
1226 Horng YS, Hwang YH, Wu HC, Liang HW, Mhe YJ, Twu FC, et al. Predicting health-related quality of life in patients with low back pain. Spine. Mar. 1. 2005;30(5):551-5. [pmid: 15738789].
1227 Horowitz AM. The role of health literacy in reducing health disparities. J Dent Hyg. Fall. 2009;83(4):182-3. [pmid: 19909638].
1228 Horowitz AM, Kleinman DV. Oral health literacy: the new imperative to better oral health. Dent Clin North Am. Apr. 2008;52(2):333-44. vi. [pmid: 18329447].
1229 Hosler AS, Melnik TA. Population-based assessment of diabetes care and self-management among Puerto Rican adults in New York City. Diabetes Educ. May-Jun. 2005;31(3):418-26. [pmid: 15919642].
1230 Hoss B, Hanson D. Evaluating the evidence: web sites. AORN J. Jan. 2008;87(1):124-41. [pmid: 18184597].
1231 Hosseinpoor AR, Van Doorslaer E, Speybroeck N, Naghavi M, Mohammad K, Majdzadeh R, et al. Decomposing socioeconomic inequality in infant mortality in Iran. Int J Epidemiol. Oct. 2006;35(5):1211-9. [pmid: 16987848].
1232 Hostgaard AM, Nohr C. Dealing with organizational change when implementing EHR systems. Stud Health Technol Inform. 2004;107(Pt 1):631-4. [pmid: 15360889].
1233 Hou SI. Experience of colorectal cancer screening using a home-administered kit for fecal occult blood tests among a Chinese worksite population in Taiwan. Psychol Rep. Feb. 2005;96(1):178-80. [pmid: 15825922].
1234 Houck PW, Whitehouse FR. Asthma prevention in urbanites. J Asthma. Oct. 2006;43(8):573-8. [pmid: 17050220].
1235 Houlden RL, Raja JB, Collier CP, Clark AF, Waugh JM. Medical students' perceptions of an undergraduate research elective. Med Teach. Nov. 2004;26(7):659-61. [pmid: 15763861].
1236 Hounton SH, Akonde A, Zannou DM, Bashi J, Meda N, Newlands D. Costing universal access of highly active antiretroviral therapy in Benin. AIDS Care. May. 2008;20(5):582-7. [pmid: 18484329].
1237 House JS, Lantz PM, Herd P. Continuity and change in the social stratification of aging and health over the life course: evidence from a nationally representative longitudinal study from 1986 to 2001/2002 (Americans' Changing Lives Study). J Gerontol B Psychol Sci Soc Sci. Oct. 2005;60 Spec No 2:15-26. [pmid: 16251586].
1238 Houts PS, Doak CC, Doak LG, Loscalzo MJ. The role of pictures in improving health communication: a review of research on attention, comprehension, recall, and adherence. Patient Educ Couns. May. 2006;61(2):173-90. [pmid: 16122896].
1239 Houweling TA, Caspar AE, Looman WN, Mackenbach JP. Determinants of under-5 mortality among the poor and the rich: a cross-national analysis of 43 developing countries. Int J Epidemiol. Dec. 2005;34(6):1257-65. [pmid: 16159940].
1240 Howard DH, Gazmararian J, Parker RM. The impact of low health literacy on the medical costs of Medicare managed care enrollees. Am J Med. Apr. 2005;118(4):371-7. [pmid: 15808134].
1241 Howard DH, Sentell T, Gazmararian JA. Impact of health literacy on socioeconomic and racial differences in health in an elderly population. J Gen Intern Med. Aug. 2006;21(8):857-61. [pmid: 16881947].
1242 Howatson-Jones L. Designing web-based education courses for nurses. Nurs Stand. Nov. 24-30. 2004;19(11):41-4. [pmid: 15615171].
1243 Hsu HM, Hsiao HW, Huang IJ, Lin IC. Factors associated with computer literacy among nurses. Stud Health Technol Inform. 2006;122:190-3. [pmid: 17102246].
1244 Hsu LL. An exploratory study of Taiwanese consumers' experiences of using health-related websites. J Nurs Res. Jun. 2005;13(2):129-40. [pmid: 15986314].
1245 Huang KC, Hsu SH. Effects of numbers of strokes on Chinese character recognition during a normal reading condition. Percept Mot Skills. Dec. 2005;101(3):845-52. [pmid: 16491688].
1246 Huckstadt A, Hayes K. Evaluation of interactive online courses for advanced practice nurses. J Am Acad Nurse Pract. Mar. 2005;17(3):85-9. [pmid: 15748220].
1247 Hudson MM, Mertens AC, Yasui Y, Hobbie W, Chen H, Gurney JG, et al. Health status of adult long-term survivors of childhood cancer: a report from the Childhood Cancer Survivor Study. JAMA. Sep. 24. 2003;290(12):1583-92. [pmid: 14506117].
1248 Hughes JM, Fallis DW, Peel JL, Murchison DF. Learning styles of orthodontic residents. J Dent Educ. Mar. 2009;73(3):319-27. [pmid: 19289721].
1249 Hughes RB, Robinson-Whelen S, Taylor HB, Petersen NJ, Nosek MA. Characteristics of depressed and nondepressed women with physical disabilities. Arch Phys Med Rehabil. Mar. 2005;86(3):473-9. [pmid: 15759231].
1250 Hughes S, Dennison CR. Progress in prevention: how can we help patients seek information on the World Wide Web?: an opportunity to improve the “net effect”. J Cardiovasc Nurs. Jul-Aug. 2008;23(4):324-5. [pmid: 18596493].
1251 Huisman M, Kunst A, Deeg D, Grigoletto F, Nusselder W, Mackenbach J. Educational inequalities in the prevalence and incidence of disability in Italy and the Netherlands were observed. J Clin Epidemiol. Oct. 2005;58(10):1058-65. [pmid: 16168352].
1252 Huizinga MM, Beech BM, Cavanaugh KL, Elasy TA, Rothman RL. Low numeracy skills are associated with higher BMI. Obesity (Silver Spring). Aug. 2008;16(8):1966-8. [pmid: 18535541].
1253 Huizinga MM, Carlisle AJ, Cavanaugh KL, Davis DL, Gregory RP, Schlundt DG, et al. Literacy, numeracy, and portion-size estimation skills. Am J Prev Med. Apr. 2009;36(4):324-8. [pmid: 19285197].
1254 Huizinga MM, Elasy TA, Wallston KA, Cavanaugh K, Davis D, Gregory RP, et al. Development and validation of the Diabetes Numeracy Test (DNT). BMC Health Serv Res. 2008;8:96. [pmid: 18452617].
1255 Hunley SA, Evans JH, Delgado-Hachey M, Krise J, Rich T, Schell C. Adolescent computer use and academic achievement. Adolescence. Summer. 2005;40(158):307-18. [pmid: 16114593].
1256 Hunt MK, Barbeau EM, Lederman R, Stoddard AM, Chetkovich C, Goldman R, et al. Process evaluation results from the Healthy Directions-Small Business study. Health Educ Behav. Feb. 2007;34(1):90-107. [pmid: 16740502].
1257 Hunter JL. Cervical cancer educational pamphlets: Do they miss the mark for Mexican immigrant women's needs?. Cancer Control. Nov. 2. 2005;12:42-50. [pmid: 16327750].
1258 Hussain T, Kulshreshtha KK, Sinha S, Yadav VS, Katoch VM. HIV, HBV, HCV, and syphilis co-infections among patients attending the STD clinics of district hospitals in Northern India. Int J Infect Dis. Sep. 2006;10(5):358-63. [pmid: 16678462].
1259 Husting PM, Cintron L. Healthcare information systems: education lessons learned. J Nurses Staff Dev. Sep-Oct. 2003;19(5):253-7. [pmid: 14581834].
1260 Huston SA, Hobson EH. Using focus groups to inform pharmacy research. Res Social Adm Pharm. Sep. 2008;4(3):186-205. [pmid: 18794031].
1261 Hutchinson JM, Whiteley HE, Smith CD, Connors L. The early identification of dyslexia: children with English as an additional language. Dyslexia. Aug. 2004;10(3):179-95. [pmid: 15341197].
1262 Hutton BM. Do school qualifications predict competence in nursing calculations?. Nurse Educ Today. Jan. 1998;18(1):25-31. [pmid: 9528527].
1263 Hutton BM. Numeracy must become a priority for nurses. Br J Nurs. Jul 27-Aug 9. 2000;9(14):894. [pmid: 11261023].
1264 Hutton M. Numeracy skills for intravenous calculations. Nurs Stand. Jul. 15-21. 1998;12(43):49-52. quiz 5-6. [pmid: 9776933].
1265 Hwang HG, Chen RF, Chang LH, Hsiao JL. A study of the informatics literacy of clinical nurses in Taiwan. Comput Inform Nurs. Sep-Oct. 2008;26(5):290-9. [pmid: 18769184].
1266 Hwang HL, Lin HS, Tung YL, Wu HC. Correlates of perceived autonomy among elders in a senior citizen home: a cross-sectional survey. Int J Nurs Stud. May. 2006;43(4):429-37. [pmid: 16109420].
1267 Hwang SW, Tram CQ, Knarr N. The effect of illustrations on patient comprehension of medication instruction labels. BMC Fam Pract. Jun. 16. 2005;6(1):26. [pmid: 15960849].
1268 Hyman SL, Arthur Shores E, North KN. Learning disabilities in children with neurofibromatosis type 1: subtypes, cognitive profile, and attention-deficit-hyperactivity disorder. Dev Med Child Neurol. Dec. 2006;48(12):973-7. [pmid: 17109785].
1269 Ianchulev T, Pham P, Makarov V, Francis B, Minckler D. Peristat: a computer-based perimetry self-test for cost-effective population screening of glaucoma. Curr Eye Res. Jan. 2005;30(1):1-6. [pmid: 15875358].
1270 Ibrahim SY, Reid F, Shaw A, Rowlands G, Gomez GB, Chesnokov M, et al. Validation of a health literacy screening tool (REALM) in a UK population with coronary heart disease. J Public Health (Oxf). Dec. 2008;30(4):449-55. [pmid: 18660507].
1271 Icks A, Moebus S, Feuersenger A, Haastert B, Jockel KH, Mielck A, et al. Widening of a social gradient in obesity risk? German national health surveys 1990 and 1998. Eur J Epidemiol. 2007;22(10):685-90. [pmid: 17674126].
1272 IJurg ME, De Meij JS, Van der Wal MF, Koelen MA. Using health promotion outcomes in formative evaluation studies to predict success factors in interventions: an application to an intervention for promoting physical activity in Dutch children (JUMP-in). Health Promot Int. Sep. 2008;23(3):231-9. [pmid: 18408231].
1273 Ikeako LC, Onah HE, Iloabachie GC. Influence of formal maternal education on the use of maternity services in Enugu, Nigeria. J Obstet Gynaecol. Jan. 2006;26(1):30-4. [pmid: 16390706].
1274 Ikechebelu JI, Joe-Ikechebelu NN, Obiajulu FN. Knowledge, attitude and practice of family planning among Igbo women of south-eastern Nigeria. J Obstet Gynaecol. Nov. 2005;25(8):792-5. [pmid: 16368587].
1275 Ikechebelu JI, Okoli CC. Morbidity and mortality following induced abortion in Nnewi, Nigeria. Trop Doct. Jul. 2003;33(3):170-2. [pmid: 12870609].
1276 Iliffe S, Kharicha K, Carmaciu C, Harari D, Swift C, Gillman G, et al. The relationship between pain intensity and severity and depression in older people: exploratory study. BMC Fam Pract. 2009;10:54. [pmid: 19638205].
1277 Iliffe S, Kharicha K, Harari D, Swift C, Gillmann G, Stuck AE. Health risk appraisal in older people 2: the implications for clinicians and commissioners of social isolation risk in older people. Br J Gen Pract. Apr. 2007;57(537):277-82. [pmid: 17394730].
1278 Iliyasu Z, Abubakar IS, Kabir M, Abbas SM. Computing knowledge, attitude and skills among healthcare professionals in Aminu Kano Teaching Hospital, Nigeria. Niger J Med. Apr-Jun. 2005;14(2):200-5. [pmid: 16083246].
1279 Im EO, Chee W. The use of Internet cancer support groups by ethnic minorities. J Transcult Nurs. Jan. 2008;19(1):74-82. [pmid: 18217235].
1280 Inamdar SC, Rotti SB. Computer use among medical students in an institution in southern India. Natl Med J India. Jan-Feb. 2004;17(1):8-10. [pmid: 15115224].
1281 Inglebret E, Jones C, Pavel DM. Integrating American Indian/alaska Native culture into shared storybook intervention. Lang Speech Hear Serv Sch. Oct. 2008;39(4):521-7. [pmid: 18820093].
1282 Inglis V, Ball K, Crawford D. Socioeconomic variations in women's diets: what is the role of perceptions of the local food environment?. J Epidemiol Community Health. Mar. 2008;62(3):191-7. [pmid: 18272732].
1283 Innes G. Faculty-librarian collaboration: an online information literacy tutorial for students. Nurse Educ. Jul-Aug. 2008;33(4):145-6. [pmid: 18600151].
1284 Iosifescu A, Halm EA, McGinn T, Siu AL, Federman AD. Beliefs about generic drugs among elderly adults in hospital-based primary care practices. Patient Educ Couns. Nov. 2008;73(2):377-83. [pmid: 18706784].
1285 Iredale R, Elwyn G, Edwards A, Gray J. Attitudes of genetic clinicians in Wales to the future development of cancer genetics services. J Eval Clin Pract. Feb. 2007;13(1):86-9. [pmid: 17286728].
1286 Iribarren C, Darbinian J, Klatsky AL, Friedman GD. Cohort study of exposure to environmental tobacco smoke and risk of first ischemic stroke and transient ischemic attack. Neuroepidemiology. Jan-Apr. 2004;23(1-2):38-44. [pmid: 14739566].
1287 Isaacs EB, Edmonds CJ, Lucas A, Gadian DG. Calculation difficulties in children of very low birthweight: a neural correlate. Brain. Sep. 2001;124(Pt 9):1701-7. [pmid: 11522573].
1288 Isaacs EB, Lucas A, Chong WK, Wood SJ, Johnson CL, Marshall C, et al. Hippocampal volume and everyday memory in children of very low birth weight. Pediatr Res. Jun. 2000;47(6):713-20. [pmid: 10832727].
1289 Isezuo SA, Abubakar SA. Epidemiologic profile of peripartum cardiomyopathy in a tertiary care hospital. Ethn Dis. Spring. 2007;17(2):228-33. [pmid: 17682350].
1290 Ishikawa H, Nomura K, Sato M, Yano E. Developing a measure of communicative and critical health literacy: a pilot study of Japanese office workers. Health Promot Int. Sep. 2008;23(3):269-74. [pmid: 18515303].
1291 Ishikawa H, Takeuchi T, Yano E. Measuring functional, communicative, and critical health literacy among diabetic patients. Diabetes Care. May. 2008;31(5):874-9. [pmid: 18299446].
1292 Ishikawa H, Yano E. Patient health literacy and participation in the health-care process. Health Expect. Jun. 2008;11(2):113-22. [pmid: 18494956].
1293 Ishikawa H, Yano E, Fujimori S, Kinoshita M, Yamanouchi T, Yoshikawa M, et al. Patient health literacy and patient-physician information exchange during a visit. Fam Pract. Dec. 2009;26(6):517-23. [pmid: 19812242].
1294 Ishiyama I, Nagai A, Muto K, Tamakoshi A, Kokado M, Mimura K, et al. Relationship between public attitudes toward genomic studies related to medicine and their level of genomic literacy in Japan. Am J Med Genet A. Jul. 1. 2008;146A(13):1696-706. [pmid: 18546279].
1295 Ito KE, Kalyanaraman S, Ford CA, Brown JD, Miller WC. “Let's Talk About Sex”: pilot study of an interactive CD-ROM to prevent HIV/STIS in female adolescents. AIDS Educ Prev. Feb. 2008;20(1):78-89. [pmid: 18312069].
1296 Iuculano T, Tang J, Hall CW, Butterworth B. Core information processing deficits in developmental dyscalculia and low numeracy. Dev Sci. Sep. 2008;11(5):669-80. [pmid: 18801122].
1297 Iughetti L, De Simone M, Verrotti A, Iezzi ML, Predieri B, Bruzzi P, et al. Thirty-year persistence of obesity after presentation to a pediatric obesity clinic. Ann Hum Biol. Jul-Aug. 2008;35(4):439-48. [pmid: 18654874].
1298 Ivanitskaya L, O'Boyle I, Casey AM. Health information literacy and competencies of information age students: results from the interactive online Research Readiness Self-Assessment (RRSA). J Med Internet Res. 2006;8(2):e6. [pmid: 16867969].
1299 Ives TJ, Chelminski PR, Hammett-Stabler CA, Malone RM, Perhac JS, Potisek NM, et al. Predictors of opioid misuse in patients with chronic pain: a prospective cohort study. BMC Health Serv Res. 2006;6:46. [pmid: 16595013].
1300 Jackson R. Health literacy: an introduction to the literature. J Indiana Dent Assoc. Winter. 2005;84(4):10-3. [pmid: 16605212].
1301 Jackson R. Parental health literacy and children's dental health: implications for the future. Pediatr Dent. Jan-Feb. 2006;28(1):72-5. [pmid: 16615379].
1302 Jackson RD, Coan LL, Hughes E, Eckert GJ. Introduction of health literacy into the allied dental curriculum: first steps and plans for the future. J Dent Educ. Mar. 2010;74(3):318-24. [pmid: 20203332].
1303 Jacobs SK, Rosenfeld P, Haber J. Information literacy as the foundation for evidence-based practice in graduate nursing education: a curriculum-integrated approach. J Prof Nurs. Sep-Oct. 2003;19(5):320-8. [pmid: 14613072].
1304 Jacobsen HE. A comparison of on-campus first year undergraduate nursing students' experiences with face-to-face and on-line discussions. Nurse Educ Today. Aug. 2006;26(6):494-500. [pmid: 16519969].
1305 Jacobson RM. Teaching numeracy to physicians-in-training. Quantitative analysis for evidence-based medicine. Minn Med. Nov. 2007;90(11):37-8. 46. [pmid: 18072471].
1306 Jafary FH, Aslam F, Mahmud H, Waheed A, Shakir M, Afzal A, et al. Cardiovascular health knowledge and behavior in patient attendants at four tertiary care hospitals in Pakistan--a cause for concern. BMC Public Health. 2005;5:124. [pmid: 16309553].
1307 Jahan S. Poverty and infant mortality in the Eastern Mediterranean region: a meta-analysis. J Epidemiol Community Health. Aug. 2008;62(8):745-51. [pmid: 18621962].
1308 Jakeway CC, Cantrell EE, Cason JB, Talley BS. Developing population health competencies among public health nurses in Georgia. Public Health Nurs. Mar-Apr. 2006;23(2):161-7. [pmid: 16684190].
1309 James DG, van Doorn J, McLeod S. The contribution of polysyllabic words in clinical decision making about children's speech. Clin Linguist Phon. Apr-May. 2008;22(4-5):345-53. [pmid: 18415734].
1310 Jamieson LM, Parker EJ, Richards L. Using qualitative methodology to inform an Indigenous-owned oral health promotion initiative in Australia. Health Promot Int. Mar. 2008;23(1):52-9. [pmid: 18056724].
1311 Janes R, Arroll B, Buetow S, Coster G, McCormick R, Hague I. Few rural general practitioners use the Internet frequently in regard to patient care. N Z Med J. Apr. 1. 2005;118(1212):U1380. [pmid: 15806182].
1312 Jansen W, Brug J. Parents often do not recognize overweight in their child, regardless of their socio-demographic background. Eur J Public Health. Dec. 2006;16(6):645-7. [pmid: 16837515].
1313 Jefferson AL, Wong S, Gracer TS, Ozonoff A, Green RC, Stern RA. Geriatric performance on an abbreviated version of the Boston naming test. Appl Neuropsychol. 2007;14(3):215-23. [pmid: 17848132].
1314 Jellema P, van der Horst HE, Vlaeyen JW, Stalman WA, Bouter LM, van der Windt DA. Predictors of outcome in patients with (sub)acute low back pain differ across treatment groups. Spine. Jul. 1. 2006;31(15):1699-705. [pmid: 16816766].
1315 Jenkins J, Grady PA, Collins FS. Nurses and the genomic revolution. J Nurs Scholarsh. 2005;37(2):98-101. [pmid: 15960052].
1316 Jenkins ML, Hewitt C, Bakken S. Women's health nursing in the context of the National Health Information Infrastructure. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2006;35(1):141-50.
1317 Jenks KM, de Moor J, van Lieshout EC, Maathuis KG, Keus I, Gorter JW. The effect of cerebral palsy on arithmetic accuracy is mediated by working memory, intelligence, early numeracy, and instruction time. Dev Neuropsychol. 2007;32(3):861-79. [pmid: 17956186].
1318 Jeppesen KM, Coyle JD, Miser WF. Screening questions to predict limited health literacy: a cross-sectional study of patients with diabetes mellitus. Ann Fam Med. Jan-Feb. 2009;7(1):24-31. [pmid: 19139446].
1319 Jerger S, Damian MF, Spence MJ, Tye-Murray N, Abdi H. Developmental shifts in children's sensitivity to visual speech: a new multimodal picture-word task. J Exp Child Psychol. Jan. 2009;102(1):40-59. [pmid: 18829049].
1320 Jerome J, Frantino EP, Sturmey P. The effects of errorless learning and backward chaining on the acquisition of Internet skills in adults with developmental disabilities. J Appl Behav Anal. Spring. 2007;40(1):185-9. [pmid: 17471803].
1321 Jerrett M, Burnett RT, Brook J, Kanaroglou P, Giovis C, Finkelstein N, et al. Do socioeconomic characteristics modify the short term association between air pollution and mortality? Evidence from a zonal time series in Hamilton, Canada. J Epidemiol Community Health. Jan. 2004;58(1):31-40. [pmid: 14684724].
1322 Jha N, Singh R, Baral D. Knowledge, attitude and practices of mothers regarding home management of acute diarrhoea in Sunsari, Nepal. Nepal Med Coll J. Mar. 2006;8(1):27-30. [pmid: 16827086].
1323 Jiang HJ, Lockee C, Bass K, Fraser I. Board engagement in quality: findings of a survey of hospital and system leaders. J Healthc Manag. Mar-Apr. 2008;53(2):121-34. discussion 35. [pmid: 18421996].
1324 Jiang WW, Chen W, Chen YC. Important computer competencies for the nursing profession. J Nurs Res. Sep. 2004;12(3):213-26. [pmid: 15362013].
1325 Jibaja-Weiss ML, Volk RJ. Utilizing computerized entertainment education in the development of decision aids for lower literate and naive computer users. J Health Commun. Oct-Nov. 2007;12(7):681-97. [pmid: 17934944].
1326 Jibaja-Weiss ML, Volk RJ, Friedman LC, Granchi TS, Neff NE, Spann SJ, et al. Preliminary testing of a just-in-time, user-defined values clarification exercise to aid lower literate women in making informed breast cancer treatment decisions. Health Expect. Sep. 2006;9(3):218-31. [pmid: 16911136].
1327 Johnson A, Sandford J, Tyndall J. Written and verbal information versus verbal information only for patients being discharged from acute hospital settings to home. Cochrane Database Syst Rev. 2003;(4):CD003716. [pmid: 14583990].
1328 Johnson CM, Smolenski D. Risk assessment models to estimate cancer probabilities. Curr Oncol Rep. Nov. 2007;9(6):503-8. [pmid: 17991360].
1329 Johnson ED, Pancoast PE, Mitchell JA, Shyu CR. Design and evaluation of a personal digital assistant- based alerting service for clinicians. J Med Libr Assoc. Oct. 2004;92(4):438-44. [pmid: 15494759].
1330 Johnson IL, Ashley MJ, Reynolds D, Goettler F, Lee-Han H, Stratton J, et al. Prevalence of smoking associated with pregnancy in three Southern Ontario Health Units. Can J Public Health. May-Jun. 2004;95(3):209-13. [pmid: 15191134].
1331 Johnson JD, Case DO, Andrews JE, Allard SL. Genomics--the perfect information-seeking research problem. J Health Commun. Jun. 2005;10(4):323-9. [pmid: 16036739].
1332 Johnson K, Weiss BD. How long does it take to assess literacy skills in clinical practice?. J Am Board Fam Med. May-Jun. 2008;21(3):211-4. [pmid: 18467532].
1333 Johnson KR, Layng TV. Breaking the structuralist barrier. Literacy and numeracy with fluency. Am Psychol. Nov. 1992;47(11):1475-90. [pmid: 1482008].
1334 Johnson RM, Smith P, Strauss EJ, Higgins A, Jensen DR, Weiss BD. Breast cancer screening in an adult literacy program. Alaska Med. Jan-Mar. 2008;49(4):126-30. [pmid: 18491805].
1335 Johnson T, Ventura R. Applied informatics for quality assessment and improvement. J Nurs Care Qua_. Apr-Jun. 2004;19(2):100-4.
1336 Johnson TV, Goodman M, Master VA. The efficacy of written screening tools in an inner city hospital: literacy based limitations on patient access to appropriate care. J Urol. Aug. 2007;178(2):623-9. discussion 9. [pmid: 17570427].
1337 Johnston A, Bruno A, Watanabe J, Quansah B, Patel N, Dakin S, et al. Visually-based temporal distortion in dyslexia. Vision Res. Aug. 2008;48(17):1852-8. [pmid: 18589473].
1338 Johnston JM, Leung GM, Tin KY, Ho LM, Lam W, Fielding R. Evaluation of a handheld clinical decision support tool for evidence-based learning and practice in medical undergraduates. Med Educ. Jun. 2004;38(6):628-37. [pmid: 15189259].
1339 Johnston MV, Diab ME, Kim SS, Kirshblum S. Health literacy, morbidity, and quality of life among individuals with spinal cord injury. J Spinal Cord Med. 2005;28(3):230-40. [pmid: 16048141].
1340 Johnston MV, Pogach L, Rajan M, Mitchinson A, Krein SL, Bonacker K, et al. Personal and treatment factors associated with foot self-care among veterans with diabetes. J Rehabil Res Dev. Mar-Apr. 2006;43(2):227-38. [pmid: 16847789].
1341 Jones M, Lee JY, Rozier RG. Oral health literacy among adult patients seeking dental care. J Am Dent Assoc. Sep. 2007;138(9):1199-208. quiz 266-7. [pmid: 17785385].
1342 Jones MW, Englestad DM. “Womb” literacy: reading to infants in the NICU. Neonatal Netw. Jul-Aug. 2004;23(4):65-9. [pmid: 15317385].
1343 Jones PM. Quality improvement initiative to integrate teaching diabetes standards into home care visits. Diabetes Educ. Nov-Dec. 2002;28(6):1009-20. [pmid: 12526641].
1344 Jones RA. Randomized, controlled trial of dexamethasone in neonatal chronic lung disease: 13- to 17-year follow-up study: I. Neurologic, psychological, and educational outcomes. Pediatrics. Aug. 2005;116(2):370-8. [pmid: 16061591].
1345 Jones S, Murphy F, Edwards M, James J. Doing things differently: advantages and disadvantages of Web questionnaires. Nurse Res. 2008;15(4):15-26. [pmid: 18700656].
1346 Jones S, Murphy F, Edwards M, James J. Using online questionnaires to conduct nursing research. Nurs Times. Nov. 25. Dec. 1. 2008;104(47):66-9. [pmid: 19068893].
1347 Jorgensen E, Sokas RK, Nickels L, Gao W, Gittleman JL. An English/Spanish safety climate scale for construction workers. Am J Ind Med. Jun. 2007;50(6):438-42. [pmid: 17492632].
1348 Jorm AF. The Informant Questionnaire on cognitive decline in the elderly (IQCODE): a review. Int Psychogeriatr. Sep. 2004;16(3):275-93. [pmid: 15559753].
1349 Jorm AF, Christensen H, Griffiths KM. The impact of beyondblue: the national depression initiative on the Australian public's recognition of depression and beliefs about treatments. Aust N Z J Psychiatry. Apr. 2005;39(4):248-54. [pmid: 15777361].
1350 Jorm AF, Christensen H, Griffiths KM. Changes in depression awareness and attitudes in Australia: the impact of beyondblue: the national depression initiative. Aust N Z J Psychiatry. Jan. 2006;40(1):42-6. [pmid: 16403036].
1351 Jorm AF, Griffiths KM, Christensen H, Korten AE, Parslow RA, Rodgers B. Providing information about the effectiveness of treatment options to depressed people in the community: a randomized controlled trial of effects on mental health literacy, help-seeking and symptoms. Psychol Med. Aug. 2003;33(6):1071-9. [pmid: 12946091].
1352 Jorm AF, Nakane Y, Christensen H, Yoshioka K, Griffiths KM, Wata Y. Public beliefs about treatment and outcome of mental disorders: a comparison of Australia and Japan. BMC Med. 2005;3:12. [pmid: 16004615].
1353 Jorm AF, Oh E. Desire for social distance from people with mental disorders. Aust N Z J Psychiatry. Mar. 2009;43(3):183-200. [pmid: 19221907].
1354 Joshi MS, Hines SC. Getting the board on board: Engaging hospital boards in quality and patient safety. Jt Comm J Qual Patient Saf. Apr. 2006;32(4):179-87. [pmid: 16649648].
1355 Joshi PT, Dalton ME, O'Donnell DA. Ethical issues in local, national, and international disaster psychiatry. Child Adolesc Psychiatr Clin N Am. Jan. 2008;17(1):165-85. x. xi. [pmid: 18036485].
1356 Joshi S, Gokhale S. Status of mastitis as an emerging disease in improved and periurban dairy farms in India. Ann N Y Acad Sci. Oct. 2006;1081:74-83. [pmid: 17135496].
1357 Jotkowitz A, Porath A. Health literacy, access to care and outcomes of care. Am J Bioeth. Nov. 2007;7(11):25-7. discussion W1-2. [pmid: 18027296].
1358 Jukes M, Simmons S, Bundy D. Education and vulnerability: the role of schools in protecting young women and girls from HIV in southern Africa. AIDS. Dec. 2008;22(Suppl 4):S41-56. [pmid: 19033754].
1359 Jukkala A, Deupree JP, Graham S. Knowledge of limited health literacy at an academic health center. J Contin Educ Nurs. Jul. 2009;40(7):298-302. quiz 3-4, 36. [pmid: 19639850].
1360 Jurdi R, Khawaja M. Caesarean section rates in the Arab region: a cross-national study. Health Policy Plan. Mar. 2004;19(2):101-10. [pmid: 14982888].
1361 Justice LM. Evidence-based practice, response to intervention, and the prevention of reading difficulties. Lang Speech Hear Serv Sch. Oct. 2006;37(4):284-97. [pmid: 17041078].
1362 Justice LM, Bowles RP, Skibbe LE. Measuring preschool attainment of print-concept knowledge: a study of typical and at-risk 3- to 5-year-old children using item response theory. Lang Speech Hear Serv Sch. Jul. 2006;37(3):224-35. [pmid: 16837445].
1363 Justice LM, Chow SM, Capellini C, Flanigan K, Colton S. Emergent literacy intervention for vulnerable preschoolers: relative effects of two approaches. Am J Speech Lang Pathol. Aug. 2003;12(3):320-32. [pmid: 12971821].
1364 Justice LM, Ezell HK. Print referencing: an emergent literacy enhancement strategy and its clinical applications. Lang Speech Hear Serv Sch. Apr. 2004;35(2):185-93. [pmid: 15191329].
1365 Justice LM, Kaderavek JN. Embedded-explicit emergent literacy intervention I: Background and description of approach. Lang Speech Hear Serv Sch. Jul. 2004;35(3):201-11. [pmid: 15248791].
1366 Justice LM, Kaderavek JN, Fan X, Sofka A, Hunt A. Accelerating preschoolers' early literacy development through classroom-based teacher-child storybook reading and explicit print referencing. Lang Speech Hear Serv Sch. Jan. 2009;40(1):67-85. [pmid: 19124650].
1367 Justice LM, Sofka AE, McGinty A. Targets, techniques, and treatment contexts in emergent literacy intervention. Semin Speech Lang. Feb. 2007;28(1):14-24. [pmid: 17340379].
1368 Jutel A. Beyond evidence-based nursing: tools for practice. J Nurs Manag. May. 2008;16(4):417-21. [pmid: 18405258].
1369 Juzych MS, Randhawa S, Shukairy A, Kaushal P, Gupta A, Shalauta N. Functional health literacy in patients with glaucoma in urban settings. Arch Ophthalmol. May. 2008;126(5):718-24. [pmid: 18474786].
1370 Kaati G, Bygren LO, Pembrey M, Sjostrom M. Transgenerational response to nutrition, early life circumstances and longevity. Eur J Hum Genet. Jul. 2007;15(7):784-90. [pmid: 17457370].
1371 Kabakian-Khasholian T, Campbell OM. Impact of written information on women's use of postpartum services: a randomised controlled trial. Acta Obstet Gynecol Scand. 2007;86(7):793-8. [pmid: 17611823].
1372 Kaderavek JN, Justice LM. Embedded-explicit emergent literacy intervention II: goal selection and implementation in the early childhood classroom. Lang Speech Hear Serv Sch. Jul. 2004;35(3):212-28. [pmid: 15248792].
1373 Kaderavek JN, Pakulski LA. Facilitating literacy development in young children with hearing loss. Semin Speech Lang. Feb. 2007;28(1):69-78. [pmid: 17340384].
1374 Kagawa-Singer M, Tanjasiri SP, Valdez A, Yu H, Foo MA. Outcomes of a breast health project for Hmong women and men in California. Am J Public Health. Oct. 2. 2009;99:S467-73. [pmid: 19443830].
1375 Kalanda BF, van Buuren S, Verhoeff FH, Brabin BJ. Catch-up growth in Malawian babies, a longitudinal study of normal and low birthweight babies born in a malarious endemic area. Early Hum Dev. Oct. 2005;81(10):841-50. [pmid: 16109465].
1376 Kalanda BF, Verhoeff FH, Brabin BJ. Chronic malnutrition in pregnant adolescents in rural Malawi: an anthropometric study. Acta Obstet Gynecol Scand. 2006;85(1):33-9. [pmid: 16521677].
1377 Kalasagar M, Sivapathasundharam B, Einstein TB. AIDS awareness in an Indian metropolitan slum dweller: a KAP (knowledge, attitude, practice) study. Indian J Dent Res. Apr-Jun. 2006;17(2):66-9. [pmid: 17051870].
1378 Kalediene R, Petrauskiene J. Inequalities in mortality by education and socio-economic transition in Lithuania: equal opportunities?. Public Health. Sep. 2005;119(9):808-15. [pmid: 15913676].
1379 Kalichman SC, Amaral CM, Stearns H, White D, Flanagan J, Pope H, et al. Adherence to antiretroviral therapy assessed by unannounced pill counts conducted by telephone. J Gen Intern Med. Jul. 2007;22(7):1003-6. [pmid: 17390095].
1380 Kalichman SC, Cain D, Fuhrel A, Eaton L, Di Fonzo K, Ertl T. Assessing medication adherence self-efficacy among low-literacy patients: development of a pictographic visual analogue scale. Health Educ Res. Feb. 2005;20(1):24-35. [pmid: 15253999].
1381 Kalichman SC, Catz S, Ramachandran B. Barriers to HIV/AIDS treatment and treatment adherence among African-American adults with disadvantaged education. J Natl Med Assoc. Aug. 1999;91(8):439-46. [pmid: 12656432].
1382 Kalichman SC, Cherry J, Cain D. Nurse-delivered antiretroviral treatment adherence intervention for people with low literacy skills and living with HIV/AIDS. J Assoc Nurses AIDS Care. Sep-Oct. 2005;16(5):3-15. [pmid: 16433105].
1383 Kalichman SC, Pope H, White D, Cherry C, Amaral CM, Swetzes C, et al. Association between health literacy and HIV treatment adherence: further evidence from objectively measured medication adherence. J Int Assoc Physicians AIDS Care (Chic Ill). Nov-Dec. 2008;7(6):317-23.
1384 Kalichman SC, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. J Gen Intern Med. May. 1999;14(5):267-73. [pmid: 10337035].
1385 Kamath J, Storlie D, Ferguson J. EMR competency: supporting quality, safe and effective care. AMIA Annu Symp Proc. 2006:974.
1386 Kamble S, Boyd AS. Health disparities and social determinants of health among African-American women undergoing percutaneous coronary interventions (PCI). J Cult Divers. Fall. 2008;15(3):132-42. [pmid: 19025201].
1387 Kamphaus RW, DiStefano C, Lease AM. A self-report typology of behavioral adjustment for young children. Psychol Assess. Mar. 2003;15(1):17-28. [pmid: 12674721].
1388 Kamps D, Abbott M, Greenwood C, Wills H, Veerkamp M, Kaufman J. Effects of small-group reading instruction and curriculum differences for students most at risk in kindergartenL: two-year results for secondary- and tertiary-level interventions. J Learn Disabil. Mar-Apr. 2008;41(2):101-14. [pmid: 18354931].
1389 Kamps DM, Greenwood CR. Formulating secondary-level reading interventions. J Learn Disabil. Nov-Dec. 2005;38(6):500-9. [pmid: 16392691].
1390 Kane SV. Strategies to improve adherence and outcomes in patients with ulcerative colitis. Drugs. 2008;68(18):2601-9. [pmid: 19093702].
1391 Kaneko Y, Motohashi Y. Male gender and low education with poor mental health literacy: a population-based study. J Epidemiol. Jul. 2007;17(4):114-9. [pmid: 17641446].
1392 Kang E, Fields HW, Cornett S, Beck FM. An evaluation of pediatric dental patient education materials using contemporary health literacy measures. Pediatr Dent. Sep-Oct. 2005;27(5):409-13. [pmid: 16435642].
1393 Kang EY, Fields HW, Kiyak A, Beck FM, Firestone AR. Informed consent recall and comprehension in orthodontics: traditional vs improved readability and processability methods. Am J Orthod Dentofacial Orthop. Oct. e1. 2009;136(4):488-13. discussion -9. [pmid: 19815144].
1394 Kanny EM, Smith R, Dudgeon BJ. Genetics in occupational therapy education: a survey of professional entry-level programs. Am J Occup Ther. Mar-Apr. 2005;59(2):165-72. [pmid: 15830616].
1395 Kantor A. A new level of understanding. Health insurers are developing health literacy initiatives and taking steps to help consumers get clear information. AHIP Cover. Nov-Dec. 2006;47(6):18-22. [pmid: 17175736].
1396 Kaona FA, Tuba M, Siziya S, Sikaona L. An assessment of factors contributing to treatment adherence and knowledge of TB transmission among patients on TB treatment. BMC Public Health. Dec. 29. 2004;4:68. [pmid: 15625004].
1397 Kaphingst KA, Rudd RE, DeJong W, Daltroy LH. Literacy demands of product information intended to supplement television direct-to-consumer prescription drug advertisements. Patient Educ Couns. Nov. 2004;55(2):293-300. [pmid: 15530767].
1398 Kaphingst KA, Rudd RE, Dejong W, Daltroy LH. Comprehension of information in three direct-to-consumer television prescription drug advertisements among adults with limited literacy. J Health Commun. Oct-Nov. 2005;10(7):609-19. [pmid: 16278198].
1399 Kaphingst KA, Zanfini CJ, Emmons KM. Accessibility of web sites containing colorectal cancer information to adults with limited literacy (United States). Cancer Causes Control. Mar. 2006;17(2):147-51. [pmid: 16425092].
1400 Kaplan B. Deriving design recommendations through discount usability engineering: ethnographic observation and thinking-aloud protocol in usability testing for computer-based teaching cases. AMIA Annu Symp Proc. 2003:346-50.
1401 Kaposy C. The real-life consequences of being denied access to an abortion. Am J Bioeth. Aug. 2007;7(8):34-6. discussion W3. [pmid: 17710701].
1402 Karande S, Patil S, Kulkarni M. Impact of an educational program on parental knowledge of cerebral palsy. Indian J Pediatr. Sep. 2008;75(9):901-6. [pmid: 18810366].
1403 Karjalainen J, Peltonen M, Vanhala M, Korpi-Hyovalti E, Puolijoki H, Saltevo J, et al. Leisure time physical activity in individuals with screen-detected type 2 diabetes compared to those with known type 2 diabetes. Diabetes Res Clin Pract. Jul. 2008;81(1):110-6. [pmid: 18433914].
1404 Karmaliani R, Bann CM, Mahmood MA, Harris HS, Akhtar S, Goldenberg RL, et al. Measuring antenatal depression and anxiety: findings from a community-based study of women in Hyderabad, Pakistan. Women Health. 2006;44(3):79-103. [pmid: 17255067].
1405 Karter AJ, Stevens MR, Brown AF, Duru OK, Gregg EW, Gary TL, et al. Educational disparities in health behaviors among patients with diabetes: the Translating Research Into Action for Diabetes (TRIAD) Study. BMC Public Health. 2007;7:308. [pmid: 17967177].
1406 Karwowski W. Ergonomics and human factors: the paradigms for science, engineering, design, technology and management of human-compatible systems. Ergonomics. Apr. 15. 2005;48(5):436-63. [pmid: 16040519].
1407 Kasparian NA, Wakefield CE, Meiser B. Assessment of psychosocial outcomes in genetic counseling research: an overview of available measurement scales. J Genet Couns. Dec. 2007;16(6):693-712. [pmid: 17694397].
1408 Kasper J, Kopke S, Muhlhauser I, Heesen C. Evidence-based patient information about treatment of multiple sclerosis--a phase one study on comprehension and emotional responses. Patient Educ Couns. Jul. 2006;62(1):56-63. [pmid: 16098706].
1409 Katz MG, Jacobson TA, Veledar E, Kripalani S. Patient literacy and question-asking behavior during the medical encounter: a mixed-methods analysis. J Gen Intern Med. Jun. 2007;22(6):782-6. [pmid: 17431697].
1410 Kaufman DR, Patel VL, Hilliman C, Morin PC, Pevzner J, Weinstock RS, et al. Usability in the real world: assessing medical information technologies in patients' homes. J Biomed Inform. Feb-Apr. 2003;36(1-2):45-60. [pmid: 14552846].
1411 Kaufman DR, Starren J, Patel VL, Morin PC, Hilliman C, Pevzner J, et al. A cognitive framework for understanding barriers to the productive use of a diabetes home telemedicine system. AMIA Annu Symp Proc. 2003:356-60.
1412 Kaufmann L, Handl P, Thony B. Evaluation of a numeracy intervention program focusing on basic numerical knowledge and conceptual knowledge: a pilot study. J Learn Disabil. Nov-Dec. 2003;36(6):564-73. [pmid: 15493438].
1413 Kay-Raining Bird E, Cleave PL, White D, Pike H, Helmkay A. Written and oral narratives of children and adolescents with Down syndrome. J Speech Lang Hear Res. Apr. 2008;51(2):436-50. [pmid: 18367688].
1414 Kazandjian S, Dupierrix E, Gaash E, Love IY, Zivotofsky AZ, De Agostini M, et al. Egocentric reference in bidirectional readers as measured by the straight-ahead pointing task. Brain Res. Jan. 9. 2009;1247:133-41. [pmid: 18973747].
1415 Kazlauskaite R, Soni S, Evans AT, Graham K, Fisher B. Accuracy of self-monitored blood glucose in type 2 diabetes. Diabetes Technol Ther. Jun. 2009;11(6):385-92. [pmid: 19459768].
1416 Ke LS, Chiu TY, Hu WY, Lo SS. Effects of educational intervention on nurses' knowledge, attitudes, and behavioral intentions toward supplying artificial nutrition and hydration to terminal cancer patients. Support Care Cancer. Nov. 2008;16(11):1265-72. [pmid: 18335258].
1417 Keefe RS, Eesley CE, Poe MP. Defining a cognitive function decrement in schizophrenia. Biol Psychiatry. Mar. 15. 2005;57(6):688-91. [pmid: 15780858].
1418 Keehner Engelke M, Guttu M, Warren MB, Swanson M. School nurse case management for children with chronic illness: health, academic, and quality of life outcomes. J Sch Nurs. Aug. 2008;24(4):205-14. [pmid: 18757353].
1419 Keeling JA, Rose JL, Beech AR. A comparison of the application of the self-regulation model of the relapse process for mainstream and special needs sexual offenders. Sex Abuse. Oct. 2006;18(4):373-82. [pmid: 17136624].
1420 Keeling JA, Rose JL, Beech AR. A preliminary evaluation of the adaptation of four assessments for offenders with special needs. J Intellect Dev Disabil. Jun. 2007;32(2):62-73. [pmid: 17613677].
1421 Kegley JA. An ethical imperative: genetics education for physicians and patients. Med Law. 2003;22(2):275-83. [pmid: 12889647].
1422 Keller C, Siegrist M, Visschers V. Effect of risk ladder format on risk perception in high- and low-numerate individuals. Risk Anal. Sep. 2009;29(9):1255-64. [pmid: 19572963].
1423 Keller DL, Wright J, Pace HA. Impact of health literacy on health outcomes in ambulatory care patients: a systematic review. Ann Pharmacother. Sep. 2008;42(9):1272-81. [pmid: 18648014].
1424 Kelly CM, Jorm AF, Rodgers B. Adolescents' responses to peers with depression or conduct disorder. Aust N Z J Psychiatry. Jan. 2006;40(1):63-6. [pmid: 16403041].
1425 Kelly CM, Jorm AF, Wright A. Improving mental health literacy as a strategy to facilitate early intervention for mental disorders. Med J Aust. Oct. 1. 2007;187(7 Suppl):S26-30. [pmid: 17908021].
1426 Kelly KM, Graves KD, Harper FW, Schmidt JE, Dickinson SL, Andrykowski MA. Assessing perceptions of cancer risk: does mode of assessment or numeracy matter?. Cancer Detect Prev. 2007;31(6):465-73. [pmid: 18061368].
1427 Kelly KM, Shedlosky-Shoemaker R, Porter K, Remy A, DeSimone P, Andrykowski MA. Cancer family history reporting: impact of method and psychosocial factors. J Genet Couns. Jun. 2007;16(3):373-82. [pmid: 17318453].
1428 Kelly KM, Sweet K. In search of a familial cancer risk assessment tool. Clin Genet. Jan. 2007;71(1):76-83. [pmid: 17204050].
1429 Kelly PA, Haidet P. Physician overestimation of patient literacy: a potential source of health care disparities. Patient Educ Couns. Apr. 2007;66(1):119-22. [pmid: 17140758].
1430 Kemper P, Savage C, Niederbaumer P, Anthony J. A study of the level of knowledge about diabetes management of low-income persons with diabetes. J Community Health Nurs. Winter. 2005;22(4):231-9. [pmid: 16245974].
1431 Kendig S. Word power: The effect of literacy on health outcomes. AWHONN Lifelines. Aug-Sep. 2006;10(4):327-31. [pmid: 16911266].
1432 Kendrick JM, Wilson C, Elder RF, Smith CS. Reliability of reporting of self-monitoring of blood glucose in pregnant women. J Obstet Gynecol Neonatal Nurs. May-Jun. 2005;34(3):329-34.
1433 Kennedy C, Charlesworth A, Chen JL. Interactive data collection: benefits of integrating new media into pediatric research. Comput Inform Nurs. May-Jun. 2003;21(3):120-7. [pmid: 12792192].
1434 Kennedy EJ, Flynn MC. Early phonological awareness and reading skills in children with Down syndrome. Downs Syndr Res Pract. Aug. 2003;8(3):100-9. [pmid: 14502837].
1435 Kennedy EJ, Flynn MC. Training phonological awareness skills in children with Down syndrome. Res Dev Disabil. Jan-Feb. 2003;24(1):44-57. [pmid: 12553967].
1436 Kennedy MG, Kiken L, Shipman JP. Addressing underutilization of consumer health information resource centers: a formative study. J Med Libr Assoc. Jan. 2008;96(1):42-9. [pmid: 18219380].
1437 Kennen EM, Davis TC, Huang J, Yu H, Carden D, Bass R, et al. Tipping the scales: the effect of literacy on obese patients' knowledge and readiness to lose weight. South Med J. Jan. 2005;98(1):15-8. [pmid: 15678634].
1438 Kenner C, Pressler JL, Loving G. New age literacy: expectations for deans. Nurse Educ. May-Jun. 2007;32(3):97-9. [pmid: 17496499].
1439 Kenyon S, Pike K, Jones DR, Brocklehurst P, Marlow N, Salt A, et al. Childhood outcomes after prescription of antibiotics to pregnant women with preterm rupture of the membranes: 7-year follow-up of the ORACLE I trial. Lancet. Oct. 11. 2008;372(9646):1310-8. [pmid: 18804274].
1440 Kenyon S, Pike K, Jones DR, Brocklehurst P, Marlow N, Salt A, et al. Childhood outcomes after prescription of antibiotics to pregnant women with spontaneous preterm labour: 7-year follow-up of the ORACLE II trial. Lancet. Oct. 11. 2008;372(9646):1319-27. [pmid: 18804276].
1441 Kerr D. Information in diabetes care: is there a need to dumb down even more?. Diabet Med. May. 2007;24(5):561-3. [pmid: 17367302].
1442 Keselman A, Tse T, Crowell J, Browne A, Ngo L, Zeng Q. Assessing consumer health vocabulary familiarity: an exploratory study. J Med Internet Res. 2007;9(1):e5. [pmid: 17478414].
1443 Kessels RP, Nys GM, Brands AM, van den Berg E, Van Zandvoort MJ. The modified Location Learning Test: norms for the assessment of spatial memory function in neuropsychological patients. Arch Clin Neuropsychol. Dec. 2006;21(8):841-6. [pmid: 17029688].
1444 Kessler TM, Nachbur BH, Kessler W. Patients' perception of preoperative information by interactive computer program-exemplified by cholecystectomy. Patient Educ Couns. Nov. 2005;59(2):135-40. [pmid: 16257617].
1445 Kestila L, Rahkonen O, Martelin T, Lahti-Koski M, Koskinen S. Do childhood social circumstances affect overweight and obesity in early adulthood?. Scand J Public Health. Mar. 2009;37(2):206-19. [pmid: 19141544].
1446 Khaleghian P. Decentralization and public services: the case of immunization. Soc Sci Med. Jul. 2004;59(1):163-83. [pmid: 15087152].
1447 Khan NZ, Muslima H, Parveen M, Bhattacharya M, Begum N, Chowdhury S, et al. Neurodevelopmental outcomes of preterm infants in Bangladesh. Pediatrics. Jul. 2006;118(1):280-9. [pmid: 16818576].
1448 Khan RI. Informed consent and some of its problems in Pakistan. J Pak Med Assoc. Feb. 2008;58(2):82-4. [pmid: 18333527].
1449 Khan TM, Sulaiman SA, Hassali MA, Anwar M, Wasif G, Khan AH. Community knowledge, attitudes, and beliefs towards depression in the state of Penang, Malaysia. Community Ment Health J. Feb. 2010;46(1):87-92. [pmid: 20146000].
1450 Khankari K, Eder M, Osborn CY, Makoul G, Clayman M, Skripkauskas S, et al. Improving colorectal cancer screening among the medically underserved: a pilot study within a federally qualified health center. J Gen Intern Med. Oct. 2007;22(10):1410-4. [pmid: 17653808].
1451 Kharicha K, Iliffe S, Harari D, Swift C, Gillmann G, Stuck AE. Health risk appraisal in older people 1: are older people living alone an “at-risk” group?. Br J Gen Pract. Apr. 2007;57(537):271-6. [pmid: 17394729].
1452 Kibble JD, Kingsbury J, Ramirez BU, Schlegel WM, Sokolove P. Effective use of course management systems to enhance student learning: Experimental Biology 2007. Adv Physiol Educ. Dec. 2007;31(4):377-9. [pmid: 18057417].
1453 Kielhofner G, Braveman B, Finlayson M, Paul-Ward A, Goldbaum L, Goldstein K. Outcomes of a vocational program for persons with AIDS. Am J Occup Ther. Jan-Feb. 2004;58(1):64-72. [pmid: 14763637].
1454 Kijsanayotin B, Pannarunothai S, Speedie S. Development of an instrument to measure health center (HC) personnel's computer use, knowledge and functionality demand for HC computerized information system in Thailand. AMIA Annu Symp Proc. 2005:1007.
1455 Kikwilu EN, Frencken JE, Masalu JR, Mulder J. Barriers to restorative care as perceived by dental practitioners in Tanzania. Community Dent Health. Mar. 2010;27(1):23-8. [pmid: 20426257].
1456 Kilbride HW, Thorstad K, Daily DK. Preschool outcome of less than 801-gram preterm infants compared with full-term siblings. Pediatrics. Apr. 2004;113(4):742-7. [pmid: 15060222].
1457 Kim J. Graduate students' experiences in web site development: a project assignment for nursing informatics class. Comput Inform Nurs. May-Jun. 2003;21(3):143-9. [pmid: 12792195].
1458 Kim JS, Lee EH, Park HC. Urinary incontinence: prevalence and knowledge among community-dwelling Korean women aged 55 and over. Taehan Kanho Hakhoe Chi. Jun. 2004;34(4):609-16. [pmid: 15502426].
1459 Kim S, Love F, Quistberg DA, Shea JA. Association of health literacy with self-management behavior in patients with diabetes. Diabetes Care. Dec. 2004;27(12):2980-2. [pmid: 15562219].
1460 Kim SH. Health literacy and functional health status in Korean older adults. J Clin Nurs. Aug. 2009;18(16):2337-43. [pmid: 19583664].
1461 Kind T, Wallace J, Moon RY. The digital divide: a comparison of online consumer health information for African-American and general audiences. J Natl Med Assoc. Nov. 2008;100(11):1333-40. [pmid: 19024231].
1462 King KM, Meehan BT, Trim RS, Chassin L. Marker or mediator? The effects of adolescent substance use on young adult educational attainment. Addiction. Dec. 2006;101(12):1730-40. [pmid: 17156172].
1463 King L, Hill AJ. Magazine adverts for healthy and less healthy foods: effects on recall but not hunger or food choice by preadolescent children. Appetite. Jul. 2008;51(1):194-7. [pmid: 18384910].
1464 King M, Walker C, Levy G, Bottomley C, Royston P, Weich S, et al. Development and validation of an international risk prediction algorithm for episodes of major depression in general practice attendees: the PredictD study. Arch Gen Psychiatry. Dec. 2008;65(12):1368-76. [pmid: 19047523].
1465 Kingsley KV, Kingsley K. A case study for teaching information literacy skills. BMC Med Educ. 2009;9:7. [pmid: 19178715].
1466 Kingston AH, Jorm AF, Kitchener BA, Hides L, Kelly CM, Morgan AJ, et al. Helping someone with problem drinking: mental health first aid guidelines - a Delphi expert consensus study. BMC Psychiatry. 2009;9:79. [pmid: 19968868].
1467 Kipnis DG, Frisby AJ. Information literacy and library attitudes of occupational therapy students. Med Ref Serv Q. Winter. 2006;25(4):11-20. [pmid: 17135148].
1468 Kirigia JM, Seddoh A, Gatwiri D, Muthuri LH, Seddoh J. E-health: determinants, opportunities, challenges and the way forward for countries in the WHO African Region. BMC Public Health. 2005;5:137. [pmid: 16364186].
1469 Kirk M, Tonkin E, Burke S. Engaging nurses in genetics: the strategic approach of the NHS National Genetics Education and Development Centre. J Genet Couns. Apr. 2008;17(2):180-8. [pmid: 17952577].
1470 Kirshner M, Salomon H, Chin H. One-on-one proficiency training: an evaluation of satisfaction and effectiveness using clinical information systems. AMIA Annu Symp Proc. 2003:366-70.
1471 Kishore PV, Palaian S, Paudel R, Paudel B, Mishra P, Prabhu M. Why treat? Better prevent: adult immunization. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2008;6(1):122-7. [pmid: 18604129].
1472 Kitchener BA, Jorm AF. Mental health first aid training in a workplace setting: a randomized controlled trial [ISRCTN13249129]. BMC Psychiatry. 2004;4:23. [pmid: 15310395].
1473 Kittler AF, Hobbs J, Volk LA, Kreps GL, Bates DW. The Internet as a vehicle to communicate health information during a public health emergency: a survey analysis involving the anthrax scare of 2001. J Med Internet Res. Mar. 3. 2004;6(1):e8. [pmid: 15111274].
1474 Klass P, Dreyer BP, Mendelsohn AL. Reach out and read: literacy promotion in pediatric primary care. Adv Pediatr. 2009;56:11-27. [pmid: 19968940].
1475 Klein MB, Lezotte DL, Fauerbach JA, Herndon DN, Kowalske KJ, Carrougher GJ, et al. The National Institute on Disability and Rehabilitation Research burn model system database: a tool for the multicenter study of the outcome of burn injury. J Burn Care Res. Jan-Feb. 2007;28(1):84-96. [pmid: 17211206].
1476 Kleinbeck C. Reaching positive diabetes outcomes for patients with low literacy. Home Healthc Nurse. Jan. 2005;23(1):16-22. [pmid: 15632502].
1477 Kleinert JO, Stewart SR. The need for technical literacy in doctoral education: a preliminary survey. J Allied Health. Summer. 2007;36(2):88-100. [pmid: 17633966].
1478 Kleinpeter MA. Health literacy affects peritoneal dialysis performance and outcomes. Adv Perit Dial. 2003;19:115-9. [pmid: 14763046].
1479 Klingner JK, Artiles AJ, Barletta LM. English language learners who struggle with reading: language acquisition or LD?. J Learn Disabil. Mar-Apr. 2006;39(2):108-28. [pmid: 16583792].
1480 Klymkowsky MW. Points of view: content versus process: is this a fair choice? Can nonmajors courses lead to biological literacy? Do majors courses do any better?. Cell Biol Educ. Fall. 2005;4(3):196-8. [pmid: 16240517].
1481 Klymkowsky MW, Garvin-Doxas K, Zeilik M. Bioliteracy and teaching efficacy: what biologists can learn from physicists. Cell Biol Educ. Fall. 2003;2(3):155-61. [pmid: 14506504].
1482 Knapp C. Bronson Methodist Hospital: journey to excellence in quality and safety. Jt Comm J Qual Patient Saf. Oct. 2006;32(10):556-63. [pmid: 17066993].
1483 Knaup P, Haag M, Leven FJ, Dickhaus H. Challenges in the evolution of the medical informatics program at heidelberg/heilbronn (Germany). Methods Inf Med. 2009;48(1):66-75. [pmid: 19151886].
1484 Knox A. Why American business demands twenty-first century learning: A company perspective. New Dir Youth Dev. Summer. 2006;(110):31-7. 10. 1. [pmid: 17017254].
1485 Kobylarz FA, Pomidor A, Heath JM. SPEAK. A mnemonic tool for addressing health literacy concerns in geriatric clinical encounters. Geriatrics. Jul. 2006;61(7):20-6. [pmid: 16827611].
1486 Koch E, Romero T, Romero CX, Akel C, Manriquez L, Paredes M, et al. Impact of education, income and chronic disease risk factors on mortality of adults: does 'a pauper-rich paradox' exist in Latin American societies?. Public Health. Jan. 2010;124(1):39-48. [pmid: 20036407].
1487 Koch-Weser S, Liang SL, Grigg-Saito DC. Self-reported health among Cambodians in Lowell, Massachusetts. J Health Care Poor Underserved. May. 2006;17(2 Suppl):133-45. [pmid: 16809880].
1488 Koelen MA, Lindstrom B. Making healthy choices easy choices: the role of empowerment. Eur J Clin Nutr. Aug. 1. 2005;59:S10-5. discussion S6, S23. [pmid: 16052175].
1489 Koenig MA, Ahmed S, Hossain MB, Khorshed Alam Mozumder AB. Women's status and domestic violence in rural Bangladesh: individual- and community-level effects. Demography. May. 2003;40(2):269-88. [pmid: 12846132].
1490 Koeniger-Donohue R. Handheld computers in nursing education: PDA pilot project. J Nurs Educ. Feb. 2008;47(2):74-7. [pmid: 18320958].
1491 Koinberg I, Langius-Eklof A, Holmberg L, Fridlund B. The usefulness of a multidisciplinary educational programme after breast cancer surgery: a prospective and comparative study. Eur J Oncol Nurs. Sep. 2006;10(4):273-82. [pmid: 16473549].
1492 Koivunen M, Hatonen H, Valimaki M. Barriers and facilitators influencing the implementation of an interactive Internet-portal application for patient education in psychiatric hospitals. Patient Educ Couns. Mar. 2008;70(3):412-9. [pmid: 18079085].
1493 Koivunen M, Valimaki M, Jakobsson T, Pitkanen A. Developing an evidence-based curriculum designed to help psychiatric nurses learn to use computers and the Internet. J Prof Nurs. Sep-Oct. 2008;24(5):302-14. [pmid: 18804084].
1494 Koivunen M, Valimaki M, Pitkanen A, Kuosmanen L. A preliminary usability evaluation of Web-based portal application for patients with schizophrenia. J Psychiatr Ment Health Nurs. Aug. 2007;14(5):462-9. [pmid: 17635254].
1495 Kokko S, Kannas L, Villberg J. Health promotion profile of youth sports clubs in Finland: club officials' and coaches' perceptions. Health Promot Int. Mar. 2009;24(1):26-35. [pmid: 19136676].
1496 Koklanis K, Georgievski Z, Brassington K, Bretherton L. The prevalence of specific reading disability in an amblyopic population. A preliminary report. Binocul Vis Strabismus Q. 2006;21(1):27-32. [pmid: 16457661].
1497 Kollipara UK, Jaffer O, Amin A, Toto KH, Nelson LL, Schneider R, et al. Relation of lack of knowledge about dietary sodium to hospital readmission in patients with heart failure. Am J Cardiol. Nov. 1. 2008;102(9):1212-5. [pmid: 18940294].
1498 Kondilis BK, Kiriaze IJ, Athanasoulia AP, Falagas ME. Mapping health literacy research in the European Union: a bibliometric analysis. PLoS ONE. 2008;3(6):e2519. [pmid: 18575594].
1499 Koo M, Krass I, Aslani P. Enhancing patient education about medicines: factors influencing reading and seeking of written medicine information. Health Expect. Jun. 2006;9(2):174-87. [pmid: 16677196].
1500 Koo MM, Krass I, Aslani P. Factors influencing consumer use of written drug information. Ann Pharmacother. Feb. 2003;37(2):259-67. [pmid: 12549958].
1501 Koo MM, Krass I, Aslani P. Patient characteristics influencing evaluation of written medicine information: lessons for patient education. Ann Pharmacother. Sep. 2005;39(9):1434-40. [pmid: 16046486].
1502 Koo MM, Krass I, Aslani P. Evaluation of written medicine information: validation of the Consumer Information Rating Form. Ann Pharmacother. Jun. 2007;41(6):951-6. [pmid: 17488832].
1503 Koponen A, Seppala U, Eriksson K, Nieminen P, Uutela A, Sillanpaa M, et al. Social functioning and psychological well-being of 347 young adults with epilepsy only--population-based, controlled study from Finland. Epilepsia. May. 2007;48(5):907-12. [pmid: 17430406].
1504 Koponen T, Mononen R, Rasanen P, Ahonen T. Basic numeracy in children with specific language impairment: heterogeneity and connections to language. J Speech Lang Hear Res. Feb. 2006;49(1):58-73. [pmid: 16533073].
1505 Koppenhaver DA, Hendrix MP, Williams AR. Toward evidence-based literacy interventions for children with severe and multiple disabilities. Semin Speech Lang. Feb. 2007;28(1):79-89. [pmid: 17340385].
1506 Kordella T. Research profile. A new tack. Overcoming low literacy in minorities. Diabetes Forecast. Jan. 2003;56(1):136-8. [pmid: 14765417].
1507 Kosmidis MH, Tsapkini K, Folia V. Lexical processing in illiteracy: effect of literacy or education?. Cortex. Oct. 2006;42(7):1021-7. [pmid: 17172182].
1508 Kosmidis MH, Tsapkini K, Folia V, Vlahou CH, Kiosseoglou G. Semantic and phonological processing in illiteracy. J Int Neuropsychol Soc. Oct. 2004;10(6):818-27. [pmid: 15637772].
1509 Kotik-Friedgut B. Development of the Lurian approach: a cultural neurolinguistic perspective. Neuropsychol Rev. Mar. 2006;16(1):43-52. [pmid: 16755405].
1510 Kountz DS. Strategies for improving low health literacy. Postgrad Med. Sep. 2009;121(5):171-7. [pmid: 19820287].
1511 Kouri TA, Selle CA, Riley SA. Comparison of meaning and graphophonemic feedback strategies for guided reading instruction of children with language delays. Am J Speech Lang Pathol. Aug. 2006;15(3):236-46. [pmid: 16896173].
1512 Kovalchik PG, Matetic RJ, Smith AK, Bealko SB. Application of Prevention through Design for hearing loss in the mining industry. J Safety Res. 2008;39(2):251-4. [pmid: 18454977].
1513 Koyama MS, Hansen PC, Stein JF. Logographic Kanji versus phonographic Kana in literacy acquisition: how important are visual and phonological skills?. Ann N Y Acad Sci. Dec. 2008;1145:41-55. [pmid: 19076388].
1514 Kozeracki CA, Carey MF, Colicelli J, Levis-Fitzgerald M, Grossel M. An intensive primary-literature-based teaching program directly benefits undergraduate science majors and facilitates their transition to doctoral programs. CBE Life Sci Educ. Winter. 2006;5(4):340-7. [pmid: 17146041].
1515 Kozlowski D. Factors for consideration in the development and implementation of an online RN-BSN course. Faculty and student perceptions. Comput Inform Nurs. Jan-Feb. 2004;22(1):34-43. [pmid: 15069847].
1516 Kozlowski LT, Edwards BQ. “Not safe” is not enough: smokers have a right to know more than there is no safe tobacco product. Tob Control. Aug. 2. 2005;14:ii3-7. [pmid: 16046699].
1517 Krauskopf PB, Wyatt TH. Even technophobic NPs can use PDAs. Nurse Pract. Jul. 2006;31(7):48-52. [pmid: 16862058].
1518 Kraywinkel K, Heidrich J, Heuschmann PU, Wagner M, Berger K. Stroke risk perception among participants of a stroke awareness campaign. BMC Public Health. 2007;7:39. [pmid: 17371603].
1519 Kreps GL. Strategic use of communication to market cancer prevention and control to vulnerable populations. Health Mark Q. 2008;25(1-2):204-16. [pmid: 18935885].
1520 Kreps GL, Sparks L. Meeting the health literacy needs of immigrant populations. Patient Educ Couns. Jun. 2008;71(3):328-32. [pmid: 18387773].
1521 Kripalani S, Bengtzen R, Henderson LE, Jacobson TA. Clinical research in low-literacy populations: using teach-back to assess comprehension of informed consent and privacy information. IR B. Mar-Apr. 2008;30(2):13-9.
1522 Kripalani S, Henderson LE, Chiu EY, Robertson R, Kolm P, Jacobson TA. Predictors of medication self-management skill in a low-literacy population. J Gen Intern Med. Aug. 2006;21(8):852-6. [pmid: 16881946].
1523 Kripalani S, Robertson R, Love-Ghaffari MH, Henderson LE, Praska J, Strawder A, et al. Development of an illustrated medication schedule as a low-literacy patient education tool. Patient Educ Couns. Jun. 2007;66(3):368-77. [pmid: 17344015].
1524 Kripalani S, Sharma J, Justice E, Justice J, Spiker C, Laufman LE, et al. Prostate cancer screening in a low-literacy population: does informed decision making occur?. Cancer Control. Nov. 2005;12(Suppl 2):116-7. [pmid: 16327763].
1525 Kripalani S, Sharma J, Justice E, Justice J, Spiker C, Laufman LE, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. Am J Prev Med. Aug. 2007;33(2):83-90. [pmid: 17673094].
1526 Kripalani S, Weiss BD. Teaching about health literacy and clear communication. J Gen Intern Med. Aug. 2006;21(8):888-90. [pmid: 16881953].
1527 Kroger K, Dragano N, Stang A, Moebus S, Mohlenkamp S, Mann K, et al. An unequal social distribution of peripheral arterial disease and the possible explanations: results from a population-based study. Vasc Med. Nov. 2009;14(4):289-96. [pmid: 19808713].
1528 Kruk ME, Galea S, Prescott M, Freedman LP. Health care financing and utilization of maternal health services in developing countries. Health Policy Plan. Sep. 2007;22(5):303-10. [pmid: 17681975].
1529 Kruk ME, Prescott MR, Galea S. Equity of skilled birth attendant utilization in developing countries: financing and policy determinants. Am J Public Health. Jan. 2008;98(1):142-7. [pmid: 18048785].
1530 Krumwiede N. What challenges do you see when caring for patients in a rural area? Access, health literacy, and health disparities are concerns. ONS Connect. Jul. 2009;24(7):13. [pmid: 19645158].
1531 Ku YL, Sheu S, Kuo SM. Efficacy of integrating information literacy education into a women's health course on information literacy for RN-BSN students. J Nurs Res. Mar. 2007;15(1):67-77. [pmid: 17370234].
1532 Kuiper R. Use of personal digital assistants to support clinical reasoning in undergraduate baccalaureate nursing students. Comput Inform Nurs. Mar-Apr. 2008;26(2):90-8. [pmid: 18317260].
1533 Kukafka R, Millery M, Chan C, LaRock W, Bakken S. Assessing the need for an online decision-support tool to promote evidence-based practices of psychosocial counseling in HIV care. AIDS Care. Jan. 2009;21(1):103-8. [pmid: 19085226].
1534 Kumar R, Jha P, Arora P, Mony P, Bhatia P, Millson P, et al. Trends in HIV-1 in young adults in south India from 2000 to 2004: a prevalence study. Lancet. Apr. 8. 2006;367(9517):1164-72. [pmid: 16616559].
1535 Kumar R, Parslow RA, Jorm AF, Rosenman SJ, Maller J, Meslin C, et al. Clinical and neuroimaging correlates of mild cognitive impairment in a middle-aged community sample: the personality and total health through life 60+ study. Dement Geriatr Cogn Disord. 2006;21(1):44-50. [pmid: 16254430].
1536 Kummerer SE, Lopez-Reyna NA, Hughes MT. Mexican immigrant mothers' perceptions of their children's communication disabilities, emergent literacy development, and speech-language therapy program. Am J Speech Lang Pathol. Aug. 2007;16(3):271-82. [pmid: 17666552].
1537 Kummervold PE, Chronaki CE, Lausen B, Prokosch HU, Rasmussen J, Santana S, et al. eHealth trends in Europe 2005-2007: a population-based survey. J Med Internet Res. 2008;10(4):e42. [pmid: 19017584].
1538 Kuo AA, Franke TM, Regalado M, Halfon N. Parent report of reading to young children. Pediatrics. Jun. 2004;113(6 Suppl):1944-51. [pmid: 15173465].
1539 Kupchunas WR. Personal health record: new opportunity for patient education. Orthop Nurs. May-Jun. 2007;26(3):185-91. quiz 92-3. [pmid: 17538475].
1540 Kuper H, Adami HO, Theorell T, Weiderpass E. The socioeconomic gradient in the incidence of stroke: a prospective study in middle-aged women in Sweden. Stroke. Jan. 2007;38(1):27-33. [pmid: 17138948].
1541 Kurumatani T, Ukawa K, Kawaguchi Y, Miyata S, Suzuki M, Ide H, et al. Teachers' knowledge, beliefs and attitudes concerning schizophrenia- a cross-cultural approach in Japan and Taiwan. Soc Psychiatry Psychiatr Epidemiol. May. 2004;39(5):402-9. [pmid: 15133598].
1542 Kurvers J, Uri H. Metalexical awareness: development, methodology or written language? A cross-linguistic comparison. J Psycholinguist Res. Jul. 2006;35(4):353-67. [pmid: 16718585].
1543 Kurz-Milcke E, Gigerenzer G, Martignon L. Transparency in risk communication: graphical and analog tools. Ann N Y Acad Sci. Apr. 2008;1128:18-28. [pmid: 18469211].
1544 Kushnir D, Zusman SP, Robinson PG. Validation of a Hebrew version of the Oral Health Impact Profile 14. J Public Health Dent. Spring. 2004;64(2):71-5. [pmid: 15180074].
1545 Kyle FE, Harris M. Concurrent correlates and predictors of reading and spelling achievement in deaf and hearing school children. J Deaf Stud Deaf Educ. Summer. 2006;11(3):273-88. [pmid: 16556897].
1546 Labelle R, Lachance L. Locus of control and academic efficacy in the thoughts of life and death of young Quebec university students. Crisis. 2003;24(2):68-72. [pmid: 12880224].
1547 Lachiewicz AM, Dawson DV, Spiridigliozzi GA, McConkie-Rosell A. Arithmetic difficulties in females with the fragile X premutation. Am J Med Genet A. Apr. 1. 2006;140(7):665-72. [pmid: 16508954].
1548 Laditka JN, Laditka SB, Eleazer GP, Cornman CB, Porter CN, Davis DR. High variation in Alzheimer's disease prevalence among South Carolina counties. J S C Med Assoc. Oct. 2008;104(7):215-8. [pmid: 19058733].
1549 Lai CK, Arthur DG, Chau WW. Implication of Internet growth on enhancing health of disadvantaged groups in China: a global perspective. J Clin Nurs. Sep. 2004;13(6B):68-73. [pmid: 15724821].
1550 Lai JC, Woo J, Hui E, Chan WM. Telerehabilitation - a new model for community-based stroke rehabilitation. J Telemed Telecare. 2004;10(4):199-205. [pmid: 15273029].
1551 Lam TK, Ruczinski I, Helzlsouer K, Shugart YY, Li KE, Clipp S, et al. Copy number variants of GSTM1 and GSTT1 in relation to lung cancer risk in a prospective cohort study. Ann Epidemiol. Aug. 2009;19(8):546-52. [pmid: 19394866].
1552 Lam TP, Cheng YH, Chan YL. Low literacy Chinese patients: how are they affected and how do they cope with health matters? A qualitative study. BMC Public Health. May. 4. 2004;4:14. [pmid: 15125781].
1553 Lamprianou I. The stability of marker characteristics across tests of the same subject and across subjects. J Appl Meas. 2006;7(2):192-205. [pmid: 16632902].
1554 Lancaster KJ, Smiciklas-Wright H, Weitzel LB, Mitchell DC, Friedmann JM, Jensen GL. Hypertension-related dietary patterns of rural older adults. Prev Med. Jun. 2004;38(6):812-8. [pmid: 15193903].
1555 Lanceley A, Cox CL. Cancer information and support needs of statutory and voluntary sector staff working with people from ethnically diverse communities. Eur J Cancer Care (Engl). Mar. 2007;16(2):122-9. [pmid: 17371420].
1556 Landman KZ, Thielman NM, Mgonja A, Shao HJ, Itemba DK, Ndosi EM, et al. Antiretroviral treatment literacy among HIV voluntary counseling and testing clients in Moshi, Tanzania, 2003 to 2005. J Int Assoc Physicians AIDS Care (Chic Ill). Mar. 2007;6(1):24-6.
1557 Landolt MA, Henderson AJ, Gourlay W, McDonald MF, Soos JG, Barrable WM, et al. They talk the talk: Surveying attitudes and judging behavior about living anonymous kidney donation. Transplantation. Nov. 27. 2003;76(10):1437-44. [pmid: 14657682].
1558 Landry SH, Swank PR, Smith KE, Assel MA, Gunnewig SB. Enhancing early literacy skills for preschool children: bringing a professional development model to scale. J Learn Disabil. Jul-Aug. 2006;39(4):306-24. [pmid: 16895156].
1559 Lanter E, Watson LR. Promoting literacy in students with ASD: the basics for the SLP. Lang Speech Hear Serv Sch. Jan. 2008;39(1):33-43. [pmid: 18162646].
1560 Lapidus M. Educating student pharmacists about herbal medicines: faculty-librarian collaboration. Health Info Libr J. Dec. 2007;24(4):267-73. [pmid: 18005301].
1561 Lapointe L, Rivard S. Getting physicians to accept new information technology: insights from case studies. CMAJ. May. 23. 2006;174(11):1573-8. [pmid: 16717265].
1562 Lapteva L, Nowak M, Yarboro CH, Takada K, Roebuck-Spencer T, Weickert T, et al. Anti-N-methyl-D-aspartate receptor antibodies, cognitive dysfunction, and depression in systemic lupus erythematosus. Arthritis Rheum. Aug. 2006;54(8):2505-14. [pmid: 16868971].
1563 Laramee AS, Morris N, Littenberg B. Relationship of literacy and heart failure in adults with diabetes. BMC Health Serv Res. 2007;7:98. [pmid: 17605784].
1564 Larsen JA, Nippold MA. Morphological analysis in school-age children: dynamic assessment of a word learning strategy. Lang Speech Hear Serv Sch. Jul. 2007;38(3):201-12. [pmid: 17625046].
1565 Larsen JK, Geenen R, Maas C, de Wit P, van Antwerpen T, Brand N, et al. Personality as a predictor of weight loss maintenance after surgery for morbid obesity. Obes Res. Nov. 2004;12(11):1828-34. [pmid: 15601979].
1566 Larson L. Health literacy: how are your patients reading you?. Trustee. May. 2007;60(5):8-12. 1.
1567 Larsson M, Sandberg AD. Phonological awareness in Swedish-speaking children with complex communication needs. J Intellect Dev Disabil. Mar. 2008;33(1):22-35. [pmid: 18300164].
1568 Lash JP, Go AS, Appel LJ, He J, Ojo A, Rahman M, et al. Chronic Renal Insufficiency Cohort (CRIC) Study: baseline characteristics and associations with kidney function. Clin J Am Soc Nephrol. Aug. 2009;4(8):1302-11. [pmid: 19541818].
1569 Latham CL, Calvillo E. A health protection model for Hispanic adults with Type 2 diabetes. J Clin Nurs. Jul. 2007;16(7B):186-96. [pmid: 17584428].
1570 Latimer WW, August GJ, Newcomb MD, Realmuto GM, Hektner JM, Mathy RM. Child and familial pathways to academic achievement and behavioral adjustment: a prospective six-year study of children with and without ADHD. J Atten Disord. Nov. 2003;7(2):101-16. [pmid: 15018359].
1571 Lau F, Yang J, Pereira J, Daeninck P, Aherne M. A survey of PDA use by palliative medicine practitioners. J Palliat Care. Winter. 2006;22(4):267-74. [pmid: 17263053].
1572 Lauber C, Ajdacic-Gross V, Fritschi N, Stulz N, Rossler W. Mental health literacy in an educational elite -- an online survey among university students. BMC Public Health. May. 9. 2005;5:44. [pmid: 15882465].
1573 Lauber C, Carlos N, Wulf R. Lay beliefs about treatments for people with mental illness and their implications for antistigma strategies. Can J Psychiatry. Oct. 2005;50(12):745-52. [pmid: 16408522].
1574 Lauber C, Nordt C, Falcato L, Rossler W. Do people recognise mental illness? Factors influencing mental health literacy. Eur Arch Psychiatry Clin Neurosci. Oct. 2003;253(5):248-51. [pmid: 14504994].
1575 Lauber C, Nordt C, Rossler W. Recommendations of mental health professionals and the general population on how to treat mental disorders. Soc Psychiatry Psychiatr Epidemiol. Oct. 2005;40(10):835-43. [pmid: 16179968].
1576 Lauder W, Holland K, Roxburgh M, Topping K, Watson R, Johnson M, et al. Measuring competence, self-reported competence and self-efficacy in pre-registration students. Nurs Stand. Jan. 23-29. 2008;22(20):35-43. [pmid: 18284020].
1577 Laughery KR. Safety communications: warnings. Appl Ergon. Jul. 2006;37(4):467-78. [pmid: 16759630].
1578 Laursen S, Liston C, Thiry H, Graf J. What good is a scientist in the classroom? Participant outcomes and program design features for a short-duration science outreach intervention in K-12 classrooms. CBE Life Sci Educ. Spring. 2007;6(1):49-64. [pmid: 17339394].
1579 Law CW, Chen EY, Cheung EF, Chan RC, Wong JG, Lam CL, et al. Impact of untreated psychosis on quality of life in patients with first-episode schizophrenia. Qual Life Res. Oct. 2005;14(8):1803-11. [pmid: 16155768].
1580 Law J, Garrett Z, Nye C. Speech and language therapy interventions for children with primary speech and language delay or disorder. Cochrane Database Syst Rev. 2003;(3):CD004110. [pmid: 12918003].
1581 Lawoyin TO, Osinowo H, Walker M. Sexual networking among married men with wives of child bearing age in Ibadan City, Nigeria: report of a pilot study. Afr J Med Med Sci. Sep. 2004;33(3):207-12. [pmid: 15819465].
1582 Le C, Chongsuvivatwong V, Geater A. Contextual socioeconomic determinants of cardiovascular risk factors in rural southwest China: a multilevel analysis. BMC Public Health. 2007;7:72. [pmid: 17480237].
1583 Leach AJ. Otitis media in Australian Aboriginal children: an overview. Int J Pediatr Otorhinolaryngol. Oct. 5. 1. 1999;49:S173-8. [pmid: 10577800].
1584 Lebrun CE, van der Schouw YT, de Jong FH, Pols HA, Grobbee DE, Lamberts SW. Relations between body composition, functional and hormonal parameters and quality of life in healthy postmenopausal women. Maturitas. Aug. 20. 2006;55(1):82-92. [pmid: 16497451].
1585 Lee A. Health-promoting schools: evidence for a holistic approach to promoting health and improving health literacy. Appl Health Econ Health Policy. 2009;7(1):11-7. [pmid: 19558191].
1586 Lee AC, Tang SW, Leung SS, Yu GK, Cheung RT. Depression literacy among Chinese stroke survivors. Aging Ment Health. May. 2009;13(3):349-56. [pmid: 19484598].
1587 Lee CS, Shiu AT. Perceived health care climate, diabetes knowledge and self-care practice of Hong Kong Chinese older patients: a pilot study. J Clin Nurs. May. 2004;13(4):534-5. [pmid: 15086640].
1588 Lee DH, Mehta MD. Evaluation of a visual risk communication tool: effects on knowledge and perception of blood transfusion risk. Transfusion (Paris). Jun. 2003;43(6):779-87.
1589 Lee JW, Park KD, Im JA, Kim MY, Lee DC. Mitochondrial DNA copy number in peripheral blood is associated with cognitive function in apparently healthy elderly women. Clin Chim Acta. Apr. 2. 2010;411(7-8):592-6. [pmid: 20114042].
1590 Lee JY, Rozier RG, Lee SY, Bender D, Ruiz RE. Development of a word recognition instrument to test health literacy in dentistry: the REALD-30—a brief communication. J Public Health Dent. Spring. 2007;67(2):94-8. [pmid: 17557680].
1591 Lee K, Ng SF, Ng EL, Lim ZY. Working memory and literacy as predictors of performance on algebraic word problems. J Exp Child Psychol. Oct. 2004;89(2):140-58. [pmid: 15388303].
1592 Lee LW. Development and validation of a reading-related assessment battery in Malay for the purpose of dyslexia assessment. Ann Dyslexia. Jun. 2008;58(1):37-57. [pmid: 18293088].
1593 Lee MK, Lee KM, Bae JM, Kim S, Kim YW, Ryu KW, et al. Employment status and work-related difficulties in stomach cancer survivors compared with the general population. Br J Cancer. Feb. 26. 2008;98(4):708-15. [pmid: 18283298].
1594 Lee S, McGrath C, Samman N. Impact of orthognathic surgery on quality of life. J Oral Maxillofac Surg. Jun. 2008;66(6):1194-9. [pmid: 18486784].
1595 Lee SY, Arozullah AM, Cho YI. Health literacy, social support, and health: a research agenda. Soc Sci Med. Apr. 2004;58(7):1309-21. [pmid: 14759678].
1596 Lee SY, Bender DE, Ruiz RE, Cho YI. Development of an easy-to-use Spanish health literacy test. Health Serv Res. Aug. 2006;41(4 Pt 1):1392-412. [pmid: 16899014].
1597 Lee TH, Shen PD, Tsai CW. Enhancing computing skills of low-achieving students via e-learning: a design experiment of Web-based, problem-based learning and self-regulated learning. Cyberpsychol Behav. Aug. 2008;11(4):431-6. [pmid: 18721091].
1598 Lee TT. Nurses' adoption of technology: application of Rogers' innovation-diffusion model. Appl Nurs Res. Nov. 2004;17(4):231-8. [pmid: 15573331].
1599 Lee TT. Nurses' experiences using a nursing information system: early stage of technology implementation. Comput Inform Nurs. Sep-Oct. 2007;25(5):294-300. [pmid: 17827993].
1600 Lee TT, Lee TY, Lin KC, Chang PC. Factors affecting the use of nursing information systems in Taiwan. J Adv Nurs. Apr. 2005;50(2):170-8. [pmid: 15788081].
1601 LeFevre JA. Research on the development of academic skills: introduction to the special issue on early literacy and early numeracy. Can J Exp Psychol. Jun. 2000;54(2):57-64. [pmid: 10881390].
1602 Leff B, Harper GM. The reading habits of medicine clerks at one medical school: frequency, usefulness, and difficulties. Acad Med. May. 2006;81(5):489-94. [pmid: 16639211].
1603 Lehna C, McNeil J. Mixed-methods exploration of parents' health information understanding. Clin Nurs Res. May. 2008;17(2):133-44. [pmid: 18387884].
1604 Leikauf J, Federman AD. Comparisons of self-reported and chart-identified chronic diseases in inner-city seniors. J Am Geriatr Soc. Jul. 2009;57(7):1219-25. [pmid: 19486197].
1605 Leinberger-Jabari A, Parker DL, Oberg C. Child labor, gender, and health. Public Health Rep. Nov-Dec. 2005;120(6):642-7. [pmid: 16350334].
1606 Leinsalu M, Vagero D, Kunst AE. Estonia 1989-2000: enormous increase in mortality differences by education. Int J Epidemiol. Dec. 2003;32(6):1081-7. [pmid: 14681279].
1607 Leitao S, Fletcher J. Literacy outcomes for students with speech impairment: long-term follow-up. Int J Lang Commun Disord. Apr-Jun. 2004;39(2):245-56. [pmid: 15204454].
1608 Lemire M, Pare G, Sicotte C, Harvey C. Determinants of Internet use as a preferred source of information on personal health. Int J Med Inform. Nov. 2008;77(11):723-34. [pmid: 18434246].
1609 Lenert L, Kaplan RM. Validity and interpretation of preference-based measures of health-related quality of life. Med Care. Sep. 2000;38(9 Suppl):II138-50. [pmid: 10982099].
1610 Lennon-Dearing R, Florence J, Garrett L, Click IA, Abercrombie S. A rural community-based interdisciplinary curriculum: a social work perspective. Soc Work Health Care. 2008;47(2):93-107. [pmid: 18956502].
1611 Leslie SJ, Hartswood M, Meurig C, McKee SP, Slack R, Procter R, et al. Clinical decision support software for management of chronic heart failure: development and evaluation. Comput Biol Med. May. 2006;36(5):495-506. [pmid: 15927176].
1612 Lester D, Yang B, James S. A short computer anxiety scale. Percept Mot Skills. Jun. 2005;100(3 Pt 2):964-8. [pmid: 16158683].
1613 Letz R, DiIorio CK, Shafer PO, Yeager KA, Henry TR, Schomer DL. A computer-based reading test for use as an index of premorbid general intellectual level in North American English-speaking adults. Neurotoxicology. Aug. 2003;24(4-5):503-12. [pmid: 12900063].
1614 Leung A, Ko P, Chan KS, Chi I, Chow N. Searching health information via the web: Hong Kong chinese older adults' experience. Public Health Nurs. Mar-Apr. 2007;24(2):169-75. [pmid: 17319889].
1615 Levandowski BA, Sharma P, Lane SD, Webster N, Nestor AM, Cibula DA, et al. Parental literacy and infant health: an evidence-based healthy start intervention. Health Promot Pract. Jan. 2006;7(1):95-102. [pmid: 16410425].
1616 Levav I, Shemesh A, Grinshpoon A, Aisenberg E, Shershevsky Y, Kohn R. Mental health-related knowledge, attitudes and practices in two kibbutzim. Soc Psychiatry Psychiatr Epidemiol. Sep. 2004;39(9):758-64. [pmid: 15672298].
1617 Levenson D. Low health literacy is a major problem, reports says. Rep Med Guidel Outcomes Res. Apr. 30. 1. 2004;15(9):6-7. [pmid: 15040384].
1618 Levin I. The role of Hebrew letter names in early literacy: the case of multiphonemic acrophonic names. J Exp Child Psychol. Dec. 2007;98(4):193-216. [pmid: 17949738].
1619 LeVine RA, LeVine SE, Rowe ML, Schnell-Anzola B. Maternal literacy and health behavior: a Nepalese case study. Soc Sci Med. Feb. 2004;58(4):863-77. [pmid: 14672599].
1620 Levinger B. School feeding, school reform, and food security: connecting the dots. Food Nutr Bull. Jun. 2005;26(2 Suppl 2):S170-8. [pmid: 16075566].
1621 Levy BA, Gong Z, Hessels S, Evans MA, Jared D. Understanding print: early reading development and the contributions of home literacy experiences. J Exp Child Psychol. Jan. 2006;93(1):63-93. [pmid: 16140318].
1622 Lewis N, Gray SW, Freres DR, Hornik RC. Examining cross-source engagement with cancer-related information and its impact on doctor-patient relations. Health Commun. Dec. 2009;24(8):723-34. [pmid: 20183381].
1623 Lewis PA, Price S. Distance education and the integration of E-learning in a graduate program. J Contin Educ Nurs. May-Jun. 2007;38(3):139-43. [pmid: 17542173].
1624 Lewis-Fernandez R, Das AK, Alfonso C, Weissman MM, Olfson M. Depression in US Hispanics: diagnostic and management considerations in family practice. J Am Board Fam Pract. Jul-Aug. 2005;18(4):282-96. [pmid: 15994474].
1625 Lew-Ting CY, Chen LH. The surrogate marker and its discontents: pluralism in immunity maintenance among HIV-infected persons in Taiwan. Sociol Health Illn. Nov. 2008;30(7):1039-54. [pmid: 18764805].
1626 Leyva M, Sharif I, Ozuah PO. Health literacy among Spanish-speaking Latino parents with limited English proficiency. Ambul Pediatr. Jan-Feb. 2005;5(1):56-9. [pmid: 15656706].
1627 Li BD, Brown WA, Ampil FL, Burton GV, Yu H, McDonald JC. Patient compliance is critical for equivalent clinical outcomes for breast cancer treated by breast-conservation therapy. Ann Surg. Jun. 2000;231(6):883-9. [pmid: 10816632].
1628 Li H, Barnhart HX, Stein AD, Martorell R. Effects of early childhood supplementation on the educational achievement of women. Pediatrics. Nov. 2003;112(5):1156-62. [pmid: 14595062].
1629 Li H, DiGirolamo AM, Barnhart HX, Stein AD, Martorell R. Relative importance of birth size and postnatal growth for women's educational achievement. Early Hum Dev. Jan. 2004;76(1):1-16. [pmid: 14729158].
1630 Li J, Luo C, de Klerk N. Trends in infant/child mortality and life expectancy in Indigenous populations in Yunnan Province, China. Aust N Z J Public Health. Jun. 2008;32(3):216-23. [pmid: 18578818].
1631 Li X, Atkins MS. Early childhood computer experience and cognitive and motor development. Pediatrics. Jun. 2004;113(6):1715-22. [pmid: 15173496].
1632 Lichtenstein AH, Rasmussen H, Yu WW, Epstein SR, Russell RM. Modified MyPyramid for Older Adults. J Nutr. Jan. 2008;138(1):5-11. [pmid: 18156396].
1633 Lieberman A, Harris D. Acknowledging adult bias: a focus-group approach to utilizing beauty salons as health-education portals for inner-city adolescent girls. Health Promot Pract. Apr. 2007;8(2):205-13. [pmid: 16980570].
1634 Light J, Drager K. AAC technologies for young children with complex communication needs: state of the science and future research directions. Augment Altern Commun. Sep. 2007;23(3):204-16. [pmid: 17701740].
1635 Light JC, Drager KD. Improving the design of augmentative and alternative technologies for young children. Assist Technol. Summer. 2002;14(1):17-32. [pmid: 12739847].
1636 Lillie SE, Brewer NT, O'Neill SC, Morrill EF, Dees EC, Carey LA, et al. Retention and use of breast cancer recurrence risk information from genomic tests: the role of health literacy. Cancer Epidemiol Biomarkers Prev. Feb. 2007;16(2):249-55. [pmid: 17267389].
1637 Lim TA, Wong WH, Lim KY. Perceived skill and utilisation of information technology in medical education among final year medical students, Universiti Putra Malaysia. Med J Malaysia. Oct. 2005;60(4):432-40. [pmid: 16570704].
1638 Lin HC, Chiu CC, Chen SF, Lou HY, Chiu WT, Chen YH. Ulcerative colitis and pregnancy outcomes in an Asian population. Am J Gastroenterol. Feb. 2010;105(2):387-94. [pmid: 19809415].
1639 Lin MJ, Liu JT. Do lower birth weight babies have lower grades? Twin fixed effect and instrumental variable method evidence from Taiwan. Soc Sci Med. May. 2009;68(10):1780-7. [pmid: 19321247].
1640 Lincoln A, Espejo D, Johnson P, Paasche-Orlow M, Speckman JL, Webber TL, et al. Limited literacy and psychiatric disorders among users of an urban safety-net hospital's mental health outpatient clinic. J Nerv Ment Dis. Sep. 2008;196(9):687-93. [pmid: 18791430].
1641 Lincoln A, Paasche-Orlow MK, Cheng DM, Lloyd-Travaglini C, Caruso C, Saitz R, et al. Impact of health literacy on depressive symptoms and mental health-related: quality of life among adults with addiction. J Gen Intern Med. Aug. 2006;21(8):818-22. [pmid: 16881940].
1642 Lindau ST, Basu A, Leitsch SA. Health literacy as a predictor of follow-up after an abnormal Pap smear: a prospective study. J Gen Intern Med. Aug. 2006;21(8):829-34. [pmid: 16881942].
1643 Lindauer SJ, Peck SL, Tufekci E, Coffey T, Best AM. The crisis in orthodontic education: goals and perceptions. Am J Orthod Dentofacial Orthop. Nov. 2003;124(5):480-7. [pmid: 14614413].
1644 Link TM, Marz R. Computer literacy and attitudes towards e-learning among first year medical students. BMC Med Educ. 2006;6:34. [pmid: 16784524].
1645 Lipka O, Lesaux NK, Siegel LS. Retrospective analyses of the reading development of grade 4 students with reading disabilities: risk status and profiles over 5 years. J Learn Disabil. Jul-Aug. 2006;39(4):364-78. [pmid: 16895160].
1646 Lipkus IM, Peters E. Understanding the role of numeracy in health: proposed theoretical framework and practical insights. Health Educ Behav. Dec. 2009;36(6):1065-81. [pmid: 19834054].
1647 Lipkus IM, Samsa G, Rimer BK. General performance on a numeracy scale among highly educated samples. Med Decis Making. Jan-Feb. 2001;21(1):37-44. [pmid: 11206945].
1648 Li-Tsang CW, Lee MY, Yeung SS, Siu AM, Lam CS. A 6-month follow-up of the effects of an information and communication technology (ICT) training programme on people with intellectual disabilities. Res Dev Disabil. Nov-Dec. 2007;28(6):559-66. [pmid: 16979318].
1649 Liu M, Lambert CE, Lambert VA. Caregiver burden and coping patterns of Chinese parents of a child with a mental illness. Int J Ment Health Nurs. Apr. 2007;16(2):86-95. [pmid: 17348959].
1650 Lium JT, Laerum H, Schulz T, Faxvaag A. From the front line, report from a near paperless hospital: mixed reception among health care professionals. J Am Med Inform Assoc. Nov-Dec. 2006;13(6):668-75. [pmid: 16929040].
1651 Llewellyn G, McConnell D, Honey A, Mayes R, Russo D. Promoting health and home safety for children of parents with intellectual disability: a randomized controlled trial. Res Dev Disabil. Nov-Dec. 2003;24(6):405-31. [pmid: 14622893].
1652 Lloyd CE, Johnson MR, Mughal S, Sturt JA, Collins GS, Roy T, et al. Securing recruitment and obtaining informed consent in minority ethnic groups in the UK. BMC Health Serv Res. 2008;8:68. [pmid: 18373876].
1653 Lloyd J, Moni KB, Jobling A. Breaking the hype cycle: using the computer effectively with learners with intellectual disabilities. Downs Syndr Res Pract. Jun. 2006;9(3):68-74. [pmid: 16869377].
1654 Lloyd JW, Frawley SL, Neer CA, Merle C, Goebel R. The Zodiak workshop: an innovative model for teaching financial management through partnership with industry. J Vet Med Educ. Summer. 2004;31(2):175-8. [pmid: 15181601].
1655 Lloyd LL, Ammary NJ, Epstein LG, Johnson R, Rhee K. A transdisciplinary approach to improve health literacy and reduce disparities. Health Promot Pract. Jul. 2006;7(3):331-5. [pmid: 16760237].
1656 Lo S, Sharif I, Ozuah PO. Health literacy among English-speaking parents in a poor urban setting. J Health Care Poor Underserved. Aug. 2006;17(3):504-11. [pmid: 16960318].
1657 Lobach DF, Arbanas JM, Mishra DD, Campbell M, Wildemuth BM. Adapting the human-computer interface for reading literacy and computer skill to facilitate collection of information directly from patients. Stud Health Technol Inform. 2004;107(Pt 2):1142-6. [pmid: 15360991].
1658 Lobach DF, Hasselblad V, Wildemuth BM. Evaluation of a tool to categorize patients by reading literacy and computer skill to facilitate the computer-administered patient interview. AMIA Annu Symp Proc. 2003:391-5.
1659 Lober WB, Zierler B, Herbaugh A, Shinstrom SE, Stolyar A, Kim EH, et al. Barriers to the use of a personal health record by an elderly population. AMIA Annu Symp Proc. 2006:514-8.
1660 Loevinsohn B, Hong R, Gauri V. Will more inputs improve the delivery of health services? Analysis of district vaccination coverage in Pakistan. Int J Health Plann Manage. Jan-Mar. 2006;21(1):45-54. [pmid: 16604848].
1661 Logan RA. Clinical, classroom, or personal education: attitudes about health literacy. J Med Libr Assoc. Apr. 2007;95(2):127-37. e48. [pmid: 17443245].
1662 Loh S, Packer TL, Yip CH, Passmore A. Targeting health disparity in breast cancer: insights into women's knowledge of their cancer profile in Malaysia. Asian Pac J Cancer Prev. Oct-Dec. 2009;10(4):631-6. [pmid: 19827884].
1663 Loke Jennifer CF. Computer mediated conferencing - a hope or hype for healthcare education in higher learning?: A review of the literature. Nurse Educ Today. May. 2007;27(4):318-24. [pmid: 16846669].
1664 Lokker N, Sanders L, Perrin EM, Kumar D, Finkle J, Franco V, et al. Parental misinterpretations of over-the-counter pediatric cough and cold medication labels. Pediatrics. Jun. 2009;123(6):1464-71. [pmid: 19482755].
1665 London L, Baldwin-Ragaven L. Human rights and health: challenges for training nurses in South Africa. Curationis. Mar. 2008;31(1):5-18. [pmid: 18592944].
1666 Long AF. The potential of complementary and alternative medicine in promoting well-being and critical health literacy: a prospective, observational study of shiatsu. BMC Complement Altern Med. 2009;9:19. [pmid: 19538728].
1667 Longstreet DA, Heath DL, Panaretto KS, Vink R. Correlations suggest low magnesium may lead to higher rates of type 2 diabetes in Indigenous Australians. Rural Remote Health. Oct-Dec. 2007;7(4):843. [pmid: 17937505].
1668 Looveer J, Mulligan J. The efficacy of link items in the construction of a numeracy achievement scale--from kindergarten to year 6. J Appl Meas. 2009;10(3):247-65. [pmid: 19671988].
1669 Lopez-Quintero C, Shtarkshall R, Neumark YD. Barriers to HIV-testing among Hispanics in the United States: analysis of the National Health Interview Survey, 2000. AIDS Patient Care STDS. Oct. 2005;19(10):672-83. [pmid: 16232051].
1670 Loprinzi CL, Ravdin PM. Decision-making for patients with resectable breast cancer: individualized decisions for and by patients and their physicians. J Natl Compr Canc Netw. Apr. 2003;1(2):189-96. [pmid: 19768877].
1671 Lorentzon M. ‘Lower than a scullery maid’. Is this view of the British Poor Law nurse justified? Examination of probationer registers from Kensington Infirmary, 1890-1916. Int Hist Nurs J. Spring. 2003;7(3):4-15. [pmid: 12710377].
1672 Lorenzen B, Melby CE, Earles B. Using principles of health literacy to enhance the informed consent process. AORN J. Jul. 2008;88(1):23-9. [pmid: 18603032].
1673 Lorenzi M, McMillan AJ, Siegel LS, Zumbo BD, Glickman V, Spinelli JJ, et al. Educational outcomes among survivors of childhood cancer in British Columbia, Canada: report of the Childhood/Adolescent/Young Adult Cancer Survivors (CAYACS) Program. Cancer. May. 15. 2009;115(10):2234-45. [pmid: 19326396].
1674 Loria Bolanos R, Partanen T, Berrocal M, Alvarez B, Cordoba L. Determinants of health in seasonal migrants: coffee harvesters in Los Santos, Costa Rica. Int J Occup Environ Health. Apr-Jun. 2008;14(2):129-37. [pmid: 18507290].
1675 Lorway R, Reza-Paul S, Pasha A. On becoming a male sex worker in Mysore: sexual subjectivity, “empowerment,” and community-based HIV prevention research. Med Anthropol Q. Jun. 2009;23(2):142-60. [pmid: 19562953].
1676 Lovelace S, Stewart SR. Increasing print awareness in preschoolers with language impairment using non-evocative print referencing. Lang Speech Hear Serv Sch. Jan. 2007;38(1):16-30. [pmid: 17218533].
1677 Lovisi Neto, BE Jennings F, Barros Ohashi C, Silva PG, Natour J. Evaluation of the efficacy of an educational program for rheumatoid arthritis patients. Clin Exp Rheumatol. Jan-Feb. 2009;27(1):28-34. [pmid: 19327226].
1678 Low AK, Grothe KB, Wofford TS, Bouldin MJ. Addressing disparities in cardiovascular risk through community-based interventions. Ethn Dis. Spring. 2007;17(2 Suppl 2):S2-55. 9. [pmid: 17684816].
1679 Low LF, Anstey KJ. Dementia literacy: recognition and beliefs on dementia of the Australian public. Alzheimers Dement. Jan. 2009;5(1):43-9. [pmid: 19118808].
1680 Lucas JA, Ivnik RJ, Smith GE, Ferman TJ, Willis FB, Petersen RC, et al. Mayo's Older African Americans Normative Studies: norms for Boston Naming Test, Controlled Oral Word Association, Category Fluency, Animal Naming, Token Test, Wrat-3 Reading, Trail Making Test, Stroop Test, and Judgment of Line Orientation. Clin Neuropsychol. Jun. 2005;19(2):243-69. [pmid: 16019707].
1681 Luckner JL, Sebald AM, Cooney J, Young J 3rd, Muir SG. An examination of the evidence-based literacy research in deaf education. Am Ann Deaf. Winter. 2005;150(5):443-56. [pmid: 16610477].
1682 Ludtke O, Marsh HW, Robitzsch A, Trautwein U, Asparouhov T, Muthen B. The multilevel latent covariate model: a new, more reliable approach to group-level effects in contextual studies. Psychol Methods. Sep. 2008;13(3):203-29. [pmid: 18778152].
1683 Lund T, Labriola M, Villadsen E. Who is at risk for long-term sickness absence? A prospective cohort study of Danish employees. Work. 2007;28(3):225-30. [pmid: 17429148].
1684 Lunney M. Helping nurses use NANDA, NOC, and NIC: novice to expert. J Nurs Adm. Mar. 2006;36(3):118-25. [pmid: 16601513].
1685 Lurie JD, Berven SH, Gibson-Chambers J, Tosteson T, Tosteson A, Hu SS, et al. Patient preferences and expectations for care: determinants in patients with lumbar intervertebral disc herniation. Spine. Nov. 15. 2008;33(24):2663-8. [pmid: 18981962].
1686 Lyons SS, Tripp-Reimer T, Sorofman BA, Dewitt JE, Bootsmiller BJ, Vaughn TE, et al. VA QUERI informatics paper: information technology for clinical guideline implementation: perceptions of multidisciplinary stakeholders. J Am Med Inform Assoc. Jan-Feb. 2005;12(1):64-71. [pmid: 15492035].
1687 Lyytinen P, Eklund K, Lyytinen H. Language development and literacy skills in late-talking toddlers with and without familial risk for dyslexia. Ann Dyslexia. Dec. 2005;55(2):166-92. [pmid: 17849192].
1688 Maag M. Podcasting and MP3 players: emerging education technologies. Comput Inform Nurs. Jan-Feb. 2006;24(1):9-13. [pmid: 16436906].
1689 Maag MM. Nursing students' attitudes toward technology: a national study. Nurse Educ. May-Jun. 2006;31(3):112-8. [pmid: 16708034].
1690 Mabiso A, Williams KP, Todem D, Templin TN. Longitudinal analysis of domain-level breast cancer literacy among African-American women. Health Educ Res. Feb. 2010;25(1):151-61. [pmid: 19861639].
1691 Mabry CC, Mosca NG. Interprofessional educational partnerships in school health for children with special oral health needs. J Dent Educ. Aug. 2006;70(8):844-50. [pmid: 16896087].
1692 Macinko J, Guanais FC, de Fatima M, de Souza M. Evaluation of the impact of the Family Health Program on infant mortality in Brazil, 1990-2002. J Epidemiol Community Health. Jan. 2006;60(1):13-9. [pmid: 16361449].
1693 Mack F, Mundt T, Mojon P, Budtz-Jorgensen E, Schwahn C, Bernhardt O, et al. Study of Health in Pomerania (SHIP): Relationship among socioeconomic and general health factors and dental status among elderly adults in Pomerania. Quintessence Int. Nov-Dec. 2003;34(10):772-8. [pmid: 14620269].
1694 Mackenbach JP, Stirbu I, Roskam AJ, Schaap MM, Menvielle G, Leinsalu M, et al. Socioeconomic inequalities in health in 22 European countries. N Engl J Med. Jun. 5. 2008;358(23):2468-81. [pmid: 18525043].
1695 Mackenzie B. Sustained efforts should promote statistics literacy in physiology Commentary on “Guidelines for reporting statistics in journals published by the American Physiological Society the sequel”. Adv Physiol Educ. Dec. 2007;31(4):305. discussion 6-7. [pmid: 18057398].
1696 Macklin A. Legal aspects of conflict-induced migration by women. Reprod Health Matters. May. 2008;16(31):22-32. [pmid: 18513604].
1697 Madanat HN, Troutman KP, Al-Madi B. The nutrition transition in Jordan: the political, economic and food consumption contexts. Promot Educ. 2008;15(1):6-10. [pmid: 18430689].
1698 Magajna L, Kavkler M, Ortar-Krizaj M. Adults with self-reported learning disabilities in Slovenia: findings from the international adult literacy survey on the incidence and correlates of learning disabilities in Slovenia. Dyslexia. Nov. 2003;9(4):229-51. [pmid: 14672511].
1699 Magasi S, Durkin E, Wolf MS, Deutsch A. Rehabilitation consumers' use and understanding of quality information: a health literacy perspective. Arch Phys Med Rehabil. Feb. 2009;90(2):206-12. [pmid: 19236975].
1700 Magnus M, Herwehe J, Andrews L, Gibson L, Daigrepont N, De Leon JM, et al. Evaluating health information technology: provider satisfaction with an HIV-specific, electronic clinical management and reporting system. AIDS Patient Care STDS. Feb. 2009;23(2):85-91. [pmid: 19133750].
1701 Magwood GS, Jenkins C, Zapka J. Validation of diabetes health-related quality-of-life instruments using cognitive interviewing with older African Americans. J Nurs Meas. 2009;17(3):195-220. [pmid: 20069949].
1702 Maharajah KR, Tet CM, Yaacob A, Tajudin LS, Foster PJ. Modified Bahasa Malaysia version of VF-14 questionnaire: assessing the impact of glaucoma in rural area of Malaysia. Clin Experiment Ophthalmol. Apr. 2008;36(3):222-31. [pmid: 18412590].
1703 Mahavarkar SH, Madhu CK, Mule VD. A comparative study of teenage pregnancy. J Obstet Gynaecol. Aug. 2008;28(6):604-7. [pmid: 19003655].
1704 Mahr J, Wuestefeld M, Ten Haaf J, Krawinkel MB. Nutrition education for illiterate children in southern Madagascar--addressing their needs, perceptions and capabilities. Public Health Nutr. Jun. 2005;8(4):366-72. [pmid: 15975181].
1705 Makanjuola AB. Public stigma towards psychiatric patients in a South-Western Nigerian town. Niger Postgrad Med J. Sep. 2006;13(3):210-5. [pmid: 17066108].
1706 Malacova E, Li J, Blair E, Leonard H, de Klerk N, Stanley F. Association of birth outcomes and maternal, school, and neighborhood characteristics with subsequent numeracy achievement. Am J Epidemiol. Jul. 1. 2008;168(1):21-9. [pmid: 18417493].
1707 Malik M, Pradhan SK, Prasuna JG. Screening for psychosocial development among infants in an urban slum of Delhi. Indian J Pediatr. Sep. 2007;74(9):841-5. [pmid: 17901671].
1708 Malik P. Numeracy. Can J Cardiol. Aug. 2007;23(10):777. [pmid: 17703253].
1709 Maluccio JA, Melgar P, Mendez H, Murphy A, Yount KM. Social and economic development and change in four Guatemalan villages: demographics, schooling, occupation, and assets. Food Nutr Bull. Jun. 2005;26(2 Suppl 1):S25-45. [pmid: 16060210].
1710 Mamabolo RL, Alberts M, Steyn NP, Delemarre-van de Waal HA, Levitt NS. Prevalence and determinants of stunting and overweight in 3-year-old black South African children residing in the Central Region of Limpopo Province, South Africa. Public Health Nutr. Aug. 2005;8(5):501-8. [pmid: 16153331].
1711 Manafa O, Lindegger G, Ijsselmuiden C. Informed consent in an antiretroviral trial in Nigeria. Indian J Med Ethics. Jan-Mar. 2007;4(1):26-30. [pmid: 18630217].
1712 Mancuso CA, Rincon M. Asthma patients' assessments of health care and medical decision making: the role of health literacy. J Asthma. Jan-Feb. 2006;43(1):41-4. [pmid: 16448964].
1713 Mancuso CA, Rincon M. Impact of health literacy on longitudinal asthma outcomes. J Gen Intern Med. Aug. 2006;21(8):813-7. [pmid: 16881939].
1714 Mancuso JM. Health literacy: a concept/dimensional analysis. Nurs Health Sci. Sep. 2008;10(3):248-55. [pmid: 18786068].
1715 Mancuso JM. Assessment and measurement of health literacy: an integrative review of the literature. Nurs Health Sci. Mar. 2009;11(1):77-89. [pmid: 19298313].
1716 Manesh AO, Sheldon TA, Pickett KE, Carr-Hill R. Accuracy of child morbidity data in demographic and health surveys. Int J Epidemiol. Feb. 2008;37(1):194-200. [pmid: 17911149].
1717 Mangan JM, Arias MS, Sierra T, Perez M, Medina RL, Yanez R, et al. Evaluating the strengths and weaknesses of tuberculosis educational activities for prisoners in Honduras. Int J Tuberc Lung Dis. Oct. 2006;10(10):1152-8. [pmid: 17044210].
1718 Manganello JA. Health literacy and adolescents: a framework and agenda for future research. Health Educ Res. Oct. 2008;23(5):840-7. [pmid: 18024979].
1719 Manger MS, McKenzie JE, Winichagoon P, Gray A, Chavasit V, Pongcharoen T, et al. A micronutrient-fortified seasoning powder reduces morbidity and improves short-term cognitive function, but has no effect on anthropometric measures in primary school children in northeast Thailand: a randomized controlled trial. Am J Clin Nutr. Jun. 2008;87(6):1715-22. [pmid: 18541560].
1720 Mangold K. Educating a new generation: teaching baby boomer faculty about millennial students. Nurse Educ. Jan-Feb. 2007;32(1):21-3. [pmid: 17220763].
1721 Maniaci MJ, Heckman MG, Dawson NL. Functional health literacy and understanding of medications at discharge. Mayo Clin Proc. May. 2008;83(5):554-8. [pmid: 18452685].
1722 Manios Y, Moschonis G, Kourlaba G, Bouloubasi Z, Grammatikaki E, Spyridaki A, et al. Prevalence and independent predictors of insulin resistance in children from Crete, Greece: the Children Study. Diabet Med. Jan. 2008;25(1):65-72. [pmid: 18028438].
1723 Manly JJ, Schupf N, Tang MX, Stern Y. Cognitive decline and literacy among ethnically diverse elders. J Geriatr Psychiatry Neurol. Dec. 2005;18(4):213-7. [pmid: 16306242].
1724 Manly JJ, Touradji P, Tang MX, Stern Y. Literacy and memory decline among ethnically diverse elders. J Clin Exp Neuropsychol. Aug. 2003;25(5):680-90. [pmid: 12815505].
1725 Mann VA, Foy JG. Speech development patterns and phonological awareness in preschool children. Ann Dyslexia. Jun. 2007;57(1):51-74. [pmid: 17849216].
1726 Manning DL, Dickens C. Health literacy: more choice, but do cancer patients have the skills to decide?. Eur J Cancer Care (Engl). Dec. 2006;15(5):448-52. [pmid: 17177901].
1727 Manning KD, Kripalani S. The use of standardized patients to teach low-literacy communication skills. Am J Health Behav. Sep-Oct. 1. 2007;31:S105-10. [pmid: 17931128].
1728 Mansoor LE, Dowse R. Medicines information and adherence in HIV/AIDS patients. J Clin Pharm Ther. Feb. 2006;31(1):7-15. [pmid: 16476115].
1729 Mantone J. Reading, writing and relating. Providers--rural and urban--urged to pay more attention to health literacy. Mod Healthc. Aug. 8. 2005;35(32):30-1.
1730 March JS, Szatmari P, Bukstein O, Chrisman A, Kondo D, Hamilton JD, et al. AACAP 2005 Research Forum: speeding the adoption of evidence-based practice in pediatric psychiatry. J Am Acad Child Adolesc Psychiatry. Sep. 2007;46(9):1098-110. [pmid: 17712233].
1731 Marcus EN. The silent epidemic--the health effects of illiteracy. N Engl J Med. Jul. 27. 2006;355(4):339-41. [pmid: 16870912].
1732 Marian V, Blumenfeld HK, Kaushanskaya M. The Language Experience and Proficiency Questionnaire (LEAP-Q): assessing language profiles in bilinguals and multilinguals. J Speech Lang Hear Res. Aug. 2007;50(4):940-67. [pmid: 17675598].
1733 Marie D, Forsyth DK, Miles LK. Categorical ethnicity and mental health literacy in New Zealand. Ethn Health. Aug. 2004;9(3):225-52. [pmid: 15369998].
1734 Marie D, Miles B. Social distance and perceived dangerousness across four diagnostic categories of mental disorder. Aust N Z J Psychiatry. Feb. 2008;42(2):126-33. [pmid: 18197507].
1735 Mark TL, Johnson G, Fortner B, Ryan K. The benefits and challenges of using computer-assisted symptom assessments in oncology clinics: results of a qualitative assessment. Technol Cancer Res Treat. Oct. 2008;7(5):401-6. [pmid: 18783291].
1736 Markel G, Woolfolk M, Inglehart MR. Feeding the pipeline: academic skills training for predental students. J Dent Educ. Jun. 2008;72(6):653-61. [pmid: 18519595].
1737 Marks DF. Literacy not intelligence moderates the relationships between economic development, income inequality and health. Br J Health Psychol. May. 2007;12(Pt 2):179-84. [pmid: 17456280].
1738 Marschark M. Interactions of language and cognition in deaf learners: from research to practice. Int J Audiol. Jul. 1. 2003;42:S41-8. [pmid: 12918609].
1739 Marschark M, Convertino C, McEvoy C, Masteller A. Organization and use of the mental lexicon by deaf and hearing individuals. Am Ann Deaf. Spring. 2004;149(1):51-61. [pmid: 15332467].
1740 Marschark M, Leigh G, Sapere P, Burnham D, Convertino C, Stinson M, et al. Benefits of sign language interpreting and text alternatives for deaf students' classroom learning. J Deaf Stud Deaf Educ. Fall. 2006;11(4):421-37. [pmid: 16928778].
1741 Marschark M, Rhoten C, Fabich M. Effects of cochlear implants on children's reading and academic achievement. J Deaf Stud Deaf Educ. Summer. 2007;12(3):269-82. [pmid: 17526867].
1742 Marschik PB, Einspieler C, Garzarolli B, Prechtl HF. Events at early development: are they associated with early word production and neurodevelopmental abilities at the preschool age?. Early Hum Dev. Feb. 2007;83(2):107-14. [pmid: 16876340].
1743 Marteleto L, Lam D, Ranchhod V. Sexual behavior, pregnancy, and schooling among young people in urban South Africa. Stud Fam Plann. Dec. 2008;39(4):351-68. [pmid: 19248720].
1744 Martin RC, Annis SM, Darling LZ, Wadley V, Harrell L, Marson DC. Loss of calculation abilities in patients with mild and moderate Alzheimer disease. Arch Neurol. Nov. 2003;60(11):1585-9. [pmid: 14623731].
1745 Martin RW, Head AJ, Rene J, Swartz TJ, Fiechtner JJ, McIntosh BA, et al. Patient decision-making related to antirheumatic drugs in rheumatoid arthritis: the importance of patient trust of physician. J Rheumatol. Apr. 2008;35(4):618-24. [pmid: 18278840].
1746 Martinet C, Valdois S, Fayol M. Lexical orthographic knowledge develops from the beginning of literacy acquisition. Cognition. Mar. 2004;91(2):B11-22. [pmid: 14738774].
1747 Martinez M, Maislos S, Rayford W. How to engage the Latino or African American patient with benign prostatic hyperplasia: crossing socioeconomic and cultural barriers. Am J Med. Aug. 2008;121(8 Suppl 2):S11-7. [pmid: 18675612].
1748 Martinez-Alarcon L, Rios A, Conesa C, Alcaraz J, Gonzalez MJ, Montoya M, et al. Attitude toward living related donation of patients on the waiting list for a deceased donor solid organ transplant. Transplant Proc. Nov. 2005;37(9):3614-7. [pmid: 16386484].
1749 Marx E, Hudson N, Deal TB, Pateman B, Middleton K. Promoting health literacy through the health education assessment project. J Sch Health. Apr. 2007;77(4):157-63. [pmid: 17425517].
1750 Masanja H, de Savigny D, Smithson P, Schellenberg J, John T, Mbuya C, et al. Child survival gains in Tanzania: analysis of data from demographic and health surveys. Lancet. Apr. 12. 2008;371(9620):1276-83. [pmid: 18406862].
1751 Masic I, Novo A, Toromanovic S, Dzananovic A, Masic Z, Piralic A, et al. Medical education and role of medical informatics. Stud Health Technol Inform. 2006;124:879-84. [pmid: 17108623].
1752 Master VA, Johnson TV, Abbasi A, Ehrlich SS, Kleris RS, Abbasi S, et al. Poorly numerate patients in an inner city hospital misunderstand the American Urological Association symptom score. Urology. Jan. 2010;75(1):148-52. [pmid: 19819537].
1753 Masters K. Access to and use of the Internet by South African general practitioners. Int J Med Inform. Nov. 2008;77(11):778-86. [pmid: 18619896].
1754 Mastrian K, McGonigle D, Pavlekovsky K. Information systems and case management practice series, part III: case management is implementation processes, additional technology tools, and future directions. Prof Case Manag. Sep-Oct. 2007;12(5):296-9. [pmid: 17885637].
1755 Mathavan A, Chockalingam A, Chockalingam S, Bilchik B, Saini V. Madurai Area Physicians Cardiovascular Health Evaluation Survey (MAPCHES)--an alarming status. Can J Cardiol. May. 2009;25(5):303-8. [pmid: 19417861].
1756 Matiasek J, Wynia MK. Reconceptualizing the informed consent process at eight innovative hospitals. Jt Comm J Qual Patient Saf. Mar. 2008;34(3):127-37. [pmid: 18419042].
1757 Matsuda O. An assessment of the attitudes of potential caregivers toward the abuse of elderly persons with and without dementia. Int Psychogeriatr. Oct. 2007;19(5):892-901. [pmid: 17234040].
1758 Mattheos N, Nattestad A, Christersson C, Jansson H, Attstrom R. The effects of an interactive software application on the self-assessment ability of dental students. Eur J Dent Educ. Aug. 2004;8(3):97-104. [pmid: 15233773].
1759 Mattheos N, Schittek MJ, Nattestad A, Shanley D, Attstrom R. A comparative evaluation of computer literacy amongst dental educators and students. Eur J Dent Educ. Feb. 2005;9(1):32-6. [pmid: 15642021].
1760 Matthew JT. The need for numeracy in midwifery. Midwives Chron. Jul. 1988;101(1206):204-5. [pmid: 3419355].
1761 Matthews AE. ‘Children and obesity: a pan-European project examining the role of food marketing’. Eur J Public Health. Feb. 2008;18(1):7-11. [pmid: 17522154].
1762 Matthews KA, Sowers MF, Derby CA, Stein E, Miracle-McMahill H, Crawford SL, et al. Ethnic differences in cardiovascular risk factor burden among middle-aged women: Study of Women's Health Across the Nation (SWAN). Am Heart J. Jun. 2005;149(6):1066-73. [pmid: 15976790].
1763 Maughan B, Carroll J. Literacy and mental disorders. Curr Opin Psychiatry. Jul. 2006;19(4):350-4. [pmid: 16721162].
1764 Maurer U, Brem S, Bucher K, Brandeis D. Emerging neurophysiological specialization for letter strings. J Cogn Neurosci. Oct. 2005;17(10):1532-52. [pmid: 16269095].
1765 Mausbach BT, Harvey PD, Pulver AE, Depp CA, Wolyniec PS, Thornquist MH, et al. Relationship of the Brief UCSD Performance-based Skills Assessment (UPSA-B) to multiple indicators of functioning in people with schizophrenia and bipolar disorder. Bipolar Disord. Feb. 2010;12(1):45-55. [pmid: 20148866].
1766 Mayben JK, Giordano TP. Internet use among low-income persons recently diagnosed with HIV infection. AIDS Care. Oct. 2007;19(9):1182-7. [pmid: 18058404].
1767 Mayben JK, Kramer JR, Kallen MA, Franzini L, Lairson DR, Giordano TP. Predictors of delayed HIV diagnosis in a recently diagnosed cohort. AIDS Patient Care STDS. Mar. 2007;21(3):195-204. [pmid: 17428187].
1768 Mayer C. What really matters in the early literacy development of deaf children. J Deaf Stud Deaf Educ. Fall. 2007;12(4):411-31. [pmid: 17566067].
1769 Mayer GG, Villaire M. Health literacy: an ethical responsibility. Mitigating the negative impact of low health literacy is an ethical imperative. Healthc Exec. Jul-Aug. 2003;18(4):50-1. [pmid: 12841058].
1770 Mayer GG, Villaire M. Low health literacy and its effects on patient care. J Nurs Adm. Oct. 2004;34(10):440-2. [pmid: 15577665].
1771 Mayes SD, Calhoun SL. WISC-IV and WIAT-II profiles in children with high-functioning autism. J Autism Dev Disord. Mar. 2008;38(3):428-39. [pmid: 17610151].
1772 Mayhew M, Hansen PM, Peters DH, Edward A, Singh LP, Dwivedi V, et al. Determinants of skilled birth attendant utilization in Afghanistan: a cross-sectional study. Am J Public Health. Oct. 2008;98(10):1849-56. [pmid: 18703445].
1773 Mayhorn CB, Goldsworthy RC. Refining teratogen warning symbols for diverse populations. Birth Defects Res A Clin Mol Teratol. Jun. 2007;79(6):494-506. [pmid: 17358036].
1774 Maynard NG, Conway GA. A view from above: use of satellite imagery to enhance our understanding of potential impacts of climate change on human health in the Arctic. Alaska Med. 2007;49(2 Suppl):38-43. [pmid: 17929607].
1775 Mayo RM, Erwin DO, Spitler HD. Implications for breast and cervical cancer control for Latinas in the rural South: a review of the literature. Cancer Control. Sep-Oct. 2003;10(5 Suppl):60-8. [pmid: 14581906].
1776 Mays CH, Kelley W, Sanford K. Keeping up: the nurse executive's present and future role in information technology. Nurs Adm Q. Jul-Sep. 2008;32(3):230-4. [pmid: 18580428].
1777 Mayuzumi K. Rethinking literacy and women's health: a Bangladesh case study. Health Care Women Int. Jun-Jul. 2004;25(6):504-26. [pmid: 15354619].
1778 Mbaezue N, Mayberry R, Gazmararian J, Quarshie A, Ivonye C, Heisler M. The impact of health literacy on self-monitoring of blood glucose in patients with diabetes receiving care in an inner-city hospital. J Natl Med Assoc. Jan. 2010;102(1):5-9. [pmid: 20158130].
1779 McAlister C, Baskett TF. Female education and maternal mortality: a worldwide survey. J Obstet Gynaecol Can. Nov. 2006;28(11):983-90. [pmid: 17169224].
1780 McAllister M. Looking below the surface: developing critical literacy skills to reduce the stigma of mental disorders. J Nurs Educ. Sep. 2008;47(9):426-30. [pmid: 18792711].
1781 McBride-Chang C, Lam F, Lam C, Doo S, Wong SW, Chow YY. Word recognition and cognitive profiles of Chinese pre-school children at risk for dyslexia through language delay or familial history of dyslexia. J Child Psychol Psychiatry. Feb. 2008;49(2):211-8. [pmid: 17979961].
1782 McCabe JA. An assignment for building an awareness of the intersection of health literacy and cultural competence skills. J Med Libr Assoc. Oct. 2006;94(4):458-61. [pmid: 17082843].
1783 McCannon M, O'Neal PV. Results of a national survey indicating information technology skills needed by nurses at time of entry into the work force. J Nurs Educ. Aug. 2003;42(8):337-40. [pmid: 12938895].
1784 McCannon R. Adolescents and media literacy. Adolesc Med Clin. Jun. 2005;16(2):463-80. xi. [pmid: 16111628].
1785 McCarthy F, Burns WJ, Sellers AH. Discrepancies between premorbid and current IQ as a function of progressive mental deterioration. Percept Mot Skills. Feb. 2005;100(1):69-76. [pmid: 15773695].
1786 McClelland MM, Cameron CE, Connor CM, Farris CL, Jewkes AM, Morrison FJ. Links between behavioral regulation and preschoolers' literacy, vocabulary, and math skills. Dev Psychol. Jul. 2007;43(4):947-59. [pmid: 17605527].
1787 McClelland MM, Kessenich M, Morrison FJ. Pathways to early literacy: the complex interplay of child, family, and sociocultural factors. Adv Child Dev Behav. 2003;31:411-47. [pmid: 14528667].
1788 McCormick MC, Brooks-Gunn J, Buka SL, Goldman J, Yu J, Salganik M, et al. Early intervention in low birth weight premature infants: results at 18 years of age for the Infant Health and Development Program. Pediatrics. Mar. 2006;117(3):771-80. [pmid: 16510657].
1789 McCray AT. Promoting health literacy. J Am Med Inform Assoc. Mar-Apr. 2005;12(2):152-63. [pmid: 15561782].
1790 McDade TW, Leonard WR, Burhop J, Reyes-Garcia V, Vadez V, Huanca T, et al. Predictors of C-reactive protein in Tsimane' 2 to 15 year-olds in lowland Bolivia. Am J Phys Anthropol. Dec. 2005;128(4):906-13. [pmid: 16118783].
1791 McDermid C. Social construction of American sign language--English interpreters. J Deaf Stud Deaf Educ. Winter. 2009;14(1):105-30. [pmid: 18424772].
1792 McDonald DD, Martin D, Foley D, Baker L, Hintz D, Faure L, et al. Motivating people to learn cardiopulmonary resuscitation and use of automated external defibrillators. J Cardiovasc Nurs. Jan-Feb. 2010;25(1):69-74. [pmid: 20134284].
1793 McDougall T. Child and adolescent mental health services in the UK: nurse consultants. J Child Adolesc Psychiatr Nurs. Apr-Jun. 2005;18(2):79-83. [pmid: 15966950].
1794 McEver M. October is National Health Literacy Month. J Med Assoc Ga. 2008;97(3):5. [pmid: 19044077].
1795 McFadyen J. Teaching sex education: are Scottish school nurses prepared for the challenge?. Nurse Educ Today. Feb. 2004;24(2):113-20. [pmid: 14769455].
1796 McGee R, Williams S, Howden-Chapman P, Martin J, Kawachi I. Participation in clubs and groups from childhood to adolescence and its effects on attachment and self-esteem. J Adolesc. Feb. 2006;29(1):1-17. [pmid: 16338427].
1797 McGinn T, Allen K. Improving refugees' reproductive health through literacy in Guinea. Glob Public Health. 2006;1(3):229-48. [pmid: 19153909].
1798 McGinn TG, Gardenier D, McGinn LK, Alfandre D, O'Connor-Moore N, Sturm TM, et al. Treating chronic hepatitis C in the primary care setting. Semin Liver Dis. Feb. 2005;25(1):65-71. [pmid: 15731998].
1799 McGinty AS, Justice LM. Predictors of print knowledge in children with specific language impairment: experiential and developmental factors. J Speech Lang Hear Res. Feb. 2009;52(1):81-97. [pmid: 18723595].
1800 McGorry P. ‘Every me and every you’: responding to the hidden challenge of mental illness in Australia. Australas Psychiatry. Mar. 2005;13(1):3-15. [pmid: 15777406].
1801 McGowan ML, Burant CJ, Moran R, Farrell R. Patient education and informed consent for preimplantation genetic diagnosis: health literacy for genetics and assisted reproductive technology. Genet Med. Sep. 2009;11(9):640-5. [pmid: 19652605].
1802 McGrath A. A new read on teen literacy. US News World Rep. Feb. 28. 2005;138(7):68-70. [pmid: 15765849].
1803 McGrath LM, Pennington BF, Willcutt EG, Boada R, Shriberg LD, Smith SD. Gene x Environment interactions in speech sound disorder predict language and preliteracy outcomes. Dev Psychopathol. Fall. 2007;19(4):1047-72. [pmid: 17931434].
1804 McInturff P, Johnson WO, Cowling D, Gardner IA. Modelling risk when binary outcomes are subject to error. Stat Med. Apr. 15. 2004;23(7):1095-109. [pmid: 15057880].
1805 McIntyre TP, Monahan TS, Villegas L, Doyle J, Jones DB. Teleconferencing surgery enhances effective communication and enriches medical education. Surg Laparosc Endosc Percutan Tech. Feb. 2008;18(1):45-8. [pmid: 18287982].
1806 McKeen NA, Chipperfield JG, Campbell DW. A longitudinal analysis of discrete negative emotions and health-services use in elderly individuals. J Aging Health. 2004;16(2):204-27. [pmid: 15030663].
1807 McLafferty E, Farley AH. Analysing qualitative research data using computer software. Nurs Times. Jun. 13-19. 2006;102(24):34-6. [pmid: 16827047].
1808 McLane S. Designing an EMR planning process based on staff attitudes toward and opinions about computers in healthcare. Comput Inform Nurs. Mar-Apr. 2005;23(2):85-92. [pmid: 15772509].
1809 McLeod DL, Wright LM. Living the as-yet unanswered: spiritual care practices in family systems nursing. J Fam Nurs. Feb. 2008;14(1):118-41. [pmid: 18281646].
1810 McManus IC, Livingston G, Katona C. The attractions of medicine: the generic motivations of medical school applicants in relation to demography, personality and achievement. BMC Med Educ. 2006;6:11. [pmid: 16504048].
1811 McMurray A, Johnson P, Wallis M, Patterson E, Griffiths S. General surgical patients' perspectives of the adequacy and appropriateness of discharge planning to facilitate health decision-making at home. J Clin Nurs. Sep. 2007;16(9):1602-9. [pmid: 17727581].
1812 McNeil BJ, Elfrink V, Beyea SC, Pierce ST, Bickford CJ. Computer literacy study: report of qualitative findings. J Prof Nurs. Jan-Feb. 2006;22(1):52-9. [pmid: 16459289].
1813 McNeil BJ, Elfrink VL, Bickford CJ, Pierce ST, Beyea SC, Averill C, et al. Nursing information technology knowledge, skills, and preparation of student nurses, nursing faculty, and clinicians: a U.S. survey. J Nurs Educ. Aug. 2003;42(8):341-9. [pmid: 12938896].
1814 McPherson AC, Glazebrook C, Smyth AR. Educational interventions--computers for delivering education to children with respiratory illness and to their parents. Paediatr Respir Rev. Sep. 2005;6(3):215-26. [pmid: 16153571].
1815 McPhillips M, Jordan-Black JA. Primary reflex persistence in children with reading difficulties (dyslexia): a cross-sectional study. Neuropsychologia. Mar. 2. 2007;45(4):748-54. [pmid: 17030045].
1816 McShane G, Bazzano C, Walter G, Barton G. Outcome of patients attending a specialist educational and mental health service for social anxiety disorders. Clin Child Psychol Psychiatry. Jan. 2007;12(1):117-24. [pmid: 17375813].
1817 McTigue K, Larson JC, Valoski A, Burke G, Kotchen J, Lewis CE, et al. Mortality and cardiac and vascular outcomes in extremely obese women. JAMA. Jul. 5. 2006;296(1):79-86. [pmid: 16820550].
1818 McVeigh H. Factors influencing the utilisation of e-learning in post-registration nursing students. Nurse Educ Today. Jan. 2009;29(1):91-9. [pmid: 18774625].
1819 McVey G, Tweed S, Blackmore E. Correlates of weight loss and muscle-gaining behavior in 10- to 14-year-old males and females. Prev Med. Jan. 2005;40(1):1-9. [pmid: 15530574].
1820 Meade CD, Martinez D, Schullo S, McMillan S. Distance learning for communicating cancer, culture, and literacy: a model for cancer control advancement. J Cancer Educ. Summer. 2006;21(2):63-70. [pmid: 17020515].
1821 Meade CD, Menard J, Martinez D, Calvo A. Impacting health disparities through community outreach: utilizing the CLEAN look (culture, literacy, education, assessment, and networking). Cancer Control. Jan. 2007;14(1):70-7. [pmid: 17242673].
1822 Meck Higgins M, Barkley MC. Barriers to nutrition education for older adults, and nutrition and aging training opportunities for educators, healthcare providers,volunteers and caregivers. J Nutr Elder. 2004;23(4):99-121. [pmid: 15149943].
1823 Medley CF, Horne C. Using simulation technology for undergraduate nursing education. J Nurs Educ. Jan. 2005;44(1):31-4. [pmid: 15673172].
1824 Mehta KM, Simonsick EM, Rooks R, Newman AB, Pope SK, Rubin SM, et al. Black and white differences in cognitive function test scores: what explains the difference?. J Am Geriatr Soc. Dec. 2004;52(12):2120-7. [pmid: 15571554].
1825 Mehta KM, Stewart AL, Langa KM, Yaffe K, Moody-Ayers S, Williams BA, et al. “Below average” self-assessed school performance and Alzheimer's disease in the Aging, Demographics, and Memory Study. Alzheimers Dement. Sep. 2009;5(5):380-7. [pmid: 19751917].
1826 Melnyk BM, Alpert-Gillis L, Feinstein NF, Crean HF, Johnson J, Fairbanks E, et al. Creating opportunities for parent empowerment: program effects on the mental health/coping outcomes of critically ill young children and their mothers. Pediatrics. Jun. 2004;113(6):e597-607. [pmid: 15173543].
1827 Menghini KG. Designing and evaluating parent educational materials. Adv Neonatal Care. Oct. 2005;5(5):273-83. [pmid: 16202969].
1828 Mengler ED, Hogben JH, Michie P, Bishop DV. Poor frequency discrimination is related to oral language disorder in children: a psychoacoustic study. Dyslexia. Aug. 2005;11(3):155-73. [pmid: 16128046].
1829 Mennenga HA, Hendrickx L. Faculty concerns about requiring laptops in the classroom. Nurse Educ. Jul-Aug. 2008;33(4):151-4. [pmid: 18600154].
1830 Menon SS. Structural adjustment programs and the trickle-down effect: a case study of the Fujimori period in Peru, using reproductive health as an indicator for levels of poverty. World Health Popul. Dec. 2007;9(4):44-64. [pmid: 18567951].
1831 Menon VU, Kumar KV, Gilchrist A, Sugathan TN, Sundaram KR, Nair V, et al. Prevalence of known and undetected diabetes and associated risk factors in central Kerala--ADEPS. Diabetes Res Clin Pract. Dec. 2006;74(3):289-94. [pmid: 16730847].
1832 Meram I, Bozkurt AI, Ahi S, Ozgur S. Plasma copper and zinc levels in pregnant women in Gaziantep, Turkey. Saudi Med J. Oct. 2003;24(10):1121-5. [pmid: 14578983].
1833 Merchant AT, Jones C, Kiure A, Kupka R, Fitzmaurice G, Herrera MG, et al. Water and sanitation associated with improved child growth. Eur J Clin Nutr. Dec. 2003;57(12):1562-8. [pmid: 14647221].
1834 Merriam PA, Tellez TL, Rosal MC, Olendzki BC, Ma Y, Pagoto SL, et al. Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Med Res Methodol. 2009;9:20. [pmid: 19284663].
1835 Messinger-Rapport B. Disparities in long-term healthcare. Nurs Clin North Am. Jun. 2009;44(2):179-85. [pmid: 19463674].
1836 Meyer T, Eshelman A, Abouljoud M. Neuropsychological changes in a large sample of liver transplant candidates. Transplant Proc. Dec. 2006;38(10):3559-60. [pmid: 17175330].
1837 Michel G, Silverman M, Strippoli MP, Zwahlen M, Brooke AM, Grigg J, et al. Parental understanding of wheeze and its impact on asthma prevalence estimates. Eur Respir J. Dec. 2006;28(6):1124-30. [pmid: 16870670].
1838 Mielck A, Reisig V, Rathmann W. Health inequalities among persons with type 2 diabetes: the example of intermittent claudication. Gesundheitswesen. Aug. 1. 2005;67:S137-43. [pmid: 16032532].
1839 Mielck A, Reitmeir P, Rathmann W. Knowledge about diabetes and participation in diabetes training courses: the need for improving health care for diabetes patients with low SES. Exp Clin Endocrinol Diabetes. May. 2006;114(5):240-8. [pmid: 16804798].
1840 Migliaresi P, Celentano A, Palmieri V, Pezzullo S, Martino S, Bonito M, et al. Knowledge of cardiovascular risk factors and awareness of non-pharmacological approach for risk prevention in young survivors of acute myocardial infarction. The cardiovascular risk prevention project “Help Your Heart Stay Young”. Nutr Metab Cardiovasc Dis. Jul. 2007;17(6):468-72. [pmid: 17379491].
1841 Mika VS, Kelly PJ, Price MA, Franquiz M, Villarreal R. The ABCs of Health Literacy. Fam Community Health. Oct-Dec. 2005;28(4):351-7. [pmid: 16166862].
1842 Mikropoulos TA, Strouboulis V. Factors that influence presence in educational virtual environments. Cyberpsychol Behav. Oct. 2004;7(5):582-91. [pmid: 15667053].
1843 Miles SB, Stipek D. Contemporaneous and longitudinal associations between social behavior and literacy achievement in a sample of low-income elementary school children. Child Dev. Jan-Feb. 2006;77(1):103-17. [pmid: 16460528].
1844 Milias GA, Panagiotakos DB, Pitsavos C, Xenaki D, Panagopoulos G, Stefanadis C. Prevalence of self-reported hypercholesterolaemia and its relation to dietary habits, in Greek adults; a national nutrition & health survey. Lipids Health Dis. 2006;5:5. [pmid: 16529663].
1845 Millan-Calenti JC, Tubio J, Pita-Fernandez S, Gonzalez-Abraldes I, Lorenzo T, Maseda A. Prevalence of cognitive impairment: effects of level of education, age, sex and associated factors. Dement Geriatr Cogn Disord. 2009;28(5):455-60. [pmid: 19907183].
1846 Miller DP Jr, Brownlee CD, McCoy TP, Pignone MP. The effect of health literacy on knowledge and receipt of colorectal cancer screening: a survey study. BMC Fam Pract. 2007;8:16. [pmid: 17394668].
1847 Miller EA, West DM. Characteristics associated with use of public and private web sites as sources of health care information: results from a national survey. Med Care. Mar. 2007;45(3):245-51. [pmid: 17304082].
1848 Miller EA, West DM, Wasserman M. Health information Websites: characteristics of US users by race and ethnicity. J Telemed Telecare. 2007;13(6):298-302. [pmid: 17785031].
1849 Miller J, Shaw-Kokot JR, Arnold MS, Boggin T, Crowell KE, Allegri F, et al. A study of personal digital assistants to enhance undergraduate clinical nursing education. J Nurs Educ. Jan. 2005;44(1):19-26. [pmid: 15673170].
1850 Miller KR. Linguistic diversity in a deaf prison population: implications for due process. J Deaf Stud Deaf Educ. Winter. 2004;9(1):112-9. [pmid: 15304406].
1851 Miller MJ, Abrams MA, McClintock B, Cantrell MA, Dossett CD, McCleeary EM, et al. Promoting health communication between the community-dwelling well-elderly and pharmacists: the Ask Me 3 program. J Am Pharm Assoc (2003). Nov-Dec. 2008;48(6):784-92. [pmid: 19019809].
1852 Miller MJ, Degenholtz HB, Gazmararian JA, Lin CJ, Ricci EM, Sereika SM. Identifying elderly at greatest risk of inadequate health literacy: a predictive model for population-health decision makers. Res Social Adm Pharm. Mar. 2007;3(1):70-85. [pmid: 17350558].
1853 Miller MJ, Schmitt MR, Allison JJ, Cobaugh DJ, Ray MN, Saag KG. The role of health literacy and written medicine information in nonsteroidal antiinflammatory drug risk awareness. Ann Pharmacother. Feb. 2010;44(2):274-84. [pmid: 20103612].
1854 Miller VM. Poor eHealth literacy and consumer-directed health plans: a recipe for market failure. Am J Bioeth. Nov. 2007;7(11):20-2. discussion W1-2. [pmid: 18027293].
1855 Mills T, Schneider A. The Office of the National Nurse: leadership for a new era of prevention. Policy Polit Nurs Pract. Feb. 2007;8(1):64-70. [pmid: 17470773].
1856 Millward LJ, Bryan K, Everatt J, Collins R. Clinicians and dyslexia--a computer-based assessment of one of the key cognitive skills involved in drug administration. Int J Nurs Stud. Mar. 2005;42(3):341-53. [pmid: 15708021].
1857 Milman A, Frongillo EA, de Onis M, Hwang JY. Differential improvement among countries in child stunting is associated with long-term development and specific interventions. J Nutr. Jun. 2005;135(6):1415-22. [pmid: 15930446].
1858 Milne E, Royle JA, Miller M, Bower C, de Klerk NH, Bailey HD, et al. Maternal folate and other vitamin supplementation during pregnancy and risk of acute lymphoblastic leukemia in the offspring. Int J Cancer. Jun. 1. 2010;126(11):2690-9. [pmid: 19839053].
1859 Mimica M. Implementation of new educational methods: how to overcome obstacles?. Coll Antropol. Mar. 1. 2010;34:11-4. [pmid: 20402289].
1860 Minnies D, Hawkridge T, Hanekom W, Ehrlich R, London L, Hussey G. Evaluation of the quality of informed consent in a vaccine field trial in a developing country setting. BMC Med Ethics. 2008;9:15. [pmid: 18826637].
1861 Mior SA, Laporte A. Economic and resource status of the chiropractic profession in Ontario, Canada: a challenge or an opportunity. J Manipulative Physiol Ther. Feb. 2008;31(2):104-14. [pmid: 18328936].
1862 Mirenda P. A back door approach to autism and AAC. Augment Altern Commun. 2008;24(3):220-34. [pmid: 18830911].
1863 Miron M, Nadon R. Inferential literacy for experimental high-throughput biology. Trends Genet. Feb. 2006;22(2):84-9. [pmid: 16377025].
1864 Mirza I, Mujtaba M, Chaudhry H, Jenkins R. Primary mental health care in rural Punjab, Pakistan: providers, and user perspectives of the effectiveness of treatments. Soc Sci Med. Aug. 2006;63(3):593-7. [pmid: 16542767].
1865 Mishoe SC, Hernlen K. Teaching and evaluating critical thinking in respiratory care. Respir Care Clin N Am. Sep. 2005;11(3):477-88. [pmid: 16168915].
1866 Mishra P, Hansen EH, Sabroe S, Kafle KK. Socio-economic status and adherence to tuberculosis treatment: a case-control study in a district of Nepal. Int J Tuberc Lung Dis. Oct. 2005;9(10):1134-9. [pmid: 16229225].
1867 Mitchell EA, Ryan A, Carson O, McCann S. An exploratory study of web-enhanced learning in undergraduate nurse education. J Clin Nurs. Dec. 2007;16(12):2287-96. [pmid: 18036119].
1868 Mitty E, Flores S. Assisted living nursing practice: health literacy and chronic illness management. Geriatr Nurs. Jul-Aug. 2008;29(4):230-5. [pmid: 18694698].
1869 Mixer SJ, McFarland MR, McInnis LA. Visual literacy in the online environment. Nurs Clin North Am. Dec. 2008;43(4):575-82. vii. [pmid: 18940414].
1870 Moebus S, Hanisch JU, Aidelsburger P, Bramlage P, Wasem J, Jockel KH. Impact of 4 different definitions used for the assessment of the prevalence of the Metabolic Syndrome in primary healthcare: The German Metabolic and Cardiovascular Risk Project (GEMCAS). Cardiovasc Diabetol. 2007;6:22. [pmid: 17822558].
1871 Moeller MP, Tomblin JB, Yoshinaga-Itano C, Connor CM, Jerger S. Current state of knowledge: language and literacy of children with hearing impairment. Ear Hear. Dec. 2007;28(6):740-53. [pmid: 17982362].
1872 Moestue H, Huttly S. Adult education and child nutrition: the role of family and community. J Epidemiol Community Health. Feb. 2008;62(2):153-9. [pmid: 18192604].
1873 Moestue H, Huttly S, Sarella L, Galab S. ‘The bigger the better’--mothers' social networks and child nutrition in Andhra Pradesh. Public Health Nutr. Nov. 2007;10(11):1274-82. [pmid: 17655811].
1874 Mohammed T, Campbell R, Macsweeney M, Barry F, Coleman M. Speechreading and its association with reading among deaf, hearing and dyslexic individuals. Clin Linguist Phon. Sep-Oct. 2006;20(7-8):621-30. [pmid: 17056494].
1875 Mohan R, Beydoun H, Barnes-Ely ML, Lee L, Davis JW, Lance R, et al. Patients' survival expectations before localized prostate cancer treatment by treatment status. J Am Board Fam Med. May-Jun. 2009;22(3):247-56. [pmid: 19429730].
1876 Mokwena K, Mokgatle-Nthabu M, Madiba S, Lewis H, Ntuli-Ngcobo B. Training of public health workforce at the National School of Public Health: meeting Africa's needs. Bull World Health Organ. Dec. 2007;85(12):949-54. [pmid: 18278255].
1877 Mokwena K, Mokgatle-Nthabu M, Madiba S, Lewis H, Ntuli-Ngcobo B. Training the public health workforce at the National School of Public Health: meeting Africa's needs. World Hosp Health Serv. 2008;44(2):27-31. [pmid: 18795503].
1878 Moller L, Gatherer A, Dara M. Barriers to implementation of effective tuberculosis control in prisons. Public Health. Jun. 2009;123(6):419-21. [pmid: 19487000].
1879 Monachos CL. Assessing and addressing low health literacy among surgical outpatients. AORN J. Sep. 2007;86(3):373-83. [pmid: 17822642].
1880 Monaco AP. Multivariate linkage analysis of specific language impairment (SLI). Ann Hum Genet. Sep. 2007;71(Pt 5):660-73. [pmid: 17388790].
1881 Monjauze C, Tuller L, Hommet C, Barthez MA, Khomsi A. Language in benign childhood epilepsy with centro-temporal spikes abbreviated form: rolandic epilepsy and language. Brain Lang. Mar. 2005;92(3):300-8. [pmid: 15721962].
1882 Monseur C, Berezner A. The computation of equating errors in international surveys in education. J Appl Meas. 2007;8(3):323-35. [pmid: 17804897].
1883 Montalto NJ, Spiegler GE. Functional health literacy in adults in a rural community health center. W V Med J. Mar-Apr. 2001;97(2):111-4. [pmid: 11392190].
1884 Montazeri A. AIDS knowledge and attitudes in Iran: results from a population-based survey in Tehran. Patient Educ Couns. May. 2005;57(2):199-203. [pmid: 15911193].
1885 Montazeri A, Goshtasebi A, Vahdaninia M, Gandek B. The Short Form Health Survey (SF-36): translation and validation study of the Iranian version. Qual Life Res. Apr. 2005;14(3):875-82. [pmid: 16022079].
1886 Montazeri A, Tavoli A, Mohagheghi MA, Roshan R, Tavoli Z. Disclosure of cancer diagnosis and quality of life in cancer patients: should it be the same everywhere?. BMC Cancer. 2009;9:39. [pmid: 19178719].
1887 Moody LE, Slocumb E, Berg B, Jackson D. Electronic health records documentation in nursing: nurses' perceptions, attitudes, and preferences. Comput Inform Nurs. Nov-Dec. 2004;22(6):337-44. [pmid: 15602303].
1888 Moore D, Castillo E, Richardson C, Reid RJ. Determinants of health status and the influence of primary health care services in Latin America, 1990-98. Int J Health Plann Manage. Oct-Dec. 2003;18(4):279-92. [pmid: 14727708].
1889 Moore DS, Ellis R, Allen PD, Cherry KE, Monroe PA, O'Neil CE, et al. Construct validation of physical activity surveys in culturally diverse older adults: a comparison of four commonly used questionnaires. Res Q Exerc Sport. Mar. 2008;79(1):42-50. [pmid: 18431950].
1890 Moore GA. On-line communities: helping “senior surfers” find health information on the Web. J Gerontol Nurs. Nov. 2005;31(11):42-8. [pmid: 16317993].
1891 Moore IM, Challinor J, Pasvogel A, Matthay K, Hutter J, Kaemingk K. Online exclusive: behavioral adjustment of children and adolescents with cancer: teacher, parent, and self-report. Oncol Nurs Forum. Sep-Oct. 2003;30(5):E84-91. [pmid: 12949601].
1892 Moore M. What does patient-centred communication mean in Nepal?. Med Educ. Jan. 2008;42(1):18-26. [pmid: 18042184].
1893 Moore M, Bias RG, Prentice K, Fletcher R, Vaughn T. Web usability testing with a Hispanic medically underserved population. J Med Libr Assoc. Apr. 2009;97(2):114-21. [pmid: 19404502].
1894 Moore RA, Derry S, McQuay HJ, Paling J. What do we know about communicating risk? A brief review and suggestion for contextualising serious, but rare, risk, and the example of cox-2 selective and non-selective NSAIDs. Arthritis Res Ther. 2008;10(1):R20. [pmid: 18257914].
1895 Moore S, Sherwin A. Improving patient access to healthcare professionals: a prospective audit evaluating the role of email communication for patients with lung cancer. Eur J Oncol Nurs. Dec. 2004;8(4):350-4. [pmid: 15550365].
1896 Moreno MA, Ralston JD, Grossman DC. Adolescent access to online health services: perils and promise. J Adolesc Health. Mar. 2009;44(3):244-51. [pmid: 19237110].
1897 Morewitz SJ, Shaw GP, Clark JR, Mullins S. A survey of podiatric medical students' computer literacy. J Am Podiatr Med Assoc. Jul-Aug. 2004;94(4):375-81. [pmid: 15265997].
1898 Morgan A, Jorm A. Awareness of beyondblue: the national depression initiative in Australian young people. Australas Psychiatry. Aug. 2007;15(4):329-33. [pmid: 17612888].
1899 Morgan AA, Marsiske M, Whitfield KE. Characterizing and explaining differences in cognitive test performance between african american and European American older adults. Exp Aging Res. Jan-Mar. 2008;34(1):80-100. [pmid: 18189169].
1900 Morgan AJ, Jorm AF. Recall of news stories about mental illness by Australian youth: associations with help-seeking attitudes and stigma. Aust N Z J Psychiatry. Sep. 2009;43(9):866-72. [pmid: 19670060].
1901 Morgan PD, Fogel J, Hicks P, Wright L, Tyler I. Strategic enhancement of nursing students information literacy skills: interdisciplinary perspectives. ABNF J. Spring. 2007;18(2):40-5. [pmid: 17608285].
1902 Moriarty-Craige SE, Ramakrishnan U, Neufeld L, Rivera J, Martorell R. Multivitamin-mineral supplementation is not as efficacious as is iron supplementation in improving hemoglobin concentrations in nonpregnant anemic women living in Mexico. Am J Clin Nutr. Nov. 2004;80(5):1308-11. [pmid: 15531680].
1903 Morris D. E-learning in the common learning curriculum for health and social care professionals: information literacy and the library. Health Info Libr J. Dec. 2005;22(Suppl 2):74-80. [pmid: 16279979].
1904 Morris NS, MacLean CD, Chew LD, Littenberg B. The Single Item Literacy Screener: evaluation of a brief instrument to identify limited reading ability. BMC Fam Pract. 2006;7:21. [pmid: 16563164].
1905 Morris NS, MacLean CD, Littenberg B. Literacy and health outcomes: a cross-sectional study in 1002 adults with diabetes. BMC Fam Pract. 2006;7:49. [pmid: 16907968].
1906 Morrow D, Clark D, Tu W, Wu J, Weiner M, Steinley D, et al. Correlates of health literacy in patients with chronic heart failure. Gerontologist. Oct. 2006;46(5):669-76. [pmid: 17050758].
1907 Morrow DG, Weiner M, Steinley D, Young J, Murray MD. Patients' health literacy and experience with instructions: influence preferences for heart failure medication instructions. J Aging Health. Aug. 2007;19(4):575-93. [pmid: 17682075].
1908 Morrow DG, Weiner M, Young J, Steinley D, Deer M, Murray MD. Improving medication knowledge among older adults with heart failure: a patient-centered approach to instruction design. Gerontologist. Aug. 2005;45(4):545-52. [pmid: 16051918].
1909 Moser DK, Watkins JF. Conceptualizing self-care in heart failure: a life course model of patient characteristics. J Cardiovasc Nurs. May-Jun. 2008;23(3):205-18. quiz 19-20. [pmid: 18437061].
1910 Moses J, Hogg B. Benefits literacy, Bugs Bunny and bridge. Benefits Q. 2009;25(3):20-7. [pmid: 19891334].
1911 Moskovitz M, Abud W, Ram D. The influence of an oral health education program provided in a community dental clinic on the prevalence of caries among 12-14 year-old children. J Clin Pediatr Dent. Spring. 2009;33(3):259-64. [pmid: 19476103].
1912 Movahedi M, Haghdoost AA, Pournik O, Hajarizadeh B, Fallah MS. Temporal variations of health indicators in Iran comparing with other Eastern Mediterranean Region countries in the last two decades. J Public Health (Oxf). Dec. 2008;30(4):499-504. [pmid: 18772146].
1913 Muhammad W, Faaruq S, Matiullah Hussain A, Khan AA. Release criteria from hospitals of 131I thyrotoxicosis therapy patients in developing countries--case study. Radiat Prot Dosimetry. 2006;121(2):136-9. [pmid: 16464838].
1914 Muir KW, Santiago-Turla C, Stinnett SS, Herndon LW, Allingham RR, Challa P, et al. Health literacy and adherence to glaucoma therapy. Am J Ophthalmol. Aug. 2006;142(2):223-6. [pmid: 16876500].
1915 Muir KW, Santiago-Turla C, Stinnett SS, Herndon LW, Allingham RR, Challa P, et al. Health literacy and vision-related quality of life. Br J Ophthalmol. Jun. 2008;92(6):779-82. [pmid: 18460538].
1916 Muirhead V, Marcenes W. An ecological study of caries experience, school performance and material deprivation in 5-year-old state primary school children. Community Dent Oral Epidemiol. Aug. 2004;32(4):265-70. [pmid: 15239777].
1917 Muldoon K, Lewis C, Freeman N. Why set-comparison is vital in early number learning. Trends Cogn Sci. May. 2009;13(5):203-8. [pmid: 19375377].
1918 Muldoon KP, Lewis C, Francis B. Using cardinality to compare quantities: the role of social-cognitive conflict in early numeracy. Dev Sci. Sep. 2007;10(5):694-711. [pmid: 17683352].
1919 Mulhern G, Wylie J. Changing levels of numeracy and other core mathematical skills among psychology undergraduates between 1992 and 2002. Br J Psychol. Aug. 2004;95(Pt 3):355-70. [pmid: 15296540].
1920 Mull LD, Kirkhorn SR. Child labor in Ghana cocoa production: focus upon agricultural tasks, ergonomic exposures, and associated injuries and illnesses. Public Health Rep. Nov-Dec. 2005;120(6):649-55. [pmid: 16350335].
1921 Mullen KH, Berry DL, Zierler BK. Computerized symptom and quality-of-life assessment for patients with cancer part II: acceptability and usability. Oncol Nurs Forum. Sep. 2004;31(5):E84-9. [pmid: 15378105].
1922 Mullins CD, Blatt L, Gbarayor CM, Yang HW, Baquet C. Health disparities: a barrier to high-quality care. Am J Health Syst Pharm. Sep. 15. 2005;62(18):1873-82. [pmid: 16141106].
1923 Munro N, Lee K, Baker E. Building vocabulary knowledge and phonological awareness skills in children with specific language impairment through hybrid language intervention: a feasibility study. Int J Lang Commun Disord. Nov-Dec. 2008;43(6):662-82. [pmid: 19016130].
1924 Murdaugh C, Moneyham L, Jackson K, Phillips K, Tavakoli A. Predictors of quality of life in HIV-infected rural women: psychometric test of the chronic illness quality of life ladder. Qual Life Res. Jun. 2006;15(5):777-89. [pmid: 16721638].
1925 Murer CG. EHRs: issues preventing widespread adoption. Rehab Manag. Jun. 2007;20(5):38-9.
1926 Murphy J, Stramer K, Clamp S, Grubb P, Gosland J, Davis S. Health informatics education for clinicians and managers--what's holding up progress?. Int J Med Inform. Mar. 18. 2004;73(2):205-13. [pmid: 15063381].
1927 Murphy-Knoll L. Low health literacy puts patients at risk: the Joint Commission proposes solutions to national problem. J Nurs Care Qua_. Jul-Sep. 2007;22(3):205-9.
1928 Murray MD, Morrow DG, Weiner M, Clark DO, Tu W, Deer MM, et al. A conceptual framework to study medication adherence in older adults. Am J Geriatr Pharmacother. Mar. 2004;2(1):36-43. [pmid: 15555477].
1929 Murray MD, Young J, Hoke S, Tu W, Weiner M, Morrow D, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
1930 Murray MD, Young JM, Morrow DG, Weiner M, Tu W, Hoke SC, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. Am J Geriatr Pharmacother. Mar. 2004;2(1):53-65. [pmid: 15555479].
1931 Murray TL, Belgrave L, Robinson VI. Nursing faculty members competence of Web-based course development systems directly influences students' satisfaction. ABNF J. Summer. 2006;17(3):100-2. [pmid: 16948361].
1932 Murtaugh MA, Jacobs DR Jr, Yu X, Gross MD, Steffes M. Correlates of urinary albumin excretion in young adult blacks and whites: the Coronary Artery Risk Development in Young Adults Study. Am J Epidemiol. Oct. 1. 2003;158(7):676-86. [pmid: 14507604].
1933 Murthy GV, Gupta SK, Bachani D, Jose R, John N. Current estimates of blindness in India. Br J Ophthalmol. Mar. 2005;89(3):257-60. [pmid: 15722298].
1934 Murto K, Bryson GL, Abushahwan I, King J, Moher D, El-Emam K, et al. Parents are reluctant to use technological means of communication in pediatric day care. Can J Anaesth. Apr. 2008;55(4):214-22. [pmid: 18378966].
1935 Myers C. “Please listen, it's my turn”: instructional approaches, curricula and contexts for supporting communication and increasing access to inclusion. J Intellect Dev Disabil. Dec. 2007;32(4):263-78. [pmid: 18049971].
1936 Nadler S, Zemanek JE Jr. Cultural differences and economic development of 31 countries. Psychol Rep. Aug. 2006;99(1):274-6. [pmid: 17037480].
1937 Naeem F, Irfan M, Zaidi QA, Kingdon D, Ayub M. Angry wives, abusive husbands: relationship between domestic violence and psychosocial variables. Womens Health Issues. Nov-Dec. 2008;18(6):453-62. [pmid: 18926727].
1938 Naghshineh S, Hafler JP, Miller AR, Blanco MA, Lipsitz SR, Dubroff RP, et al. Formal art observation training improves medical students' visual diagnostic skills. J Gen Intern Med. Jul. 2008;23(7):991-7. [pmid: 18612730].
1939 Nagle LM. Everything I know about informatics, I didn't learn in nursing school. Nurs Leadersh (Tor Ont). 2007;20(3):22-5. [pmid: 17987824].
1940 Nagle LM. Infoway's EHR user engagement strategy. Nurs Leadersh (Tor Ont). 2007;20(2):31-3. [pmid: 17619593].
1941 Nahm ES, Mills ME, Feege B. Long-term care information systems: an overview of the selection process. J Gerontol Nurs. Jun. 2006;32(6):32-8. [pmid: 16773861].
1942 Nahm ES, Preece J, Resnick B, Mills ME. Usability of health Web sites for older adults: a preliminary study. Comput Inform Nurs. Nov-Dec. 2004;22(6):326-34. quiz 35-6. [pmid: 15602301].
1943 Naicker AS, Roohi SA, Lee CS, Chan WH, Tay LS, Din XJ, et al. Alteration of foot temperature in diabetic neuropathy: is it another piece of puzzle?. Med J Malaysia. Feb. A. 2006;61:10-3. [pmid: 17042221].
1944 Nail-Chiwetalu B, Bernstein Ratner N. An assessment of the information-seeking abilities and needs of practicing speech-language pathologists. J Med Libr Assoc. Apr. 2007;95(2):182-8. e56. 7. [pmid: 17443251].
1945 Nail-Chiwetalu BJ, Ratner NB. Information literacy for speech-language pathologists: a key to evidence-based practice. Lang Speech Hear Serv Sch. Jul. 2006;37(3):157-67. [pmid: 16837439].
1946 Nair EL, Cienkowski KM. The impact of health literacy on patient understanding of counseling and education materials. Int J Audiol. Feb. 2010;49(2):71-5. [pmid: 20151879].
1947 Nair P, Black MM, Ackerman JP, Schuler ME, Keane VA. Children's cognitive-behavioral functioning at age 6 and 7: prenatal drug exposure and caregiving environment. Ambul Pediatr. May-Jun. 2008;8(3):154-62. [pmid: 18501861].
1948 Naito M, Nakayama T, Hamajima N. Health literacy education for children: acceptability of a school-based program in oral health. J Oral Sci. Mar. 2007;49(1):53-9. [pmid: 17429183].
1949 Naito M, Suzukamo Y, Nakayama T, Hamajima N, Fukuhara S. Linguistic adaptation and validation of the General Oral Health Assessment Index (GOHAI) in an elderly Japanese population. J Public Health Dent. Fall. 2006;66(4):273-5. [pmid: 17225823].
1950 Najman JM, Hayatbakhsh MR, Heron MA, Bor W, O'Callaghan MJ, Williams GM. The impact of episodic and chronic poverty on child cognitive development. J Pediatr. Feb. 2009;154(2):284-9. [pmid: 19038402].
1951 Nakawatase Y, Taru C, Tsutou A, Shiotani H, Kido Y, Ohara T, et al. Development of an evaluation scale for self-management behavior related to physical activity of type 2 diabetic patients. Diabetes Care. Nov. 2007;30(11):2843-8. [pmid: 17644618].
1952 Nalcaci R, Erdemir EO, Baran I. Evaluation of the oral health status of the people aged 65 years and over living in near rural district of Middle Anatolia, Turkey. Arch Gerontol Geriatr. Jul-Aug. 2007;45(1):55-64. [pmid: 17097161].
1953 Nancollis A, Lawrie BA, Dodd B. Phonological awareness intervention and the acquisition of literacy skills in children from deprived social backgrounds. Lang Speech Hear Serv Sch. Oct. 2005;36(4):325-35. [pmid: 16389704].
1954 Narr RF. Phonological awareness and decoding in deaf/hard-of-hearing students who use visual phonics. J Deaf Stud Deaf Educ. Summer. 2008;13(3):405-16. [pmid: 18209021].
1955 Nash R. Inequality/difference in education: is a real explanation of primary and secondary effects possible?. Br J Sociol. Dec. 2003;54(4):433-51. [pmid: 14660253].
1956 Natale-Pereira A, Marks J, Vega M, Mouzon D, Hudson SV, Salas-Lopez D. Barriers and facilitators for colorectal cancer screening practices in the Latino community: perspectives from community leaders. Cancer Control. Apr. 2008;15(2):157-65. [pmid: 18376383].
1957 Nath C. Literacy and diabetes self-management. Am J Nurs. Jun. 2007;107(6 Suppl):43-9. quiz 9. [pmid: 17563437].
1958 Nathan L, Stackhouse J, Goulandris N, Snowling MJ. The development of early literacy skills among children with speech difficulties: a test of the “critical age hypothesis”. J Speech Lang Hear Res. Apr. 2004;47(2):377-91. [pmid: 15157138].
1959 Nathan L, Stackhouse J, Goulandris N, Snowling MJ. Educational consequences of developmental speech disorder: Key Stage 1 National Curriculum assessment results in English and mathematics. Br J Educ Psychol. Jun. 2004;74(Pt 2):173-86. [pmid: 15130186].
1960 Nations MK, Calvasina PG, Martin MN, Dias HF. Cultural significance of primary teeth for caregivers in Northeast Brazil. Cad Saude Publica. Apr. 2008;24(4):800-8. [pmid: 18392357].
1961 Nazari M, Fakoorziba MR, Shobeiri F. Pediculus capitis infestation according to sex and social factors in Hamedan, Iran. Southeast Asian J Trop Med Public Health. 3. 2006;37:95-8. [pmid: 17547060].
1962 Nazari M, Saidijam M. Pediculus capitis infestation according to sex and social factors in Hamedan-Iran. Pak J Biol Sci. Oct. 1. 2007;10(19):3473-5. [pmid: 19090174].
1963 Neafsey PJ, Anderson E, Peabody S, Lin CA, Strickler Z, Vaughn K. Beta testing of a network-based health literacy program tailored for older adults with hypertension. Comput Inform Nurs. Nov-Dec. 2008;26(6):311-9. [pmid: 19047879].
1964 Neal KC. Health literacy: more than a oneway street. Am J Bioeth. Nov. 2007;7(11):29-30. discussion W1-2. [pmid: 18027298].
1965 Near JA, Martin BJ. Expanding course goals beyond disciplinary boundaries: physiology education in an undergraduate course on psychoactive drugs. Adv Physiol Educ. Jun. 2007;31(2):161-6. [pmid: 17562905].
1966 Nebel IT, Klemm T, Fasshauer M, Muller U, Verlohren HJ, Klaiberg A, et al. Comparative analysis of conventional and an adaptive computer-based hypoglycaemia education programs. Patient Educ Couns. Jun. 2004;53(3):315-8. [pmid: 15186869].
1967 Nedrow AR, Heitkemper M, Frenkel M, Mann D, Wayne P, Hughes E. Collaborations between allopathic and complementary and alternative medicine health professionals: four initiatives. Acad Med. Oct. 2007;82(10):962-6. [pmid: 17895657].
1968 Nelson CS, Wissow LS, Cheng TL. Effectiveness of anticipatory guidance: recent developments. Curr Opin Pediatr. Dec. 2003;15(6):630-5. [pmid: 14631211].
1969 Nelson MC, Lytle LA, Pasch KE. Improving literacy about energy-related issues: the need for a better understanding of the concepts behind energy intake and expenditure among adolescents and their parents. J Am Diet Assoc. Feb. 2009;109(2):281-7. [pmid: 19167955].
1970 Nelson R. Electronic health records: useful tools or high-tech headache?. Am J Nurs. Mar. 2007;107(3):25-6.
1971 Nelson RL, Hawley HK. Inner control as an operational mechanism in attention deficit hyperactivity disorder. Semin Speech Lang. Aug. 2004;25(3):255-61. [pmid: 15359369].
1972 Nelson W, Reyna VF, Fagerlin A, Lipkus I, Peters E. Clinical implications of numeracy: theory and practice. _nn Behav Med. Jun. 2008;35(3):261-74.
1973 Neuhauser L, Kreps GL. Online cancer communication: meeting the literacy, cultural and linguistic needs of diverse audiences. Patient Educ Couns. Jun. 2008;71(3):365-77. [pmid: 18424046].
1974 Neuhauser L, Rothschild R, Rodriguez FM. MyPyramid.gov: assessment of literacy, cultural and linguistic factors in the USDA food pyramid web site. J Nutr Educ Behav. Jul-Aug. 2007;39(4):219-25. [pmid: 17606248].
1975 Neville A, Jenkins J, Williams JD, Craig KJ. Peritoneal dialysis training: a multisensory approach. Perit Dial Int. Feb. 3. 2005;25:S149-51. [pmid: 16048283].
1976 Newmann SJ, Goldberg AB, Aviles R, Molina de Perez O, Foster-Rosales AF. Predictors of contraception knowledge and use among postpartum adolescents in El Salvador. Am J Obstet Gynecol. May. 2005;192(5):1391-4. [pmid: 15902118].
1977 Ngatia EM, Ng'ang'a PM, Muita JW, Imungi JK. Dietary patterns and nutritional status of pre-school children in Nairobi. East Afr Med J. Oct. 2005;82(10):520-5. [pmid: 16450680].
1978 Nguyen HQ, Carrieri-Kohlman V, Rankin SH, Slaughter R, Stulbarg MS. Supporting cardiac recovery through eHealth technology. J Cardiovasc Nurs. May-Jun. 2004;19(3):200-8. [pmid: 15191263].
1979 Nicholas D, Williams P, Smith A, Longbottom P. The information needs of perioperative staff: a preparatory study for a proposed specialist library for theatres (NeLH). Health Info Libr J. Mar. 2005;22(1):35-43. [pmid: 15810930].
1980 Nichols T. Signs of change in Turkey's working class: workers' age-related perceptions in the modern manufacturing sector. Br J Sociol. Dec. 2003;54(4):527-46. [pmid: 14660257].
1981 Nicholson WJ, Cates CU, Patel AD, Niazi K, Palmer S, Helmy T, et al. Face and content validation of virtual reality simulation for carotid angiography: results from the first 100 physicians attending the Emory NeuroAnatomy Carotid Training (ENACT) program. Simul Healthc. Fall. 2006;1(3):147-50. [pmid: 19088583].
1982 Nickerson JF. Deaf college students' perspectives on literacy portfolios. Am Ann Deaf. Spring. 2003;148(1):31-7. [pmid: 12765088].
1983 Nickol T, Lorber CG. Germany between 1780 and 1810. Clio Med. 2003;72:361-70. [pmid: 12952666].
1984 Nicolson RI, Fawcett AJ. Developmental dyslexia, learning and the cerebellum. J Neural Transm Suppl. 2005;(69):19-36. [pmid: 16355601].
1985 Nikolopoulos D, Goulandris N, Hulme C, Snowling MJ. The cognitive bases of learning to read and spell in Greek: evidence from a longitudinal study. J Exp Child Psychol. May. 2006;94(1):1-17. [pmid: 16403510].
1986 Nimmon LE. Within the eyes of the people: using a photonovel as a consciousness-raising health literacy tool with ESL-speaking immigrant women. Can J Public Health. Jul-Aug. 2007;98(4):337-40. [pmid: 17896748].
1987 Nippold MA, Duthie JK, Larsen J. Literacy as a leisure activity: free-time preferences of older children and young adolescents. Lang Speech Hear Serv Sch. Apr. 2005;36(2):93-102. [pmid: 15981705].
1988 Nirmalan PK, Padmavathi A, Thulasiraj RD. Sex inequalities in cataract blindness burden and surgical services in south India. Br J Ophthalmol. Jul. 2003;87(7):847-9. [pmid: 12812882].
1989 Nisar N, White F. Factors affecting utilization of antenatal care among reproductive age group women (15-49 years) in an urban squatter settlement of Karachi. J Pak Med Assoc. Feb. 2003;53(2):47-53. [pmid: 12705483].
1990 Nishiwaki Y, Clark H, Morton SM, Leon DA. Early life factors, childhood cognition and postal questionnaire response rate in middle age: the Aberdeen Children of the 1950s study. BMC Med Res Methodol. 2005;5(1):16. [pmid: 15876348].
1991 Nishiyori A, Shibata A, Ogimoto I, Uchimura N, Egami H, Nakamura J, et al. Alcohol drinking frequency is more directly associated with alcohol use disorder than alcohol metabolizing enzymes among male Japanese. Psychiatry Clin Neurosci. Feb. 2005;59(1):38-44. [pmid: 15679538].
1992 Noble KG, McCandliss BD. Reading development and impairment: behavioral, social, and neurobiological factors. J Dev Behav Pediatr. Oct. 2005;26(5):370-8. [pmid: 16222178].
1993 Noel DH. Financial literacy tools for young people with disabilities. NCSL Legisbrief. Oct. 2005;13(39):1-2.
1994 Noel M, Peterson C, Jesso B. The relationship of parenting stress and child temperament to language development among economically disadvantaged preschoolers. J Child Lang. Nov. 2008;35(4):823-43. [pmid: 18838014].
1995 Nojomi M, Akbarian A, Ashory-Moghadam S. Burden of abortion: induced and spontaneous. Arch Iran Med. Jan. 2006;9(1):39-45. [pmid: 16649376].
1996 Nokes KM, Coleman CL, Cashen M, Dole P, Sefcik E, Hamilton MJ, et al. Health literacy and health outcomes in HIV seropositive persons. Res Nurs Health. Dec. 2007;30(6):620-7. [pmid: 18022832].
1997 Nolan A. Education. The kids are alright. Health Serv J. Jun. 21. 2007;117(6061). 8-9.
1998 Noor AM, Omumbo JA, Amin AA, Zurovac D, Snow RW. Wealth, mother's education and physical access as determinants of retail sector net use in rural Kenya. Malar J. 2006;5:5. [pmid: 16436216].
1999 Norman CD, Skinner HA. eHEALS: The eHealth Literacy Scale. J Med Internet Res. 2006;8(4):e27. [pmid: 17213046].
2000 Norman CD, Skinner HA. eHealth Literacy: Essential Skills for Consumer Health in a Networked World. J Med Internet Res. 2006;8(2):e9. [pmid: 16867972].
2001 Northcott E, Connolly AM, Berroya A, Sabaz M, McIntyre J, Christie J, et al. The neuropsychological and language profile of children with benign rolandic epilepsy. Epilepsia. Jun. 2005;46(6):924-30. [pmid: 15946332].
2002 Nour A. Breast-conserving therapy in low-literacy patients in a developing country. Breast J. Mar-Apr. 2003;9(2):71-3. [pmid: 12603377].
2003 Novo A, Masic I. Ensuring patient safety. Med Arh. 2007;61(4):262-3. [pmid: 18298006].
2004 Nowalk MP, Lin CJ, Zimmerman RK, Ko FS, Hoberman A, Zoffel L, et al. Changes in parents' perceptions of infant influenza vaccination over two years. J Natl Med Assoc. Jun. 2007;99(6):636-41. [pmid: 17595932].
2005 Nowalk MP, Zimmerman RK, Lin CJ, Ko FS, Raymund M, Hoberman A, et al. Parental perspectives on influenza immunization of children aged 6 to 23 months. Am J Prev Med. Oct. 2005;29(3):210-4. [pmid: 16168870].
2006 Nsiah-Kumi PA. Communicating effectively with vulnerable populations during water contamination events. J Water Health. 1. 2008;6:63-75. [pmid: 18401130].
2007 Ntshebe O, Pitso JM, Segobye AK. The use of culturally themed HIV messages and their implications for future behaviour change communication campaigns: the case of Botswana. Sahara J. Aug. 2006;3(2):466-76. [pmid: 17605206].
2008 Nuckles M, Wittwer J, Renkl A. Information about a layperson's knowledge supports experts in giving effective and efficient online advice to laypersons. J Exp Psychol Appl. Dec. 2005;11(4):219-36. [pmid: 16393032].
2009 Nusbaum NJ. Mathematics preparation for medical school: do all premedical students need calculus?. Teach Learn Med. Spring. 2006;18(2):165-8. [pmid: 16626276].
2010 Nutbeam D. The evolving concept of health literacy. Soc Sci Med. Dec. 2008;67(12):2072-8. [pmid: 18952344].
2011 Nwogu R, Larson JS, Kim MS. Reducing child mortality in Nigeria: a case study of immunization and systemic factors. Soc Sci Med. Jul. 2008;67(1):161-4. [pmid: 18420324].
2012 Oates DJ, Silliman RA. Health literacy: improving patient understanding. Oncology (Williston Park). Apr. 15. 2009;23(4):376. 9. [pmid: 19476268].
2013 Oba S, Nagata C, Nakamura K, Fujii K, Kawachi T, Takatsuka N, et al. Consumption of coffee, green tea, oolong tea, black tea, chocolate snacks and the caffeine content in relation to risk of diabetes in Japanese men and women. Br J Nutr. Feb. 2010;103(3):453-9. [pmid: 19818197].
2014 Oberprieler G, Masters K, Gibbs T. Information technology and information literacy for first year health sciences students in South Africa: matching early and professional needs. Med Teach. Nov. 2005;27(7):595-8. [pmid: 16332550].
2015 O'Bryant SE, Lucas JA, Willis FB, Smith GE, Graff-Radford NR, Ivnik RJ. Discrepancies between self-reported years of education and estimated reading level among elderly community-dwelling African-Americans: Analysis of the MOAANS data. Arch Clin Neuropsychol. Mar. 2007;22(3):327-32. [pmid: 17336494].
2016 O'Bryant SE, O'Jile JR. Attenuating demographic influences on verbal fluency and animal naming in a psychiatric sample. Appl Neuropsychol. 2004;11(4):210-4. [pmid: 15673493].
2017 O'Bryant SE, Schrimsher GW, O'Jile JR. Discrepancies between self-reported years of education and estimated reading level: potential implications for neuropsychologists. Appl Neuropsychol. 2005;12(1):5-11. [pmid: 15788217].
2018 O'Callaghan C, Quine S. How older Vietnamese Australian women manage their medicines. J Cross Cult Gerontol. Dec. 2007;22(4):405-19. [pmid: 17846877].
2019 O'Callaghan FV, O'Callaghan M, Najman JM, Williams GM, Bor W. Prenatal alcohol exposure and attention, learning and intellectual ability at 14 years: a prospective longitudinal study. Early Hum Dev. Feb. 2007;83(2):115-23. [pmid: 16842939].
2020 O'Connor M, Arnott W, McIntosh B, Dodd B. Phonological awareness and language intervention in preschoolers from low socio-economic backgrounds: a longitudinal investigation. Br J Dev Psychol. Nov. 2009;27(Pt 4):767-82. [pmid: 19994478].
2021 O'Connor PJ. Mental energy: Assessing the mood dimension. Nutr Rev. Jul. 2006;64(7 Pt 2):S7-9. [pmid: 16910215].
2022 O'Connor PJ, Pronk NP, Tan A, Whitebird RR. Characteristics of adults who use prayer as an alternative therapy. Am J Health Promot. May-Jun. 2005;19(5):369-75. [pmid: 15895540].
2023 O'Connor RC, Rasmussen S, Miles J, Hawton K. Self-harm in adolescents: self-report survey in schools in Scotland. Br J Psychiatry. Jan. 2009;194(1):68-72. [pmid: 19118330].
2024 Ogbu CN. Sudden infant death syndrome (SIDS) or cot death: a review. West Afr J Med. Jan-Mar. 2003;22(1):88-91. [pmid: 12769316].
2025 Ogden JA, Cross GL, Williams SS. Bilateral chronic proximal plantar fasciopathy: treatment with electrohydraulic orthotripsy. Foot Ankle Int. May. 2004;25(5):298-302. [pmid: 15134609].
2026 Ogedegbe G. Barriers to optimal hypertension control. J Clin Hypertens (Greenwich). Aug. 2008;10(8):644-6. [pmid: 18772648].
2027 Oh H, Eom M, Kwon Y. A study on aggressive behavior among nursing home residents with cognitive impairment. Taehan Kanho Hakhoe Chi. Dec. 2004;34(8):1451-9. [pmid: 15687787].
2028 O'Hara DM, Seagriff-Curtin P, Levitz M, Davies D, Stock S. Using Personal Digital Assistants to improve self-care in oral health. J Telemed Telecare. 2008;14(3):150-1. [pmid: 18430286].
2029 O'Hare A. Acquiring literacy in the face of severe speech and physical impairments. Dev Med Child Neurol. Aug. 2006;48(8):628. [pmid: 16836772].
2030 Ohnishi M, Nakamura K, Takano T. Improvement in maternal health literacy among pregnant women who did not complete compulsory education: policy implications for community care services. Health Policy. May. 2005;72(2):157-64. [pmid: 15802151].
2031 O'Keeffe MJ, O'Callaghan M, Williams GM, Najman JM, Bor W. Learning, cognitive, and attentional problems in adolescents born small for gestational age. Pediatrics. Aug. 2003;112(2):301-7. [pmid: 12897278].
2032 Okuyama T, Nakane Y, Endo C, Seto T, Kato M, Seki N, et al. Mental health literacy in Japanese cancer patients: ability to recognize depression and preferences of treatments-comparison with Japanese lay public. Psychooncology. Sep. 2007;16(9):834-42. [pmid: 17120276].
2033 O'Leary DS, Davis RM, Cordell T. Low health literacy puts patients at risk: The Joint Commission sets forth solutions to national problem. Director. Summer. 2007;15(3):44. 59. [pmid: 19343859].
2034 Olendzki BC, Ma Y, Hebert JR, Pagoto SL, Merriam PA, Rosal MC, et al. Underreporting of energy intake and associated factors in a Latino population at risk of developing type 2 diabetes. J Am Diet Assoc. Jun. 2008;108(6):1003-8. [pmid: 18502234].
2035 Oliver BR, Dale PS, Plomin R. Predicting literacy at age 7 from preliteracy at age 4. Psychol Sci. Nov. 2005;16(11):861-5. [pmid: 16262770].
2036 Olney CA, Warner DG, Reyna G, Wood FB, Siegel ER. MedlinePlus and the challenge of low health literacy: findings from the Colonias project. J Med Libr Assoc. Jan. 2007;95(1):31-9. [pmid: 17252064].
2037 Olson CK, Kutner LA, Warner DE, Almerigi JB, Baer L, Nicholi AM 2nd, et al. Factors correlated with violent video game use by adolescent boys and girls. J Adolesc Health. Jul. 2007;41(1):77-83. [pmid: 17577537].
2038 Olson R, Sabogal F, Perez A. Viva la Vida: helping Latino Medicare beneficiaries with diabetes live their lives to the fullest. Am J Public Health. Feb. 2008;98(2):205-8. [pmid: 18172150].
2039 Olusanya BO, Okolo AA, Aderemi AA. Predictors of hearing loss in school entrants in a developing country. J Postgrad Med. Jul-Sep. 2004;50(3):173-8. discussion 8-9. [pmid: 15377800].
2040 Oman KM, Usher K, Moulds R. Lack of coordination between health policy and medical education: a contributing factor to the resignation of specialist trainees in Fiji?. N Z Med J. 2009;122(1291):28-38. [pmid: 19322253].
2041 Omokhodion FO, Omokhodion SI, Odusote TO. Perceptions of child labour among working children in Ibadan, Nigeria. Child Care Health Dev. May. 2006;32(3):281-6. [pmid: 16634973].
2042 Onyeaso CO, Arowojulo MO, Obiechina AE, Fasola AO, Olumide EA. A survey of the medical and dental consultants' management skills in University College Hospital, Ibadan, Nigeria. Niger Postgrad Med J. Dec. 2003;10(4):224-7. [pmid: 15045014].
2043 Ormandy P, Vlaminck H, Harrington M, Forest M, Visser R. A new Internet resource for chronic kidney disease patients. Edtna Erca J. Jan-Mar. 2006;32(1):63-6. [pmid: 16700172].
2044 Ormond KE, Iris M, Banuvar S, Minogue J, Annas GJ, Elias S. What do patients prefer: informed consent models for genetic carrier testing. J Genet Couns. Aug. 2007;16(4):539-50. [pmid: 17492496].
2045 Ornes LL, Gassert C. Computer competencies in a BSN program. J Nurs Educ. Feb. 2007;46(2):75-8. [pmid: 17315566].
2046 Ortolon K. Clearing the confusion. Physicians turn attention to low health literacy concerns. Tex Med. Jun. 2004;100(6):49-51.
2047 Osborn CY, Cavanaugh K, Wallston KA, White RO, Rothman RL. Diabetes numeracy: an overlooked factor in understanding racial disparities in glycemic control. Diabetes Care. Sep. 2009;32(9):1614-9. [pmid: 19401443].
2048 Osborn CY, Paasche-Orlow MK, Davis TC, Wolf MS. Health literacy: an overlooked factor in understanding HIV health disparities. Am J Prev Med. Nov. 2007;33(5):374-8. [pmid: 17950402].
2049 Osborn CY, Weiss BD, Davis TC, Skripkauskas S, Rodrigue C, Bass PF, et al. Measuring adult literacy in health care: performance of the newest vital sign. Am J Health Behav. Sep-Oct. 1. 1. 2007;31:S36-46. [pmid: 17931135].
2050 Osborne H. Communicating with clients in person and over the phone. Issue Brief Cent Medicare Educ. 2003;4(8):1-8. [pmid: 14608993].
2051 Osborne H. Health literacy: how visuals can help tell the healthcare story. J Vis Commun Med. Mar. 2006;29(1):28-32. [pmid: 16766310].
2052 Osborne H. NDNA Nursing Education Council Health Literacy: five steps to effective written communication. Prairie Rose. Feb-Apr. 2006;75(1):25. [pmid: 19264077].
2053 Ostrow L, DiMaria-Ghalili RA. Distance education for graduate nursing: one state school's experience. J Nurs Educ. Jan. 2005;44(1):5-10. [pmid: 15673168].
2054 Ouellette G, Senechal M. Pathways to literacy: a study of invented spelling and its role in learning to read. Child Dev. Jul-Aug. 2008;79(4):899-913. [pmid: 18717897].
2055 Overy K. Dyslexia and music. From timing deficits to musical intervention. Ann N Y Acad Sci. Nov. 2003;999:497-505. [pmid: 14681173].
2056 Owens L, Walden D. Health literacy: the new essential in nursing education. Nurse Educ. Nov-Dec. 2007;32(6):238-9. [pmid: 17998849].
2057 Ownby RL. Development of an interactive tailored information application to improve patient medication adherence. AMIA Annu Symp Proc. 2005:1069.
2058 Ownby RL. Medication adherence and health care literacy: filling in the gap between efficacy and effectiveness. Curr Psychiatry Rep. Mar. 2005;7(1):1-2. [pmid: 15717976].
2059 Ownby RL, Czaja SJ. Healthcare website design for the elderly: improving usability. AMIA Annu Symp Proc. 2003:960.
2060 Oyadoke AA, Salami KK, Brieger WR. Planning health education: Internet and computer resources in southwestern Nigeria. 2000-2001. Int Q Community Health Educ. 2005;25(1-2):169-83. [pmid: 17686702].
2061 Ozsoy SA, Ardahan M. Research on knowledge sources used in nursing practices. Nurse Educ Today. Jul. 2008;28(5):602-9. [pmid: 17988767].
2062 Paasche-Orlow MK, Cheng DM, Palepu A, Meli S, Faber V, Samet JH. Health literacy, antiretroviral adherence, and HIV-RNA suppression: a longitudinal perspective. J Gen Intern Med. Aug. 2006;21(8):835-40. [pmid: 16881943].
2063 Paasche-Orlow MK, Clarke JG, Hebert MR, Ray MK, Stein MD. Educational attainment but not literacy is associated with HIV risk behavior among incarcerated women. J Womens Health (Larchmt). Nov. 2005;14(9):852-9. [pmid: 16313213].
2064 Paasche-Orlow MK, Jacob DM, Powell JN. Notices of Privacy Practices: a survey of the Health Insurance Portability and Accountability Act of 1996 documents presented to patients at US hospitals. Med Care. Jun. 2005;43(6):558-64. [pmid: 15908850].
2065 Paasche-Orlow MK, Parker RM, Gazmararian JA, Nielsen-Bohlman LT, Rudd RR. The prevalence of limited health literacy. J Gen Intern Med. Feb. 2005;20(2):175-84. [pmid: 15836552].
2066 Paasche-Orlow MK, Riekert KA, Bilderback A, Chanmugam A, Hill P, Rand CS, et al. Tailored education may reduce health literacy disparities in asthma self-management. Am J Respir Crit Care Med. Oct. 15. 2005;172(8):980-6. [pmid: 16081544].
2067 Paasche-Orlow MK, Schillinger D, Greene SM, Wagner EH. How health care systems can begin to address the challenge of limited literacy. J Gen Intern Med. Aug. 2006;21(8):884-7. [pmid: 16881952].
2068 Paasche-Orlow MK, Taylor HA, Brancati FL. Readability standards for informed-consent forms as compared with actual readability. N Engl J Med. Feb. 20. 2003;348(8):721-6. [pmid: 12594317].
2069 Paasche-Orlow MK, Wolf MS. The causal pathways linking health literacy to health outcomes. Am J Health Behav. Sep-Oct. 1. 2007;31:S19-26. [pmid: 17931132].
2070 Padgette D. Are you computer-competent?. S C Nurse. Apr-Jun. 2003;10(2):20. [pmid: 13677109].
2071 Pal R, Sagar V. Correlates of vitamin A deficiency among Indian rural preschool-age children. Eur J Ophthalmol. Nov-Dec. 2007;17(6):1007-9. [pmid: 18050135].
2072 Palfrey JS, Hauser-Cram P, Bronson MB, Warfield ME, Sirin S, Chan E. The Brookline Early Education Project: a 25-year follow-up study of a family-centered early health and development intervention. Pediatrics. Jul. 2005;116(1):144-52. [pmid: 15995045].
2073 Palmer BW, Dunn LB, Appelbaum PS, Mudaliar S, Thal L, Henry R, et al. Assessment of capacity to consent to research among older persons with schizophrenia, Alzheimer disease, or diabetes mellitus: comparison of a 3-item questionnaire with a comprehensive standardized capacity instrument. Arch Gen Psychiatry. Jul. 2005;62(7):726-33. [pmid: 15997013].
2074 Pan BA, Rowe ML, Singer JD, Snow CE. Maternal correlates of growth in toddler vocabulary production in low-income families. Child Dev. Jul-Aug. 2005;76(4):763-82. [pmid: 16026495].
2075 Panagiotakos DB, Pitsavos C, Chrysohoou C, Skoumas I, Stefanadis C. Five-year incidence of cardiovascular disease and its predictors in Greece: the ATTICA study. Vasc Med. 2008;13(2):113-21. [pmid: 18593800].
2076 Pandav R, Dodge HH, DeKosky ST, Ganguli M. Blood pressure and cognitive impairment in India and the United States: a cross-national epidemiological study. Arch Neurol. Aug. 2003;60(8):1123-8. [pmid: 12925370].
2077 Pandav RS, Chandra V, Dodge HH, DeKosky ST, Ganguli M. Hemoglobin levels and Alzheimer disease: an epidemiologic study in India. Am J Geriatr Psychiatry. Sep-Oct. 2004;12(5):523-6. [pmid: 15353391].
2078 Pandey M. Quality of life of patients with cancer in India: challenges and hurdles in putting theory into practice. Psychooncology. Jun. 2004;13(6):429-33. [pmid: 15188448].
2079 Pank CM. Online education. Am J Nurs. May. 2007;107(5):74-6. [pmid: 17443089].
2080 Pankow JS, Duncan BB, Schmidt MI, Ballantyne CM, Couper DJ, Hoogeveen RC, et al. Fasting plasma free fatty acids and risk of type 2 diabetes: the atherosclerosis risk in communities study. Diabetes Care. Jan. 2004;27(1):77-82. [pmid: 14693970].
2081 Panteghini M. The new definition of myocardial infarction and the impact of troponin determination on clinical practice. Int J Cardiol. Jan. 26. 2006;106(3):298-306. [pmid: 15950298].
2082 Pappas G, Kiriaze IJ, Giannakis P, Falagas ME. Psychosocial consequences of infectious diseases. Clin Microbiol Infect. Aug. 2009;15(8):743-7. [pmid: 19754730].
2083 Pappas G, Panagopoulou P, Christou L, Akritidis N. Brucella as a biological weapon. Cell Mol Life Sci. Oct. 2006;63(19-20):2229-36. [pmid: 16964579].
2084 Pappas G, Papadimitriou P, Falagas ME. World Wide Web hepatitis B virus resources. J Clin Virol. Feb. 2007;38(2):161-4. [pmid: 17174595].
2085 Pappas G, Siozopoulou V, Saplaoura K, Vasiliou A, Christou L, Akritidis N, et al. Health literacy in the field of infectious diseases: the paradigm of brucellosis. J Infect. Jan. 2007;54(1):40-5. [pmid: 16533534].
2086 Paradise JL, Feldman HM, Campbell TF, Dollaghan CA, Rockette HE, Pitcairn DL, et al. Tympanostomy tubes and developmental outcomes at 9 to 11 years of age. N Engl J Med. Jan. 18. 2007;356(3):248-61. [pmid: 17229952].
2087 Parashar S. Moving beyond the mother-child dyad: women's education, child immunization, and the importance of context in rural India. Soc Sci Med. Sep. 2005;61(5):989-1000. [pmid: 15955401].
2088 Parker C, Philp I. Screening for cognitive impairment among older people in black and minority ethnic groups. Age Ageing. Sep. 2004;33(5):447-52. [pmid: 15217776].
2089 Parker G, Crawford J. Judged effectiveness of differing antidepressant strategies by those with clinical depression. Aust N Z J Psychiatry. Jan. 2007;41(1):32-7. [pmid: 17464679].
2090 Parker R, Kreps GL. Library outreach: overcoming health literacy challenges. J Med Libr Assoc. Oct. 2005;93(4 Suppl):S81-5. [pmid: 16239962].
2091 Parker RM, Gazmararian JA. Health literacy: essential for health communication. J Health Commun. 1. 2003;8:116-8. [pmid: 14692576].
2092 Parker RM, Ratzan SC, Lurie N. Health literacy: a policy challenge for advancing high-quality health care. Health Aff (Millwood). Jul-Aug. 2003;22(4):147-53. [pmid: 12889762].
2093 Parmet WE, Robbins A. Public health literacy for lawyers. J Law Med Ethics. Winter. 2003;31(4):701-13. [pmid: 14968671].
2094 Parna K, Rahu M, Youngman LD, Rahu K, Nygard-Kibur M, Koupil I. Self-reported and serum cotinine-validated smoking in pregnant women in Estonia. Matern Child Health J. Dec. 2005;9(4):385-92. [pmid: 16249943].
2095 Parris TM, Kates RW. Characterizing a sustainability transition: goals, targets, trends, and driving forces. Proc Natl Acad Sci U S A. Jul. 8. 2003;100(14):8068-73. [pmid: 12819346].
2096 Partridge MR. An assessment of the feasibility of telephone and email consultation in a chest clinic. Patient Educ Couns. Jul. 2004;54(1):11-3. [pmid: 15210254].
2097 Paschal AM, Hawley SR, St Romain T, Ablah E. Measures of adherence to epilepsy treatment: review of present practices and recommendations for future directions. Epilepsia. Jul. 2008;49(7):1115-22. [pmid: 18479395].
2098 Pasnak R, Greene MS, Ferguson EO, Levit K. Applying principles of development to help at-risk preschoolers develop numeracy. J Psychol. Mar. 2006;140(2):155-73. [pmid: 16770941].
2099 Pasnak R, MacCubbin E, Ferral-Like M. Using developmental principles to assist preschoolers in developing numeracy and literacy. Percept Mot Skills. Aug. 2007;105(1):163-76. [pmid: 17918560].
2100 Patel MX, Smith DG, Chalder T, Wessely S. Chronic fatigue syndrome in children: a cross sectional survey. Arch Dis Child. Oct. 2003;88(10):894-8. [pmid: 14500310].
2101 Patel V. Mental health in low- and middle-income countries. Br Med Bull. 2007;81-82:81-96. [pmid: 17470476].
2102 Patel V, Pednekar S, Weiss H, Rodrigues M, Barros P, Nayak B, et al. Why do women complain of vaginal discharge? A population survey of infectious and pyschosocial risk factors in a South Asian community. Int J Epidemiol. Aug. 2005;34(4):853-62. [pmid: 15833795].
2103 Pattamadilok C, Perre L, Dufau S, Ziegler JC. On-line orthographic influences on spoken language in a semantic task. J Cogn Neurosci. Jan. 2009;21(1):169-79. [pmid: 18476763].
2104 Patten CA, Croghan IT, Meis TM, Decker PA, Pingree S, Colligan RC, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. Dec. 2006;64(1-3):249-58. [pmid: 16616449].
2105 Pattillo RE, Brewer M, Smith CM. Tracking clinical use of personal digital assistant reference resources. Nurse Educ. Jan-Feb. 2007;32(1):39-42. [pmid: 17220767].
2106 Pattishall AE, Spector ND. Vitamin D deficiency, eosinophilic esophagitis, and health literacy. Curr Opin Pediatr. Dec. 2009;21(6):817-23. [pmid: 19797953].
2107 Patton DE, Duff K, Schoenberg MR, Mold J, Scott JG, Adams RL. Base rates of longitudinal RBANS discrepancies at one- and two-year intervals in community-dwelling older adults. Clin Neuropsychol. Feb. 2005;19(1):27-44. [pmid: 15814476].
2108 Paul PP, George RJ, Arvind H, Raj M, Augustian, Ramesh SV, et al. A comparison of participants and non-participants in the Chennai Glaucoma Study-rural population. Ophthalmic Epidemiol. Apr. 2005;12(2):125-35. [pmid: 16028345].
2109 Paul PV. New literacies, multiple literacies, unlimited literacies: what now, what next, where to? A response to blue listerine, parochialism and ASL literacy. J Deaf Stud Deaf Educ. Summer. 2006;11(3):382-7. [pmid: 16614376].
2110 Pavlovic J, Kaufmann F, Boltshauser E, Capone Mori A, Gubser Mercati D, Haenggeli CA, et al. Neuropsychological problems after paediatric stroke: two year follow-up of Swiss children. Neuropediatrics. Feb. 2006;37(1):13-9. [pmid: 16541363].
2111 Pawlak R. Economic considerations of health literacy. Nurs Econ. Jul-Aug. 2005;23(4):173-80. 47. [pmid: 16189982].
2112 Payne G. Re-counting ‘illiteracy’: literacy skills in the sociology of social inequality. Br J Sociol. Jun. 2006;57(2):219-40. [pmid: 16759193].
2113 Payne JG, Schulte SK. Mass media, public health, and achieving health literacy. J Health Commun. 1. 2003;8:124-5. [pmid: 14692579].
2114 Peadon E, Rhys-Jones B, Bower C, Elliott EJ. Systematic review of interventions for children with Fetal Alcohol Spectrum Disorders. BMC Pediatr. 2009;9:35. [pmid: 19463198].
2115 Pearce JM. Sir Francis Walshe, MD FRS (1885-1973). J Med Biogr. May. 2006;14(2):93-5. [pmid: 16607409].
2116 Peckover S, Chidlaw RG. The (un)-certainties of district nurses in the context of cultural diversity. J Adv Nurs. May. 2007;58(4):377-85. [pmid: 17442037].
2117 Peek ME. Screening mammography in the elderly: a review of the issues. J Am Med Womens Assoc. Summer. 2003;58(3):191-8. [pmid: 12948112].
2118 Peek ME, Han JH. Disparities in screening mammography. Current status, interventions and implications. J Gen Intern Med. Feb. 2004;19(2):184-94. [pmid: 15009798].
2119 Peereman R, Lete B, Sprenger-Charolles L. Manulex-infra: distributional characteristics of grapheme-phoneme mappings, and infralexical and lexical units in child-directed written material. Behav Res Methods. Aug. 2007;39(3):579-89. [pmid: 17958171].
2120 Pelicano N, Branco LM, Pinto A, Sa A, Timoteo AT, Feliciano J, et al. Thromboembolic and/or bleeding complications in patients under oral anticoagulation followed at a tertiary hospital. Rev Port Cardiol. Jul-Aug. 2005;24(7-8):957-68. [pmid: 16240682].
2121 Pellegrino L, Kobb R. Skill sets for the home telehealth practitioner: a recipe for success. Telemed J E Health. Apr. 2005;11(2):151-6. [pmid: 15857256].
2122 Penson RT, Dignan F, Seiden MV, Lee H, Gallagher CJ, Matulonis UA, et al. Attitudes to chemotherapy in patients with ovarian cancer. Gynecol Oncol. Aug. 2004;94(2):427-35. [pmid: 15297184].
2123 Peota C. Health literacy and patient safety. Minn Med. Apr. 2004;87(4):32-4. [pmid: 15144160].
2124 Percy KE, Karnosky DF. Air quality in natural areas: interface between the public, science and regulation. Environ Pollut. Oct. 2007;149(3):256-67. [pmid: 17628236].
2125 Peregrin T. Picture this: visual cues enhance health education messages for people with low literacy skills. J Am Diet Assoc. Apr. 2010;110(4):500-5. [pmid: 20338272].
2126 Peres K, Verret C, Alioum A, Barberger-Gateau P. The disablement process: factors associated with progression of disability and recovery in French elderly people. Disabil Rehabil. Mar. 4. 2005;27(5):263-76. [pmid: 16025753].
2127 Perre L, Ziegler JC. On-line activation of orthography in spoken word recognition. Brain Res. Jan. 10. 2008;1188:132-8. [pmid: 18062940].
2128 Perry MW, Mittelmark MB. The use of emerging technology to build health promotion capacity in regions with diversity in language and culture. Promot Educ. 2006;13(3):197-202. [pmid: 17294710].
2129 Persell SD, Osborn CY, Richard R, Skripkauskas S, Wolf MS. Limited health literacy is a barrier to medication reconciliation in ambulatory care. J Gen Intern Med. Nov. 2007;22(11):1523-6. [pmid: 17786521].
2130 Peterman TA, Lindsey CA, Selik RM. This place is killing me: a comparison of counties where the incidence rates of AIDS increased the most and the least. J Infect Dis. Feb. 1. 1. 2005;191:S123-6. [pmid: 15627222].
2131 Peters E. Numeracy and the perception and communication of risk. Ann N Y Acad Sci. Apr. 2008;1128:1-7. [pmid: 18469208].
2132 Peters E, Dieckmann N, Dixon A, Hibbard JH, Mertz CK. Less is more in presenting quality information to consumers. Med Care Res Rev. Apr. 2007;64(2):169-90. [pmid: 17406019].
2133 Peters E, Hibbard J, Slovic P, Dieckmann N. Numeracy skill and the communication, comprehension, and use of risk-benefit information. Health Aff (Millwood). May-Jun. 2007;26(3):741-8. [pmid: 17485752].
2134 Peters E, Vastfjall D, Slovic P, Mertz CK, Mazzocco K, Dickert S. Numeracy and decision making. Psychol Sci. May. 2006;17(5):407-13. [pmid: 16683928].
2135 Peterson G, Aslani P, Williams KA. How do consumers search for and appraise information on medicines on the Internet? A qualitative study using focus groups. J Med Internet Res. Dec. 19. 2003;5(4):e33. [pmid: 14713661].
2136 Peterson KJ, Van Buren K. Implementing Essentials of Critical Care Orientation: one hospital's experience with an online critical care course. Crit Care Nurs Q. Jul-Sep. 2006;29(3):218-30. [pmid: 16862023].
2137 Peterson MW, Rowat J, Kreiter C, Mandel J. Medical students' use of information resources: is the digital age dawning?. Acad Med. Jan. 2004;79(1):89-95. [pmid: 14691004].
2138 Peterson NB, Dwyer KA, Mulvaney SA, Dietrich MS, Rothman RL. The influence of health literacy on colorectal cancer screening knowledge, beliefs and behavior. J Natl Med Assoc. Oct. 2007;99(10):1105-12. [pmid: 17987913].
2139 Peterson RL, McGrath LM, Smith SD, Pennington BF. Neuropsychology and genetics of speech, language, and literacy disorders. Pediatr Clin North Am. Jun. 2007;54(3):543-61. vii. [pmid: 17543909].
2140 Petersson KM, Silva C, Castro-Caldas A, Ingvar M, Reis A. Literacy: a cultural influence on functional left-right differences in the inferior parietal cortex. Eur J Neurosci. Aug. 2007;26(3):791-9. [pmid: 17651423].
2141 Peto T, Srebnik D, Zick E, Russo J. Support needed to create psychiatric advance directives. Adm Policy Ment Health. May. 2004;31(5):409-19. [pmid: 15382320].
2142 Petrak J, Markulin H, Matic T. Information literacy in continuing professional development of medical practitioners: a Croatian example. Health Info Libr J. Mar. 2008;25(1):46-9. [pmid: 18251912].
2143 Petrini K, Dahl S, Rocchesso D, Waadeland CH, Avanzini F, Puce A, et al. Multisensory integration of drumming actions: musical expertise affects perceived audiovisual asynchrony. Exp Brain Res. Sep. 2009;198(2-3):339-52. [pmid: 19404620].
2144 Pevzner J, Kaufmann DR, Hilliman C, Shea S, Weinstock RS, Starren J. Developing computer skills and competencies in seniors. AMIA Annu Symp Proc. 2005:1078.
2145 Phaladze NA, Human S, Dlamini SB, Hulela EB, Hadebe IM, Sukati NA, et al. Quality of life and the concept of “living well” with HIV/AIDS in sub-Saharan Africa. J Nurs Scholarsh. 2005;37(2):120-6. [pmid: 15960055].
2146 Phillips C, Blakey G 3rd. Short-term recovery after orthognathic surgery: a medical daily diary approach. Int J Oral Maxillofac Surg. Oct. 2008;37(10):892-6. [pmid: 18768296].
2147 Phillips JM. Preparing preceptors through online education. J Nurses Staff Dev. May-Jun. 2006;22(3):150-6. [pmid: 16760776].
2148 Pickard AS, Lin HW, Knight SJ, Sharifi R, Wu Z, Hung SY, et al. Proxy assessment of health-related quality of life in african american and white respondents with prostate cancer: perspective matters. Med Care. Feb. 2009;47(2):176-83. [pmid: 19169118].
2149 Pieper B, Sieggreen M, Freeland B, Kulwicki P, Frattaroli M, Sidor D, et al. Discharge information needs of patients after surgery. J Wound Ostomy Continence Nurs. May-Jun. 2006;33(3):281-9. quiz 90-1. [pmid: 16717518].
2150 Pieper B, Sieggreen M, Nordstrom CK, Freeland B, Kulwicki P, Frattaroli M, et al. Discharge knowledge and concerns of patients going home with a wound. J Wound Ostomy Continence Nurs. May-Jun. 2007;34(3):245-53. quiz 54-5. [pmid: 17505242].
2151 Pierce RU, Steinle VA, Stacey KC, Widjaja W. Understanding decimal numbers: a foundation for correct calculations. Int J Nurs Educ Scholarsh. 2008:5. Article7.
2152 Pierce S. Faculty matters. Susan Pierce Nurs Educ Perspect. Sep-Oct. 2005;26(5):266-7.
2153 Pietrobon R, Shah A, Kuo P, Harker M, McCready M, Butler C, et al. Duke Surgery Research Central: an open-source Web application for the improvement of compliance with research regulation. BMC Med Inform Decis Mak. 2006;6:32. [pmid: 16872540].
2154 Pignone M, DeWalt DA, Sheridan S, Berkman N, Lohr KN. Interventions to improve health outcomes for patients with low literacy. A systematic review. J Gen Intern Med. Feb. 2005;20(2):185-92. [pmid: 15836553].
2155 Pin S, Guilley E, Spini D, Lalive d'Epinay C. The impact of social relationships on the maintenance of independence in advanced old age: findings of a Swiss longitudinal study. Z Gerontol Geriatr. Jun. 2005;38(3):203-9. [pmid: 15965795].
2156 Pinfold V, Byrne P, Toulmin H. Challenging stigma and discrimination in communities: a focus group study identifying UK mental health service users' main campaign priorities. Int J Soc Psychiatry. Jun. 2005;51(2):128-38. [pmid: 16048242].
2157 Pinfold V, Toulmin H, Thornicroft G, Huxley P, Farmer P, Graham T. Reducing psychiatric stigma and discrimination: evaluation of educational interventions in UK secondary schools. Br J Psychiatry. Apr. 2003;182:342-6. [pmid: 12668411].
2158 Pinkleton BE, Austin EW, Cohen M, Chen YC, Fitzgerald E. Effects of a peer-led media literacy curriculum on adolescents' knowledge and attitudes toward sexual behavior and media portrayals of sex. Health Commun. Sep. 2008;23(5):462-72. [pmid: 18850393].
2159 Pinkleton BE, Weintraub Austin E, Cohen M, Miller A, Fitzgerald E. A statewide evaluation of the effectiveness of media literacy training to prevent tobacco use among adolescents. Health Commun. 2007;21(1):23-34. [pmid: 17461749].
2160 Pinton F, Ducot B, Motte J, Arbues AS, Barondiot C, Barthez MA, et al. Cognitive functions in children with benign childhood epilepsy with centrotemporal spikes (BECTS). Epileptic Disord. Mar. 2006;8(1):11-23. [pmid: 16567321].
2161 Pleasant A, Kuruvilla S. A tale of two health literacies: public health and clinical approaches to health literacy. Health Promot Int. Jun. 2008;23(2):152-9. [pmid: 18223203].
2162 Pluhar E, McDonnell Holstad M, Yeager KA, Denzmore-Nwagbara P, Corkran C, Fielder B, et al. Implementation of audio computer-assisted interviewing software in HIV/AIDS research. J Assoc Nurses AIDS Care. Jul-Aug. 2007;18(4):51-63. [pmid: 17662924].
2163 Pocock N. Bringing dental literacy to the classroom. Todays FD A. Feb. 2009;21(2):32-3. 5.
2164 Poduval RD, Wolgemuth C, Ferrell J, Hammes MS. Hyperphosphatemia in dialysis patients: is there a role for focused counseling?. J Ren Nutr. Jul. 2003;13(3):219-23. [pmid: 12874747].
2165 Pointer D, Stillman D. The essentials of good governance. Financial literacy, organizational skills and access to the right data are critical. Mod Healthc. Nov. 15. 2004;34(46):24. [pmid: 15609732].
2166 Pokhrel AK, Smith KR, Khalakdina A, Deuja A, Bates MN. Case-control study of indoor cooking smoke exposure and cataract in Nepal and India. Int J Epidemiol. Jun. 2005;34(3):702-8. [pmid: 15737974].
2167 Pokhrel D, Viraraghavan T. Diarrhoeal diseases in Nepal vis-a-vis water supply and sanitation status. J Water Health. Jun. 2004;2(2):71-81. [pmid: 15387131].
2168 Polacek GN, Ramos MC, Ferrer RL. Breast cancer disparities and decision-making among U.S. women. Patient Educ Couns. Feb. 2007;65(2):158-65. [pmid: 16870385].
2169 Polivka BJ, Gottesman MM. Parental perceptions of barriers to blood lead testing. J Pediatr Health Care. Sep-Oct. 2005;19(5):276-84. [pmid: 16202835].
2170 Pollitt E, Gorman KS, Engle PL, Martorell R, Rivera J. Early supplementary feeding and cognition: effects over two decades. Monogr Soc Res Child Dev. 1993;58(7):1-99. discussion 111-8. [pmid: 8272081].
2171 Pollitt E, Gorman KS, Engle PL, Rivera JA, Martorell R. Nutrition in early life and the fulfillment of intellectual potential. J Nutr. Apr. 1995;125(4 Suppl):1111S-8S. [pmid: 7536831].
2172 Pollock JB, Jaffery JB. Knowledge of phosphorus compared with other nutrients in maintenance dialysis patients. J Ren Nutr. Sep. 2007;17(5):323-8. [pmid: 17720101].
2173 Polonsky WH, Fisher L, Earles J, Dudl RJ, Lees J, Mullan J, et al. Assessing psychosocial distress in diabetes: development of the diabetes distress scale. Diabetes Care. Mar. 2005;28(3):626-31. [pmid: 15735199].
2174 Popernack ML. A critical change in a day in the life of intensive care nurses: rising to the e-challenge of an integrated clinical information system. Crit Care Nurs Q. Oct-Dec. 2006;29(4):362-75. [pmid: 17063103].
2175 Porr C, Drummond J, Richter S. Health literacy as an empowerment tool for low-income mothers. Fam Community Health. Oct-Dec. 2006;29(4):328-35. [pmid: 16980808].
2176 Posner MI, Rothbart MK. Influencing brain networks: implications for education. Trends Cogn Sci. Mar. 2005;9(3):99-103. [pmid: 15737817].
2177 Potocky-Tripodi M, Dodge K, Greene M. Bridging cultural chasms between providers and HIV-positive Haitians in Palm Beach County, Florida. J Health Care Poor Underserved. Aug. 2007;18(3 Suppl):105-17. [pmid: 17938469].
2178 Poureslami IM, Rootman I, Balka E, Devarakonda R, Hatch J, Fitzgerald JM. A systematic review of asthma and health literacy: a cultural-ethnic perspective in Canada. MedGenMed. 2007;9(3):40. [pmid: 18092046].
2179 Powell CA, Case-Smith J. Information literacy skills of occupational therapy graduates: a survey of learning outcomes. J Med Libr Assoc. Oct. 2003;91(4):468-77. [pmid: 14566378].
2180 Powell CK, Hill EG, Clancy DE. The relationship between health literacy and diabetes knowledge and readiness to take health actions. Diabetes Educ. Jan-Feb. 2007;33(1):144-51. [pmid: 17272800].
2181 Powell CK, Kripalani S. Brief report: Resident recognition of low literacy as a risk factor in hospital readmission. J Gen Intern Med. Nov. 2005;20(11):1042-4. [pmid: 16307631].
2182 Powell M. Health literacy: implications for ambulatory care. Nurs Econ. Sep-Oct. 2009;27(5):343-7. [pmid: 19927453].
2183 Powers BJ, Olsen MK, Oddone EZ, Thorpe CT, Bosworth HB. Literacy and blood pressure--do healthcare systems influence this relationship? A cross-sectional study. BMC Health Serv Res. 2008;8:219. [pmid: 18947408].
2184 Prabhakar KS. Cadaveric & living organ donation. Natural limitations. Possible solutions. Singapore experience. Ann Transplant. 2004;9(1):31-3. [pmid: 15478886].
2185 Praska JL, Kripalani S, Seright AL, Jacobson TA. Identifying and assisting low-literacy patients with medication use: a survey of community pharmacies. Ann Pharmacother. Sep. 2005;39(9):1441-5. [pmid: 16046489].
2186 Pravikoff DS. Mission critical: a culture of evidence-based practice and information literacy. Nurs Outlook. Jul-Aug. 2006;54(4):254-5. [pmid: 16929570].
2187 Pravikoff DS, Tanner AB, Pierce ST. Readiness of U.S. nurses for evidence-based practice. Am J Nurs. Sep. 2005;105(9):40-51. quiz 2. [pmid: 16138038].
2188 Prencipe M, Santini M, Casini AR, Pezzella FR, Scaldaferri N, Culasso F. Prevalence of non-dementing cognitive disturbances and their association with vascular risk factors in an elderly population. J Neurol. Aug. 2003;250(8):907-12. [pmid: 12928907].
2189 Prepas SB. Light, literacy and the absence of ultraviolet radiation in the development of myopia. Med Hypotheses. 2008;70(3):635-7. [pmid: 17804172].
2190 Pressley M, Graham S, Harris K. The state of educational intervention research as viewed through the lens of literacy intervention. Br J Educ Psychol. Mar. 2006;76(Pt 1):1-19. [pmid: 16573976].
2191 Preston AS, Heaton SC, McCann SJ, Watson WD, Selke G. The role of multidimensional attentional abilities in academic skills of children with ADHD. J Learn Disabil. May-Jun. 2009;42(3):240-9. [pmid: 19264927].
2192 Priest SH, Bonfadelli H, Rusanen M. The “trust gap” hypothesis: predicting support for biotechnology across national cultures as a function of trust in actors. Risk Anal. Aug. 2003;23(4):751-66. [pmid: 12926568].
2193 Primack BA, Bui T, Fertman CI. Social marketing meets health literacy: Innovative improvement of health care providers' comfort with patient interaction. Patient Educ Couns. Sep. 2007;68(1):3-9. [pmid: 17418522].
2194 Primack BA, Gold MA, Land SR, Fine MJ. Association of cigarette smoking and media literacy about smoking among adolescents. J Adolesc Health. Oct. 2006;39(4):465-72. [pmid: 16982379].
2195 Primack BA, Gold MA, Switzer GE, Hobbs R, Land SR, Fine MJ. Development and validation of a smoking media literacy scale for adolescents. Arch Pediatr Adolesc Med. Apr. 2006;160(4):369-74. [pmid: 16585481].
2196 Primack BA, Hobbs R. Association of various components of media literacy and adolescent smoking. Am J Health Behav. Mar-Apr. 2009;33(2):192-201. [pmid: 18844513].
2197 Prior M, Smart D, Sanson A, Oberklaid F. Relationships between learning difficulties and psychological problems in preadolescent children from a longitudinal sample. J Am Acad Child Adolesc Psychiatry. Apr. 1999;38(4):429-36. [pmid: 10199115].
2198 Pritchard VE, Clark CA, Liberty K, Champion PR, Wilson K, Woodward LJ. Early school-based learning difficulties in children born very preterm. Early Hum Dev. Apr. 2009;85(4):215-24. [pmid: 19022593].
2199 Probst YC, Tapsell LC. Overview of computerized dietary assessment programs for research and practice in nutrition education. J Nutr Educ Behav. Jan-Feb. 2005;37(1):20-6. [pmid: 15745652].
2200 Prosser LA, Corso PS. Measuring health-related quality of life for child maltreatment: a systematic literature review. Health Qual Life Outcomes. 2007;5:42. [pmid: 17634122].
2201 Pullen DL. An evaluative case study of online learning for healthcare professionals. J Contin Educ Nurs. Sep-Oct. 2006;37(5):225-32. [pmid: 17004396].
2202 Pulsifer MB, Radonovich K, Belcher HM, Butz AM. Intelligence and school readiness in preschool children with prenatal drug exposure. Child Neuropsychol. Jun. 2004;10(2):89-101. [pmid: 15590488].
2203 Qiu Y, Yu P, Hyland P. A multi-method approach to assessing health information systems end users' training needs. Stud Health Technol Inform. 2007;129(Pt 2):1352-6. [pmid: 17911934].
2204 Qualls CD, Lantz JM, Pietrzyk RM, Blood GW, Hammer CS. Comprehension of idioms in adolescents with language-based learning disabilities compared to their typically developing peers. J Commun Disord. Jul-Aug. 2004;37(4):295-311. [pmid: 15159191].
2205 Quandt SA, Chen H, Bell RA, Anderson AM, Savoca MR, Kohrman T, et al. Disparities in oral health status between older adults in a multiethnic rural community: the rural nutrition and oral health study. J Am Geriatr Soc. Aug. 2009;57(8):1369-75. [pmid: 19563519].
2206 Quisumbing AR, Behrman JR, Maluccio JA, Murphy A, Yount KM. Levels, correlates, and differences in human, physical, and financial assets brought into marriages by young Guatemalan adults. Food Nutr Bull. Jun. 2005;26(2 Suppl 1):S55-67. [pmid: 16060212].
2207 Rabiei K, Kelishadi R, Sarrafzadegan N, Abedi HA, Alavi M, Heidari K, et al. Process evaluation of a community-based program for prevention and control of non-communicable disease in a developing country: The Isfahan Healthy Heart Program, Iran. BMC Public Health. 2009;9:57. [pmid: 19216762].
2208 Rabino I. Genetic testing and its implications: human genetics researchers grapple with ethical issues. Sci Technol Human Values. Spring. 2003;28(2):365-402.
2209 Rachon D, Pokrywka L, Suchecka-Rachon K. Prevalence and risk factors of anabolic-androgenic steroids (AAS) abuse among adolescents and young adults in Poland. Soz Praventivmed. 2006;51(6):392-8. [pmid: 17658145].
2210 Rack JP, Snowling MJ, Hulme C, Gibbs S. No evidence that an exercise-based treatment programme (DDAT) has specific benefits for children with reading difficulties. Dyslexia. May. 2007;13(2):97-104. discussion 5-9. [pmid: 17557686].
2211 Raehl CL, Bond CA, Woods TJ, Patry RA, Sleeper RB. Screening tests for intended medication adherence among the elderly. Ann Pharmacother. May. 2006;40(5):888-93. [pmid: 16595567].
2212 Ragneskog H, Gerdner L. Competence in nursing informatics among nursing students and staff at a nursing institute in Sweden. Health Info Libr J. Jun. 2006;23(2):126-32. [pmid: 16706868].
2213 Rahim MA, Vaaler S, Keramat Ali SM, Khan AK, Hussain A, Nahar Q. Prevalence of type 2 diabetes in urban slums of Dhaka, Bangladesh. Bangladesh Med Res Counc Bull. Aug. 2004;30(2):60-70. [pmid: 15813484].
2214 Rahman A, Giashuddin SM, Svanstrom L, Rahman F. Drowning--a major but neglected child health problem in rural Bangladesh: implications for low income countries. Int J Inj Contr Saf Promot. Jun. 2006;13(2):101-5. [pmid: 16707346].
2215 Rahman M, Banerjee M, Rahman M, Akhter FU. Vaccination status of tribal mothers and their under five children. Mymensingh Med J. Jan. 2006;15(1):55-7. [pmid: 16467764].
2216 Raitano NA, Pennington BF, Tunick RA, Boada R, Shriberg LD. Pre-literacy skills of subgroups of children with speech sound disorders. J Child Psychol Psychiatry. May. 2004;45(4):821-35. [pmid: 15056313].
2217 Rajab LD, Baqain ZH. Use of information and communication technology among dental students at the University of Jordan. J Dent Educ. Mar. 2005;69(3):387-98. [pmid: 15749951].
2218 Ramos E, Lopes C, Oliveira A, Barros H. Unawareness of weight and height--the effect on self-reported prevalence of overweight in a population-based study. J Nutr Health Aging. Apr. 2009;13(4):310-4. [pmid: 19300865].
2219 Ramsbottom R, Kinch RF, Morris MG, Dennis AM. Practical application of fundamental concepts in exercise physiology. Adv Physiol Educ. Dec. 2007;31(4):347-51. [pmid: 18057408].
2220 Ramus F, Rosen S, Dakin SC, Day BL, Castellote JM, White S, et al. Theories of developmental dyslexia: insights from a multiple case study of dyslexic adults. Brain. Apr. 2003;126(Pt 4):841-65. [pmid: 12615643].
2221 Rana AK, Wahlin A, Lundborg CS, Kabir ZN. Impact of health education on health-related quality of life among elderly persons: results from a community-based intervention study in rural Bangladesh. Health Promot Int. Mar. 2009;24(1):36-45. [pmid: 19136677].
2222 Rangachari PK, Rangachari U. Information literacy in an inquiry course for first-year science undergraduates: a simplified 3C approach. Adv Physiol Educ. Jun. 2007;31(2):176-9. [pmid: 17562907].
2223 Rao D, Hahn EA, Cella D, Hernandez L. The health related quality of life outcomes of English and Spanish speaking persons living with HIV/AIDS from the continental United States and Puerto Rico. AIDS Patient Care STDS. May. 2007;21(5):339-46. [pmid: 17518526].
2224 Rao G. Physician numeracy: essential skills for practicing evidence-based medicine. Fam Med. May. 2008;40(5):354-8. [pmid: 18465286].
2225 Rashid FL, Morris RD, Sevcik RA. Relationship between home literacy environment and reading achievement in children with reading disabilities. J Learn Disabil. Jan-Feb. 2005;38(1):2-11. [pmid: 15727325].
2226 Rathbun A, Thornton LA, Fox JE. Are our investments paying off?: a study of reading level and bereavement materials. Am J Hosp Palliat Care. Aug-Sep. 2008;25(4):278-81. [pmid: 18463410].
2227 Rathore M, Vyas L, Bhardwaj AK. Prevalence of reproductive tract infections amongst ever married women and sociocultural factors associated with it. J Indian Med Assoc. Feb. 2007;105(2):71-2. 4. 8. [pmid: 17822170].
2228 Ratzan SC, Parker RM. National library of medicine current bibliographies in medicine: health literacy. Selden CR, Zorn M, Ratzan SC, Parker RM, Bethesda M, editors. National Institutes of Health, U.S. Department of Health and Human Services. 2000.
2229 Rawi M. Betrayal. Reprod Health Matters. May. 2004;12(23):116-9. [pmid: 15242217].
2230 Rawl R, Kolasa KM, Lee J, Whetstone LM. A learn and serve nutrition program: the Food Literacy Partners Program. J Nutr Educ Behav. Jan-Feb. 2008;40(1):49-51. [pmid: 18174105].
2231 Rayamajhi R, Thapa M, Pande S. The challenge of grandmultiparity in obstetric practice. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2006;4(1):70-4. [pmid: 18603872].
2232 Rayford W. Managing the low-socioeconomic-status prostate cancer patient. J Natl Med Assoc. Apr. 2006;98(4):521-30. [pmid: 16623064].
2233 Reach G, Zerrouki A, Leclercq D, d'Ivernois JF. Adjusting insulin doses: from knowledge to decision. Patient Educ Couns. Jan. 2005;56(1):98-103. [pmid: 15590229].
2234 Read C, Bateson D, Weisberg E, Estoesta J. Contraception and pregnancy then and now: examining the experiences of a cohort of mid-age Australian women. Aust N Z J Obstet Gynaecol. Aug. 2009;49(4):429-33. [pmid: 19694702].
2235 Redpath DP, Reynolds GL, Jaffe A, Fisher DG, Edwards JW, Deaugustine N. Internet access and use among homeless and indigent drug users in Long Beach, California. Cyberpsychol Behav. Oct. 2006;9(5):548-51. [pmid: 17034321].
2236 Reed HC. Promoting health literacy with orofacial myofunctional patients. Int J Orofacial Myology. Nov. 2007;33:31-6. [pmid: 18942479].
2237 Reed S. Beliefs and practices of itinerant teachers of deaf and hard of hearing children concerning literacy development. Am Ann Deaf. Fall. 2003;148(4):333-43. [pmid: 14992041].
2238 Reed VA, Brammall H. Methodological adaptations for investigating the perceptions of language-impaired adolescents regarding the relative importance of selected communication skills. Clin Linguist Phon. Sep-Oct. 2006;20(7-8):573-82. [pmid: 17056488].
2239 Reeves CB, Palmer SL, Reddick WE, Merchant TE, Buchanan GM, Gajjar A, et al. Attention and memory functioning among pediatric patients with medulloblastoma. J Pediatr Psychol. Apr. 2006;31(3):272-80. [pmid: 15788715].
2240 Reeves K. Health literacy: the newest vital sign. Medsurg Nurs. Oct. 2008;17(5):288. 96. [pmid: 19051972].
2241 Regassa K, Teshome T. Trachoma among adults in Damot Gale District, South Ethiopia. Ophthalmic Epidemiol. Feb. 2004;11(1):9-16. [pmid: 14977493].
2242 Register D. The effects of live music groups versus an educational children's television program on the emergent literacy of young children. J Music Ther. Spring. 2004;41(1):2-27. [pmid: 15157126].
2243 Regtvoort AG, van Leeuwen TH, Stoel RD, van der Leij A. Efficiency of visual information processing in children at-risk for dyslexia: habituation of single-trial ERPs. Brain Lang. Sep. 2006;98(3):319-31. [pmid: 16870246].
2244 Reid AA, Szczerbinski M, Iskierka-Kasperek E, Hansen P. Cognitive profiles of adult developmental dyslexics: theoretical implications. Dyslexia. Feb. 2007;13(1):1-24. [pmid: 17330733].
2245 Reid J, Robb E, Stone D, Bowen P, Baker R, Irving S, et al. Improving the monitoring and assessment of fluid balance. Nurs Times. May. 18. 2004;100(20):36-9. [pmid: 15176276].
2246 Reijneveld SA, Vogels AG, Brugman E, van Ede J, Verhulst FC, Verloove-Vanhorick SP. Early detection of psychosocial problems in adolescents: how useful is the Dutch short indicative questionnaire (KIVPA)?. Eur J Public Health. Jun. 2003;13(2):152-9. [pmid: 12803414].
2247 Reis A, Faisca L, Ingvar M, Petersson KM. Color makes a difference: two-dimensional object naming in literate and illiterate subjects. Brain Cogn. Feb. 2006;60(1):49-54. [pmid: 16271820].
2248 Reis A, Faisca L, Mendonca S, Ingvar M, Petersson KM. Semantic interference on a phonological task in illiterate subjects. Scand J Psychol. Feb. 2007;48(1):69-74. [pmid: 17257371].
2249 Reis A, Guerreiro M, Petersson KM. A sociodemographic and neuropsychological characterization of an illiterate population. Appl Neuropsychol. 2003;10(4):191-204. [pmid: 14690800].
2250 Reis A, Petersson KM. Educational level, socioeconomic status and aphasia research: a comment on Connor et al. (2001)--effect of socioeconomic status on aphasia severity and recovery. Brain Lang. Dec. 2003;87(3):449-52. [pmid: 14642547].
2251 Reisfield GM, Wilson GR. Health literacy in palliative medicine #153. J Palliat Med. Jan-Feb. 2008;11(1):105-6. [pmid: 18370900].
2252 Renahy E, Chauvin P. Internet uses for health information seeking: A literature review. Rev Epidemiol Sante Publique. Jun. 2006;54(3):263-75. [pmid: 16902386].
2253 Renahy E, Parizot I, Chauvin P. WHIST: a web-based survey on health information seeking on Internet in France, 2007. AMIA Annu Symp Proc. 2007:1090-1.
2254 Renahy E, Parizot I, Chauvin P. Health information seeking on the Internet: a double divide? Results from a representative survey in the Paris metropolitan area, France, 2005-2006. BMC Public Health. 2008;8:69. [pmid: 18291024].
2255 Renwick S. Knowledge and use of electronic information resources by medical sciences faculty at The University of the West Indies. J Med Libr Assoc. Jan. 2005;93(1):21-31. [pmid: 15685270].
2256 Repique RJ. Computers and information technologies in psychiatric nursing. Perspect Psychiatr Care. Apr. 2007;43(2):77-83. [pmid: 17388850].
2257 Resnik DB, Roman G. Health, justice, and the environment. Bioethics. May. 2007;21(4):230-41. [pmid: 17845481].
2258 Restrepo MA, Gray S. Optimizing literacy in English language learners. Semin Speech Lang. Feb. 2007;28(1):25-34. [pmid: 17340380].
2259 Reyes-Ortiz CA, Camacho ME, Amador LF, Velez LF, Ottenbacher KJ, Markides KS. The impact of education and literacy levels on cancer screening among older Latin American and Caribbean adults. Cancer Control. Oct. 2007;14(4):388-95. [pmid: 17914339].
2260 Reynolds AJ, Ou SR, Topitzes JW. Paths of effects of early childhood intervention on educational attainment and delinquency: a confirmatory analysis of the Chicago Child-Parent Centers. Child Dev. Sep-Oct. 2004;75(5):1299-328. [pmid: 15369516].
2261 Reynolds D, Nicolson RI. Follow-up of an exercise-based treatment for children with reading difficulties. Dyslexia. May. 2007;13(2):78-96. [pmid: 17557685].
2262 Rhee M, Sissoko M, Perry S, Dicko A, McFarland W, Doumbo O. Malaria prevention practices in Mopti region, Mali. East Afr Med J. Aug. 2005;82(8):396-402. [pmid: 16261915].
2263 Ribeiro LH, Jennings F, Jones A, Furtado R, Natour J. Effectiveness of a back school program in low back pain. Clin Exp Rheumatol. Jan-Feb. 2008;26(1):81-8. [pmid: 18328151].
2264 Richards-Kortum R, Buckley D, Schwarz RA, Atkinson EN, Follen M. A translational bioengineering course provides substantial gains in civic scientific literacy. Ann Biomed Eng. Aug. 2007;35(8):1324-32. [pmid: 17458698].
2265 Richman JA, Lee JY, Rozier RG, Gong DA, Pahel BT, Vann WF Jr. Evaluation of a word recognition instrument to test health literacy in dentistry: the REALD-99. J Public Health Dent. Spring. 2007;67(2):99-104. [pmid: 17557681].
2266 Rickard CM. Statistics for clinical nursing practice: an introduction. Aust Crit Care. Nov. 2008;21(4):216-9. [pmid: 18926715].
2267 Ridolfi DR, Vander Wal JS. Eating disorders awareness week: the effectiveness of a one-time body image dissatisfaction prevention session. Eat Disord. Oct-Dec. 2008;16(5):428-43. [pmid: 18821366].
2268 Riegel B, Moser DK, Powell M, Rector TS, Havranek EP. Nonpharmacologic care by heart failure experts. J Card Fail. Mar. 2006;12(2):149-53. [pmid: 16520265].
2269 Rigby M. Improving governance and reducing risk in electronic patient record systems: ensuring appropriate competencies for support and end-user staff. Stud Health Technol Inform. 2004;107(Pt 2):926-30. [pmid: 15360948].
2270 Rigby M. Protecting the patient by promoting end-user competence in health informatics systems-moves towards a generic health computer user “driving license”. Int J Med Inform. Mar. 18. 2004;73(2):151-6. [pmid: 15063374].
2271 Rigby MJ, Hulm C, Detmer D, Buccoliero L. Enabling the safe and effective implementation of health informatics systems--validating rolling out the ECDL/ICDL health supplement. Stud Health Technol Inform. 2007;129(Pt 2):1347-51. [pmid: 17911933].
2272 Riley C, DuPaul GJ, Pipan M, Kern L, Van Brakle J, Blum NJ. Combined type versus ADHD predominantly hyperactive-impulsive type: is there a difference in functional impairment?. J Dev Behav Pediatr. Aug. 2008;29(4):270-5. [pmid: 18454040].
2273 Riley J, Cloonan P, Rogan E. Improving student understanding of health literacy through experiential learning. J Health Adm Educ. Summer. 2008;25(3):213-28. [pmid: 19655629].
2274 Riley JB, Cloonan P, Norton C. Low health literacy: a challenge to critical care. Crit Care Nurs Q. Apr-Jun. 2006;29(2):174-8. [pmid: 16641654].
2275 Rischewski D, Kuper H, Atijosan O, Simms V, Jofret-Bonet M, Foster A, et al. Poverty and musculoskeletal impairment in Rwanda. Trans R Soc Trop Med Hyg. Jun. 2008;102(6):608-17. [pmid: 18430444].
2276 Risser J, Jacobson TA, Kripalani S. Development and psychometric evaluation of the Self-efficacy for Appropriate Medication Use Scale (SEAMS) in low-literacy patients with chronic disease. J Nurs Meas. 2007;15(3):203-19. [pmid: 18232619].
2277 Rizvi SA, Naqvi SA, Hashmi A, Akhtar F, Hussain M, Ahmed E, et al. Improving kidney and live donation rates in Asia: living donation. Transplant Proc. Sep. 2004;36(7):1894-5. [pmid: 15518688].
2278 Rizvi SA, Naqvi SA, Hussain Z, Hashmi A, Akhtar F, Hussain M, et al. Renal transplantation in developing countries. Kidney Int Suppl. Feb. 2003;(83):S96-100. [pmid: 12864884].
2279 Roach P, Marrero D. A critical dialogue: communicating with type 2 diabetes patients about cardiovascular risk. Vasc Health Risk Manag. 2005;1(4):301-7. [pmid: 17315602].
2280 Roberfroid D, Pelto GH, Kolsteren P. Plot and see! Maternal comprehension of growth charts worldwide. Trop Med Int Health. Sep. 2007;12(9):1074-86. [pmid: 17875018].
2281 Roberts J, Jurgens J, Burchinal M. The role of home literacy practices in preschool children's language and emergent literacy skills. J Speech Lang Hear Res. Apr. 2005;48(2):345-59. [pmid: 15989397].
2282 Roberts NJ, Ghiassi R, Partridge MR. Health literacy in COPD. Int J Chron Obstruct Pulmon Dis. 2008;3(4):499-507. [pmid: 19281068].
2283 Roberts NJ, Mohamed Z, Wong PS, Johnson M, Loh LC, Partridge MR. The development and comprehensibility of a pictorial asthma action plan. Patient Educ Couns. Jan. 2009;74(1):12-8. [pmid: 18789626].
2284 Robertson CL, Halcon L, Savik K, Johnson D, Spring M, Butcher J, et al. Somali and Oromo refugee women: trauma and associated factors. J Adv Nurs. Dec. 2006;56(6):577-87. [pmid: 17118037].
2285 Robinson L, Hilger-Ellis J, Osborne L, Rowlands J, Smith JM, Weist A, et al. Healthcare librarians and learner support: a review of competences and methods. Health Info Libr J. Dec. 2. 2005;22:42-50. [pmid: 16279975].
2286 Robinson LD Jr, Calmes DP, Bazargan M. The impact of literacy enhancement on asthma-related outcomes among underserved children. J Natl Med Assoc. Aug. 2008;100(8):892-6. [pmid: 18717138].
2287 Robinson S, Lawson S. Evaluating the impact of Information Skills Training within primary care. Health Info Libr J. Mar. 2005;22(1):63-5. [pmid: 15810933].
2288 Robinson T. Living with severe hypoxic COPD: the patients' experience. Nurs Times. Feb. 15-21. 2005;101(7):38-42. [pmid: 15759524].
2289 Robles J, Karnas J. The electronic medical record: shifting the paradigm. A conversation with Jane Robles and Joan Karnas. Interview by Beth Beaty. Creat Nurs. 2007;13(2):7-9. [pmid: 18232582].
2290 Rochelle KS, Talcott JB. Impaired balance in developmental dyslexia? A meta-analysis of the contending evidence. J Child Psychol Psychiatry. Nov. 2006;47(11):1159-66. [pmid: 17076755].
2291 Rochelle KS, Witton C, Talcott JB. Symptoms of hyperactivity and inattention can mediate deficits of postural stability in developmental dyslexia. Exp Brain Res. Feb. 2009;192(4):627-33. [pmid: 18830588].
2292 Rock M, Lail P. Could pets be of help in achieving health literacy? A media analysis demonstration study. Health Educ Res. Feb. 2009;24(1):153-61. [pmid: 18359950].
2293 Rodger S, Ziviani J, Watter P, Ozanne A, Woodyatt G, Springfield E. Motor and functional skills of children with developmental coordination disorder: a pilot investigation of measurement issues. Hum Mov Sci. Nov. 2003;22(4-5):461-78. [pmid: 14624828].
2294 Rodrigues MA, Facchini LA, Piccini RX, Tomasi E, Thume E, Silveira DS, et al. Use of primary care services by elderly people with chronic conditions, Brazil. Rev Saude Publica. Aug. 2009;43(4):604-12. [pmid: 19503974].
2295 Roehrig AD, Petscher Y, Nettles SM, Hudson RF, Torgesen JK. Accuracy of the DIBELS oral reading fluency measure for predicting third grade reading comprehension outcomes. J Sch Psychol. Jun. 2008;46(3):343-66. [pmid: 19083363].
2296 Rogers ES, Wallace LS, Weiss BD. Misperceptions of medical understanding in low-literacy patients: implications for cancer prevention. Cancer Control. Jul. 2006;13(3):225-9. [pmid: 16885919].
2297 Rohit M, Levine A, Hinkin C, Abramyan S, Saxton E, Valdes-Sueiras M, et al. Education correction using years in school or reading grade-level equivalent? Comparing the accuracy of two methods in diagnosing HIV-associated neurocognitive impairment?. J Int Neuropsychol Soc. May. 2007;13(3):462-70. [pmid: 17445295].
2298 Rohlman DS, Gimenes LS, Eckerman DA, Kang SK, Farahat FM, Anger WK. Development of the Behavioral Assessment and Research System (BARS) to detect and characterize neurotoxicity in humans. Neurotoxicology. Aug. 2003;24(4-5):523-31. [pmid: 12900065].
2299 Roizen M, Rodriguez S, Bauer G, Medin G, Bevilacqua S, Varni JW, et al. Initial validation of the Argentinean Spanish version of the PedsQL 4.0 Generic Core Scales in children and adolescents with chronic diseases: acceptability and comprehensibility in low-income settings. Health Qual Life Outcomes. 2008;6:59. [pmid: 18687134].
2300 Rollins G. Study is first to tie low health literacy with poor diabetes outcomes. Rep Med Guidel Outcomes Res. Aug. 23. 2002;13(16):1-2. 5.
2301 Romani C, Di Betta AM, Tsouknida E, Olson A. Lexical and nonlexical processing in developmental dyslexia: a case for different resources and different impairments. Cogn Neuropsychol. Sep. 2008;25(6):798-830. [pmid: 18781498].
2302 Romanov K, Aarnio M. A survey of the use of electronic scientific information resources among medical and dental students. BMC Med Educ. 2006;6:28. [pmid: 16684347].
2303 Ronnemaa E, Zethelius B, Sundelof J, Sundstrom J, Degerman-Gunnarsson M, Berne C, et al. Impaired insulin secretion increases the risk of Alzheimer disease. Neurology. Sep. 30. 2008;71(14):1065-71. [pmid: 18401020].
2304 Rootman I. Health promotion and literacy: implications for nursing. Can J Nurs Res. Mar. 2004;36(1):13-21. [pmid: 15133916].
2305 Rootman I. Health literacy: where are the Canadian doctors?. CMAJ. Sep. 12. 2006;175(6):606. [pmid: 16966665].
2306 Rootman I, Edwards P. As the ship sails forth. Can J Public Health. May-Jun. 2. 2006;97:S43-6. [pmid: 16805161].
2307 Rootman I, El-Bihbety DG. Staying the course: the Captain's Log continues. Can J Public Health. May-Jun. 2. 2006;97:S5-9. [pmid: 16805153].
2308 Rootman I, Ronson B. Literacy and health research in Canada: where have we been and where should we go?. Can J Public Health. Mar-Apr. 2. 2005;96:S62-77. [pmid: 16078556].
2309 Rosal MC, Carbone ET, Goins KV. Use of cognitive interviewing to adapt measurement instruments for low-literate Hispanics. Diabetes Educ. Nov-Dec. 2003;29(6):1006-17. [pmid: 14692374].
2310 Rosal MC, Goins KV, Carbone ET, Cortes DE. Views and preferences of low-literate Hispanics regarding diabetes education: results of formative research. Health Educ Behav. Jun. 2004;31(3):388-405. [pmid: 15155047].
2311 Roseman M, Kurzynske J. Food safety perceptions and behaviors of Kentucky consumers. J Food Prot. Jun. 2006;69(6):1412-21. [pmid: 16786865].
2312 Rosen H, Saleh F, Lipsitz S, Rogers SO Jr, Gawande AA. Downwardly mobile: the accidental cost of being uninsured. Arch Surg. Nov. 2009;144(11):1006-11. [pmid: 19917936].
2313 Rosen H, Saleh F, Lipsitz SR, Meara JG, Rogers SO Jr. Lack of insurance negatively affects trauma mortality in US children. J Pediatr Surg. Oct. 2009;44(10):1952-7. [pmid: 19853754].
2314 Rosen L, Manor O, Engelhard D, Zucker D. Design of the Jerusalem Handwashing Study: meeting the challenges of a preschool-based public health intervention trial. Clin Trials. 2006;3(4):376-84. [pmid: 17060212].
2315 Rosenthal MS, Socolar RR, DeWalt DA, Pignone M, Garrett J, Margolis PA. Parents with low literacy report higher quality of parent-provider relationships in a residency clinic. Ambul Pediatr. Jan-Feb. 2007;7(1):51-5. [pmid: 17261483].
2316 Rosenthal MS, Werner MJ, Dubin NH. The effect of a literacy training program on family medicine residents. Fam Med. Sep. 2004;36(8):582-7. [pmid: 15343420].
2317 Ross CJ, Williams BA, Low G, Vethanayagam D. Perceptions about self-management among people with severe asthma. J Asthma. Apr. 2010;47(3):330-6. [pmid: 20394519].
2318 Ross J. Health literacy and its influence on patient safety. J Perianesth Nurs. Jun. 2007;22(3):220-2. [pmid: 17543808].
2319 Ross MK, Ibbetson RJ. Educational needs and employment status of Scottish dental technicians. Br Dent J. Jul. 23. 2005;199(2):97-101. [pmid: 16041341].
2320 Roter DL, Erby LH, Larson S, Ellington L. Assessing oral literacy demand in genetic counseling dialogue: preliminary test of a conceptual framework. Soc Sci Med. Oct. 2007;65(7):1442-57. [pmid: 17614177].
2321 Roth MT, Ivey JL. Self-reported medication use in community-residing older adults: A pilot study. Am J Geriatr Pharmacother. Sep. 2005;3(3):196-204. [pmid: 16257822].
2322 Roth MT, Moore CG, Ivey JL, Esserman DA, Campbell WH, Weinberger M. The quality of medication use in older adults: methods of a longitudinal study. Am J Geriatr Pharmacother. Oct. 2008;6(4):220-33. [pmid: 19028378].
2323 Roth MT, Watson LC, Esserman DA, Ivey JL, Hansen R, Lewis CL, et al. Methodology of a pilot study to improve the quality of medication use in older adults: Enhancing Quality in Psychiatry Using Pharmacists (EQUIPP). Am J Geriatr Pharmacother. Dec. 2009;7(6):362-72. [pmid: 20129257].
2324 Rother HA. South African farm workers' interpretation of risk assessment data expressed as pictograms on pesticide labels. Environ Res. Nov. 2008;108(3):419-27. [pmid: 18755451].
2325 Rothman R, Malone R, Bryant B, Horlen C, DeWalt D, Pignone M. The relationship between literacy and glycemic control in a diabetes disease-management program. Diabetes Educ. Mar-Apr. 2004;30(2):263-73. [pmid: 15095516].
2326 Rothman RL, DeWalt DA, Malone R, Bryant B, Shintani A, Crigler B, et al. Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program. J Am Med Assoc. Oct. 13. 2004;292(14):1711-6.
2327 Rothman RL, Housam R, Weiss H, Davis D, Gregory R, Gebretsadik T, et al. Patient understanding of food labels: the role of literacy and numeracy. Am J Prev Med. Nov. 2006;31(5):391-8. [pmid: 17046410].
2328 Rothman RL, Malone R, Bryant B, Shintani AK, Crigler B, Dewalt DA, et al. A randomized trial of a primary care-based disease management program to improve cardiovascular risk factors and glycated hemoglobin levels in patients with diabetes. Am J Med. Mar. 2005;118(3):276-84. [pmid: 15745726].
2329 Rothman RL, Malone R, Bryant B, Wolfe C, Padgett P, DeWalt DA, et al. The Spoken Knowledge in Low Literacy in Diabetes scale: a diabetes knowledge scale for vulnerable patients. Diabetes Educ. Mar-Apr. 2005;31(2):215-24. [pmid: 15797850].
2330 Rothman RL, Montori VM, Cherrington A, Pignone MP. Perspective: the role of numeracy in health care. J Health Commun. Sep. 2008;13(6):583-95. [pmid: 18726814].
2331 Rothman RL, Yin HS, Mulvaney S, Co JP, Homer C, Lannon C. Health literacy and quality: focus on chronic illness care and patient safety. Pediatrics. Nov. 3. 2009;124:S315-26. [pmid: 19861486].
2332 Rothschild B. Health literacy: what the issue is, what is happening, and what can be done. Health Promot Pract. Jan. 2005;6(1):8-11. [pmid: 15574521].
2333 Routh K, Rao JN, Denley J. A simple, and potentially low-cost method for measuring the prevalence of childhood obesity. Child Care Health Dev. Mar. 2006;32(2):239-45. [pmid: 16441858].
2334 Rowe J, Barnes M. The role of child health nurses in enhancing mothering know-how. Collegian. Oct. 2006;13(4):22-6. [pmid: 17285827].
2335 Royak-Schaler R, Blocker DE, Yali AM, Bynoe M, Briant KJ, Smith S. Breast and colorectal cancer risk communication approaches with low-income African-American and Hispanic women: implications for healthcare providers. J Natl Med Assoc. May. 2004;96(5):598-608. [pmid: 15160974].
2336 Royall DR, Espino DV, Polk MJ, Palmer RF, Markides KS. Prevalence and patterns of executive impairment in community dwelling Mexican Americans: results from the Hispanic EPESE Study. Int J Geriatr Psychiatry. Oct. 2004;19(10):926-34. [pmid: 15449370].
2337 Rozmovits L, Ziebland S. What do patients with prostate or breast cancer want from an Internet site? A qualitative study of information needs. Patient Educ Couns. Apr. 2004;53(1):57-64. [pmid: 15062905].
2338 Rudd R, Horowitz AM. The role of health literacy in achieving oral health for elders. J Dent Educ. Sep. 2005;69(9):1018-21. [pmid: 16141088].
2339 Rudd RE. Health literacy skills of U.S. adults. Am J Health Behav. Sep-Oct. 1. 2007;31:S8-18. [pmid: 17931141].
2340 Rudd RE, Comings JP, Hyde JN. Leave no one behind: improving health and risk communication through attention to literacy. J Health Commun. 1. 2003;8:104-15. [pmid: 14692575].
2341 Rudd RE, Horowitz AM. Health and literacy: supporting the oral health research agenda. J Public Health Dent. Summer. 2005;65(3):131-2. [pmid: 16171256].
2342 Rudd RE, Rosenfeld L, Gall V. Health literacy and arthritis research and practice. Curr Opin Rheumatol. Mar. 2007;19(2):97-100. [pmid: 17278921].
2343 Rudd RE, Zobel EK, Fanta CH, Surkan P, Rodriguez-Louis J, Valderrama Y, et al. Asthma: in plain language. Health Promot Pract. Jul. 2004;5(3):334-40. [pmid: 15228789].
2344 Rudin-Brown CM, Jenkins RW, Whitehead T, Burns PC. Could ESC (Electronic Stability Control) change the way we drive?. Traffic Inj Prev. Aug. 2009;10(4):340-7. [pmid: 19593710].
2345 Rudolph JL. Turning science to account: Chicago and the general science movement in secondary education, 1905-1920. Isis. Sep. 2005;96(3):353-89. [pmid: 16465728].
2346 Rudolph JW, Simon R, Raemer DB. Which reality matters? Questions on the path to high engagement in healthcare simulation. Simul Healthc. Fall. 2007;2(3):161-3. [pmid: 19088618].
2347 Ruijssenaars AJ, Ghesquiere P. Adults with learning disabilities: differences between The Netherlands and Flanders. Dyslexia. Nov. 2003;9(4):252-65. [pmid: 14672512].
2348 Ruiz-Quintanilla SA, Weathers RR 2nd, Melburg V, Campbell K, Madi N. Participation in programs designed to improve employment outcomes for persons with psychiatric disabilities: evidence from the New York WORKS demonstration project. Soc Secur Bull. 2005;66(2):49-79. [pmid: 16878427].
2349 Russell CK, Burchum JR, Likes WM, Jacob S, Graff JC, Driscoll C, et al. WebQuests: creating engaging, student-centered, constructivist learning activities. Comput Inform Nurs. Mar-Apr. 2008;26(2):78-87. quiz 8-9. [pmid: 18317258].
2350 Rutherford J, Holman R, MacDonald J, Taylor A, Jarrett D, Bigrigg A. Low literacy: a hidden problem in family planning clinics. J Fam Plann Reprod Health Care. Oct. 2006;32(4):235-40. [pmid: 17032511].
2351 Rutledge DN, Jones K, Jones CJ. Predicting high physical function in people with fibromyalgia. J Nurs Scholarsh. 2007;39(4):319-24. [pmid: 18021131].
2352 Rvachew S, Chiang PY, Evans N. Characteristics of speech errors produced by children with and without delayed phonological awareness skills. Lang Speech Hear Serv Sch. Jan. 2007;38(1):60-71. [pmid: 17218536].
2353 Rvachew S, Grawburg M. Correlates of phonological awareness in preschoolers with speech sound disorders. J Speech Lang Hear Res. Feb. 2006;49(1):74-87. [pmid: 16533074].
2354 Rvachew S, Ohberg A, Grawburg M, Heyding J. Phonological awareness and phonemic perception in 4-year-old children with delayed expressive phonology skills. Am J Speech Lang Pathol. Nov. 2003;12(4):463-71. [pmid: 14658998].
2355 Ryan EL, Baird R, Mindt MR, Byrd D, Monzones J, Bank SM. Neuropsychological impairment in racial/ethnic minorities with HIV infection and low literacy levels: effects of education and reading level in participant characterization. J Int Neuropsychol Soc. Nov. 2005;11(7):889-98. [pmid: 16519268].
2356 Ryan EL, Byrd D, Mindt MR, Rausch WJ, Morgello S. Understanding the neuropsychological profile of HIV+ participants with low literacy: role of the General Ability Measure for Adults (GAMA). Clin Neuropsychol. Dec. 2008;22(6):1018-34. [pmid: 18609327].
2357 Ryan JG, Leguen F, Weiss BD, Albury S, Jennings T, Velez F, et al. Will patients agree to have their literacy skills assessed in clinical practice?. Health Educ Res. Aug. 2008;23(4):603-11. [pmid: 17890757].
2358 Rysdale L. Evaluation of a nutrition education component nested in the NutriSTEP Project. Can J Diet Pract Res. Spring. 2008;69(1):38-42. [pmid: 18334053].
2359 Sachs-Ericsson N, Blazer DG. Racial differences in cognitive decline in a sample of community-dwelling older adults: the mediating role of education and literacy. Am J Geriatr Psychiatry. Nov. 2005;13(11):968-75. [pmid: 16286440].
2360 Sadan B. Patient empowerment and the asymmetry of knowledge. Stud Health Technol Inform. 2002;90:514-8. [pmid: 15460747].
2361 Safeer RS, Cooke CE, Keenan J. The impact of health literacy on cardiovascular disease. Vasc Health Risk Manag. 2006;2(4):457-64. [pmid: 17323600].
2362 Safeer RS, Cooke CE, Robertson TA. Pharmacy measures to improve medication use through health-literacy principles. Manag Care Interface. Oct. 2007;20(10):37-41. [pmid: 18405206].
2363 Safeer RS, Keenan J. Health literacy: the gap between physicians and patients. Am Fam Physician. Aug. 1. 2005;72(3):463-8. [pmid: 16100861].
2364 Safren SA, Kumarasamy N, Hosseinipour M, Harwood MM, Hoffman I, McCauley M, et al. Perceptions about the acceptability of assessments of HIV medication adherence in Lilongwe, Malawi and Chennai, India. AIDS Behav. Jul. 2006;10(4):443-50. [pmid: 16604297].
2365 Saha S. Improving literacy as a means to reducing health disparities. J Gen Intern Med. Aug. 2006;21(8):893-5. [pmid: 16881955].
2366 Saha S, Barnett AG, Foldi C, Burne TH, Eyles DW, Buka SL, et al. Advanced paternal age is associated with impaired neurocognitive outcomes during infancy and childhood. PLoS Med. Mar. 10. 2009;6(3):e40. [pmid: 19278291].
2367 Saha SK, Bag T, De Aloke K, Basak S, Chhetri A, Banerjee J. Contraceptive practice of the tribal women in tea garden area of North Bengal. J Indian Med Assoc. Aug. 2007;105(8):440. 2. 8. [pmid: 18236906].
2368 Sahip Y, Turan JM. Education for expectant fathers in workplaces in Turkey. J Biosoc Sci. Nov. 2007;39(6):843-60. [pmid: 17537276].
2369 Saiepour N, Mohammad K, Abhari R, Zeraati H, Noorbala AA. Mental disorder assessed by General Health Questionnaire and back pain among postmenopausal Iranian women. Pak J Biol Sci. Mar. 1. 2008;11(5):809-12. [pmid: 18819584].
2370 Sainio P, Martelin T, Koskinen S, Heliovaara M. Educational differences in mobility: the contribution of physical workload, obesity, smoking and chronic conditions. J Epidemiol Community Health. May. 2007;61(5):401-8. [pmid: 17435206].
2371 Saint-Aubin J, Klein RM, Landry T. Age changes in the missing-letter effect revisited. J Exp Child Psychol. Jun. 2005;91(2):158-82. [pmid: 15890175].
2372 Sakraida TJ, Robinson MV. Health literacy self-management by patients with type 2 diabetes and stage 3 chronic kidney disease. West J Nurs Res. Aug. 2009;31(5):627-47. [pmid: 19390053].
2373 Salaffi F, Carotti M, Stancati A, Grassi W. Health-related quality of life in older adults with symptomatic hip and knee osteoarthritis: a comparison with matched healthy controls. Aging Clin Exp Res. Aug. 2005;17(4):255-63. [pmid: 16285189].
2374 Saleem S, Fikree FF. The quest for small family size among Pakistani women--is voluntary termination of pregnancy a matter of choice or necessity?. J Pak Med Assoc. Jul. 2005;55(7):288-91. [pmid: 16108512].
2375 Salmon J. Fetal alcohol spectrum disorder: New Zealand birth mothers' experiences. Can J Clin Pharmacol. Summer. 2008;15(2):e191-213. [pmid: 18515921].
2376 Salonna F, Middel B, Sleskova M, Geckova AM, Reijneveld SA, Groothoff JW, et al. Deterioration is not the only prospect for adolescents' health: improvement in self-reported health status among boys and girls from age 15 to age 19. Croat Med J. Feb. 2008;49(1):66-74. [pmid: 18293459].
2377 Sam KG, Andrade HH, Pradhan L, Pradhan A, Sones SJ, Rao PG, et al. Effectiveness of an educational program to promote pesticide safety among pesticide handlers of South India. Int Arch Occup Environ Health. May. 2008;81(6):787-95. [pmid: 17962973].
2378 Sami N, Ali TS. Health seeking behavior of couples with secondary infertility. J Coll Physicians Surg Pak. Apr. 2006;16(4):261-4. [pmid: 16624188].
2379 Samuel M, Coombes JC, Miranda JJ, Melvin R, Young EJ, Azarmina P. Assessing computer skills in Tanzanian medical students: an elective experience. BMC Public Health. Aug. 12. 2004;4:37. [pmid: 15306029].
2380 Sanchez CD, Newby LK, McGuire DK, Hasselblad V, Feinglos MN, Ohman EM. Diabetes-related knowledge, atherosclerotic risk factor control, and outcomes in acute coronary syndromes. Am J Cardiol. Jun. 1. 2005;95(11):1290-4. [pmid: 15904631].
2381 Sanders LM, Federico S, Klass P, Abrams MA, Dreyer B. Literacy and child health: a systematic review. Arch Pediatr Adolesc Med. Feb. 2009;163(2):131-40. [pmid: 19188645].
2382 Sanders LM, Shaw JS, Guez G, Baur C, Rudd R. Health literacy and child health promotion: implications for research, clinical care, and public policy. Pediatrics. Nov. 3. 2009;124:S306-14. [pmid: 19861485].
2383 Sanders LM, Thompson VT, Wilkinson JD. Caregiver health literacy and the use of child health services. Pediatrics. Jan. 2007;119(1):e86-92. [pmid: 17200263].
2384 Sanders LM, Zacur G, Haecker T, Klass P. Number of children's books in the home: an indicator of parent health literacy. Ambul Pediatr. Sep-Oct. 2004;4(5):424-8. [pmid: 15369414].
2385 Sandwell M, Carson P. Developing numeracy in child branch students. Paediatr Nurs. Nov. 2005;17(9):24-6. [pmid: 16315813].
2386 Santo A, Laizner AM, Shohet L. Exploring the value of audiotapes for health literacy: a systematic review. Patient Educ Couns. Sep. 2005;58(3):235-43. [pmid: 16054796].
2387 Santos JN, Lemos SM, Rates SP, Lamounier JA. Hearing abilities and language development in anemic children of a public daycare center. Pro Fono. Oct-Dec. 2008;20(4):255-60. [pmid: 19142469].
2388 Saperstein SL, Atkinson NL, Gold RS. The impact of Internet use for weight loss. Obes Rev. Sep. 2007;8(5):459-65. [pmid: 17716303].
2389 Sapkota YD, Pokharel GP, Nirmalan PK, Dulal S, Maharjan IM, Prakash K. Prevalence of blindness and cataract surgery in Gandaki Zone, Nepal. Br J Ophthalmol. Apr. 2006;90(4):411-6. [pmid: 16547315].
2390 Sarangmath N, Rattihalli R, Ragothaman M, Gopalkrishna G, Doddaballapur S, Louis ED, et al. Validity of a modified Parkinson's disease screening questionnaire in India: effects of literacy of participants and medical training of screeners and implications for screening efforts in developing countries. Mov Disord. Dec. 2005;20(12):1550-6. [pmid: 16078206].
2391 Sarfaty M, Turner CH, Damotta E. Use of a patient assistant to facilitate medical visits for Latino patients with low health literacy. J Community Health. Aug. 2005;30(4):299-307. [pmid: 15989211].
2392 Sarkar K, Bal B, Mukherjee R, Saha MK, Chakraborty S, Niyogi SK, et al. Young age is a risk factor for HIV among female sex workers--an experience from India. J Infect. Oct. 2006;53(4):255-9. [pmid: 16386307].
2393 Sarkar U, Fisher L, Schillinger D. Is self-efficacy associated with diabetes self-management across race/ethnicity and health literacy?. Diabetes Care. Apr. 2006;29(4):823-9. [pmid: 16567822].
2394 Sarkar U, Piette JD, Gonzales R, Lessler D, Chew LD, Reilly B, et al. Preferences for self-management support: findings from a survey of diabetes patients in safety-net health systems. Patient Educ Couns. Jan. 2008;70(1):102-10. [pmid: 17997264].
2395 Saroha E, Altarac M, Sibley LM. Caste and maternal health care service use among rural Hindu women in Maitha, Uttar Pradesh, India. J Midwifery Womens Health. Sep-Oct. 2008;53(5):e41-7. [pmid: 18761290].
2396 Sass HM. New options for health care policy and health status insurance: citizens as customers. Croat Med J. Oct. 2003;44(5):562-7. [pmid: 14515414].
2397 Sasson R, Grinshpoon A, Lachman M, Ponizovsky A. A program of supported education for adult Israeli students with schizophrenia. Psychiatr Rehabil J. Fall. 2005;29(2):139-41. [pmid: 16268010].
2398 Sastry J, Pisal H, Sutar S, Kapadia-Kundu N, Joshi A, Suryavanshi N, et al. Optimizing the HIV/AIDS informed consent process in India. BMC Med. Aug. 2. 2004;2:28. [pmid: 15287983].
2399 Savage R. Cerebellar tasks do not distinguish between children with developmental dyslexia and children with intellectual disability. Child Neuropsychol. Sep. 2007;13(5):389-407. [pmid: 17805993].
2400 Savage R, Carless S. Predicting curriculum and test performance at age 7 years from pupil background, baseline skills and phonological awareness at age 5. Br J Educ Psychol. Jun. 2004;74(Pt 2):155-71. [pmid: 15130185].
2401 Savage R, Carless S. Phoneme manipulation not onset-rime manipulation ability is a unique predictor of early reading. J Child Psychol Psychiatry. Dec. 2005;46(12):1297-308. [pmid: 16313430].
2402 Savage R, Carless S, Ferraro V. Predicting curriculum and test performance at age 11 years from pupil background, baseline skills and phonological awareness at age 5 years. J Child Psychol Psychiatry. Jul. 2007;48(7):732-9. [pmid: 17593154].
2403 Sawardekar KP. Genetic analysis of lethal congenital malformations causing perinatal mortality at Nizwa Hospital, Oman. Clin Genet. Sep. 2004;66(3):239-43. [pmid: 15324324].
2404 Scalise D. Patient satisfaction and the new consumer. Hosp Health Netw. Dec. 57. 2006;80(12):9-62. [pmid: 16773884].
2405 Scazufca M, Almeida OP, Vallada HP, Tasse WA, Menezes PR. Limitations of the Mini-Mental State Examination for screening dementia in a community with low socioeconomic status: results from the Sao Paulo Ageing & Health Study. Eur Arch Psychiatry Clin Neurosci. Feb. 2009;259(1):8-15. [pmid: 18560791].
2406 Scazufca M, Menezes PR, Araya R, Di Rienzo VD, Almeida OP, Gunnell D, et al. Risk factors across the life course and dementia in a Brazilian population: results from the Sao Paulo Ageing & Health Study (SPAH). Int J Epidemiol. Aug. 2008;37(4):879-90. [pmid: 18583392].
2407 Schaafsma ES, Raynor TD, de Jong-van den Berg LT. Accessing medication information by ethnic minorities: barriers and possible solutions. Pharm World Sci. Oct. 2003;25(5):185-90. [pmid: 14584223].
2408 Schaefer CT. Integrated review of health literacy interventions. Orthop Nurs. Sep-Oct. 2008;27(5):302-17. [pmid: 18832992].
2409 Schapira MM, Davids SL, McAuliffe TL, Nattinger AB. Agreement between scales in the measurement of breast cancer risk perceptions. Risk Anal. Jun. 2004;24(3):665-73. [pmid: 15209937].
2410 Schapira MM, Fletcher KE, Gilligan MA, King TK, Laud PW, Matthews BA, et al. A framework for health numeracy: how patients use quantitative skills in health care. J Health Commun. Jul-Aug. 2008;13(5):501-17. [pmid: 18661390].
2411 Scharer K. Internet social support for parents: the state of science. J Child Adolesc Psychiatr Nurs. Jan-Mar. 2005;18(1):26-35. [pmid: 15701096].
2412 Scheinfeld NS, Flanigan K, Moshiyakhov M, Weinberg JM. Trends in the use of cameras and computer technology among dermatologists in New York City 2001-2002. Dermatol Surg. Aug. 2003;29(8):822-5. discussion 6. [pmid: 12859381].
2413 Scherl WF, Krupp LB, Christodoulou C, Morgan TM, Hyman L, Chandler B, et al. Normative data for the selective reminding test: a random digit dialing sample. Psychol Rep. Oct. 2004;95(2):593-603. [pmid: 15587227].
2414 Schillinger D. Literacy and health communication: reversing the ‘inverse care law’. Am J Bioeth. Nov. 2007;7(11):15-8. discussion W1-2. [pmid: 18027291].
2415 Schillinger D, Barton LR, Karter AJ, Wang F, Adler N. Does literacy mediate the relationship between education and health outcomes? A study of a low-income population with diabetes. Public Health Rep. May-Jun. 2006;121(3):245-54. [pmid: 16640146].
2416 Schillinger D, Bindman A, Wang F, Stewart A, Piette J. Functional health literacy and the quality of physician-patient communication among diabetes patients. Patient Educ Couns. Mar. 2004;52(3):315-23. [pmid: 14998602].
2417 Schillinger D, Hammer H, Wang F, Palacios J, McLean I, Tang A, et al. Seeing in 3-D: examining the reach of diabetes self-management support strategies in a public health care system. Health Educ Behav. Oct. 2008;35(5):664-82. [pmid: 17513690].
2418 Schillinger D, Piette J, Grumbach K, Wang F, Wilson C, Daher C, et al. Closing the loop: physician communication with diabetic patients who have low health literacy. Arch Intern Med. Jan. 13. 2003;163(1):83-90. [pmid: 12523921].
2419 Schirmer TN, Meyer KA, Samarasinghe R. Teaching literacy and mathematics skills to adult psychiatric inpatients: an evaluation of the adult literacy program at Hawaii State Hospital. Psychiatr Rehabil J. Winter. 2005;28(3):251-9. [pmid: 15690738].
2420 Schleyer TK, Teasley SD, Bhatnagar R. Comparative case study of two biomedical research collaboratories. J Med Internet Res. 2005;7(5):e53. [pmid: 16403717].
2421 Schlichting JA, Quinn MT, Heuer LJ, Schaefer CT, Drum ML, Chin MH. Provider perceptions of limited health literacy in community health centers. Patient Educ Couns. Dec. 2007;69(1-3):114-20. [pmid: 17889494].
2422 Schloman BF. Health literacy: a key ingredient for managing personal health. Online J Issues Nurs. May. 31. 2004;9(2):6. [pmid: 15485303].
2423 Schmid MA, Egeland GM, Salomeyesudas B, Satheesh PV, Kuhnlein HV. Traditional food consumption and nutritional status of Dalit mothers in rural Andhra Pradesh, South India. Eur J Clin Nutr. Nov. 2006;60(11):1277-83. [pmid: 16721395].
2424 Schmier JK, Kane DW, Halpern MT. Practical applications of usability theory to electronic data collection for clinical trials. Contemp Clin Trials. Jun. 2005;26(3):376-85. [pmid: 15911471].
2425 Schnitzer MI, Kaplin DB, Keane VA, Zuckerman B, Sharfstein JM. Giving literacy a shot in the arm. Public Health Rep. Jul-Aug. 2008;123(4):523-6. [pmid: 18763415].
2426 Schoenwald SK, Halliday-Boykins CA, Henggeler SW. Client-level predictors of adherence to MST in community service settings. Fam Process. Fall. 2003;42(3):345-59. [pmid: 14606199].
2427 Schofield P, Ugalde A, Carey M, Mileshkin L, Duffy M, Ball D, et al. Lung cancer: challenges and solutions for supportive care intervention research. Palliat Support Care. Sep. 2008;6(3):281-7. [pmid: 18662422].
2428 Schooling CM, Jiang CQ, Heys M, Zhang WS, Adab P, Cheng KK, et al. Are height and leg length universal markers of childhood conditions? The Guangzhou Biobank cohort study. J Epidemiol Community Health. Jul. 2008;62(7):607-14. [pmid: 18559443].
2429 Schopp LH, Shigaki CL, Bounds TA, Johnstone B, Stucky RC, Conway DL. Outcomes in TBI with violent versus nonviolent etiology in a predominantly rural setting. J Head Trauma Rehabil. May-Jun. 2006;21(3):213-25. [pmid: 16717499].
2430 Schuele CM. The impact of developmental speech and language impairments on the acquisition of literacy skills. Ment Retard Dev Disabil Res Rev. 2004;10(3):176-83. [pmid: 15611989].
2431 Schuele CM, Boudreau D. Phonological awareness intervention: beyond the basics. Lang Speech Hear Serv Sch. Jan. 2008;39(1):3-20. [pmid: 18162644].
2432 Schuele CM, Spencer EJ, Barako-Arndt K, Guillot KM. Literacy and children with specific language impairment. Semin Speech Lang. Feb. 2007;28(1):35-47. [pmid: 17340381].
2433 Schulte SJ. Integrating information literacy into an online undergraduate nursing informatics course: the librarian's role in the design and teaching of the course. Med Ref Serv Q. Summer. 2008;27(2):158-72. [pmid: 18844089].
2434 Schulz PJ, Rubinelli S, Mariotti G, Keller N. Meeting the ranging of informational needs of chronic low back pain sufferers: conceptual design and rationale of the interactive website ONESELF. Disabil Rehabil. 2009;31(25):2118-24. [pmid: 19888842].
2435 Schutt MA, Hightower B. Enhancing RN-to-BSN students' information literacy skills through the use of instructional technology. J Nurs Educ. Feb. 2009;48(2):101-5. [pmid: 19260403].
2436 Schwartz C, Welch G, Santiago-Kelley P, Bode R, Sun X. Computerized adaptive testing of diabetes impact: a feasibility study of Hispanics and non-Hispanics in an active clinic population. Qual Life Res. Nov. 2006;15(9):1503-18. [pmid: 17031500].
2437 Schwartz LM, Woloshin S, Black WC, Welch HG. The role of numeracy in understanding the benefit of screening mammography. Ann Intern Med. Dec. 1. 1997;127(11):966-72. [pmid: 9412301].
2438 Schwartz LM, Woloshin S, Welch HG. Can patients interpret health information? An assessment of the medical data interpretation test. Med Decis Making. May-Jun. 2005;25(3):290-300. [pmid: 15951456].
2439 Schwartz SR, McDowell J, Yueh B. Numeracy and the shortcomings of utility assessment in head and neck cancer patients. Head Neck. May. 2004;26(5):401-7. [pmid: 15122656].
2440 Schwartzberg JG, Cowett A, VanGeest J, Wolf MS. Communication techniques for patients with low health literacy: a survey of physicians, nurses, and pharmacists. Am J Health Behav. Sep-Oct. 1. 2007;31:S96-104. [pmid: 17931143].
2441 Schyve PM. Language differences as a barrier to quality and safety in health care: the Joint Commission perspective. J Gen Intern Med. Nov. 2. 2007;22:360-1. [pmid: 17957426].
2442 Sciamanna CN, Gifford DR, Smith RJ. Design and acceptability of patient-oriented computerized diabetes care reminders for use at the point of care. Med Inform Internet Med. Jun. 2004;29(2):157-68. [pmid: 15370995].
2443 Scott KA, Roberts JA, Krakow R. Oral and written language development of children adopted from china. Am J Speech Lang Pathol. May. 2008;17(2):150-60. [pmid: 18448602].
2444 Scott L, Chur-Hansen A. The mental health literacy of rural adolescents: Emo subculture and SMS texting. Australas Psychiatry. Oct. 2008;16(5):359-62. [pmid: 18608151].
2445 Scott SD, Gilmour J, Fielden J. Nursing students and Internet health information. Nurse Educ Today. Nov. 2008;28(8):993-1001. [pmid: 18700178].
2446 Seasholtz SI. Financial literacy--no nurse left behind. Am Nurse. May-Jun. 2006;38(3):9. [pmid: 16833075].
2447 Secco ML, Woodgate RL, Hodgson A, Kowalski S, Plouffe J, Rothney PR, et al. A survey study of pediatric nurses' use of information sources. Comput Inform Nurs. Mar-Apr. 2006;24(2):105-12. [pmid: 16554694].
2448 Sedlar D, Potomkova J, Rehorova J, Seckar P, Sukopova V. Computer literacy enhancement in the Teaching Hospital Olomouc. Part I: project management techniques. Short communication. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Nov. 2003;147(1):109-11. [pmid: 15034614].
2449 Segalas C, Alonso P, Labad J, Jaurrieta N, Real E, Jimenez S, et al. Verbal and nonverbal memory processing in patients with obsessive-compulsive disorder: its relationship to clinical variables. Neuropsychology. Mar. 2008;22(2):262-72. [pmid: 18331169].
2450 Segovis C. Pointers for PowerPointers. Minn Med. Jun. 2006;89(6):38-40. [pmid: 16846182].
2451 Selassie GR, Viggedal G, Olsson I, Jennische M. Speech, language, and cognition in preschool children with epilepsy. Dev Med Child Neurol. Jun. 2008;50(6):432-8. [pmid: 18422681].
2452 Seligman HK, Wallace AS, DeWalt DA, Schillinger D, Arnold CL, Shilliday BB, et al. Facilitating behavior change with low-literacy patient education materials. Am J Health Behav. Sep-Oct. 1. 2007;31:S69-78. [pmid: 17931139].
2453 Seligman HK, Wang FF, Palacios JL, Wilson CC, Daher C, Piette JD, et al. Physician notification of their diabetes patients' limited health literacy. A randomized, controlled trial. J Gen Intern Med. Nov. 2005;20(11):1001-7. [pmid: 16307624].
2454 Selkowitz DM, Kulig K, Poppert EM, Flanagan SP, Matthews ND, Beneck GJ, et al. The immediate and long-term effects of exercise and patient education on physical, functional, and quality-of-life outcome measures after single-level lumbar microdiscectomy: a randomized controlled trial protocol. BMC Musculoskelet Disord. 2006;7:70. [pmid: 16934143].
2455 Selva KA, Harper A, Downs A, Blasco PA, Lafranchi SH. Neurodevelopmental outcomes in congenital hypothyroidism: comparison of initial T4 dose and time to reach target T4 and TSH. J Pediatr. Dec. 2005;147(6):775-80. [pmid: 16356430].
2456 Semenza JC, Krishnasamy PV. Design of a health-promoting neighborhood intervention. Health Promot Pract. Jul. 2007;8(3):243-56. [pmid: 16816029].
2457 Senay I, Kaphingst KA. Anchoring-and-adjustment bias in communication of disease risk. Med Decis Making. Mar-Apr. 2009;29(2):193-201. [pmid: 19279297].
2458 Senechal M, Kearnan K. The role of morphology in reading and spelling. Adv Child Dev Behav. 2007;35:297-325. [pmid: 17682329].
2459 Sensmeier J. The future of IT? Aggressive educational reform. TIGER initiative preps nurses for healthcare's digital era. Nurs Manage. Sep. 2007;(Suppl):2. 4. 6 passim. [pmid: 18159649].
2460 Sentell TL, Halpin HA. Importance of adult literacy in understanding health disparities. J Gen Intern Med. Aug. 2006;21(8):862-6. [pmid: 16881948].
2461 Sentell TL, Ratcliff-Baird B. Literacy and comprehension of Beck Depression Inventory response alternatives. Community Ment Health J. Aug. 2003;39(4):323-31. [pmid: 12908646].
2462 Sentell TL, Shumway MA. Low literacy and mental illness in a nationally representative sample. J Nerv Ment Dis. Aug. 2003;191(8):549-52. [pmid: 12972860].
2463 Serniclaes W, Ventura P, Morais J, Kolinsky R. Categorical perception of speech sounds in illiterate adults. Cognition. Dec. 2005;98(2):B35-44. [pmid: 15993403].
2464 Servonsky EJ, Daniels WL, Davis BL. Evaluation of Blackboard as a platform for distance education delivery. ABNF J. Nov-Dec. 2005;16(6):132-5. [pmid: 16382797].
2465 Settersten RA Jr, Ray B. What's going on with young people today? the long and twisting path to adulthood. Future Child. Spring. 2010;20(1):19-41. [pmid: 20364620].
2466 Seymour PH, Aro M, Erskine JM. Foundation literacy acquisition in European orthographies. Br J Psychol. May. 2003;94(Pt 2):143-74. [pmid: 12803812].
2467 Shah N. Gender issues and oral health in elderly Indians. Int Dent J. Dec. 2003;53(6):475-84. [pmid: 14725376].
2468 Shah N, Sundaram KR. Impact of socio-demographic variables, oral hygiene practices, oral habits and diet on dental caries experience of Indian elderly: a community-based study. Gerodontology. Mar. 2004;21(1):43-50. [pmid: 15074539].
2469 Shah SP, Dineen B, Jadoon Z, Bourne R, Khan MA, Johnson GJ, et al. Lens opacities in adults in Pakistan: prevalence and risk factors. Ophthalmic Epidemiol. Nov-Dec. 2007;14(6):381-9. [pmid: 18161612].
2470 Shaheen FA, Kurpad R, Al-Attar BA, Muna B, Al-Khader AA. Comparative psychosocial analysis of patients on maintenance hemodialysis and transplanted patients. Ann Transplant. 2005;10(1):17-21. [pmid: 15926746].
2471 Shahraki M, Shahraki T, Ansari H. The effects of socio-economic status on BMI, waist:hip ratio and waist circumference in a group of Iranian women. Public Health Nutr. Jul. 2008;11(7):757-61. [pmid: 18194587].
2472 Shane HC, Albert PD. Electronic screen media for persons with autism spectrum disorders: results of a survey. J Autism Dev Disord. Sep. 2008;38(8):1499-508. [pmid: 18293074].
2473 Shankar S, Evans MA, Bobier WR. Hyperopia and emergent literacy of young children: pilot study. Optom Vis Sci. Nov. 2007;84(11):1031-8. [pmid: 18043422].
2474 Shankweiler D, Mencl WE, Braze D, Tabor W, Pugh KR, Fulbright RK. Reading differences and brain: cortical integration of speech and print in sentence processing varies with reader skill. Dev Neuropsychol. 2008;33(6):745-75. [pmid: 19005913].
2475 Shapiro LR, Solity J. Delivering phonological and phonics training within whole-class teaching. Br J Educ Psychol. Dec. 2008;78(Pt 4):597-620. [pmid: 18433521].
2476 Share DL, Blum P. Syllable splitting in literate and preliterate Hebrew speakers: onsets and rimes or bodies and codas?. J Exp Child Psychol. Oct. 2005;92(2):182-202. [pmid: 16040046].
2477 Sharma AK, Aggarwal OP, Chaturvedi S, Bhasin SK. Is education a determinant of knowledge about malaria among Indian tribal population?. J Commun Dis. Jun. 2003;35(2):109-17. [pmid: 15562957].
2478 Sharma D. Cultural pathways through the information age. New Dir Child Adolesc Dev. Fall. 2004;(105):3-23. [pmid: 15552205].
2479 Sharma P, Sharma BC, Puri V, Sarin SK. Critical flicker frequency: diagnostic tool for minimal hepatic encephalopathy. J Hepatol. Jul. 2007;47(1):67-73. [pmid: 17459511].
2480 Sharp LK, Kimmel LG, Kee R, Saltoun C, Chang CH. Assessing the Perceived Stress Scale for African American adults with asthma and low literacy. J Asthma. May. 2007;44(4):311-6. [pmid: 17530531].
2481 Shatil E, Share DL. Cognitive antecedents of early reading ability: a test of the modularity hypothesis. J Exp Child Psychol. Sep. 2003;86(1):1-31. [pmid: 12943615].
2482 Shaw BA, Janevic M. Associations between anticipated support, physical functioning, and education level among a nationally representative sample of older adults. J Aging Health. 2004;16(4):539-61. [pmid: 15271269].
2483 Shaw BR, Hawkins R, Arora N, McTavish F, Pingree S, Gustafson DH. An exploratory study of predictors of participation in a computer support group for women with breast cancer. Comput Inform Nurs. Jan-Feb. 2006;24(1):18-27. [pmid: 16436908].
2484 She L, Wu B, Xu L, Wu J, Zhang P, Li E. Determinants of career aspirations of medical students in southern China. BMC Med Educ. 2008;8:59. [pmid: 19077214].
2485 Shea JA, Aguirre AC, Sabatini J, Weiner J, Schaffer M, Asch DA. Developing an illustrated version of the Consumer Assessment of Health Plans (CAHPS). Jt Comm J Qual Patient Saf. Jan. 2005;31(1):32-42. [pmid: 15691208].
2486 Shea JA, Beers BB, McDonald VJ, Quistberg DA, Ravenell KL, Asch DA. Assessing health literacy in African American and Caucasian adults: disparities in rapid estimate of adult literacy in medicine (REALM) scores. Fam Med. Sep. 2004;36(8):575-81. [pmid: 15343419].
2487 Shea JA, Guerra CE, Ravenell KL, McDonald VJ, Henry CA, Asch DA. Health literacy weakly but consistently predicts primary care patient dissatisfaction. Int J Qual Health Care. Feb. 2007;19(1):45-9. [pmid: 17178765].
2488 Shea JA, Guerra CE, Weiner J, Aguirre AC, Ravenell KL, Asch DA. Adapting a patient satisfaction instrument for low literate and Spanish-speaking populations: comparison of three formats. Patient Educ Couns. Oct. 2008;73(1):132-40. [pmid: 18486414].
2489 Shedlin MG, Shulman L. Qualitative needs assessment of HIV services among Dominican, Mexican and Central American immigrant populations living in the New York City area. AIDS Care. May. 2004;16(4):434-45. [pmid: 15203412].
2490 Shefter SM. Workflow technology: the new frontier. How to overcome the barriers and join the future. Lippincotts Case Manag. Jan-Feb. 2006;11(1):25-34. quiz 5-6. [pmid: 16444119].
2491 Sheikholeslam R, Kimiagar M, Siasi F, Abdollahi Z, Jazayeri A, Keyghobadi K, et al. Multidisciplinary intervention for reducing malnutrition among children in the Islamic Republic of Iran. East Mediterr Health J. Nov. 2004;10(6):844-52. [pmid: 16335772].
2492 Sheil D, Liswanti N. Scoring the importance of tropical forest landscapes with local people: patterns and insights. Environ Manage. Jul. 2006;38(1):126-36. [pmid: 16508796].
2493 Sheridan C, Gorman T, Claffey N. Dental nursing education and the introduction of technology-assisted learning. Eur J Dent Educ. Nov. 2008;12(4):225-32. [pmid: 19021729].
2494 Sheridan SL, Pignone M. Numeracy and the medical student's ability to interpret data. Eff Clin Pract. Jan-Feb. 2002;5(1):35-40. [pmid: 11874195].
2495 Sheridan SR. A theory of marks and mind: the effect of notational systems on hominid brain evolution and child development with an emphasis on exchanges between mothers and children. Med Hypotheses. 2005;64(2):417-27. [pmid: 15607580].
2496 Shermer M. Folk numeracy and middle land. Why our brains do not intuitively grasp probabilities, Part 1. Sci Am. Sep. 2008;299(3):40.
2497 Shieh C, Halstead JA. Understanding the impact of health literacy on women's health. J Obstet Gynecol Neonatal Nurs. Sep-Oct. 2009;38(5):601-10. quiz 10-2.
2498 Shieh C, Hosei B. Printed health information materials: evaluation of readability and suitability. J Community Health Nurs. Apr-Jun. 2008;25(2):73-90. [pmid: 18449833].
2499 Shield BM, Dockrell JE. The effects of environmental and classroom noise on the academic attainments of primary school children. J Acoust Soc Am. Jan. 2008;123(1):133-44. [pmid: 18177145].
2500 Shim M. Connecting internet use with gaps in cancer knowledge. Health Commun. Sep. 2008;23(5):448-61. [pmid: 18850392].
2501 Shkolnikov VM, Jasilionis D, Andreev EM, Jdanov DA, Stankuniene V, Ambrozaitiene D. Linked versus unlinked estimates of mortality and length of life by education and marital status: evidence from the first record linkage study in Lithuania. Soc Sci Med. Apr. 2007;64(7):1392-406. [pmid: 17196723].
2502 Shobeiri F, Nazari M. Assessment of cervical erosion in Hamedan city, Iran. Pak J Biol Sci. Oct. 1. 2007;10(19):3470-2. [pmid: 19090173].
2503 Shohet L, Renaud L. Critical analysis on best practices in health literacy. Can J Public Health. May-Jun. 2. 2006;97:S10-3. [pmid: 16805154].
2504 Shrank WH, Patrick A, Gleason PP, Canning C, Walters C, Heaton AH, et al. An evaluation of the relationship between the implementation of a newly designed prescription drug label at Target pharmacies and health outcomes. Med Care. Sep. 2009;47(9):1031-5. [pmid: 19648829].
2505 Shu H, Peng H, McBride-Chang C. Phonological awareness in young Chinese children. Dev Sci. Jan. 2008;11(1):171-81. [pmid: 18171377].
2506 Shulman KI, Herrmann N, Brodaty H, Chiu H, Lawlor B, Ritchie K, et al. IPA survey of brief cognitive screening instruments. Int Psychogeriatr. Jun. 2006;18(2):281-94. [pmid: 16466586].
2507 Sices L, Taylor HG, Freebairn L, Hansen A, Lewis B. Relationship between speech-sound disorders and early literacy skills in preschool-age children: impact of comorbid language impairment. J Dev Behav Pediatr. Dec. 2007;28(6):438-47. [pmid: 18091088].
2508 Siddiqi A, Kawachi I, Berkman L, Subramanian SV, Hertzman C. Variation of socioeconomic gradients in children's developmental health across advanced Capitalist societies: analysis of 22 OECD nations. Int J Health Serv. 2007;37(1):63-87. [pmid: 17436986].
2509 Siddiqui AR. Maternal characteristics in relation to income in a semi-rural community in Pakistan. East Mediterr Health J. Nov-Dec. 2007;13(6):1353-63. [pmid: 18341185].
2510 Sidhu R, Sakellariou V, Layte P, Soliman A. Patient feedback on helpfulness of postal information packs regarding informed consent for endoscopic procedures. Gastrointest Endosc. Aug. 2006;64(2):229-34. [pmid: 16860074].
2511 Silk KJ, Sherry J, Winn B, Keesecker N, Horodynski MA, Sayir A. Increasing nutrition literacy: testing the effectiveness of print, web site, and game modalities. J Nutr Educ Behav. Jan-Feb. 2008;40(1):3-10. [pmid: 18174098].
2512 Silveira MP, de Adorno RF, Fontana T. Profile of patients with tuberculosis: evaluation of the Brazilian national tuberculosis control program in Bage, Brazil. J Bras Pneumol. Apr. 2007;33(2):199-205. [pmid: 17724540].
2513 Silveri MM, Tzilos GK, Pimentel PJ, Yurgelun-Todd DA. Trajectories of adolescent emotional and cognitive development: effects of sex and risk for drug use. Ann N Y Acad Sci. Jun. 2004;1021:363-70. [pmid: 15251911].
2514 Silverman MM. In this issue. Mental health literacy. Suicide Life Threat Behav. Apr. 2008;38(2):iii-v.
2515 Silverstein M, Guppy N, Young R, Augustyn M. Receipt of special education services following elementary school grade retention. Arch Pediatr Adolesc Med. Jun. 2009;163(6):547-53. [pmid: 19487611].
2516 Simon C, Acheson L, Burant C, Gerson N, Schramm S, Lewis S, et al. Patient interest in recording family histories of cancer via the Internet. Genet Med. Dec. 2008;10(12):895-902. [pmid: 19092442].
2517 Simon CE. Breast cancer screening: cultural beliefs and diverse populations. Health Soc Work. Feb. 2006;31(1):36-43. [pmid: 16550846].
2518 Simon SR, Kaushal R, Cleary PD, Jenter CA, Volk LA, Orav EJ, et al. Physicians and electronic health records: a statewide survey. Arch Intern Med. Mar. 12. 2007;167(5):507-12. [pmid: 17353500].
2519 Simon SR, Kaushal R, Cleary PD, Jenter CA, Volk LA, Poon EG, et al. Correlates of electronic health record adoption in office practices: a statewide survey. J Am Med Inform Assoc. Jan-Feb. 2007;14(1):110-7. [pmid: 17068351].
2520 Simon SR, McCarthy ML, Kaushal R, Jenter CA, Volk LA, Poon EG, et al. Electronic health records: which practices have them, and how are clinicians using them?. J Eval Clin Pract. Feb. 2008;14(1):43-7. [pmid: 18211642].
2521 Simpson J, Everatt J. Reception class predictors of literacy skills. Br J Educ Psychol. Jun. 2005;75(Pt 2):171-88. [pmid: 16033661].
2522 Simpson RL. From Tele-ed to Telehealth: the need for IT ubiquity in nursing. Nurs Adm Q. Oct-Dec. 2005;29(4):344-8. [pmid: 16260999].
2523 Simpson RL. Practice to evidence to practice: closing the loop with IT. Nurs Manage. Sep. 2005;36(9):12-7. [pmid: 16155488].
2524 Simpson RL. What's nursing's PLAN for IT ubiquity?. Nurs Manage. Sep. 2006;37(9):12. 6. [pmid: 16983231].
2525 Simpson RL. Information technology: building nursing intellectual capital for the information age. Nurs Adm Q. Jan-Mar. 2007;31(1):84-8. [pmid: 17198124].
2526 Sims T, Holmes TH, Bravata DM, Garber AM, Nelson LM, Goldstein MK. Simple counts of ADL dependencies do not adequately reflect older adults' preferences toward states of functional impairment. J Clin Epidemiol. Dec. 2008;61(12):1261-70. [pmid: 18722749].
2527 Sims TL, Garber AM, Miller DE, Mahlow PT, Bravata DM, Goldstein MK. Multimedia quality of life assessment: advances with FLAIR. AMIA Annu Symp Proc. 2005:694-8.
2528 Singleton C, Stuart M. Measurement mischief: a critique of Reynolds, Nicolson and Hambly 2003. Dyslexia. Aug. 2003;9(3):151-60. discussion 67-76.
2529 Singleton JL, Morgan D, DiGello E, Wiles J, Rivers R. Vocabulary Use by Low, Moderate, and High ASL-Proficient Writers Compared to Hearing ESL and Monolingual Speakers. J Deaf Stud Deaf Educ. Winter. 2004;9(1):86-103. [pmid: 15304404].
2530 Sinha R, Vanathi M, Sharma N, Titiyal JS, Vajpayee RB, Tandon R. Outcome of penetrating keratoplasty in patients with bilateral corneal blindness. Eye. Apr. 2005;19(4):451-4. [pmid: 15319790].
2531 Skeels MM, Kurth A, Clausen M, Severynen A, Garcia-Smith H. CARE+ user study: usability and attitudes towards a tablet pc computer counseling tool for HIV+ men and women. AMIA Annu Symp Proc. 2006:729-33.
2532 Skiba DJ. Informatics competencies. Nurs Educ Perspect. Nov-Dec. 2004;25(6):312. [pmid: 15675380].
2533 Skiba DJ. Preparing for evidence-based practice: revisiting information literacy. Nurs Educ Perspect. Sep-Oct. 2005;26(5):310-1. [pmid: 16295311].
2534 Skiba DJ. It's all about you: my resolutions for 2007. Nurs Educ Perspect. Jan-Feb. 2007;28(1):44-5. [pmid: 17460849].
2535 Skiba DJ. Moving forward: the informatics agenda. Nurs Educ Perspect. Sep-Oct. 2008;29(5):300-1. [pmid: 18834061].
2536 Skiba DJ, Barton AJ. Adapting your teaching to accommodate the net generation of learners. Online J Issues Nurs. 2006;11(2):5. [pmid: 17201579].
2537 Skiba DJ, DuLong D. Using TIGER vision to move your agenda forward. Nurs Manage. Mar. 2008;39(3):14-6. [pmid: 18414219].
2538 Skibs DJ. The millennials: have they arrived at your school of nursing?. Nurs Educ Perspect. Nov-Dec. 2005;26(6):370-1. [pmid: 16430005].
2539 Sleath BL, Jackson E, Thomas KC, Galloway J, Dumain L, Thorpe J, et al. Literacy and perceived barriers to medication taking among homeless mothers and their children. Am J Health Syst Pharm. Feb. 15. 2006;63(4):346-51. [pmid: 16452520].
2540 Smedley A. The importance of informatics competencies in nursing: an Australian perspective. Comput Inform Nurs. Mar-Apr. 2005;23(2):106-10. [pmid: 15772512].
2541 Smerecnik CM, Mesters I. Validating the Medical Data Interpretation Test in a Dutch population. Patient Educ Couns. Nov. 2007;68(3):287-90. [pmid: 17686603].
2542 Smit F, Ederveen A, Cuijpers P, Deeg D, Beekman A. Opportunities for cost-effective prevention of late-life depression: an epidemiological approach. Arch Gen Psychiatry. Mar. 2006;63(3):290-6. [pmid: 16520434].
2543 Smith AL. Health policy and the coloring of an American male crisis: a perspective on community-based health services. Am J Public Health. May. 2003;93(5):749-52. [pmid: 12721136].
2544 Smith B, Chu LK, Smith TC, Amoroso PJ, Boyko EJ, Hooper TI, et al. Challenges of self-reported medical conditions and electronic medical records among members of a large military cohort. BMC Med Res Methodol. 2008;8:37. [pmid: 18644098].
2545 Smith JA, Bollen C. A focus on health promotion and prevention through the development of the national men's health policy. Health Promot J Austr. Aug. 2009;20(2):98-101. [pmid: 19642956].
2546 Smith JL, Haggerty J. Literacy in primary care populations: is it a problem?. Can J Public Health. Nov-Dec. 2003;94(6):408-12. [pmid: 14700237].
2547 Smith RD. The application of information technology in the teaching of veterinary epidemiology and public health. J Vet Med Educ. Winter. 2003;30(4):344-50. [pmid: 14976620].
2548 Smith SK, Trevena L, Nutbeam D, Barratt A, McCaffery KJ. Information needs and preferences of low and high literacy consumers for decisions about colorectal cancer screening: utilizing a linguistic model. Health Expect. Jun. 2008;11(2):123-36. [pmid: 18494957].
2549 Smith WR, Betancourt JR, Wynia MK, Bussey-Jones J, Stone VE, Phillips CO, et al. Recommendations for teaching about racial and ethnic disparities in health and health care. Ann Intern Med. Nov. 6. 2007;147(9):654-65. [pmid: 17975188].
2550 Smith-Spark JH, Fawcett AJ, Nicolson RI, Fisk JE. Dyslexic students have more everyday cognitive lapses. Memory. Mar. 2004;12(2):174-82. [pmid: 15250182].
2551 Smolderen KG, Pelle AJ, Kupper N, Mols F, Denollet J. Impact of peripheral arterial disease on health status: a comparison with chronic heart failure. J Vasc Surg. Dec. 2009;50(6):1391-8. [pmid: 19958988].
2552 Smylie J, Williams L, Cooper N. Culture-based literacy and Aboriginal health. Can J Public Health. May-Jun. 2. 2006;97:S21-5. [pmid: 16805157].
2553 Smythe I, Everatt J, Al-Menaye N, He X, Capellini S, Gyarmathy E, et al. Predictors of word-level literacy amongst Grade 3 children in five diverse languages. Dyslexia. Aug. 2008;14(3):170-87. [pmid: 18697190].
2554 Smythe P, Annett M. Phonology and handedness in primary school: predictions of the right shift theory. J Child Psychol Psychiatry. Feb. 2006;47(2):205-12. [pmid: 16423151].
2555 Snow CE, Beals DE. Mealtime talk that supports literacy development. New Dir Child Adolesc Dev. Spring. 2006;(111):51-66. [pmid: 16646499].
2556 Snowling MJ. Specific disorders and broader phenotypes: the case of dyslexia. Q J Exp Psychol (Colchester). Jan. 2008;61(1):142-56.
2557 Snowling MJ, Hulme C. A critique of claims from Reynolds, Nicolson & Hambly (2003) that DDAT is an effective treatment for children with reading difficulties--‘lies, damned lies and (inappropriate) statistics’?. Dyslexia. May. 2003;9(2):127-33. discussion 34-5. [pmid: 12775086].
2558 Snowling MJ, Muter V, Carroll J. Children at family risk of dyslexia: a follow-up in early adolescence. J Child Psychol Psychiatry. Jun. 2007;48(6):609-18. [pmid: 17537077].
2559 Snyder RA, Fields WL. Measuring hospital readiness for information technology (IT) innovation: A multisite study of the Organizational Information Technology Innovation Readiness Scale. J Nurs Meas. Spring-Summer. 2006;14(1):45-55. [pmid: 16764177].
2560 Sobel RM, Paasche-Orlow MK, Waite KR, Rittner SS, Wilson EA, Wolf MS. Asthma 1-2-3: a low literacy multimedia tool to educate African American adults about asthma. J Community Health. Aug. 2009;34(4):321-7. [pmid: 19353250].
2561 Sorensen L, Gavier M, Helleso R. Latina breast cancer survivors informational needs: information partners. Stud Health Technol Inform. 2009;146:727. [pmid: 19592948].
2562 Sorrell JM. Health literacy in older adults. J Psychosoc Nurs Ment Health Serv. Mar. 2006;44(3):17-20. [pmid: 16583872].
2563 Sorrell JT, McNeil DW, Gochenour LL, Jackson CR. Evidence-based patient education: knowledge transfer to endodontic patients. J Dent Educ. Nov. 2009;73(11):1293-305. [pmid: 19910479].
2564 Soto G, Hartmann E, Wilkins DP. Exploring the elements of narrative that emerge in the interactions between an 8-year-old child who uses an AAC device and her teacher. Augment Altern Commun. Dec. 2006;22(4):231-41. [pmid: 17127612].
2565 Sotoudeh G, Khosravi S, Khajehnasiri F, Khalkhali HR. High prevalence of overweight and obesity in women of Islamshahr, Iran. Asia Pac J Clin Nutr. 2005;14(2):169-72. [pmid: 15927935].
2566 Spalla TL, Nininger JM, Daley LK. You've got mail: a new tool to help millennials prepare for the national council licensure examination. Nurse Educ. Mar-Apr. 2007;32(2):52-4. [pmid: 17496817].
2567 Spallek H, Etzel KR, Maher BS. Dental school applicants' use of website information during the application process. J Dent Educ. Dec. 2005;69(12):1359-67. [pmid: 16352772].
2568 Sparks L, Nussbaum JF. Health literacy and cancer communication with older adults. Patient Educ Couns. Jun. 2008;71(3):345-50. [pmid: 18374536].
2569 Sparks RL, Patton J, Ganschow L, Humbach N, Javorsky J. Native language predictors of foreign language proficiency and foreign language aptitude. Ann Dyslexia. Jun. 2006;56(1):129-60. [pmid: 17849211].
2570 Spear-Swerling L, Brucker PO, Alfano MP. Teachers' literacy-related knowledge and self-perceptions in relation to preparation and experience. Ann Dyslexia. Dec. 2005;55(2):266-96. [pmid: 17849196].
2571 Specht K, Hugdahl K, Ofte S, Nygard M, Bjornerud A, Plante E, et al. Brain activation on pre-reading tasks reveals at-risk status for dyslexia in 6-year-old children. Scand J Psychol. Feb. 2009;50(1):79-91. [pmid: 18826418].
2572 Spector F, Maurer D. The colour of Os: naturally biased associations between shape and colour. Perception. 2008;37(6):841-7. [pmid: 18686703].
2573 Spencer EJ, Schuele CM, Guillot KM, Lee MW. Phonemic awareness skill of speech-language pathologists and other educators. Lang Speech Hear Serv Sch. Oct. 2008;39(4):512-20. [pmid: 18820092].
2574 Spencer K. Predicting children's word-spelling difficulty for common English words from measures of orthographic transparency, phonemic and graphemic length and word frequency. Br J Psychol. May. 2007;98(Pt 2):305-38. [pmid: 17456275].
2575 Spencer LJ, Barker BA, Tomblin JB. Exploring the language and literacy outcomes of pediatric cochlear implant users. Ear Hear. Jun. 2003;24(3):236-47. [pmid: 12799546].
2576 Spencer-Smith M, Leventer R, Jacobs R, Luca CD, Anderson V. Neuropsychological profile of children with subcortical band heterotopia. Dev Med Child Neurol. Nov. 2009;51(11):909-16. [pmid: 19416314].
2577 Speros C. Health literacy: concept analysis. J Adv Nurs. Jun. 2005;50(6):633-40. [pmid: 15926968].
2578 Spira EG, Bracken SS, Fischel JE. Predicting improvement after first-grade reading difficulties: the effects of oral language, emergent literacy, and behavior skills. Dev Psychol. Jan. 2005;41(1):225-34. [pmid: 15656751].
2579 Spira EG, Fischel JE. The impact of preschool inattention, hyperactivity, and impulsivity on social and academic development: a review. J Child Psychol Psychiatry. Jul. 2005;46(7):755-73. [pmid: 15972069].
2580 Spooner SA. Preschoolers, computers, and school readiness: are we on to something?. Pediatrics. Sep. 2004;114(3):852. [pmid: 15342862].
2581 Srinivasan M, McElvany M, Shay JM, Shavelson RJ, West DC. Measuring knowledge structure: reliability of concept mapping assessment in medical education. Acad Med. Dec. 2008;83(12):1196-203. [pmid: 19202500].
2582 St John W, Wallis M, James H, McKenzie S, Guyatt S. Targeting community-dwelling urinary incontinence sufferers: a multidisciplinary community based model for conservative continence services. Contemp Nurse. Oct. 2004;17(3):211-22. [pmid: 15551672].
2583 St Pierre RG, Ricciuti AE, Rimdzius TA. Effects of a family literacy program on low-literate children and their parents: findings from an evaluation of the Even Start family literacy program. Dev Psychol. Nov. 2005;41(6):953-70. [pmid: 16351339].
2584 Stableford S, Mettger W. Plain language: a strategic response to the health literacy challenge. J Public Health Policy. 2007;28(1):71-93. [pmid: 17363939].
2585 Staiger TO, Jarvik JG, Deyo RA, Martin B, Braddock CH 3rd. BRIEF REPORT: Patient-physician agreement as a predictor of outcomes in patients with back pain. J Gen Intern Med. Oct. 2005;20(10):935-7. [pmid: 16191141].
2586 Stallings KD, Bacon TJ. Health professions education to promote health literacy: leverage points and new opportunities. N C Med J. Sep-Oct. 2007;68(5):368-71. [pmid: 18183764].
2587 Stallwood L. Relationship between caregiver knowledge and socioeconomic factors on glycemic outcomes of young children with diabetes. J Spec Pediatr Nurs. Jul. 2006;11(3):158-65. [pmid: 16774526].
2588 Standen PJ, Brown DJ, Anderton N, Battersby S. Systematic evaluation of current control devices used by people with intellectual disabilities in non-immersive virtual environments. Cyberpsychol Behav. Oct. 2006;9(5):608-13. [pmid: 17034329].
2589 Stansbury K, Schumacher M. An exploration of mental health literacy among African American clergy. J Gerontol Soc Work. 2008;51(1-2):126-42. [pmid: 18826072].
2590 Stansbury KL, Brown-Hughes T, Harley DA. Rural African American clergy: are they literate on late-life depression?. Aging Ment Health. Jan. 2009;13(1):9-16. [pmid: 19197685].
2591 Staskowski M, Zagaiski K. Reaching for the stars: SLPs shine on literacy teams. Semin Speech Lang. Aug. 2003;24(3):199-213. [pmid: 14533053].
2592 Steen DM, Meyer P. Modernization and the male-female suicide ratio in India 1967-1997: divergence or convergence?. Suicide Life Threat Behav. Summer. 2004;34(2):147-59. [pmid: 15191271].
2593 Stein AD, Behrman JR, DiGirolamo A, Grajeda R, Martorell R, Quisumbing A, et al. Schooling, educational achievement, and cognitive functioning among young Guatemalan adults. Food Nutr Bull. Jun. 2005;26(2 Suppl 1):S46-54. [pmid: 16060211].
2594 Stein DJ, Seedat S. From research methods to clinical practice in psychiatry: challenges and opportunities in the developing world. Int Rev Psychiatry. Oct. 2007;19(5):573-81. [pmid: 17896236].
2595 Stein K. Cultural literacy in health care. J Am Diet Assoc. Nov. 2004;104(11):1657-9. [pmid: 15499349].
2596 Steinhauser KE, Alexander SC, Byock IR, George LK, Olsen MK, Tulsky JA. Do preparation and life completion discussions improve functioning and quality of life in seriously ill patients? Pilot randomized control trial. J Palliat Med. Nov. 2008;11(9):1234-40. [pmid: 19021487].
2597 Steinman BA, Pynoos J, Nguyen AQ. Fall risk in older adults: roles of self-rated vision, home modifications, and limb function. J Aging Health. Aug. 2009;21(5):655-76. [pmid: 19494362].
2598 Stepankova O, Engova D. Professional competence and computer literacy in e-age, focus on healthcare. Methods Inf Med. 2006;45(3):300-4. [pmid: 16685340].
2599 Stephens TT, Oriuwa CL, Uzoho M. Enhancing participation of women of child-bearing age in a literacy for health project in southeastern Nigeria. Trop Doct. Jan. 1999;29(1):12-8. [pmid: 10418274].
2600 Stephenson L. Health literacy: are you doing enough to communicate with your patients?. Iowa Med. Jul-Aug. 2006;96(4):16-7.
2601 Stephenson PL, Green BF, Wallace RL, Earl MF, Orick JT, Taylor MV. Community partnerships for health information training: medical librarians working with health-care professionals and consumers in Tennessee. Health Info Libr J. Jun. 1. 2004;21:20-6. [pmid: 15186287].
2602 Stewart L. A neurocognitive approach to music reading. Ann N Y Acad Sci. Dec. 2005;1060:377-86. [pmid: 16597789].
2603 Stewart L, Henson R, Kampe K, Walsh V, Turner R, Frith U. Becoming a pianist. An fMRI study of musical literacy acquisition. Ann N Y Acad Sci. Nov. 2003;999:204-8. [pmid: 14681142].
2604 Stewart R, Powell J, Prince M, Mann A. ACE genotype and cognitive decline in an African-Caribbean population. Neurobiol Aging. Nov-Dec. 2004;25(10):1369-75. [pmid: 15465635].
2605 Stilwell G, Reynolds PJ, Parameswaran V, Blizzard L, Greenaway TM, Burgess JR. The influence of gestational stage on urinary iodine excretion in pregnancy. J Clin Endocrinol Metab. May. 2008;93(5):1737-42. [pmid: 18285419].
2606 Stineman MG, Wechsler B, Ross R, Maislin G. A method for measuring quality of life through subjective weighting of functional status. Arch Phys Med Rehabil. Apr. 2003;84(4 Suppl 2):S15-22. [pmid: 12692767].
2607 Stjernsward S, Ostman M. Potential of e-health in relation to depression: short survey of previous research. J Psychiatr Ment Health Nurs. Dec. 2006;13(6):698-703. [pmid: 17087672].
2608 Stobel-Richter Y, Beutel ME, Finck C, Brahler E. The ‘wish to have a child’, childlessness and infertility in Germany. Hum Reprod. Oct. 2005;20(10):2850-7. [pmid: 15958401].
2609 Stock SE, Davies DK, Davies KR, Wehmeyer ML. Evaluation of an application for making palmtop computers accessible to individuals with intellectual disabilities. J Intellect Dev Disabil. Mar. 2006;31(1):39-46. [pmid: 16766321].
2610 Stock SE, Davies DK, Wehmeyer ML, Palmer SB. Evaluation of cognitively accessible software to increase independent access to cellphone technology for people with intellectual disability. J Intellect Disabil Res. Dec. 2008;52(12):1155-64. [pmid: 18647214].
2611 Stone CA, May AL. The accuracy of academic self-evaluations in adolescents with learning disabilities. J Learn Disabil. Jul-Aug. 2002;35(4):370-83. [pmid: 15493246].
2612 Stonecypher K. Creating a patient education tool. J Contin Educ Nurs. Oct. 2009;40(10):462-7. [pmid: 19831328].
2613 Stoodley CJ, Fawcett AJ, Nicolson RI, Stein JF. Impaired balancing ability in dyslexic children. Exp Brain Res. Dec. 2005;167(3):370-80. [pmid: 16044303].
2614 Stoodley CJ, Fawcett AJ, Nicolson RI, Stein JF. Balancing and pointing tasks in dyslexic and control adults. Dyslexia. Nov. 2006;12(4):276-88. [pmid: 17152343].
2615 Stoodley CJ, Harrison EP, Stein JF. Implicit motor learning deficits in dyslexic adults. Neuropsychologia. 2006;44(5):795-8. [pmid: 16125207].
2616 Stoodley CJ, Hill PR, Stein JF, Bishop DV. Auditory event-related potentials differ in dyslexics even when auditory psychophysical performance is normal. Brain Res. Nov. 22. 2006;1121(1):190-9. [pmid: 17010945].
2617 Stoodley CJ, Ray NJ, Jack A, Stein JF. Implicit learning in control, dyslexic, and garden-variety poor readers. Ann N Y Acad Sci. Dec. 2008;1145:173-83. [pmid: 19076396].
2618 Stoodley CJ, Stein JF. A processing speed deficit in dyslexic adults? Evidence from a peg-moving task. Neurosci Lett. May. 22. 2006;399(3):264-7. [pmid: 16500025].
2619 Stoop AP, van't Riet A, Berg M. Using information technology for patient education: realizing surplus value?. Patient Educ Couns. Aug. 2004;54(2):187-95. [pmid: 15288913].
2620 Stopforth L. Driving the roll out. Nurses and new communication technologies. Nurs N Z. Nov. 2006;12(10):17. [pmid: 17319204].
2621 Strasburger VC. Adolescents, sex, and the media: ooooo, baby, baby-a Q & A. Adolesc Med Clin. Jun. 2005;16(2):269-88. vii. [pmid: 16111618].
2622 Stroud SD, Smith CA, Erkel EA. Personal digital assistant use by nurse practitioners: a descriptive study. J Am Acad Nurse Pract. Jan. 2009;21(1):31-8. [pmid: 19125893].
2623 Struthers R, Baker M, Savik K. Cardiovascular risk factors among Native American women Inter-Tribal Heart Project participants. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2006;35(4):482-90.
2624 Stryker JE, Emmons KM, Viswanath K. Uncovering differences across the cancer control continuum: a comparison of ethnic and mainstream cancer newspaper stories. Prev Med. Jan. 2007;44(1):20-5. [pmid: 16949141].
2625 Stuck AE, Kharicha K, Dapp U, Anders J, von Renteln-Kruse W, Meier-Baumgartner HP, et al. Development, feasibility and performance of a health risk appraisal questionnaire for older persons. BMC Med Res Methodol. 2007;7:1. [pmid: 17217545].
2626 Sturgis P, Cooper H, Fife-Schaw C. Attitudes to biotechnology: estimating the opinions of a better-informed public. New Genet Soc. Apr. 2005;24(1):31-56. [pmid: 16552916].
2627 Sturm JM, Spadorcia SA, Cunningham JW, Cali KS, Staples A, Erickson K, et al. What happens to reading between first and third grade? Implications for students who use AAC. Augment Altern Commun. Mar. 2006;22(1):21-36. [pmid: 17114156].
2628 Subba N. Demographic assessment on vasectomy clients of Sankhuwasabha Nepal. Nepal Med Coll J. Dec. 2003;5(2):98-9. [pmid: 15024777].
2629 Sudha G, Nirupa C, Rajasakthivel M, Sivasusbramanian S, Sundaram V, Bhatt S, et al. Factors influencing the care-seeking behaviour of chest symptomatics: a community-based study involving rural and urban population in Tamil Nadu, South India. Trop Med Int Health. Apr. 2003;8(4):336-41. [pmid: 12667153].
2630 Sudore RL, Landefeld CS, Barnes DE, Lindquist K, Williams BA, Brody R, et al. An advance directive redesigned to meet the literacy level of most adults: a randomized trial. Patient Educ Couns. Dec. 2007;69(1-3):165-95. [pmid: 17942272].
2631 Sudore RL, Landefeld CS, Pantilat SZ, Noyes KM, Schillinger D. Reach and impact of a mass media event among vulnerable patients: the Terri Schiavo story. J Gen Intern Med. Nov. 2008;23(11):1854-7. [pmid: 18716849].
2632 Sudore RL, Landefeld CS, Williams BA, Barnes DE, Lindquist K, Schillinger D. Use of a modified informed consent process among vulnerable patients: a descriptive study. J Gen Intern Med. Aug. 2006;21(8):867-73. [pmid: 16881949].
2633 Sudore RL, Mehta KM, Simonsick EM, Harris TB, Newman AB, Satterfield S, et al. Limited literacy in older people and disparities in health and healthcare access. J Am Geriatr Soc. May. 2006;54(5):770-6. [pmid: 16696742].
2634 Sudore RL, Schickedanz AD, Landefeld CS, Williams BA, Lindquist K, Pantilat SZ, et al. Engagement in multiple steps of the advance care planning process: a descriptive study of diverse older adults. J Am Geriatr Soc. Jun. 2008;56(6):1006-13. [pmid: 18410324].
2635 Sudore RL, Yaffe K, Satterfield S, Harris TB, Mehta KM, Simonsick EM, et al. Limited literacy and mortality in the elderly: the health, aging, and body composition study. J Gen Intern Med. Aug. 2006;21(8):806-12. [pmid: 16881938].
2636 Suleiman C, O'Connell DC. Gender differences in the media interviews of Bill and Hillary Clinton. J Psycholinguist Res. Jan. 2008;37(1):33-48. [pmid: 17447143].
2637 Suler J. In class and online: using discussion boards in teaching. Cyberpsychol Behav. Aug. 2004;7(4):395-401. [pmid: 15331026].
2638 Sullivan HW, Klassen AC. Nutrition-related cancer prevention attitudes in low-income women. Prev Med. Aug-Sep. 2007;45(2-3):139-45. [pmid: 17604830].
2639 Sullivan LW. Promoting health literacy and health behaviors. Breastfeed Med. Oct. 1. 2009;4:S67. [pmid: 19827930].
2640 Sullivan MC, Margaret MM. Perinatal morbidity, mild motor delay, and later school outcomes. Dev Med Child Neurol. Feb. 2003;45(2):104-12. [pmid: 12578236].
2641 Sur D, Ali M, von Seidlein L, Manna B, Deen JL, Acosta CJ, et al. Comparisons of predictors for typhoid and paratyphoid fever in Kolkata, India. BMC Public Health. 2007;7:289. [pmid: 17935611].
2642 Susser SR, McCusker J, Belzile E. Comorbidity information in older patients at an emergency visit: self-report vs. administrative data had poor agreement but similar predictive validity. J Clin Epidemiol. May. 2008;61(5):511-5. [pmid: 18394546].
2643 Sutcliffe PA, Bishop DV, Houghton S, Taylor M. Effect of attentional state on frequency discrimination: a comparison of children with ADHD on and off medication. J Speech Lang Hear Res. Oct. 2006;49(5):1072-84. [pmid: 17077215].
2644 Sutton PD, Mathews TJ. Trends in characteristics of births by State: United States, 1990, 1995, and 2000-2002. Natl Vital Stat Rep. May. 10. 2004;52(19):1-152. [pmid: 15151252].
2645 Svanaes D, Das A, Alsos OA. The contextual nature of usability and its relevance to medical informatics. Stud Health Technol Inform. 2008;136:541-6. [pmid: 18487787].
2646 Svirko E, Mellanby J, Impey L. The association between cord pH at birth and intellectual function in childhood. Early Hum Dev. Jan. 2008;84(1):37-41. [pmid: 17379460].
2647 Swanson HL, Rosston K, Gerber M, Solari E. Influence of oral language and phonological awareness on children's bilingual reading. J Sch Psychol. Aug. 2008;46(4):413-29. [pmid: 19083366].
2648 Swanson TJ, Hodson BW, Schommer-Aikins M. An examination of phonological awareness treatment outcomes for seventh-grade poor readers from a bilingual community. Lang Speech Hear Serv Sch. Oct. 2005;36(4):336-45. [pmid: 16389705].
2649 Swanwick R, Watson L. Parents sharing books with young deaf children in spoken english and in BSL: the common and diverse features of different language settings. J Deaf Stud Deaf Educ. Summer. 2007;12(3):385-405. [pmid: 17434904].
2650 Sweeney AE. Social and ethical dimensions of nanoscale science and engineering research. Sci Eng Ethics. Jul. 2006;12(3):435-64. [pmid: 16909148].
2651 Sweeney NM, Saarmann L, Flagg J, Seidman R. The keys to successful online continuing education programs for nurses. J Contin Educ Nurs. Jan. 2008;39(1):34-41. [pmid: 18286929].
2652 Sylva K, Scott S, Totsika V, Ereky-Stevens K, Crook C. Training parents to help their children read: a randomized control trial. Br J Educ Psychol. Sep. 2008;78(Pt 3):435-55. [pmid: 17999781].
2653 Tacker KA, Dobie S. MasterMind: Empower Yourself With Mental Health. A program for adolescents. J Sch Health. Jan. 2008;78(1):54-7. [pmid: 18177301].
2654 Tak SH, Hong SH. Use of the Internet for health information by older adults with arthritis. Orthop Nurs. Mar-Apr. 2005;24(2):134-8. [pmid: 15902012].
2655 Takele L, Belachew T, Bekele T. Iodine concentration in salt at household and retail shop levels in Shebe town, south west Ethiopia. East Afr Med J. Oct. 2003;80(10):532-9. [pmid: 15250627].
2656 Tallal P. Improving language and literacy is a matter of time. Nat Rev Neurosci. Sep. 2004;5(9):721-8. [pmid: 15322530].
2657 Tan E, Yates KM. Use of information technology in New Zealand emergency departments. Emerg Med Australas. Dec. 2007;19(6):515-22. [pmid: 18021103].
2658 Tan EL, Stark H, Lowinger JS, Ringland C, Ward R, Pearson SA. Information sources used by New South Wales cancer clinicians: a qualitative study. Intern Med J. Nov. 2006;36(11):711-7. [pmid: 17040357].
2659 Tandon R, Verma K, Vanathi M, Pandey RM, Vajpayee RB. Factors affecting eye donation from postmortem cases in a tertiary care hospital. Cornea. Aug. 2004;23(6):597-601. [pmid: 15256999].
2660 T'Ang J, Chan C, Chan NF, Ng CB, Tse K, Lau L. A survey of elderly diabetic patients attending a community clinic in Hong Kong. Patient Educ Couns. Mar. 1999;36(3):259-70. [pmid: 14528561].
2661 Tang YH, Pang SM, Chan MF, Yeung GS, Yeung VT. Health literacy, complication awareness, and diabetic control in patients with type 2 diabetes mellitus. J Adv Nurs. Apr. 2008;62(1):74-83. [pmid: 18352966].
2662 Tannery NH, Wessel CB, Epstein BA, Gadd CS. Hospital nurses' use of knowledge-based information resources. Nurs Outlook. Jan-Feb. 2007;55(1):15-9. [pmid: 17289463].
2663 Tarnow KG, Mayo-Rejai R. Quick assessment of computer skills: setting the bar. Nurse Educ. Mar-Apr. 2005;30(2):50-1. [pmid: 15785338].
2664 Tarrant M, Dodgson JE, Law BV. A curricular approach to improve the information literacy and academic writing skills of part-time post-registration nursing students in Hong Kong. Nurse Educ Today. May. 2008;28(4):458-68. [pmid: 17826873].
2665 Tavasoli S, Heidarnazhad H, Kazemnejad A. Factors affecting patients' compliance to metered-dose inhaler drugs in two asthma clinics in Tehran, Iran. Iran J Allergy Asthma Immunol. Dec. 2006;5(4):187-93. [pmid: 17237572].
2666 Taveras EM, LaPelle N, Gupta RS, Finkelstein JA. Planning for health promotion in low-income preschool child care settings: focus groups of parents and child care providers. Ambul Pediatr. Nov-Dec. 2006;6(6):342-6. [pmid: 17116608].
2667 Tawil I, Marinaro J, Brown LH. Development and validation of a tool for assessing understanding of brain death. Prog Transplant. Sep. 2009;19(3):272-6. [pmid: 19813491].
2668 Taylor-Piliae RE, Froelicher ES. Measurement properties of Tai Chi exercise self-efficacy among ethnic Chinese with coronary heart disease risk factors: a pilot study. Eur J Cardiovasc Nurs. Dec. 2004;3(4):287-94. [pmid: 15572017].
2669 Teghtsoonian K. Depression and mental health in neoliberal times: a critical analysis of policy and discourse. Soc Sci Med. Jul. 2009;69(1):28-35. [pmid: 19427730].
2670 Teleki SS, Kanouse DE, Elliott MN, Hiatt L, de Vries H, Quigley DD. Understanding the reporting practices of CAHPS sponsors. Health Care Financ Rev. Spring. 2007;28(3):17-30. [pmid: 17645153].
2671 Teller H, Harney J. Views from the field: program directors' perceptions of teacher education and the education of students who are deaf or hard of hearing. Am Ann Deaf. Winter. 2005;150(5):470-9. [pmid: 16610479].
2672 Ternstrom S. Does the acoustic waveform mirror the voice?. Logoped Phoniatr Vocol. 2005;30(3-4):100-7. [pmid: 16287648].
2673 Terry PE, Masvaure TB, Gavin L. HIV/AIDS health literacy in Zimbabwe--focus group findings from university students. Methods Inf Med. 2005;44(2):288-92. [pmid: 15924194].
2674 Tessaro I, Rye S, Parker L, Trangsrud K, Mangone C, McCrone S, et al. Cookin' Up Health: developing a nutrition intervention for a rural Appalachian population. Health Promot Pract. Apr. 2006;7(2):252-7. [pmid: 16585148].
2675 Teutsch C. Patient-doctor communication. Med Clin North Am. Sep. 2003;87(5):1115-45. [pmid: 14621334].
2676 Thacker N, Shendurnikar N. Current status of polio eradication and future prospects. Indian J Pediatr. Mar. 2004;71(3):241-5. [pmid: 15080411].
2677 Thackeray R, Merrill RM, Neiger BL. Disparities in diabetes management practice between racial and ethnic groups in the United States. Diabetes Educ. Jul-Aug. 2004;30(4):665-75. [pmid: 15669782].
2678 Theisen V, Duquette D, Kardia S, Wang C, Beene-Harris R, Bach J. Blood Pressure Sunday: introducing genomics to the community through family history. Prev Chronic Dis. Apr. 2005;2(2):A23. [pmid: 15888234].
2679 Theriot JA, Franco SM, Sisson BA, Metcalf SC, Kennedy MA, Bada HS. The impact of early literacy guidance on language skills of 3-year-olds. Clin Pediatr (Phila). Mar. 2003;42(2):165-72. [pmid: 12659391].
2680 Therrell BL Jr. Ethical, legal and social issues in newborn screening in the United States. Southeast Asian J Trop Med Public Health. 3. 2003;34:52-8. [pmid: 15906695].
2681 Thomas DM, Ray SM, Morton FJ, Drew JS, Offutt G, Whitney CG, et al. Patient education strategies to improve pneumococcal vaccination rates: randomized trial. J Investig Med. May. 2003;51(3):141-8.
2682 Thomas N, Murray E, Rogstad KE. Confidentiality is essential if young people are to access sexual health services. Int J STD AIDS. Aug. 2006;17(8):525-9. [pmid: 16925898].
2683 Thomas P, Rutter PM. A computer literacy skills profile of pharmacists residing in two counties of England. Health Info Libr J. Dec. 2008;25(4):288-94. [pmid: 19076675].
2684 Thomas SP. Identifying and intervening with girls at risk for violence. J Sch Nurs. Jun. 2003;19(3):130-9. [pmid: 12755677].
2685 Thompson A, Hunt C, Issakidis C. Why wait? Reasons for delay and prompts to seek help for mental health problems in an Australian clinical sample. Soc Psychiatry Psychiatr Epidemiol. Oct. 2004;39(10):810-7. [pmid: 15669662].
2686 Thompson BW, Skiba DJ. Informatics in the nursing curriculum: a national survey of nursing informatics requirements in nursing curricula. Nurs Educ Perspect. Sep-Oct. 2008;29(5):312-7. [pmid: 18834062].
2687 Thompson CA, Craig HK, Washington JA. Variable production of African American English across oracy and literacy contexts. Lang Speech Hear Serv Sch. Jul. 2004;35(3):269-82. [pmid: 15248796].
2688 Thompson FE, McNeel TS, Dowling EC, Midthune D, Morrissette M, Zeruto CA. Interrelationships of added sugars intake, socioeconomic status, and race/ethnicity in adults in the United States: National Health Interview Survey, 2005. J Am Diet Assoc. Aug. 2009;109(8):1376-83. [pmid: 19631043].
2689 Thompson FE, Midthune D, Subar AF, McNeel T, Berrigan D, Kipnis V. Dietary intake estimates in the National Health Interview Survey, 2000: methodology, results, and interpretation. J Am Diet Assoc. Mar. 2005;105(3):352-63. quiz 487. [pmid: 15746822].
2690 Thompson HS, Wahl E, Fatone A, Brown K, Kwate NO, Valdimarsdottir H. Enhancing the readability of materials describing genetic risk for breast cancer. Cancer Control. Jul-Aug. 2004;11(4):245-53. [pmid: 15284716].
2691 Thompson L, Diaz J, Jenny A, Diaz A, Bruce N, Balmes J. Nxwisen, ntzarrin or ntzo'lin? Mapping children's respiratory symptoms among indigenous populations in Guatemala. Soc Sci Med. Oct. 2007;65(7):1337-50. [pmid: 17582669].
2692 Thomson MD, Hoffman-Goetz L. Readability and cultural sensitivity of web-based patient decision aids for cancer screening and treatment: a systematic review. Med Inform Internet Med. Dec. 2007;32(4):263-86. [pmid: 18072004].
2693 Thomson P, Dowding D, Swanson V, Bland R, Mair C, Morrison A, et al. A computerised guidance tree (decision aid) for hypertension, based on decision analysis: development and preliminary evaluation. Eur J Cardiovasc Nurs. Jun. 2006;5(2):146-9. [pmid: 16309966].
2694 Thorn F, Cruz AA, Machado AJ, Carvalho RA. Refractive status of indigenous people in the northwestern Amazon region of Brazil. Optom Vis Sci. Apr. 2005;82(4):267-72. [pmid: 15829854].
2695 Thornicroft G, Rose D, Kassam A. Discrimination in health care against people with mental illness. Int Rev Psychiatry. Apr. 2007;19(2):113-22. [pmid: 17464789].
2696 Thoroddsen A, Ehnfors M. Putting policy into practice: pre- and posttests of implementing standardized languages for nursing documentation. J Clin Nurs. Oct. 2007;16(10):1826-38. [pmid: 17880471].
2697 Thorp JA, O'Connor M, Belden B, Etzenhouser J, Hoffman EL, Jones PG. Effects of phenobarbital and multiple-dose corticosteroids on developmental outcome at age 7 years. Obstet Gynecol. Feb. 2003;101(2):363-73. [pmid: 12576262].
2698 Thoutenhoofd E. Cochlear implanted pupils in Scottish schools: 4-year school attainment data (2000-2004). J Deaf Stud Deaf Educ. Spring. 2006;11(2):171-88. [pmid: 16452610].
2699 Thrall TH. Dump the mumbo-jumbo. Hosp Health Netw. Oct. 2004;78(10):70-2. 4. [pmid: 15536740].
2700 Thumboo J, Wee HL, Cheung YB, Machin D, Luo N, Fong KY. Development of a Smiling Touchscreen multimedia program for HRQoL assessment in subjects with varying levels of literacy. Value Health. Sep-Oct. 2006;9(5):312-9. [pmid: 16961549].
2701 Tian Y, Robinson JD. Incidental health information use and media complementarity: a comparison of senior and non-senior cancer patients. Patient Educ Couns. Jun. 2008;71(3):340-4. [pmid: 18372141].
2702 Tieman J, Rawlings D. Exploring nurses' attitudes to, and use of, an online palliative care resource. Int J Palliat Nurs. Dec. 2008;14(12):587-94. [pmid: 19104475].
2703 Tierney MC, Yao C, Kiss A, McDowell I. Neuropsychological tests accurately predict incident Alzheimer disease after 5 and 10 years. Neurology. Jun. 14. 2005;64(11):1853-9. [pmid: 15955933].
2704 Tilghman J, Raley D, Conway JJ. Family nurse practitioner students utilization of Personal Digital Assistants (PDAs): implications for practice. ABNF J. Summer. 2006;17(3):115-7. [pmid: 16948365].
2705 Timmons S. Nurses resisting information technology. Nurs Inq. Dec. 2003;10(4):257-69. [pmid: 14622372].
2706 Tkacz VL, Metzger A, Pruchnicki MC. Health literacy in pharmacy. Am J Health Syst Pharm. May. 15. 2008;65(10):974-81. [pmid: 18463348].
2707 Tlauka M, Williams J, Williamson P. Spatial ability in secondary school students: intra-sex differences based on self-selection for physical education. Br J Psychol. Aug. 2008;99(Pt 3):427-40. [pmid: 18257970].
2708 Tod AM, Stringer E, Levery C, Dean J, Brown J. Rectal irrigation in the management of functional bowel disorders: a review. Br J Nurs. Jul. 26. Aug. 8. 2007;16(14):858-64. [pmid: 17851346].
2709 Tomaskova H, Slachtova H, Splichalova A. Methodical approach to data processing from a questionnaire survey. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Nov. 2003;147(1):101-7. [pmid: 15034613].
2710 Tombaugh TN. Test-retest reliable coefficients and 5-year change scores for the MMSE and 3MS. Arch Clin Neuropsychol. Jun. 2005;20(4):485-503. [pmid: 15896562].
2711 Tomlinson LM. Patient and practitioner literacy and women's health: a global view from the closing decade 1990-2000. Ethn Dis. Spring. 2003;13(2):248-58. [pmid: 12785423].
2712 Torppa M, Tolvanen A, Poikkeus AM, Eklund K, Lerkkanen MK, Leskinen E, et al. Reading development subtypes and their early characteristics. Ann Dyslexia. Jun. 2007;57(1):3-32. [pmid: 17849214].
2713 Torres RY, Marks R. Relationships among health literacy, knowledge about hormone therapy, self-efficacy, and decision-making among postmenopausal health. J Health Commun. Jan-Feb. 2009;14(1):43-55. [pmid: 19180370].
2714 Toumbourou JW, Hemphill SA, Tresidder J, Humphreys C, Edwards J, Murray D. Mental health promotion and socio-economic disadvantage: lessons from substance abuse, violence and crime prevention and child health. Health Promot J Austr. Dec. 2007;18(3):184-90. [pmid: 18201160].
2715 Townsend MS, Sylva K, Martin A, Metz D, Wooten-Swanson P. Improving readability of an evaluation tool for low-income clients using visual information processing theories. J Nutr Educ Behav. May-Jun. 2008;40(3):181-6. [pmid: 18457787].
2716 Treiman R. Spelling and dialect: comparisons between speakers of African American vernacular English and White speakers. Psychon Bull Rev. Apr. 2004;11(2):338-42. [pmid: 15260203].
2717 Treiman R. Linguistic constraints on literacy development: introduction to the special issue. J Exp Child Psychol. Oct. 2005;92(2):103-6. [pmid: 16105669].
2718 Treiman R, Kessler B. The role of letter names in the acquisition of literacy. Adv Child Dev Behav. 2003;31:105-35. [pmid: 14528660].
2719 Treiman R, Levin I, Kessler B. Learning of letter names follows similar principles across languages: Evidence from Hebrew. J Exp Child Psychol. Feb. 2007;96(2):87-106. [pmid: 17046016].
2720 Trenholm B, Mirenda P. Home and community literacy experiences of individuals with Down syndrome. Downs Syndr Res Pract. Jul. 2006;10(1):30-40. [pmid: 16869371].
2721 Treschan TA, Scheck T, Kober A, Fleischmann E, Birkenberg B, Petschnigg B, et al. The influence of protocol pain and risk on patients' willingness to consent for clinical studies: a randomized trial. Anesth Analg. Feb. 2003;96(2):498-506. table of contents. [pmid: 12538203].
2722 Trifiletti LB, Shields WC, McDonald EM, Walker AR, Gielen AC. Development of injury prevention materials for people with low literacy skills. Patient Educ Couns. Dec. 2006;64(1-3):119-27. [pmid: 16723205].
2723 Trinder VM, Fleet GE, Gray AE. Evaluating the impact of library user training programmes across Thames Valley Strategic Health Authority in the UK. Health Info Libr J. Mar. 2007;24(1):34-40. [pmid: 17331142].
2724 Trivedi MH, Daly EJ, Kern JK, Grannemann BD, Sunderajan P, Claassen CA. Barriers to implementation of a computerized decision support system for depression: an observational report on lessons learned in “real world” clinical settings. BMC Med Inform Decis Mak. 2009;9:6. [pmid: 19159458].
2725 Troy AR, Grove JM, O'Neil-Dunne JP, Pickett ST, Cadenasso ML. Predicting opportunities for greening and patterns of vegetation on private urban lands. Environ Manage. Sep. 2007;40(3):394-412. [pmid: 17602257].
2726 Tsai CC. Adolescents' perceptions toward the internet: a 4-T framework. Cyberpsychol Behav. Aug. 2004;7(4):458-63. [pmid: 15331033].
2727 Tsai JH. Use of computer technology to enhance immigrant families' adaptation. J Nurs Scholarsh. 2006;38(1):87-93. [pmid: 16579329].
2728 Tsai SY, Lee HC, Chen CC, Huang YL. Cognitive impairment in later life in patients with early-onset bipolar disorder. Bipolar Disord. Dec. 2007;9(8):868-75. [pmid: 18076536].
2729 Tse MM, Choi KC, Leung RS. E-health for older people: the use of technology in health promotion. Cyberpsychol Behav. Aug. 2008;11(4):475-9. [pmid: 18721097].
2730 Turner S, Alborz A. Academic attainments of children with Down's syndrome: a longitudinal study. Br J Educ Psychol. Dec. 2003;73(Pt 4):563-83. [pmid: 14713378].
2731 Turner S, Alborz A, Gayle V. Predictors of academic attainments of young people with Down's syndrome. J Intellect Disabil Res. May. 2008;52(Pt 5):380-92. [pmid: 18205756].
2732 Turner T, Cull WL, Bayldon B, Klass P, Sanders LM, Frintner MP, et al. Pediatricians and health literacy: descriptive results from a national survey. Pediatrics. Nov. 3. 2009;124:S299-305. [pmid: 19861484].
2733 Tuttle D, Holloway R, Baird T, Sheehan B, Skelton WK. Electronic reporting to improve patient safety. Qual Saf Health Care. Aug. 2004;13(4):281-6. [pmid: 15289631].
2734 Uccelli P, Paez MM. Narrative and vocabulary development of bilingual children from kindergarten to first grade: developmental changes and associations among English and Spanish skills. Lang Speech Hear Serv Sch. Jul. 2007;38(3):225-36. [pmid: 17625049].
2735 Ugboma HA, Akani CI. Abdominal massage: another cause of maternal mortality. Niger J Med. Jul-Sep. 2004;13(3):259-62. [pmid: 15532228].
2736 Ulukanligil M, Seyrek A. Demographic and socio-economic factors affecting the physical development, haemoglobin and parasitic infection status of schoolchildren in Sanliurfa province, Turkey. Public Health. Mar. 2004;118(2):151-8. [pmid: 15037047].
2737 Unden AL, Elofsson S, Andreasson A, Hillered E, Eriksson I, Brismar K. Gender differences in self-rated health, quality of life, quality of care, and metabolic control in patients with diabetes. Gend Med. Jun. 2008;5(2):162-80. [pmid: 18573483].
2738 Underwood C, Serlemitsos E, Macwangi M. Health communication in multilingual contexts: a study of reading preferences, practices, and proficiencies among literate adults in Zambia. J Health Commun. Jun. 2007;12(4):317-37. [pmid: 17558786].
2739 Upton P, Eiser C. School experiences after treatment for a brain tumour. Child Care Health Dev. Jan. 2006;32(1):9-17. [pmid: 16398787].
2740 Urquhart C, Durbin J, Cumbers B. Evaluation of the KA24 (Knowledge Access 24) service for health and social care staff in London and the south-east of England. Part 2: qualitative. Health Info Libr J. Sep. 2006;23(3):159-68. [pmid: 16911122].
2741 Usha Kiran TS, Shylasree TS, Jayawickrama NS. Computer skills among trainee doctors. J Obstet Gynaecol. Jan. 2004;24(1):81-2. [pmid: 14675990].
2742 Usta MB, Mitchell EM, Gebreselassie H, Brookman-Amissah E, Kwizera A. Who is excluded when abortion access is restricted to twelve weeks? Evidence from Maputo, Mozambique. Reprod Health Matters. May. 2008;16(31 Suppl):14-7. [pmid: 18772079].
2743 Utley-Smith Q. 5 competencies needed by new baccalaureate graduates. Nurs Educ Perspect. Jul-Aug. 2004;25(4):166-70. [pmid: 15387509].
2744 Utz JC, Rausch CM, Fruth L, Thomas ME, van Breukelen F. Desert Survivors: the design and implementation of a television program to enhance local scientific literacy. Adv Physiol Educ. Mar. 2007;31(1):1-4. [pmid: 17327575].
2745 Vaidya VG, Sahasrabudhe BG, Jogi JA, Mitkar RP. Profile of sterilized women in urban slums and evaluation of motivational strategies. Indian J Public Health. Jan-Mar. 2003;47(1):31-3. [pmid: 14723293].
2746 Valaitis RK, O'Mara LM. Public health nurses' perceptions of mobile computing in a school program. Comput Inform Nurs. May-Jun. 2005;23(3):153-60. [pmid: 15900173].
2747 Valaitis RK, Sword WA, Jones B, Hodges A. Problem-based learning online: perceptions of health science students. Adv Health Sci Educ Theory Pract. Aug. 2005;10(3):231-52. [pmid: 16193403].
2748 Valenti WM. Health literacy, HIV and outcomes. AIDS Read. Mar. 2007;17(3):124-6. 8. [pmid: 17396329].
2749 Vallance JK, Taylor LM, Lavallee C. Suitability and readability assessment of educational print resources related to physical activity: implications and recommendations for practice. Patient Educ Couns. Aug. 2008;72(2):342-9. [pmid: 18450409].
2750 van Alphen P, de Bree E, Gerrits E, de Jong J, Wilsenach C, Wijnen F. Early language development in children with a genetic risk of dyslexia. Dyslexia. Nov. 2004;10(4):265-88. [pmid: 15573960].
2751 van Atteveldt N, Formisano E, Goebel R, Blomert L. Integration of letters and speech sounds in the human brain. Neuron. Jul. 22. 2004;43(2):271-82. [pmid: 15260962].
2752 van Atteveldt NM, Formisano E, Blomert L, Goebel R. The effect of temporal asynchrony on the multisensory integration of letters and speech sounds. Cereb Cortex. Apr. 2007;17(4):962-74. [pmid: 16751298].
2753 van Bruggen R, Gorter KJ, Stolk RP, Verhoeven RP, Rutten GE. Implementation of locally adapted guidelines on type 2 diabetes. Fam Pract. Dec. 2008;25(6):430-7. [pmid: 18718886].
2754 Van de Rijt BA, Van Luit JE. Milestones in the development of infant numeracy. Scand J Psychol. Mar. 1999;40(1):65-71. [pmid: 10216465].
2755 van de Sande M, Dippenaar H, Rutten GE. The relationship between patient education and glycaemic control in a South African township. Prim Care Diabetes. Jun. 2007;1(2):87-91. [pmid: 18632025].
2756 van de Walle E. Fertility transition, conscious choice, and numeracy. Demography. Nov. 1992;29(4):487-502. [pmid: 1483538].
2757 van den Brink JL, Moorman PW, de Boer MF, Hop WC, Pruyn JF, Verwoerd CD, et al. Impact on quality of life of a telemedicine system supporting head and neck cancer patients: a controlled trial during the postoperative period at home. J Am Med Inform Assoc. Mar-Apr. 2007;14(2):198-205. [pmid: 17213498].
2758 Van den Broeck W. Will the real discrepant learning disability please stand up?. J Learn Disabil. May-Jun. 2002;35(3):209-13. [pmid: 15493318].
2759 Van der Bijl C, Alant E, Lloyd L. A comparison of two strategies of sight word instruction in children with mental disability. Res Dev Disabil. Jan-Feb. 2006;27(1):43-55. [pmid: 15939572].
2760 Van der Elst W, Van Boxtel MP, Van Breukelen GJ, Jolles J. Detecting the significance of changes in performance on the Stroop Color-Word Test, Rey's Verbal Learning Test, and the Letter Digit Substitution Test: the regression-based change approach. J Int Neuropsychol Soc. Jan. 2008;14(1):71-80. [pmid: 18078533].
2761 van Hooren SA, van Boxtel MP, Valentijn SA, Bosma H, Ponds RW, Jolles J. Influence of cognitive functioning on functional status in an older population: 3-and 6-year follow-up of the Maastricht Aging Study. Int J Geriatr Psychiatry. Sep. 2005;20(9):883-8. [pmid: 16116574].
2762 van Kraayenoord CE, Elkins J. Learning difficulties in numeracy in Australia. J Learn Disabil. Jan-Feb. 2004;37(1):32-41. [pmid: 15493465].
2763 Van Moorsel G. Library-sponsored instruction improves core informatics competencies among allied health students: a research-based case study. J Allied Health. Fall. 2005;34(3):145-52. [pmid: 16252677].
2764 Van Reijswoud V, De Jager A. E-governance in the developing world in action: the case of DistrictNet in Uganda. World Hosp Health Serv. 2007;43(1):32-41. [pmid: 17621772].
2765 Van Servellen G, Brown JS, Lombardi E, Herrera G. Health literacy in low-income Latino men and women receiving antiretroviral therapy in community-based treatment centers. AIDS Patient Care STDS. Jun. 2003;17(6):283-98. [pmid: 12880492].
2766 van Servellen G, Carpio F, Lopez M, Garcia-Teague L, Herrera G, Monterrosa F, et al. Program to enhance health literacy and treatment adherence in low-income HIV-infected Latino men and women. AIDS Patient Care STDS. Nov. 2003;17(11):581-94. [pmid: 14746666].
2767 van Servellen G, Nyamathi A, Carpio F, Pearce D, Garcia-Teague L, Herrera G, et al. Effects of a treatment adherence enhancement program on health literacy, patient-provider relationships, and adherence to HAART among low-income HIV-positive Spanish-speaking Latinos. AIDS Patient Care STDS. Nov. 2005;19(11):745-59. [pmid: 16283835].
2768 van 't Veer JT, Kraan HF, Drosseart SH, Modde JM. Determinants that shape public attitudes towards the mentally ill: a Dutch public study. Soc Psychiatry Psychiatr Epidemiol. Apr. 2006;41(4):310-7. [pmid: 16501885].
2769 van Tol-Geerdink JJ, Stalmeier PF, van Lin EN, Schimmel EC, Huizenga H, van Daal WA, et al. Do prostate cancer patients want to choose their own radiation treatment?. Int J Radiat Oncol Biol Phys. Nov. 15. 2006;66(4):1105-11. [pmid: 16965869].
2770 Van Winghem J, Telfer B, Reid T, Ouko J, Mutunga A, Jama Z, et al. Implementation of a comprehensive program including psycho-social and treatment literacy activities to improve adherence to HIV care and treatment for a pediatric population in Kenya. BMC Pediatr. 2008;8:52. [pmid: 19025581].
2771 Vandelanotte C, De Bourdeaudhuij I, Brug J. Acceptability and feasibility of an interactive computer-tailored fat intake intervention in Belgium. Health Promot Int. Dec. 2004;19(4):463-70. [pmid: 15522947].
2772 VanderJagt DJ, Ganga S, Obadofin MO, Stanley P, Zimmerman M, Skipper BJ, et al. Comparison of the clock test and a questionnaire-based test for screening for cognitive impairment in Nigerians. West Afr J Med. Jul-Sep. 2006;25(3):212-8. [pmid: 17191421].
2773 Vanheusden K, Mulder CL, van der Ende J, van Lenthe FJ, Mackenbach JP, Verhulst FC. Young adults face major barriers to seeking help from mental health services. Patient Educ Couns. Oct. 2008;73(1):97-104. [pmid: 18584997].
2774 Vanslyke JG, Baum J, Plaza V, Otero M, Wheeler C, Helitzer DL. HPV and cervical cancer testing and prevention: knowledge, beliefs, and attitudes among Hispanic women. Qual Health Res. May. 2008;18(5):584-96. [pmid: 18337618].
2775 Vardavas CI, Kondilis BK, Patelarou E, Akrivos PD, Falagas ME. Health literacy and sources of health education among adolescents in Greece. Int J Adolesc Med Health. Apr-Jun. 2009;21(2):179-86. [pmid: 19702197].
2776 Vargas CM, Arevalo O. How dental care can preserve and improve oral health. Dent Clin North Am. Jul. 2009;53(3):399-420. [pmid: 19482119].
2777 Varkey AB, Manwell LB, Williams ES, Ibrahim SA, Brown RL, Bobula JA, et al. Separate and unequal: clinics where minority and nonminority patients receive primary care. Arch Intern Med. Feb. 9. 2009;169(3):243-50. [pmid: 19204215].
2778 Vassilev ZP, Marcus S, Jennis T, Ruck B, Swenson R, Rego G. Rapid communication: sociodemographic differences between counties with high and low utilization of a regional poison control center. J Toxicol Environ Health A. Oct. 24. 2003;66(20):1905-8. [pmid: 14514432].
2779 Vastag B. Low health literacy called a major problem. JAMA. May. 12. 2004;291(18):2181-2. [pmid: 15138230].
2780 Vavrus F. Girls' schooling in Tanzania: the key to HIV/AIDS prevention?. AIDS Care. Nov. 2006;18(8):863-71. [pmid: 17012074].
2781 Vegas E. Teacher labor markets in developing countries. Future Child. Spring. 2007;17(1):219-32. [pmid: 17407930].
2782 Ventura P, Kolinsky R, Querido JL, Fernandes S, Morais J. Is phonological encoding in naming influenced by literacy?. J Psycholinguist Res. Sep. 2007;36(5):341-60. [pmid: 17318434].
2783 Ventura P, Pattamadilok C, Fernandes T, Klein O, Morais J, Kolinsky R. Schooling in western culture promotes context-free processing. J Exp Child Psychol. Jun. 2008;100(2):79-88. [pmid: 18343399].
2784 Venturaa P, Kolinsky R, Fernandesa S, Queridoa L, Morais J. Lexical restructuring in the absence of literacy. Cognition. Nov. 2007;105(2):334-61. [pmid: 17113063].
2785 Vepa SS. Gender equity & human development. Indian J Med Res. Oct. 2007;126(4):328-40. [pmid: 18032808].
2786 Verhoeven L, Vermeer A. Literacy achievement of children with intellectual disabilities and differing linguistic backgrounds. J Intellect Disabil Res. Oct. 2006;50(Pt 10):725-38. [pmid: 16961702].
2787 Vidrine DJ, Amick BC 3rd, Gritz ER, Arduino RC. Functional status and overall quality of life in a multiethnic HIV-positive population. AIDS Patient Care STDS. Apr. 2003;17(4):187-97. [pmid: 12737642].
2788 Vidyasagar D. Global notes: counting the world's poor--how do we define poverty?. J Perinatol. Jun. 2006;26(6):325-7. [pmid: 16688201].
2789 Vijaya L, George R, Arvind H, Baskaran M, Raju P, Ramesh SV, et al. Prevalence and causes of blindness in the rural population of the Chennai Glaucoma Study. Br J Ophthalmol. Apr. 2006;90(4):407-10. [pmid: 16547314].
2790 Vikram BK, Khaja N, Udayashankar SG, Venkatesha BK, Manjunath D. Clinico-epidemiological study of complicated and uncomplicated chronic suppurative otitis media. J Laryngol Otol. May. 2008;122(5):442-6. [pmid: 17666139].
2791 Vileikyte L, Gonzalez JS, Leventhal H, Peyrot MF, Rubin RR, Garrow A, et al. Patient Interpretation of Neuropathy (PIN) questionnaire: an instrument for assessment of cognitive and emotional factors associated with foot self-care. Diabetes Care. Dec. 2006;29(12):2617-24. [pmid: 17130194].
2792 Vileikyte L, Rubin RR, Leventhal H. Psychological aspects of diabetic neuropathic foot complications: an overview. Diabetes Metab Res Rev. May-Jun. 1. 2004;20:S13-8. [pmid: 15150807].
2793 Villaire M, Mayer G. Chronic illness management and health literacy: an overview. J Med Pract Manage. Nov-Dec. 2007;23(3):177-81. [pmid: 18225822].
2794 Villaire M, Mayer G. Low health literacy: the impact on chronic illness management. Prof Case Manag. Jul-Aug. 2007;12(4):213-6. quiz 7-8. [pmid: 17667783].
2795 Villani VS, Olson CK, Jellinek MS. Media literacy for clinicians and parents. Child Adolesc Psychiatr Clin N Am. Jul. 2005;14(3):523-53. x. [pmid: 15936672].
2796 Vines AI, Godley PA. The challenges of eliminating racial and ethnic health disparities: inescapable realities? Perplexing science? Ineffective policy?. N C Med J. Nov-Dec. 2004;65(6):341-9. [pmid: 15714722].
2797 Viste J. Communicating (birth defects) prevention information to a hmong population in Wisconsin: a study of cultural relevance. Subst Use Misuse. 2007;42(4):753-74. [pmid: 17558962].
2798 Vitolins MZ, Tooze JA, Golden SL, Arcury TA, Bell RA, Davis C, et al. Older adults in the rural South are not meeting healthful eating guidelines. J Am Diet Assoc. Feb. 2007;107(2):265-72. [pmid: 17258963].
2799 Vogel SA, Holt JK. A comparative study of adults with and without self-reported learning disabilities in six English-speaking populations: what have we learned?. Dyslexia. Nov. 2003;9(4):193-228. [pmid: 14672510].
2800 Vohr BR, Allan WC, Westerveld M, Schneider KC, Katz KH, Makuch RW, et al. School-age outcomes of very low birth weight infants in the indomethacin intraventricular hemorrhage prevention trial. Pediatrics. Apr. 2003;111(4 Pt 1):e340-6. [pmid: 12671149].
2801 Volandes AE, Paasche-Orlow M, Gillick MR, Cook EF, Shaykevich S, Abbo ED, et al. Health literacy not race predicts end-of-life care preferences. J Palliat Med. Jun. 2008;11(5):754-62. [pmid: 18588408].
2802 Volandes AE, Paasche-Orlow MK. Health literacy, health inequality and a just healthcare system. Am J Bioeth. Nov. 2007;7(11):5-10. [pmid: 18027287].
2803 Volandes AE, Paasche-Orlow MK, Barry MJ, Gillick MR, Minaker KL, Chang Y, et al. Video decision support tool for advance care planning in dementia: randomised controlled trial. Br Med J. 2009;338:b2159. [pmid: 19477893].
2804 Volk RJ, Jibaja-Weiss ML, Hawley ST, Kneuper S, Spann SJ, Miles BJ, et al. Entertainment education for prostate cancer screening: a randomized trial among primary care patients with low health literacy. Patient Educ Couns. Dec. 2008;73(3):482-9. [pmid: 18760888].
2805 Volkers AC, Westert GP, Schellevis FG. Health disparities by occupation, modified by education: a cross-sectional population study. BMC Public Health. 2007;7:196. [pmid: 17686141].
2806 Volkl-Kernstock S, Bauch-Prater S, Ponocny-Seliger E, Feucht M. Speech and school performance in children with benign partial epilepsy with centro-temporal spikes (BCECTS). Seizure. Jun. 2009;18(5):320-6. [pmid: 19249229].
2807 von Wagner C, Knight K, Steptoe A, Wardle J. Functional health literacy and health-promoting behaviour in a national sample of British adults. J Epidemiol Community Health. Dec. 2007;61(12):1086-90. [pmid: 18000132].
2808 Voracek M. National intelligence, suicide rate in the elderly, and a threshold intelligence for suicidality: an ecological study of 48 Eurasian countries. J Biosoc Sci. Nov. 2005;37(6):721-40. [pmid: 16221322].
2809 Voracek M, Egle J, Schleicher S, Loibl LM, Sonneck G. The Beliefs in the Inheritance of Risk Factors for Suicide Scale (BIRFSS): further results on demographic correlates, dimensionality, reliability, and validity. Omega (Westport). 2007;55(4):279-96. [pmid: 18027643].
2810 Voracek M, Fisher ML, Loibl LM, Tan H, Sonneck G. Beliefs about the genetics of suicide in Canadian students: cross-language validation of the Beliefs in the Inheritance of Risk Factors for Suicide Scale (BIRFSS). Psychiatry Clin Neurosci. Jun. 2008;62(3):271-8. [pmid: 18588586].
2811 Voracek M, Loibl LM, Sonneck G. Beliefs in the Inheritance of Risk Factors for Suicide Scale: development, reliability, stability, and convergent and discriminant validity. Psychol Rep. Aug. 2007;101(1):107-16. [pmid: 17958114].
2812 Voracek M, Loibl LM, Swami V, Vintila M, Kolves K, Sinniah D, et al. The beliefs in the inheritance of risk factors for suicide scale (BIRFSS): cross-cultural validation in Estonia, Malaysia, Romania, the United Kingdom, and the United States. Suicide Life Threat Behav. Dec. 2008;38(6):688-98. [pmid: 19152299].
2813 Vrabel M. Computerized versus paper-and-pencil testing methods for a nursing certification examination: a review of the literature. Comput Inform Nurs. Mar-Apr. 2004;22(2):94-8. quiz 9-100. [pmid: 15520572].
2814 Wade TD, Davidson S, O'Dea JA. A preliminary controlled evaluation of a school-based media literacy program and self-esteem program for reducing eating disorder risk factors. Int J Eat Disord. May. 2003;33(4):371-83. discussion 84-7. [pmid: 12658666].
2815 Wadsworth LA, Thompson AM. Media literacy: a critical role for dietetic practice. Can J Diet Pract Res. Spring. 2005;66(1):30-6. [pmid: 15780154].
2816 Wagner J, Lacey K, Chyun D, Abbott G. Development of a questionnaire to measure heart disease risk knowledge in people with diabetes: the Heart Disease Fact Questionnaire. Patient Educ Couns. Jul. 2005;58(1):82-7. [pmid: 15950840].
2817 Wahlqvist ML. The new nutrition science: sustainability and development. Public Health Nutr. Sep. 2005;8(6A):766-72. [pmid: 16236214].
2818 Wahlqvist ML, Lee MS. Regional food culture and development. Asia Pac J Clin Nutr. 1. 2007;16:2-7. [pmid: 17392068].
2819 Wainwright MA, Wright MJ, Luciano M, Montgomery GW, Geffen GM, Martin NG. A linkage study of academic skills defined by the Queensland core skills test. Behav Genet. Jan. 2006;36(1):56-64. [pmid: 16362232].
2820 Waite KR, Paasche-Orlow M, Rintamaki LS, Davis TC, Wolf MS. Literacy, social stigma, and HIV medication adherence. J Gen Intern Med. Sep. 2008;23(9):1367-72. [pmid: 18563494].
2821 Waked M, Salameh P. Symptoms, severity and asthma control in 5-14 y-old Lebanon school children. J Med Liban. Jul-Sep. 2007;55(3):145-51. [pmid: 17966735].
2822 Waldman HB, Swerdloff M, Perlman SP. Do your pediatric patients have chronic health conditions? Medical history responses may not be accurate. J Dent Child (Chic). May-Aug. 2003;70(2):96-9. [pmid: 14528766].
2823 Waldrop-Valverde D, Jones DL, Weiss S, Kumar M, Metsch L. The effects of low literacy and cognitive impairment on medication adherence in HIV-positive injecting drug users. AIDS Care. Nov. 2008;20(10):1202-10. [pmid: 19012081].
2824 Walker AP, Tucker DC, Hall MA, Lohman K, Harrison H, Harrison BW, et al. Results communication and patient education after screening for possible hemochromatosis and iron overload: experience from the HEIRS Study of a large ethnically and linguistically diverse group. Genet Med. Nov. 2007;9(11):778-91. [pmid: 18007147].
2825 Walker BL, Harrington SS. Can nursing facility staff with minimal education be successfully trained with computer-based training?. Nurse Educ Today. May. 2004;24(4):301-9. [pmid: 15110440].
2826 Walker C, Weeks A, McAvoy B, Demetriou E. Exploring the role of self-management programmes in caring for people from culturally and linguistically diverse backgrounds in Melbourne, Australia. Health Expect. Dec. 2005;8(4):315-23. [pmid: 16266419].
2827 Walker D, Adebajo A, Heslop P, Hill J, Firth J, Bishop P, et al. Patient education in rheumatoid arthritis: the effectiveness of the ARC booklet and the mind map. Rheumatology (Oxford). Oct. 2007;46(10):1593-6. [pmid: 17767002].
2828 Walker J, Pepa C, Gerard PS. Assessing the health literacy levels of patients using selected hospital services. Clin Nurse Spec. Jan-Feb. 2010;24(1):31-7. [pmid: 20010182].
2829 Walker SE, Weidner TG, Armstrong KJ. Evaluation of athletic training students' clinical proficiencies. J Athl Train. Jul-Aug. 2008;43(4):386-95. [pmid: 18668172].
2830 Wallace L. Patients' health literacy skills: the missing demographic variable in primary care research. Ann Fam Med. Jan-Feb. 2006;4(1):85-6. [pmid: 16449402].
2831 Wallace LS, Cassada DC, Rogers ES, Freeman MB, Grandas OH, Stevens SL, et al. Can screening items identify surgery patients at risk of limited health literacy?. J Surg Res. Jun. 15. 2007;140(2):208-13. [pmid: 17509266].
2832 Wallace LS, Keenum AJ, Roskos SE, Blake GH, Colwell ST, Weiss BD. Suitability and readability of consumer medical information accompanying prescription medication samples. Patient Educ Couns. Mar. 2008;70(3):420-5. [pmid: 18178363].
2833 Wallace LS, Keenum AJ, Roskos SE, McDaniel KS. Development and validation of a low-literacy opioid contract. J Pain. Oct. 2007;8(10):759-66. [pmid: 17569596].
2834 Wallace LS, Lennon ES. American Academy of Family Physicians patient education materials: can patients read them?. Fam Med. Sep. 2004;36(8):571-4. [pmid: 15343418].
2835 Wallace LS, Rogers ES, Malagon-Rogers M. Literacy, medical care, and health status in Tennessee. Tenn Med. Sep. 2004;97(9):405-6. [pmid: 15497568].
2836 Wallace LS, Rogers ES, Roskos SE, Holiday DB, Weiss BD. Brief report: screening items to identify patients with limited health literacy skills. J Gen Intern Med. Aug. 2006;21(8):874-7. [pmid: 16881950].
2837 Wallace LS, Rogers ES, Weiss BD. Relationship between health literacy and health-related quality of life among Tennesseans. Tenn Med. May. 2008;101(5):35-9. [pmid: 18507259].
2838 Wallin MT, Wilken J, Alfaro MH, Rogers C, Mahan C, Chapman JC, et al. Neuropsychologic assessment of a population-based sample of Gulf War veterans. Cogn Behav Neurol. Sep. 2009;22(3):155-66. [pmid: 19741325].
2839 Wallis L. Safety in numbers. Concern about nurses' numeracy skills has been revived by research on drug calculation errors. Nurs Stand. Apr. 23-29. 2008;22(33):62-3.
2840 Walsh JC, Curtis R, Mylotte M. Anxiety levels in women attending a colposcopy clinic: a randomised trial of an educational intervention using video colposcopy. Patient Educ Couns. Nov. 2004;55(2):247-51. [pmid: 15530762].
2841 Wang F, Veugelers PJ. Self-esteem and cognitive development in the era of the childhood obesity epidemic. Obes Rev. Nov. 2008;9(6):615-23. [pmid: 18647242].
2842 Wang J, Adair C, Fick G, Lai D, Evans B, Perry BW, et al. Depression literacy in Alberta: findings from a general population sample. Can J Psychiatry. Jul. 2007;52(7):442-9. [pmid: 17688008].
2843 Wang J, Fick G, Adair C, Lai D. Gender specific correlates of stigma toward depression in a Canadian general population sample. J Affect Disord. Nov. 2007;103(1-3):91-7. [pmid: 17292968].
2844 Wang J, Lai D. The relationship between mental health literacy, personal contacts and personal stigma against depression. J Affect Disord. Sep. 2008;110(1-2):191-6. [pmid: 18261806].
2845 Wang JJ. Prevalence and correlates of depressive symptoms in the elderly of rural communities in southern Taiwan. J Nurs Res. Jun. 2001;9(3):1-12. [pmid: 12688568].
2846 Wang YS, Wang HY. Developing and validating an instrument for measuring mobile computing self-efficacy. Cyberpsychol Behav. Aug. 2008;11(4):405-13. [pmid: 18721088].
2847 Warburton P. Numeracy and patient safety: the need for regular staff assessment. Nurs Stand. Mar. 10-16. 2010;24(27):42-4. [pmid: 20373629].
2848 Warburton P. Poor numeracy skills must be tackled to cut medication errors. Nurs Times. Mar. 9-15. 2010;106(9):13. [pmid: 20344984].
2849 Warburton P, Kahn P. Improving the numeracy skills of nurse prescribers. Nurs Stand. Mar. 21-27. 2007;21(28):40-3. [pmid: 17436893].
2850 Ward MM, Yankey JW, Vaughn TE, BootsMiller BJ, Flach SD, Welke KF, et al. Physician process and patient outcome measures for diabetes care: relationships to organizational characteristics. Med Care. Sep. 2004;42(9):840-50. [pmid: 15319609].
2851 Ward R, Moule P. Supporting pre-registration students in practice: A review of current ICT use. Nurse Educ Today. Jan. 2007;27(1):60-7. [pmid: 16624450].
2852 Ward R, Stevens C, Brentnall P, Briddon J. The attitudes of health care staff to information technology: a comprehensive review of the research literature. Health Info Libr J. Jun. 2008;25(2):81-97. [pmid: 18494643].
2853 Wareham P, Salmon K. Mother-child reminiscing about everyday experiences: implications for psychological interventions in the preschool years. Clin Psychol Rev. Sep. 2006;26(5):535-54. [pmid: 16815615].
2854 Washington KT, Demiris G, Oliver DP, Day M. Telehospice acceptance among providers: a multidisciplinary comparison. Am J Hosp Palliat Care. 2008 Dec-2009 Jan. 25(6):452-7. [pmid: 18812614].
2855 Wass V, van der Vleuten C. The long case. Med Educ. Nov. 2004;38(11):1176-80. [pmid: 15507012].
2856 Waters EA, Weinstein ND, Colditz GA, Emmons K. Formats for improving risk communication in medical tradeoff decisions. J Health Commun. Mar. 2006;11(2):167-82. [pmid: 16537286].
2857 Wathen CN, Harris RM. “I try to take care of it myself.” how rural women search for health information. Qual Health Res. May. 2007;17(5):639-51. [pmid: 17478646].
2858 Watson FL, Lom B. More than a picture: helping undergraduates learn to communicate through scientific images. CBE Life Sci Educ. Spring. 2008;7(1):27-35. [pmid: 18316805].
2859 Watson R, Vaughn LM. Limiting the effects of the media on body image: does the length of a media literacy intervention make a difference?. Eat Disord. Oct-Dec. 2006;14(5):385-400. [pmid: 17062449].
2860 Watt RG, Harnett R, Daly B, Fuller SS, Kay E, Morgan A, et al. Evaluating oral health promotion: need for quality outcome measures. Community Dent Oral Epidemiol. Feb. 2006;34(1):11-7. [pmid: 16423026].
2861 Watters EK. Literacy for health: an interdisciplinary model. J Transcult Nurs. Jan. 2003;14(1):48-54. [pmid: 12593270].
2862 Wayne PM, Buring JE, Davis RB, Andrews SM, John MS, Kerr CE, et al. Increasing research capacity at the New England School of Acupuncture through faculty and student research training initiatives. Altern Ther Health Med. Mar-Apr. 2008;14(2):52-8. [pmid: 18383990].
2863 Weathers RR 2nd, Walter G, Schley S, Hennessey J, Hemmeter J, Burkhauser RV. How postsecondary education improves adult outcomes for Supplemental Security Income children with severe hearing impairments. Soc Secur Bull. 2007;67(2):101-31. [pmid: 18457089].
2864 Weaver GD, Kuo YF, Raji MA, Al Snih S, Ray L, Torres E, et al. Pain and disability in older Mexican-American adults. J Am Geriatr Soc. Jun. 2009;57(6):992-9. [pmid: 19453304].
2865 Weaver NF, Hayes L, Unwin NC, Murtagh MJ. “Obesity” and “Clinical Obesity” Men's understandings of obesity and its relation to the risk of diabetes: a qualitative study. BMC Public Health. 2008;8:311. [pmid: 18789165].
2866 Webb J, Davis TC, Bernadella P, Clayman ML, Parker RM, Adler D, et al. Patient-centered approach for improving prescription drug warning labels. Patient Educ Couns. Sep. 2008;72(3):443-9. [pmid: 18644691].
2867 Weber S. Critical care nurse practitioners and clinical nurse specialists interface patterns with computer-based decision support systems. J Am Acad Nurse Pract. Nov. 2007;19(11):580-90. [pmid: 17970858].
2868 Weber S. A qualitative analysis of how advanced practice nurses use clinical decision support systems. J Am Acad Nurse Pract. Dec. 2007;19(12):652-67. [pmid: 18042131].
2869 Wee CC, Pratt JS, Fanelli R, Samour PQ, Trainor LS, Paasche-Orlow MK. Best practice updates for informed consent and patient education in weight loss surgery. Obesity (Silver Spring). May. 2009;17(5):885-8. [pmid: 19396067].
2870 Wefer SH, Sheppard K. Bioinformatics in high school biology curricula: a study of state science standards. CBE Life Sci Educ. Spring. 2008;7(1):155-62. [pmid: 18316818].
2871 Weiner DK, Rudy TE, Morrow L, Slaboda J, Lieber S. The relationship between pain, neuropsychological performance, and physical function in community-dwelling older adults with chronic low back pain. Pain Med. Jan-Feb. 2006;7(1):60-70. [pmid: 16533199].
2872 Weiner J, Aguirre A, Ravenell K, Kovath K, McDevit L, Murphy J, et al. Designing an illustrated patient satisfaction instrument for low-literacy populations. Am J Manag Care. Nov. 2004;10(11 Pt 2):853-60. [pmid: 15609739].
2873 Weinert C, Cudney S, Hill W. Retention in a computer-based outreach intervention for chronically ill rural women. Appl Nurs Res. Feb. 2008;21(1):23-9. [pmid: 18226760].
2874 Weinert C, Cudney S, Winters C. Social support in cyberspace: the next generation. Comput Inform Nurs. Jan-Feb. 2005;23(1):7-15. [pmid: 15681989].
2875 Weinert C, Hill WG. Rural women with chronic illness: computer use and skill acquisition. Womens Health Issues. Sep-Oct. 2005;15(5):230-6. [pmid: 16165009].
2876 Weinfurt KP, Castel LD, Li Y, Sulmasy DP, Balshem AM, Benson AB 3rd, et al. The correlation between patient characteristics and expectations of benefit from Phase I clinical trials. Cancer. Jul. 1. 2003;98(1):166-75. [pmid: 12833469].
2877 Weinfurt KP, Depuy V, Castel LD, Sulmasy DP, Schulman KA, Meropol NJ. Understanding of an aggregate probability statement by patients who are offered participation in Phase I clinical trials. Cancer. Jan. 1. 2005;103(1):140-7. [pmid: 15534885].
2878 Weisel A, Most T, Michael R. Mothers' stress and expectations as a function of time since child's cochlear implantation. J Deaf Stud Deaf Educ. Winter. 2007;12(1):55-64. [pmid: 16984966].
2879 Weiss BD, Francis L, Senf JH, Heist K, Hargraves R. Literacy education as treatment for depression in patients with limited literacy and depression: a randomized controlled trial. J Gen Intern Med. Aug. 2006;21(8):823-8. [pmid: 16881941].
2880 Weiss BD, Mays MZ, Martz W, Castro KM, DeWalt DA, Pignone MP, et al. Quick assessment of literacy in primary care: the newest vital sign. Ann Fam Med. Nov-Dec. 2005;3(6):514-22. [pmid: 16338915].
2881 Weiss BD, Palmer R. Relationship between health care costs and very low literacy skills in a medically needy and indigent Medicaid population. J Am Board Fam Pract. Jan-Feb. 2004;17(1):44-7. [pmid: 15014052].
2882 Weiss ME, Ryan P, Lokken L. Validity and reliability of the Perceived Readiness for Discharge After Birth Scale. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2006;35(1):34-45.
2883 Weitzman CC, Roy L, Walls T, Tomlin R. More evidence for reach out and read: a home-based study. Pediatrics. May. 2004;113(5):1248-53. [pmid: 15121937].
2884 Weld KK, Padden D, Ramsey G, Garmon Bibb SC. A framework for guiding health literacy research in populations with universal access to healthcare. ANS Adv Nurs Sci. Oct-Dec. 2008;31(4):308-18. [pmid: 19033746].
2885 Weld KK, Padden D, Ricciardi R, Bibb SC. Health literacy rates in a sample of active duty military personnel. Mil Med. Nov. 2009;174(11):1137-43. [pmid: 19960819].
2886 Welk A, Splieth C, Seyer D, Rosin M, Siemer M, Meyer G. German dental faculty attitudes towards computer-assisted simulation systems correlated with personal and professional profiles. Eur J Dent Educ. May. 2006;10(2):87-95. [pmid: 16634816].
2887 Wensing M, van Lieshout J, Jung HP, Hermsen J, Rosemann T. The Patients Assessment Chronic Illness Care (PACIC) questionnaire in The Netherlands: a validation study in rural general practice. BMC Health Serv Res. 2008;8:182. [pmid: 18761749].
2888 Werner P. Lay perceptions about mental health: where is age and where is Alzheimer's disease?. Int Psychogeriatr. Sep. 2005;17(3):371-82. [pmid: 16252371].
2889 West RR, McNabb R, Thompson AG, Sheldon TA, Grimley Evans J. Estimating implied rates of discount in healthcare decision-making. Health Technol Assess. 2003;7(38):1-60. [pmid: 14622489].
2890 Westby C. 21st century literacy for a diverse world. Folia Phoniatr Logop. Jul-Aug. 2004;56(4):254-71. [pmid: 15258437].
2891 Westerman GH, Elsasser GN, Kavan MG. Dental student experiences with gambling: a survey of attitudes, exposure, and impact. J Dent Educ. Aug. 2009;73(8):934-41. [pmid: 19648564].
2892 Westert GP, Schellevis FG, de Bakker DH, Groenewegen PP, Bensing JM, van der Zee J. Monitoring health inequalities through general practice: the Second Dutch National Survey of General Practice. Eur J Public Health. Feb. 2005;15(1):59-65. [pmid: 15788805].
2893 Whaley KC. America's digital divide: 2000-2003 trends. J Med Syst. Apr. 2004;28(2):183-95. [pmid: 15195849].
2894 Whalley LJ, Dick FD, McNeill G. A life-course approach to the aetiology of late-onset dementias. Lancet Neurol. Jan. 2006;5(1):87-96. [pmid: 16361026].
2895 Wharf Higgins J, Begoray D, MacDonald M. A social ecological conceptual framework for understanding adolescent health literacy in the health education classroom. Am J Community Psychol. Dec. 2009;44(3-4):350-62. [pmid: 19838790].
2896 Wharrad HJ, Cook E, Poussa C. Putting post-registration nursing students on-line: important lessons learned. Nurse Educ Today. May. 2005;25(4):263-71. [pmid: 15896411].
2897 Wheeler DP, Goodman H. Health and mental health social workers need information literacy skills. Health Soc Work. Aug. 2007;32(3):235-7. [pmid: 17896682].
2898 White A, Allen P, Goodwin L, Breckinridge D, Dowell J, Garvy R. Infusing PDA technology into nursing education. Nurse Educ. Jul-Aug. 2005;30(4):150-4. [pmid: 16030450].
2899 White S, Chen J, Atchison R. Relationship of preventive health practices and health literacy: a national study. Am J Health Behav. May-Jun. 2008;32(3):227-42. [pmid: 18067463].
2900 White S, Milne E, Rosen S, Hansen P, Swettenham J, Frith U, et al. The role of sensorimotor impairments in dyslexia: a multiple case study of dyslexic children. Dev Sci. May. 2006;9(3):237-55. discussion 65-9. [pmid: 16669791].
2901 Whiteford H, Groves A. Policy implications of the 2007 Australian National Survey of Mental Health and Wellbeing. Aust N Z J Psychiatry. Jul. 2009;43(7):644-51. [pmid: 19530021].
2902 Whitehouse AJ, Barry JG, Bishop DV. The broader language phenotype of autism: a comparison with specific language impairment. J Child Psychol Psychiatry. Aug. 2007;48(8):822-30. [pmid: 17683454].
2903 Wiberg M. Gender differences in the Swedish driving-license test. J Safety Res. 2006;37(3):285-91. [pmid: 16815446].
2904 Wiener RL, Baron-Donovan C, Gross K, Block-Lieb S. Debtor education, financial literacy, and pending bankruptcy legislation. Behav Sci Law. 2005;23(3):347-66. [pmid: 15968706].
2905 Wigen TI, Wang NJ. Caries and background factors in Norwegian and immigrant 5-year-old children. Community Dent Oral Epidemiol. Feb. 2010;38(1):19-28. [pmid: 19845710].
2906 Wigney T, Parker G. Medical student observations on a career in psychiatry. Aust N Z J Psychiatry. Sep. 2007;41(9):726-31. [pmid: 17687658].
2907 Wijdicks EF, Wijdicks CA. The portrayal of coma in contemporary motion pictures. Neurology. May. 9. 2006;66(9):1300-3. [pmid: 16682658].
2908 Wijeratne C, Harris P. Late life depression and dementia: a mental health literacy survey of Australian general practitioners. Int Psychogeriatr. Apr. 2009;21(2):330-7. [pmid: 19138460].
2909 Wilbright WA, Haun DE, Romano T, Krutzfeldt T, Fontenot CE, Nolan TE. Computer use in an urban university hospital: technology ahead of literacy. Comput Inform Nurs. Jan-Feb. 2006;24(1):37-43. [pmid: 16436911].
2910 Wilk CM, Gold JM, Humber K, Dickerson F, Fenton WS, Buchanan RW. Brief cognitive assessment in schizophrenia: normative data for the Repeatable Battery for the Assessment of Neuropsychological Status. Schizophr Res. Oct. 1. 2004;70(2-3):175-86. [pmid: 15329294].
2911 Wilkinson A, Forbes A, Bloomfield J, Fincham Gee C. An exploration of four web-based open and flexible learning modules in post-registration nurse education. Int J Nurs Stud. May. 2004;41(4):411-24. [pmid: 15050852].
2912 Wilksch SM, Durbridge MR, Wade TD. A preliminary controlled comparison of programs designed to reduce risk of eating disorders targeting perfectionism and media literacy. J Am Acad Child Adolesc Psychiatry. Aug. 2008;47(8):937-47. [pmid: 18596551].
2913 Wilksch SM, Tiggemann M, Wade TD. Impact of interactive school-based media literacy lessons for reducing internalization of media ideals in young adolescent girls and boys. Int J Eat Disord. Jul. 2006;39(5):385-93. [pmid: 16528696].
2914 Willenberg I. Foundations for literacy: emergent literacy competencies of grade R learners on the Cape Flats. S Afr J Commun Disord. 2007;54:20-8. [pmid: 18240657].
2915 Willett JG, Hood NE, Burns EK, Swetlick JL, Wilson SM, Lang DA, et al. Clinical faxed referrals to a tobacco quitline: reach, enrollment, and participant characteristics. Am J Prev Med. Apr. 2009;36(4):337-40. [pmid: 19201150].
2916 Williams C. Emergent literacy of deaf children. J Deaf Stud Deaf Educ. Fall. 2004;9(4):352-65. [pmid: 15314011].
2917 Williams DM, Bentley R, Cobourne MT, Gibilaro A, Good S, Huppa C, et al. The impact of idealised facial images on satisfaction with facial appearance: comparing ‘ideal’ and ‘average’ faces. J Dent. Sep. 2008;36(9):711-7. [pmid: 18639969].
2918 Williams KP, Mullan PB, Fletcher F. Working with African American women to develop a cancer literacy assessment tool. J Cancer Educ. Winter. 2007;22(4):241-4. [pmid: 18067436].
2919 Williams MV, Parker RM, Baker DW, Parikh NS, Pitkin K, Coates WC, et al. Inadequate functional health literacy among patients at two public hospitals. JAMA. Dec. 6. 1995;274(21):1677-82. [pmid: 7474271].
2920 Williams O, Noble JM. ‘Hip-hop’ stroke: a stroke educational program for elementary school children living in a high-risk community. Stroke. Oct. 2008;39(10):2809-16. [pmid: 18635851].
2921 Williams WR, Latif AH, Hannington L, Watkins DR. Hyperopia and educational attainment in a primary school cohort. Arch Dis Child. Feb. 2005;90(2):150-3. [pmid: 15665167].
2922 Willis E, Kabler-Babbitt C, Zuckerman B. Early literacy interventions: reach out and read. Pediatr Clin North Am. Jun. 2007;54(3):625-42. viii. [pmid: 17543913].
2923 Willmer M. How nursing leadership and management interventions could facilitate the effective use of ICT by student nurses. J Nurs Manag. Mar. 2007;15(2):207-13. [pmid: 17352704].
2924 Willson VL, Reynolds CR. Misconceptions in Van den Broeck's representation of misconceptions about learning disability research. J Learn Disabil. May-Jun. 2002;35(3):205-8. discussion 9-13. [pmid: 15493317].
2925 Wilson EA, Wolf MS. Working memory and the design of health materials: a cognitive factors perspective. Patient Educ Couns. Mar. 2009;74(3):318-22. [pmid: 19121915].
2926 Wilson FL, Baker LM, Nordstrom CK, Legwand C. Using the teach-back and Orem's Self-care Deficit Nursing theory to increase childhood immunization communication among low-income mothers. Issues Compr Pediatr Nurs. Jan-Mar. 2008;31(1):7-22. [pmid: 18300059].
2927 Wilson FL, Racine E, Tekieli V, Williams B. Literacy, readability and cultural barriers: critical factors to consider when educating older African Americans about anticoagulation therapy. J Clin Nurs. Mar. 2003;12(2):275-82. [pmid: 12603561].
2928 Wilson FL, Williams BN. Assessing the readability of skin care and pressure ulcer patient education materials. J Wound Ostomy Continence Nurs. Jul. 2003;30(4):224-30. [pmid: 12851598].
2929 Wilson HR. Hepatitis B and you: a patient education resource for pregnant women and new mothers. J Womens Health (Larchmt). Jun. 2003;12(5):437-41. [pmid: 12869290].
2930 Wilson J. Meeting the health literacy needs of clients. Nurs N Z. Aug. 2006;12(7):18-9. [pmid: 17076295].
2931 Wilson JF. The crucial link between literacy and health. Ann Intern Med. Nov. 18. 2003;139(10):875-8. [pmid: 14623636].
2932 Wilson M. Readability and patient education materials used for low-income populations. Clin Nurse Spec. Jan-Feb. 2009;23(1):33-40. quiz 1-2. [pmid: 19098513].
2933 Wilson RS, McCann JJ, Li Y, Aggarwal NT, Gilley DW, Evans DA. Nursing home placement, day care use, and cognitive decline in Alzheimer's disease. A_ J Psychiatry. Jun. 2007;164(6):910-5.
2934 Wilson RS, Scherr PA, Hoganson G, Bienias JL, Evans DA, Bennett DA. Early life socioeconomic status and late life risk of Alzheimer's disease. Neuroepidemiology. 2005;25(1):8-14. [pmid: 15855799].
2935 Wilson RT, Chase GA, Chrischilles EA, Wallace RB. Hip fracture risk among community-dwelling elderly people in the United States: a prospective study of physical, cognitive, and socioeconomic indicators. Am J Public Health. Jul. 2006;96(7):1210-8. [pmid: 16735617].
2936 Winskel H. The effects of an early history of otitis media on children's language and literacy skill development. Br J Educ Psychol. Dec. 2006;76(Pt 4):727-44. [pmid: 17094883].
2937 Winston FK, Erkoboni D, Xie D. Identifying interventions that promote belt-positioning booster seat use for parents with low educational attainment. J Trauma. Sep. 2007;63(3 Suppl):S29-38. [pmid: 17823581].
2938 Winters CA, Lee HJ, Besel J, Strand A, Echeverri R, Jorgensen KP, et al. Access to and use of research by rural nurses. Rural Remote Health. Jul-Sep. 2007;7(3):758. [pmid: 17892348].
2939 Wister AV, Wanless D. A health profile of community-living nonagenarians in Canada. Can J Aging. Spring. 2007;26(1):1-18. [pmid: 17430800].
2940 Withy K, Berry S, Moore N, Veehala DP. How Hawaii/Pacific Basin Area Health Education Center (AHEC) is using technology to make the Pacific smaller. Hawaii Med J. Oct. 2004;63(10):285-6. [pmid: 15570712].
2941 Wittich AR, Mangan J, Grad R, Wang W, Gerald LB. Pediatric asthma: caregiver health literacy and the clinician's perception. J Asthma. Jan-Feb. 2007;44(1):51-5. [pmid: 17365205].
2942 Wocadlo C, Rieger I. Educational and therapeutic resource dependency at early school-age in children who were born very preterm. Early Hum Dev. Jan. 2006;82(1):29-37. [pmid: 16378698].
2943 Wocadlo C, Rieger I. Motor impairment and low achievement in very preterm children at eight years of age. Early Hum Dev. Nov. 2008;84(11):769-76. [pmid: 18639396].
2944 Wolf AM, Siadaty M, Yaeger B, Conaway MR, Crowther JQ, Nadler JL, et al. Effects of lifestyle intervention on health care costs: Improving Control with Activity and Nutrition (ICAN). J Am Diet Assoc. Aug. 2007;107(8):1365-73. [pmid: 17659904].
2945 Wolf MS, Bennett CL, Davis TC, Marin E, Arnold C. A qualitative study of literacy and patient response to HIV medication adherence questionnaires. J Health Commun. Sep. 2005;10(6):509-17. [pmid: 16203630].
2946 Wolf MS, Chang CH, Davis T, Makoul G. Development and validation of the Communication and Attitudinal Self-Efficacy scale for cancer (CASE-cancer). Patient Educ Couns. Jun. 2005;57(3):333-41. [pmid: 15893217].
2947 Wolf MS, Davis TC, Arozullah A, Penn R, Arnold C, Sugar M, et al. Relation between literacy and HIV treatment knowledge among patients on HAART regimens. AIDS Care. Oct. 2005;17(7):863-73. [pmid: 16120503].
2948 Wolf MS, Davis TC, Cross JT, Marin E, Green K, Bennett CL. Health literacy and patient knowledge in a Southern US HIV clinic. Int J STD AIDS. Nov. 2004;15(11):747-52. [pmid: 15537462].
2949 Wolf MS, Davis TC, Osborn CY, Skripkauskas S, Bennett CL, Makoul G. Literacy, self-efficacy, and HIV medication adherence. Patient Educ Couns. Feb. 2007;65(2):253-60. [pmid: 17118617].
2950 Wolf MS, Davis TC, Shrank W, Rapp DN, Bass PF, Connor UM, et al. To err is human: patient misinterpretations of prescription drug label instructions. Patient Educ Couns. Aug. 2007;67(3):293-300. [pmid: 17587533].
2951 Wolf MS, Davis TC, Shrank WH, Neuberger M, Parker RM. A critical review of FDA-approved Medication Guides. Patient Educ Couns. Sep. 2006;62(3):316-22. [pmid: 16884888].
2952 Wolf MS, Davis TC, Tilson HH, Bass PF 3rd, Parker RM. Misunderstanding of prescription drug warning labels among patients with low literacy. Am J Health Syst Pharm. Jun. 1. 2006;63(11):1048-55. [pmid: 16709891].
2953 Wolf MS, Gazmararian JA, Baker DW. Health literacy and functional health status among older adults. Arch Intern Med. Sep. 26. 2005;165(17):1946-52. [pmid: 16186463].
2954 Wolf MS, Gazmararian JA, Baker DW. Health literacy and health risk behaviors among older adults. Am J Prev Med. Jan. 2007;32(1):19-24. [pmid: 17184964].
2955 Wolf MS, Knight SJ, Lyons EA, Durazo-Arvizu R, Pickard SA, Arseven A, et al. Literacy, race, and PSA level among low-income men newly diagnosed with prostate cancer. Urology. Jul. 2006;68(1):89-93. [pmid: 16844451].
2956 Wolf MS, Shekelle P, Choudhry NK, Agnew-Blais J, Parker RM, Shrank WH. Variability in pharmacy interpretations of physician prescriptions. Med Care. Mar. 2009;47(3):370-3. [pmid: 19194338].
2957 Wolf MS, Williams MV, Parker RM, Parikh NS, Nowlan AW, Baker DW. Patients' shame and attitudes toward discussing the results of literacy screening. J Health Commun. Dec. 2007;12(8):721-32. [pmid: 18030638].
2958 Wolf MS, Wilson EA, Rapp DN, Waite KR, Bocchini MV, Davis TC, et al. Literacy and learning in health care. Pediatrics. Nov. 3. 2009;124:S275-81. [pmid: 19861481].
2959 Wolf RL, Lepore SJ, Vandergrift JL, Wetmore-Arkader L, McGinty E, Pietrzak G, et al. Knowledge, barriers, and stage of change as correlates of fruit and vegetable consumption among urban and mostly immigrant black men. J Am Diet Assoc. Aug. 2008;108(8):1315-22. [pmid: 18656571].
2960 Wolff K, Cavanaugh K, Malone R, Hawk V, Gregory BP, Davis D, et al. The Diabetes Literacy and Numeracy Education Toolkit (DLNET): materials to facilitate diabetes education and management in patients with low literacy and numeracy skills. Diabetes Educ. Mar-Apr. 2009;35(2):233-6. 8. 41. 44. 5. [pmid: 19240246].
2961 Wolff M, Bates T, Beck B, Young S, Ahmed SM, Maurana C. Cancer prevention in underserved African American communities: barriers and effective strategies--a review of the literature. Wmj. 2003;102(5):36-40. [pmid: 14621929].
2962 Wolke D, Samara M, Bracewell M, Marlow N. Specific language difficulties and school achievement in children born at 25 weeks of gestation or less. J Pediatr. Feb. 2008;152(2):256-62. [pmid: 18206699].
2963 Woloshin S, Schwartz LM, Moncur M, Gabriel S, Tosteson AN. Assessing values for health: numeracy matters. Med Decis Making. Sep-Oct. 2001;21(5):382-90. [pmid: 11575488].
2964 Woloshin S, Schwartz LM, Welch HG. The effectiveness of a primer to help people understand risk: two randomized trials in distinct populations. Ann Intern Med. Feb. 20. 2007;146(4):256-65. [pmid: 17310049].
2965 Wolter JA, Dilollo A, Apel K. A narrative therapy approach to counseling: a model for working with adolescents and adults with language-literacy deficits. Lang Speech Hear Serv Sch. Jul. 2006;37(3):168-77. [pmid: 16837440].
2966 Wong BM, Yung BM, Wong A, Chow CM, Abramson BL. Increasing Internet use among cardiovascular patients: new opportunities for heart health promotion. Can J Cardiol. Mar. 15. 2005;21(4):349-54. [pmid: 15838562].
2967 Wood MR, Kettinger CA, Lessick M. Knowledge is power: how nurses can promote health literacy. Nurs Womens Health. Apr. 2007;11(2):180-8. [pmid: 17883800].
2968 Wood RM. Student computer competence and the NCLEX-RN examination: strategies for success. Comput Inform Nurs. Sep-Oct. 2005;23(5):241-3. [pmid: 16166823].
2969 Woodrow P. Numeracy skills. Nurs Stand. Apr. 15-21. 1998;12(30):48-53. quiz 4-5. [pmid: 9633392].
2970 Woods PS, Wynne HJ, Ploeger HW, Leonard DK. Path analysis of subsistence farmers' use of veterinary services in Zimbabwe. Prev Vet Med. Dec. 12. 2003;61(4):339-58. [pmid: 14623416].
2971 Woodward WR, Hetley RS. Diffusion, decolonializing, and participatory action research. Integr Psychol Behav Sci. Mar. 2007;41(1):97-105. discussion 14-9. [pmid: 17992874].
2972 Wooldridge JA. Digital literacy in a landscape of data: a plea for a broader definition for citizens and patients. Stud Health Technol Inform. 2005;118:263-9. [pmid: 16301785].
2973 Worley S, Didiza Z, Nomatshila S, Porter S, Makwedini N, Macharia D, et al. Wellness programmes for persons living with HIV/AIDS: experiences from Eastern Cape province, South Africa. Glob Public Health. 2009;4(4):367-85. [pmid: 19343601].
2974 Worthen MR. Education policy implications from the Expert Panel on Electronic Media and Youth Violence. J Adolesc Health. Dec. 2007;41(6 Suppl 1):S61-3. [pmid: 18047948].
2975 Wouters E, Van Damme W, Van Loon F, van Rensburg D, Meulemans H. Public-sector ART in the Free State Province, South Africa: community support as an important determinant of outcome. Soc Sci Med. Oct. 2009;69(8):1177-85. [pmid: 19692165].
2976 Wozar JA, Worona PC. The use of online information resources by nurses. J Med Libr Assoc. Apr. 2003;91(2):216-21. [pmid: 12883576].
2977 Wright A, Harris MG, Wiggers JH, Jorm AF, Cotton SM, Harrigan SM, et al. Recognition of depression and psychosis by young Australians and their beliefs about treatment. Med J Aust. Jul. 4. 2005;183(1):18-23. [pmid: 15992332].
2978 Wright A, McGorry PD, Harris MG, Jorm AF, Pennell K. Development and evaluation of a youth mental health community awareness campaign - The Compass Strategy. BMC Public Health. 2006;6:215. [pmid: 16923195].
2979 Wright AJ, Whitwell SC, Takeichi C, Hankins M, Marteau TM. The impact of numeracy on reactions to different graphic risk presentation formats: an experimental analogue study. Br J Health Psychol. Feb. 2009;14(Pt 1):107-25. [pmid: 18442447].
2980 Wright CS. Orienting the clinician to point of service systems. Home Healthc Nurse. Oct. 2004;22(10):687-94. [pmid: 15486506].
2981 Wright FV, Boschen K, Jutai J. Exploring the comparative responsiveness of a core set of outcome measures in a school-based conductive education programme. Child Care Health Dev. May. 2005;31(3):291-302. [pmid: 15840149].
2982 Wright K. A written assessment is an invalid test of numeracy skills. Br J Nurs. Jul. 12-25. 2007;16(13):828-31. [pmid: 17851340].
2983 Wright K. The assessment and development of drug calculation skills in nurse education--a critical debate. Nurse Educ Today. Jul. 2009;29(5):544-8. [pmid: 19324475].
2984 Wright K. Resources to help solve drug calculation problems. Br J Nurs. Jul. 23. Aug. 12. 2009;18(14):878-80. 82. 3. [pmid: 19633600].
2985 Wrigley S, Jackson H, Judd F, Komiti A. Role of stigma and attitudes toward help-seeking from a general practitioner for mental health problems in a rural town. Aust N Z J Psychiatry. Jun. 2005;39(6):514-21. [pmid: 15943655].
2986 Wu CH, Chiu YH, Guo CS. Text generation from Taiwanese Sign Language using a PST-based language model for augmentative communication. IEEE Trans Neural Syst Rehabil Eng. Dec. 2004;12(4):441-54. [pmid: 15615000].
2987 Wu T, Flowers JW, Tudiver F, Wilson JL, Punyasavatsut N. Subclinical thyroid disorders and cognitive performance among adolescents in the United States. BMC Pediatr. 2006;6:12. [pmid: 16623938].
2988 Wu TY, Bancroft J. Filipino American women's perceptions and experiences with breast cancer screening. Oncol Nurs Forum. Jul. 2006;33(4):E71-8. [pmid: 16858450].
2989 Wu W, West SG, Hughes JN. Short-term effects of grade retention on the growth rate of Woodcock-Johnson III broad math and reading scores. J Sch Psychol. Feb. 2008;46(1):85-105. [pmid: 19083352].
2990 Xiao H, Gwede CK, Kiros G, Milla K. Analysis of prostate cancer incidence using geographic information system and multilevel modeling. J Natl Med Assoc. Mar. 2007;99(3):218-25. [pmid: 17393945].
2991 Xu G, Meyer JS, Huang Y, Du F, Chowdhury M, Quach M. Adapting mini-mental state examination for dementia screening among illiterate or minimally educated elderly Chinese. Int J Geriatr Psychiatry. Jul. 2003;18(7):609-16. [pmid: 12833305].
2992 Yager Z, O'Dea JA. Prevention programs for body image and eating disorders on University campuses: a review of large, controlled interventions. Health Promot Int. Jun. 2008;23(2):173-89. [pmid: 18263883].
2993 Yaghmaie F, Jayasuriya R. The roles of ‘subjective computer training’ and management support in the use of computers in community health centres. Inform Prim Care. 2004;12(3):163-70. [pmid: 15606989].
2994 Yamada J. Implications of articulatory awareness in learning literacy in English as a second language. Dyslexia. May. 2004;10(2):95-104. [pmid: 15180391].
2995 Yan A, Mekikian A, Bazargan M, Chandramohan G. Adequacy of urinary tract infection management among minority underserved children. Pediatr Nephrol. Dec. 2004;19(12):1375-8. [pmid: 15490253].
2996 Yan Z, Fischer KW. How children and adults learn to use computers: a developmental approach. New Dir Child Adolesc Dev. Fall. 2004;(105):41-61. [pmid: 15552207].
2997 Yang B, Lester D. Liaw's scales to measure attitudes toward computers and the Internet. Percept Mot Skills. Oct. 2003;97(2):384. [pmid: 14620221].
2998 Yang B, Lester D, Wong WW, Cappelletti D, Ruiz Jimenez A. Some personality correlates of using eBay. Psychol Rep. Dec. 2006;99(3):762. [pmid: 17305193].
2999 Yang FM, Jones RN. Measurement differences in depression: chronic health-related and sociodemographic effects in older Americans. Psychosom Med. Nov. 2008;70(9):993-1004. [pmid: 18981269].
3000 Yang KF, Yu S, Lin MS, Hsu CL. Study of basic computer competence among public health nurses in Taiwan. J Nurs Res. Mar. 2004;12(1):1-10. [pmid: 15136958].
3001 Yannakoulia M, Panagiotakos DB, Pitsavos C, Bathrellou E, Chrysohoou C, Skoumas Y, et al. Low energy reporting related to lifestyle, clinical, and psychosocial factors in a randomly selected population sample of Greek adults: the ATTICA Study. J Am Coll Nutr. Aug. 2007;26(4):327-33. [pmid: 17906184].
3002 Yates K, Pena A. Comprehension of discharge information for minor head injury: a randomised controlled trial in New Zealand. N Z Med J. 2006;119(1239):U2101. [pmid: 16912719].
3003 Yavuz M. Computer courses in the undergraduate nursing curriculum in Turkey. Comput Inform Nurs. May-Jun. 2006;24(3):159-66. [pmid: 16707947].
3004 Yee KC, Miils E, Airey C. Perfect match? Generation Y as change agents for information communication technology implementation in healthcare. Stud Health Technol Inform. 2008;136:496-501. [pmid: 18487780].
3005 Yen YC, Rebok GW, Yang MJ, Lung FW. A multilevel analysis of the influence of Apolipoprotein E genotypes on depressive symptoms in late-life moderated by the environment. Prog Neuropsychopharmacol B_ol Psychiatry. Feb. 15. 2008;32(2):479-86.
3006 Yeo G. How will the U.S. healthcare system meet the challenge of the ethnogeriatric imperative?. J Am Geriatr Soc. Jul. 2009;57(7):1278-85. [pmid: 19558479].
3007 Yeo SG, Parker G, Yap HL, Mahendran R. Mental health literacy beliefs. A comparison of psychiatric trained nurses and enrolled nurses in Singapore. J Psychosoc Nurs Ment Health Serv. Mar. 2003;41(3):34-41. [pmid: 12643081].
3008 Yildirim A, Ogutmen B, Bektas G, Isci E, Mete M, Tolgay HI. Translation, cultural adaptation, initial reliability, and validation of the Kidney Disease and Quality of Life-Short Form (KDQOL-SF 1.3) in Turkey. Transplant Proc. Jan-Feb. 2007;39(1):51-4. [pmid: 17275473].
3009 Yin HS, Dreyer BP, Foltin G, van Schaick L, Mendelsohn AL. Association of low caregiver health literacy with reported use of nonstandardized dosing instruments and lack of knowledge of weight-based dosing. Ambul Pediatr. Jul-Aug. 2007;7(4):292-8. [pmid: 17660100].
3010 Yin HS, Dreyer BP, van Schaick L, Foltin GL, Dinglas C, Mendelsohn AL. Randomized controlled trial of a pictogram-based intervention to reduce liquid medication dosing errors and improve adherence among caregivers of young children. Arch Pediatr Adolesc Med. Sep. 2008;162(9):814-22. [pmid: 18762597].
3011 Yin HS, Forbis SG, Dreyer BP. Health literacy and pediatric health. Curr Probl Pediatr Adolesc Health Care. Aug. 2007;37(7):258-86. [pmid: 17656324].
3012 Yin HS, Johnson M, Mendelsohn AL, Abrams MA, Sanders LM, Dreyer BP. The health literacy of parents in the United States: a nationally representative study. Pediatrics. Nov. 3. 2009;124:S289-98. [pmid: 19861483].
3013 Yin HS, Mendelsohn AL, Wolf MS, Parker RM, Fierman A, van Schaick L, et al. Parents' medication administration errors: role of dosing instruments and health literacy. Arch Pediatr Adolesc Med. Feb. 2010;164(2):181-6. [pmid: 20124148].
3014 Yin JC, Li GX, Ren XF. An overview of veterinary medical education in China: current status, deficiencies, and strategy for improvement. J Vet Med Educ. Summer. 2006;33(2):238-43. [pmid: 16849304].
3015 Yip YB, Wong TK, Chung JW, Ko SK, Sit JW, Chan TM. Cardiovascular disease: application of a composite risk index from the Telehealth System in a district community. Public Health Nurs. Nov-Dec. 2004;21(6):524-32. [pmid: 15566557].
3016 Yolton K, Dietrich K, Auinger P, Lanphear BP, Hornung R. Exposure to environmental tobacco smoke and cognitive abilities among U.S. children and adolescents. Environ Health Perspect. Jan. 2005;113(1):98-103. [pmid: 15626655].
3017 Young BA, Hall Y, Rodriguez RA. Health disparities in chronic kidney disease: are we making any progress?. Nephrol News Issues. Apr. 50. 2009;23(4):48-1. [pmid: 19437948].
3018 Young D. Low health literacy is high among Americans, studies say. Am J Health Syst Pharm. May. 15. 2004;61(10):986-7. [pmid: 15160772].
3019 Young HK, Barton BA, Waisbren S, Portales Dale L, Ryan MM, Webster RI, et al. Cognitive and psychological profile of males with Becker muscular dystrophy. J Child Neurol. Feb. 2008;23(2):155-62. [pmid: 18056690].
3020 Young SE, Mainous AG 3rd, Carnemolla M. Hyperinsulinemia and cognitive decline in a middle-aged cohort. Diabetes Care. Dec. 2006;29(12):2688-93. [pmid: 17130206].
3021 Yu S, Chen IJ, Yang KF, Wang TF, Yen LL. A feasibility study on the adoption of e-learning for public health nurse continuing education in Taiwan. Nurse Educ Today. Oct. 2007;27(7):755-61. [pmid: 17175074].
3022 Yu S, Yang KF. Attitudes toward Web-based distance learning among public health nurses in Taiwan: a questionnaire survey. Int J Nurs Stud. Aug. 2006;43(6):767-74. [pmid: 16253261].
3023 Yun LS, Hassan Y, Aziz NA, Awaisu A, Ghazali R. A comparison of knowledge of diabetes mellitus between patients with diabetes and healthy adults: a survey from north Malaysia. Patient Educ Couns. Dec. 2007;69(1-3):47-54. [pmid: 17720351].
3024 Zahnd WE, Scaife SL, Francis ML. Health literacy skills in rural and urban populations. Am J Health Behav. Sep-Oct. 2009;33(5):550-7. [pmid: 19296745].
3025 Zambrana RE, Molnar C, Munoz HB, Lopez DS. Cultural competency as it intersects with racial/ethnic, linguistic, and class disparities in managed healthcare organizations. Am J Manag Care. Sep. Spec No:. 2004;10:SP37-44. [pmid: 15481435].
3026 Zanchetta MS, Perreault M, Kaszap M, Viens C. Patterns in information strategies used by older men to understand and deal with prostate cancer: an application of the modelisation qualitative research design. Int J Nurs Stud. Aug. 2007;44(6):961-72. [pmid: 16730729].
3027 Zanchetta MS, Poureslami IM. Health literacy within the reality of immigrants' culture and language. Can J Public Health. May-Jun. 2. 2006;97:S26-30. [pmid: 16805158].
3028 Zarcadoolas C, Pleasant A, Greer DS. Elaborating a definition of health literacy: a commentary. J Health Commun. 1. 2003;8:119-20. [pmid: 14692577].
3029 Zarcadoolas C, Pleasant A, Greer DS. Understanding health literacy: an expanded model. Health Promot Int. Jun. 2005;20(2):195-203. [pmid: 15788526].
3030 Zargarzadeh AH, Tavakoli N, Hassanzadeh A. A survey on the extent of medication storage and wastage in urban Iranian households. Clin Ther. Jun. 2005;27(6):970-8. [pmid: 16117997].
3031 Zary N, Johnson G, Fors U. Web-based virtual patients in dentistry: factors influencing the use of cases in the Web-SP system. Eur J Dent Educ. Feb. 2009;13(1):2-9. [pmid: 19196286].
3032 Zazove P, Meador HE, Aikens JE, Nease DE, Gorenflo DW. Assessment of depressive symptoms in deaf persons. J Am Board Fam Med. Mar-Apr. 2006;19(2):141-7. [pmid: 16513902].
3033 Zhang J, Niaura R, Dyer JR, Shen BJ, Todaro JF, McCaffery JM, et al. Hostility and urine norepinephrine interact to predict insulin resistance: the VA Normative Aging Study. Psychosom Med. Sep-Oct. 2006;68(5):718-26. [pmid: 17012525].
3034 Zhao R, Gao H, Shi X, Tucker JD, Yang Z, Min X, et al. Sexually transmitted disease/HIV and heterosexual risk among miners in townships of Yunnan Province, China. AIDS Patient Care STDS. Dec. 2005;19(12):848-52. [pmid: 16375617].
3035 Ziegler JC, Goswami U. Becoming literate in different languages: similar problems, different solutions. Dev Sci. Sep. 2006;9(5):429-36. [pmid: 16911438].
3036 Ziemer DC, Berkowitz KJ, Panayioto RM, El-Kebbi IM, Musey VC, Anderson LA, et al. A simple meal plan emphasizing healthy food choices is as effective as an exchange-based meal plan for urban African Americans with type 2 diabetes. Diabetes Care. Jun. 2003;26(6):1719-24. [pmid: 12766100].
3037 Zikmund-Fisher BJ, Smith DM, Ubel PA, Fagerlin A. Validation of the Subjective Numeracy Scale: effects of low numeracy on comprehension of risk communications and utility elicitations. Med Decis Making. Sep-Oct. 2007;27(5):663-71. [pmid: 17652180].
3038 Zottarelli LK, Sunil TS, Rajaram S. Influence of parental and socioeconomic factors on stunting in children under 5 years in Egypt. East Mediterr Health J. Nov-Dec. 2007;13(6):1330-42. [pmid: 18341183].
3039 Zubal-Ruggieri R. Making links, making connections: internet resources for self-advocates and people with developmental disabilities. Intellect Dev Disabil. Jun. 2007;45(3):209-15. [pmid: 17472429].
3040 Zuckerman B. Promoting early literacy in pediatric practice: twenty years of reach out and read. Pediatrics. Dec. 2009;124(6):1660-5. [pmid: 19917584].
3041 Zun LS, Sadoun T, Downey L. English-language competency of self-declared English-speaking Hispanic patients using written tests of health literacy. J Natl Med Assoc. Jun. 2006;98(6):912-7. [pmid: 16775913].
3042 Zuniga JM. Promoting HIV literacy. J Int Assoc Physicians AIDS Care (Chic Ill). Sep-Oct. 2008;7(5):215-6.
3043 Zvarova J. New approaches to health promotion and informatics education using Internet in the Czech Republic. Rocz Akad Med Bialymst. 2005;50:138-41. [pmid: 16358953].
3044 Zwar NA, Weller DP, McCloughan L, Traynor VJ. Supporting research in primary care: are practice-based research networks the missing link?. Med J Aust. Jul. 17. 2006;185(2):110-3. [pmid: 16842071].