# Excluded Studies

1 Diehl SJ. Incorporating health literacy into adult basic education: from life skills to life saving. N C Med J. 2007;68(5):336-9. [pmid: 18183754].
2 DeWalt DA. Low health literacy: epidemiology and interventions. N C Med J. 2007;68(5):327-30. [pmid: 18183751].
3 Holmes M, Bacon TJ, Dobson LA, et al. Addressing health literacy through improved patient-practitioner communication. N C Med J. 2007;68(5):319-26. [pmid: 18183750].
4 Roberts NJ, Ghiassi R, Partridge MR. Health literacy in COPD. Int J Chron Obstruct Pulmon Dis. 2008;3(4):499-507. [pmid: 19281068].
5 Nath C. Literacy and diabetes self-management. Am J Nurs. 2007;107(6 Suppl):43-9. quiz 49. [pmid: 17563437].
6 Faguy K. Health literacy. Radiol Technol. 2004;76(2):139-46. quiz 147-9. [pmid: 15587616].
7 Mayer GG, Villaire M. Low health literacy and its effects on patient care. J Nurs Adm. 2004;34(10):440-2. [pmid: 15577665].
8 Parmet WE, Robbins A. Public health literacy for lawyers. J Law Med Ethics. 2003;31(4):701-13. [pmid: 14968671].
9 Bendycki NA. Health literacy. Mark Health Serv. 2008;28(3):32-7. [pmid: 19062445].
10 Reeves K. Health literacy: the newest vital sign. Medsurg Nurs. 2008;17(5):288. 296. [pmid: 19051972].
11 Clancy C. PAs, health literacy, and medication safety. Jaapa. 2008;21(10):51. [pmid: 19024637].
12 Ferguson B. Health literacy and health disparities: the role they play in maternal and child health. Nurs Womens Health. 2008;12(4):286-98. [pmid: 18715376].
13 Wallis L. Safety in numbers. Concern about nurses' numeracy skills has been revived by research on drug calculation errors. Nurs Stand. 2008;22(33):62-3.
14 Frankel A. Health literacy and harm: who is at risk? What is the fix?. Cmaj. 2008;178(12):1573-4. [pmid: 18519906].
15 Summaries for patients. Association of numeracy and diabetes control. Ann Intern Med. 2008;148(10):I53. [pmid: 18490670].
16 Brey RA, Clark SE, Wantz MS. This is your future: a case study approach to foster health literacy. J Sch Health. 2008;78(6):351-5. [pmid: 18489469].
17 Tkacz VL, Metzger A, Pruchnicki MC. Health literacy in pharmacy. Am J Health Syst Pharm. 2008;65(10):974-81. [pmid: 18463348].
18 Silverman MM. In this issue. Mental health literacy. Suicide Life Threat Behav. 2008;38(2):iii-v.
19 Reisfield GM, Wilson GR. Health literacy in palliative medicine #153. J Palliat Med. 2008;11(1):105-6. [pmid: 18370900].
20 Buescher PA, White AE, DeWalt DA. Seleted data related to health literacy in North Carolina. N C Med J. 2007;68(5):377-8. [pmid: 18183768].
21 Stallings KD, Bacon TJ. Health professions education to promote health literacy: leverage points and new opportunities. N C Med J. 2007;68(5):368-71. [pmid: 18183764].
22 Neal KC. Health literacy: more than a one-way street. Am J Bioeth. 2007;7(11):29-30. discussion W1-2. [pmid: 18027298].
23 Jotkowitz A, Porath A. Health literacy, access to care and outcomes of care. Am J Bioeth. 2007;7(11):25-7. discussion W1-2. [pmid: 18027296].
24 Dees RH. Health literacy and autonomy. Am J Bioeth. 2007;7(11):22-3. discussion W1-2. [pmid: 18027294].
25 Goldberg DS. Justice, health literacy and social epidemiology. Am J Bioeth. 2007;7(11):18-20. discussion W1-2. [pmid: 18027292].
26 Gordon EJ, Wolf MS. Beyond the basics: designing a comprehensive response to low health literacy. Am J Bioeth. 2007;7(11):11-3. discussion W1-2. [pmid: 18027289].
27 Owens L, Walden D. Health literacy: the new essential in nursing education. Nurse Educ. 2007;32(6):238-9. [pmid: 17998849].
28 Brey RA, Clark SE, Wantz MS. Enhancing health literacy through accessing health information, products, and services: an exercise for children and adolescents. J Sch Health. 2007;77(9):640-4. [pmid: 17970869].
29 Rudolph JW, Simon R, Raemer DB. Which reality matters? Questions on the path to high engagement in healthcare simulation. Simul Healthc. 2007;2(3):161-3. [pmid: 19088618].
30 Low health literacy puts patients at risk. Bull Am Coll Surg. 2007;92(7):94-5. [pmid: 17849633].
31 Kaposy C. The real-life consequences of being denied access to an abortion. Am J Bioeth. 2007;7(8):34-6. discussion W3. [pmid: 17710701].
32 Malik P. Numeracy. Can J Cardiol. 2007;23(10):777. [pmid: 17703253].
33 Yin HS, Forbis SG, Dreyer BP. Health literacy and pediatric health. Curr Probl Pediatr Adolesc Health Care. 2007;37(7):258-86. [pmid: 17656324].
34 Chisholm MA, Fair J, Spivey CA. Health literacy and transplant patients and practitioners. Public Health. 2007;121(10):800-3. [pmid: 17574640].
35 Murphy-Knoll L. Low health literacy puts patients at risk: the Joint Commission proposes solutions to national problem. J Nurs Care Qual. 2007;22(3):205-9. [pmid: 17563587].
36 Ross J. Health literacy and its influence on patient safety. J Perianesth Nurs. 2007;22(3):220-2. [pmid: 17543808].
37 Larson L. Health literacy: how are your patients reading you?. Trustee. 2007;60(5):8-12. 1.
38 White paper underscores patient health literacy. ED Manag. 2007;19(5):3-4.
39 Valenti WM. Health literacy, HIV and outcomes. AIDS Read. 2007;17(3):124-6. 128. [pmid: 17396329].
40 Barrett SE, Puryear JS. Health literacy: improving quality of care in primary care settings. J Health Care Poor Underserved. 2006;17(4):690-7. [pmid: 17242524].
41 McCabe JA. An assignment for building an awareness of the intersection of health literacy and cultural competence skills. J Med Libr Assoc. 2006;94(4):458-61. [pmid: 17082843].
42 Wilson J. Meeting the health literacy needs of clients. Nurs N Z. 2006;12(7):18-9. [pmid: 17076295].
43 Rootman I. Health literacy: where are the Canadian doctors?. Cmaj. 2006;175(6):606. [pmid: 16966665].
44 Kripalani S, Weiss BD. Teaching about health literacy and clear communication. J Gen Intern Med. 2006;21(8):888-90. [pmid: 16881953].
45 Baker DW. The meaning and the measure of health literacy. J Gen Intern Med. 2006;21(8):878-83. [pmid: 16881951].
46 Lloyd LL, Ammary NJ, Epstein LG, Johnson R, Rhee K. A transdisciplinary approach to improve health literacy and reduce disparities. Health Promot Pract. 2006;7(3):331-5. [pmid: 16760237].
47 Brown L, Upchurch G, Frank SK. Low health literacy: what pharmacists can do to help. J Am Pharm Assoc (2003). 2006;46(1):4-11. [pmid: 16529335].
48 Wallace L. Patients' health literacy skills: the missing demographic variable in primary care research. Ann Fam Med. 2006;4(1):85-6. [pmid: 16449402].
49 NQF looks to improve informed consent for individuals with limited health literacy. Qual Lett Healthc Lead. 2005;17(10):13-4.
50 Carmona RH. Improving Americans' health literacy. J Am Diet Assoc. 2005;105(9):1345. [pmid: 16129071].
51 Mantone J. Reading, writing and relating. Providers--rural and urban--urged to pay more attention to health literacy. Mod Healthc. 2005;35(32):30-1.
52 Hamilton S. How do we assess the learning style of our patients?. Rehabil Nurs. 2005;30(4):129-31. [pmid: 15999856].
53 Gillis DE, MacIsaac A, Quigley Allan B, Shively J. Health literacy: expanding practitioners' horizons through collaborative research. J Interprof Care. 2004;18(4):449-51. [pmid: 15801563].
54 Fitzgerald N. Health literacy and your practice. Mich Med. 2005;104(1):22. [pmid: 15751381].
55 Hardin LR. Counseling patients with low health literacy. Am J Health Syst Pharm. 2005;62(4):364-5. [pmid: 15745888].
56 Rothschild B. Health literacy: what the issue is, what is happening, and what can be done. Health Promot Pract. 2005;6(1):8-11. [pmid: 15574521].
57 Murray MD, Young JM, Morrow DG, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. Am J Geriatr Pharmacother. 2004;2(1):53-65. [pmid: 15555479].
58 Gomez E. Web-based tools can help to improve health literacy. ONS News. 2004;19(9):6. [pmid: 15473214].
59 Ortolon K. Clearing the confusion. Physicians turn attention to low health literacy concerns. Tex Med. 2004;100(6):49-51.
60 Dubow J. Adequate literacy and health literacy: prerequisites for informed health care decision making. Issue Brief (Public Policy Inst (Am Assoc Retired Pers)). 2004;(IB70):1-11. [pmid: 15243980].
61 Young D. Low health literacy is high among Americans, studies say. Am J Health Syst Pharm. 2004;61(10):986-7. [pmid: 15160772].
62 Hixon AL. Functional health literacy: improving health outcomes. Am Fam Physician. 2004;69(9):2077-8. [pmid: 15152955].
63 Peota C. Health literacy and patient safety. Minn Med. 2004;87(4):32-4. [pmid: 15144160].
64 Vastag B. Low health literacy called a major problem. Jama. 2004;291(18):2181-2. [pmid: 15138230].
65 Lee CS, Shiu AT. Perceived health care climate, diabetes knowledge and self-care practice of Hong Kong Chinese older patients: a pilot study. J Clin Nurs. 2004;13(4):534-5. [pmid: 15086640].
66 Devereux J. Nursing. Low health literacy: a covert barrier to patient self-management. HIV Clin. 2004;16(1):12-4. [pmid: 15052990].
67 Evans T. Why health literacy matters. Iowa Med. 2003;93(6):6.
68 Payne JG, Schulte SK. Mass media, public health, and achieving health literacy. J Health Commun. 1. 2003;8:124-5. [pmid: 14692579].
69 Zarcadoolas C, Pleasant A, Greer DS. Elaborating a definition of health literacy: a commentary. J Health Commun. 1. 2003;8:119-20. [pmid: 14692577].
70 Parker RM, Gazmararian JA. Health literacy: essential for health communication. J Health Commun. 1. 2003;8:116-8. [pmid: 14692576].
71 Francis C, Pirkis JE, Blood RW, Burgess PM, Dunt DR. Media reporting of specific mental illnesses in the context of crime: implications for mental health literacy. Med J Aust. 2003;179(11-12):638. [pmid: 14636140].
72 Sass HM. New options for health care policy and health status insurance: citizens as customers. Croat Med J. 2003;44(5):562-7. [pmid: 14515414].
73 Feifer R. How a few simple words improve patients' health. Manag Care Q. 2003;11(2):29-31. [pmid: 12968440].
74 Hochhauser M. The continuing critical issue is health literacy. Manag Care Interface. 2003;16(8):23-4. 29. [pmid: 12964549].
75 Putting the spotlight on health literacy to improve quality care. Qual Lett Healthc Lead. 2003;15(7):2-11. 1.
76 Parker RM, Ratzan SC, Lurie N. Health literacy: a policy challenge for advancing high-quality health care. Health Aff (Millwood). 2003;22(4):147-53. [pmid: 12889762].
77 Mayer GG, Villaire M. Health literacy: an ethical responsibility. Mitigating the negative impact of low health literacy is an ethical imperative. Healthc Exec. 2003;18(4):50-1. [pmid: 12841058].
78 Hutton BM. Numeracy must become a priority for nurses. Br J Nurs. 2000;9(14):894. [pmid: 11261023].
79 LeFevre JA. Research on the development of academic skills: introduction to the special issue on early literacy and early numeracy. Can J Exp Psychol. 2000;54(2):57-64. [pmid: 10881390].
80 Hutton M. Numeracy skills for intravenous calculations. Nurs Stand. 1998;12(43):49-52. quiz 55-6. [pmid: 9776933].
81 Low literacy levels can limit effectiveness of DM programs. Dis Manag Advis. 2003;9(5):65-9. [pmid: 12825392].
82 Ferrell DK, DeBord CL. Make computer-based training user-friendly. Nurs Manage. 2003;(Suppl):30-1. [pmid: 14574185].
83 Hill SC, Lindsay GB. Using health infomercials to develop media literacy skills. J Sch Health. 2003;73(6):239-41. [pmid: 12899106].
84 Kordella T. Research profile. A new tack. Overcoming low literacy in minorities. Diabetes Forecast. 2003;56(1):136-8. [pmid: 14765417].
85 Rudd RE, Comings JP, Hyde JN. Leave no one behind: improving health and risk communication through attention to literacy. J Health Commun. 1. 2003;8:104-15. [pmid: 14692575].
86 Treiman R, Kessler B. The role of letter names in the acquisition of literacy. Adv Child Dev Behav. 2003;31:105-35. [pmid: 14528660].
87 Wilson JF. The crucial link between literacy and health. Ann Intern Med. 2003;139(10):875-8. [pmid: 14623636].
88 Intensive approach pays off in diabetics with low literacy skills. Dis Manag Advis. 2004;10(12):133-7. [pmid: 15673127].
89 Applegate KE, Crewson PE. Statistical literacy. Radiology. 2004;230(3):613-4. [pmid: 14990828].
90 Duke R. Easy as ABC? Low literacy rates in Arkansas are causing problems with health care. J Ark Med Soc. 2004;100(10):345-7. [pmid: 15080274].
91 Gates EA. Communicating risk in prenatal genetic testing. J Midwifery Womens Health. 2004;49(3):220-7. [pmid: 15134675].
92 Jones MW, Englestad DM. “Womb” literacy: reading to infants in the NICU. Neonatal Netw. 2004;23(4):65-9. [pmid: 15317385].
93 Mayuzumi K. Rethinking literacy and women's health: a Bangladesh case study. Health Care Women Int. 2004;25(6):504-26. [pmid: 15354619].
94 Pokhrel D, Viraraghavan T. Diarrhoeal diseases in Nepal vis-a-vis water supply and sanitation status. J Water Health. 2004;2(2):71-81. [pmid: 15387131].
95 Roman SP. Illiteracy and older adults: Individual and societal implications. Educational Gerontology. 2004;30(2):79-93.
96 Rootman I. Health promotion and literacy: implications for nursing. Can J Nurs Res. 2004;36(1):13-21. [pmid: 15133916].
97 Stein K. Cultural literacy in health care. J Am Diet Assoc. 2004;104(11):1657-9. [pmid: 15499349].
98 Ownby RL. Medication adherence and health care literacy: filling in the gap between efficacy and effectiveness. Curr Psychiatry Rep. 2005;7(1):1-2. [pmid: 15717976].
99 Robinson S, Lawson S. Evaluating the impact of Information Skills Training within primary care. Health Info Libr J. 2005;22(1):63-5. [pmid: 15810933].
100 Rudd RE, Horowitz AM. Health and literacy: supporting the oral health research agenda. J Public Health Dent. 2005;65(3):131-2. [pmid: 16171256].
101 Literacy and health practice resources. Can J Public Health. 2. 2006;97:S14-5. [pmid: 16805155].
102 Wardle J. Make sure your patients understand discharge plan: low health literacy contributes to readmissions. Patient Education Management. 2006;13(4):45-48.
103 Davis LJ. Life, death, and biocultural literacy. Chron High Educ. 2006;52(18):B9-10. [pmid: 16459383].
104 Greenberg D, Lackey J. The importance of adult literacy issues in social work practice. Soc Work. 2006;51(2):177-9. [pmid: 16858924].
105 Kendig S. Word power: The effect of literacy on health outcomes. AWHONN Lifelines. 2006;10(4):327-31. [pmid: 16911266].
106 Lunney M. Helping nurses use NANDA, NOC, and NIC: novice to expert. J Nurs Adm. 2006;36(3):118-25. [pmid: 16601513].
107 Maag M. Podcasting and MP3 players: emerging education technologies. Comput Inform Nurs. 2006;24(1):9-13. [pmid: 16436906].
108 O'Hare A. Acquiring literacy in the face of severe speech and physical impairments. Dev Med Child Neurol. 2006;48(8):628. [pmid: 16836772].
109 Paasche-Orlow MK, Schillinger D, Greene SM, Wagner EH. How health care systems can begin to address the challenge of limited literacy. J Gen Intern Med. 2006;21(8):884-7. [pmid: 16881952].
110 Pravikoff DS. Mission critical: a culture of evidence-based practice and information literacy. Nurs Outlook. 2006;54(4):254-5. [pmid: 16929570].
111 Seasholtz SI. Financial literacy--no nurse left behind. Am Nurse. 2006;38(3):9. [pmid: 16833075].
112 Simpson RL. What's nursing's PLAN for IT ubiquity?. Nurs Manage. 2006;37(9):12. 16. [pmid: 16983231].
113 Snow CE, Beals DE. Mealtime talk that supports literacy development. New Dir Child Adolesc Dev. 2006;(111):51-66. [pmid: 16646499].
114 Stopforth L. Driving the roll out. Nurses and new communication technologies. Nurs N Z. 2006;12(10):17. [pmid: 17319204].
115 An emerging giant: nursing informatics. Nurs Manage. 2007;38(3):38-42.
116 Allen D. You're never too old for a Wii. Nurs Older People. 2007;19(8):8.
117 Baerlocher MO. Adult literacy rates in African and Eastern Mediterranean countries. Can Med Assoc J. 2007;177(11):1347. [pmid: 18025423].
118 Boehl T. Linguistic issues and literacy barriers in nutrition. J Am Diet Assoc. 2007;107(3):380-3. [pmid: 17415943].
119 Booth A. In search of the information literacy training ‘half-life’. Health Info Libr J. 2007;24(2):145-9. [pmid: 17584219].
120 Callister LC. Improving literacy in women and girls globally. MCN Am J Matern Child Nurs. 2007;32(3):194. [pmid: 17479059].
121 Chepesiuk R. Environmental literacy: knowledge for a healthier public. Environ Health Perspect. 2007;115(10):A494-9. [pmid: 17938718].
122 Curran C, Sheets D, Kirkpatrick B, Bauldoff GS. Virtual patients support point-of-care nursing education. Nurs Manage. 2007;38(12):27-33. [pmid: 18188006].
123 Delaney C. Nursing and informatics for the 21st century: a conversation with Connie Delaney, PhD, RN, FAAN, FACMI. Interview by Joan Karnas. Creat Nurs. 2007;13(2):4-6. [pmid: 18232581].
124 Fleming J. Health literacy. RDH. 2007;27(3):48.
125 Low AK, Grothe KB, Wofford TS, Bouldin MJ. Addressing disparities in cardiovascular risk through community-based interventions. Ethn Dis. 2007;17(2 Suppl 2):S2-55-9. [pmid: 17684816].
126 X1Lurie N, Parker R. Editorial: moving health literacy from the individual to the community. American Journal of Health Behavior. 2007;31:S6-7. [pmid: 17931138].
127 Mackenzie B. Sustained efforts should promote statistics literacy in physiology Commentary on “Guidelines for reporting statistics in journals published by the American Physiological Society: the sequel”. Adv Physiol Educ. 2007;31(4):305. discussion 306-7. [pmid: 18057398].
128 Mastrian K, McGonigle D, Pavlekovsky K. Information systems and case management practice series, part III: case management is implementation processes, additional technology tools, and future directions. Prof Case Manag. 2007;12(5):296-9. [pmid: 17885637].
129 Miller VM. Poor eHealth literacy and consumer-directed health plans: a recipe for market failure. Am J Bioeth. 2007;7(11):20-2. discussion W1-2. [pmid: 18027293].
130 Murer CG. EHRs: issues preventing widespread adoption. Rehab Manag. 2007;20(5):38-9.
131 Nagle LM. Everything I know about informatics, I didn't learn in nursing school. Nurs Leadersh (Tor Ont). 2007;20(3):22-5. [pmid: 17987824].
132 Nagle LM. Infoway's EHR user engagement strategy. Nurs Leadersh (Tor Ont). 2007;20(2):31-3. [pmid: 17619593].
133 Nelson R. Electronic health records: useful tools or high-tech headache?. Am J Nurs. 2007;107(3):25-6.
134 Pank CM. Online education. Am J Nurs. 2007;107(5):74-6. [pmid: 17443089].
135 Robles J, Karnas J. The electronic medical record: shifting the paradigm. A conversation with Jane Robles and Joan Karnas. Interview by Beth Beaty. Creat Nurs. 2007;13(2):7-9. [pmid: 18232582].
136 Schillinger D. Literacy and health communication: reversing the ‘inverse care law’. Am J Bioeth. 2007;7(11):15-8. discussion W1-2. [pmid: 18027291].
137 Sensmeier J. The future of IT? Aggressive educational reform. TIGER initiative preps nurses for healthcare's digital era. Nurs Manage. 2007;(Suppl):2. 4. 6. passim. [pmid: 18159649].
138 Spalla TL, Nininger JM, Daley LK. You've got mail: a new tool to help millennials prepare for the national council licensure examination. Nurse Educ. 2007;32(2):52-4. [pmid: 17496817].
139 Thobaben M. Health literacy and elderly home health clients. Home Health Care Management & Practice. 2007;19(6):478-479.
140 Wheeler DP, Goodman H. Health and mental health social workers need information literacy skills. Health Soc Work. 2007;32(3):235-7. [pmid: 17896682].
141 Andretta S. Promoting reflective information literacy practice through Facilitating Information Literacy Education (FILE). Health Info Libr J. 2008;25(2):150-3. [pmid: 18494650].
142 Chapman L. Effective teamwork. Nurs Manag (Harrow). 2008;15(6):18-21. [pmid: 18982881].
143 Costa DM. Facilitating health literacy. OT Practice. 2008;13(15):13.
144 DeCastro J, Stone B. Improving therapeutic outcomes in BPH through diagnosis, treatment and patient compliance. Am J Med. 2008;121(8 Suppl 2):S27-33. [pmid: 18675614].
145 Delaney C. Facilitating cultural competence and computer literacy in RN-to-BSN. J Nurs Educ. 2008;47(5):240. [pmid: 18522158].
146 Dougall A, Fiske J. Access to special care dentistry, part 3. Consent and capacity. Br Dent J. 2008;205(2):71-81. [pmid: 18660768].
147 Dragon N. Leaving the paper trail behind. Aust Nurs J. 2008;16(1):22-5. [pmid: 18727263].
148 Hijazi ZM, Marshall JJ. Seconds-Count.org offers enhanced tools for patients and physicians. Catheter Cardiovasc Interv. 2008;72(7):1027-9. [pmid: 19031412].
149 Hughes S, Dennison CR. Progress in prevention: how can we help patients seek information on the World Wide Web?: an opportunity to improve the “net effect”. J Cardiovasc Nurs. 2008;23(4):324-5. [pmid: 18596493].
150 Innes G. Faculty-librarian collaboration: an online information literacy tutorial for students. Nurse Educ. 2008;33(4):145-6. [pmid: 18600151].
151 Skiba DJ. Moving forward: the informatics agenda. Nurs Educ Perspect. 2008;29(5):300-1. [pmid: 18834061].
152 Skiba DJ, DuLong D. Using TIGER vision to move your agenda forward. Nurs Manage. 2008;39(3):14-6. [pmid: 18414219].
153 Zuniga JM. Promoting HIV literacy. J Int Assoc Physicians AIDS Care (Chic Ill). 2008;7(5):215-6.
154 Brown T. Literacy and healthcare: the challenge of communication in home healthcare and hospice. Home Healthc Nurse. 2009;27(1):55-9. [pmid: 19114788].
155 Craig E. Better informed for better health and better care: an information literacy framework to support health care in Scotland. Health Info Libr J. 2009;26(1):77-80. [pmid: 19245647].
156 Fetter MS. Health information literacy and mental health nursing. Issues Ment Health Nurs. 2009;30(1):64-5. [pmid: 19148825].
157 Krumwiede N. What challenges do you see when caring for patients in a rural area? Access, health literacy, and health disparities are concerns. ONS Connect. 2009;24(7):13. [pmid: 19645158].
158 Goske MJ, Bulas D. Improving health literacy: informed decision-making rather than informed consent for CT scans in children. Pediatr Radiol. 2009;39(9):901-3. [pmid: 19557404].
159 Oates DJ, Silliman RA. Health literacy: improving patient understanding. Oncology (Williston Park). 2009;23(4):376. 379. [pmid: 19476268].
160 Worley S, Didiza Z, Nomatshila S, et al. Wellness programmes for persons living with HIV/AIDS: experiences from Eastern Cape province, South Africa. Glob Public Health. 2009;4(4):367-85. [pmid: 19343601].
161 Wolff K, Cavanaugh K, Malone R, et al. The Diabetes Literacy and Numeracy Education Toolkit (DLNET): materials to facilitate diabetes education and management in patients with low literacy and numeracy skills. Diabetes Educ. 2009;35(2):233-6. 238. 41. 244. 5. [pmid: 19240246].
162 Cutilli CC, Bennett IM. Understanding the health literacy of America: results of the National Assessment of Adult Literacy. Orthop Nurs. 2009;28(1):27-32. quiz 33-4. [pmid: 19190475].
163 A health literacy example: revising a HIPAA privacy notice. ASHA Leader. 2009;14(2):29.
164 Meehan D. Building a stronger foundation: raising health literacy awareness. Med Surg Matters. 2009;18(4):16-8.
165 Bulletin board AHRQ launches health literacy measurement tools. Journal of AHIMA. 2009;80(3):12.
166 Family council can help make materials readable: revamping written handout distribution. Patient Education Management. 2009;16(4):42.
167 Hasselkus A, Moxley A. Health literacy at the intersection of cultures Last in a three-part series. ASHA Leader. 2009;14(4):30-1.
168 Hasselkus A. Health literacy in clinical practice first in a three-part series. ASHA Leader. 2009;14(1):28-9.
169 Kohler D. Health literacy: improving comprehension and adherence of written patient instructions by simplifying educational materials at or below a sixth-grade reading level. Gastroenterology Nursing. 2009;32(2):143.
170 Health literacy: one pillar of patient education. Briefings on Patient Safety. 2009;10(6):6-8.
171 Jones CM. Internet resources: health literacy. MLA News. 2009;416:11.
172 Iowa Health System addresses health literacy within state facilities by adopting patient-centered approaches. Briefings on Patient Safety. 2009;10(3):5-6.
173 Lack of compliance may mean patients don't understand. Case Management Advisor. 2009;20(8):85-7.
174 Lack of compliance may mean patients misunderstand: low health literacy contributes to readmissions. Patient Education Management. 2009;16(9):103-5.
175 Log on for health literacy materials. American Dental Association News. 2009;40(2):11.
176 Owens J. OJIN tackles health literacy. American Nurse. 2009;41(5):6. [pmid: 19731571].
177 Sullivan CH. Partnering with community agencies to provide nursing students with cultural awareness experiences and refugee health promotion access. Journal of Nursing Education. 2009;48(9):519-22. [pmid: 19645368].
178 Wicklund K, Ramos K. Plain language: effective communication in the health care setting. Journal of Hospital Librarianship. 2009;9(2):177-85.
179 Volunteers address low health literacy: provide someone to teach tasks. Patient Education Management. 2009;16(5):54-5.
180 Denham SA. Diabetes: A family matter. Journal of Family Nursing. 2009;15(3):400-401. [pmid: 19622843].
181 Peregrin T. Picture this: visual cues enhance health education messages for people with low literacy skills. J Am Diet Assoc. 2010;110(4):500-5. [pmid: 20338272].
182 Warburton P. Poor numeracy skills must be tackled to cut medication errors. Nurs Times. 2010;106(9):13. [pmid: 20344984].
183 D'Alessandro DM. Challenges and options for patient education in the office setting. Pediatr Ann. 2010;39(2):78-83. [pmid: 20166636].
184 Glass AP, Butler DQ. Health literacy and older adults. J Am Geriatr Soc. 2010;58(1):152-3. [pmid: 20122046].
185 Pattishall AE, Spector ND. Vitamin D deficiency, eosinophilic esophagitis, and health literacy. Curr Opin Pediatr. 2009;21(6):817-23. [pmid: 19797953].
186 Fetter MS. Promoting health literacy with vulnerable behavioral health clients. Issues Ment Health Nurs. 2009;30(12):798-802. [pmid: 19916815].
187 Abrams MA, Klass P, Dreyer BP. Health literacy and children: recommendations for action. Pediatrics. 3. 2009;124:S327-31. [pmid: 19861487].
188 Sullivan LW. Promoting health literacy and health behaviors. Breastfeed Med. 1. 2009;4:S67. [pmid: 19827930].
189 Horowitz AM. The role of health literacy in reducing health disparities. J Dent Hyg. 2009;83(4):182-3. [pmid: 19909638].
190 Klass P, Dreyer BP, Mendelsohn AL. Reach out and read: literacy promotion in pediatric primary care. Adv Pediatr. 2009;56:11-27. [pmid: 19968940].
191 AHRQ introduces new Pharmacy Health Literacy Center. AHRQ Research Activities. 2009;(352):21-21.
192 AHRQ releases a new health literacy tool. AHRQ Research Activities. 2010;(354):18-18.
193 Awards aim to promote health literacy. World of Irish Nursing & Midwifery. 2010;18(1). [39].
194 Better educational materials are needed to boost the health literacy of individuals who are deaf. AHRQ Research Activities. 2009;(352):8-8.
195 Glover C. Have you thought about your patients' health literacy today?. AAACN Viewpoint. 2010;32(1):3-4.
196 Health literacy competencies staff should have. Patient Education Management. 2010;17(3):29-29.
197 Health literacy is linked to personal happiness. AHRQ Research Activities. 2009;(350):12-12.
198 Susic J. Health literacy. NIHSeniorHealth classes for senior citizens at a public library in Louisiana. Journal of Consumer Health on the Internet. 2009;13(4):417-419.
199 Villaire M, Mayer G. Health literacy: the low-hanging fruit in health care reform. Journal of Health Care Finance. 2009;36(2):55-59. [pmid: 20499721].
200 Crozier S. House directs continued action on health literacy in dentistry. American Dental Association News. 2009;40(22):24-25.
201 Wessling MN. Success stories in health literacy. AMWA Journal: American Medical Writers Association Journal. 2010;25(1):17-18.
202 Dunn DJ. The nurse role in health literacy. Florida Nurse. 2010;58(1):14-14.
203 Harrington S. Thinking about the daily realities of diversity and health literacy. AORN Connections. 2009;7(12):2p.
204 To improve health literacy, follow QI model: goal is to create a culture change. Healthcare Benchmarks & Quality Improvement. 2010;17(1):10-10. [pmid: 20121010].
205 To improve health literacy, follow Ql model: goal is to create a culture change. Patient Education Management. 2009;16(11):124-125.
206 Clement S, Ibrahim S, Crichton N, Wolf M, Rowlands G. Complex interventions to improve the health of people with limited literacy: a systematic review (Structured abstract). Patient Education and Counseling. 2009;(3):340-351. [pmid: 19261426].

## SER only

1 Bennett IM, Kripalani S, Weiss BD, Coyne CA. Combining cancer control information with adult literacy education: opportunities to reach adults with limited literacy skills. Cancer Control. 2003;10(5 Suppl):81-3. [pmid: 14581908].
2 Berkman ND, Dewalt DA, Pignone MP, et al. Literacy and health outcomes. Evid Rep Technol Assess (Summ). 2004;(87):1-8. [pmid: 15819598].
3 Mancuso JM. Assessment and measurement of health literacy: an integrative review of the literature. Nurs Health Sci. 2009;11(1):77-89. [pmid: 19298313].

## Studies that do not measure literacy or health literacy

1 Latham CL, Calvillo E. A health protection model for Hispanic adults with Type 2 diabetes. J Clin Nurs. 2007;16(7B):186-96. [pmid: 17584428].
2 Frew PM, del Rio C, Lu L, Clifton S, Mulligan MJ. Understanding differences in enrollment outcomes among high-risk populations recruited to a phase IIb HIV vaccine trial. J Acquir Immune Defic Syndr. 2009;50(3):314-9. [pmid: 19194310].
3 Voracek M, Loibl LM, Swami V, et al. The beliefs in the inheritance of risk factors for suicide scale (BIRFSS): cross-cultural validation in Estonia, Malaysia, Romania, the United Kingdom, and the United States. Suicide Life Threat Behav. 2008;38(6):688-98. [pmid: 19152299].
4 Rana AK, Wahlin A, Lundborg CS, Kabir ZN. Impact of health education on health-related quality of life among elderly persons: results from a community-based intervention study in rural Bangladesh. Health Promot Int. 2009;24(1):36-45. [pmid: 19136677].
5 Bousamra M, Kloecker G, Herbig S. Drive cancer out: a physician-led anti-smoking program directed at teens and adolescents. J Ky Med Assoc. 2008;106(12):561-5. [pmid: 19130873].
6 Laditka JN, Laditka SB, Eleazer GP, Cornman CB, Porter CN, Davis DR. High variation in Alzheimer's disease prevalence among South Carolina counties. J S C Med Assoc. 2008;104(7):215-8. [pmid: 19058733].
7 Fraser E, Pakenham KI. Evaluation of a resilience-based intervention for children of parents with mental illness. Aust N Z J Psychiatry. 2008;42(12):1041-50. [pmid: 19016092].
8 Cohen LA, Bonito AJ, Akin DR, et al. Toothache pain: a comparison of visits to physicians, emergency departments and dentists. J Am Dent Assoc. 2008;139(9):1205-16. [pmid: 18762631].
9 Yin HS, Dreyer BP, van Schaick L, Foltin GL, Dinglas C, Mendelsohn AL. Randomized controlled trial of a pictogram-based intervention to reduce liquid medication dosing errors and improve adherence among caregivers of young children. Arch Pediatr Adolesc Med. 2008;162(9):814-22. [pmid: 18762597].
10 Volk RJ, Jibaja-Weiss ML, Hawley ST, et al. Entertainment education for prostate cancer screening: a randomized trial among primary care patients with low health literacy. Patient Educ Couns. 2008;73(3):482-9. [pmid: 18760888].
11 Hawley ST, Zikmund-Fisher B, Ubel P, Jancovic A, Lucas T, Fagerlin A. The impact of the format of graphical presentation on health-related knowledge and treatment choices. Patient Educ Couns. 2008;73(3):448-55. [pmid: 18755566].
12 Smith B, Chu LK, Smith TC, et al. Challenges of self-reported medical conditions and electronic medical records among members of a large military cohort. BMC Med Res Methodol. 2008;8:37. [pmid: 18644098].
13 Donelle L, Hoffman-Goetz L. An exploratory study of canadian aboriginal online health care forums. Health Commun. 2008;23(3):270-81. [pmid: 18569056].
14 Ishikawa H, Nomura K, Sato M, Yano E. Developing a measure of communicative and critical health literacy: a pilot study of Japanese office workers. Health Promot Int. 2008;23(3):269-74. [pmid: 18515303].
15 Greenhalgh T, Wood GW, Bratan T, Stramer K, Hinder S. Patients' attitudes to the summary care record and HealthSpace: qualitative study. Bmj. 2008;336(7656):1290-5. [pmid: 18511764].
16 Olendzki BC, Ma Y, Hebert JR, et al. Underreporting of energy intake and associated factors in a Latino population at risk of developing type 2 diabetes. J Am Diet Assoc. 2008;108(6):1003-8. [pmid: 18502234].
17 Maniaci MJ, Heckman MG, Dawson NL. Functional health literacy and understanding of medications at discharge. Mayo Clin Proc. 2008;83(5):554-8. [pmid: 18452685].
18 Farrer L, Leach L, Griffiths KM, Christensen H, Jorm AF. Age differences in mental health literacy. BMC Public Health. 2008;8:125. [pmid: 18423049].
19 IJurg ME, De Meij JS, Van der Wal MF, Koelen MA. Using health promotion outcomes in formative evaluation studies to predict success factors in interventions: an application to an intervention for promoting physical activity in Dutch children (JUMP-in). Health Promot Int. 2008;23(3):231-9. [pmid: 18408231].
20 Chang C. Increasing mental health literacy via narrative advertising. J Health Commun. 2008;13(1):37-55. [pmid: 18307135].
21 Guerra CE, McDonald VJ, Ravenell KL, Asch DA, Shea JA. Effect of race on patient expectations regarding their primary care physicians. Fam Pract. 2008;25(1):49-55. [pmid: 18304974].
22 Blanson Henkemans OA, Rogers WA, Fisk AD, Neerincx MA, Lindenberg J, van der Mast CA. Usability of an adaptive computer assistant that improves self-care and health literacy of older adults. Methods Inf Med. 2008;47(1):82-8. [pmid: 18213433].
23 Marie D, Miles B. Social distance and perceived dangerousness across four diagnostic categories of mental disorder. Aust N Z J Psychiatry. 2008;42(2):126-33. [pmid: 18197507].
24 Dahlberg KM, Waern M, Runeson B. Mental health literacy and attitudes in a Swedish community sample - investigating the role of personal experience of mental health care. BMC Public Health. 2008;8:8. [pmid: 18184424].
25 Voracek M, Loibl LM, Sonneck G. Beliefs in the Inheritance of Risk Factors for Suicide Scale: development, reliability, stability, and convergent and discriminant validity. Psychol Rep. 2007;101(1):107-16. [pmid: 17958114].
26 Harper W, Cook S, Makoul G. Teaching medical students about health literacy: 2 Chicago initiatives. Am J Health Behav. 1. 2007;31:S111-4. [pmid: 17931129].
27 Goto R, Nishimura S, Ida T. Discrete choice experiment of smoking cessation behaviour in Japan. Tob Control. 2007;16(5):336-43. [pmid: 17897993].
28 Nimmon LE. Within the eyes of the people: using a photonovel as a consciousness-raising health literacy tool with ESL-speaking immigrant women. Can J Public Health. 2007;98(4):337-40. [pmid: 17896748].
29 O'Callaghan C, Quine S. How older Vietnamese Australian women manage their medicines. J Cross Cult Gerontol. 2007;22(4):405-19. [pmid: 17846877].
30 Wang J, Adair C, Fick G, et al. Depression literacy in Alberta: findings from a general population sample. Can J Psychiatry. 2007;52(7):442-9. [pmid: 17688008].
31 Kaneko Y, Motohashi Y. Male gender and low education with poor mental health literacy: a population-based study. J Epidemiol. 2007;17(4):114-9. [pmid: 17641446].
32 Guerra CE, Jacobs SE, Holmes JH, Shea JA. Are physicians discussing prostate cancer screening with their patients and why or why not? A pilot study. J Gen Intern Med. 2007;22(7):901-7. [pmid: 17549576].
33 Goldney RD, Taylor AW, Bain MA. Depression and remoteness from health services in South Australia. Aust J Rural Health. 2007;15(3):201-10. [pmid: 17542794].
34 Hepworth NS, Paxton SJ, Williams B. Predictors of attitudes towards treatments for bulimia nervosa. Aust N Z J Psychiatry. 2007;41(3):247-56. [pmid: 17464706].
35 Akoijam BS, Thangjam ND, Singh KT, Devi SR, Devi RK. Birth weight pattern in the only referral teaching hospital in Manipur. Indian J Public Health. 2006;50(4):220-4. [pmid: 17444050].
36 Naito M, Nakayama T, Hamajima N. Health literacy education for children: acceptability of a school-based program in oral health. J Oral Sci. 2007;49(1):53-9. [pmid: 17429183].
37 Primack BA, Bui T, Fertman CI. Social marketing meets health literacy: Innovative improvement of health care providers' comfort with patient interaction. Patient Educ Couns. 2007;68(1):3-9. [pmid: 17418522].
38 Miller EA, West DM. Characteristics associated with use of public and private web sites as sources of health care information: results from a national survey. Med Care. 2007;45(3):245-51. [pmid: 17304082].
39 Boissy P, Briere S, Tousignant M, Rousseau E. The eSMAF: a software for the assessment and follow-up of functional autonomy in geriatrics. BMC Geriatr. 2007;7:2. [pmid: 17298673].
40 Olney CA, Warner DG, Reyna G, Wood FB, Siegel ER. MedlinePlus and the challenge of low health literacy: findings from the Colonias project. J Med Libr Assoc. 2007;95(1):31-9. [pmid: 17252064].
41 Dailey R, Schwartz KL, Binienda J, Moorman J, Neale AV. Challenges in making therapeutic lifestyle changes among hypercholesterolemic African-American patients and their physicians. J Natl Med Assoc. 2006;98(12):1895-903. [pmid: 17225831].
42 Hiscock H, Canterford L, Ukoumunne OC, Wake M. Adverse associations of sleep problems in Australian preschoolers: national population study. Pediatrics. 2007;119(1):86-93. [pmid: 17200274].
43 Kuper H, Adami HO, Theorell T, Weiderpass E. The socioeconomic gradient in the incidence of stroke: a prospective study in middle-aged women in Sweden. Stroke. 2007;38(1):27-33. [pmid: 17138948].
44 McGinn T, Allen K. Improving refugees' reproductive health through literacy in Guinea. Glob Public Health. 2006;1(3):229-48. [pmid: 19153909].
45 Lieberman A, Harris D. Acknowledging adult bias: a focus-group approach to utilizing beauty salons as health-education portals for inner-city adolescent girls. Health Promot Pract. 2007;8(2):205-13. [pmid: 16980570].
46 Lo S, Sharif I, Ozuah PO. Health literacy among English-speaking parents in a poor urban setting. J Health Care Poor Underserved. 2006;17(3):504-11. [pmid: 16960318].
47 Al-Harazi AH. Obstructed labor. A real problem in Yemeni s rural areas. Saudi Med J. 2006;27(9):1435-6. [pmid: 16951795].
48 Bell JA, Patel B, Malasanos T. Knowledge improvement with web-based diabetes education program: brainfood. Diabetes Technol Ther. 2006;8(4):444-8. [pmid: 16939369].
49 Wu TY, Bancroft J. Filipino American women's perceptions and experiences with breast cancer screening. Oncol Nurs Forum. 2006;33(4):E71-8. [pmid: 16858450].
50 Barbarin O, Bryant D, McCandies T, et al. Children enrolled in public pre-K: the relation of family life, neighborhood quality, and socioeconomic resources to early competence. Am J Orthopsychiatry. 2006;76(2):265-76. [pmid: 16719646].
51 Chung JH, Voss KJ, Caughey AB, Wing DA, Henderson EJ, Major CA. Role of patient education level in predicting macrosomia among women with gestational diabetes mellitus. J Perinatol. 2006;26(6):328-32. [pmid: 16642026].
52 Pappas G, Siozopoulou V, Saplaoura K, et al. Health literacy in the field of infectious diseases: the paradigm of brucellosis. J Infect. 2007;54(1):40-5. [pmid: 16533534].
53 McCormick MC, Brooks-Gunn J, Buka SL, et al. Early intervention in low birth weight premature infants: results at 18 years of age for the Infant Health and Development Program. Pediatrics. 2006;117(3):771-80. [pmid: 16510657].
54 Mansoor LE, Dowse R. Medicines information and adherence in HIV/AIDS patients. J Clin Pharm Ther. 2006;31(1):7-15. [pmid: 16476115].
55 Routh K, Rao JN, Denley J. A simple, and potentially low-cost method for measuring the prevalence of childhood obesity. Child Care Health Dev. 2006;32(2):239-45. [pmid: 16441858].
56 Hunter JL. Cervical cancer educational pamphlets: Do they miss the mark for Mexican immigrant women's needs?. Cancer Control. 2. 2005;12:42-50. [pmid: 16327750].
57 Devaney A, Outhwaite H. Learning resource needs of UK NHS support staff. Health Info Libr J. 2005;22(4):253-61. [pmid: 16293167].
58 Abernethy AP, Currow DC, Hunt R, et al. A pragmatic 2 × 2 × 2 factorial cluster randomized controlled trial of educational outreach visiting and case conferencing in palliative care-methodology of the Palliative Care Trial [ISRCTN 81117481]. Contemp Clin Trials. 2006;27(1):83-100. [pmid: 16290094].
59 Zargarzadeh AH, Tavakoli N, Hassanzadeh A. A survey on the extent of medication storage and wastage in urban Iranian households. Clin Ther. 2005;27(6):970-8. [pmid: 16117997].
60 Kalanda BF, van Buuren S, Verhoeff FH, Brabin BJ. Catch-up growth in Malawian babies, a longitudinal study of normal and low birthweight babies born in a malarious endemic area. Early Hum Dev. 2005;81(10):841-50. [pmid: 16109465].
61 Peres K, Verret C, Alioum A, Barberger-Gateau P. The disablement process: factors associated with progression of disability and recovery in French elderly people. Disabil Rehabil. 2005;27(5):263-76. [pmid: 16025753].
62 Palfrey JS, Hauser-Cram P, Bronson MB, Warfield ME, Sirin S, Chan E. The Brookline Early Education Project: a 25-year follow-up study of a family-centered early health and development intervention. Pediatrics. 2005;116(1):144-52. [pmid: 15995045].
63 Sarfaty M, Turner CH, Damotta E. Use of a patient assistant to facilitate medical visits for Latino patients with low health literacy. J Community Health. 2005;30(4):299-307. [pmid: 15989211].
64 Holmes-Rovner M, Stableford S, Fagerlin A, et al. Evidence-based patient choice: a prostate cancer decision aid in plain language. BMC Med Inform Decis Mak. 2005;5:16. [pmid: 15963238].
65 Montazeri A. AIDS knowledge and attitudes in Iran: results from a population-based survey in Tehran. Patient Educ Couns. 2005;57(2):199-203. [pmid: 15911193].
66 Al-Safi SA, Alkofahi AS, El-Eid HS. Public response to chest pain in Jordan. Eur J Cardiovasc Nurs. 2005;4(2):139-44. [pmid: 15904884].
67 Sanchez CD, Newby LK, McGuire DK, Hasselblad V, Feinglos MN, Ohman EM. Diabetes-related knowledge, atherosclerotic risk factor control, and outcomes in acute coronary syndromes. Am J Cardiol. 2005;95(11):1290-4. [pmid: 15904631].
68 Ohnishi M, Nakamura K, Takano T. Improvement in maternal health literacy among pregnant women who did not complete compulsory education: policy implications for community care services. Health Policy. 2005;72(2):157-64. [pmid: 15802151].
69 Atchison KA, Black EE, Leathers R, et al. A qualitative report of patient problems and postoperative instructions. J Oral Maxillofac Surg. 2005;63(4):449-56. [pmid: 15789315].
70 Angus J, Evans S, Lapum J, et al. “Sneaky disease”: the body and health knowledge for people at risk for coronary heart disease in Ontario, Canada. Soc Sci Med. 2005;60(9):2117-28. [pmid: 15743659].
71 Dodani S, Mistry R, Khwaja A, Farooqi M, Qureshi R, Kazmi K. Prevalence and awareness of risk factors and behaviours of coronary heart disease in an urban population of Karachi, the largest city of Pakistan: a community survey. J Public Health (Oxf). 2004;26(3):245-9. [pmid: 15454591].
72 Borrayo EA. Where's Maria? A video to increase awareness about breast cancer and mammography screening among low-literacy Latinas. Prev Med. 2004;39(1):99-110. [pmid: 15207991].
73 Firestone DN, Jimenez-Briceno L, Reimann JO, Talavera GA, Polonsky WH, Edelman SV. Predictors of diabetes-specific knowledge and treatment satisfaction among Costa Ricans. Diabetes Educ. 2004;30(2):281-92. [pmid: 15095518].
74 Kaufman DR, Starren J, Patel VL, et al. A cognitive framework for understanding barriers to the productive use of a diabetes home telemedicine system. AMIA Annu Symp Proc. 2003:356-60.
75 Rosal MC, Carbone ET, Goins KV. Use of cognitive interviewing to adapt measurement instruments for low-literate Hispanics. Diabetes Educ. 2003;29(6):1006-17. [pmid: 14692374].
76 Kaufman DR, Patel VL, Hilliman C, et al. Usability in the real world: assessing medical information technologies in patients' homes. J Biomed Inform. 2003;36(1-2):45-60. [pmid: 14552846].
77 T'Ang J, Chan C, Chan NF, Ng CB, Tse K, Lau L. A survey of elderly diabetic patients attending a community clinic in Hong Kong. Patient Educ Couns. 1999;36(3):259-70. [pmid: 14528561].
78 Dutta-Bergman M. Trusted online sources of health information: differences in demographics, health beliefs, and health-information orientation. J Med Internet Res. 2003;5(3):e21. [pmid: 14517112].
79 Brownhill S, Wilhelm K, Eliovson G, Waterhouse M. ‘For men only’. A mental health prompt list in primary care. Aust Fam Physician. 2003;32(6):443-50. [pmid: 12833772].
80 Adelsward V, Sachs L. The meaning of 6.8: numeracy and normality in health information talks. Soc Sci Med. 1996;43(8):1179-87. [pmid: 8903121].
81 Birtwistle GE, Brodie DA. Children's attitudes towards activity and perceptions of physical education. Health Educ Res. 1991;6(4):465-78. [pmid: 10148703].
82 Adams A, Duffield C. The value of drills in developing and maintaining numeracy skills in an undergraduate nursing programme. Nurse Educ Today. 1991;11(3):213-9. [pmid: 2062280].
83 Echeverry DM, Dike MR, Washington C, Davidson MB. The impact of using a low-literacy patient education tool on process measures of diabetes care in a minority population. J Natl Med Assoc. 2003;95(11):1074-81. [pmid: 14651374].
84 Estape T, Estape J, Grau JJ, Ferrer C. Cancer knowledge among Spanish women participating in literacy schemes. Psychooncology. 2003;12(2):194-7. [pmid: 12619151].
85 Familoni OB, Ariba AJ. Ability of Nigerian hypertensive patients to perceive changes in their blood pressure. Cardiovasc J S Afr. 2003;14(4):195-8. [pmid: 14532961].
86 Gathwala G, Yadav OP, Sangwan K, Singh I, Yadav J. A study on plasma selenium level among pregnant women at Rohtak, Haryana. Indian J Public Health. 2003;47(2):45-8. [pmid: 15129852].
87 Hahn EA, Cellal D, Dobrez DG, et al. Quality of life assessment for low literacy Latinos: a new multimedia program for self-administration. J Oncol Manag. 2003;12(5):9-12. [pmid: 14619989].
88 Jacobs SK, Rosenfeld P, Haber J. Information literacy as the foundation for evidence-based practice in graduate nursing education: a curriculum-integrated approach. J Prof Nurs. 2003;19(5):320-8. [pmid: 14613072].
89 Moore D, Castillo E, Richardson C, Reid RJ. Determinants of health status and the influence of primary health care services in Latin America, 1990-98. Int J Health Plann Manage. 2003;18(4):279-92. [pmid: 14727708].
90 Nirmalan PK, Padmavathi A, Thulasiraj RD. Sex inequalities in cataract blindness burden and surgical services in south India. Br J Ophthalmol. 2003;87(7):847-9. [pmid: 12812882].
91 Nisar N, White F. Factors affecting utilization of antenatal care among reproductive age group women (15-49 years) in an urban squatter settlement of Karachi. J Pak Med Assoc. 2003;53(2):47-53. [pmid: 12705483].
92 Nour A. Breast-conserving therapy in low-literacy patients in a developing country. Breast J. 2003;9(2):71-3. [pmid: 12603377].
93 Shah N. Gender issues and oral health in elderly Indians. Int Dent J. 2003;53(6):475-84. [pmid: 14725376].
94 Sudha G, Nirupa C, Rajasakthivel M, et al. Factors influencing the care-seeking behaviour of chest symptomatics: a community-based study involving rural and urban population in Tamil Nadu, South India. Trop Med Int Health. 2003;8(4):336-41. [pmid: 12667153].
95 Thomas DM, Ray SM, Morton FJ, et al. Patient education strategies to improve pneumococcal vaccination rates: randomized trial. J Investig Med. 2003;51(3):141-8.
96 Wade TD, Davidson S, O'Dea JA. A preliminary controlled evaluation of a school-based media literacy program and self-esteem program for reducing eating disorder risk factors. Int J Eat Disord. 2003;33(4):371-83. discussion 384-7. [pmid: 12658666].
97 Wilson FL, Williams BN. Assessing the readability of skin care and pressure ulcer patient education materials. J Wound Ostomy Continence Nurs. 2003;30(4):224-30. [pmid: 12851598].
98 Wilson HR. Hepatitis B and you: a patient education resource for pregnant women and new mothers. J Womens Health (Larchmt). 2003;12(5):437-41. [pmid: 12869290].
99 Woods PS, Wynne HJ, Ploeger HW, Leonard DK. Path analysis of subsistence farmers' use of veterinary services in Zimbabwe. Prev Vet Med. 2003;61(4):339-58. [pmid: 14623416].
100 Xu G, Meyer JS, Huang Y, Du F, Chowdhury M, Quach M. Adapting mini-mental state examination for dementia screening among illiterate or minimally educated elderly Chinese. Int J Geriatr Psychiatry. 2003;18(7):609-16. [pmid: 12833305].
101 Ziemer DC, Berkowitz KJ, Panayioto RM, et al. A simple meal plan emphasizing healthy food choices is as effective as an exchange-based meal plan for urban African Americans with type 2 diabetes. Diabetes Care. 2003;26(6):1719-24. [pmid: 12766100].
102 Anand S, Barnighausen T. Human resources and health outcomes: cross-country econometric study. Lancet. 2004;364(9445):1603-9. [pmid: 15519630].
103 Aziz Z, Sana S, Akram M, Saeed A. Socioeconomic status and breast cancer survival in Pakistani women. J Pak Med Assoc. 2004;54(9):448-53. [pmid: 15518365].
104 Borooah VK. On the incidence of diarrhoea among young Indian children. Econ Hum Biol. 2004;2(1):119-38. [pmid: 15463998].
105 Bourne RR, Dineen BP, Ali SM, Noorul Huq DM, Johnson GJ. Prevalence of refractive error in Bangladeshi adults: results of the National Blindness and Low Vision Survey of Bangladesh. Ophthalmology. 2004;111(6):1150-60. [pmid: 15177965].
106 Calderon JL, Zadshir A, Norris K. A survey of kidney disease and risk-factor information on the World Wide Web. MedGenMed. 2004;6(4):3. [pmid: 15775830].
107 Calderon JL, Zadshir A, Norris K. Structure and content of chronic kidney disease information on the World Wide Web: barriers to public understanding of a pandemic. Nephrol News Issues. 78. 2004;18(11):76-9. 81. 4. [pmid: 15551616].
108 Dwight-Johnson M, Lagomasino IT, Aisenberg E, Hay J. Using conjoint analysis to assess depression treatment preferences among low-income Latinos. Psychiatr Serv. 2004;55(8):934-6. [pmid: 15292545].
109 Friedman DB, Hoffman-Goetz L, Arocha JF. Readability of cancer information on the internet. J Cancer Educ. 2004;19(2):117-22. [pmid: 15456669].
110 Jurdi R, Khawaja M. Caesarean section rates in the Arab region: a cross-national study. Health Policy Plan. 2004;19(2):101-10. [pmid: 14982888].
111 Kaphingst KA, Rudd RE, DeJong W, Daltroy LH. Literacy demands of product information intended to supplement television direct-to-consumer prescription drug advertisements. Patient Educ Couns. 2004;55(2):293-300. [pmid: 15530767].
112 Kirkcaldy B, Furnham A, Siefen G. The Relationship Between Health Efficacy, Educational Attainment, and Well-Being Among 30 Nations. European Psychologist. 2004;9(2):107-119.
113 Moore S, Sherwin A. Improving patient access to healthcare professionals: a prospective audit evaluating the role of e-mail communication for patients with lung cancer. Eur J Oncol Nurs. 2004;8(4):350-4. [pmid: 15550365].
114 Moriarty-Craige SE, Ramakrishnan U, Neufeld L, Rivera J, Martorell R. Multivitamin-mineral supplementation is not as efficacious as is iron supplementation in improving hemoglobin concentrations in nonpregnant anemic women living in Mexico. Am J Clin Nutr. 2004;80(5):1308-11. [pmid: 15531680].
115 Pandav RS, Chandra V, Dodge HH, DeKosky ST, Ganguli M. Hemoglobin levels and Alzheimer disease: an epidemiologic study in India. Am J Geriatr Psychiatry. 2004;12(5):523-6. [pmid: 15353391].
116 Puertas G, Patel V, Marshall T. Are visual measures of mood superior to questionnaire measures in non-Western settings. Social psychiatry and psychiatric epidemiology. 2004;(8):662-6. [pmid: 15300377].
117 Rahim MA, Vaaler S, Keramat Ali SM, Khan AK, Hussain A, Nahar Q. Prevalence of type 2 diabetes in urban slums of Dhaka, Bangladesh. Bangladesh Med Res Counc Bull. 2004;30(2):60-70. [pmid: 15813484].
118 Regassa K, Teshome T. Trachoma among adults in Damot Gale District, South Ethiopia. Ophthalmic Epidemiol. 2004;11(1):9-16. [pmid: 14977493].
119 Rosal MC, Goins KV, Carbone ET, Cortes DE. Views and preferences of low-literate Hispanics regarding diabetes education: results of formative research. Health Educ Behav. 2004;31(3):388-405. [pmid: 15155047].
120 Rosenthal MS, Werner MJ, Dubin NH. The effect of a literacy training program on family medicine residents. Fam Med. 2004;36(8):582-7. [pmid: 15343420].
121 Shah N, Sundaram KR. Impact of socio-demographic variables, oral hygiene practices, oral habits and diet on dental caries experience of Indian elderly: a community-based study. Gerodontology. 2004;21(1):43-50. [pmid: 15074539].
122 Shedlin MG, Shulman L. Qualitative needs assessment of HIV services among Dominican, Mexican and Central American immigrant populations living in the New York City area. AIDS Care. 2004;16(4):434-45. [pmid: 15203412].
123 Tandon R, Verma K, Vanathi M, Pandey RM, Vajpayee RB. Factors affecting eye donation from postmortem cases in a tertiary care hospital. Cornea. 2004;23(6):597-601. [pmid: 15256999].
124 Thompson HS, Wahl E, Fatone A, Brown K, Kwate NO, Valdimarsdottir H. Enhancing the readability of materials describing genetic risk for breast cancer. Cancer Control. 2004;11(4):245-53. [pmid: 15284716].
125 Ugboma HA, Akani CI. Abdominal massage: another cause of maternal mortality. Niger J Med. 2004;13(3):259-62. [pmid: 15532228].
126 Ulukanligil M, Seyrek A. Demographic and socio-economic factors affecting the physical development, haemoglobin and parasitic infection status of schoolchildren in Sanliurfa province, Turkey. Public Health. 2004;118(2):151-8. [pmid: 15037047].
127 Vandelanotte C, De Bourdeaudhuij I, Brug J. Acceptability and feasibility of an interactive computer-tailored fat intake intervention in Belgium. Health Promot Int. 2004;19(4):463-70. [pmid: 15522947].
128 Wallace LS, Lennon ES. American Academy of Family Physicians patient education materials: can patients read them?. Fam Med. 2004;36(8):571-4. [pmid: 15343418].
129 Weiner J, Aguirre A, Ravenell K, et al. Designing an illustrated patient satisfaction instrument for low-literacy populations. Am J Manag Care. 2004;10(11 Pt 2):853-60. [pmid: 15609739].
130 Yan Z, Fischer KW. How children and adults learn to use computers: a developmental approach. New Dir Child Adolesc Dev. 2004;(105):41-61. [pmid: 15552207].
131 Agbaje EO, Babatunde EO. A KAP study of the attitude and practice of traditional medicine in a contemporary Nigerian community. Cent Afr J Med. 2005;51(5-6):58-62. [pmid: 17432433].
132 Ahmad K, Jafary F, Jehan I, et al. Prevalence and predictors of smoking in Pakistan: results of the National Health Survey of Pakistan. Eur J Cardiovasc Prev Rehabil. 2005;12(3):203-8. [pmid: 15942416].
133 Ali SS, Karim N, Billoo AG, Haider SS. Association of literacy of mothers with malnutrition among children under three years of age in rural area of district Malir, Karachi. J Pak Med Assoc. 2005;55(12):550-3. [pmid: 16438277].
134 Bailey R, Rhee KB. Reach Out and Read: promoting pediatric literacy guidance through a transdisciplinary team. J Health Care Poor Underserved. 2005;16(2):225-30. [pmid: 15937385].
135 Bhurgri Y. Cancer of the oral cavity - trends in Karachi South (1995-2002). Asian Pac J Cancer Prev. 2005;6(1):22-6. [pmid: 15780026].
136 Boiko P, Katon W, Guerra JC, Mazzoni S. An audiotaped mental health evaluation tool for Hispanic immigrants with a range of literacy levels. J Immigr Health. 2005;7(1):33-6. [pmid: 15744475].
137 Changrani J, Gany F. Online cancer education and immigrants: effecting culturally appropriate websites. J Cancer Educ. 2005;20(3):183-6. [pmid: 16122368].
138 Christian P, Khatry SK, LeClerq SC, et al. Prevalence and risk factors of chlamydia and gonorrhea among rural Nepali women. Sex Transm Infect. 2005;81(3):254-8. [pmid: 15923297].
139 Das DK, Biswas R. Nutritional status of adolescent girls in a rural area of North 24 Parganas district, West Bengal. Indian J Public Health. 2005;49(1):18-21. [pmid: 15989155].
140 Date J, Okita K. Gender and literacy: factors related to diagnostic delay and unsuccessful treatment of tuberculosis in the mountainous area of Yemen. Int J Tuberc Lung Dis. 2005;9(6):680-5. [pmid: 15971397].
141 Dawn A, Biswas R. Reproductive tract infection: an experience in rural West Bengal. Indian J Public Health. 2005;49(2):102-3. [pmid: 16457102].
142 Echeverry D, Dike M, Jovanovic L, et al. Efforts to improve subsequent treatment of cardiovascular risk factors in older patients with diabetes hospitalized for a cardiac event. Am J Manag Care. 2005;11(12):758-64. [pmid: 16336059].
143 Enders SR, Paterniti DA, Meyers FJ. An approach to develop effective health care decision making for women in prison. J Palliat Med. 2005;8(2):432-9. [pmid: 15890054].
144 Eser E, Dinc G, Oral AM, Ozcan C. Contrasting children and women's health and the determinants of health in a small-sized city. J Urban Health. 2005;82(4):666-81. [pmid: 16195473].
145 Fries E, Edinboro P, McClish D, et al. Randomized trial of a low-intensity dietary intervention in rural residents: the Rural Physician Cancer Prevention Project. Am J Prev Med. 2005;28(2):162-8. [pmid: 15710271].
146 Ghosh R, Bharati P. Women's status and health of two ethnic groups inhabiting a periurban habitat of Kolkata City, India: a micro-level study. Health Care Women Int. 2005;26(3):194-211. [pmid: 15804693].
147 Gupta U, Sharma S, Sheth PD, Jha J, Chaudhury RR. Improving medicine usage through patient information leaflets in India. Trop Doct. 2005;35(3):164-6. [pmid: 16105344].
148 Haldar A, Mundle M, Ray A, Haldar S. Acute lower respiratory tract infection among under- fives in urban eastern India--an appraisal of risk factors. J Commun Dis. 2005;37(3):203-8. [pmid: 17080704].
149 Haldar A, Saha S, Mandal S, Haldar S, Mundle M, Mitra SP. Life events as risk factors for myocardial infarction: a pilot case-control study in Kolkata, India. J Health Popul Nutr. 2005;23(2):131-6. [pmid: 16117364].
150 He N, Detels R, Zhu J, et al. Characteristics and sexually transmitted diseases of male rural migrants in a metropolitan area of Eastern China. Sex Transm Dis. 2005;32(5):286-92. [pmid: 15849529].
151 Hou SI. Experience of colorectal cancer screening using a home-administered kit for fecal occult blood tests among a Chinese worksite population in Taiwan. Psychol Rep. 2005;96(1):178-80. [pmid: 15825922].
152 Ikechebelu JI, Joe-Ikechebelu NN, Obiajulu FN. Knowledge, attitude and practice of family planning among Igbo women of south-eastern Nigeria. J Obstet Gynaecol. 2005;25(8):792-5. [pmid: 16368587].
153 Kalichman SC, Cain D, Fuhrel A, Eaton L, Di Fonzo K, Ertl T. Assessing medication adherence self-efficacy among low-literacy patients: development of a pictographic visual analogue scale. Health Educ Res. 2005;20(1):24-35. [pmid: 15253999].
154 Kripalani S, Sharma J, Justice E, et al. Prostate cancer screening in a low-literacy population: does informed decision making occur?. Cancer Control. 2. 2005;12:116-7. [pmid: 16327763].
155 Mishra P, Hansen EH, Sabroe S, Kafle KK. Socio-economic status and adherence to tuberculosis treatment: a case-control study in a district of Nepal. Int J Tuberc Lung Dis. 2005;9(10):1134-9. [pmid: 16229225].
156 Murthy GV, Gupta SK, Bachani D, Jose R, John N. Current estimates of blindness in India. Br J Ophthalmol. 2005;89(3):257-60. [pmid: 15722298].
157 Neville A, Jenkins J, Williams JD, Craig KJ. Peritoneal dialysis training: a multisensory approach. Perit Dial Int. 3. 2005;25:S149-51. [pmid: 16048283].
158 Newmann SJ, Goldberg AB, Aviles R, Molina de Perez O, Foster-Rosales AF. Predictors of contraception knowledge and use among postpartum adolescents in El Salvador. Am J Obstet Gynecol. 2005;192(5):1391-4. [pmid: 15902118].
159 Ngatia EM, Ng'ang'a PM, Muita JW, Imungi JK. Dietary patterns and nutritional status of pre-school children in Nairobi. East Afr Med J. 2005;82(10):520-5. [pmid: 16450680].
160 Patel V, Pednekar S, Weiss H, et al. Why do women complain of vaginal discharge? A population survey of infectious and pyschosocial risk factors in a South Asian community. Int J Epidemiol. 2005;34(4):853-62. [pmid: 15833795].
161 Pelicano N, Branco LM, Pinto A, et al. Thromboembolic and/or bleeding complications in patients under oral anticoagulation followed at a tertiary hospital. Rev Port Cardiol. 2005;24(7-8):957-68. [pmid: 16240682].
162 Rhee M, Sissoko M, Perry S, Dicko A, McFarland W, Doumbo O. Malaria prevention practices in Mopti region, Mali. East Afr Med J. 2005;82(8):396-402. [pmid: 16261915].
163 Rosal MC, Olendzki B, Reed GW, Gumieniak O, Scavron J, Ockene I. Diabetes self-management among low-income Spanish-speaking patients: a pilot study. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2005;(3):225-35. [pmid: 15946117].
164 Saleem S, Fikree FF. The quest for small family size among Pakistani women--is voluntary termination of pregnancy a matter of choice or necessity?. J Pak Med Assoc. 2005;55(7):288-91. [pmid: 16108512].
165 Sarangmath N, Rattihalli R, Ragothaman M, et al. Validity of a modified Parkinson's disease screening questionnaire in India: effects of literacy of participants and medical training of screeners and implications for screening efforts in developing countries. Mov Disord. 2005;20(12):1550-6. [pmid: 16078206].
166 Shaheen FA, Kurpad R, Al-Attar BA, Muna B, Al-Khader AA. Comparative psychosocial analysis of patients on maintenance hemodialysis and transplanted patients. Ann Transplant. 2005;10(1):17-21. [pmid: 15926746].
167 Shea JA, Aguirre AC, Sabatini J, Weiner J, Schaffer M, Asch DA. Developing an illustrated version of the Consumer Assessment of Health Plans (CAHPS). Jt Comm J Qual Patient Saf. 2005;31(1):32-42. [pmid: 15691208].
168 Sinha R, Vanathi M, Sharma N, Titiyal JS, Vajpayee RB, Tandon R. Outcome of penetrating keratoplasty in patients with bilateral corneal blindness. Eye. 2005;19(4):451-4. [pmid: 15319790].
169 Sotoudeh G, Khosravi S, Khajehnasiri F, Khalkhali HR. High prevalence of overweight and obesity in women of Islamshahr, Iran. Asia Pac J Clin Nutr. 2005;14(2):169-72. [pmid: 15927935].
170 Thorn F, Cruz AA, Machado AJ, Carvalho RA. Refractive status of indigenous people in the northwestern Amazon region of Brazil. Optom Vis Sci. 2005;82(4):267-72. [pmid: 15829854].
171 Walker C, Weeks A, McAvoy B, Demetriou E. Exploring the role of self-management programmes in caring for people from culturally and linguistically diverse backgrounds in Melbourne, Australia. Health Expect. 2005;8(4):315-23. [pmid: 16266419].
172 Weinert C, Hill WG. Rural women with chronic illness: computer use and skill acquisition. Womens Health Issues. 2005;15(5):230-6. [pmid: 16165009].
173 Wong BM, Yung BM, Wong A, Chow CM, Abramson BL. Increasing Internet use among cardiovascular patients: new opportunities for heart health promotion. Can J Cardiol. 2005;21(4):349-54. [pmid: 15838562].
174 Agarwal KN, Agarwal DK, Sharma A, et al. Prevalence of anaemia in pregnant and lactating women in India. Indian J Med Res. 2006;124(2):173-84. [pmid: 17015931].
175 Bakken S, Grullon-Figueroa L, Izquierdo R, et al. Development, validation, and use of English and Spanish versions of the telemedicine satisfaction and usefulness questionnaire. J Am Med Inform Assoc. 2006;13(6):660-7. [pmid: 16929036].
176 Basu P, Sarkar S, Mukherjee S, et al. Women's perceptions and social barriers determine compliance to cervical screening: results from a population based study in India. Cancer Detect Prev. 2006;30(4):369-74. [pmid: 16963194].
177 Basu S, Paul DK, Ganguly S, Chandra PK. Risk factors for mortality from neonatal tetanus: 7 years experience in North Bengal, India. Ann Trop Paediatr. 2006;26(3):233-9. [pmid: 16925961].
178 Begum S, Haque MM, Nasreen SA. Contraceptive prevalence: experience from rural areas of Mymensingh. Mymensingh Med J. 2006;15(2):124-7. [pmid: 16878089].
179 Bose S, Trent K. Socio-demographic determinants of abortion in India: a north-South comparison. J Biosoc Sci. 2006;38(2):261-82. [pmid: 16202178].
180 Choi J, Bakken S. Heuristic evaluation of a Web-based Educational Resource for low literacy NICU parents. Stud Health Technol Inform. 2006;122:194-9. [pmid: 17102247].
181 Coldren RL, Prosser T, Ogolla F, Ofula VO, Adungo N. Literacy and recent history of diarrhoea are predictive of Plasmodium falciparum parasitaemia in Kenyan adults. Malar J. 2006;5:96. [pmid: 17076908].
182 Davis RE, Armstrong DK, Dignan M, Norling GR, Redmond J. Evaluation of educational materials on colorectal cancer screening in Appalachian Kentucky. Prev Chronic Dis. 2006;3(2):A43. [pmid: 16539784].
183 de Oliveira DF, Arieta CE, Temporini ER, Kara-Jose N. Quality of health care: patient satisfaction in a university hospital. Arq Bras Oftalmol. 2006;69(5):731-6. [pmid: 17187144].
184 Dike N, Onwujekwe O, Ojukwu J, Ikeme A, Uzochukwu B, Shu E. Influence of education and knowledge on perceptions and practices to control malaria in Southeast Nigeria. Soc Sci Med. 2006;63(1):103-6. [pmid: 16448735].
185 Elliott C, Farmer K. Immunization status of children under 7 years in the Vikas Nagar area, North India. Child Care Health Dev. 2006;32(4):415-21. [pmid: 16784497].
186 Evangelista LS, Stromberg A, Westlake C, Ter-Galstanyan A, Anderson N, Dracup K. Developing a Web-based education and counseling program for heart failure patients. Prog Cardiovasc Nurs. 2006;21(4):196-201. [pmid: 17170595].
187 Evans AE, Dave J, Tanner A, et al. Changing the home nutrition environment: effects of a nutrition and media literacy pilot intervention. Fam Community Health. 2006;29(1):43-54. [pmid: 16340677].
188 Gupta R, Misra A, Pais P, Rastogi P, Gupta VP. Correlation of regional cardiovascular disease mortality in India with lifestyle and nutritional factors. Int J Cardiol. 2006;108(3):291-300. [pmid: 15978684].
189 Hamrosi K, Taylor SJ, Aslani P. Issues with prescribed medications in Aboriginal communities: Aboriginal health workers' perspectives. Rural Remote Health. 2006;6(2):557. [pmid: 16683907].
190 Houck PW, Whitehouse FR. Asthma prevention in urbanites. J Asthma. 2006;43(8):573-8. [pmid: 17050220].
191 Hussain T, Kulshreshtha KK, Sinha S, Yadav VS, Katoch VM. HIV, HBV, HCV, and syphilis co-infections among patients attending the STD clinics of district hospitals in Northern India. Int J Infect Dis. 2006;10(5):358-63. [pmid: 16678462].
192 Ikeako LC, Onah HE, Iloabachie GC. Influence of formal maternal education on the use of maternity services in Enugu, Nigeria. J Obstet Gynaecol. 2006;26(1):30-4. [pmid: 16390706].
193 Jha N, Singh R, Baral D. Knowledge, attitude and practices of mothers regarding home management of acute diarrhoea in Sunsari, Nepal. Nepal Med Coll J. 2006;8(1):27-30. [pmid: 16827086].
194 Jibaja-Weiss ML, Volk RJ, Friedman LC, et al. Preliminary testing of a just-in-time, user-defined values clarification exercise to aid lower literate women in making informed breast cancer treatment decisions. Health Expect. 2006;9(3):218-31. [pmid: 16911136].
195 Kalanda BF, Verhoeff FH, Brabin BJ. Chronic malnutrition in pregnant adolescents in rural Malawi: an anthropometric study. Acta Obstet Gynecol Scand. 2006;85(1):33-9. [pmid: 16521677].
196 Khan NZ, Muslima H, Parveen M, et al. Neurodevelopmental outcomes of preterm infants in Bangladesh. Pediatrics. 2006;118(1):280-9. [pmid: 16818576].
197 Koch-Weser S, Liang SL, Grigg-Saito DC. Self-reported health among Cambodians in Lowell, Massachusetts. J Health Care Poor Underserved. 2006;17(2 Suppl):133-45. [pmid: 16809880].
198 Levandowski BA, Sharma P, Lane SD, et al. Parental literacy and infant health: an evidence-based healthy start intervention. Health Promot Pract. 2006;7(1):95-102. [pmid: 16410425].
199 Loevinsohn B, Hong R, Gauri V. Will more inputs improve the delivery of health services? Analysis of district vaccination coverage in Pakistan. Int J Health Plann Manage. 2006;21(1):45-54. [pmid: 16604848].
200 McAlister C, Baskett TF. Female education and maternal mortality: a worldwide survey. J Obstet Gynaecol Can. 2006;28(11):983-90. [pmid: 17169224].
201 Nazari M, Fakoorziba MR, Shobeiri F. Pediculus capitis infestation according to sex and social factors in Hamedan, Iran. Southeast Asian J Trop Med Public Health. 3. 2006;37:95-8. [pmid: 17547060].
202 Nojomi M, Akbarian A, Ashory-Moghadam S. Burden of abortion: induced and spontaneous. Arch Iran Med. 2006;9(1):39-45. [pmid: 16649376].
203 Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1-3):249-58. [pmid: 16616449].
204 Rahman A, Giashuddin SM, Svanstrom L, Rahman F. Drowning--a major but neglected child health problem in rural Bangladesh: implications for low income countries. Int J Inj Contr Saf Promot. 2006;13(2):101-5. [pmid: 16707346].
205 Rahman M, Banerjee M, Rahman M, Akhter FU. Vaccination status of tribal mothers and their under five children. Mymensingh Med J. 2006;15(1):55-7. [pmid: 16467764].
206 Sami N, Ali TS. Health seeking behavior of couples with secondary infertility. J Coll Physicians Surg Pak. 2006;16(4):261-4. [pmid: 16624188].
207 Sarkar K, Bal B, Mukherjee R, et al. Young age is a risk factor for HIV among female sex workers--an experience from India. J Infect. 2006;53(4):255-9. [pmid: 16386307].
208 Saunders CM. Insuring the Uninsured: Reducing the Barriers to Public Insurance. Qualitative Report. 2006;11(3):499-515.
209 Schmid MA, Egeland GM, Salomeyesudas B, Satheesh PV, Kuhnlein HV. Traditional food consumption and nutritional status of Dalit mothers in rural Andhra Pradesh, South India. Eur J Clin Nutr. 2006;60(11):1277-83. [pmid: 16721395].
210 Tavasoli S, Heidarnazhad H, Kazemnejad A. Factors affecting patients' compliance to metered-dose inhaler drugs in two asthma clinics in Tehran, Iran. Iran J Allergy Asthma Immunol. 2006;5(4):187-93. [pmid: 17237572].
211 Vijaya L, George R, Arvind H, et al. Prevalence and causes of blindness in the rural population of the Chennai Glaucoma Study. Br J Ophthalmol. 2006;90(4):407-10. [pmid: 16547314].
212 Adesiyun AG. Female sterilization by tubal ligation: a re-appraisal of factors influencing decision making in a tropical setting. Arch Gynecol Obstet. 2007;275(4):241-4. [pmid: 17021769].
213 Babar TF, Khan MT, Marwat MZ, Shah SA, Murad Y, Khan MD. Patterns of ocular trauma. J Coll Physicians Surg Pak. 2007;17(3):148-53. [pmid: 17374300].
214 Bharati S, Pal M, Bharati P. Obstetric care practice in Birbhum District, West Bengal, India. Int J Qual Health Care. 2007;19(4):244-9. [pmid: 17569683].
215 de Albuquerque Mde F, Ximenes RA, Lucena-Silva N, et al. Factors associated with treatment failure, dropout, and death in a cohort of tuberculosis patients in Recife, Pernambuco State, Brazil. Cad Saude Publica. 2007;23(7):1573-82. [pmid: 17572806].
216 Fekede B, GM A. Antenatal care services utilization and factors associated in Jimma Town (south west Ethiopia). Ethiop Med J. 2007;45(2):123-33. [pmid: 17642168].
217 Francis L, Weiss BD, Senf JH, Heist K, Hargraves R. Does literacy education improve symptoms of depression and self-efficacy in individuals with low literacy and depressive symptoms? A preliminary investigation. J Am Board Fam Med. 2007;20(1):23-7. [pmid: 17204731].
218 George AC, Hoshing A, Joshi NV. A study of the reasons for irregular dental attendance in a private dental college in a rural setup. Indian J Dent Res. 2007;18(2):78-81. [pmid: 17502713].
219 Gonzalez YM, Lozier EB. Oral cancer screening, dental needs assessment and risk factors literacy in Hispanic population of western New York. N Y State Dent J. 2007;73(6):32-5. [pmid: 18265766].
220 Gouvea MV, Werneck GL, Costa CH, de Amorim Carvalho FA. Factors associated to Montenegro skin test positivity in Teresina, Brazil. Acta Trop. 2007;104(2-3):99-107. [pmid: 17825238].
221 Hazarey VK, Erlewad DM, Mundhe KA, Ughade SN. Oral submucous fibrosis: study of 1000 cases from central India. J Oral Pathol Med. 2007;36(1):12-7. [pmid: 17181736].
222 He M, Chan V, Baruwa E, Gilbert D, Frick KD, Congdon N. Willingness to pay for cataract surgery in rural Southern China. Ophthalmology. 2007;114(3):411-6. [pmid: 17197026].
223 Hohenadel J, Kaegi E, Laidlaw J, et al. Leveling the playing field: the personal coach program as an innovative approach to assess and address the supportive care needs of underserved cancer patients. J Support Oncol. 2007;5(4):185-93. [pmid: 17500506].
224 Hunt MK, Barbeau EM, Lederman R, et al. Process evaluation results from the Healthy Directions-Small Business study. Health Educ Behav. 2007;34(1):90-107. [pmid: 16740502].
225 Kaati G, Bygren LO, Pembrey M, Sjostrom M. Transgenerational response to nutrition, early life circumstances and longevity. Eur J Hum Genet. 2007;15(7):784-90. [pmid: 17457370].
226 Kabakian-Khasholian T, Campbell OM. Impact of written information on women's use of postpartum services: a randomised controlled trial. Acta Obstet Gynecol Scand. 2007;86(7):793-8. [pmid: 17611823].
227 Landman KZ, Thielman NM, Mgonja A, et al. Antiretroviral treatment literacy among HIV voluntary counseling and testing clients in Moshi, Tanzania, 2003 to 2005. J Int Assoc Physicians AIDS Care (Chic Ill). 2007;6(1):24-6.
228 Manafa O, Lindegger G, Ijsselmuiden C. Informed consent in an antiretroviral trial in Nigeria. Indian J Med Ethics. 2007;4(1):26-30. [pmid: 18630217].
229 Nalcaci R, Erdemir EO, Baran I. Evaluation of the oral health status of the people aged 65 years and over living in near rural district of Middle Anatolia, Turkey. Arch Gerontol Geriatr. 2007;45(1):55-64. [pmid: 17097161].
230 Nazari M, Saidijam M. Pediculus capitis infestation according to sex and social factors in Hamedan-Iran. Pak J Biol Sci. 2007;10(19):3473-5. [pmid: 19090174].
231 Pal R, Sagar V. Correlates of vitamin A deficiency among Indian rural preschool-age children. Eur J Ophthalmol. 2007;17(6):1007-9. [pmid: 18050135].
232 Pieper B, Sieggreen M, Nordstrom CK, et al. Discharge knowledge and concerns of patients going home with a wound. J Wound Ostomy Continence Nurs. 2007;34(3):245-53. quiz 254-5. [pmid: 17505242].
233 Rathore M, Vyas L, Bhardwaj AK. Prevalence of reproductive tract infections amongst ever married women and sociocultural factors associated with it. J Indian Med Assoc. 2007;105(2):71-2. 74. 78. [pmid: 17822170].
234 Reyes-Ortiz CA, Camacho ME, Amador LF, Velez LF, Ottenbacher KJ, Markides KS. The impact of education and literacy levels on cancer screening among older Latin American and Caribbean adults. Cancer Control. 2007;14(4):388-95. [pmid: 17914339].
235 Saha SK, Bag T, De Aloke K, Basak S, Chhetri A, Banerjee J. Contraceptive practice of the tribal women in tea garden area of North Bengal. J Indian Med Assoc. 2007;105(8):440. 442. 448. [pmid: 18236906].
236 Seligman HK, Wallace AS, DeWalt DA, et al. Facilitating behavior change with low-literacy patient education materials. Am J Health Behav. 1. 2007;31:S69-78. [pmid: 17931139].
237 Sharma P, Sharma BC, Puri V, Sarin SK. Critical flicker frequency: diagnostic tool for minimal hepatic encephalopathy. J Hepatol. 2007;47(1):67-73. [pmid: 17459511].
238 Sur D, Ali M, von Seidlein L, et al. Comparisons of predictors for typhoid and paratyphoid fever in Kolkata, India. BMC Public Health. 2007;7:289. [pmid: 17935611].
239 Trinder VM, Fleet GE, Gray AE. Evaluating the impact of library user training programmes across Thames Valley Strategic Health Authority in the UK. Health Info Libr J. 2007;24(1):34-40. [pmid: 17331142].
240 Ackerson LK, Kawachi I, Barbeau EM, Subramanian SV. Effects of individual and proximate educational context on intimate partner violence: a population-based study of women in India. Am J Public Health. 2008;98(3):507-14. [pmid: 18235066].
241 Afolabi AO. Factors influencing the pattern of self-medication in an adult Nigerian population. Ann Afr Med. 2008;7(3):120-7. [pmid: 19253521].
242 Bateson K, Delaney J, Pybus R. Meeting expectations: the pilot evaluation of the Solihull Approach Parenting Group. Community Pract. 2008;81(5):28-31. [pmid: 18549120].
243 Bawdekar M, Ladusingh L. Contextual correlates of child malnutrition in rural Maharashtra. J Biosoc Sci. 2008;40(5):771-86. [pmid: 18241523].
244 Bharati S, Pal M, Bharati P. Determinants of nutritional status of pre-school children in India. J Biosoc Sci. 2008;40(6):801-14. [pmid: 18442431].
245 Blanch DC, Rudd RE, Wright E, Gall V, Katz JN. Predictors of refusal during a multi-step recruitment process for a randomized controlled trial of arthritis education. Patient Educ Couns. 2008;73(2):280-5. [pmid: 18715740].
246 Carcaise-Edinboro P, McClish D, Kracen AC, Bowen D, Fries E. Fruit and vegetable dietary behavior in response to a low-intensity dietary intervention: the rural physician cancer prevention project. J Rural Health. 2008;24(3):299-305. [pmid: 18643808].
247 Daniel AB, Nagaraj K, Kamath R. Prevalence and determinants of tobacco use in a highly literate rural community in southern India. Natl Med J India. 2008;21(4):163-5. [pmid: 19267035].
248 Franks-Meeks S. Nurses and computer competency. J Nurses Staff Dev. 2008;24(5):248-51. [pmid: 18838908].
249 Friedman DB, Tanwar M, Richter JV. Evaluation of online disaster and emergency preparedness resources. Prehosp Disaster Med. 2008;23(5):438-46. [pmid: 19189613].
250 Ganesh B, Talole SD, Dikshit R, Badwe RA, Dinshaw KA. Estimation of survival rates of breast cancer patients--a hospital-based study from Mumbai. Asian Pac J Cancer Prev. 2008;9(1):53-7. [pmid: 18439074].
251 Geller BM, Skelly JM, Dorwaldt AL, Howe KD, Dana GS, Flynn BS. Increasing patient/physician communications about colorectal cancer screening in rural primary care practices. Med Care. 2008;46(9 Suppl 1):S36-43. [pmid: 18725831].
252 Gupta M, Thakur JS, Kumar R. Reproductive and child health inequities in Chandigarh Union Territory of India. J Urban Health. 2008;85(2):291-9. [pmid: 18197478].
253 Hanck SE, Blankenship KM, Irwin KS, West BS, Kershaw T. Assessment of self-reported sexual behavior and condom use among female sex workers in India using a polling box approach: a preliminary report. Sex Transm Dis. 2008;35(5):489-94. [pmid: 18356771].
254 Ito KE, Kalyanaraman S, Ford CA, Brown JD, Miller WC. “Let's Talk About Sex”: pilot study of an interactive CD-ROM to prevent HIV/STIS in female adolescents. AIDS Educ Prev. 2008;20(1):78-89. [pmid: 18312069].
255 Johnson RM, Smith P, Strauss EJ, Higgins A, Jensen DR, Weiss BD. Breast cancer screening in an adult literacy program. Alaska Med. 2008;49(4):126-30. [pmid: 18491805].
256 Kind T, Wallace J, Moon RY. The digital divide: a comparison of online consumer health information for African-American and general audiences. J Natl Med Assoc. 2008;100(11):1333-40. [pmid: 19024231].
257 Maharajah KR, Tet CM, Yaacob A, Tajudin LS, Foster PJ. Modified Bahasa Malaysia version of VF-14 questionnaire: assessing the impact of glaucoma in rural area of Malaysia. Clin Experiment Ophthalmol. 2008;36(3):222-31. [pmid: 18412590].
258 Mahavarkar SH, Madhu CK, Mule VD. A comparative study of teenage pregnancy. J Obstet Gynaecol. 2008;28(6):604-7. [pmid: 19003655].
259 Manesh AO, Sheldon TA, Pickett KE, Carr-Hill R. Accuracy of child morbidity data in demographic and health surveys. Int J Epidemiol. 2008;37(1):194-200. [pmid: 17911149].
260 Mayhew M, Hansen PM, Peters DH, et al. Determinants of skilled birth attendant utilization in Afghanistan: a cross-sectional study. Am J Public Health. 2008;98(10):1849-56. [pmid: 18703445].
261 Minnies D, Hawkridge T, Hanekom W, Ehrlich R, London L, Hussey G. Evaluation of the quality of informed consent in a vaccine field trial in a developing country setting. BMC Med Ethics. 2008;9:15. [pmid: 18826637].
262 Moestue H, Huttly S. Adult education and child nutrition: the role of family and community. J Epidemiol Community Health. 2008;62(2):153-9. [pmid: 18192604].
263 Nations MK, Calvasina PG, Martin MN, Dias HF. Cultural significance of primary teeth for caregivers in Northeast Brazil. Cad Saude Publica. 2008;24(4):800-8. [pmid: 18392357].
264 Olson R, Sabogal F, Perez A. Viva la Vida: helping Latino Medicare beneficiaries with diabetes live their lives to the fullest. Am J Public Health. 2008;98(2):205-8. [pmid: 18172150].
265 Rathbun A, Thornton LA, Fox JE. Are our investments paying off?: a study of reading level and bereavement materials. Am J Hosp Palliat Care. 2008;25(4):278-81. [pmid: 18463410].
266 Rawl R, Kolasa KM, Lee J, Whetstone LM. A learn and serve nutrition program: the Food Literacy Partners Program. J Nutr Educ Behav. 2008;40(1):49-51. [pmid: 18174105].
267 Rother HA. South African farm workers' interpretation of risk assessment data expressed as pictograms on pesticide labels. Environ Res. 2008;108(3):419-27. [pmid: 18755451].
268 Sam KG, Andrade HH, Pradhan L, et al. Effectiveness of an educational program to promote pesticide safety among pesticide handlers of South India. Int Arch Occup Environ Health. 2008;81(6):787-95. [pmid: 17962973].
269 Santos JN, Lemos SM, Rates SP, Lamounier JA. Hearing abilities and language development in anemic children of a public daycare center. Pro Fono. 2008;20(4):255-60. [pmid: 19142469].
270 Saroha E, Altarac M, Sibley LM. Caste and maternal health care service use among rural Hindu women in Maitha, Uttar Pradesh, India. J Midwifery Womens Health. 2008;53(5):e41-7. [pmid: 18761290].
271 Schnitzer MI, Kaplin DB, Keane VA, Zuckerman B, Sharfstein JM. Giving literacy a shot in the arm. Public Health Rep. 2008;123(4):523-6. [pmid: 18763415].
272 Schooling CM, Jiang CQ, Heys M, et al. Are height and leg length universal markers of childhood conditions? The Guangzhou Biobank cohort study. J Epidemiol Community Health. 2008;62(7):607-14. [pmid: 18559443].
273 Shahraki M, Shahraki T, Ansari H. The effects of socio-economic status on BMI, waist:hip ratio and waist circumference in a group of Iranian women. Public Health Nutr. 2008;11(7):757-61. [pmid: 18194587].
274 Shieh C, Hosei B. Printed health information materials: evaluation of readability and suitability. J Community Health Nurs. 2008;25(2):73-90. [pmid: 18449833].
275 Smith SK, Trevena L, Nutbeam D, Barratt A, McCaffery KJ. Information needs and preferences of low and high literacy consumers for decisions about colorectal cancer screening: utilizing a linguistic model. Health Expect. 2008;11(2):123-36. [pmid: 18494957].
276 Thompson BW, Skiba DJ. Informatics in the nursing curriculum: a national survey of nursing informatics requirements in nursing curricula. Nurs Educ Perspect. 2008;29(5):312-7. [pmid: 18834062].
277 Usta MB, Mitchell EM, Gebreselassie H, Brookman-Amissah E, Kwizera A. Who is excluded when abortion access is restricted to twelve weeks? Evidence from Maputo, Mozambique. Reprod Health Matters. 2008;16(31 Suppl):14-7. [pmid: 18772079].
278 Van Winghem J, Telfer B, Reid T, et al. Implementation of a comprehensive program including psychosocial and treatment literacy activities to improve adherence to HIV care and treatment for a pediatric population in Kenya. BMC Pediatr. 2008;8:52. [pmid: 19025581].
279 Vikram BK, Khaja N, Udayashankar SG, Venkatesha BK, Manjunath D. Clinico-epidemiological study of complicated and uncomplicated chronic suppurative otitis media. J Laryngol Otol. 2008;122(5):442-6. [pmid: 17666139].
280 Hejaili FF, Assad L, Shaheen FA, et al. Culture-related service expectations: a comparative study using the Kano model. Qual Manag Health Care. 2009;18(1):48-58. [pmid: 19148029].
281 Merriam PA, Tellez TL, Rosal MC, et al. Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Med Res Methodol. 2009;9:20. [pmid: 19284663].
282 Tokuda Y, Doba N, Butler JP, Paasche-Orlow MK. Health literacy and physical and psychological wellbeing in Japanese adults. Patient Educ Couns. 2009;75(3):411-7. [pmid: 19403259].
283 Bautista RE, Glen ET, Shetty NK, Wludyka P. The association between health literacy and outcomes of care among epilepsy patients. Seizure. 2009;18(6):400-4. [pmid: 19324575].
284 Cormier CM, Kotrlik JW. Health literacy knowledge and experiences of senior baccalaureate nursing students. J Nurs Educ. 2009;48(5):237-48. [pmid: 19476028].
285 Pollard RQ, Dean RK, O'Hearn A, Haynes SL. Adapting health education material for deaf audiences. Rehabil Psychol. 2009;54(2):232-8. [pmid: 19469615].
286 Herman A, Young KD, Espitia D, Fu N, Farshidi A. Impact of a health literacy intervention on pediatric emergency department use. Pediatr Emerg Care. 2009;25(7):434-8. [pmid: 19564810].
287 Lewis CL, Pignone MP, Sheridan SL, Downs SM, Kinsinger LS. A randomized trial of three videos that differ in the framing of information about mammography in women 40 to 49 years old. J Gen Intern Med. 2003;18(11):875-83. [pmid: 14687272].
288 Aikens JE, Piette JD. Diabetic patients' medication underuse, illness outcomes, and beliefs about antihyperglycemic and antihypertensive treatments. Diabetes Care. 2009;32(1):19-24. [pmid: 18852334].
289 Wouters E, Van Damme W, Van Loon F, van Rensburg D, Meulemans H. Public-sector ART in the Free State Province, South Africa: community support as an important determinant of outcome. Soc Sci Med. 2009;69(8):1177-85. [pmid: 19692165].
290 Shrank WH, Patrick A, Gleason PP, et al. An evaluation of the relationship between the implementation of a newly designed prescription drug label at Target pharmacies and health outcomes. Med Care. 2009;47(9):1031-5. [pmid: 19648829].
291 Hess J, Whelan JS. Making health literacy real: adult literacy and medical students teach each other. J Med Libr Assoc. 2009;97(3):221-4. [pmid: 19626149].
292 Long AF. The potential of complementary and alternative medicine in promoting well-being and critical health literacy: a prospective, observational study of shiatsu. BMC Complement Altern Med. 2009;9:19. [pmid: 19538728].
293 Kagawa-Singer M, Tanjasiri SP, Valdez A, Yu H, Foo MA. Outcomes of a breast health project for Hmong women and men in California. Am J Public Health. 2. 2009;99:S467-73. [pmid: 19443830].
294 Moore M, Bias RG, Prentice K, Fletcher R, Vaughn T. Web usability testing with a Hispanic medically underserved population. J Med Libr Assoc. 2009;97(2):114-21. [pmid: 19404502].
295 Brumby SA, Willder SJ, Martin J. The sustainable farm families project: changing attitudes to health. Rural Remote Health. 2009;9(1):1012. [pmid: 19292570].
296 Barnholtz-Sloan J, Patel N, Rollison D, Kortepeter K, MacKinnon J, Giuliano A. Incidence trends of invasive cervical cancer in the United States by combined race and ethnicity. Cancer Causes Control. 2009;20(7):1129-38. [pmid: 19253025].
297 Hossain D, Gorman D, Eley R, Coutts J. Farm Advisors' reflections on Mental Health First Aid training. Australian e Journal for the Advancement of Mental Health. 2009;8(1):1-7.
298 Hoffman-Goetz L, Meissner HI, Thomson MD. Literacy and cancer anxiety as predictors of health status: An exploratory study. Journal of Cancer Education. 2009;24(3):218-224. [pmid: 19526411].
299 Han HR, Lee H, Kim MT, Kim KB. Tailored lay health worker intervention improves breast cancer screening outcomes in nonadherent Korean-American women. Health Education Research. 2009;24(2):318-329. [pmid: 18463411].
300 Dwamena FC, Mavis B, Holmes-Rovner M, Walsh KB, Loyson AC. Teaching medical interviewing to patients: The other side of the encounter. Patient Education and Counseling. 2009;76(3):380-384. [pmid: 19674860].
301 Liu Cj, Kemper S, McDowd J. The use of illustration to improve older adultsâ€™ comprehension of health-related information: Is it helpful?. Patient Education and Counseling. 2009;76(2):283-288. [pmid: 19286343].
302 Alati R, Gunnell D, Najman J, Williams G, Lawlor D. Is IQ in childhood associated with suicidal thoughts and attempts? Findings from the Mater University study of pregnancy and its outcomes. Suicide and Life-Threatening Behavior. 2009;39(3):282-93. [pmid: 19606920].
303 Saha S, Barnett AG, Foldi C, et al. Advanced paternal age is associated with impaired neurocognitive outcomes during infancy and childhood. PLoS Med. 2009;6(3):e40. [pmid: 19278291].
304 Preston AS, Heaton SC, McCann SJ, Watson WD, Selke G. The role of multidimensional attentional abilities in academic skills of children with ADHD. J Learn Disabil. 2009;42(3):240-9. [pmid: 19264927].
305 Banerjee D, Perry M, Tran D, Arafat R. Self-reported health, functional status and chronic disease in community dwelling older adults: untangling the role of demographics. J Community Health. 2010;35(2):135-41. [pmid: 20033835].
306 Guerrero AD, Chen J, Inkelas M, Rodriguez HP, Ortega AN. Racial and ethnic disparities in pediatric experiences of family-centered care. Med Care. 2010;48(4):388-93. [pmid: 20220533].
307 Mausbach BT, Harvey PD, Pulver AE, et al. Relationship of the Brief UCSD Performance-based Skills Assessment (UPSA-B) to multiple indicators of functioning in people with schizophrenia and bipolar disorder. Bipolar Disord. 2010;12(1):45-55. [pmid: 20148866].
308 Mabiso A, Williams KP, Todem D, Templin TN. Longitudinal analysis of domain-level breast cancer literacy among African-American women. Health Educ Res. 2010;25(1):151-61. [pmid: 19861639].
309 Nair EL, Cienkowski KM. The impact of health literacy on patient understanding of counseling and education materials. Int J Audiol. 2010;49(2):71-5. [pmid: 20151879].
310 Lewis N, Gray SW, Freres DR, Hornik RC. Examining cross-source engagement with cancer-related information and its impact on doctor-patient relations. Health Commun. 2009;24(8):723-34. [pmid: 20183381].
311 Tawil I, Marinaro J, Brown LH. Development and validation of a tool for assessing understanding of brain death. Prog Transplant. 2009;19(3):272-6. [pmid: 19813491].
312 Schulz PJ, Rubinelli S, Mariotti G, Keller N. Meeting the ranging of informational needs of chronic low back pain sufferers: conceptual design and rationale of the interactive website ONESELF. Disabil Rehabil. 2009;31(25):2118-24. [pmid: 19888842].
313 Samal L, Yeh HC, Gary-Webb TL, Jackson CL, Brancati FL. Computer and internet use of urban african americans with type 2 diabetes in relation to glycemic control, emergency department use, diabetes-related knowledge, and health literacy. Diabetes care. 2010;(1):e9. [pmid: 20040672].
314 Rana AK, Wahlin A, Lundborg CS, Kabir ZN. Impact of health education on health-related quality of life among elderly persons: results from a community-based intervention study in rural Bangladesh. Health promotion international. 2009;(1):36-45. [pmid: 19136677].
315 Cohan D, Gomez E, Greenberg M, Washington S, Charlebois ED. Patient perspectives with abbreviated versus standard pre-test HIV counseling in the prenatal setting: a randomized-controlled, non-inferiority trial. PloS one. 2009;(4):e5166. [pmid: 19367335].
316 Murthy GV, Vashist P, John N, Pokharel G, Ellwein LB. Prevalence and vision-related outcomes of cataract surgery in Gujarat, India. Ophthalmic epidemiology. 2009;(6):400-9. [pmid: 19995206].
317 Lee JP, Battle RS, Lipton R, Soller B. ‘Smoking’: Use of cigarettes, cigars and blunts among Southeast Asian American youth and young adults. Health education research. 2010;25(1):83-96. [pmid: 19959564].
318 Lohse B, Rifkin R, Krall JS. Digital photo receivers deliver herbal education for low-income persons. Journal of Nutrition Education and Behavior. 2009;41(6):438-440. [pmid: 19879502].
319 Angner E, Miller MJ, Ray MN, Saag KG, Allison JJ. Health literacy and happiness: A community-based study. Social Indicators Research. 2010;95(2):325-338.
320 Halbert CH, Kumanyika S, Bowman M, et al. Participation rates and representativeness of African Americans recruited to a health promotion program. Health education research. 2010;25(1):6-13. [pmid: 19875730].
321 Huang YW, Hung CH. The effect of health education through the internet on university female students hepatitis B knowledge and cognition. Journal of Clinical Nursing. 2009;18(23):3342-3348. [pmid: 19732240].

## Studies with no health outcomes (ie. descriptive only or have outcomes like likability, satisfaction)

1 Baker LM, Wilson FL, Winebarger A. An exploratory study of the health problems, stigmatization, life satisfaction, and literacy skills of urban, street-level sex workers. Women Health. 2004;39(2):83-96. [pmid: 15130863].
2 Magasi S, Durkin E, Wolf MS, Deutsch A. Rehabilitation consumers' use and understanding of quality information: a health literacy perspective. Arch Phys Med Rehabil. 2009;90(2):206-12. [pmid: 19236975].
3 Varkey AB, Manwell LB, Williams ES, et al. Separate and unequal: clinics where minority and nonminority patients receive primary care. Arch Intern Med. 2009;169(3):243-50. [pmid: 19204215].
4 Pickard AS, Lin HW, Knight SJ, et al. Proxy assessment of health-related quality of life in african american and white respondents with prostate cancer: perspective matters. Med Care. 2009;47(2):176-83. [pmid: 19169118].
5 Glasgow RE, Gaglio B, Estabrooks PA, et al. Long-term results of a smoking reduction program. Med Care. 2009;47(1):115-20. [pmid: 19106739].
6 Neafsey PJ, Anderson E, Peabody S, Lin CA, Strickler Z, Vaughn K. Beta testing of a network-based health literacy program tailored for older adults with hypertension. Comput Inform Nurs. 2008;26(6):311-9. [pmid: 19047879].
7 Roth MT, Moore CG, Ivey JL, Esserman DA, Campbell WH, Weinberger M. The quality of medication use in older adults: methods of a longitudinal study. Am J Geriatr Pharmacother. 2008;6(4):220-33. [pmid: 19028378].
8 Glasgow RE, Estabrooks PA, Marcus AC, et al. Evaluating initial reach and robustness of a practical randomized trial of smoking reduction. Health Psychol. 2008;27(6):780-8. [pmid: 19025274].
9 Brice JH, Travers D, Cowden CS, Young MD, Sanhueza A, Dunston Y. Health literacy among Spanish-speaking patients in the emergency department. J Natl Med Assoc. 2008;100(11):1326-32. [pmid: 19024230].
10 Downey LV, Zun LS. Assessing adult health literacy in urban healthcare settings. J Natl Med Assoc. 2008;100(11):1304-8. [pmid: 19024227].
11 Miller MJ, Abrams MA, McClintock B, et al. Promoting health communication between the community-dwelling well-elderly and pharmacists: the Ask Me 3 program. J Am Pharm Assoc (2003). 2008;48(6):784-92. [pmid: 19019809].
12 Clark DO, Frankel RM, Morgan DL, et al. The meaning and significance of self-management among socioeconomically vulnerable older adults. J Gerontol B Psychol Sci Soc Sci. 2008;63(5):S312-9. [pmid: 18818452].
13 Hawley ST, Janz NK, Hamilton A, et al. Latina patient perspectives about informed treatment decision making for breast cancer. Patient Educ Couns. 2008;73(2):363-70. [pmid: 18786799].
14 Iosifescu A, Halm EA, McGinn T, Siu AL, Federman AD. Beliefs about generic drugs among elderly adults in hospital-based primary care practices. Patient Educ Couns. 2008;73(2):377-83. [pmid: 18706784].
15 Ibrahim SY, Reid F, Shaw A, et al. Validation of a health literacy screening tool (REALM) in a UK population with coronary heart disease. J Public Health (Oxf). 2008;30(4):449-55. [pmid: 18660507].
16 Webb J, Davis TC, Bernadella P, et al. Patient-centered approach for improving prescription drug warning labels. Patient Educ Couns. 2008;72(3):443-9. [pmid: 18644691].
17 Ryan EL, Byrd D, Mindt MR, Rausch WJ, Morgello S. Understanding the neuropsychological profile of HIV+ participants with low literacy: role of the General Ability Measure for Adults (GAMA). Clin Neuropsychol. 2008;22(6):1018-34. [pmid: 18609327].
18 Volandes AE, Paasche-Orlow M, Gillick MR, et al. Health literacy not race predicts end-of-life care preferences. J Palliat Med. 2008;11(5):754-62. [pmid: 18588408].
19 Shea JA, Guerra CE, Weiner J, Aguirre AC, Ravenell KL, Asch DA. Adapting a patient satisfaction instrument for low literate and Spanish-speaking populations: comparison of three formats. Patient Educ Couns. 2008;73(1):132-40. [pmid: 18486414].
20 Ginde AA, Clark S, Goldstein JN, Camargo CA Jr. Demographic disparities in numeracy among emergency department patients: evidence from two multicenter studies. Patient Educ Couns. 2008;72(2):350-6. [pmid: 18462915].
21 Lehna C, McNeil J. Mixed-methods exploration of parents' health information understanding. Clin Nurs Res. 2008;17(2):133-44. [pmid: 18387884].
22 Wilson FL, Baker LM, Nordstrom CK, Legwand C. Using the teach-back and Orem's Self-care Deficit Nursing theory to increase childhood immunization communication among low-income mothers. Issues Compr Pediatr Nurs. 2008;31(1):7-22. [pmid: 18300059].
23 Ishikawa H, Takeuchi T, Yano E. Measuring functional, communicative, and critical health literacy among diabetic patients. Diabetes Care. 2008;31(5):874-9. [pmid: 18299446].
24 Pleasant A, Kuruvilla S. A tale of two health literacies: public health and clinical approaches to health literacy. Health Promot Int. 2008;23(2):152-9. [pmid: 18223203].
25 Williams KP, Mullan PB, Fletcher F. Working with African American women to develop a cancer literacy assessment tool. J Cancer Educ. 2007;22(4):241-4. [pmid: 18067436].
26 Kelly KM, Graves KD, Harper FW, Schmidt JE, Dickinson SL, Andrykowski MA. Assessing perceptions of cancer risk: does mode of assessment or numeracy matter?. Cancer Detect Prev. 2007;31(6):465-73. [pmid: 18061368].
27 Mayben JK, Giordano TP. Internet use among low-income persons recently diagnosed with HIV infection. AIDS Care. 2007;19(9):1182-7. [pmid: 18058404].
28 Young HK, Barton BA, Waisbren S, et al. Cognitive and psychological profile of males with Becker muscular dystrophy. J Child Neurol. 2008;23(2):155-62. [pmid: 18056690].
29 Sarkar U, Piette JD, Gonzales R, et al. Preferences for self-management support: findings from a survey of diabetes patients in safety-net health systems. Patient Educ Couns. 2008;70(1):102-10. [pmid: 17997264].
30 Castro CM, Wilson C, Wang F, Schillinger D. Babel babble: physicians' use of unclarified medical jargon with patients. Am J Health Behav. 1. 2007;31:S85-95. [pmid: 17931142].
31 Osborn CY, Weiss BD, Davis TC, et al. Measuring adult literacy in health care: performance of the newest vital sign. Am J Health Behav. 1. 2007;31:S36-46. [pmid: 17931135].
32 Donelle L, Hoffman-Goetz L, Arocha JF. Assessing health numeracy among community-dwelling older adults. J Health Commun. 2007;12(7):651-65. [pmid: 17934942].
33 Chang CH, Sharp LK, Kimmel LG, Grammer LC, Kee R, Shannon JJ. A 6-item brief measure for assessing perceived control of asthma in culturally diverse patients. Ann Allergy Asthma Immunol. 2007;99(2):130-5. [pmid: 17718100].
34 Guerra CE, Shea JA. Health literacy and perceived health status in Latinos and African Americans. Ethn Dis. 2007;17(2):305-12. [pmid: 17682363].
35 Downey LV, Zun L. Testing of a verbal assessment tool of English proficiency for use in the healthcare setting. J Natl Med Assoc. 2007;99(7):795-8. [pmid: 17668646].
36 Gong DA, Lee JY, Rozier RG, Pahel BT, Richman JA, Vann WF Jr. Development and testing of the Test of Functional Health Literacy in Dentistry (TOFHLiD). J Public Health Dent. 2007;67(2):105-12. [pmid: 17557682].
37 Richman JA, Lee JY, Rozier RG, Gong DA, Pahel BT, Vann WF Jr. Evaluation of a word recognition instrument to test health literacy in dentistry: the REALD-99. J Public Health Dent. 2007;67(2):99-104. [pmid: 17557681].
38 Lee JY, Rozier RG, Lee SY, Bender D, Ruiz RE. Development of a word recognition instrument to test health literacy in dentistry: the REALD-30--a brief communication. J Public Health Dent. 2007;67(2):94-8. [pmid: 17557680].
39 Dani KA, Stobo DB, Capell HA, Madhok R. Audit of literacy of medical patients in north Glasgow. Scott Med J. 2007;52(2):21-4. [pmid: 17536637].
40 Wallace LS, Cassada DC, Rogers ES, et al. Can screening items identify surgery patients at risk of limited health literacy?. J Surg Res. 2007;140(2):208-13. [pmid: 17509266].
41 Koo MM, Krass I, Aslani P. Evaluation of written medicine information: validation of the Consumer Information Rating Form. Ann Pharmacother. 2007;41(6):951-6. [pmid: 17488832].
42 Keselman A, Tse T, Crowell J, Browne A, Ngo L, Zeng Q. Assessing consumer health vocabulary familiarity: an exploratory study. J Med Internet Res. 2007;9(1):e5. [pmid: 17478414].
43 Kalichman SC, Amaral CM, Stearns H, et al. Adherence to antiretroviral therapy assessed by unannounced pill counts conducted by telephone. J Gen Intern Med. 2007;22(7):1003-6. [pmid: 17390095].
44 Kelly KM, Shedlosky-Shoemaker R, Porter K, Remy A, DeSimone P, Andrykowski MA. Cancer family history reporting: impact of method and psychosocial factors. J Genet Couns. 2007;16(3):373-82. [pmid: 17318453].
45 Diamond JJ. Development of a reliable and construct valid measure of nutritional literacy in adults. Nutr J. 2007;6:5. [pmid: 17300716].
46 Lillie SE, Brewer NT, O'Neill SC, et al. Retention and use of breast cancer recurrence risk information from genomic tests: the role of health literacy. Cancer Epidemiol Biomarkers Prev. 2007;16(2):249-55. [pmid: 17267389].
47 Rosenthal MS, Socolar RR, DeWalt DA, Pignone M, Garrett J, Margolis PA. Parents with low literacy report higher quality of parent-provider relationships in a residency clinic. Ambul Pediatr. 2007;7(1):51-5. [pmid: 17261483].
48 Brown SL, Teufel JA, Birch DA. Early adolescents perceptions of health and health literacy. J Sch Health. 2007;77(1):7-15. [pmid: 17212754].
49 Shea JA, Guerra CE, Ravenell KL, McDonald VJ, Henry CA, Asch DA. Health literacy weakly but consistently predicts primary care patient dissatisfaction. Int J Qual Health Care. 2007;19(1):45-9. [pmid: 17178765].
50 Kelly PA, Haidet P. Physician overestimation of patient literacy: a potential source of health care disparities. Patient Educ Couns. 2007;66(1):119-22. [pmid: 17140758].
51 Apter AJ, Cheng J, Small D, et al. Asthma numeracy skill and health literacy. J Asthma. 2006;43(9):705-10. [pmid: 17092853].
52 Bova C, Fennie KP, Watrous E, Dieckhaus K, Williams AB. The health care relationship (HCR) trust scale: development and psychometric evaluation. Res Nurs Health. 2006;29(5):477-88. [pmid: 16977644].
53 van Tol-Geerdink JJ, Stalmeier PF, van Lin EN, et al. Do prostate cancer patients want to choose their own radiation treatment?. Int J Radiat Oncol Biol Phys. 2006;66(4):1105-11. [pmid: 16965869].
54 Rogers ES, Wallace LS, Weiss BD. Misperceptions of medical understanding in low-literacy patients: implications for cancer prevention. Cancer Control. 2006;13(3):225-9. [pmid: 16885919].
55 Zun LS, Sadoun T, Downey L. English-language competency of self-declared English-speaking Hispanic patients using written tests of health literacy. J Natl Med Assoc. 2006;98(6):912-7. [pmid: 16775913].
56 Zanchetta MS, Perreault M, Kaszap M, Viens C. Patterns in information strategies used by older men to understand and deal with prostate cancer: an application of the modelisation qualitative research design. Int J Nurs Stud. 2007;44(6):961-72. [pmid: 16730729].
57 Trifiletti LB, Shields WC, McDonald EM, Walker AR, Gielen AC. Development of injury prevention materials for people with low literacy skills. Patient Educ Couns. 2006;64(1-3):119-27. [pmid: 16723205].
58 Peters E, Vastfjall D, Slovic P, Mertz CK, Mazzocco K, Dickert S. Numeracy and decision making. Psychol Sci. 2006;17(5):407-13. [pmid: 16683928].
59 Koo M, Krass I, Aslani P. Enhancing patient education about medicines: factors influencing reading and seeking of written medicine information. Health Expect. 2006;9(2):174-87. [pmid: 16677196].
60 Griffin J, McKenna K, Tooth L. Discrepancy between older clients' ability to read and comprehend and the reading level of written educational materials used by occupational therapists. Am J Occup Ther. 2006;60(1):70-80. [pmid: 16541986].
61 Buchbinder R, Hall S, Youd JM. Functional health literacy of patients with rheumatoid arthritis attending a community-based rheumatology practice. J Rheumatol. 2006;33(5):879-86. [pmid: 16511936].
62 Kang E, Fields HW, Cornett S, Beck FM. An evaluation of pediatric dental patient education materials using contemporary health literacy measures. Pediatr Dent. 2005;27(5):409-13. [pmid: 16435642].
63 Holmes-Rovner M, Price C, Rovner DR, et al. Men's theories about benign prostatic hyperplasia and prostate cancer following a benign prostatic hyperplasia decision aid. J Gen Intern Med. 2006;21(1):56-60. [pmid: 16423124].
64 Gerber BS, Pagcatipunan M, Smith EV Jr, et al. The assessment of diabetes knowledge and self-efficacy in a diverse population using Rasch measurement. J Appl Meas. 2006;7(1):55-73. [pmid: 16385151].
65 Kasper J, Kopke S, Muhlhauser I, Heesen C. Evidence-based patient information about treatment of multiple sclerosis--a phase one study on comprehension and emotional responses. Patient Educ Couns. 2006;62(1):56-63. [pmid: 16098706].
66 Koo MM, Krass I, Aslani P. Patient characteristics influencing evaluation of written medicine information: lessons for patient education. Ann Pharmacother. 2005;39(9):1434-40. [pmid: 16046486].
67 Schwartz LM, Woloshin S, Welch HG. Can patients interpret health information? An assessment of the medical data interpretation test. Med Decis Making. 2005;25(3):290-300. [pmid: 15951456].
68 Aguirre AC, Ebrahim N, Shea JA. Performance of the English and Spanish S-TOFHLA among publicly insured Medicaid and Medicare patients. Patient Educ Couns. 2005;56(3):332-9. [pmid: 15721976].
69 Georges CA, Bolton LB, Bennett C. Functional health literacy: an issue in African-American and other ethnic and racial communities. J Natl Black Nurses Assoc. 2004;15(1):1-4. [pmid: 15712814].
70 Levav I, Shemesh A, Grinshpoon A, Aisenberg E, Shershevsky Y, Kohn R. Mental health-related knowledge, attitudes and practices in two kibbutzim. Soc Psychiatry Psychiatr Epidemiol. 2004;39(9):758-64. [pmid: 15672298].
71 Leyva M, Sharif I, Ozuah PO. Health literacy among Spanish-speaking Latino parents with limited English proficiency. Ambul Pediatr. 2005;5(1):56-9. [pmid: 15656706].
72 Weinfurt KP, Depuy V, Castel LD, Sulmasy DP, Schulman KA, Meropol NJ. Understanding of an aggregate probability statement by patients who are offered participation in Phase I clinical trials. Cancer. 2005;103(1):140-7. [pmid: 15534885].
73 Birru MS, Monaco VM, Charles L, et al. Internet usage by low-literacy adults seeking health information: an observational analysis. J Med Internet Res. 2004;6(3):e25. [pmid: 15471751].
74 Collins M, Crowley R, Karlawish JH, Casarett DJ. Are depressed patients more likely to share health care decisions with others?. J Palliat Med. 2004;7(4):527-32. [pmid: 15353096].
75 Shea JA, Beers BB, McDonald VJ, Quistberg DA, Ravenell KL, Asch DA. Assessing health literacy in African American and Caucasian adults: disparities in rapid estimate of adult literacy in medicine (REALM) scores. Fam Med. 2004;36(8):575-81. [pmid: 15343419].
76 Schapira MM, Davids SL, McAuliffe TL, Nattinger AB. Agreement between scales in the measurement of breast cancer risk perceptions. Risk Anal. 2004;24(3):665-73. [pmid: 15209937].
77 Schwartz SR, McDowell J, Yueh B. Numeracy and the shortcomings of utility assessment in head and neck cancer patients. Head Neck. 2004;26(5):401-7. [pmid: 15122656].
78 Schillinger D, Bindman A, Wang F, Stewart A, Piette J. Functional health literacy and the quality of physician-patient communication among diabetes patients. Patient Educ Couns. 2004;52(3):315-23. [pmid: 14998602].
79 Boswell C, Cannon S, Aung K, Eldridge J. An application of health literacy research. Appl Nurs Res. 2004;17(1):61-4. [pmid: 14991557].
80 Bass PF 3rd, Wilson JF, Griffith CH. A shortened instrument for literacy screening. J Gen Intern Med. 2003;18(12):1036-8. [pmid: 14687263].
81 Baker DW, Williams MV, Parker RM, Gazmararian JA, Nurss J. Development of a brief test to measure functional health literacy. Patient Educ Couns. 1999;38(1):33-42. [pmid: 14528569].
82 Van Servellen G, Brown JS, Lombardi E, Herrera G. Health literacy in low-income Latino men and women receiving antiretroviral therapy in community-based treatment centers. AIDS Patient Care STDS. 2003;17(6):283-98. [pmid: 12880492].
83 Weinfurt KP, Castel LD, Li Y, et al. The correlation between patient characteristics and expectations of benefit from Phase I clinical trials. Cancer. 2003;98(1):166-75. [pmid: 12833469].
84 Galloway G, Murphy P, Chesson AL, Martinez K. MDA and AAEM informational brochures: can patients read them?. J Neurosci Nurs. 2003;35(3):171-4. [pmid: 12830665].
85 Schillinger D, Piette J, Grumbach K, et al. Closing the loop: physician communication with diabetic patients who have low health literacy. Arch Intern Med. 2003;163(1):83-90. [pmid: 12523921].
86 Woloshin S, Schwartz LM, Moncur M, Gabriel S, Tosteson AN. Assessing values for health: numeracy matters. Med Decis Making. 2001;21(5):382-90. [pmid: 11575488].
87 Montalto NJ, Spiegler GE. Functional health literacy in adults in a rural community health center. W V Med J. 2001;97(2):111-4. [pmid: 11392190].
88 Hutton BM. Do school qualifications predict competence in nursing calculations?. Nurse Educ Today. 1998;18(1):25-31. [pmid: 9528527].
89 Cartwright M. Numeracy needs of the beginning registered nurse. Nurse Educ Today. 1996;16(2):137-43. [pmid: 8716545].
90 Williams MV, Parker RM, Baker DW, et al. Inadequate functional health literacy among patients at two public hospitals. Jama. 1995;274(21):1677-82. [pmid: 7474271].
91 O'Bryant SE, Schrimsher GW, O'Jile JR. Discrepancies between self-reported years of education and estimated reading level: potential implications for neuropsychologists. Appl Neuropsychol. 2005;12(1):5-11. [pmid: 15788217].
92 Bennett IM, Robbins S, Al-Shamali N, Haecker T. Screening for low literacy among adult caregivers of pediatric patients. Fam Med. 2003;35(8):585-90. [pmid: 12947522].
93 Dellatolas G, Willadino Braga L, Souza Ldo N, Filho GN, Queiroz E, Deloche G. Cognitive consequences of early phase of literacy. J Int Neuropsychol Soc. 2003;9(5):771-82. [pmid: 12901783].
94 Fortman KK, Fisch RO, Phinney MY, Defor TA. Books and babies: clinical-based literacy programs. J Pediatr Health Care. 2003;17(6):295-300. [pmid: 14610443].
95 Fourney AM, Williams ML. Formative evaluation of an intervention to increase compliance to HIV therapies: the ALP project. Health Promot Pract. 2003;4(2):165-70. [pmid: 14610986].
96 Lobach DF, Hasselblad V, Wildemuth BM. Evaluation of a tool to categorize patients by reading literacy and computer skill to facilitate the computer-administered patient interview. AMIA Annu Symp Proc. 2003:391-5.
97 Sentell TL, Ratcliff-Baird B. Literacy and comprehension of Beck Depression Inventory response alternatives. Community Ment Health J. 2003;39(4):323-31. [pmid: 12908646].
98 Barnes DE, Tager IB, Satariano WA, Yaffe K. The relationship between literacy and cognition in well-educated elders. J Gerontol A Biol Sci Med Sci. 2004;59(4):390-5. [pmid: 15071084].
99 Benotsch EG, Kalichman S, Weinhardt LS. HIV-AIDS patients' evaluation of health information on the internet: the digital divide and vulnerability to fraudulent claims. J Consult Clin Psychol. 2004;72(6):1004-11. [pmid: 15612847].
100 Byrd DA, Touradji P, Tang MX, Manly JJ. Cancellation test performance in African American, Hispanic, and White elderly. J Int Neuropsychol Soc. 2004;10(3):401-11. [pmid: 15147598].
101 Hahn EA, Cella D, Dobrez D, et al. The talking touchscreen: a new approach to outcomes assessment in low literacy. Psychooncology. 2004;13(2):86-95. [pmid: 14872527].
102 Hindin TJ, Contento IR, Gussow JD. A media literacy nutrition education curriculum for head start parents about the effects of television advertising on their children's food requests. J Am Diet Assoc. 2004;104(2):192-8. [pmid: 14760566].
103 Lam TP, Cheng YH, Chan YL. Low literacy Chinese patients: how are they affected and how do they cope with health matters? A qualitative study. BMC Public Health. 2004;4:14. [pmid: 15125781].
104 Lee K, Ng SF, Ng EL, Lim ZY. Working memory and literacy as predictors of performance on algebraic word problems. J Exp Child Psychol. 2004;89(2):140-58. [pmid: 15388303].
105 Carroll JM, Maughan B, Goodman R, Meltzer H. Literacy difficulties and psychiatric disorders: evidence for comorbidity. J Child Psychol Psychiatry. 2005;46(5):524-32. [pmid: 15845132].
106 Kennen EM, Davis TC, Huang J, et al. Tipping the scales: the effect of literacy on obese patients' knowledge and readiness to lose weight. South Med J. 2005;98(1):15-8. [pmid: 15678634].
107 McDade TW, Leonard WR, Burhop J, et al. Predictors of C-reactive protein in Tsimane' 2 to 15 year-olds in lowland Bolivia. Am J Phys Anthropol. 2005;128(4):906-13. [pmid: 16118783].
108 Pan BA, Rowe ML, Singer JD, Snow CE. Maternal correlates of growth in toddler vocabulary production in low-income families. Child Dev. 2005;76(4):763-82. [pmid: 16026495].
109 Rothman RL, Malone R, Bryant B, et al. The Spoken Knowledge in Low Literacy in Diabetes scale: a diabetes knowledge scale for vulnerable patients. Diabetes Educ. 2005;31(2):215-24. [pmid: 15797850].
110 Ryan EL, Baird R, Mindt MR, Byrd D, Monzones J, Bank SM. Neuropsychological impairment in racial/ethnic minorities with HIV infection and low literacy levels: effects of education and reading level in participant characterization. J Int Neuropsychol Soc. 2005;11(7):889-98. [pmid: 16519268].
111 Schnell-Anzola B, Rowe ML, LeVine RA. Literacy as a Pathway between Schooling and Health-Related Communication Skills: A Study of Venezuelan Mothers. International Journal of Educational Development. 2005;25(1):19-37.
112 Wolf MS, Bennett CL, Davis TC, Marin E, Arnold C. A qualitative study of literacy and patient response to HIV medication adherence questionnaires. J Health Commun. 2005;10(6):509-17. [pmid: 16203630].
113 Wolf MS, Chang CH, Davis T, Makoul G. Development and validation of the Communication and Attitudinal Self-Efficacy scale for cancer (CASE-cancer). Patient Educ Couns. 2005;57(3):333-41. [pmid: 15893217].
114 Borson S, Scanlan JM, Watanabe J, Tu SP, Lessig M. Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. 2006;21(4):349-55. [pmid: 16534774].
115 Davis TC, Fredrickson DD, Potter L, et al. Patient understanding and use of oral contraceptive pills in a southern public health family planning clinic. South Med J. 2006;99(7):713-8. [pmid: 16866052].
116 Herlitz A, Kabir ZN. Sex differences in cognition among illiterate Bangladeshis: a comparison with literate Bangladeshis and Swedes. Scand J Psychol. 2006;47(6):441-7. [pmid: 17107492].
117 Schillinger D, Wang F, Palacios J, Rodriguez M, Machtinger EL, Bindman A. Language, Literacy, and Communication Regarding Medication in an Anticoagulation Clinic: A Comparison of Verbal vs. Visual Assessment. Journal of Health Communication. 2006;11(7):651-664. [pmid: 17074733].
118 Sleath BL, Jackson E, Thomas KC, et al. Literacy and perceived barriers to medication taking among homeless mothers and their children. Am J Health Syst Pharm. 2006;63(4):346-51. [pmid: 16452520].
119 Wallace LS, Rogers ES, Roskos SE, Holiday DB, Weiss BD. Screening Items to Identify Patients with Limited Health Literacy Skills. Journal of General Internal Medicine. 2006;21(8):874-877. [pmid: 16881950].
120 Wolf MS, Davis TC, Tilson HH, Bass PF 3rd, Parker RM. Misunderstanding of prescription drug warning labels among patients with low literacy. Am J Health Syst Pharm. 2006;63(11):1048-55. [pmid: 16709891].
121 Zazove P, Meador HE, Aikens JE, Nease DE, Gorenflo DW. Assessment of depressive symptoms in deaf persons. J Am Board Fam Med. 2006;19(2):141-7. [pmid: 16513902].
122 Gautam RK. Biosocial covariates of adult male body mass index in Central India. J Biosoc Sci. 2007;39(6):875-93. [pmid: 17349067].
123 Hubbard B, Rainey J. Health Literacy Instruction and Evaluation among Secondary School Students. American Journal of Health Education. 2007;38:332-337.
124 Isezuo SA, Abubakar SA. Epidemiologic profile of peripartum cardiomyopathy in a tertiary care hospital. Ethn Dis. 2007;17(2):228-33. [pmid: 17682350].
125 Katz MG, Jacobson TA, Veledar E, Kripalani S. Patient literacy and question-asking behavior during the medical encounter: a mixed-methods analysis. J Gen Intern Med. 2007;22(6):782-6. [pmid: 17431697].
126 Kerr D. Information in diabetes care: is there a need to dumb down even more?. Diabet Med. 2007;24(5):561-3. [pmid: 17367302].
127 Le C, Chongsuvivatwong V, Geater A. Contextual socioeconomic determinants of cardiovascular risk factors in rural south-west China: a multilevel analysis. BMC Public Health. 2007;7:72. [pmid: 17480237].
128 Lesaux NK, Vukovic RK, Hertzman C, Siegel LS. Context matters: The interrelatedness of early literacy skills, developmental health, and community demographics. Early Education and Development. 2007;18(3):497-518.
129 Marks DF. Literacy not intelligence moderates the relationships between economic development, income inequality and health. Br J Health Psychol. 2007;12(Pt 2):179-84. [pmid: 17456280].
130 Rao D, Hahn EA, Cella D, Hernandez L. The health related quality of life outcomes of English and Spanish speaking persons living with HIV/AIDS from the continental United States and Puerto Rico. AIDS Patient Care STDS. 2007;21(5):339-46. [pmid: 17518526].
131 Sharp LK, Kimmel LG, Kee R, Saltoun C, Chang CH. Assessing the Perceived Stress Scale for African American adults with asthma and low literacy. J Asthma. 2007;44(4):311-6. [pmid: 17530531].
132 Shobeiri F, Nazari M. Assessment of cervical erosion in Hamedan city, Iran. Pak J Biol Sci. 2007;10(19):3470-2. [pmid: 19090173].
133 Siddiqi A, Kawachi I, Berkman L, Subramanian SV, Hertzman C. Variation of socioeconomic gradients in children's developmental health across advanced Capitalist societies: analysis of 22 OECD nations. Int J Health Serv. 2007;37(1):63-87. [pmid: 17436986].
134 Ventura P, Kolinsky R, Querido JL, Fernandes S, Morais J. Is phonological encoding in naming influenced by literacy?. J Psycholinguist Res. 2007;36(5):341-60. [pmid: 17318434].
135 Arkkila E, Rasanen P, Roine RP, Vilkman E. Specific language impairment in childhood is associated with impaired mental and social well-being in adulthood. Logoped Phoniatr Vocol. 2008;33(4):179-89. [pmid: 18608878].
136 Chowdhary N, Patel V. The effect of spousal violence on women's health: findings from the Stree Arogya Shodh in Goa, India. J Postgrad Med. 2008;54(4):306-12. [pmid: 18953151].
137 Du H, Valenzuela V, Diaz P, Cella D, Hahn EA. Factors affecting enrollment in literacy studies for English- and Spanish-speaking cancer patients. Stat Med. 2008;27(20):4119-31. [pmid: 18381706].
138 Goodfellow GW, Trachimowicz R, Steele G. Patient literacy levels within an inner-city optometry clinic. Optometry. 2008;79(2):98-103. [pmid: 18215800].
139 Groeneveld PW, Kwoh CK, Mor MK, et al. Racial differences in expectations of joint replacement surgery outcomes. Arthritis Rheum. 2008;59(5):730-7. [pmid: 18438917].
140 Gul S, Ghaffar H, Mirza S, et al. Multitasking a telemedicine training unit in earthquake disaster response: paraplegic rehabilitation assessment. Telemed J E Health. 2008;14(3):280-3. [pmid: 18570553].
141 Martin RW, Head AJ, Rene J, et al. Patient decision-making related to antirheumatic drugs in rheumatoid arthritis: the importance of patient trust of physician. J Rheumatol. 2008;35(4):618-24. [pmid: 18278840].
142 Movahedi M, Haghdoost AA, Pournik O, Hajarizadeh B, Fallah MS. Temporal variations of health indicators in Iran comparing with other Eastern Mediterranean Region countries in the last two decades. J Public Health (Oxf). 2008;30(4):499-504. [pmid: 18772146].
143 Roizen M, Rodriguez S, Bauer G, et al. Initial validation of the Argentinean Spanish version of the PedsQL 4.0 Generic Core Scales in children and adolescents with chronic diseases: acceptability and comprehensibility in low-income settings. Health Qual Life Outcomes. 2008;6:59. [pmid: 18687134].
144 Saiepour N, Mohammad K, Abhari R, Zeraati H, Noorbala AA. Mental disorder assessed by General Health Questionnaire and back pain among postmenopausal Iranian women. Pak J Biol Sci. 2008;11(5):809-12. [pmid: 18819584].
145 Britigan DH, Murnan J, Rojas-Guyler L. A qualitative study examining Latino functional health literacy levels and sources of health information. Journal of Community Health. 2009;34(3):222-230. [pmid: 19127413].
146 Roberts NJ, Mohamed Z, Wong PS, Johnson M, Loh LC, Partridge MR. The development and comprehensibility of a pictorial asthma action plan. Patient Educ Couns. 2009;74(1):12-8. [pmid: 18789626].
147 Sudore RL, Landefeld CS, Perez-Stable EJ, Bibbins-Domingo K, Williams BA, Schillinger D. Unraveling the relationship between literacy, language proficiency, and patient-physician communication. Patient Educ Couns. 2009;75(3):398-402. [pmid: 19442478].
148 Federman AD, Safran DG, Keyhani S, Cole H, Halm EA, Siu AL. Awareness of pharmaceutical cost-assistance programs among inner-city seniors. Am J Geriatr Pharmacother. 2009;7(2):117-29. [pmid: 19447364].
149 Looveer J, Mulligan J. The efficacy of link items in the construction of a numeracy achievement scale--from kindergarten to year 6. J Appl Meas. 2009;10(3):247-65. [pmid: 19671988].
150 Hall J, Donelle L. Research with women serving court-mandated probation or parole orders. Can J Nurs Res. 2009;41(2):37-53. [pmid: 19650512].
151 Arthur SA, Geiser HR, Arriola KR, Kripalani S. Health literacy and control in the medical encounter: a mixed-methods analysis. J Natl Med Assoc. 2009;101(7):677-83. [pmid: 19634588].
152 Keller C, Siegrist M, Visschers V. Effect of risk ladder format on risk perception in high- and low-numerate individuals. Risk Anal. 2009;29(9):1255-64. [pmid: 19572963].
153 Leikauf J, Federman AD. Comparisons of self-reported and chart-identified chronic diseases in inner-city seniors. J Am Geriatr Soc. 2009;57(7):1219-25. [pmid: 19486197].
154 Mohan R, Beydoun H, Barnes-Ely ML, et al. Patients' survival expectations before localized prostate cancer treatment by treatment status. J Am Board Fam Med. 2009;22(3):247-56. [pmid: 19429730].
155 Bankson HL. Health literacy: an exploratory bibliometric analysis, 1997-2007. J Med Libr Assoc. 2009;97(2):148-50. [pmid: 19404510].
156 Gordon EJ, Wolf MS. Health literacy skills of kidney transplant recipients. Prog Transplant. 2009;19(1):25-34. [pmid: 19341060].
157 Peters E, Dieckmann NF, VÃ¤stfjÃ¤ll D, Mertz CK, Slovic P, Hibbard JH. Bringing meaning to numbers: The impact of evaluative categories on decisions. Journal of Experimental Psychology: Applied. 2009;15(3):213-227. [pmid: 19751072].
158 Shaw A, Ibrahim S, Reid F, Ussher M, Rowlands G. Patients' perspectives of the doctor-patient relationship and information giving across a range of literacy levels. Patient Education and Counseling. 2009;75(1):114-120. [pmid: 19041210].
159 Miller MJ, Schmitt MR, Allison JJ, Cobaugh DJ, Ray MN, Saag KG. The role of health literacy and written medicine information in nonsteroidal antiinflammatory drug risk awareness. Ann Pharmacother. 2010;44(2):274-84. [pmid: 20103612].
160 Master VA, Johnson TV, Abbasi A, et al. Poorly numerate patients in an inner city hospital misunderstand the American Urological Association symptom score. Urology. 2010;75(1):148-52. [pmid: 19819537].
161 Roth MT, Watson LC, Esserman DA, et al. Methodology of a pilot study to improve the quality of medication use in older adults: Enhancing Quality in Psychiatry Using Pharmacists (EQUIPP). Am J Geriatr Pharmacother. 2009;7(6):362-72. [pmid: 20129257].
162 Ishikawa H, Yano E, Fujimori S, et al. Patient health literacy and patient-physician information exchange during a visit. Fam Pract. 2009;26(6):517-23. [pmid: 19812242].
163 Couper MP, Singer E. The role of numeracy in informed consent for surveys. J Empir Res Hum Res Ethics. 2009;4(4):17-26. [pmid: 19919316].
164 Carvalho Sde A, Barreto SM, Guerra HL, Gama AC. Oral language comprehension assessment among elderly: a population based study in Brazil. Prev Med. 2009;49(6):541-5. [pmid: 19800364].
165 Pizur-Barnekow K, Doering J, Cashin S, Patrick T, Rhyner P. Functional health literacy and mental health in urban and rural mothers of children enrolled in early intervention programs. Infants & Young Children: An Interdisciplinary Journal of Special Care Practices. 2010;23(1):42-51.
166 Khare MM, Huber R, Carpenter RA, et al. A lifestyle approach to reducing cardiovascular risk factors in underserved women: design and methods of the Illinois WISEWOMAN Program. Journal of women's health (2002). 2009;(3):409-19.
167 DeWalt DA, Broucksou KA, Hawk V, et al. Comparison of a one-time educational intervention to a teach-to-goal educational intervention for self-management of heart failure: design of a randomized controlled trial. BMC health services research. 2009:99.
168 Rosal MC, White MJ, Restrepo A, et al. Design and methods for a randomized clinical trial of a diabetes self-management intervention for low-income Latinos: Latinos en Control. BMC medical research methodology. 2009:81.
169 Steckelberg A, Hülfenhaus C, Kasper J, Mühlhauser I. Ebm@school--a curriculum of critical health literacy for secondary school students: results of a pilot study. International journal of public health. 2009;(3):158-65. [pmid: 19183847].

## Studies examining normal reading development in children

1 Malacova E, Li J, Blair E, Leonard H, de Klerk N, Stanley F. Association of birth outcomes and maternal, school, and neighborhood characteristics with subsequent numeracy achievement. Am J Epidemiol. 2008;168(1):21-9. [pmid: 18417493].
2 Li H, Barnhart HX, Stein AD, Martorell R. Effects of early childhood supplementation on the educational achievement of women. Pediatrics. 2003;112(5):1156-62. [pmid: 14595062].
3 Prior M, Smart D, Sanson A, Oberklaid F. Relationships between learning difficulties and psychological problems in preadolescent children from a longitudinal sample. J Am Acad Child Adolesc Psychiatry. 1999;38(4):429-36. [pmid: 10199115].
4 O'Callaghan FV, O'Callaghan M, Najman JM, Williams GM, Bor W. Prenatal alcohol exposure and attention, learning and intellectual ability at 14 years: a prospective longitudinal study. Early Hum Dev. 2007;83(2):115-23. [pmid: 16842939].
5 Grunau RE, Whitfield MF, Fay TB. Psychosocial and academic characteristics of extremely low birth weight (&lt; or =800 g) adolescents who are free of major impairment compared with term-born control subjects. Pediatrics. 2004;114(6):e725-32. [pmid: 15576337].
6 Daley TC, Whaley SE, Sigman MD, Espinosa MP, Neumann C. IQ on the rise: the Flynn effect in rural Kenyan children. Psychol Sci. 2003;14(3):215-9. [pmid: 12741743].

## Studies about dyslexia

1 Hetherington R, Dennis M, Barnes M, Drake J, Gentili F. Functional outcome in young adults with spina bifida and hydrocephalus. Childs Nerv Syst. 2006;22(2):117-24. [pmid: 16170574].
2 Llewellyn G, McConnell D, Honey A, Mayes R, Russo D. Promoting health and home safety for children of parents with intellectual disability: a randomized controlled trial. Res Dev Disabil. 2003;24(6):405-31. [pmid: 14622893].

## Studies answering KQ1 where literacy is measured (not numeracy) and the only study outcome is knowledge

1 Kollipara UK, Jaffer O, Amin A, et al. Relation of lack of knowledge about dietary sodium to hospital readmission in patients with heart failure. Am J Cardiol. 2008;102(9):1212-5. [pmid: 18940294].
2 Hill-Briggs F, Renosky R, Lazo M, et al. Development and pilot evaluation of literacy-adapted diabetes and CVD education in urban, diabetic African Americans. J Gen Intern Med. 2008;23(9):1491-4. [pmid: 18521688].
3 Fortner KB, Zite NB, Wallace LS. In my own words: misunderstanding of Pap smears and colposcopy among Appalachian women. J Low Genit Tract Dis. 2007;11(4):251-7. [pmid: 17917569].
4 Pollock JB, Jaffery JB. Knowledge of phosphorus compared with other nutrients in maintenance dialysis patients. J Ren Nutr. 2007;17(5):323-8. [pmid: 17720101].
5 Baker LM, Wilson FL, Nordstrom CK, Legwand C. Mothers' knowledge and information needs relating to childhood immunizations. Issues Compr Pediatr Nurs. 2007;30(1-2):39-53. [pmid: 17613141].
6 Cho RN, Plunkett BA, Wolf MS, Simon CE, Grobman WA. Health literacy and patient understanding of screening tests for aneuploidy and neural tube defects. Prenat Diagn. 2007;27(5):463-7. [pmid: 17345585].
7 Hicks G, Barragan M, Franco-Paredes C, Williams MV, del Rio C. Health literacy is a predictor of HIV/AIDS knowledge. Fam Med. 2006;38(10):717-23. [pmid: 17075745].
8 Davis TC, Wolf MS, Bass PF 3rd, et al. Low literacy impairs comprehension of prescription drug warning labels. J Gen Intern Med. 2006;21(8):847-51. [pmid: 16881945].
9 Dolan NC, Ferreira MR, Davis TC, et al. Colorectal cancer screening knowledge, attitudes, and beliefs among veterans: does literacy make a difference?. J Clin Oncol. 2004;22(13):2617-22. [pmid: 15226329].
10 Gazmararian JA, Williams MV, Peel J, Baker DW. Health literacy and knowledge of chronic disease. Patient Educ Couns. 2003;51(3):267-75. [pmid: 14630383].
11 Wilson FL, Racine E, Tekieli V, Williams B. Literacy, readability and cultural barriers: critical factors to consider when educating older African Americans about anticoagulation therapy. J Clin Nurs. 2003;12(2):275-82. [pmid: 12603561].
12 Kaphingst KA, Rudd RE, Dejong W, Daltroy LH. Comprehension of information in three direct-to-consumer television prescription drug advertisements among adults with limited literacy. J Health Commun. 2005;10(7):609-19. [pmid: 16278198].
13 Wolf MS, Davis TC, Arozullah A, et al. Relation between literacy and HIV treatment knowledge among patients on HAART regimens. AIDS Care. 2005;17(7):863-73. [pmid: 16120503].
14 Johnson TV, Goodman M, Master VA. The efficacy of written screening tools in an inner city hospital: literacy based limitations on patient access to appropriate care. J Urol. 2007;178(2):623-9. discussion 629. [pmid: 17570427].
15 Fang MC, Panguluri P, Machtinger EL, Schillinger D. Language, literacy, and characterization of stroke among patients taking warfarin for stroke prevention: Implications for health communication. Patient Educ Couns. 2009;75(3):403-10. [pmid: 19171448].
16 Huizinga MM, Carlisle AJ, Cavanaugh KL, et al. Literacy, numeracy, and portion-size estimation skills. Am J Prev Med. 2009;36(4):324-8. [pmid: 19285197].
17 Marks JR, Schectman JM, Groninger H, Plews-Ogan ML. The association of health literacy and socio-demographic factors with medication knowledge. Patient Education and Counseling. 2010;78(3):372-376. [pmid: 19773144].

## Studies in which the outcome is limited to dementia or cognitive impairment

1 Manly JJ, Touradji P, Tang MX, Stern Y. Literacy and memory decline among ethnically diverse elders. J Clin Exp Neuropsychol. 2003;25(5):680-90. [pmid: 12815505].
2 Martin RC, Annis SM, Darling LZ, Wadley V, Harrell L, Marson DC. Loss of calculation abilities in patients with mild and moderate Alzheimer disease. Arch Neurol. 2003;60(11):1585-9. [pmid: 14623731].
3 Mehta KM, Simonsick EM, Rooks R, et al. Black and white differences in cognitive function test scores: what explains the difference?. J Am Geriatr Soc. 2004;52(12):2120-7. [pmid: 15571554].
4 Mehta KM, Stewart AL, Langa KM, et al. “Below average” self-assessed school performance and Alzheimer's disease in the Aging, Demographics, and Memory Study. Alzheimers Dement. 2009;5(5):380-7. [pmid: 19751917].

## Studies published in abstract form only

1 Baird AD, Ford M, Podell K. Ethnic differences in functional and neuropsychological test performance in older adults. Arch Clin Neuropsychol. 2007;22(3):309-18. [pmid: 17317093].

## Ecological data only

1 Anand S, Barnighausen T. Health workers and vaccination coverage in developing countries: an econometric analysis. Lancet. 2007;369(9569):1277-85. [pmid: 17434403].
2 Berhane Y, Wall S, Fantahun M, et al. A rural Ethiopian population undergoing epidemiological transition over a generation: Butajira from 1987 to 2004. Scand J Public Health. 2008;36(4):436-41. [pmid: 18539699].
3 Fantahun M, Berhane Y, Hogberg U, Wall S, Byass P. Young adult and middle age mortality in Butajira demographic surveillance site, Ethiopia: lifestyle, gender and household economy. BMC Public Health. 2008;8:268. [pmid: 18671854].
4 Li J, Luo C, de Klerk N. Trends in infant/child mortality and life expectancy in Indigenous populations in Yunnan Province, China. Aust N Z J Public Health. 2008;32(3):216-23. [pmid: 18578818].
5 Nwogu R, Larson JS, Kim MS. Reducing child mortality in Nigeria: a case study of immunization and systemic factors. Soc Sci Med. 2008;67(1):161-4. [pmid: 18420324].

## Unable to obtain the article

1 Osborne H. In other words… Building healthy literacy programs one step at a time. On Call. 2004;7(6):16-17.