# Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. We would also like to extend our appreciation to our Associate Editor, Robert L. Kane, MD, Director of Minnesota Evidence-based Practice Center for his review and advice on improving the initial draft. Our peer review panel includes four members of the TEP: David Baker, Cindy Brach, Darren DeWalt, and Joanne Schwartzberg. Peer review was a separate duty for these individuals and not part of their commitment as TEP members. All are active professionals in the field. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

David Baker, MD

Internal Medicine, Northwestern University

Chicago, IL

Cindy Brach, MPP

Agency for Healthcare Research and Quality

Rockville, MD

Terry C. Davis, PhD

Louisiana State University Health Sciences Center

Shreveport, LA

Darren DeWalt, MD

Internal Medicine, University of North Carolina

Chapel Hill, NC

Elissa Schuler Adair, PhD

Consumer Reports

New York, NY

Joanne Schwartzberg, MD

American Medical Association

Chicago, IL