# Strength of Evidence

KQ 1 Health literacy strength of evidence grade by domain and overall summary grade

Outcome for Health Literacy Studies | Number of Studies | Results | Domain: Risk of Bias | Domain: Consistency | Domain: Directness | Domain: Precision | Overall Grade
Hospitalization | 6 | Low literacy associated with increased hospitalization | Medium | Consistent | Direct | Precise | Moderate
Emergency Care Visit | 9 | Low literacy associated with greater emergency care use except in one study of urgent care visits (measured by self-report) | Medium | Consistent | Direct | Imprecise | Moderate
Colon Screening | 5 | Larger studies found lower probability of screening | Medium | Inconsistent | Direct | Imprecise | Low
Pap Smears | 3 | Low literacy associated with decreased probability of ever having a Pap smear | Medium | Inconsistent | Direct | Imprecise | Low
Mammogram | 4 | Low literacy associated with less use of mammography; measures and populations differed across studies | Medium | Consistent | Direct | Imprecise | Moderate
Sexually Transmitted Infection | 1 | Low literacy associated with greater odds of accepting HIV testing | Medium | Not Applicable | Direct | Precise | Low
Immunization: Influenza | 4 | Low literacy associated with lower probability of receipt of influenza vaccine | Medium | Consistent | Direct | Precise | Moderate
Immunization: Pneumococcal | 2 | Mixed results | Medium | Not Applicable | Direct | Imprecise | Insufficient
Access to Care | 9 | Mixed results for association with number of physician visits, dental and vision visits. | Medium | Inconsistent | Direct | Imprecise | Insufficient
Access to Insurance | 1 | Parental low literacy associated with having child without health insurance | Medium | Not Applicable | Direct | Precise | Low
Adherence | 11 | Mixed results depending on adherence measure, disease state, and adjustment for confounding | Medium | Inconsistent | Direct | Imprecise | Insufficient
Self-Efficacy | 5 | Mixed results in studies conducted within various sub-populations | Medium | Inconsistent | Direct | Imprecise | Insufficient
Smoking | 2 | Mixed results | Medium | Inconsistent | Direct | Imprecise | Insufficient
Drug and Alcohol Use | 2 | No effect on current alcohol consumption, higher health literacy associated with greater substance use in one study. | Medium | Inconsistent | Direct | Imprecise | Insufficient
Healthy Lifestyle (Physical Activity, Eating Habits, and Seat Belt Use) | 3 | Mixed results from 1 study each on exercise, diet, a composite measure, and seatbelt use | Medium | Inconsistent | Direct | Imprecise | Insufficient
Healthy Lifestyle (Obesity and Weight) | 5 | Mixed results,4 of 5 studies unadjusted | High | Inconsistent | Direct | Imprecise | Insufficient
Review of Prescription Information | 1 | Low health literacy associated with being less likely to read prescription information | Medium | Not Applicable | Direct | Precise | Low
HIV Risk and Sexual Behaviors | 2 | Mixed results | Medium | Inconsistent | Direct | Imprecise | Insufficient
Taking Medications Appropriately | 6 | Lower health literacy associated with poorer ability to demonstrate being able to take mediations appropriately | Medium | Consistent | Direct | Imprecise | Moderate
Interpreting Labels and Health Messages | 3 | Low literacy associated with poorer ability to interpret labels and health messages; smaller likelihood of giving an organized health narrative | Medium | Consistent | Direct | Precise | Moderate
Asthma Self-Care | 1 | Low literacy associated with poorer self-care skill in 1 study | Medium | Not Applicable | Direct | Imprecise | Low
Mental Health Symptomatology | 10 | Results in 8 of 10 studies found association between lower literacy and depression but control for confounding was limited | Medium | Consistent | Direct | Imprecise | Low
Chronic Disease Outcomes | 7 | Mixed results: 3 studies on association with chronic diseases generally and 4 on association with specific diseases | Medium | Inconsistent | Direct | Imprecise | Insufficient
HIV Severity and Symptoms | 5 | Results in 3 studies found no relationship but control for confounding was limited and sample sizes were small | Medium | Consistent | Direct | Imprecise | Low
Asthma Severity and Control | 2 | Mixed results; only unadjusted analysis of asthma control | High | Inconsistent | Direct | Imprecise | Insufficient
Diabetes Control and Related Symptoms | 5 | Glycemic control: 5 studies mixed results Complications: 1 study no relationship | Medium | Inconsistent | Direct | Imprecise | Insufficient
Hypertension Control | 2 | Mixed results | Medium | Inconsistent | Direct | Imprecise | Insufficient
Prostate Cancer Control | 1 | Patients with low HL more likely to have higher PSA (worse levels) | Medium | Not Applicable | Direct | Precise | Low
Health Status: All Adults | 1 | No relationship with global health status | Medium | Not Applicable | Direct | Precise | Low
Health Status and Quality of Life: Seniors | 5 | Lower health literacy associated with lower overall health status | Overall: Moderate | Overall: Consistent | Direct | Overall: Precise | Overall: Moderate
Health Status and Quality of Life: Seniors | 5 | Mental and Physical functioning: mixed results | Mental/Physical: moderate | Mental/Physical: inconsistent | Direct | Mental/Physical: Imprecise | Mental/Physical: Insufficient
Health Status and Quality of Life: Individuals with Specific Diseases | 5 | Mental and physical functioning by disease state and measure: mixed results | Medium | Inconsistent | Direct | Imprecise | Insufficient
Mortality: Seniors | 2 | Higher risk of mortality in the lower literacy group. Risk not elevated in the marginal literacy group (1study) | Low | Consistent | Direct | Precise | High
Costs of Health Care | 2 | Results mixed across payment source and patient populations | Medium | Inconsistent | Direct | Imprecise | Insufficient
Disparities | 8 | Health literacy mediates disparities in some specific health outcomes between black and white race but results were mixed. Health literacy not found to mediate the relationship between Hispanic and white race or males and females but little data available. | Black/White and Health Outcome: Moderate | Black/White: Inconsistent | Black/White : Direct | Black/White :Precise | Black/White: Low
Disparities | 8 | | Hispanic: Low | Hispanic: Not Applicable | Hispanic: Direct | Hispanic: Precise | Hispanic: Insufficient
Disparities | 8 | | Sex: Low | Sex: Not Applicable | Sex: Direct | Sex: Precise | Sex: Insufficient

HIV=human immunodeficiency virus; HL=health literacy; Pap=Papanicolau; PSA=prostate-specific antigen

KQ1 Numeracy strength of evidence grade by domain and overall summary grade

Outcome | Number of Studies | Results | Risk of Bias | Domain: Risk of Bias | Domain: Directness | Domain: Precision | Overall Grade
Accuracy of Risk Perception | 5 | Perceived risk (n = 2): mixed results depending on length over which risk estimated Perceived treatment benefit (n = 4): Mixed results depending on numeracy level categories, 3 of 4 studies suggested low numeracy reduced accuracy of perceived benefit. | Medium | Inconsistent | Direct | Imprecise | Insufficient
Knowledge | 4 | Mixed results, partially dependent on type of knowledge, sample size, and adjustment for confounding | Medium | Inconsistent | Direct | Imprecise | Insufficient
Self Efficacy | 1 | Lower numeracy associated with lower self-efficacy in unadjusted analysis | High | Not Applicable | Direct | Precise | Insufficient
Behavior | 1 | Lower numeracy not related to self-care behavior in unadjusted analysis | High | Not Applicable | Direct | Precise | Insufficient
Skills | 6 | Mixed results depending on type of skill Skill in taking medication (n = 4): mixed results | Skill in taking medication: Medium | Skill in taking medication: inconsistent | Skill in taking medication: Direct | Skill in taking medication: Imprecise | Skill in taking medication: Insufficient
Skills | 6 | Skill in interpreting health information (n = 2): Lower numeracy related to lower comprehension | Skill in interpreting health information: Medium | Skill in interpreting health information: consistent | Skill in interpreting health information: Direct | Skill in interpreting health information: Precise | Skill in interpreting health information: Low
Disease Prevalence and Severity | 3 | BMI (n = 2), HbA1c (n = 1), illness requiring dietary restriction (n = 1): Mixed results | Medium | Inconsistent | Direct | Imprecise | Insufficient
Use of Healthcare Services | 1 | Mixed results, no adjustment for confounding | High | Inconsistent | Direct | Imprecise | Insufficient
Disparities | 2 | Numeracy appears to partially mediate the relationship between race and HgbA1c (n = 1) and between gender and HIV medication management capacity (n = 1) | Medium | Consistent | Direct | Imprecise | Low

BMI=body mass index; HbA1c=glycosylated hemoglobin; HIV=human immunodeficiency virus

KQ 2 specific interventions, strength of evidence grade by domain and overall summary grade

Outcome | Number of Studies | Results | Domain: Risk of Bias | Domain: Consistency | Domain: Directness | Domain: Precision | Overall Grade
Alternative Document Design | 2 RCTs examining multiple simplifications | Highlighting common quality features (n=1): No effect Providing a framework for quality features (i.e. chunking advantages and disadvantages; n=1): improved comprehension for high literacy, worsened comprehension for low literacy if long rather than short list of features Presenting only essential quality info (i.e. death rates, not satisfaction) (n=1): Improved comprehension and choice of higher quality plans Presenting essential quality info first (n=1): Improved comprehension for low literacy only. No effect on health plan choice. | Medium | Not Applicable | Direct | Imprecise | Insufficient
Alternative Numerical Presentation | 3 RCTs examining different numerical presentations | Presenting quality information such that the higher number (vs. lower number) is better: Improved comprehension and choices of higher quality options for low (but not high) numeracy individuals Presenting information about the baseline risk of disease and treatment benefit information with the same versus different numbers: Improved accuracy of risk perception with greater effect in low versus high numeracy group Presenting positive predictive values as natural frequencies rather than conditional probabilities: improved comprehension equally for low and high literacy individuals | Medium | Consistent | Direct | Imprecise | Low
Alternative Pictorial Representations | 6 RCTs and 2 quasi-experimental studies examining; 1. adding symbols to numerical information,; 2. adding icon arrays to numbers,; 3. adding illustrations to prose,; 4. using different pictorial representtations for same concept | Adding symbols to numerical info (n=2): Mixed effects depending on the symbols and the information to which they were added. Plus/minus signs to indicate fewer/more had no overall effect, although there was an interaction by whether higher quality was indicated by higher or lower numbers. Black and white and colored traffic light circles had no effect on comprehension, but increased the proportion of individuals choosing high quality hospitals. However, there was an interaction by 1) whether essential (i.e. death rates) or both essential and non-essential (i.e. death rates and satisfaction) quality information was presented, and 2) by numeracy level. Adding icon arrays to numbers (n=2): Improved understanding of both ARR and RRR presentations when icons were added. Interaction by 1) numeracy level, and 2) whether numbers and icon arrays depicted baseline risk and the risk following treatment with the same or different denominators. Adding illustrations to prose (n=2): No effect of mind map added to brochure or illustrations added to simple medication label text Using different pictorial representations for the same concept (n=2): No overall improvement with grouped (versus random) icon arrays, although interaction by numeracy level. Some teratogen warning symbols | Medium | Inconsistent | Direct | Imprecise | Insufficient
Alternative Media | 4 RCT examining alternate media; 3 examining adding or substituting other media for print and 1 examining adding video to verbal narrative | Effect of adding or substituting for print (n = 3) : Effect for adding video, computer, or slide show presentations to print were mixed. Effect for simplified print were mixed depending on the reading level of the printed materials and study design and quality Effect of adding video to verbal narrative (n = 1) : Improved knowledge and preference for comfort care | Medium | Inconsistent | Direct | Imprecise | Insufficient
Alternative Readability and Document Design | 6 RCTs, 1 quasi-experimental study with post-only data | Mixed results depending on degree of simplification, literacy level of population, and study quality | Medium | Inconsistent | Direct | Imprecise | Insufficient
Physician Notification of Patient Literacy Status | 1 cRCT | No effect on patient level outcomes | Medium | Not Applicable | Direct | Precise | Low

RCTs=randomized controlled trials; info=information; vs.=versus; cRCT=cluster randomized controlled trial

KQ 2 Mixed interventions, strength of evidence grade by domain and overall summary grade

Outcome | Number of Studies | Results | Domain: Risk of Bias | Domain: Consistency | Domain: Directness | Domain: Precision | Overall Grade
Use of Healthcare Services | 4 RCTs, 1cRCT, and 1 quasi-experimental study | Preventive services (n=2): Increased use across literacy levels ED visits (n=2): Reduced use across literacy levels Hospitalizations (n=3): Reduced use (or trends toward reduced use) across literacy levels; greater reductions in low literacy population | Medium | Consistent | Direct | Precise | Moderate
Knowledge | 3 RCTs and 7 quasi-experimental studies (including 2 with post-test only data on knowledge, which precluded conclusions) | Mixed results with 5 of 8 studies with interpretable data showing an effect on knowledge | Medium | Inconsistent | Direct | Imprecise | Insufficient
Self Efficacy | 4 RCTs and 5 quasi-experimental studies | Mixed results depending on intensity of intervention; for intensive interventions although these analyses for these interventions weren't stratified by literacy level | Medium | Consistent | Direct | Precise | Insufficient
Skill | 1 RCT | Improved label reading skill with greater effect in those with high literacy (However, 2 studies from review found mixed results) | Medium | Not Applicable | Direct | Imprecise | Insufficient
Behavior | 2 RCTs and 1 quasi-experimental study | Improved self-management behaviors, greater improvement in adequate literacy group in the 1 study that performed analysis stratified by literacy level | Medium | Consistent | Direct | Imprecise | Moderate
Disease Prevalence and Severity | 4 RCTs, 3 quasi-experimental studies | Self-management programs (n=3): mixed effects on biomarkers depending on study quality | Self-management programs: Medium | Self-management programs: Inconsistent | Self-management programs: Direct | Self-management programs: Imprecise | Self-management programs: Insufficient
Disease Prevalence and Severity | 4 RCTs, 3 quasi-experimental studies | Disease management programs (n=2): improved HbA1c in low literacy group, improved BP across literacy levels | Disease management programs: Medium | Disease management programs: Consistent | Disease management programs: Direct | Disease management programs: Precise | Disease manage programs: Moderate
Disease Prevalence and Severity | 4 RCTs, 3 quasi-experimental studies | Adult Basic and Literacy Education (n=1): improved depression severity across literacy levels | Adult Basic and Literacy Education: Medium | Adult Basic and Literacy Education: Not Applicable | Adult Basic and Literacy Education: Direct | Adult Basic and Literacy Education: Imprecise | Adult Basic and Literacy Education: Low
Adherence | 3 RCTs and 2 quasi-experimental studies (1 with post-test only data) | Mixed results related to the intensity of the intervention and measure of adherence | Medium | Inconsistent | Direct | Imprecise | Insufficient
Quality of Life | 4 RCTs (1 measured QoL only post-test in intervention group) | Mixed results | Medium | Inconsistent | Indirect | Imprecise | Insufficient
Costs | 2 RCT | Non-significant trend toward reduced cost across literacy groups | Low | Not Applicable | Indirect | Imprecise | Insufficient

a Data from 2004 review modify overall strength of evidence to be moderate

RCTs=randomized controlled trials; HbA1c=glycosylated hemoglobin; BP=blood pressure; QoL=quality of Life; cRCT=cluster randomized controlled trial; ED=emergency department