# Evidence Tables

Evidence Table 1 Key Question 1: Health literacy outcome studies

Evidence Table 2 Key Question 1: Numeracy Outcome Studies

Evidence Table 3 Key Question 2: Intervention studies

## Glossary of Abbreviations and Acronyms Used in Evidence Tables

Abbreviation/Acronym: Definition
*: Calculated by evidence report authors
AA: African-American
ABCD: Assessment of Body Change Distress Scale
ABLE: Adult Basic Learning Examination
ABMT: Autologous bone marrow transplant
AC: Asthma clinic
ACE: Angiotensin-converting enzyme
ADEPT: Adherence and Efficacy to Protease Inhibitor Therapy study
ADL: Activities of daily living
AdLit: Adolescent Literacy
AFDC: Aid for Families with Dependent Children
AIDS: Acquired immune deficiency syndrome
ANCOVA: Analysis of covariance
ANOVA: Analysis of variance
AOR: adjusted odds ratio
AQLQ: Asthma Quality of Life Questionnaire
ARB: Angiotensin II receptor blockers
ARC: Arthritis Research Campaign
ARR: Absolute Risk Reduction
ART: Antiretrovial therapy
ASI-Aic: Addition Severity Index-alcohol scale
ASI-drug: Addition Severity Index-drug scale
Avg: average
b/c: because
BA/BS: Bachelor of Arts/Bachelor of Science
BCT: breast-conservation therapy
BDI: Beck Depression Inventory
BMI: Body mass index
BMQ: Beliefs about Medicines Questionnaire
BP: blood pressure
BSE: Breast self-exam
BSI: Brief Symptom Inventory
CA: cancer
CAD: coronary artery disease
CAGE: Capillary Affinity Gel Electrophoresis
CARDES: Cardiovascular Dietary Education System
CASI: computer-assisted self interview
CBE: Clinical breast exam
CD: Compact disc
CD4: Cluster Difference 4
CD-ROM: Compact disc—read-only memory
CES-D: Center for Epidemiology Studies Depression Scale
CHART: Craig Handicap Assessment and Reporting Technique
CHD: coronary heart disease
CHF: congestive heart failure
CI: Confidence interval
cigs: cigarettes
COMBO: combination of 3 risk reduction presentations (RRR + ARR + NNT)
COOP/WONCA: Dartmouth Primary Care Cooperative Information Project/World Organization of National Colleges, Academies
COPD: Chronic obstructive pulmonary disease
CPAP: Continuous positive airway pressure
CRC: colorectal cancer
C-SDSCA: Chinese version of the Summary of Diabetes Self-Care Activities
CT: Computed Tomography
dB: Decibel
DBP: Diastolic blood pressure
DDS: Diabetes Distress Scale
DICCT: Deaconess Informed Consent Comprehension Test
dl: Deciliter
DM: Diabetes mellitus
DMHDS: Dunedin Multidisciplinary Health and Development Study
DNA: Deoxyribonucleic Acid
DNR: Do Not Resuscitate
DRUGS: Drug Regimen Unassisted Grading Scale
E or S: English or Spanish
ED: Emergency department
EFNEP: Expanded Food and Nutrition Education Program
FACT-G: Functional Assessment of Cancer Therapy-General
FOBT: fecal occult blood testing
FQHC: Federally Qualified Health Centers
FSC: Family Service Center
G: Group
GA: Georgia
GED: General equivalency degree
GEE: Generalized Estimating Equation
Grady: Grady Memorial Hospital, Atlanta, GA
HAART: Highly active antiretroviral therapy
HAQ/HAD: Hospital Anxiety and Depression Scale
Harbor: Harbor-UCLA Medical Center, Torrance, CA
HbA1c: Glycosylated hemoglobin
Hep C: hepatitis C
Hg: Mercury
HIV: Human immunodeficiency virus
HIV/AIDS: Human immunodeficiency virus/Acquired Immune Deficiency Syndrome
HL: health literacy
HMO: Health maintenance organization
HRQoL: health related quality of life
HS: high school
HTN: Hypertension
IADL: Instrumental activities of daily living
ICD-9: International Classification of Disease-Ninth Revision
ICD-9-CM: International Classification of Disease-Ninth Revision, Clinical Modification
IDL: Instrument for the diagnosis of reading
IDR: Instrument for the Diagnosis of Reading
IEP: Individualized Educational Plan
INR: International Normalized Ratio
IQ: Intelligence quotient
IQR: Individual Qualification Record
IRR: Incidence rate ratio
IUD: Intra-uterine device
kcal: Kilocalories
kg: Kilogram
KMS: Knowledge of Medication Subtest
KQ: key question
KSQ: Knowledge Scale Questionnaire
l: Liter
LA: Louisiana
LAE: Los Angeles English speaking (Harbor-UCLA Medical Center)
LAS: Los Angeles Spanish speaking (Harbor-UCLA Medical Center)
LDL: Low Density Lipoprotein
MCS: Mental Component Summary of SF-36
MD: medical doctor
MDI: Metered dose inhaler
med: medical
MEMS: Medical Equipment Management System
mg: Milligrams
MHMC: Mercy Hospital and Medical Center
MHP: mental health problem
MKS: Medication Knowledge Score
mL: Milliliter
mm: Millimeters
MMC: Medication management capacity
MML: Marginal Maximum Likelihood
mmol: Millimoles
MMSE: Mini-Mental State Examination
MUSP: Mater–University of Queensland Study of Pregnancy
N: Number
NA: Not applicable
NAAL: National Assessment of Adult Literacy
NALS: National Adult Literacy Survey
NART: National Adult Reading Test
NC: North Carolina
ng/mL: Nanograms per mililiter
NH: New Hampshire
NLS: Nutrition Label Survey
NNT: number needed to treat
NOS: not otherwise specified
NR: Not reported
NS: Not significant
NY: New York
OAD: oral anti-diabetic drug
OCP: Oral contraceptive pill
OLS: Ordinary Least Squares
OR: Odds ratio
P: Probability
PA: Pennsylvania
PACE: Pima County adult education program, Tucson, AZ
PACQLQ: Pediatric Asthma Caregiver's Quality of Life Questionnaire
PAG: Pictorial anticipatory guidance
PAM: Patient Activiation Measure
Pap test: Papanicolaou smear
PCKQ: Prostate Cancer Knowledge Questionnaire
PCP: primary care physician
PMAQ: Patient Medication Adherence Questionnaire
PORT: Patient Outcomes Research Team
PR: prevalence ratio
PSA: Prostate-Specific Antigen
QLS: Questionnaire Literacy Screen
r: Correlation coefficient
RA: Research assistant
RCT: Randomized controlled trial
REALM: Rapid Estimate of Adult Literacy in Medicine
RNA: Ribonucleic Acid
RR: Relative risk
RRR: Relative risk ratio
RSPM: Raven Standard Progressive Matrices
SBP: Systolic blood pressure
SD: Standard deviation
SDSCA: Summary of Diabetes Self-Care Activities Measure
SES: Socio-economic status
SF-12: Short Form 12
SF-36: Short Form 36
SF-36 PCS: Medical Outcomes Study Physical Component
SGUQ: Standard Gamble Utility Questionnaire
Sig: Significant
SIP: Sickness Impact Profile
SMOG: Readability formula
SNAP: Stanford Nutrition Action Program
SPMSQ: Short Portable Mental Status Questionnaire
SSC-HIVrev: Revised Sign and Symptom Checklist for persons with HIV Disease
STD: Sexually transmitted diseases
S-TOFHLA: Short Test of Functional Health Literacy in Adults
SWOG: Southwestern Oncology Group
TABE: Test of Adult Basic Education
TALS: Test of Applied Literacy Skills
TIPP: The Injury Prevention Program
TN: Tennessee
TOFHLA: Test of Functional Health Literacy in Adults
TOFHLS-S: Test of Functional Health Literacy in Adults in Spanish
TT: Talking Touchscreen
t-tests: Statistical hypothesis test
TX: Texas
UCLA: University of California, Los Angeles
UHS: Duke University Healthcare System
UK: United Kingdom
U-PENN: University of Pennsylvania
US: United States
VA: Veterans Affairs
VAHS: Veterans Affairs Healthcare System
VFQ-25: 25-item Visual Function Questionnaire
VRQoL: vision-related quality of life
vs.: versus
VT: Vermont
WAIS-R: Wechsler Adult Intelligence Scale–Revised
WIC: Women, Infants, and Children
wk: week
WRAT: Wide Range Achievement Test
WRAT3: Wide Range Achievement Test, 3rd edition
WRAT-R: Wide Range Achievement Test–Revised
yr(s): Year(s)

## References

1 Bailey SC, Pandit AU, Yin S, et al. Predictors of misunderstanding pediatric liquid medication instructions. Fam Med. Nov-Dec. 2009;41(10):715-21. [pmid: 19882395].
2 Baker DW, Gazmararian JA, Williams MV, et al. Health literacy and use of outpatient physician services by Medicare managed care enrollees. J Gen Intern Med. Mar. 2004;19(3):215-20. [pmid: 15009775].
3 Gazmararian JA, Kripalani S, Miller MJ, et al. Factors associated with medication refill adherence in cardiovascular-related diseases: a focus on health literacy. J Gen Intern Med. Dec. 2006;21(12):1215-21. [pmid: 17105519].
4 Wolf MS, Gazmararian JA, Baker DW. Health literacy and health risk behaviors among older adults. Am J Prev Med. Jan. 2007;32(1):19-24. [pmid: 17184964].
5 Baker DW, Wolf MS, Feinglass J, et al. Health literacy and mortality among elderly persons. Arch Intern Med. Jul. 23. 2007;167(14):1503-9. [pmid: 17646604].
6 Howard DH, Sentell T, Gazmararian JA. Impact of health literacy on socioeconomic and racial differences in health in an elderly population. J Gen Intern Med. Aug. 2006;21(8):857-61. [pmid: 16881947].
7 Wolf MS, Gazmararian JA, Baker DW. Health literacy and functional health status among older adults. Arch Intern Med. Sep. 26. 2005;165(17):1946-52. [pmid: 16186463].
8 Baker DW, Wolf MS, Feinglass J, et al. Health literacy, cognitive abilities, and mortality among elderly persons. J Gen Intern Med. Jun. 2008;23(6):723-6. [pmid: 18330654].
9 Howard DH, Gazmararian J, Parker RM. The impact of low health literacy on the medical costs of Medicare managed care enrollees. Am J Med. Apr. 2005;118(4):371-7. [pmid: 15808134].
10 Barragan M, Hicks G, Williams MV, et al. Low health literacy is associated with HIV test acceptance. J Gen Intern Med. May. 2005;20(5):422-5. [pmid: 15963165].
11 Bennett IM, Chen J, Soroui JS, et al. The contribution of health literacy to disparities in self-rated health status and preventive health behaviors in older adults. Ann Fam Med. May-Jun. 2009;7(3):204-11. [pmid: 19433837].
12 White S, Chen J, Atchison R. Relationship of preventive health practices and health literacy: a national study. Am J Health Behav. May-Jun. 2008;32(3):227-42. [pmid: 18067463].
13 Bennett IM, Culhane JF, McCollum KF, et al. Literacy and depressive symptomatology among pregnant Latinas with limited English proficiency. Am J Orthopsychiatry. Apr. 2007;77(2):243-8. [pmid: 17535122].
14 Chew LD, Bradley KA, Flum DR, et al. The impact of low health literacy on surgical practice. Am J Surg. Sep. 2004;188(3):250-3. [pmid: 15450829].
15 Cho YI, Lee SY, Arozullah AM, et al. Effects of health literacy on health status and health service utilization amongst the elderly. Soc Sci Med. Apr. 2008;66(8):1809-16. [pmid: 18295949].
16 Lee SYD, Arozullah AM, Cho YI, et al. Health literacy, social support, and health status among older adults. Educational Gerontology. 03. 2009;35(3):191-201.
17 Coffman MJ, Norton CK. Demands of immigration, health literacy, and depression in recent Latino immigrants. Home Health Care Management & Practice. 2010;22(2):116-22.
18 Davis TC, Wolf MS, Bass PF 3rd, et al. Literacy and misunderstanding prescription drug labels. Ann Intern Med. Dec. 19. 2006;145(12):887-94. [pmid: 17135578].
19 Wolf MS, Davis TC, Shrank W, et al. To err is human: patient misinterpretations of prescription drug label instructions. Patient Educ Couns. Aug. 2007;67(3):293-300. [pmid: 17587533].
20 DeWalt DA, Dilling MH, Rosenthal MS, et al. Low parental literacy is associated with worse asthma care measures in children. Ambul Pediatr. Jan-Feb. 2007;7(1):25-31. [pmid: 17261479].
21 Estrada CA, Martin-Hryniewicz M, Peek BT, et al. Literacy and numeracy skills and anticoagulation control. Am J Med Sci. Aug. 2004;328(2):88-93. [pmid: 15311167].
22 Fang MC, Machtinger EL, Wang F, et al. Health literacy and anticoagulation-related outcomes among patients taking warfarin. J Gen Intern Med. Aug. 2006;21(8):841-6. [pmid: 16881944].
23 Garbers S, Chiasson MA. Inadequate functional health literacy in Spanish as a barrier to cervical cancer screening among immigrant Latinas in New York City. Prev Chronic Dis. Oct. 2004;1(4):A07. [pmid: 15670438].
24 Gatti ME, Jacobson KL, Gazmararian JA, et al. Relationships between beliefs about medications and adherence. Am J Health Syst Pharm. Apr. 1. 2009;66(7):657-64. [pmid: 19299373].
25 Graham J, Bennett IM, Holmes WC, et al. Medication beliefs as mediators of the health literacy-antiretroviral adherence relationship in HIV-infected individuals. AIDS Behav. May. 2007;11(3):385-92. [pmid: 17053858].
26 Grubbs V, Gregorich SE, Perez-Stable EJ, et al. Health literacy and access to kidney transplantation. Clin J Am Soc Nephrol. Jan. 2009;4(1):195-200. [pmid: 19056617].
27 Guerra CE, Dominguez F, Shea JA. Literacy and knowledge, attitudes, and behavior about colorectal cancer screening. J Health Commun. Oct-Nov. 2005;10(7):651-63. [pmid: 16278201].
28 Guerra CE, Krumholz M, Shea JA. Literacy and knowledge, attitudes and behavior about mammography in Latinas. J Health Care Poor Underserved. Feb. 2005;16(1):152-66. [pmid: 15741716].
29 Hahn EA, Cella D, Dobrez DG, et al. The impact of literacy on health-related quality of life measurement and outcomes in cancer outpatients. Qual Life Res. Apr. 2007;16(3):495-507. [pmid: 17091362].
30 Hibbard JH, Peters E, Dixon A, et al. Consumer competencies and the use of comparative quality information: it isn't just about literacy. Med Care Res Rev. Aug. 2007;64(4):379-94. [pmid: 17684108].
31 Hironaka LK, Paasche-Orlow MK, Young RL, et al. Caregiver health literacy and adherence to a daily multi-vitamin with iron regimen in infants. Patient Educ Couns. Jun. 2009;75(3):376-80. [pmid: 19395227].
32 Hope CJ, Wu J, Tu W, et al. Association of medication adherence, knowledge, and skills with emergency department visits by adults 50 years or older with congestive heart failure. Am J Health Syst Pharm. Oct. 1. 2004;61(19):2043-9. [pmid: 15509127].
33 Huizinga MM, Beech BM, Cavanaugh KL, et al. Low numeracy skills are associated with higher BMI. Obesity (Silver Spring). Aug. 2008;16(8):1966-8. [pmid: 18535541].
34 Johnson VR, Jacobson KL, Gazmararian JA, et al. Does social support help limited-literacy patients with medication adherence?: A mixed methods study of patients in the pharmacy intervention for limited literacy (PILL) study. Patient Education and Counseling. 2010;79(1):14-24. [pmid: 19647967].
35 Johnston MV, Diab ME, Kim SS, et al. Health literacy, morbidity, and quality of life among individuals with spinal cord injury. J Spinal Cord Med. 2005;28(3):230-40. [pmid: 16048141].
36 Kalichman SC, Pope H, White D, et al. Association between health literacy and HIV treatment adherence: further evidence from objectively measured medication adherence. J Int Assoc Physicians AIDS Care (Chic Ill). Nov-Dec. 2008;7(6):317-23.
37 Kim SH. Health literacy and functional health status in Korean older adults. J Clin Nurs. Aug. 2009;18(16):2337-43. [pmid: 19583664].
38 Kripalani S, Henderson LE, Chiu EY, et al. Predictors of medication self-management skill in a low-literacy population. J Gen Intern Med. Aug. 2006;21(8):852-6. [pmid: 16881946].
39 Laramee AS, Morris N, Littenberg B. Relationship of literacy and heart failure in adults with diabetes. BMC Health Serv Res. 2007;7:98. [pmid: 17605784].
40 LeVine RA, LeVine SE, Rowe ML, et al. Maternal literacy and health behavior: a Nepalese case study. Soc Sci Med. Feb. 2004;58(4):863-77. [pmid: 14672599].
41 Lincoln A, Paasche-Orlow MK, Cheng DM, et al. Impact of health literacy on depressive symptoms and mental health-related: quality of life among adults with addiction. J Gen Intern Med. Aug. 2006;21(8):818-22. [pmid: 16881940].
42 Lindau ST, Basu A, Leitsch SA. Health literacy as a predictor of follow-up after an abnormal Pap smear: a prospective study. J Gen Intern Med. Aug. 2006;21(8):829-34. [pmid: 16881942].
43 Mancuso CA, Rincon M. Impact of health literacy on longitudinal asthma outcomes. J Gen Intern Med. Aug. 2006;21(8):813-7. [pmid: 16881939].
44 Mancuso CA, Rincon M. Asthma patients' assessments of health care and medical decision making: the role of health literacy. J Asthma. Jan-Feb. 2006;43(1):41-4. [pmid: 16448964].
45 Mancuso JM. Impact of health literacy and patient trust on glycemic control in an urban USA population. Nursing & Health Sciences. 2010;12(1):94-104. [pmid: 20487332].
46 Marteleto L, Lam D, Ranchhod V. Sexual behavior, pregnancy, and schooling among young people in urban South Africa. Stud Fam Plann. Dec. 2008;39(4):351-68. [pmid: 19248720].
47 Mayben JK, Kramer JR, Kallen MA, et al. Predictors of delayed HIV diagnosis in a recently diagnosed cohort. AIDS Patient Care STDS. Mar. 2007;21(3):195-204. [pmid: 17428187].
48 Miller DP Jr, Brownlee CD, McCoy TP, et al. The effect of health literacy on knowledge and receipt of colorectal cancer screening: a survey study. BMC Fam Pract. 2007;8:16. [pmid: 17394668].
49 Morris NS, MacLean CD, Littenberg B. Literacy and health outcomes: a cross-sectional study in 1002 adults with diabetes. BMC Fam Pract. 2006;7:49. [pmid: 16907968].
50 Muir KW, Santiago-Turla C, Stinnett SS, et al. Health literacy and vision-related quality of life. Br J Ophthalmol. Jun. 2008;92(6):779-82. [pmid: 18460538].
51 Murphy DA, Lam P, Naar-King S, et al. Health literacy and antiretroviral adherence among HIV-infected adolescents. Patient Education and Counseling. 2010;79(1):25-9. [pmid: 19665860].
52 Murray MD, Tu W, Wu J, et al. Factors associated with exacerbation of heart failure include treatment adherence and health literacy skills. Clin Pharmacol Ther. Jun. 2009;85(6):651-8. [pmid: 19262464].
53 Nokes KM, Coleman CL, Cashen M, et al. Health literacy and health outcomes in HIV seropositive persons. Res Nurs Health. Dec. 2007;30(6):620-7. [pmid: 18022832].
54 Osborn CY, Paasche-Orlow MK, Davis TC, et al. Health literacy: an overlooked factor in understanding HIV health disparities. Am J Prev Med. Nov. 2007;33(5):374-8. [pmid: 17950402].
55 Wolf MS, Davis TC, Osborn CY, et al. Literacy, self-efficacy, and HIV medication adherence. Patient Educ Couns. Feb. 2007;65(2):253-60. [pmid: 17118617].
56 Waite KR, Paasche-Orlow M, Rintamaki LS, et al. Literacy, social stigma, and HIV medication adherence. J Gen Intern Med. Sep. 2008;23(9):1367-72. [pmid: 18563494].
57 Osborn CY, Cavanaugh K, Wallston KA, et al. Diabetes numeracy: an overlooked factor in understanding racial disparities in glycemic control. Diabetes Care. Sep. 2009;32(9):1614-9. [pmid: 19401443].
58 Osborn CY, Davis TC, Bailey SC, et al. Health literacy in the context of HIV treatment: Introducing the Brief Estimate of Health Knowledge and Action (BEHKA)—HIV version. AIDS and Behavior. 2010;14(1):181-8. [pmid: 19023653].
59 Paasche-Orlow MK, Clarke JG, Hebert MR, et al. Educational attainment but not literacy is associated with HIV risk behavior among incarcerated women. J Womens Health (Larchmt). Nov. 2005;14(9):852-9. [pmid: 16313213].
60 Paasche-Orlow MK, Cheng DM, Palepu A, et al. Health literacy, antiretroviral adherence, and HIV-RNA suppression: a longitudinal perspective. J Gen Intern Med. Aug. 2006;21(8):835-40. [pmid: 16881943].
61 Paasche-Orlow MK, Riekert KA, Bilderback A, et al. Tailored education may reduce health literacy disparities in asthma self-management. Am J Respir Crit Care Med. Oct. 15. 2005;172(8):980-6. [pmid: 16081544].
62 Pandit AU, Tang JW, Bailey SC, et al. Education, literacy, and health: Mediating effects on hypertension knowledge and control. Patient Educ Couns. Jun. 2009;75(3):381-5. [pmid: 19442477].
63 Peterson NB, Dwyer KA, Mulvaney SA, et al. The influence of health literacy on colorectal cancer screening knowledge, beliefs and behavior. J Natl Med Assoc. Oct. 2007;99(10):1105-12. [pmid: 17987913].
64 Powell CK, Hill EG, Clancy DE. The relationship between health literacy and diabetes knowledge and readiness to take health actions. Diabetes Educ. Jan-Feb. 2007;33(1):144-51. [pmid: 17272800].
65 Powers BJ, Olsen MK, Oddone EZ, et al. Literacy and blood pressure--do healthcare systems influence this relationship? A cross-sectional study. BMC Health Serv Res. 2008;8:219. [pmid: 18947408].
66 Raehl CL, Bond CA, Woods TJ, et al. Screening tests for intended medication adherence among the elderly. Ann Pharmacother. May. 2006;40(5):888-93. [pmid: 16595567].
67 Rothman RL, Housam R, Weiss H, et al. Patient understanding of food labels: the role of literacy and numeracy. Am J Prev Med. Nov. 2006;31(5):391-8. [pmid: 17046410].
68 Schillinger D, Barton LR, Karter AJ, et al. Does literacy mediate the relationship between education and health outcomes? A study of a low-income population with diabetes. Public Health Rep. May-Jun. 2006;121(3):245-54. [pmid: 16640146].
69 Sentell TL, Halpin HA. Importance of adult literacy in understanding health disparities. J Gen Intern Med. Aug. 2006;21(8):862-6. [pmid: 16881948].
70 Sharif I, Blank AE. Relationship between child health literacy and body mass index in overweight children. Patient Education and Counseling. 2010;79(1):43-8. [pmid: 19716255].
71 Shone LP, Conn KM, Sanders L, et al. The role of parent health literacy among urban children with persistent asthma. Patient Educ Couns. Jun. 2009;75(3):368-75. [pmid: 19233588].
72 Smith JL, Haggerty J. Literacy in primary care populations: is it a problem?. Can J Public Health. Nov-Dec. 2003;94(6):408-12. [pmid: 14700237].
73 Sudore RL, Yaffe K, Satterfield S, et al. Limited literacy and mortality in the elderly: the health, aging, and body composition study. J Gen Intern Med. Aug. 2006;21(8):806-12. [pmid: 16881938].
74 Sudore RL, Mehta KM, Simonsick EM, et al. Limited literacy in older people and disparities in health and healthcare access. J Am Geriatr Soc. May. 2006;54(5):770-6. [pmid: 16696742].
75 Tang YH, Pang SM, Chan MF, et al. Health literacy, complication awareness, and diabetic control in patients with type 2 diabetes mellitus. J Adv Nurs. Apr. 2008;62(1):74-83. [pmid: 18352966].
76 Torres RY, Marks R. Relationships among health literacy, knowledge about hormone therapy, self-efficacy, and decision-making among postmenopausal health. J Health Commun. Jan-Feb. 2009;14(1):43-55. [pmid: 19180370].
77 von Wagner C, Semmler C, Good A, et al. Health literacy and self-efficacy for participating in colorectal cancer screening: The role of information processing. Patient Educ Couns. Jun. 2009;75(3):352-7. [pmid: 19386461].
78 Waldrop-Valverde D, Jones DL, Jayaweera D, et al. Gender differences in medication management capacity in HIV infection: The role of health literacy and numeracy. AIDS and Behavior. 2009;13(1):46-52. [pmid: 18618237].
79 Walker D, Adebajo A, Heslop P, et al. Patient education in rheumatoid arthritis: the effectiveness of the ARC booklet and the mind map. Rheumatology (Oxford). Oct. 2007;46(10):1593-6. [pmid: 17767002].
80 Weiss BD, Palmer R. Relationship between health care costs and very low literacy skills in a medically needy and indigent Medicaid population. J Am Board Fam Pract. Jan-Feb. 2004;17(1):44-7. [pmid: 15014052].
81 Wolf MS, Davis TC, Shrank WH, et al. A critical review of FDA-approved Medication Guides. Patient Educ Couns. Sep. 2006;62(3):316-22. [pmid: 16884888].
82 Wolf MS, Knight SJ, Lyons EA, et al. Literacy, race, and PSA level among low-income men newly diagnosed with prostate cancer. Urology. Jul. 2006;68(1):89-93. [pmid: 16844451].
83 Yin HS, Mendelsohn AL, Wolf MS, et al. Parents' medication administration errors: role of dosing instruments and health literacy. Arch Pediatr Adolesc Med. Feb. 2010;164(2):181-6. [pmid: 20124148].
84 Yin HS, Johnson M, Mendelsohn AL, et al. The health literacy of parents in the United States: a nationally representative study. Pediatrics. Nov. 3. 2009;124:S289-98. [pmid: 19861483].
85 Yin HS, Dreyer BP, Foltin G, et al. Association of low caregiver health literacy with reported use of nonstandardized dosing instruments and lack of knowledge of weight-based dosing. Ambul Pediatr. Jul-Aug. 2007;7(4):292-8. [pmid: 17660100].
86 Aggarwal A, Speckman JL, Paasche-Orlow MK, et al. The role of numeracy on cancer screening among urban women. Am J Health Behav. Sep-Oct. 1. 2007;31:S57-68. [pmid: 17931137].
87 Cavanaugh K, Huizinga MM, Wallston KA, et al. Association of numeracy and diabetes control. Ann Intern Med. May. 20. 2008;148(10):737-46. [pmid: 18490687].
88 Davids SL, Schapira MM, McAuliffe TL, et al. Predictors of pessimistic breast cancer risk perceptions in a primary care population. J Gen Intern Med. Apr. 2004;19(4):310-5. [pmid: 15061739].
89 Haggstrom DA, Schapira MM. Black-white differences in risk perceptions of breast cancer survival and screening mammography benefit. J Gen Intern Med. Apr. 2006;21(4):371-7. [pmid: 16686816].
90 Schwartz LM, Woloshin S, Black WC, et al. The role of numeracy in understanding the benefit of screening mammography. Ann Intern Med. Dec. 1. 1997;127(11):966-72. [pmid: 9412301].
91 Sheridan SL, Pignone M. Numeracy and the medical student's ability to interpret data. Eff Clin Pract. Jan-Feb. 2002;5(1):35-40. [pmid: 11874195].
92 Sheridan SL, Pignone MP, Lewis CL. A randomized comparison of patients' understanding of number needed to treat and other common risk reduction formats. J Gen Intern Med. Nov. 2003;18(11):884-92. [pmid: 14687273].
93 Vavrus F. Girls' schooling in Tanzania: the key to HIV/AIDS prevention?. AIDS Care. Nov. 2006;18(8):863-71. [pmid: 17012074].
94 Bosworth HB, Olsen MK, Gentry P, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
95 Brock TP, Smith SR. Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings. Int J Med Inform. Nov-Dec. 2007;76(11-12):829-35. [pmid: 17113345].
96 Bryant MD, Schoenberg ED, Johnson TV, et al. Multimedia version of a standard medical questionnaire improves patient understanding across all literacy levels. J Urol. Sep. 2009;182(3):1120-5. [pmid: 19625036].
97 Campbell FA, Goldman BD, Boccia ML, et al. The effect of format modifications and reading comprehension on recall of informed consent information by low-income parents: a comparison of print, video, and computer-based presentations. Patient Educ Couns. May. 2004;53(2):205-16. [pmid: 15140461].
98 Coyne CA, Xu R, Raich P, et al. Randomized, controlled trial of an easy-to-read informed consent statement for clinical trial participation: a study of the Eastern Cooperative Oncology Group. J Clin Oncol. Mar. 1. 2003;21(5):836-42. [pmid: 12610182].
99 Davis TC, Wolf MS, Bass PF, et al. Provider and patient intervention to improve weight loss: a pilot study in a public hospital clinic. Patient Educ Couns. Jul. 2008;72(1):56-62. [pmid: 18346861].
100 DeWalt DA, Malone RM, Bryant ME, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. 2006;6:30. [pmid: 16533388].
101 Ferreira MR, Dolan NC, Fitzgibbon ML, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
102 Galesic M, Garcia-Retamero R, Gigerenzer G. Using icon arrays to communicate medical risks: overcoming low numeracy. Health Psychol. Mar. 2009;28(2):210-6. [pmid: 19290713].
103 Galesic M, Gigerenzer G, Straubinger N. Natural frequencies help older adults and people with low numeracy to evaluate medical screening tests. Med Decis Making. May-Jun. 2009;29(3):368-71. [pmid: 19129155].
104 Garcia-Retamero R, Galesic M. Communicating treatment risk reduction to people with low numeracy skills: a cross-cultural comparison. Am J Public Health. Dec. 2009;99(12):2196-202. [pmid: 19833983].
105 Gerber BS, Brodsky IG, Lawless KA, et al. Implementation and evaluation of a low-literacy diabetes education computer multimedia application. Diabetes Care. Jul. 2005;28(7):1574-80. [pmid: 15983303].
106 Greene J, Peters E. Medicaid consumers and informed decisionmaking. Health Care Financ Rev. Spring. 2009;30(3):25-40. [pmid: 19544933].
107 Greene J, Peters E, Mertz CK, et al. Comprehension and choice of a consumer-directed health plan: an experimental study. Am J Manag Care. Jun. 2008;14(6):369-76. [pmid: 18554075].
108 Hwang SW, Tram CQ, Knarr N. The effect of illustrations on patient comprehension of medication instruction labels. BMC Fam Pract. Jun. 16. 2005;6(1):26. [pmid: 15960849].
109 Jay M, Adams J, Herring SJ, et al. A randomized trial of a brief multimedia intervention to improve comprehension of food labels. Preventive Medicine. 2009(1):25-31.
110 Kang EY, Fields HW, Kiyak A, et al. Informed consent recall and comprehension in orthodontics: traditional vs improved readability and processability methods. Am J Orthod Dentofacial Orthop. Oct. e1. 2009;136(4):488-13. discussion -9. [pmid: 19815144].
111 Kim S, Love F, Quistberg DA, et al. Association of health literacy with self-management behavior in patients with diabetes. Diabetes Care. Dec. 2004;27(12):2980-2. [pmid: 15562219].
112 Kripalani S, Bengtzen R, Henderson LE, et al. Clinical research in low-literacy populations: using teach-back to assess comprehension of informed consent and privacy information. IRB. Mar-Apr. 2008;30(2):13-9. [pmid: 18512655].
113 Kripalani S, Robertson R, Love-Ghaffari MH, et al. Development of an illustrated medication schedule as a low-literacy patient education tool. Patient Educ Couns. Jun. 2007;66(3):368-77. [pmid: 17344015].
114 Kripalani S, Sharma J, Justice E, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. Am J Prev Med. Aug. 2007;33(2):83-90. [pmid: 17673094].
115 Mayhorn CB, Goldsworthy RC. Refining teratogen warning symbols for diverse populations. Birth Defects Res A Clin Mol Teratol. Jun. 2007;79(6):494-506. [pmid: 17358036].
116 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
117 Peters E, Dieckmann N, Dixon A, et al. Less is more in presenting quality information to consumers. Med Care Res Rev. Apr. 2007;64(2):169-90. [pmid: 17406019].
118 Robinson LD Jr, Calmes DP, Bazargan M. The impact of literacy enhancement on asthma-related outcomes among underserved children. J Natl Med Assoc. Aug. 2008;100(8):892-6. [pmid: 18717138].
119 Rothman R, Malone R, Bryant B, et al. The relationship between literacy and glycemic control in a diabetes disease-management program. Diabetes Educ. Mar-Apr. 2004;30(2):263-73. [pmid: 15095516].
120 Rothman RL, DeWalt DA, Malone R, et al. Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program. J Am Med Assoc. Oct. 13. 2004;292(14):1711-6.
121 Rothman RL, So SA, Shin J, et al. Labor characteristics and program costs of a successful diabetes management program. Am J Manag Care. 2006;12(5):277-83. [pmid: 16686585].
122 Rudd RE, Blanch DC, Gall V, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
123 Schillinger D, Hammer H, Wang F, et al. Seeing in 3-D: examining the reach of diabetes self-management support strategies in a public health care system. Health Educ Behav. Oct. 2008;35(5):664-82. [pmid: 17513690].
124 Schillinger D, Handley M, Wang F, et al. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. Apr. 2009;32(4):559-66. [pmid: 19131469].
125 Seligman HK, Wang FF, Palacios JL, et al. Physician notification of their diabetes patients' limited health literacy. A randomized, controlled trial. J Gen Intern Med. Nov. 2005;20(11):1001-7. [pmid: 16307624].
126 Sobel RM, Paasche-Orlow MK, Waite KR, et al. Asthma 1-2-3: a low literacy multimedia tool to educate African American adults about asthma. J Community Health. Aug. 2009;34(4):321-7. [pmid: 19353250].
127 Sudore RL, Landefeld CS, Barnes DE, et al. An advance directive redesigned to meet the literacy level of most adults: a randomized trial. Patient Educ Couns. Dec. 2007;69(1-3):165-95. [pmid: 17942272].
128 Sudore RL, Schickedanz AD, Landefeld CS, et al. Engagement in multiple steps of the advance care planning process: a descriptive study of diverse older adults. J Am Geriatr Soc. Jun. 2008;56(6):1006-13. [pmid: 18410324].
129 Sudore RL, Landefeld CS, Williams BA, et al. Use of a modified informed consent process among vulnerable patients: a descriptive study. J Gen Intern Med. Aug. 2006;21(8):867-73. [pmid: 16881949].
130 Volandes AE, Paasche-Orlow MK, Barry MJ, et al. Video decision support tool for advance care planning in dementia: randomised controlled trial. Br Med J. 2009;338:b2159. [pmid: 19477893].
131 Wallace AS, Seligman HK, Davis TC, et al. Literacy-appropriate educational materials and brief counseling improve diabetes self-management. Patient Educ Couns. Jun. 2009;75(3):328-33. [pmid: 19167857].
132 Weiss BD, Francis L, Senf JH, et al. Literacy education as treatment for depression in patients with limited literacy and depression: a randomized controlled trial. J Gen Intern Med. Aug. 2006;21(8):823-8. [pmid: 16881941].
133 Wright AJ, Whitwell SC, Takeichi C, et al. The impact of numeracy on reactions to different graphic risk presentation formats: an experimental analogue study. Br J Health Psychol. Feb. 2009;14(Pt 1):107-25. [pmid: 18442447].
134 Yates K, Pena A. Comprehension of discharge information for minor head injury: a randomised controlled trial in New Zealand. N Z Med J. 2006;119(1239):U2101. [pmid: 16912719].