# Search Strings

May 2009 Search

PubMed

#1 | Search numeracy | 173
#2 | Search numeracy Limits: Humans, English | 146
#3 | Search “health literacy” | 789
#4 | Search “health literacy” Limits: Entrez Date from 2003, Humans, English | 586
#5 | Search #2 OR #4 | 716
#6 | Search literacy | 39075
#7 | Search “rapid estimate of adult literacy” OR real* | 215538
#8 | Search #6 AND #7 | 920
#9 | Search “test of functional health literacy” OR tofhl* | 295
#10 | Search #6 AND #9 | 295
#11 | Search “Hebrew health literacy test” OR HHLT | 6
#12 | Search “medical achievement reading test” OR MART | 1202
#13 | Search #6 AND #12 | 23
#14 | Search “newest vital signs” OR NVS | 203
#15 | Search #6 AND #14 | 6
#16 | Search “short assessment of health literacy” OR SAHLSA | 170
#17 | Search #6 AND #16 | 170
#18 | Search “wide range achievement test” OR WRAT | 290
#19 | Search #6 AND #18 | 77
#20 | Search “nutritional literacy” OR “literacy assessment for diabetes” OR LAD OR SIL OR “single item numeracy screener” OR DAHL OR “demographic assessment” OR BEHKA OR “brief estimate” OR “diabetes numeracy” OR “medical data interpretation” OR “subjective numeracy” OR “numeracy test” | 18220
#21 | Search #6 AND #20 | 264
#22 | Search #8 OR #10 OR #11 OR #13 OR #15 OR #17 OR #19 OR #21 | 1661
#23 | Search #8 OR #10 OR #11 OR #13 OR #15 OR #17 OR #19 OR #21 Limits: Entrez Date from 2003, Humans, English | 729
#24 | Search #5 OR #23 | 1310
#25 | Search #5 OR #23 Limits: Editorial, Letter, Case Reports | 58
#26 | Search #24 NOT #25 | 1252

PubMed

#1 | Search “rapid estimate of adult literacy” | 104
#2 | Search “test of functional health literacy” | 290
#3 | Search “Hebrew health literacy test” | 6
#4 | Search “medical achievement reading test | 0
#5 | Search medical achievements reading test | 68
#6 | Search “newest vital signs” | 1
#7 | Search “short assessment of health literacy” | 170
#8 | Search “wide range achievement test” | 219
#9 | Search “literacy assessment for diabetes” | 225
#10 | Search “nutritional literacy” | 3
#11 | Search “single item numeracy screener” | 0
#12 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 | 991
#13 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 Limits: Entrez Date from 2003, Humans, English | 473
#14 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 Limits: Entrez Date from 2003, Humans, Editorial, Letter, Case Reports, English | 5
#15 | Search #13 NOT #14 | 468

PubMed

#1 | Search literacy [tw] | 5516
#2 | Search literacy [tw] Limits: Entrez Date from 2003, Humans, English | 2337
#3 | Search literacy [tw] Limits: Editorial, Letter, Case Reports | 243
#4 | Search #2 NOT #3 | 2226

Term used in other databases:

“health literacy”

CINAHL = 34 = 22 NEW

Cochrane = 61 = 34 NEW

PsycINFO = 65 = 26

ERIC = 34 = 31

Total Unduplicated Database = 2855

December 2009 Search

PubMed

Search | Queries | Result
#1 | Search numeracy | 213
#2 | Search numeracy Limits: Humans, English | 169
#3 | Search “health literacy” | 964
#4 | Search (“2009/01/01”[Entrez Date] : “3000”[Entrez Date]) AND (“health literacy”) Limits: Humans, English | 110
#5 | Search #2 OR #4 Limits: Humans, English | 273
#6 | Search literacy | 41096
#7 | Search “rapid estimate of adult literacy” OR real* | 232562
#8 | Search #6 AND #7 | 968
#9 | Search “test of functional health literacy” OR tofhl* | 326
#10 | Search #6 AND #9 | 326
#11 | Search “Hebrew health literacy test” OR HHLT | 7
#12 | Search “medical achievement reading test” OR MART | 1300
#13 | Search #6 AND #12 | 26
#14 | Search “newest vital signs” OR NVS | 220
#15 | Search #6 AND #14 | 8
#16 | Search “short assessment of health literacy” OR SAHLSA | 187
#17 | Search #6 AND #16 | 187
#18 | Search “wide range achievement test” OR WRAT | 302
#19 | Search #6 AND #18 | 83
#20 | Search “nutritional literacy” OR “literacy assessment for diabetes” OR LAD OR SIL OR “single item numeracy screener” OR DAHL OR “demographic assessment” OR BEHKA OR “brief estimate” OR “diabetes numeracy” OR “medical data interpretation” OR “subjective numeracy” OR “numeracy test” | 18849
#21 | Search #6 AND #20 | 282
#22 | Search #8 OR #10 OR #11 OR #13 OR #15 OR #17 OR #19 OR #21 | 1773
#23 | Search (“2009/01/01”[Entrez Date] : “3000”[Entrez Date]) AND (#8 OR #10 OR #11 OR #13 OR #15 OR #17 OR #19 OR #21) Limits: Humans, English | 86
#24 | Search #5 OR #23 | 342
#25 | Search #5 OR #23 Limits: Editorial, Letter, Case Reports | 24
#26 | Search #24 NOT #25 | 318

CINAHL

“health literacy” limited to English language and non-Medline = 37 :

“health literacy” Limiters - Published Date from: 20090101-20101231; Exclude MEDLINE records; Language: English

Search modes - Boolean/Phrase

(37)

Cochrane Library

“health literacy” 2009-present= 1 review; 4 clinical trials = 5 total.

PsycINFO

“health literacy”, 2009-present, English language, no editorials, no letters = 74

“health literacy” Limiters - Published Date from: 20090101-20101231; Language: English

Search modes - Boolean/Phrase

(74)

ERIC

Main Search:

“health literacy”, 2009-present, English language = 9

May 2010 Search

PubMed

Search | Most Recent Queries | Result
#1 | Search numeracy | 243
#2 | Search “health literacy” | 1084
#3 | Search #1 OR #2 | 1285
#4 | Search literacy | 42702
#5 | Search “rapid estimate of adult literacy” OR real* | 245476
#6 | Search #4 AND #5 | 1000
#7 | Search “test of functional health literacy” OR tofhl* | 154
#8 | Search #4 AND #7 | 154
#9 | Search “Hebrew health literacy test” OR HHLT | 1
#10 | Search #4 AND #9 | 1
#11 | Search “medical achievement reading test” OR MART | 1358
#12 | Search #4 AND #11 | 28
#13 | Search “newest vital signs” OR NVS | 261
#14 | Search #4 AND #13 | 11
#15 | Search “short assessment of health literacy” OR SAHLSA | 49
#16 | Search #4 AND #15 | 49
#17 | Search “wide range achievement test” OR WRAT | 303
#18 | Search #4 AND #17 | 84
#19 | Search “nutritional literacy” OR “literacy assessment for diabetes” OR LAD OR SIL OR “single item numeracy screener” OR DAHL OR “demographic assessment” OR BEHKA OR “brief estimate” OR “diabetes numeracy” OR “medical data interpretation” OR “subjective numeracy” OR “numeracy test” | 19266
#20 | Search #4 AND #19 | 303
#21 | Search #6 OR #8 OR #10 OR #12 OR #14 OR #16 OR #18 OR #20 | 1522
#22 | Search #3 OR #21 | 2561
#23 | Search #22 Limits: Humans, English | 2042
#24 | Search #23 Limits: Editorial, Letter, Case Reports | 93
#25 | Search #23 NOT #24 | 1949
#26 | Search (#25) AND “2009/10/01”[Entrez Date] : “3000”[Entrez Date] Sort by: PublicationDate | 106

Analogous terms were used to conduct searches in the following databases:

CINAHL

39 initially imported

38 after duplicates removed

PsycINFO

68 initially imported

53 after duplicates removed

Cochrane Library

44 initially imported

41 after duplicates removed

ERIC

8 initially imported

6 after duplicates removed

Total records = 24