# Author Queries

Queries to Authors for Additional Information

Author | Research Objective | Questions for Authors
Bosworth et al., 2005^1^ | To determine if a nurse administered patient-tailored intervention can improve blood pressure control | What strategies did you employ in your intervention specifically to address the problem of low health literacy?
Brock & Smith, 2007^2^ | To evaluate the effects of using an audiovisual animation displayed on a PDA for patient education in a clinical setting | What behavioral theory did you use in the design of your intervention?
Bryant et al., 2009^3^ | To determine whether a novel multimedia computer version of the AUA-SS would be better understood by patients than the original form, and to see whether improvement in understanding varied by literacy level | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention? What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention? Did you tailor your intervention to address individual patient characteristics? If so, how?
Campbell et al., 2004^4^ | To compare comprehension of consent information (for a hypothetical research study) as a function of the medium of presentation, mostly among a low-literacy population | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
DeWalt et al., 2006^5^ | To compare the efficacy of a heart failure self-management program designed for patients with low literacy versus usual care | What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention?
Ferreira et al., 2005^6^ | To test whether health-care provider directed intervention increased colorectal cancer screening rates | What strategies did you employ in your intervention specifically to address the problem of low health literacy? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Galesic et al., 2009^7^ | Experiment 1: To investigate whether icon arrays increase accuracy of understanding medical risks (either ARR or RRR) Experiment 2: To investigate whether icon arrays and alternate denominators affect perceived seriousness of risks and helpfulness of treatments; this experiment is not of interest to SER | What was the total contact time with participants during the delivery of your intervention?
Galesic et al., 2009^8^ | To examine whether natural frequencies can improve posterior probability judgments of older adults and of people with lower numeracy skills | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention? What was the total contact time with participants during the delivery of your intervention?
Garcia-Retamero and Galesic, 2009^9^ | 1. To determine whether participants show denominator neglect in their estimates of risk reduction and whether those with low numeracy show more denominator neglect than those with high numeracy; 2. To evaluate whether icon array presentation helps reduce misunderstanding of risk reduction information due to denominator neglect; 3. To determine whether US participants show more denominator neglect than German participants | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Gerber et al., 2005^10^ | To evaluate a multimedia intervention for diabetes education targeting low literacy individuals from a diverse population | How many intervention sessions did you provide for study participants? What was the total contact time with participants during the delivery of your intervention?
Greene and Peters, 2009^11^ | To test whether simplifying official Medicaid comparison chart improved comprehension and to examine how important literacy and numeracy skills were for comprehension | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention? What was the total contact time with participants during the delivery of your intervention?
Greene et al., 2008^12^ | 1. To test whether comprehension could be improved by varying the way information was presented; 2. To examine the effect of numeracy on comprehension of CDHP design and informed decision making (i.e. is numeracy of moderator) | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Jay et al., 2009^13^ | To determine whether a multimedia intervention can improve food label comprehension in a sample of low-income patients | What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Kang et al, 2009^14^ | 1. To investigate the recall and comprehension of orthodontic informed consent among patients and their parents with the traditional AAO informed consent form and other methods with improved readability and processability; 2. To investigate the association between reading ability, anxiety, and sociodemographic variables, and recall and comprehension; 3. To determine how different domains of information are affected by varying degrees of readability and processability | What was the total contact time with participants during the delivery of your intervention?
Kim et al., 2004^15^ | To examine the association between health literacy and self management behaviors in patients with diabetes and to determine whether diabetes education improves self-management behaviors in patients with limited compared with adequate health literacy | What was the total contact time with participants during the delivery of your intervention? What strategies did you employ in your intervention specifically to address the problem of low health literacy? Did you tailor your intervention to address individual patient characteristics? If so, how? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Kripalani et al., 2007^16^ | To design and evaluate an illustrated medication schedule (pill card) that depicts a patient's daily medication regimen using pill images and icons | How many intervention sessions did you provide for study participants? What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention?
Kripalani et al., 2007^17^ | To determine the effects of two low-literacy educational handouts on the frequency of subsequent prostate cancer discussion and screening | How many intervention sessions did you provide for study participants? What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention?
Kripalani et al., 2008^18^ | To determine whether simplified written documents, a short verbal description of the study, and a visual aid to describe the randomization process improved participant comprehension of informed consent and HIPAA Privacy Rule requirements regarding authorization for use and disclosure of protected health information | What was the total contact time with participants during the delivery of your intervention?
Murray et al., 2007^19^ | To determine whether a pharmacist intervention improves medication adherence and health outcomes compared with usual care for low-income patients with heart failure | How many intervention sessions did you provide for study participants? What was the total contact time with participants during the delivery of your intervention?
Peters et al., 2007^20^ | Examine whether simpler presentations of quantitative information have a larger influence on (on comprehension) among consumers with low numeracy compared to those higher in numeracy | What was the total contact time with participants during the delivery of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Robinson et al., 2008^21^ | To determine the effects of literacy classes given to asthmatic pediatric patients in an urban area on reading level, asthma treatment self-efficacy, ED visits and hospitalizations | What strategies did you employ in your intervention specifically to address the problem of low health literacy? What behavioral theory did you use in the design of your intervention?
Rothman et al., 2004^22^ | To examine the role of literacy in glycemic control in a cohort of patients with type 2 diabetes | How many intervention sessions did you provide for study participants? What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Rothman et al., 2004^23^ | To examine the role of literacy on the effectiveness of a comprehensive disease management program for patients with diabetes | What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Rudd et al., 2009^24^ | To test the efficacy of educational interventions to reduce literacy barriers and enhance health outcomes among patients with inflammatory arthritis | How many intervention sessions did you provide for study participants? What was the total contact time with participants during the delivery of your intervention? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Schillinger et al., 2009^25^ Schillinger et al., 2008^26^ | Examined the effects of 2 self-management support (SMS) strategies (automated telephone self-management support (ATSM) and group medical visits (GMV)) across outcomes corresponding to the Chronic Care Model | What strategies did you employ in your intervention specifically to address the problem of low health literacy? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Seligman et al., 2005^27^ | To determine if notifying physicians of their patients' limited health literacy affects physician behavior, physician satisfaction, or patient self-efficacy | What behavioral theory did you use in the design of your intervention?
Sobel et al., 2009^28^ | To determine whether a low-literacy multimedia tool can improve asthma knowledge in African-American adults | What behavioral theory did you use in the design of your intervention?
Volandes et al., 2009^29^ | To evaluate the effect of a video decision support tool on preferences for future medical care in older people if they develop advanced dementia, and stability of preferences after 6 weeks | What behavioral theory did you use in the design of your intervention? Did you tailor your intervention to address individual patient characteristics? If so, how?
Walker et al., 2007^30^ | Intervention: To determine the effectiveness of a pictorial ‘mind map’ together with the Arthritis Research Campaign (ARC) booklet for imparting knowledge to participants with rheumatoid arthritis, and to relate this to participant reading ability Health outcome: To investigate the relationship between anxiety/depression and HL | What was the total contact time with participants during the delivery of your intervention? Who delivered your intervention?
Wallace et al., 2009^31^ | To evaluate the impact of providing patients with a literacy-appropriate diabetes education guide accompanied by brief counseling designed for use in primary care | What was the total contact time with participants during the delivery of your intervention?
Weiss et al., 2006^32^ | To determine whether literacy education, provided along with standard depression treatment to adults with depression and limited literacy, would result in greater improvement in depression than would standard depression treatment alone | How many intervention sessions did you provide for study participants? What behavioral theory did you use in the design of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Wright et al., 2009^33^ | To determine whether low numeracy participants would better understand risks presented using grouped dot or dispersed dot displays | What was the total contact time with participants during the delivery of your intervention? Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?
Yates & Pena, 2006^34^ | To assess differences in comprehension between standard and simplified head injury advice sheets | Did you perform any pre-testing (either cognitive and usability testing or pilot testing) of your intervention?

## References

1 Bosworth HB, Olsen MK, Gentry P, Orr M, Dudley T, McCant F, et al. Nurse administered telephone intervention for blood pressure control: a patient-tailored multifactorial intervention. Patient Educ Couns. Apr. 2005;57(1):5-14. [pmid: 15797147].
2 Brock TP, Smith SR. Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings. Int J Med Inform. Nov-Dec. 2007;76(11-12):829-35. [pmid: 17113345].
3 Bryant MD, Schoenberg ED, Johnson TV, Goodman M, Owen-Smith A, Master VA. Multimedia version of a standard medical questionnaire improves patient understanding across all literacy levels. J Urol. Sep. 2009;182(3):1120-5. [pmid: 19625036].
4 Campbell FA, Goldman BD, Boccia ML, Skinner M. The effect of format modifications and reading comprehension on recall of informed consent information by low-income parents: a comparison of print, video, and computer-based presentations. Patient Educ Couns. May. 2004;53(2):205-16. [pmid: 15140461].
5 DeWalt DA, Malone RM, Bryant ME, Kosnar MC, Corr KE, Rothman RL, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. 2006;6:30. [pmid: 16533388].
6 Ferreira MR, Dolan NC, Fitzgibbon ML, Davis TC, Gorby N, Ladewski L, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar. 1. 2005;23(7):1548-54. [pmid: 15735130].
7 Galesic M, Garcia-Retamero R, Gigerenzer G. Using icon arrays to communicate medical risks: overcoming low numeracy. Health Psychol. Mar. 2009;28(2):210-6. [pmid: 19290713].
8 Galesic M, Gigerenzer G, Straubinger N. Natural frequencies help older adults and people with low numeracy to evaluate medical screening tests. Med Decis Making. May-Jun. 2009;29(3):368-71. [pmid: 19129155].
9 Garcia-Retamero R, Galesic M. Communicating treatment risk reduction to people with low numeracy skills: a cross-cultural comparison. Am J Public Health. Dec. 2009;99(12):2196-202. [pmid: 19833983].
10 Gerber BS, Brodsky IG, Lawless KA, Smolin LI, Arozullah AM, Smith EV, et al. Implementation and evaluation of a low-literacy diabetes education computer multimedia application. Diabetes Care. Jul. 2005;28(7):1574-80. [pmid: 15983303].
11 Greene J, Peters E. Medicaid consumers and informed decisionmaking. Health Care Financ Rev. Spring. 2009;30(3):25-40. [pmid: 19544933].
12 Greene J, Peters E, Mertz CK, Hibbard JH. Comprehension and choice of a consumer-directed health plan: an experimental study. Am J Manag Care. Jun. 2008;14(6):369-76. [pmid: 18554075].
13 Jay M, Adams J, Herring SJ, Gillespie C, Ark T, Feldman H, et al. A randomized trial of a brief multimedia intervention to improve comprehension of food labels. Preventive medicine. 2009:25-31.
14 Kang EY, Fields HW, Kiyak A, Beck FM, Firestone AR. Informed consent recall and comprehension in orthodontics: traditional vs improved readability and processability methods. Am J Orthod Dentofacial Orthop. Oct. 2009;136(4):e1-13. discussion -9. [pmid: 19815144].
15 Kim S, Love F, Quistberg DA, Shea JA. Association of health literacy with self-management behavior in patients with diabetes. Diabetes Care. Dec. 2004;27(12):2980-2. [pmid: 15562219].
16 Kripalani S, Robertson R, Love-Ghaffari MH, Henderson LE, Praska J, Strawder A, et al. Development of an illustrated medication schedule as a low-literacy patient education tool. Patient Educ Couns. Jun. 2007;66(3):368-77. [pmid: 17344015].
17 Kripalani S, Sharma J, Justice E, Justice J, Spiker C, Laufman LE, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. Am J Prev Med. Aug. 2007;33(2):83-90. [pmid: 17673094].
18 Kripalani S, Bengtzen R, Henderson LE, Jacobson TA. Clinical research in low-literacy populations: using teach-back to assess comprehension of informed consent and privacy information. Irb. Mar-Apr. 2008;30(2):13-9. [pmid: 18512655].
19 Murray MD, Young J, Hoke S, Tu W, Weiner M, Morrow D, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. [pmid: 17502632].
20 Peters E, Dieckmann N, Dixon A, Hibbard JH, Mertz CK. Less is more in presenting quality information to consumers. Med Care Res Rev. Apr. 2007;64(2):169-90. [pmid: 17406019].
21 Robinson LD Jr, Calmes DP, Bazargan M. The impact of literacy enhancement on asthma-related outcomes among underserved children. J Natl Med Assoc. Aug. 2008;100(8):892-6. [pmid: 18717138].
22 Rothman R, Malone R, Bryant B, Horlen C, DeWalt D, Pignone M. The relationship between literacy and glycemic control in a diabetes disease-management program. Diabetes Educ. Mar-Apr. 2004;30(2):263-73. [pmid: 15095516].
23 Rothman RL, DeWalt DA, Malone R, Bryant B, Shintani A, Crigler B, et al. Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program. Jama. Oct. 13. 2004;292(14):1711-6. [pmid: 15479936].
24 Rudd RE, Blanch DC, Gall V, Chibnik LB, Wright EA, Reichmann W, et al. A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management. Patient Educ Couns. Jun. 2009;75(3):334-9. [pmid: 19345053].
25 Schillinger D, Handley M, Wang F, Hammer H. Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care. Apr. 2009;32(4):559-66. [pmid: 19131469].
26 Schillinger D, Hammer H, Wang F, Palacios J, McLean I, Tang A, et al. Seeing in 3-D: examining the reach of diabetes self-management support strategies in a public health care system. Health Educ Behav. Oct. 2008;35(5):664-82. [pmid: 17513690].
27 Seligman HK, Wang FF, Palacios JL, Wilson CC, Daher C, Piette JD, et al. Physician notification of their diabetes patients' limited health literacy. A randomized, controlled trial. J Gen Intern Med. Nov. 2005;20(11):1001-7. [pmid: 16307624].
28 Sobel RM, Paasche-Orlow MK, Waite KR, Rittner SS, Wilson EA, Wolf MS. Asthma 1-2-3: a low literacy multimedia tool to educate African American adults about asthma. J Community Health. Aug. 2009;34(4):321-7. [pmid: 19353250].
29 Volandes AE, Paasche-Orlow MK, Barry MJ, Gillick MR, Minaker KL, Chang Y, et al. Video decision support tool for advance care planning in dementia: randomised controlled trial. Bmj. 2009;338:b2159. [pmid: 19477893].
30 Walker D, Adebajo A, Heslop P, Hill J, Firth J, Bishop P, et al. Patient education in rheumatoid arthritis: the effectiveness of the ARC booklet and the mind map. Rheumatology (Oxford). Oct. 2007;46(10):1593-6. [pmid: 17767002].
31 Wallace AS, Seligman HK, Davis TC, Schillinger D, Arnold CL, Bryant-Shilliday B, et al. Literacy-appropriate educational materials and brief counseling improve diabetes self-management. Patient Educ Couns. Jun. 2009;75(3):328-33. [pmid: 19167857].
32 Weiss BD, Francis L, Senf JH, Heist K, Hargraves R. Literacy education as treatment for depression in patients with limited literacy and depression: a randomized controlled trial. J Gen Intern Med. Aug. 2006;21(8):823-8. [pmid: 16881941].
33 Wright AJ, Whitwell SC, Takeichi C, Hankins M, Marteau TM. The impact of numeracy on reactions to different graphic risk presentation formats: An experimental analogue study. Br J Health Psychol. Feb. 2009;14(Pt 1):107-25. [pmid: 18442447].
34 Yates K, Pena A. Comprehension of discharge information for minor head injury: a randomised controlled trial in New Zealand. N Z Med J. 2006;119(1239):U2101. [pmid: 16912719].