# Appendixes

Appendix A Author Queries

Appendix B Search Strings

Appendix C Inclusion/Exclusion Criteria and Study Internal Validity Quality Form

Appendix D Evidence Tables

Appendix E Characteristics of Studies with Poor Internal Validity

Appendix F Strength of Evidence

Appendix G Peer Reviewers

Appendix H Excluded Studies

Appendix I Articles by Database Search

Appendix J Summary of KQ 1 Findings from Literacy and Health Outcomes Report