# Acknowledgments

This study was supported by Contract 290-2007-10056-I from the Agency for Healthcare Research and Quality (AHRQ), Task No. 5. We acknowledge the continuing support of Stephanie Chang, M.D., M.P.H., Director of the AHRQ Evidence-based Practice Center (EPC) Program, and Marian D. James, Ph.D., M.A., the AHRQ Task Order Officer for this project.

We extend our appreciation to our Technical Expert Panel (TEP). All provided thoughtful advice and input during our research process. The TEP was both a substantive resource and a “sounding board” throughout the study. It was also the body from which expertise was formally sought at several junctions. The investigators would like to particularly thank Cindy Brach for her assistance in querying intervention study researchers. TEP members are listed below:

Michael Paasche-Orlow, M.D., M.A.

M.P.H.

Internal Medicine, Boston University School of Medicine

Boston, MA

Cindy Brach, M.P.P.

Agency for Healthcare Research and Quality

Rockville, MD

Darren DeWalt, M.D.

Internal Medicine, University of North Carolina

Chapel Hill, NC

Sue Stableford, M.P.H., M.S.B.

Health Literacy Institute, University of New England

Portland, ME

Marilyn Shapira, M.D., M.P.H.

Medical College of Wisconsin

Milwaukee, WI

David Baker, M.D.

Internal Medicine, Northwestern University

Chicago, IL

Rima Rudd, Sc.D.

Harvard School of Public Health

Boston, MA

Joanne Schwartzberg, M.D.

American Medical Association

Chicago, IL

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to Megan Van Noord, M.S.I.S., Christiane Voisin, M.S.L.S., and Lynn Whitener, M.S.L.S., Dr.P.H. our EPC Librarians; Loraine Monroe, our EPC publications specialist; Jennifer Drolet, M.A., our editor; and Linda Lux, M.P.A., the RTI-UNC Administrator. We would also like to thank Shrikant Bangdiwala, Ph.D. for his helpful consultation on questions related to statistical methodology included in the literature. Finally, we would like to thank Michael Pignone and Darren Dewalt, who were our collaborators on the original review we performed in 2004; our discussions and work with them provided a critical foundation for the current review.