# References

1 Laine MK, Tahtinen PA, Ruuskanen O, Huovinen P, Ruohola A. Symptoms or symptom-based scores cannot predict acute otitis media at otitis-prone age. Pediatrics. 05. 2010;125(5):e1154-61. [pmid: 20368317].
2 Little P, Gould C, Williamson I, Moore M, Warner G, Dunleavey J. Pragmatic randomised controlled trial of two prescribing strategies for childhood acute otitis media. BMJ. 02. 10. 2001;322(7282):336-42. [pmid: 11159657].
3 McCormick DP, Chonmaitree T, Pittman C, Saeed K, Friedman NR, Uchida T, et al. Nonsevere acute otitis media: a clinical trial comparing outcomes of watchful waiting versus immediate antibiotic treatment. Pediatrics. 06. 2005;115(6):1455-65. [pmid: 15930204].
4 Scholz H, Noack R. Multicenter, randomized, double-blind comparison of erythromycin estolate versus amoxicillin for the treatment of acute otitis media in children. AOM Study Group. Eur J Clin Microbiol Infect Dis. 07. 1998;17(7):470-8. [pmid: 9764549].
5 Subba Rao SD, Macias MP, Dillman CA, Ramos BD, Kierszenbaum JS, Soliman AE. A randomized, observer-blind trial of amoxycillin/clavulanate versus cefaclor in the treatment of children with acute otitis media. Augmentin 415 Study Group. J Chemother. 12. 1998;10(6):460-8. [pmid: 9876054].
6 Damrikarnlert L, Jauregui AC, Kzadri M. Efficacy and safety of amoxycillin/clavulanate (Augmentin) twice daily versus three times daily in the treatment of acute otitis media in children. The Augmentin 454 Study Group. J Chemother. 02. 2000;12(1):79-87. [pmid: 10768519].
7 Dagan R, Johnson CE, McLinn S, Abughali N, Feris J, Leibovitz E, et al. Bacteriologic and clinical efficacy of amoxicillin/clavulanate vs. azithromycin in acute otitis media. Pediatr Infect Dis J. 02. 2000;19(2):95-104. [pmid: 10693993].
8 Casey JR, Adlowitz DG, Pichichero ME. New patterns in the otopathogens causing acute otitis media six to eight years after introduction of pneumococcal conjugate vaccine. Pediatr Infect Dis J. 04. 2010;29(4):304-9. [pmid: 19935445].
9 Daly KA, Brown JE, Lindgren BR, Meland MH, Le CT, Giebink GS. Epidemiology of otitis media onset by six months of age. Pediatrics. 06. 1999;103(6 Pt 1):1158-66. [pmid: 10353923].
10 McCaig LF, Besser RE, Hughes JM. Trends in antimicrobial prescribing rates for children and adolescents. JAMA. 06. 19. 2002;287(23):3096-102. [pmid: 12069672].
11 Teele DW, Klein JO, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston: a prospective, cohortstudy. J Infect Dis. 07. 1989;160(1):83-94. [pmid: 2732519].
12 Bharmal M, Kamble S. Incremental scost of otitis media among children in the United States. Qunitles, Inc, Falls Church, CA, USA. University of North Carolina. Charlotte, NC, USA. 2009:PIH20.
13 Marcy M, Takata G, Chan LS, Shekelle P, Mason W, Wachsman L, et al. Management of Acute Otitis Media, Evidence Report/Technology Assessment No 15. Rockville, MD. Agency for Healthcare Research and Quality. 2001. Report No.: AHRQ Publication No. 01-E010 Contract No.: Document Number|.
14 Rosenfeld RM. Diagnostic certainty for acute otitis media. Int J Pediatr Otorhinolaryngol. 06. 17. 2002;64(2):89-95. [pmid: 12049821].
15 Rothman R, Owens T, Simel DL. Does this child have acute otitis media?. JAMA. 09. 24. 2003;290(12):1633-40. [pmid: 14506123].
16 Diagnosis and management of acute otitis media. Pediatrics. 05. 2004;113(5):1451-65. [pmid: 15121972].
17 Paradise JL. Otitis media in infants and children. Pediatrics. 05. 1980;65(5):917-43. [pmid: 6102754].
18 Segal N, Leibovitz E, Dagan R, Leiberman A. Acute otitis media-diagnosis and treatment in the era of antibiotic resistant organisms: updated clinical practice guidelines. Int J Pediatr Otorhinolaryngol. 10. 2005;69(10):1311-9. [pmid: 15955573].
19 Froom J, Culpepper L, Grob P, Bartelds A, Bowers P, Bridges-Webb C, et al. Diagnosis and antibiotic treatment of acute otitis media: report from International Primary Care Network. BMJ. 03. 3. 1990;300(6724):582-6. [pmid: 2108756].
20 Coco AS, Horst MA, Gambler AS. Trends in broad-spectrum antibiotic prescribing for children with acute otitis media in the United States, 1998–2004. BMC Pediatr. 2009;9:41. [pmid: 19552819].
21 Dowell SF, Butler JC, Giebink GS, Jacobs MR, Jernigan D, Musher DM, et al. Acute otitis media: management and surveillance in an era of pneumococcal resistance--a report from the Drug-resistant Streptococcus pneumoniae Therapeutic Working Group. Pediatr Infect Dis J. 01. 1999;18(1):1-9. [pmid: 9951971].
22 Arrieta A, Singh J. Management of recurrent and persistent acute otitis media: new options with familiar antibiotics. Pediatr Infect Dis J. 02. 2004;23(2 Suppl):S115-24. [pmid: 14770074].
23 Pichichero ME. Recurrent and persistent otitis media. Pediatr Infect Dis J. 09. 2000;19(9):911-6. [pmid: 11001126].
24 Jacobs MR. Antibiotic-resistant Streptococcus pneumoniae in acute otitis media: overview and update. Pediatr Infect Dis J. 10. 1998;17(10):947-52. [pmid: 9802651].
25 Preventing pneumococcal disease among infants and young children. Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR Recomm Rep. 10. 6. 2000;49(RR-9):1-35.
26 Paradise JL, Bluestone CD, Colborn DK, Bernard BS, Smith CG, Rockette HE, et al. Adenoidectomy and adenotonsillectomy for recurrent acute otitis media: parallel randomized clinical trials in children not previously treated with tympanostomy tubes. Jama. 09. 8. 1999;282(10):945-53. [pmid: 10485679].
27 Hendley JO. Clinical practice. Otitis media. N Engl J Med. 10. 10. 2002;347(15):1169-74. [pmid: 12374878].
28 Pichichero ME, Arguedas A, Dagan R, Sher L, Saez-Llorens X, Hamed K, et al. Safety and efficacy of gatifloxacin therapy for children with recurrent acute otitis media (AOM) and/or AOM treatment failure. Clin Infect Dis. 08. 15. 2005;41(4):470-8. [pmid: 16028153].
29 Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 02. 1996;17(1):1-12. [pmid: 8721797].
30 Sackett DL, Tugwell P, Guyatt GH. Clinical epidemiology: a basic science for clinical medicine. 1991.
31 Trout KS. How to read clinical journals: IV. To determine etiology or causation. Can Med Assoc J. 1981;124:985-90. [pmid: 7260801].
32 Tugwell P. How to read clinical journals: III. To determine etiology or causation. Can Med Assoc J. 1981;124:869-72. [pmid: 7214286].
33 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 11. 10. 2003;3:25. [pmid: 14606960].
34 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 09. 1986;7(3):177-88. [pmid: 3802833].
35 Laird NM, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6(1):5-30. [pmid: 2361819].
36 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 09. 6. 2003;327(7414):557-60. [pmid: 12958120].
37 StataCorp Stata Statistical Software: Release 10. College Station, TX. 2007.
38 Cohen J. Statistical Power Analysis for the Behavioral Sciences. Academic Press, Inc. 1977:179-213.
39 Saeed K, Coglianese CL, McCormick DP, Chonmaitree T. Otoscopic and tympanometric findings in acute otitis media yielding dry tap at tympanocentesis. Pediatr Infect Dis J. 11. 2004;23(11):1030-4. [pmid: 15545858].
40 Legros JM, Hitoto H, Garnier F, Dagorne C, Parot-Schinkel E, Fanello S. Clinical qualitative evaluation of the diagnosis of acute otitis media in general practice. Int J Pediatr Otorhinolaryngol. 01. 2008;72(1):23-30. [pmid: 17976829].
41 Niemela M, Uhari M, Jounio-Ervasti K, Luotonen J, Alho OP, Vierimaa E. Lack of specific symptomatology in children with acute otitis media. Pediatr Infect Dis J. 09. 1994;13(9):765-8. [pmid: 7808842].
42 Heikkinen T, Ruuskanen O. Signs and symptoms predicting acute otitis media. Arch Pediatr Adolesc Med. 01. 1995;149(1):26-9. [pmid: 7827655].
43 Ingvarsson L. Acute otalgia in children — findings and diagnosis. Acta Paediatr Scand. 09. 1982;71(5):705-10. [pmid: 6891167].
44 Kontiokari T, Koivunen P, Niemela M, Pokka T, Uhari M. Symptoms of acute otitis media. Pediatr Infect Dis J. 08. 1998;17(8):676-9. [pmid: 9726339].
45 Legros JM, Hitoto H, Garnier F, Dagorne C, Dubin J, Fanello S. Reliability of the diagnosis of acute otitis media by general practitioners. Arch Pediatr. 05. 2007;14(5):427-33. [pmid: 17289358].
46 Block SL, Hedrick J, Harrison CJ, Tyler R, Smith A, Findlay R, et al. Community-wide vaccination with the heptavalent pneumococcal conjugate significantly alters the microbiology of acute otitis media. Pediatr Infect Dis J. 09. 2004;23(9):829-33. [pmid: 15361721].
47 Casey JR, Pichichero ME. Changes in frequency and pathogens causing acute otitis media in 1995–2003. Pediatr Infect Dis J. 09. 2004;23(9):824-8. [pmid: 15361720].
48 McEllistrem MC, Adams JM, Patel K, Mendelsohn AB, Kaplan SL, Bradley JS, et al. Acute otitis media due to penicillin-nonsusceptible Streptococcus pneumoniae before and after the introduction of the pneumococcal conjugate vaccine. Clin Infect Dis. 06. 15. 2005;40(12):1738-44. [pmid: 15909260].
49 Brook I, Gober AE. Bacteriology of spontaneously draining acute otitis media in children before and after the introduction of pneumococcal vaccination. Pediatr Infect Dis J. 07. 2009;28(7):640-2. [pmid: 19561428].
50 Veenhoven R, Bogaert D, Uiterwaal C, Brouwer C, Kiezebrink H, Bruin JI, et al. Effect of conjugate pneumococcal vaccine followed by polysaccharide pneumococcal vaccine on recurrent acute otitis media: a randomised study. Lancet. 06. 28. 2003;361(9376):2189-95. [pmid: 12842372].
51 Eskola J, Kilpi T, Palmu A, Jokinen J, Haapakoski J, Herva E, et al. Efficacy of a pneumococcal conjugate vaccine against acute otitis media. N Engl J Med. 02. 8. 2001;344(6):403-9. [pmid: 11172176].
52 Guven M, Bulut Y, Sezer T, Aladag I, Eyibilen A, Etikan I. Bacterial etiology of acute otitis media and clinical efficacy of amoxicillin-clavulanate versus azithromycin. Int J Pediatr Otorhinolaryngol. 05. 2006;70(5):915-23. [pmid: 16293317].
53 Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SE, Wincott JL, Sitar DS, Klassen TP, et al. Short course antibiotics for acute otitis media. Cochrane Database Syst Rev. 2000;(2):CD001095. [pmid: 10796591].
54 Glasziou PP, Del Mar CB, Sanders SL, Hayem M. Antibiotics for acute otitis media in children. Cochrane Database Syst Rev. 2004;(1):CD000219. [pmid: 14973951].
55 Foxlee R, Johansson A, Wejfalk J, Dawkins J, Dooley L, Del Mar C. Topical analgesia for acute otitis media. Cochrane Database Syst Rev. 2006;3:CD005657. [pmid: 16856108].
56 Rovers MM, Glasziou P, Appelman CL, Burke P, McCormick DP, Damoiseaux RA, et al. Antibiotics for acute otitis media: a meta-analysis with individual patient data. Lancet. 10. 21. 2006;368(9545):1429-35. [pmid: 17055944].
57 Spurling GK, Del Mar CB, Dooley L, Foxlee R. Delayed antibiotics for respiratory infections. Cochrane Database Syst Rev. 2007;(3):CD004417. [pmid: 17636757].
58 Coleman C, Moore M. Decongestants and antihistamines for acute otitis media in children. Cochrane Database Syst Rev. 2008;(3):CD001727. [pmid: 18646076].
59 Thanaviratananich S, Laopaiboon M, Vatanasapt P. Once. or twice daily versus three times daily amoxicillin with or without clavulanate for the treatment of acute otitis media. Cochrane Database Syst Rev. 2008;(4):CD004975. [pmid: 18843673].
60 Del Mar C, Glasziou P, Hayem M. Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. BMJ. 05. 24. 1997;314(7093):1526-9. [pmid: 9183201].
61 Rosenfeld RM, Vertrees JE, Carr J, Cipolle RJ, Uden DL, Giebink GS, et al. Clinical efficacy of antimicrobial drugs for acute otitis media: metaanalysis of 5400 children from thirty-three randomized trials. J Pediatr. 03. 1994;124(3):355-67. [pmid: 8120703].
62 Damoiseaux RA, van Balen FA, Hoes AW, de Melker RA. Antibiotic treatment of acute otitis media in children under two years of age: evidence based?. Br J Gen Pract. 12. 1998;48(437):1861-4. [pmid: 10198511].
63 Rosenfeld RM, Kay D. Natural history of untreated otitis media. Laryngoscope. 10. 2003;113(10):1645-57. [pmid: 14520089].
64 Rosenfeld RM. What to expect from medical theraphy. Bluestone CD, editor. Evidence-baed otitis media. Decker Inc. 1999:179-205.
65 Zielnik-Jurkiewicz B, Jurkiewicz D. Usefulness of fenspiride in the treatment of acute otitis media in children. Pol Merkur Lekarski. 06. 2005;18(108):624-8. [pmid: 16124370].
66 Arguedas A, Emparanza P, Schwartz RH, Soley C, Guevara S, de Caprariis PJ, et al. A randomized, multicenter, double blind, double dummy trial of single dose azithromycin versus high dose amoxicillin for treatment of uncomplicated acute otitis media. Pediatr Infect Dis J. 02. 2005;24(2):153-61. [pmid: 15702045].
67 Morris PS, Gadil G, McCallum GB, Wilson CA, Smith-Vaughan HC, Torzillo P, et al. Single-dose azithromycin versus seven days of amoxycillin in the treatment of acute otitis media in Aboriginal children (AATAAC): a double blind, randomised controlled trial. Med J Aust. 01. 4. 2010;192(1):24-9. [pmid: 20047544].
68 Zhang YM, Dong P, Lu P. Efficacy and safety of one dose ceftriaxone vs. ten-day oral amoxicillin for treatment of acute otitis media in children. Zhonghua Er Ke Za Zhi. 02. 2003;41(2):135-8. [pmid: 14759321].
69 Casellas JMJ, Israele V, Marin M, Ishida MT, Heguilen R, Soutric J, et al. Amoxicillin-sulbactam versus amoxicillin-clavulanic acid for the treatment of non-recurrent-acute otitis media in Argentinean children. Int J Pediatr Otorhinolaryngol. 09. 2005;69(9):1225-33. [pmid: 16061111].
70 Dunne MW, Latiolais T, Lewis B, Pistorius B, Bottenfield G, Moore WH, et al. Randomized, double-blind study of the clinical efficacy of 3 days of azithromycin compared with co-amoxiclav for the treatment of acute otitis media. J Antimicrob Chemother. 09. 2003;52(3):469-72. [pmid: 12888586].
71 Biner B, Celtik C, Oner N, Kucukugurluoglu Y, Guzel A, Yildirim C, et al. The comparison of single-dose ceftriaxone, five-day azithromycin, and ten-day amoxicillin/clavulanate for the treatment of children with acute otitis media. Turk J Pediatr. 10–12. 2007;49(4):390-6. [pmid: 18246740].
72 Block SL, McCarty JM, Hedrick JA, Nemeth MA, Keyserling CH, Tack KJ. Comparative safety and efficacy of cefdinir vs amoxicillin/clavulanate for treatment of suppurative acute otitis media in children. Pediatr Infect Dis J. 12. 2000;19(12 Suppl):S159-65. [pmid: 11144398].
73 Adler M, McDonald PJ, Trostmann U, Keyserling C, Tack K. Cefdinir vs. amoxicillin/clavulanic acid in the treatment of suppurative acute otitis media in children. Pediatr Infect Dis J. 12. 2000;19(12 Suppl):S166-70. [pmid: 11144399].
74 Cifaldi MA, Paris MM, Devcich KJ, Bukofzer S. Parent-reported outcomes for treatment of acute otitis media with cefdinir or amoxicillin/clavulanate oral suspensions. Paediatr Drugs. 2004;6(6):387-93. [pmid: 15612839].
75 Block SL, Busman TA, Paris MM, Bukofzer S. Comparison of five-day cefdinir treatment with ten-day low dose amoxicillin/clavulanate treatment for acute otitis media. Pediatr Infect Dis J. 09. 2004;23(9):834-8. [pmid: 15361722].
76 Hedrick JA, Sher LD, Schwartz RH, Pierce P. Cefprozil versus high-dose amoxicillin/clavulanate in children with acute otitis media. Clin Ther. 02. 2001;23(2):193-204. [pmid: 11293553].
77 Cohen R, Navel M, Grunberg J, Boucherat M, Geslin P, Derriennic M, et al. One dose ceftriaxone vs. ten days of amoxicillin/clavulanate therapy for acute otitis media: clinical efficacy and change in nasopharyngeal flora. Pediatr Infect Dis J. 05. 1999;18(5):403-9. [pmid: 10353511].
78 Wang CY, Lu CY, Hsieh YC, Lee CY, Huang LM. Intramuscular ceftriaxone in comparison with oral amoxicillin-clavulanate for the treatment of acute otitis media in infants and children. J Microbiol Immunol Infect. 02. 2004;37(1):57-62. [pmid: 15060689].
79 Pessey JJ, Gehanno P, Thoroddsen E, Dagan R, Leibovitz E, Machac J, et al. Short course therapy with cefuroxime axetil for acute otitis media: results of a randomized multicenter comparison with amoxicillin/clavulanate. Pediatr Infect Dis J. 10. 1999;18(10):854-9. [pmid: 10530579].
80 Dohar J, Giles W, Roland P, Bikhazi N, Carroll S, Moe R, et al. Topical ciprofloxacin/dexamethasone superior to oral amoxicillin/clavulanic acid in acute otitis media with otorrhea through tympanostomy tubes. Pediatrics. 09. 2006;118(3):e561-9. [pmid: 16880248].
81 Dagan R, Leibovitz E, Fliss DM, Leiberman A, Jacobs MR, Craig W, et al. Bacteriologic efficacies of oral azithromycin and oral cefaclor in treatment of acute otitis media in infants and young children. Antimicrob Agents Chemother. 01. 2000;44(1):43-50. [pmid: 10602721].
82 Oguz F, Unuvar E, Suoglu Y, Erdamar B, Dundar G, Katircioglu S, et al. Etiology of acute otitis media in childhood and evaluation of two different protocols of antibiotic therapy: 10 days cefaclor vs. 3 days azitromycin. Int J Pediatr Otorhinolaryngol. 01. 2003;67(1):43-51. [pmid: 12560149].
83 Block SL, Cifaldi M, Gu Y, Paris MM. A comparison of 5 days of therapy with cefdinir or azithromycin in children with acute otitis media: a multicenter, prospective, single-blind study. Clin Ther. 06. 2005;27(6):786-94. [pmid: 16117986].
84 Carvalho ES, Campos SO, Pignatari SN, Weckx LL. Efficacy and safety of cefprozil versus cefaclor in the treatment of acute otitis media in pediatric patients. J Pediatr (Rio J). 11–12. 1998;74(6):461-6. [pmid: 14685589].
85 Block SL, Kratzer J, Nemeth MA, Tack KJ. Five-day cefdinir course vs. ten-day cefprozil course for treatment of acute otitis media. Pediatr Infect Dis J. 12. 2000;19(12 Suppl):S147-52. [pmid: 11144396].
86 Tsai HY, Huang LM, Chiu HH, Hsueh PR, Lee PI, Lu CY, et al. Comparison of once daily cefpodoxime proxetil suspension and thrice daily cefaclor suspension in the treatment of acute otitis media in children. J Microbiol Immunol Infect. 09. 1998;31(3):165-70. [pmid: 10496153].
87 Neumark T, Molstad S, Rosen C, Persson LG, Torngren A, Brudin L, et al. Evaluation of phenoxymethylpenicillin treatment of acute otitis media in children aged 2–16. Scand J Prim Health Care. 09. 2007;25(3):166-71. [pmid: 17846935].
88 Damoiseaux RA, van Balen FA, Hoes AW, Verheij TJ, de Melker RA. Primary care based randomised, double blind trial of amoxicillin versus placebo for acute otitis media in children aged under 2 years. BMJ. 02. 5. 2000;320(7231):350-4. [pmid: 10657332].
89 Le Saux N, Gaboury I, Baird M, Klassen TP, MacCormick J, Blanchard C, et al. A randomized, double-blind, placebo-controlled noninferiority trial of amoxicillin for clinically diagnosed acute otitis media in children 6 months to 5 years of age. CMAJ. 02. 1. 2005;172(3):335-41. [pmid: 15684116].
90 Bolt P, Barnett P, Babl FE, Sharwood LN. Topical lignocaine for pain relief in acute otitis media: results of a double-blind placebo-controlled randomised trial. Arch Dis Child. 01. 2008;93(1):40-4. [pmid: 18156478].
91 Hatakka K, Blomgren K, Pohjavuori S, Kaijalainen T, Poussa T, Leinonen M, et al. Treatment of acute otitis media with probiotics in otitis-prone children-a double-blind, placebo-controlled randomised study. Clin Nutr. 06. 2007;26(3):314-21. [pmid: 17353072].
92 Jacobs J, Springer DA, Crothers D. Homeopathic treatment of acute otitis media in children: a preliminary randomized placebo-controlled trial. Pediatr Infect Dis J. 02. 2001;20(2):177-83. [pmid: 11224838].
93 Little P, Moore M, Warner G, Dunleavy J, Williamson I. Longer term outcomes from a randomised trial of prescribing strategies in otitis media. Br J Gen Pract. 03. 2006;56(524):176-82. [pmid: 16536957].
94 Spiro DM, Tay KY, Arnold DH, Dziura JD, Baker MD, Shapiro ED. Wait-and-see prescription for the treatment of acute otitis media: a randomized controlled trial. JAMA. 09. 13. 2006;296(10):1235-41. [pmid: 16968847].
95 Chao JH, Kunkov S, Reyes LB, Lichten S, Crain EF. Comparison of two approaches to observation therapy for acute otitis media in the emergency department. Pediatrics. 05. 2008;121(5):e1352-6. [pmid: 18450878].
96 Garrison GD, Sorum PC, Hioe W, Miller MM. High-dose versus standard-dose amoxicillin for acute otitis media. Ann Pharmacother. 01. 2004;38(1):15-9. [pmid: 14742786].
97 Bottenfield GW, Burch DJ, Hedrick JA, Schaten R, Rowinski CA, Davies JT. Safety and tolerability of a new formulation (90 mg/kg/day divided every 12 h) of amoxicillin/clavulanate (Augmentin) in the empiric treatment of pediatric acute otitis media caused by drug-resistant Streptococcus pneumoniae. Pediatr Infect Dis J. 10. 1998;17(10):963-8. [pmid: 9802654].
98 Cohen R, Levy C, Boucherat M, Langue J, de La Rocque F. A multicenter, randomized, double-blind trial of 5 versus 10 days of antibiotic therapy for acute otitis media in young children. J Pediatr. 11. 1998;133(5):634-9. [pmid: 9821420].
99 Catania S, Gallo A. Clinical efficacy and tolerability of short course therapy with cefaclor compared with long-term therapy for treatment of acute otitis media in children. Infez Med. 12. 2004;12(4):259-65. [pmid: 15729016].
100 Cohen R, Levy C, Boucherat M, Langue J, Autret E, Gehanno P, et al. Five vs. ten days of antibiotic therapy for acute otitis media in young children. Pediatr Infect Dis J. 05. 2000;19(5):458-63. [pmid: 10819344].
101 Chonmaitree T, Saeed K, Uchida T, Heikkinen T, Baldwin CD, Freeman DH Jr, et al. A randomized, placebo-controlled trial of the effect of antihistamine or corticosteroid treatment in acute otitis media. J Pediatr. 09. 2003;143(3):377-85. [pmid: 14517524].
102 Sarrell EM, Mandelberg A, Cohen HA. Efficacy of naturopathic extracts in the management of ear pain associated with acute otitis media. Arch Pediatr Adolesc Med. 07. 2001;155(7):796-9. [pmid: 11434846].
103 Sarrell EM, Cohen HA, Kahan E. Naturopathic treatment for ear pain in children. Pediatrics. 05. 2003;111(5 Pt 1):e574-9. [pmid: 12728112].
104 Halsted C, Lepow ML, Balassanian N, Emmerich J, Wolinsky E. Otitis media: microbiology and evaluation of therapy. Ann N Y Acad Sci. 09. 27. 1967;145(2):372-8. [pmid: 4397881].
105 Laxdal OE, Merida J, Jones RH. Treatment of acute otitis media: a controlled study of 142 children. Can Med Assoc J. 02. 14. 1970;102(3):263-8. [pmid: 4190002].
106 Howie VM, Ploussard JH. Efficacy of fixed combination antibiotics versus separate components in otitis media. Effectiveness of erythromycin estrolate, triple sulfonamide, ampicillin, erythromycin estolate- triple sulfonamide, and placebo in 280 patients with acute otitis media under two and one-half years of age. Clin Pediatr (Phila). 04. 1972;11(4):205-14. [pmid: 4537206].
107 Burke P, Bain J, Robinson D, Dunleavey J. Acute red ear in children: controlled trial of non-antibiotic treatment in general practice. BMJ. 09. 7. 1991;303(6802):558-62. [pmid: 1912887].
108 Kaleida PH, Casselbrant ML, Rockette HE, Paradise JL, Bluestone CD, Blatter MM, et al. Amoxicillin or myringotomy or both for acute otitis media: results of a randomized clinical trial. Pediatrics. 04. 1991;87(4):466-74. [pmid: 2011422].
109 Glasziou PP, Hayem M, Del Mar CB. Antibiotics for acute otitis media in children. Cochrane Database Syst Rev. 2000;(2):CD000219.
110 Varsano I, Frydman M, Amir J, Alpert G. Single intramuscular dose of ceftriaxone as compared to 7-day amoxicillin therapy for acute otitis media in children. A double-blind clinical trial. Chemotherapy. 1988;34(Suppl 1):39-46. [pmid: 3246170].
111 Green SM, Rothrock SG. Single-dose intramuscular ceftriaxone for acute otitis media in children. Pediatrics. 01. 1993;91(1):23-30. [pmid: 8416502].
112 Kara CO, Ozuer MZ, Kilic I, Yalcin AN, Ergin H. Comparison of amoxicillin with second and third generation cephalosporins in the treatment of acute otitis media. Infez Med. 1998;6(2):93-5. [pmid: 12750572].
113 Bauchner H, Adams W, Barnett E, Klein J. Therapy for acute otitis media. Preference of parents for oral or parenteral antibiotic. Arch Pediatr Adolesc Med. 04. 1996;150(4):396-9. [pmid: 8634735].
114 Varsano I, Volovitz B, Horev Z, Robinson J, Laks Y, Rosenbaum I, et al. Intramuscular ceftriaxone compared with oral amoxicillin-clavulanate for treatment of acute otitis media in children. Eur J Pediatr. 11. 1997;156(11):858-63. [pmid: 9392401].
115 Pestalozza G, Cioce C, Facchini M. Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scand J Infect Dis Suppl. 1992;83:22-5. [pmid: 1336892].
116 Daniel RR. Comparison of azithromycin and co-amoxiclav in the treatment of otitis media in children. J Antimicrob Chemother. 06. 1993;31(Suppl E):65-71.
117 Schaad UB. Multicentre evaluation of azithromycin in comparison with co-amoxiclav for the treatment of acute otitis media in children. J Antimicrob Chemother. 06. 1993;31(Suppl E):81-8.
118 Principi N. Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media. Eur J Clin Microbiol Infect Dis. 08. 1995;14(8):669-76. [pmid: 8565983].
119 Arguedas A, Loaiza C, Herrera M, Mohs E. Comparative trial of 3-day azithromycin versus 10-day amoxycillin/clavulanate potassium in the treatment of children with acute otitis media with effusion. Int J Antimicrob Agents. 04. 1996;6(4):233-8. [pmid: 18611713].
120 Rodriguez AF. An open study to compare azithromycin with cefaclor in the treatment of children with acute otitis media. J Antimicrob Chemother. 06. 1996;37(Suppl C):63-9. [pmid: 8818847].
121 Saez-Llorens X, Rodriguez A, Arguedas A, Hamed KA, Yang J, Pierce P, et al. Randomized, investigator-blinded, multicenter study of gatifloxacin versus amoxicillin/clavulanate treatment of recurrent and nonresponsive otitis media in children. Pediatr Infect Dis J. 04. 2005;24(4):293-300. [pmid: 15818287].
122 Sher L, Arguedas A, Husseman M, Pichichero M, Hamed KA, Biswas D, et al. Randomized, investigator-blinded, multicenter, comparative study of gatifloxacin versus amoxicillin/clavulanate in recurrent otitis media and acute otitis media treatment failure in children. Pediatr Infect Dis J. 04. 2005;24(4):301-8. [pmid: 15818288].
123 Noel GJ, Blumer JL, Pichichero ME, Hedrick JA, Schwartz RH, Balis DA, et al. A randomized comparative study of levofloxacin versus amoxicillin/clavulanate for treatment of infants and young children with recurrent or persistent acute otitis media. Pediatr Infect Dis J. 06. 2008;27(6):483-9. [pmid: 18449063].
124 Arrieta A, Arguedas A, Fernandez P, Block SL, Emperanza P, Vargas SL, et al. High-dose azithromycin versus high-dose amoxicillin-clavulanate for treatment of children with recurrent or persistent acute otitis media. Antimicrob Agents Chemother. 10. 2003;47(10):3179-86. [pmid: 14506028].
125 Turik MA, Johns D Jr. Comparison of cefaclor and cefuroxime axetil in the treatment of acute otitis media with effusion in children who failed amoxicillin therapy. J Chemother. 08. 1998;10(4):306-12. [pmid: 9720470].
126 Roland PS, Anon JB, Moe RD, Conroy PJ, Wall GM, Dupre SJ, et al. Topical ciprofloxacin/dexamethasone is superior to ciprofloxacin alone in pediatric patients with acute otitis media and otorrhea through tympanostomy tubes. Laryngoscope. 12. 2003;113(12):2116-22. [pmid: 14660913].
127 Roland PS, Kreisler LS, Reese B, Anon JB, Lanier B, Conroy PJ, et al. Topical ciprofloxacin/dexamethasone otic suspension is superior to ofloxacin otic solution in the treatment of children with acute otitis media with otorrhea through tympanostomy tubes. Pediatrics. 01. 2004;113(1 Pt 1):e40-6. [pmid: 14702493].
128 De Diego JI, Prim MP, Alfonso C, Sastre N, Rabanal I, Gavilan J. Comparison of amoxicillin and azithromycin in the prevention of recurrent acute otitis media. Int J Pediatr Otorhinolaryngol. 04. 6. 2001;58(1):47-51. [pmid: 11249979].
129 Teele DW, Klein JO, Word BM, Rosner BA, Starobin S, Earle R Jr, et al. Antimicrobial prophylaxis for infants at risk for recurrent acute otitis media. Vaccine. 12. 8. 2000;19(Suppl 1):S140-3. [pmid: 11163478].
130 Koivunen P, Uhari M, Luotonen J, Kristo A, Raski R, Pokka T, et al. Adenoidectomy versus chemoprophylaxis and placebo for recurrent acute otitis media in children aged under 2 years: randomised controlled trial. BMJ. 02. 28. 2004;328(7438):487. [pmid: 14769785].
131 Roos K, Larsson P. Efficacy of ceftibuten in 5 versus 10 days treatment of recurrent acute otitis media in children. Int J Pediatr Otorhinolaryngol. 09. 29. 2000;55(2):109-15. [pmid: 11006450].
132 Hammaren-Malmi S, Saxen H, Tarkkanen J, Mattila PS. Adenoidectomy does not significantly reduce the incidence of otitis media in conjunction with the insertion of tympanostomy tubes in children who are younger than 4 years: a randomized trial. Pediatrics. 07. 2005;116(1):185-9. [pmid: 15995051].
133 Marchisio PES, Bianchini S, Desantis C, Galeone C, Nazzari E, Pignataro L, Principi N. Effectiveness of a propolis and zinc solution in preventing acute otitis media in children with a history of recurrent acute otitis media. Int J Immunopathol Pharmacol. 04–06. 2010;23(2):567-75. [pmid: 20646352].
134 Abes G, Espallardo N, Tong M, Subramaniam KN, Hermani B, Lasiminigrum L, et al. A systematic review of the effectiveness of ofloxaxin otic solution for the treatment of suppurative otitis media. ORL J Otorhinolaryngol Relat Spec. 03–04. 2003;65(2):106-16. [pmid: 12824733].
135 Goldblatt EL, Dohar J, Nozza RJ, Nielsen RW, Goldberg T, Sidman JD, et al. Topical ofloxacin versus systemic amoxicillin/clavulanate in purulent otorrhea in children with tympanostomy tubes. Int J Pediatr Otorhinolaryngol. 11. 15. 1998;46(1–2):91-101. [pmid: 10190709].
136 Dohar JE, Garner ET, Nielsen RW, Biel MA, Seidlin M. Topical ofloxacin treatment of otorrhea in children with tympanostomy tubes. Arch Otolaryngol Head Neck Surg. 05. 1999;125(5):537-45. [pmid: 10326811].
137 Goldblatt EL. Efficacy of ofloxacin and other otic preparations for acute otitis media in patients with tympanostomy tubes. Pediatr Infect Dis J. 01. 2001;20(1):116-9. discussion 20–2.
138 Wall GM, Stroman DW, Roland PS, Dohar J. Ciprofloxacin 0.3%/dexamethasone 0.1% sterile otic suspension for the topical treatment of ear infections: a review of the literature. Pediatr Infect Dis J. 02. 2009;28(2):141-4. [pmid: 19116600].
139 Bonati M, Marchetti F, Pistotti V, Agostin M, Bisogno G, Bussi R, et al. Metaanalysis of antimicrobial prophylaxis for recurrent acute otitis-media. Clinical Trials and Meta-Analysis. 1992;28(1):39-50.
140 Williams RL, Chalmers TC, Stange KC, Chalmers FT, Bowlin SJ. Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion. A meta-analytic attempt to resolve the brouhaha. JAMA. 09. 15. 1993;270(11):1344-51. [pmid: 8141875].
141 Straetemans M, Sanders EA, Veenhoven RH, Schilder AG, Damoiseaux RA, Zielhuis GA. Pneumococcal vaccines for preventing otitis media. Cochrane Database Syst Rev. 2004;(1):CD001480. [pmid: 14973970].
142 Leach AJ, Morris PS, Mathews JD. Compared to placebo, long-term antibiotics resolve otitis media with effusion (OME) and prevent acute otitis media with perforation (AOMwiP) in a high-risk population: a randomized controlled trial. BMC Pediatr. 2008;8:23. [pmid: 18513453].
143 McDonald S, Langton Hewer CD, Nunez DA. Grommets (ventilation tubes) for recurrent acute otitis media in children. Cochrane Database Syst Rev. 2008;(4):CD004741. [pmid: 18843668].
144 Shea BJ, Grimshaw JM, Wells GA, Boers M, Andersson N, Hamel C, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
145 Maynard JE, Fleshman JK, Tschopp CF. Otitis media in Alaskan Eskimo children. Prospective evaluation of chemoprophylaxis. JAMA. 01. 31. 1972;219(5):597-9. [pmid: 5066805].
146 Perrin JM, Charney E, MacWhinney JB Jr, McInerny TK, Miller RL, Nazarian LF. Sulfisoxazole as chemoprophylaxis for recurrent otitis media. A double-blind crossover study in pediatric practice. N Engl J Med. 09. 26. 1974;291(13):664-7. [pmid: 4153093].
147 Gray B. Controlled trial of sulfamethoxazole-trimethoprim for the prevention of recurrent otitis media in young children Current Cheomotherapy and Immunotherapy. Proceedings of the 12th International Congress of Chemotherapy. 1981.
148 Gaskins JD, Holt RJ, Kyong CU, Weart CW, Ward J. Chemoprophylaxis of recurrent otitis media using trimethoprim/sulfamethoxazole. Drug Intell Clin Pharm. 05. 1982;16(5):387-90. [pmid: 7084029].
149 Schwartz RH, Puglise J, Rodriguez WJ. Sulphamethoxazole prophylaxis in the otitis-prone child. Arch Dis Child. 08. 1982;57(8):590-3. [pmid: 7051984].
150 Liston TE, Foshee WS, Pierson WD. Sulfisoxazole chemoprophylaxis for frequent otitis media. Pediatrics. 04. 1983;71(4):524-30. [pmid: 6601256].
151 Schuller DE. Prophylaxis of otitis media in asthmatic children. Pediatr Infect Dis. 07–08. 1983;2(4):280-3. [pmid: 6889154].
152 Persico M, Podoshin L, Fradis M, Grushka M, Golan D, Foltin V, et al. Recurrent acute otitis media--prophylactic penicillin treatment: a prospective study. Part I. Int J Pediatr Otorhinolaryngol. 10. 1985;10(1):37-46. [pmid: 3935589].
153 Varsano I, Volovitz B, Mimouni F. Sulfisoxazole prophylaxis of middle ear effusion and recurrent acute otitis media. Am J Dis Child. 06. 1985;139(6):632-5. [pmid: 3890523].
154 Gonzalez C, Arnold JE, Woody EA, Erhardt JB, Pratt SR, Getts A, et al. Prevention of recurrent acute otitis media: chemoprophylaxis versus tympanostomy tubes. Laryngoscope. 12. 1986;96(12):1330-4. [pmid: 3537596].
155 Principi N, Marchisio P, Massironi E, Grasso RM, Filiberti G. Prophylaxis of recurrent acute otitis media and middle-ear effusion. Comparison of amoxicillin with sulfamethoxazole and trimethoprim. Am J Dis Child. 12. 1989;143(12):1414-8. [pmid: 2589274].
156 Casselbrant ML, Kaleida PH, Rockette HE, Paradise JL, Bluestone CD, Kurs-Lasky M, et al. Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: results of a randomized clinical trial. Pediatr Infect Dis J. 04. 1992;11(4):278-86. [pmid: 1565551].
157 Sih T, Moura R, Caldas S, Schwartz B. Prophylaxis for recurrent acute otitis media: a Brazilian study. Int J Pediatr Otorhinolaryngol. 01. 1993;25(1–3):19-24. [pmid: 8436464].
158 Mandel EM, Casselbrant ML, Rockette HE, Bluestone CD, Kurs-Lasky M. Efficacy of antimicrobial prophylaxis for recurrent middle ear effusion. Pediatr Infect Dis J. 12. 1996;15(12):1074-82. [pmid: 8970215].
159 Roark R, Berman S. Continuous twice daily or once daily amoxicillin prophylaxis compared with placebo for children with recurrent acute otitis media. Pediatr Infect Dis J. 04. 1997;16(4):376-81. [pmid: 9109139].
160 Gray B, editor. Controlled trial of sulfamethoxazole-trimethoprim for the prevention of recurrent acute otitis media in young children. Proceedings of the 12th International Congrress of Chemotherapy. 1981. Florence, Italy.
161 Gebhart DE. Tympanostomy tubes in the otitis media prone child. Laryngoscope. 06. 1981;91(6):849-66. [pmid: 7017311].
162 El Sayed Y. Treatment of recurrent acute otitis media chemoprophylaxis versus ventilation tubes. Australian Journal of Otolaryngology. 1996;2(4):352-5.
163 Block SL, Hedrick JA, Kratzer J, Nemeth MA, Tack KJ. Five-day twice daily cefdinir therapy for acute otitis media: microbiologic and clinical efficacy. Pediatr Infect Dis J. 12. 2000;19(12 Suppl):S153-8. [pmid: 11144397].
164 Bezakova N, Damoiseaux RA, Hoes AW, Schilder AG, Rovers MM. Recurrence up to 3.5 years after antibiotic treatment of acute otitis media in very young Dutch children: survey of trial participants. BMJ. 2009;338:b2525. [pmid: 19567910].