# Discussion

## Limitations

### Publication Bias

Our literature search procedures were extensive and included canvassing experts from academia, the clinical arena, and the FDA MedWatch database for studies. However, it is possible that other unpublished trial results exist for the treatments included in our report. Publication bias may occur, resulting in an overestimation of the efficacy of these treatments. In a few instances, we detected statistical evidence of possible publication bias (these instances are noted in the text).

### Study Quality

An important limitation common to systematic reviews is the quality of the original studies. Recent attempts to assess which elements of study design and execution are related to bias have shown that in many cases, such efforts are not reproducible. Therefore, the current approach is to avoid using quality criteria to reject studies, which could affect meta-analysis results. However, for the assessment of quality of trials, we did use the Jadad scale, which is the only set of quality criteria for trials for which there is empirical evidence of an association with bias. Where feasible, we performed sensitivity analyses that used only the “high quality” studies (those scoring 3 or more on Jadad‘s scale). In some cases, this sensitivity analysis yielded a pooled result that was lower than the result of the primary analysis, a result seen in other clinical settings. Therefore, it is possible that some individual trials and some primary pooled analyses overestimate the true effectiveness of treatments. To assess the quality of diagnostic studies, we used QUADAS criteria. As there is a lack of empirical evidence regarding other study characteristics and their relationship to bias, we did not attempt to use other criteria.

Further limitations are provided below with respect to each of the key questions.

## Conclusions

### Key Question I Diagnosis of AOM

Limited evidence exists on clinicians‘ accuracy and precision in identifying the three clinical criteria necessary for a diagnosis of AOM. There is some evidence to suggest that clinicians accurately identify MEE by reliance on otoscopic findings of decreased mobility or abnormal position. However, there is little evidence to help us fully understand how accurate and precise clinicians are at identifying all three criteria in one patient to make a diagnosis of AOM.

We reviewed studies that examined the association of individual physical exam findings with a diagnosis of AOM, which did not fully address this key question. Further studies are needed that examine clinician‘s identification of all three clinical criteria of AOM in a patient, compared to identification of all three criteria by an independent examiner to serve as the criterion standard. These types of studies should clearly identify the level of expertise of the studied clinicians to help evaluate the level of generalizability of results to clinicians in practice. Perhaps the most important way to improve diagnosis is to increase clinicians’ ability to recognize and rely on key otoscopic findings.

### Key Question II The impact of the Pneumococcal Heptavalent Immunization (PCV7) on AOM Microbial Epidemiology

Since the introduction of PCV7, there have been significant shifts in AOM microbiology. Our review indicates that overall, SP is becoming less prevalent, yet still important, while HF is increasing in its importance as an infectious agent of AOM. The pattern of penicillin-susceptibility among SP isolates is unclear; some studies have indicated that the proportion of penicillin–non susceptibility among vaccine serotype SP isolates has increased, while others have indicated that the proportion of SP that are non-susceptible has decreased. Future studies may need to consider susceptibility separately for vaccine and non-vaccine SP serotypes.

One of the major limitations of our review for this particular key question is that tympanocentesis, which is required for the isolation of a microbiologic agent, is not routinely performed in children with uncomplicated AOM. Most of the studies that compared the microbiology of AOM before and after the introduction and use of PCV7 examined middle-ear fluid samples for children with complicated, recurrent, or persistent OM. Another limitation is that we do not have adequate data to understand the possible impact of PCV7 on non-bacterial agents (i.e., viruses). Although the importance of non-bacterial agents has been studied for AOM, we were unable to find studies examining the impact of PCV7 on the importance of non-bacterial causes of AOM.

### Key Question III Treatment of Uncomplicated AOM

Immediate antibiotic therapy is more effective than placebo for treating uncomplicated AOM. However, between eight and nine children would need to be treated with immediate antibiotics in order to observe this difference in clinical success. Clinicians will have to determine if this number needed to treat justifies the immediate prescription of antibiotics in children with uncomplicated AOM and average risk. The evidence for immediate antibiotic therapy vs. a delayed prescription or a wait-and-see approach is mixed, with two studies showing an advantage for immediate antibiotics and two studies showing inconclusive results.

Amoxicillin-clavulanate is superior to azithromycin in terms of clinical success by day 14 when the pathogen is HF. This finding has clinical significance, given the microbiologic shift following the introduction of PCV7 that seems to indicate that HF is becoming more prevalent than SP as a cause of AOM.

Our review of data to address this key question (as well as questions pertaining to prevention and treatment of ROM) had several limitations. First, as described above in our list of the general limitations, definitions for clinical success were usually not equivalent between studies comparing the same treatments. For example, studies used different clinical criteria to define success, and success was often measured at different time points. Second, the inclusion criteria for participants also varied widely among studies. Some studies used only one of the three criteria for AOM diagnosis, while others considered two or all three. It is possible that some studies with less stringent inclusion criteria may have included participants who did not have AOM, but rather had OME or no middle ear infective process at all. Third, the timing of study completion could affect results. As evidenced by the analysis of changes in epidemiology, the microbiology of AOM is changing, in part, based on the introduction of PCV7. It is unclear how differences in AOM microbiology over time might affect our findings from pooled analyses. Because we considered a minimum clinically important difference (MCID) of 5%, we sometimes considered results as clinically insignificant that were statistically significant. Since the minimum clinically significant difference for AOM is not empirically known, readers who assume an MCID different than 5% would reach modestly different conclusions. Any decision to suggest antibiotic treatment or choice of antibiotic involves a trade-off between the expectation of benefit compared with the risks.

### Key Question IV Prevention or Treatment of Acute Otitis Media in Children with Recurrent Otitis Media

We are unable to draw any definitive conclusions regarding the comparative effectiveness of different antibiotic treatments for treatment of AOM in children with ROM. Leach (2006) found on systematic review that long-term antibiotics, defined as treatment for six weeks or longer, prevented 1.5 episodes of AOM for every 12 months of treatment per otitis-prone child during active treatment (95% CI: 1.2, 2.1) who would otherwise average three episodes of AOM annually without treatment. Since this reduced risk of AOM was present only during therapy, the drawbacks of long-term antibiotics (including adverse effects such as diarrhea and allergic reactions, and emergence of bacterial resistance to antibiotics) must be weighed against the occurrence of another episode of AOM in the patient. In addition, all of the studies on which this finding is based were conducted prior to the widespread introduction of the heptavalent pneumococcal vaccine, which may influence bacterial etiology and resistance as noted in the findings for Key Question II in this review. It was decided that a review of the effectiveness of vaccines in preventing AOM was beyond the scope of this report. Thus, it may be difficult to generalize the Leach (2006) findings to the current population of children with ROM.

Further, we can also conclude that tympanostomy tubes can help decrease the likelihood of a repeat infection in a child with a history of ROM within the first six months after tube insertion. This conclusion may be tempered by the issue of AOM diagnostic accuracy in the presence of tympanostomy tubes possibly confounding these results, i.e. the pressure equalization and drainage afforded by the tubes and their physical presence decreasing the intensity or visibility of signs and symptoms used to diagnose AOM leading to false negatives. Again, whether or not the benefit of avoiding a repeat episode of AOM over six months outweighs the costs of a tympanostomy tube placement will depend on the clinician‘s assessment of the child with AOM, and discussions of advantages and disadvantages with the family.

The limitations in our ability to address this question mirror those for Key Question III. The lack of uniformity of definitions for ROM and clinical success and differences in measurement times made synthesis of the available evidence difficult. Similar to Key Question III, one treatment comparison that demonstrated statistically significant results did not demonstrate clinically significant results in terms of the zone of MCID. We again acknowledge that others may practice from a zone of MCID different from the +/−5% standard utilized in this study.

### Key Question V

Whereas the 2001 evidence review identified only sufficient evidence to allow the assessment of age on treatment effectiveness, the current review identified information to assess the effect of laterality and otorrhea, as well. Few to no conclusions can be made on the effect of other influencing factors such as characteristics of the patient, AOM episode, environment, and the health care system on the comparative effectiveness of treatment.

Meta-analysis conducted for this review indicates that children over the age of 2 years had better outcomes with various treatment options including placebo or no treatment than children under age 2. Data from a systematic review by Rovers (2006) utilizing individual patient data showed a similar effect of age on antibiotic treatment of uncomplicated AOM. In addition, Rovers (2006) found that laterality, especially in children 2 years and younger, and otorrhea had impacts on antibiotic effectiveness. These findings suggest that clinicians may need to monitor response to treatment and outcomes more closely when treating very young children with AOM, particularly those with bilateral AOM and those with otorrhea. The primary limitation related to this question was that the available evidence was limited and primarily focused on the association of age with AOM treatment, though other influencing factors are commonly cited as being important, such as AOM characteristics, including severity and characteristics of the patient, environment, and the healthcare delivery system. In addition, if the operating characteristics of AOM diagnostic criteria differ by age, then it is possible that treatment outcomes stratified by age may be confounded by a differential rate of inclusion of children who do not actually have AOM.

### Key Question VI

The available evidence indicated an increased rate of gastrointestinal adverse effects and diarrhea specifically with amoxicillin-clavulanate and cefixime in comparison with cefdinir, ceftriaxone, or ciprofloxacin-dexamethasone ear drops and with ampicillin or amoxicillin, respectively. In addition amoxicillin-clavulanate appeared to have a higher overall adverse effect rate than cefdinir, ceftriaxone, or azithromycin.

The limitations in our assessment for this question are similar to those cited above. The lack of uniformity of definitions for AOM and ROM and adverse effects and the differences in measurement times made synthesis of the available evidence difficult. As with key questions III and IV, treatment comparisons that demonstrated statistically significant results did not always demonstrate clinically significant results in terms of the zone of MCID. We again acknowledge that others may practice from a zone of MCID that is different from the +/−5% standard used in this study.

## Future Research Suggestions

Based on the findings of this review, we provide the following suggestions for future research directions.

### Key Question I Diagnostic Criteria for AOM

Additional studies are needed to more fully understand the precision of the current diagnostic criteria for AOM: acute onset of signs and symptoms, MEE, and middle ear inflammation. For example, evidence is insufficient to guide clinicians on the most effective and efficient ways to assess each of these elements in the clinical setting. Also needed are more studies that use a reference standard that can take into account all three criteria of an AOM diagnosis. Thus, a reference standard that takes into account only MEE does not provide sufficient evidence on overall diagnostic accuracy for AOM.

### Key Question II Effects of the PCV7 Vaccine

The five studies included in this report that address Key Question II provide information about the changing microbiologic patterns of otitis media since the introduction of PCV7, specifically, that HF has become more prevalent as a causative agent of AOM, although SP remains an important pathogen. The introduction of the vaccine has also resulted in a greater proportion of non-vaccine serotypes and a smaller proportion of vaccine serotypes as causative agents in AOM. However, none of the studies addressed the implications of this observed evolution in microbiology subsequent to introduction of the vaccine. For example, will this shift in microbiology translate to a shift in the type and incidence of suppurative and other complications? Further research is needed to explore the impact of PCV7 on the clinical progression and outcomes of uncomplicated AOM, and of AOM in otitis-prone children with recurrent AOM.

More inquiry is needed into microbiologic shifts in AOM, especially as it relates to resistance patterns of the non-PCV7 serotypes of SP that seem to be increasing since the introduction of PCV7. Such research will require continued surveillance of both shifts in the causative organisms of AOM and in the antibiotic resistance/susceptibility of these organisms.

A recent study of a single pediatric practice, not meeting our inclusion criteria, found evidence suggesting that an increase in the proportion of AOM with non-vaccine SP serotypes may be leading to another shift in AOM microbiology.8 These new data support the need for ongoing surveillance of AOM isolates.

Continued surveillance will also help us understand the impact of new pneumococcal vaccines, such as the newly-licensed PCV 13, that include more serotypes than PCV7 currently does. It will be important to have information to help conduct cost-benefit analysis of vaccines that cover more than the current seven serotypes.

A growing body of research is assessing the efficacy of the vaccine in preventing AOM. Although a review of this literature was beyond the scope of this report, such a review may be warranted in the near future.

### Key Questions III–VI Treatment Efficacy and Adverse Effects

Research issues identified in the original AOM review13 are still applicable to the review update as it relates to treatment of uncomplicated AOM as well as to treatment of ROM, which was not previously addressed. Though we report several definitive conclusions, the usefulness of these conclusions to the practitioner is suspect because of concerns regarding the internal validity of some of the source studies and the generalizability of the findings because of a lack of standard definitions for AOM and ROM as well as for treatment outcomes across studies; the variability of study quality; and the relative paucity of evidence related to influencing factors such as AOM severity, and other important factors. In addition, the impact of PCV7 as noted in this review‘s findings for KQ2, and of changing patterns of AOM bacterial etiology and resistance in general, must be considered in designing future studies.

Standard definitions of AOM and ROM that lead to standard diagnostic criteria and that are acceptable to both researchers and practitioners have not been developed since the initial review and are still needed. In the studies newly identified for this review update, only two of the 43 articles on treatment of uncomplicated AOM and one of the fifteen articles on treatment of children with ROM, persistent AOM, or AOM treatment failure included all three AOM diagnostic criteria recommended by the AAP AOM guidelines. This finding represents a slight improvement compared to the original review (Table 37).13 The continued diversity of definitions for AOM as well as for ROM and, therefore, the diversity of diagnostic criteria that control entry of participants into these treatment trials make it difficult to synthesize and generalize findings, as it is unclear if the same condition is being assessed across studies. Greater knowledge regarding the operating characteristics of criteria used to diagnose children of different ages will also help to assess results of studies comparing treatment options (e.g., are we more likely to be treating real AOM in an infant or an older child diagnosed with AOM?) In addition, knowledge of the effect of tympanostomy tube presence on these diagnostic operating characteristics will help to better assess the true impact of tympanostomy tubes on prevention of AOM in children with ROM.

Table 37 Number of Randomized Controlled Trials in the Original Review by Marcy (2001)13 and the Review Update by Number of AOM Diagnostic Criteria Used and by Number of Jadad Study Quality Criteria Met

Topic | AOM diagnostic criteria | | | Jadad study quality criteria
Topic | Number | Number of studies (Percent) | | Number | Number of studies (Percent)
Topic | Number | Original Review | Review Update | Number | Original Review | Review Update
Treatment of uncomplicated AOM | 0 | 38 (35%) | 8 (19%) | 0 | 1 (1%) | 0 (0%)
Treatment of uncomplicated AOM | 1 | 34 (43%) | 4 (9%) | 1 | 8 (11%) | 5 (12%)
Treatment of uncomplicated AOM | 2 | 18 (23%) | 29 (67%) | 2 | 26 (35%) | 14 (32%)
Treatment of uncomplicated AOM | 3 | 0 (0%) | 2 (5%) | 3 | 21 (28%) | 15 (35%)
Treatment of uncomplicated AOM | | | | 4 | 12 (16%) | 3 (7%)
Treatment of uncomplicated AOM | | | | 5 | 6 (8%) | 6 (14%)
Treatment of recurrent otitis media, persistent acute otitis media, or AOM treatment failure | 0 | n/a | 6 (40%) | 0 | n/a | 0 (0%)
Treatment of recurrent otitis media, persistent acute otitis media, or AOM treatment failure | 1 | | 0 (0%) | 1 | | 1 (7%)
Treatment of recurrent otitis media, persistent acute otitis media, or AOM treatment failure | 2 | | 8 (53%) | 2 | | 6 (40%)
Treatment of recurrent otitis media, persistent acute otitis media, or AOM treatment failure | 3 | | 1 (7%) | 3 | | 6 (40%)
Treatment of recurrent otitis media, persistent acute otitis media, or AOM treatment failure | | | | 4 | | 0 (0%)
Treatment of recurrent otitis media, persistent acute otitis media, or AOM treatment failure | | | | 5 | | 2 (13%)
Total | 0 | 38 (35%) | 14 (24%) | 0 | 1 (1%) | 0 (0%)
Total | 1 | 34 (43%) | 4 (7%) | 1 | 8 (11%) | 6 (10%)
Total | 2 | 18 (23%) | 37 (64%) | 2 | 26 (35%) | 20 (34%)
Total | 3 | 0 (0%) | 3 (5%) | 3 | 21 (28%) | 21 (36%)
Total | | | | 4 | 12 (16%) | 3 (5%)
Total | | | | 5 | 6 (8%) | 8 (14%)

Standard definitions related to the quality of AOM management in terms of specific structures, processes, and outcomes are still needed. For example, Table 8 documents the diversity of high-level outcomes chosen for measurement in the 63 treatment option comparisons for uncomplicated AOM. Though 62 comparisons measured clinical success, only three measured invasive infections 14, bacteriologic cure; 24, disease recurrence; 48, adverse effects; four, quality of life; seven, patient satisfaction; six, cost; and 16, other outcomes. Information in the evidence table demonstrates the varying definitions of clinical success among the 62 comparisons. Differences in terminology and in particular outcome choice and definitions between studies make it difficult to synthesize the results across studies and to generalize findings. This issue should be addressed in future studies.

Higher quality studies as well as improved reporting of study characteristics related to quality are still needed to come to definitive conclusions for AOM and ROM treatment options. Of the 58 RCTs newly identified for this review update, reported compliance with the 5 Jadad study quality criteria was not universal: one criterion in six studies; two criteria in 20 studies; three criteria in 21 studies; four criteria in three studies; five criteria in eight studies. Thus, study quality is not improved compared to the original review.13(Table 37) Although we recognize that the issue may be the documentation of study characteristics rather than the actual study quality, sensitivity analysis by quality in this review significantly affected the results of the comparisons of ampicillin/amoxicillin in treatment of uncomplicated AOM, changing the results from significant to not significant when pooling studies. This finding suggests that the quality of the studies as currently documented may indeed reflect the true quality of these studies and may have an effect on the study results.

Since the previous review, further evidence confirms that age is an important factor influencing treatment outcome in uncomplicated AOM and ROM with particular treatment options, and new evidence suggests a role for laterality and otorrhea. In addition, the role of laterality on antibiotic effect was associated with age and highlights the need to have studies of sufficient power to allow study of interactions as is suggested by the studies of Leibovitz (2007) and McCormick (2007), which describe the clinical and microbiologic characteristics of patients with bilateral vs. unilateral AOM. Both studies found that bilateral disease is more often associated with bacteria in the MEE, in particular HF; younger age; and greater severity disease. However, additional high quality research is needed to establish definitive conclusions regarding the influence of other factors, including characteristics of the AOM episode (such as disease severity), the patient, the environment (such as the daytime caretaker and use of daycare), and the healthcare delivery systems (such as the examiner) on treatment success. Future research must be designed so the selection of study participants balances the need for generalizability of findings with the need to study the applicability of findings to patients with specific characteristics. Practitioners take these unique characteristics into account when treating individual patients. Thus, future research will lead to greater improvements if it also addresses individual patient characteristics.

Finally, we recommend that the concept of an a priori established zone of MCID be included in assessing the impact of treatment options in addition to statistical significance. As noted throughout the report results, many instances of statistically significant results with clinically insignificant impacts were identified during the review update. Clinical practice should be guided by evidence that exceeds a MCID for the practitioner. However, we acknowledge that the minimal clinically important difference must be established by the clinician based on the particular decision in question.