# Results

This chapter presents the results of the literature searches, reviews of pertinent systematic reviews, the accepted key questions, and the findings and analyses for each key question.

In total, the reviewers examined 8, 946 titles for the draft version of this report (including 7,356 from the original searches with three updated searches producing 1, 300 titles (Appendix A).

The reviewers selected 739 titles for further review. Of those 739, four were excluded because they were duplicates; 500 were further rejected as they were determined not to be relevant to the project, they reported duplicate findings from a study already included; the age of the study population was ≥ 18 years; or the study population had immunodeficiencies or craniofacial deformities or were non-human subjects.

Screening of the remaining 235 retrieved articles resulted in exclusion of 11 due to publication being before 2002; no key question addressed; or for being included as part of a diagnostic review article; 67 were excluded for study design, not being a valid pre/post vaccine study, or reporting duplicate data. Eighty three observational studies were set aside for possible review of efficacy or adverse events at a later time; they were subsequently determined not to add further evidence. One RCT was rejected for not addressing the key question, and one article for lack of translation resources. The remaining 72 were reviewed in detail. The literature search and review flow appear in Appendix A. The list of excluded studies appears in Appendix D.

## Key Question I Diagnosis of AOM: What are the Operating Characteristics (Sensitivity, Specificity, and Likelihood Ratios) of Clinical Symptoms and Otoscopic Findings (Such As Bulging Tympanic Membrane) to Diagnose Uncomplicated AOM and to Distinguish It from OME?

### Description of the Studies

In our initial search, we identified a 2003 systematic review that addressed the question and included six original research studies. We requested the search strategy from the principal investigator for the review and, using that strategy, re-ran the literature search on PubMed for articles published after 2002. This search identified three articles published subsequent to the Rothman review. Details of all accepted articles are presented in Tables 1 through 3 below.

Table 1 Evidence for Key Question I (Diagnosis)

Author, Year | Time/Place/Affiliation Inclusion/Exclusion Criteria Patient Characteristics | Examiner Group(s) and Sample Size | Comparison(s) Influencing factors Diagnostic Methods (Dx), cutpoints Gold Standards (GS), cutpoints | Findings | Quality a
Saeed, 2004^39^ | [underlined: Time] Recruitment period: Sept 1995–May 1998 Place: pediatric clinics [underlined: Affiliation] University of Texas Medical Branch, Galveston [underlined: Inclusion] Clinical diagnosis of AOM by:; - acute symptoms; - acute TM inflammation; - evidence of MEE by pneumatic otoscopy and/or tympanometry; [underlined: Exclusion]; - ear or nasopharynx defects; - tympanostomy tubes; - major medical condition; - antibiotic treatment w/in 7 days of enrollment; - treatment of AOM w/in 30 days; - allergy to study medication; [underlined: Patient Characteristics]; - mean age 19.2 months, age range 3–72 months; - part of clinical trial (double blind RCT) to evaluate adjunctive drugs in AOM with AOM from pediatric clinics; - all participants received IM ceftriaxone. | [underlined: Examiner(s)] Pneumatic otoscopy-Pediatrician/investigator Tympanometry-research assistant Tympanostomy-same Pediatrician/investigator as otoscopy examiner [underlined: Group] children with a dx of AOM and findings from otoscopy, tympanometry, and tympanocentesis available [underlined: Sample size] N=81 participants, 130 ears | [underlined: Comparisons]; 1. Pneumatic otoscopy; Dx− : no AOM; Dx+ : AOM; Tympanostomy; GS− : no MEE; GS+ : MEE present; 2. Tympanogram; Dx− :Type A (normal); Dx+ Type B (abnormal); Tympanostomy; GS− : no MEE; GS+ :MEE present | [underlined: Comparisons]; 1. Tympanogram; Sensitivity: 97%; Specificity: 7%; PPV 88%; NPV: 25%; falsely low true negatives b/c GS test not performed on normal ears; 2. Pneumatic otoscopy; Sensitivity: 100%; Specificity: 5%; PPV 86%; NPV: 100%; falsely low true negatives b/c GS test not performed on normal ears | [underlined: Study Quality Assessment] Rothman scale: 4 QUADAS: 11 y, y, y, y, n, n, y, y, y, y, n, y, y, y
Legros, 2007^40^ | [underlined: Time] Recruitment period: December 04–March 05 and October 05–January 06 [underlined: Place] GP clinics [underlined: Affiliation] Angers Medical School, France [underlined: Inclusion]; - children from 1–4 years old who had been suspected of having AOM or diagnosed with AOM by GP; - Parents had to agree to see ENT within 48 hours at another location; [underlined: Exclusion]; - chronic ear pathology; [underlined: Patient Characteristics]; - mean age 27.1 months, range 12–48 months | [underlined: Examiner(s)] GP clinical exam: by GP ENT clinical diagnosis: by ENT [underlined: Group] first 6 children either suspected or diagnosed with AOM by a GP [underlined: Sample Size] N=104 participants, 137 ears | [underlined: Comparisons]; 1. GP clinical diagnosis/suspicion; Dx− : no AOM; Dx +: AOM; ENT clinical diagnosis; GS− : no AOM; GS+ : has AOM; 2. GP clinical diagnosis/suspicion when eardrum only partially visible or not visible (subset of #1); Dx− : no AOM; Dx+ : AOM; ENT clinical diagnosis; GS− : no AOM; GS+ : has AOM | 1. GP clinical diagnosis/ suspicion 137 AOM diagnoses/ suspicions by GPs of these, 122 based on visible/partially visible TMs (54 had redness and bulging of TM; 32 had redness only), 13 based on non-visible TM, 2 based on otorrhea; Of the 137:; ENTs diagnosed- 107 as AOM, and 30 as not AOM. of these 30, --- 16 as OME, 4 as viral otitis, and 10 as normal; 2. Study also gives descriptions of what happened with the cases based on non- visible TMs. 19 of the 24 cases of non- visible TMs did not have a contralateral ear w/ AOM. Of these, the main signs noted by GP for diagnosis were night cries, irritability, pain, ear pulling, and fever.; GP diagnoses/suspicions based on 42 visible/partially visible eardrums:; 24 GP diagnoses/ suspicions of AOM; 18/24 were confirmed by the ENT | [underlined: Study Quality Score] Rothman scale: 4 QUADAS: 13 y, y, y, u, y, y, y, y, y, y, u, y, y, y
Laine, 2010^1^ | [underlined: Time:] November 2006–December 2008 [underlined: Place:] Outpatient setting Affiliation: Turku University Hospital, Finland [underlined: Inclusion:] Parental suspicion of AOM in child based on symptoms [underlined: Patient Characteristics:] 6–35 months | [underlined: Examiner:] Study physician validated to assess TM findings [underlined: Group:] Children presenting to an outpatient setting with a parental suspicion of AOM by symptoms [underlined: Sample Size:] N= 469 children. 237 with AOM by study physician exam and 3 criteria, 232 without. | [underlined: Comparisons:]; 1. [underlined: Parental Suspicion]; Dx−: no AOM; Dx +: AOM; 2. [underlined: Ear-related symptoms]; (pain, rubbing, fever, non-specific symptoms, respiratory symptoms) | 1. Parental suspicion was correct for 51% of all children, 48% of children without a previous AOM diagnosis, and 52% of children with a previous AOM diagnosis.; 2. The occurrence, duration, and severity of ear- related symptoms were not associated with AOM diagnosis | Rothman scale: 4 QUADAS: 12 n,y,y,y,y,y,y,y,y,y,n,y,y,y

Table Notes: B/c: because; Dx: diagnosis; GS: gold standard; MEE: middle ear effusion; NPV: negative predictive value; PPV: positive predictive value; TM: tympanic membrane

a QUADAS: 1 (y=yes); 2(n=no); 3(u=unclear). Answers to QUADAS questions presented in the following order:

1. Was the spectrum of patients representative of the patients who will receive the test in practice?
2. Were selection criteria clearly described?
3. Is the reference standard likely to correctly classify the target condition?
4. Is the time period between reference standard and index test short enough to be reasonably sure that the target condition did not change between the two tests?
5. Did the whole sample or a random selection of the sample, receive verification using a reference standard?
6. Did patients receive the same reference standard regardless of the index test result?
7. Was the reference standard independent of the index test (i.e. the index test did not form part of the reference standard)?
8. Was the execution of the index test described in sufficient detail to permit replication of the test?
9. Was the execution of the reference standard described in sufficient detail to permit its replication?
10. Were the index test results interpreted without knowledge of the results of the reference standard?
11. Were the reference standard results interpreted without knowledge of the results of the index test?
12. Were the same clinical data available when test results were interpreted as would be available when the test is used in practice?
13. Were uninterruptible/intermediate test results reported?
14. Were withdrawals from the study explained?

Table 2 Accuracy of Symptoms

Source and Symptoms | Sensitivity, % | Specificity, % | Positive LR (95% CI) | Negative LR 95% CI)
Niemela et al, 1994 41
Ear pain | 54 | 82 | 3.0 (2.1–4.3) | 0.6 (0.5–0.7)
Ear rubbing | 42 | 87 | 3.3 (2.1–5.1) | 0.7 (0.6–0.8)
Fever | 40 | 48 | 0.8 (0.6–1.0) | 1.2 (1.0–1.5)
Cough | 47 | 45 | 0.9 (0.7–1.1) | 1.2 (0.9–1.4)
Rhinitis | 75 | 43 | 1.3 (1.1–1.5) | 0.6 (0.4–0.8)
Excessive crying | 55 | 69 | 1.8 (1.4–2.3) | 0.7 (0.5–0.8)
Poor appetite | 36 | 66 | 1.1 (0.8–1.4) | 1.0 (9.8–1.1)
Vomiting | 11 | 89 | 1.0 (0.6–1.8) | 1.0 (0.9–1.1)
Sore throat | 13 | 74 | 0.5 (0.3–0.8) | 1.2 (1.1–1.3)
Headache | 9 | 76 | 0.4 (0.2–0.7) | 1.2 (1.1–1.3)
Heikkenen & Ruuskannen, 1995 42
Ear pain | 60 | 92 | 7.3 (4.4–12.1) | 0.4 (0.4–0.5)
Fever | 69 | 23 | 0.9 (0.8–1.0) | 1.4 (0.9–2.0)
Cough | 84 | 17 | 1.0 (0.9–1.1) | 1.0 (0.6–1.6)
Rhinitis | 96 | 8 | 1.0 (1.0–1.1) | 0.5 (0.2–1.4)
Restless sleep | 64 | 51 | 1.3 (1.1–1.6) | 0.7 (0.5–0.9)
Ingvarsson, 1982 43
Ear pain | 100 | NA | NA | NA
Fever | 79 | 70 | 2.6 (1.9–3.6) | 0.3 (0.2–0.5)
URI | 96 | 29 | 1.4 (1.2–1.6) | 0.3 (0.2–0.5)_
Kontiokari et al, 1998 44
Parental suspicion of AOM | 70 | 80 | 3.4 (2.8–4.2) | 0.4 (0.3–0.5)
Laine et al, 2010 1
Ear pain | 92 | 8 | 1.0 (1.0–1.1) | 0.9 (0.5, 1.7)
Ear rubbing | 70 | 22 | 0.9 (0.8–1.0) | 1.4 (1.0, 1.8)
Fever | 43 | 65 | 1.2 (1.0–1.6) | 0.9 (0.8, 1.0)
Cough | 79 | 26 | 1.1 (1.0, 1.2) | 0.8 (0.6, 1.1)
Rhinitis | 94 | 95 | 1.0 (0.9, 1.0) | 1.2 (0.6, 2.6)
Excessive crying | 87 | 88 | 1.0 (0.9, 1.1) | 1.1 (0.7, 1.7)
Poor appetite | 63 | 64 | 1.0 (0.9, 1.1) | 1.0 (0.8, 1.3)
Vomiting | 1 | 2 | 0.6 (0.1, 2.4) | 1.0 (1.0, 1.0)

Table Notes: AOM: acute otitis media; CI: confidence interval; LR: likelihood ratio; URI: upper respiratory infection. Adapted from Rothman et al, 2003^15^

Table 3 Accuracy of Signs

ACCURACY OF SIGNS | Karma, et al 1989
Signs | Unadjusted Positive LR | Adjusted Positive LR (95% CI)
Color
Cloudy | 11 | 34 (28–42)
Distinctly red | 2.6 | 8.4 (6.7–11)
Slightly red | 0.4 | 1.4 (1.1–1.8)
Normal | 0.1 | 0.2 (0.19–0.21)
Position
Bulging | 20 | 51 (36–73)
Retracted | 1.3 | 3.5 (2.9–4.2)
Normal | 0.4 | 0.5 (0.49–0.51)
Mobility
Distinctly impaired | 8.4 | 31 (26–37)
Slightly impaired | 1.1 | 4.0 (3.4–4.7)
Normal | .04 | 0.2 (0.19–0.21)

Adapted from Rothman et al, 2003^15^

### Findings for Key Question I

A systematic review by Rothman and colleagues15 examined the study question of diagnostic operating characteristics for AOM. The authors searched for articles from 1966 through May 2002 (English language only) that specifically examined the role of any sign or symptom directly related to the diagnosis of AOM. Five studies met the criteria for inclusion in this review; study participants ranged in age from birth to 15 years (although the findings were not stratified by age). Partly based on the findings of a single study, the authors concluded that the diagnosis of AOM was often uncertain; agreement between pediatric residents and otolaryngologists was fair for overall diagnosis (kappa statistic 0.30) and slight to fair (Kappa statistics range from 0.16 to 0.40) for specific TM findings.

Furthermore, the authors concluded that among symptoms, only otalgia (ear pain) in three studies (reported sensitivity/specificity/positive likelihood ratio [95% confidence interval]/negative likelihood ratio [95% confidence interval]: 54%/82%/3.0 [2.1–4.3]/0.6 [0.5–0.7]; 60%/92%/7.3 [4.4–12.1]/0.4[0.4–0.5]; 100%/NA/NA/NA), and ear rubbing in one study 42%/87%/3.3 [2.1–5.1]/0.7[0.6–0.8]) seemed to predict a clinical diagnosis of AOM. Other symptoms, such as fever, did not show much effect, whether present or absent (two studies showed no effect, one study showed a slightly increased likelihood ratio [LR]). The major drawback to these types of studies examining the accuracy of symptoms in the clinical diagnosis of AOM is that the criterion standard is the clinical diagnosis itself, which can include these same acute symptoms.

One of the studies examined in this review assessed the accuracy of individual physical exam findings (cloudy, bulging, immobile, or red TM) using tympanocentesis as the criterion standard. Otoscopy was performed by an otolaryngologist and a pediatrician. They found these signs to be positively associated with AOM (determined by the presence of MEE on tympanocentesis and clinical symptoms). Specifically, a TM that was cloudy (adjusted positive LR 34 [28–42]; sensitivity and specificity not reported), bulging (adjusted positive LR 51 [37–73]), or distinctly immobile (adjusted positive LR 31 [26–37]) greatly increased the likelihood of AOM, and a moderately or strongly red TM also increased the likelihood of AOM but with a much lower adjusted positive LR (8.4 [6.7–11]).

Using the same inclusion criteria as this systematic review, we searched for articles published after May 2002 and found three additional relevant publications. Similar to the articles in the systematic review discussed above, these three additional articles met the 2003 review’s quality criteria for evidence level 4 (on a 1–5 scale, with 1 being the highest and 5 being the lowest, e.g., with scores of 1–2 reserved for studies that used an independent blind comparison of signs/symptoms against a criterion standard among consecutive patients). We additionally used the QUADAS (Quality Assessment of Diagnostic Accuracy of Studies) criteria to assess the quality of these two studies; QUADAS is a widely-used quality scale for studies of diagnostic accuracy. The total QUADAS scores and the answers for each of the 14 QUADAS questions are detailed for each article in Table 1. Tables 2 and 3 present the findings on the accuracy of signs and symptoms.

Saeed examined the accuracy of otoscopic and tympanometric findings compared with tympanocentesis as the criterion standard to determine the presence of MEE.39 The investigator performing the tympanocentesis was not blinded to the findings of tympanometry (performed by a research assistant) or otoscopic exam (performed by an “experienced” physician investigator), and only patients whose tympanometry or otoscopic exam suggested MEE received the criterion standard of tympanocentesis. Ninety-seven percent of children with MEE on tympanocentesis had “Type B” tympanogram findings (abnormal), and all children with MEE on tympanocentesis had an otoscopic exam consistent with AOM. However, LR and predictive value estimates are not as useful, since all participants had an AOM diagnosis at enrollment.

The second study (Legros, 2007) examined the diagnostic accuracy of French general practitioners (GP) compared with otolaryngologists’ clinical diagnoses as the criterion standard.45 The study used a consecutive sample of patients who had a suspected diagnosis of AOM by the GP and received the criterion standard (otolaryngology clinical exam). The study included 137 eardrums that were either assumed to be or were diagnosed as AOM by the GP. Of these 137, 78% (107) were confirmed by ear-nose-and throat (ENT) exam and the remaining were not, because the otolaryngologist diagnosed OME, viral otitis, or a normal TM. The ENT exam confirmed the GP diagnoses more often when redness and bulging were noted by the GP (83%) than when only redness was noted (75%). One major drawback to this study was that the criterion standard was not performed at the time of GP exam; in the majority of cases, the ENT exam occurred the following day when it was possible that GP-prescribed antibiotic treatment might have already altered the physical signs and clinical symptoms.

The third study published subsequent to the 2003 review found that among 469 children ages 6–36 months with parent-suspected AOM in primary care offices, AOM diagnosis was not associated with the occurrence, duration, or severity of parent-reported symptoms (e.g., ear pain: sensitivity 92%, specificity 8%, positive LR 1.0 [1.0–1.1]; ear rubbing: sensitivity 70%, specificity 22%, positive LR 0.9 [0.8–1.0]; fever: sensitivity 43%, specificity 65%, positive LR 1.2 [1.0–1.6]).1

In summary, there is limited evidence on clinicians‘ accuracy and precision in identifying each of the three clinical criteria necessary to diagnose AOM, or their accuracy and precision in identifying all three together. The prior review and studies examined above do not directly or completely answer our key question; however, they do suggest that clinical findings of MEE (decreased mobility or abnormal position) and middle ear inflammation (distinctly red color of the TM) are positively associated with AOM, defined by positive tympanocentesis and acute onset of symptoms. Further, studies comparing diagnostic accuracy between generalist or primary care physicians and otolaryngologists suggest that clinicians‘ accuracy in identifying all three clinical criteria in one patient is moderate, at best. The overall quality of evidence for this Key Question is considered low, meaning that further high-quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

## Key Question II What Has Been the Impact of the Pneumococcal Heptavalent Immunization (PCV7) on AOM Microbial Epidemiology (Including Acute Mastoiditis and Suppurative Complications)?

### Description of the Studies

The combined searches for titles pertaining to this key question resulted in 1,044 titles. Of these 1,044 titles, 73 titles appeared potentially relevant and full-text articles were ordered. A second level of screening was conducted to identify only articles that assessed microbiology both pre- and post-implementation of the vaccine. Of the 73 articles screened, six were accepted for our report and 67 were rejected. Details of all accepted articles are described below and presented in Tables 4 and 5. The rejected articles and the reasons for rejection are listed in Appendix D.

Table 4 Overview of Studies that Reported on Microbiology

Study | Age | Setting | Study Design | Number Patients | Number of Specimens | Inclusive Years
Casey, 2004^47^ | mean age 20–22 months | Pediatric practice, US | prospective observational cohort study | 551 patients with AOM treatment failure or persistent AOM | 551 | 1995–1997 1998–2000 2001–2003
Block, 2004^46^ | 7–24 months | Pediatric practice, US | prospective observational cohort study | 379 | 419 | 1992–1998 2000–2003
Veenhoven, 2003^50^ | 12–84 months, median age 2 years | 2 hospitals in the Netherlands | RCT of vaccine among unvaccinated toddlers/children with previous AOM) | 383 patients with recurrent AOM; 181 with MEF samples | 181 | 1998–2002
McEllistrem, 2005^48^ | not reported | 5 hospitals in the US | retrospective observational cohort study | not reported | 505 | 1999–2002
Eskola, 2001^51^ | infants enrolled <2 months; follow-up 6.5 to 25 months of age | 8 clinics in Finland | RCT for vaccine efficacy | 1662 (with 2,596 episodes of AOM) | 2,444 episodes of AOM with cultures (685 with S. pneumoniae) | 1995–1999
Brook, 2009^49^ | 1993–1998 cohort: 5 months- 12 years, median age 3 years, 1 month 2001–2006 cohort: 10 months – 12 years, median age 3 years, 8 months | Outpatient practice, US | retrospective observational cohort study | 100 patients with AOM with a new spontaneous perforation | 125 | 1993–1998 2001–2006

Table 5 Studies That Reported on Microbiology, Specific Findings

Study | % of all specimens caused by SP (S. pneumoniae) | % of all – HF (H. influenzae) | % of all-MC (M. catarrhalis) | % of SP AOM caused by PCV7 serotypes | % of SP AOM caused by non-vaccine serotypes | % of SP vaccine-related serotypes | Other bacteria and subgroup analyses
Intervention/Post-vaccine vs. Control/Pre-vaccine
Casey, 2004^47^ Differences in bold are significant at the p<0.05 level | 31% vs. 48% 1995–1997-48% 1998–2000-44% 2001–2003-31% Proportion by Susceptibility: [underlined: Susceptible:] 1995–1997–54% 1998–2000-58% 2001–2003-72% [underlined: Intermediate-susceptibility:] 1995–1997-12% 1998–2000-18% 2001–2003-14% [underlined: Resistant:] 1995–1997-34% 1998–2000-24% 2001–2003-14% | 57% vs. 38% 1995–1997: 38% 1998–2000: 43% 2001–2003: 57% Proportion by Susceptibility: B-lactamase positive: 1995–1997-46% 1998–2000-33% 2001–2003-55% B-lactamase negative: 1995–1997- 54% 1998–2000-67% 2001–2003-45% | 1% vs. 4% 1995–1997: 4% 1998–2000: 5% 2001–2003: 1% | no serotype analysis | no serotype analysis | no serotype analysis | S. pyogenes: 1995–1997- 3% 1998–2000-3% 2001–2003-2% No growth (not included in total): a includes S. epidermidis. S. aureus and diphtheroids were considered non-pathogens 1995–1997-47% 1998–2000-44% 2001–2003-42%
Block, 2004^46^ | 31% vs. 48% p=0.007 Proportion by Susceptibility: [underlined: Susceptible:] 12% vs. 23% [underlined: Intermediate:] 13% vs. 16% [underlined: Resistant:] 6% vs. 9% PCV7 Serogroups: % of SP isolates that were nonsusceptible 27% vs. 46% Non-PCV7 Serogroups: % of SP isolates that were nonsusceptible 18% vs. 1% PCV7 Related Serogroups: % of SP isolates that were nonsusceptible 27% vs. 5% | 56% vs. 41% p=0.001 Proportion by Susceptibility: Non-B lactamase 20% vs. 18% B-lactamase 36% vs. 23% | 11% vs. 9% (B-lactamase) | 36% vs. 70% p=0.005 | 32% vs. 22% 1, 11, 15A, 29, and 33F | 32% vs. 8% p=0.005 6A and 19A | S. Pyogenes 2% vs. 2% [underlined: Otitis prone] All SP-85% vs. 43% PNSP-81% vs. 53% Gram Negative-78% vs. 45% [underlined: Antibiotics within 30 days] All SP-62% vs. 58% PNSP-75% vs. 70% Gram Negative-85% vs. 61% [underlined: Antibiotics within 3 days] All SP-27% vs. 34% PNSP-38% vs. 41% Gram Negative-38% vs. 24% [underlined: Male] All SP- 67% vs. 59% PNSP-75% vs. 60% Gram Negative-58% vs. 51% [underlined: Day-care attendees] All SP-57% vs. 31% PNSP-63% vs. 40% Gram Negative-69% vs. 29%
Veenhoven, 2003^50^ | 22% vs. 35% (re-calculated to exclude negative cultures) | 35% vs. 43% PCV7: 21/60 Control: 23/54 | 13% vs. 11% PCV7: 8/60 Control: 6/54 | 31% vs. 42% PCV7: 4/13 Control: 8/19 vaccine serotypes: 4, 6B, 9V, 14, 18c, 19F, 23F | 70% vs. 58% PCV7: 9/13 Control: 11/19 non-vaccine serotypes not specified | | P. aeruginosa 10% vs. 17% PCV7: 9/60 Control: 6/54 S. aureus 34% vs. 17% (p=0.004) PCV7: 26/60 Control: 9/54 Group A Strep 10% vs. 7% PCV7: 6/60 Control: 4/54
McEllistrem, 2005^48^ | All cases were SP % that were PNSP: Overall nonsusceptible 1999: 62% 2000: 63% 2001: 50% 2002: 59%; p=0.21 [underlined: Intermediate] 1999: 23% 2000: 22% 2001: 19% 2002: 23%; p=0.74 [underlined: Resistant] 1999: 39% 2000: 41% 2001: 31% 2002: 35%; p=0.32 By number of PCV7 doses: 2–4 doses vs. ≤1 dose [underlined: Overall]-56% vs. 60% p=.64 [underlined: Intermediate-]22% vs. 22%; p=.88 [underlined: Resistant] 33% vs. 37% p=.64 PCV7 Serogroups: % of SP isolates that were nonsusceptible 1999: 70% 2000: 71% 2001: 66% 2003: 88% p=.12 2–4 doses 89% ≤1 dose-70% p=.08 Non-PCV7 Serogroups: % of SP isolates that were nonsusceptible 1999: 27% 2000: 12% 2001: 14% 2003: 23% p=.75 2–4 doses 24% ≤1 dose-28% p=.86 | All cases were SP | All cases were SP | 52% vs.. 76%^a^ 1999: 76% 2000: 74% 2001:50% 2002: 52% p<0.01 By number of PCV7 doses: 2–4 doses vs. ≤1 dose 41% vs. 70% p<0.01 | 32% vs.. 12% 1999: 12 2000: 13 2001:30 2002: 32 p<0.01 By number of PCV7 doses: 2–4 doses vs. ≤1 dose 35% vs. 18% p<0.01 | 13% vs. 10% 1999: 10 2000: 10 2001: 13 2002: 13 p<0.29 By number of PCV7 doses: 2–4 doses vs. ≤1 dose 19% vs. 10% p=0.05 | Subgroups: [underlined: Antibiotic within 30 days % of SP isolates that were nonsusceptible] 1999: 65% 2000: 65% 2001: 65% 2003: 56% p=.23 2–4 doses 67% ≤1 dose-63% p=.62
Eskola, 2009^51^ Comparisons in bold are significant at the p<0.05 level | 23% vs. 33% (p<0.001) | 27% vs.. 23% (p=0.02) Denominator: all AOM episodes | 32% vs.. 30% Denominator: all AOM episodes | 40% vs. 60% (p<0.001) Denominator: all S.pne isolates vaccine serotypes: 4, 6B, 9V, 14, 18c, 19F, 23F (also separately analyzed) | 46% vs. 23% p<0.001) Denominator: all S.pne isolates non-vaccine serotypes: 3, 11, 15, 16, 22, 33, 35, 38, and others combined: 7, 10, 12, 28, 34, pool G | 15% vs. 20% Denominator: all S.pne isolates vaccine-related serotypes: 6A, 9N, 18B, 19A, 23A (also separately analyzed)
Brook, 2009^49^ | 44% vs. 54% 1993–1998: 54% 2001–2006: 44% Proportion by Susceptibility: [underlined: Susceptible:] 1993–1998: 52% 2001–2006: 73% [underlined: Intermediate-Susceptibility] 1993–1998: 33% 2001–2006: 23% [underlined: Resistant] 1993–1998: 15% 2001–2006: 4% | 24% vs. 18% Proportion by Susceptibility: B-lactamase positive: 1993–1998: 67% 2001–2006: 50% B-lactamase negative: 1993–1998: 33% 2001–2006: 50% | 12% vs. 10% | Not reported | Not reported | S. pyogenes 10% vs. 14% | Methicillin-sensitive S. aureus 1993–1998: 8% 2001–2006: 8% Methicillin-resistant S. aureus 1993–1998: 0% 2001–2008: 10% p<0.05

Table Notes : PCV7 : Heptavalent pneumococcal vaccine ; PSSP: Penicillin sensitive SP; PNSP- Penicillin non-susceptible SP ; S. pne : staphylococcus pneumoniae

a (Vaccine serotype 19F did not decrease; molecular analyses and serologic data suggest that PCV7 may be less protective against 19F compared with other vaccine serotypes)

### Findings for Key Question II

In order to address this question, we searched for studies and RCTs that compared the organisms (bacterial and viral) that caused AOM in children who had received PCV7 to those in children who had not received PCV7. Two main types of studies would directly address this question: observational studies that take advantage of the time periods both before and after the licensure of PCV7 and RCTs of PCV7 efficacy.

This first group of studies consists of observational studies that either retrospectively or prospectively examine two separate cohorts of children, before and after 2000 (PCV7 was licensed in February 2000 and recommended for all children aged 2–23 months by the CDC Advisory Committee on Immunization Practices (ACIP) in June 2000).

We identified four such studies.46–49 (Table 4). Casey and Pichichero (2004) reported data based on a prospective study of children diagnosed with AOM with treatment failure (AOMTF) and persistent AOM at a suburban pediatric private practice in Rochester, New York. Between 1995 and 2003, middle ear fluid (MEF) was obtained by tympanocentesis for 551 patients (minimum age 2 months) with persistent AOM (otalgia and AOM signs after 48 hours of antibiotic treatment) or AOMTF (clinical failure within 30 days of antibiotic completion). None of the 195 children in the 1995–1997 cohort had received PCV7, 4% of the 204 children in the 1998–2000 cohort received at least one dose of PCV7, and 85% of the 152 children in the 2001–2003 cohort received at least one dose. In each successive cohort, the proportion of all isolates that were S. pneumoniae (SP) decreased significantly, with 44% of isolates identified as SP in the 1998–2000 cohort and 31% of the 2001–2003 cohort (p<0.017). Conversely, the proportion of isolates that were found to be H. influenzae (HF) increased significantly from 43% in the 1998–2000 cohort to 57% in the 2001–2003 cohort (p<0.012). In addition to the decrease in SP isolates and increase in HF isolates from 1998–2000 to 2001–2003, the authors report an increase in the proportion of SP that was penicillin-susceptible (58% and 72% p=0.017) and variation in the proportion of HF that were B-lactamase-producing (33% and 55%, p=0.44) from 1998–2000 to 2001–2003.

The second observational study described in Table 4 by Block (2004)46 reports a similar decrease in SP isolates after PCV7 introduction. In this study, 419 MEF specimens from 379 patients from a pediatric practice in a rural Kentucky area in the U.S. were examined. The researchers compared 336 isolates with positive cultures from 1992–1998 with 83 isolates from 2000–2003 (all had three or more vaccine doses). The proportion of isolates due to SP decreased over these two time periods (48% in 1992–1998 and 31% in 2000–2003; p=0.007), while the proportion of isolates from HF increased (41% in 1992–1998 and 56% in 2000–2003; p=0.01). In addition, among the SP isolates, vaccine serotypes decreased, while vaccine-related and non-vaccine serotypes increased significantly (because of an error in shipping/storage, two serotypes could not be analyzed).

This change over time in the serogroup composition of SP isolates was also found in the third observational study (Table 4). This study examined only the MEF specimens that were positive for SP among 505 episodes of AOM in children in five hospitals across four states.48 These SP-positive MEF specimens were obtained either from spontaneous otorrhea, myringotomy and/or tympanostomy tube placement, or tympanocentesis performed in children with AOMTF or in children with AOM in a clinical trial. Comparing specimens from 1999 to 2002, a significant decrease was reported in the proportion of SP isolates that were of a vaccine serogroup (76% in 1999 and 52% in 2002; p<0.01) while isolates from non-vaccine serogroups increased (12% in 1999; 32% in 2002, p<0.01). The authors of this study recognized a limitation to observational studies that retrospectively or prospectively rely on tympanocentesis performed in children with AOM for analysis of AOM bacteriology—in most cases, tympanocentesis is not performed in uncomplicated, non-recurrent, non-persistent cases of AOM. To address this limitation, the authors separately analyzed those AOM cases when tympanocentesis was not performed but MEF specimens were obtained by collection of spontaneous otorrhea. Results were similar to the entire sample; the proportion of greater SP isolates due to vaccine serotypes decreased and the proportion due to non-vaccine serotypes increased over time. Additionally, among the vaccine serotype isolates, the proportion that were penicillin non-susceptible increased (60% in 1999 to 100% in 2002, p<0.01).

The final observational study examined was smaller; it examined middle ear fluid from 50 children diagnosed with AOM with perforation (collected by aspiration with a syringe inserted through the TM perforation) between 1993 and 1998 with 50 children with the same diagnosis between 2001 and 2006. Ninety-two percent of children in the group from 2001–2006 had received PCV7. This study did not find changes in microbiology described above; however, the authors did find that methicillin-resistant S. aureus (MRSA) was significantly greater in children from the later time period. There was no MRSA isolated from middle ear fluid samples during 1993–1998, but there were five MRSA isolates in middle ear fluid samples collected from 2001–2006.^49^ The three previous studies described above either did not report S. aureus isolates,46, 48 or did not report on methicillin resistance of S. aureus isolates.

Two RCTs addressed our study question directly as well (Table 5). Eskola (2001)51 report the results of a double-blind RCT of the efficacy of PCV7. In 1,662 children with 2,596 episodes of AOM, investigators collected MEF and found that 685 were positive for SP (33% in control group; 23% in the PCV7 group). Findings comparing the intervention (PCV7) and control groups are similar to the findings in the observational studies described above. Vaccine serotype isolates were less prevalent in the intervention group isolates than the control group isolates (40% vs. 60%), while non-vaccine serotype isolates were more prevalent in the intervention group isolates than in the control group (46% vs. 23%). There were also fewer isolates from vaccine-related serotypes in the intervention vs. control group. The proportion of AOM episodes caused by HF (27% vs. 23%) was greater for the vaccine group and the proportion of AOM episodes caused by M. catarrhalis (MC) (32% vs. 30%) was similar across both groups.

Another RCT for vaccine efficacy studied recurrent AOM in previously unvaccinated children with at least two episodes of AOM in the previous year.50 The authors report fewer vaccine serotype SP isolates and more non-vaccine serotype SP isolates in the intervention (PCV7) group compared with the control group. There were no significant differences in the numbers of HF or MC isolates between the two groups; however, the sample size was very small, with 60 and 54 positive culture isolates in intervention and control groups, respectively. Further, a majority of MEF specimens were obtained from spontaneous otorrhea, calling into question the higher rate of S. aureus and P. aeruginosa cultures found in the intervention group.

### Findings According to Antibiotic History

As part of our review, we were also asked to analyze changes in causative agents among the following subpopulations: children who have never had antibiotics for any reason; children who have had antibiotics for any reason, including ROM, persistent otitis media or relapse of AOM; children with unknown antibiotic history. We found that only a few studies separately analyzed data for these subpopulations.

The observational study by Casey, et al47 specifically examined patients with AOMTF or persistent AOM; the study by McEllistrem and colleagues48 performed a subgroup analysis of patients with AOM and spontaneous drainage to look for any differences in the microbiology patterns for children with uncomplicated AOM; and finally, the study by Block and colleagues46 examined differences in SP resistance in otitis-prone children before and after the introduction of PCV7.

In summary, these six studies shed some light on the first part of our study question. Since the introduction of PCV7, these studies report that HF has become more prevalent as a causative agent of AOM, although SP remains an important agent as well. The introduction of the vaccine has also resulted in a greater proportion of non-vaccine serotypes and a smaller proportion of the vaccine serotypes. The overall quality of evidence for this Key Question is considered high for the conclusion that use of PCV7 vaccine has resulted in shifts in the prevalence of causative agents, meaning further research is very unlikely to change our confidence in the estimate of effect. The quality of evidence is insufficient for the special populations (such as patients with recurrent or persistent AOM) since we found virtually no evidence about the vaccine‘s effect on these special populations.

## Key Question III What is the Comparative Effectiveness of Different Treatment Options for Treating Uncomplicated Acute Otitis Media in Average Risk Children?

### Description of the Studies

Initial screening of the titles identified for Key Questions III–VI found 147 studies reporting on trials that appeared potentially relevant, and full-text articles were ordered. Of the 147 articles that underwent further screening, 62 were accepted. A total of 85 articles were rejected; these articles and the reasons for rejection are listed in Appendix D. The studies that were accepted for analysis are described in the Evidence Table in Appendix C.

### Findings for Key Question III

The present review updates the 2001 AOM systematic review report, which addressed the natural history of uncomplicated AOM, the efficacy of antibiotic vs. no antibiotic therapy, and the comparative efficacy of various antibiotic regimens, including amoxicillin or trimethoprim-sulfamethoxazole vs. other antibiotics, high-dose vs. standard-dose amoxicillin or amoxicillin-clavulanate, high-dose amoxicillin twice daily vs. standard-dose amoxicillin three times daily, and short-term vs. long-term antibiotic therapy. That review found no significant differences in clinical failure rates between the antibiotic regimens that were compared. The findings of that review that are relevant to specific treatment regimen comparisons are presented in the relevant sections below. Tables 6a-e summarize the studies that addressed the comparative effectiveness of different treatment options for uncomplicated AOM in average-risk children that were identified in the 2001 report, and further details can be found in the evidence and meta-analysis tables in that report.3 Table 6f summarizes key findings of the comparisons in the 2001 report, those included only in the present report, and those in both reports.

Table 6a Randomized Controlled Trials from Marcy (2001)13 Addressing Comparative Effectiveness of Different Treatment Options for Treating Uncomplicated Acute Otitis Media in Average Risk Children

Author Year | RCT Quality^a^ | AOM Definition^b^ | Intervention^c^ | Time | Place | Age
Appelman, 1991; Claessen, 1994 | [1,1,1,1,1] | [0,0,1] | amox-clav vs. placebo | 9/86–4/90 | Netherlands | 6 mo–<12 yr
Burke, 1991 | [1,1,0,1,1] | [0,0,1] | amox vs. control | 10/86–4/87; 10/87–4/88; 10/88–4/89 | Great Britain | 3-<10 yr
Halsted, 1967; 1968 | [1,1,1,1,1] | [1,0,0] | amp vs. pcn G-sulfisoxazole vs. placebo | 7/65–3/66 | Cleveland, OH | 2–66 mo
Howie, 1972 | [1,0,0,0,0] | [1,0,0] | triple sulfa vs. ery vs. amp vs. ery-triple sulfa vs. placebo | 12/68–7/70 | Alabama | <=2.5 yr
Kaleida, 1991 | [1,1,0,0,0] | [1,0,0] | amox vs. myringotomy vs. amox with myringotomy vs. placebo | 5/81–8/85 | Pittsburgh, PA | 7 mo–12 yr
Laxdal, 1970 | [1,0,0,1,0] | [0,0,0] | amp vs. pcn vs. symptomatic treatment | 1/66–9/68 | Canada | <15 yr
Mygind, 1981 | [1,1,1,0,0] | [0,1,1] | pcn V vs. placebo | 11/77–4/78 | Denmark | 1–10 yr
Thalin, 1985 | [1,1,0,1,1] | [0,0,0] | pcn V vs. placebo | 7/84–6/85 | Sweden | 2–15 yr
van Buchem, 1981 | [1,1,1,0,1] | [0,0,0] | myringotomy vs. amox vs. amox plus myringotomy vs. placebo | 1/79–5/79; 10/80–3/81 | Netherlands | 2–12 yr
Barnett, 1997 | [1,0,1,1,0] | [1,0,0] | ceftriaxone vs. tmp-smx | 2/91–4/94 | Boston | 3 mo–3 yr

a Jadad study quality score components (1=present; 0=not present): randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

b AOM definition components (1=required; 0=not required): MEE; rapid onset; acute inflammation

c amox=amoxicillin; clav=clavulanate; amp=ampicillin; pcn=penicillin; triple sulfa=triple sulfonamide; ery=erythromycin; tmp-smx=trimethoprim-sulfamethoxazole

Table 6b Randomized Controlled Trials from Marcy (2001)13 Addressing Other Antibiotic vs. Amoxicillin or Trimethoprim-Sulfamethoxazole

Author, Year | RCT Quality^a^ | AOM Definition^b^ | Intervention^c^ | Time | Place | Age
Barnett, 1997 | [1,0,1,1,0] | [1,0,0] | ceftriaxone vs. tmp-smx | 2/91–4/94 | Boston | 3 mo–3 yr
Bass, 1967 | [1,1,0,1,0] | [0,0,0] | oxytetracycline vs. procaine pcn & benzathine pcn G plus sulfisoxazole vs. pcn V plus sulfisoxazole vs. amp | 1/66–5/66 | ? | 2 mo–12 yr
Bass, 1973 | [1,1,0,1,0] | [0,0,0] | pcn V vs. pcn V plus sulfa vs. ery vs. amp | 11/68–8/71 | Hawaii | 2 mo–12 yr
Berman, 1983 | [1,1,1,0,0] | [1,0,0] | amox vs. cefaclor | 6/80–3/82 | Denver, CO | <3 mo
Blumer, 1984 | [1,1,1,0,0] | [1,0,0] | cefaclor vs. tmp-smx | ? | Cleveland, OH | 3 mo–7 yrs
Brodie, 1990 | [1,0,1,0,0] | [0,0,0] | cefuroxime vs. amox | ? | United Kingdom | 3 mo–12 yr
Coles, 1993 | [1,0,1,0,0] | [0,0,0] | | 7/91–1/92 | United Kingdom | 1–12yrs
Feigin. 1973 | [1,0,1,1,0] | [0,0,0] | clindamycin vs. amp | 3/70–12/71 | St. Louis, MS | 3mo–10yr
Feldman, 1990 | [1,1,1,1,1] | [1,0,1] | tmp-smx vs. amox-clav | 1987–1988 | Canada | 1–14 yrs
Foshee, 1992 | [1,1,1,0,1] | [1,0,1] | loracarbef vs. amox | 10/88–3/90 | Finland; Iceland; Netherland | 6m–12y
Giebink, 1984 | [1,0,1,1,0] | [1,0,0] | cefaclor vs. amox | ? | Minneapolis, MN | 3mo–17yrs
Green, 1993 | [1,1,1,0,1] | [0,0,1] | ceftriaxone vs. amox | 9/90–6/91 | California | 5mo–5yrs
Halsted, 1967; 1968 | [1,1,1,1,1] | [1,0,0] | amp vs. pcn G-sulfisoxazole vs. placebo | 7/65–3/66 | Cleveland, OH | 2–66 mo
Howie, 1972 | [1,0,0,0,0] | [1,0,0] | triple sulfa vs. ery vs. amp vs. ery-triple sulfa vs. placebo | 12/68–7/70 | Alabama | <=2.5 yr
Jacobson, 1979 | [1,1,1,1,1] | [1,0,0] | Cefaclor vs. amox | 5/77–8/78 | Utah | 1–12yrs
Johnson, 1991 | [1,0,0,0,0] | [1,0,1] | cefuroxime vs. amox | 10/86–6/89 | Cleveland, OH | 8wk–13yrs
Kara, 1998 | [1,0,0,0,0 | | amox vs. cefuroxime | 9/97 – 5/97 | Turkey | 6m–6yr
Laxdal, 1970 | [1,0,0,1,0] | [0,0,0] | amp vs. pcn vs. symptomatic treatment | 1/66–9/68 | Canada | <15 yr
Leigh, 1989 | [1,0,1,0,0] | [0,0,0] | cefixime vs. amox | ? | United Kingdom | 6mo–16 yrs
Lenoski, 1968 | [1,0,1,1,0] | [0,0,0] | ery vs. ery plus triple sulfa vs. triple sulfa vs. amp | 8/66–8/67 | Los Angeles, CA | ?
Marchant, 1984 | [1,1,1,1,0] | [1,0,1] | cefaclor vs. tmp-smx | ? | Cleveland, OH | 2–24months
McLinn, 1979 | [1,0,0,0,0] | [1,0,0] | cephradine vs. amox | ? | Pennsylvania | 4mo–14yrs
McLinn, 1980 | [1,0,0,1,0] | [1,0,0] | cefaclor vs. amox | ? | Pennsylvania | 1mo–11yrs
McLinn, 1987 | [1,0,1,1,0] | [1,0,1] | cefuroxime vs. amox | 4/85–9/85 | United States | 6mo–11yr
Nassar, 1974 | [1,1,0,0,1] | [0,0,0] | cephalexin vs. amp | ? | England | under 12yrs
Nilson, 1969 | [1,1,1,1,0] | [1,0,0] | pcn V vs. pcn V plus sulfa vs. amp | 12/66–2/68 | Baltimore, MD | <3yr
Owen, 1993 | [1,0,1,0,0] | [1,0,1] | cefixime vs. amox | 10/87–3/88 | Texas | 2mo–6yrs
Ploussard, 1984 | [1,0,0,1,0] | [1,0,0] | cefaclor vs. amox | ? | ? | 5mo–5yr
Principi, 1991 | [1,0,0,1,0] | [1,0,1] | cefixime vs. amox | ? | Italy | <12yr
Pukander, 1993 | [1,0,1,0,0] | [1,0,0] | clarithromycin vs. amox | 12/90–3/92 | Finland | 1–12yrs
Rodriguez, 1985 | [1,1,1,1,1] | [1,0,0] | ery vs. amox | 2/80 – 5/82 | Washington, DC | 2mo–17yr
Scholz, 1998 | [1,1,1,0,1] | [1,0,0] | ery vs. amox | 5/95–1/96 | Germany | 6mo–11yr
Stechenberg, 1976 | [1,0,1,0,0] | [0,0,0] | cephalexin vs. amp | 7/73–7/75 | St. Louis, MS | 3mo–11.6yr
Varsano, 1988 | [1,1,1,0,1] | [1,0,1] | ceftriaxone vs. amox | ? | Israel | 6mos–8yrs

a Jadad study quality score components (1=present; 0=not present): randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

b AOM definition components (1=required; 0=not required):MEE; rapid onset; acute inflammation

c amox=amoxicillin; clav=clavulanate; amp=ampicillin; pcn=penicillin; triple sulfa=triple sulfonamide; ery=erythromycin; tmp-smx=trimethoprim-sulfamethoxazole

Table 6c Randomized Controlled Trials from Marcy (2001)13 Addressing High-Dose Amoxicillin vs. Standard-Dose Amoxicillin

Author Year | RCT Quality^a^ | AOM Definition^b^ | Intervention^c^ | Time | Place | Age
Bottenfield, 1998 | [1,0,0,0,0] | [0,0,0] | Amox-clav high dose vs. low dose | 12/96–2/97 | USA | 3mo – 12yr

a Jadad study quality score components (1=present; 0=not present): randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

b AOM definition components (1=required; 0=not required):MEE; rapid onset; acute inflammation

c amox=amoxicillin; clav=clavulanate; amp=ampicillin; pcn=penicillin; triple sulfa=triple sulfonamide; ery=erythromycin; tmp-smx=trimethoprim-sulfamethoxazole

Table 6d Randomized Controlled Trials from Marcy (2001)13 Addressing Twice a Day High-Dose Amoxicillin Therapy vs. Three Time a Day Amoxicillin

Author Year | RCT Quality^a^ | AOM Definition^b^ | Intervention^c^ | Time | Place | Age
Principi, 1986 | [1,0,1,0,0] | [1,0,1] | amox twice vs. three times daily | 10/84–2/85 | Italy | 6mo–12yrs

a Jadad study quality score components (1=present; 0=not present): randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

b AOM definition components (1=required; 0=not required):MEE; rapid onset; acute inflammation

c amox=amoxicillin; clav=clavulanate; amp=ampicillin; pcn=penicillin; triple sulfa=triple sulfonamide; ery=erythromycin; tmp-smx=trimethoprim-sulfamethoxazole

Table 6e Randomized Controlled Trials from Marcy (2001)13 Addressing Short- vs. Long-Term Antibiotic Therapy

Author Year | RCT Quality^a^ | AOM Definition^b^ | Intervention^c^ | Time | Place | Age
Adam, 1995 | [1,0,1,0,0] | [0,0,0] | cefpodoxime vs. cefaclor | ? | Germany | 3m–6yr
Arguedas, 1996 | [1,0,1,1,0] | [1,0,0] | azithromycin vs. amox-clav | ? | Costa Rica | 6m–12y
Arguedas, 1997 | [1,0,1,1,0] | [1,0,0] | azithromycin vs. clarithromycin | ? | Costa Rica | 6mo–12yrs
Aronovitz, 1996 | [1,0,1,0,0] | [1,0,0] | azithromycin vs. amox-clav | ? | USA | 2–15yrs
Bain, 1985 | [1,0,1,1,0] | [0,0,0] | amox 2 day vs. 7 day | winter 1983, 1984 | ? | 3–10 yrs
Barnett, 1997 | [1,0,1,1,0] | [1,0,0] | ceftriaxone vs. tmp-smx | 2/91–4/94 | Boston | 3 mo–3 yr
Bauchner, 1996 | [1,0,0,1,0] | [1,0,0] | ceftriaxone vs. amox-clav | 10/93–5/94 | USA | 3mo–6yrs
Boulesteix, 1995 | [1,0,1,0,0] | [0,0,0] | cefpodoxime vs. cefixime | 9/91–3/92 | France | 6m–6yr
Chamberlain, 1994 | [1,0,1,1,0] | [1,0,1] | ceftriaxone vs. cefaclor | ? | Washington, DC | 18mo–6yrs
Chaput de Saintongen, 1982 | [1,1,1,0,1] | [0,0,0] | amox 3 day vs. 10 day | Winter 1979, 1980 | England | 2–10yrs
Cohen, 1997 | [1,0,1,0,0] | [0,0,0] | cefpodoxime vs. amox-clav | 10/93–3/94 | France | 4mos–4.5yrs
Cohen, 1998 | [1,1,1,1,1] | [1,0,1] | amox-clav 5 day vs. 10 day | 11/94–6/96 | France | 4m–2.5yr
Daniel, 1993 | [1,0,1,0,0] | [1,0,1] | azithromycin vs. amox-clav | ? | European | 2–8yr
Gooch, 1996 | [1,0,1,0,0] | [1,0,1] | cefuroxime vs. amox-clav | ? | USA | 3mos–12yrs
Green, 1993 | [1,1,1,0,1] | [0,0,1] | ceftriaxone vs. amox | 9/90–6/91 | California | 5mo–5yrs
Hendrickse, 1988 | [1,1,1,1,1] | [1,0,1] | cefaclor 5 day vs. 10 day | ? | USA | 1mo–12yrs
Hoberman, 1997 | [1,0,1,0,0] | [0,0,0] | amox-clav 5 day vs. 10 day | 1/94–7/94 | USA & Canada | 2m–12yr
Ingvarsson, 1982 | [1,0,0,0,0] | [0,0,0] | pcn V 5 day vs. 10 day | 10/76–12/76; 2/77–4/77 | Sweden | 6m–7yr
Jones, 1986 | [1,1,1,0,1] | [0,0,0] | cefaclor 3 day vs. 7 day | Winter 1983 and 1984 | Great Britain | 3–10yrs
Kafetzis, 1997 | [1,0,1,0,0] | [0,0,1] | cefprozil 5 day vs. 10 day | ? | Greece | 2m–14.3yr
Kara, 1998 | [1,0,0,0,0] | [0,0,0] | amox vs. cefuroxime vs. ceftriaxone | 9/97 – 5/97 | Turkey | 6m–6yr
Khurana, 1996 | [1,0,1,0,0] | [1,0,0] | erythromycin vs. amox-clav | ? | USA | 6mo–12yrs
Leigh, 1989 | [1,0,1,0,0] | [0,0,0] | cefixime vs. amox | ? | United Kingdom | 6mo–16 yrs
McLinn, 1996 | [1,1,1,0,1] | [1,0,0] | azithromycin vs. amox-clav | ? | USA | 1–15yr
Meistrup-Larsen, 1983 | [1,1,0,0,1] | [0,1,1] | pcn 2 day vs. 7 day | 11/80–5/81 | Denmark | 1–10yrs
Pestalozza, 1992 | [1,0,0,0,0] | [0,0,1] | azithromycin vs. amox-clav | ? | Italy | 11mo–9 yrs
Ploussard, 1984 | [1,0,1,1,0] | [1,0,0] | cefaclor vs. amox | ? | ? | 5mo–5yr
Principi, 1995 | [1,0,1,0,0] | [1,0,1] | azithromycin vs. amox-clav | ? | Italy | <12yr
Puczynski, 1987 | [1,1,1,0,0] | [1,0,1] | amox vs. placebo | 5/84–2/85 | Chicago, IL | >2yrs
Rodriguez, 1996 | [1,0,1,0,0] | [0,0,0] | azithromycin vs. cefaclor | ? | Guatemala | 6mo–13yrs
Rubenstein, 1965 | [1,0,1,0,0] | [0,0,0] | benzathine pcn G plus procaine pcn vs. benzathine pcn G plus pseudoephedrine vs. benzathine pcn G plus triple sulfa vs. benzathine pcn G plus triple sulfa plus pseudoephedrine vs. tetracycline vs. tetracycline plus pseudoephedrine | 11/63–4/64 | Rochester, MN | <15yr
Schaad, 1993 | [1,0,1,0,0] | [0,0,0] | azithromycin vs. amox-clav | ? | Switzerland | 0.5–10.2 yrs
Simon, 1997 | [1,1,0,0,0] | [1,0,0] | ceftibuten 5 day vs. 10 day | ? | Kentucky | 6m–14yr
Stickler, 1967 | [1,0,1,1,0] | [0,0,0] | pcn vs. pcn plus antihistamine vs. pcn plus triple sulfa vs. pcn plus triple sulfa | ? | Rochester, MN | <15yr
Varsano, 1988 | [1,1,1,0,1] | [1,0,1] | ceftriaxone vs. amox | ? | Israel | 6ms–8yrs
Varsano, 1997 | [1,0,1,1,0] | [1,0,1] | ceftriaxone vs. amox-clav | ? | Israel | 4mo–6yr

a Jadad study quality score components (1=present; 0=not present): randomization mentioned; double-blind mentioned; dropouts described; randomization appropriate; double-blinding appropriate.

b AOM definition components (1=required; 0=not required): MEE; rapid onset; acute inflammation

c amox=amoxicillin; clav=clavulanate; amp=ampicillin; pcn=penicillin; triple sulfa=triple sulfonamide; ery=erythromycin; tmp-smx=trimethoprim-sulfamethoxazole

Table 6f Comparative Effectiveness of Different Treatment Options for Treating Uncomplicated Acute Otitis Media in Average Risk Children in the 2001 Report and the Present Report

| 2001 Report | | 2009 Update
Comparison | Number of trials | Success rate difference (95% CI) | Number of new trials | Total number of trials | Success rate difference | Conclusion^a^
Drug vs. placebo, wait-and-see, and/or prescription-to-hold
Ampicillin or amoxicillin vs. placebo | 5 | 12% (−22%, −3%) | 2 | 7 | 12%(5%, 18%) | Ampicillin or amoxicillin was more successful than placebo
Amoxicillin tid (7d) vs. prescription-to-hold) 2 | 0 | N/A | 1 | 1 | 16% (6, 26) | Amoxicillin is more successful than prescription-to-hold (defined as success at day 3)
Antibiotic vs. prescription-to-hold)2 | 0 | N/A | 1 | 1 | 3% (−8, 14) | Inconclusive (defined as otalgia at day 4–6)
Amoxicillin 90mg/kg/d bid (10d) vs. wait-and-see 3 | 0 | N/A | 1 | 1 | 15% (6, 24) | Amoxicillin was more successful (defined as success at day 12)
PcV vs. wait-and-see 3 | 0 | N/A | 1 | 1 | −3% (−14, 8) | Inconclusive (defined as success at day 14)
Drug vs. drug
Ampicillin or amoxicillin vs. Ceftriaxone | 3 | 3% (−8%, 2%) | 1 | 4 | 0% (−7%, 7%) | Inconclusive
Amoxicillin 50mg/kg/d (bid, 10d) vs. erythromycin 40mg/kg/d (bid, 10d) 4 | 0 | N/A | 1 | 1 | 0.6% (−3, 4) | Treatments were equivalent (when success defined as freedom from recurrence day 31–40)
Amoxicillin-clavulanate vs. amoxicillin sulbactam 80mg/kg/d; (bid 10d) | 0 | N/A | 1 | 1 | 0% (−3.3, 3.3) | Treatments were equivalent (success d.12–14)
Amoxicillin-clavulanate (>6 yrs old: 250 mg tid x 7d; < 6 yrs old: 125 mg tid x7d) vs. cefaclor (125 or 250 mg tid x 7 d) 5 | 0 | N/A | 1 | 1 | 13% (5, 21) | Amoxicillin-clavulanate was more effective than cefaclor (success at day 28–34, as defined by clinical symptoms but not by culture)
Cefaclor vs. trimethoprim-sulfamethoxazole | 3 | −6% (−13, 2) (success at less than 14 d) | 0 | 3 | N/A | Inconclusive (defined as success at less than day 14); no new data but using MCID
Cefaclor vs. Ampicillin or amoxicillin | 4 | −5% (−16, 6) (success at d. 3–7) | 0 | 4 | N/A | Inconclusive (defined as success at day 3–7); no new data but using MCID
Cefixime vs. Ampicillin or amoxicillin | 4 | 0.1% (−3.9, 4.2) (success at d. 10–15) | 0 | 4 | N/A | Treatments were equivalent; no new data
Penicillin vs. ampicillin or amoxicillin | 3 | −5% (−11, 2) (success at d. 7–14) | 0 | 3 | N/A | Inconclusive (defined as success at day 7–14); no new data but using MCID
High vs. Low Dose Treatment
Amoxicillin-clavulanate >60mg/kg/d vs. amoxicillin-clavulanate 40mg/kg/d | 1 | 1.5% (−3, 13) | 0 | 1 | N/A | Inconclusive(defined as persistent clinical cure with no recurrence at follow-up)
High-dose amoxicillin bid vs. lower-dose amoxicillin tid | 1 | −4% (−14, 7) | 0 | 1 | N/A | Inconclusive (defined as success at day 15)t; no new data
Amoxicillin-clavulanate 45/64 mg/kg/day/bid for 7–10 days vs. Amoxicillin-clavulanate 40/10 mg/kg/day/tid for 7–10 days 6 | 0 | N/A | 1 | 1 | 0.1% (−4.8, 4.6) | Treatments were equivalent (success d. 7–12)
Short vs. Long Treatment Duration^b^
Ampicillin or Amoxicillin (7–10d) vs. Ceftriaxone (1 dose) | 3 | 3% (−2%, 9%) (success rate at 5–10d) | 1 | 4 | 0% (−7%, 7%) | Inconclusive
Amoxicillin-Clavulanate (7–10d) vs. Ceftriaxone (1 dose) | 2 | No meta-analysis | 3 | 5 | 3% (−2%, 7%) | Inconclusive
Cefaclor (7–10d) vs. Azithromycin (<5d) | 1 | N/A | 2 | 3 | −1% (−4%, 3%) | Treatments were equivalent
Amoxicillin (7d) vs. Azithromycin (1 dose) | 0 | N/A | 1 | 1 | 1% (−1%, 4%) | Treatments were equivalent (defined as no new pain between day 1 and 11)
Amoxicillin-clavulanate (7–10d) vs. Azithromycin (<5d) | 5 | 2% (−1, 5%) (success at 10–14d) | 4 | 9 | −0.3% (−6%, 6%) | Inconclusive
Amoxicillin-clavulanate 45/6.4 mg/kg/d (bid, 10d) vs. azithromycin 10 mg/kg/d (qd for 1 day), 5 mg/kg/d (qd for 4d) 7 | 0 | N/A | 1 | 1 | 26% (6,36) | Longer-term amoxicillin-clavulanate is more successful than shorter-term azithromycin (at d. 12–14, when pathogen is H. influenzae)
Amoxicillin-clavulanate 45/6.4 mg/kg/d (bid, 10d) vs. azithromycin 10 mg/kg/d (qd for 3 day) 52 | 0 | N/A | 1 | 1 | −20% (−34, −6) | Amoxicillin-clavulanate was worse than azithromycin (cure defined as negative culture)
Cefaclor 50mg/kg/d; bid 5 d) vs. cefaclor 40mg/kg/d; bid 10d) | 0 | N/A | 1 | 1 | 0.7% (−3.5–4.9) | Treatments were equivalent

Table Notes: bid twice a day; CI confidence intervals; d day(s); kg kilograms (body weight); mg milligrams; NNT number needed to treat; PcV phenoxymethylpenicillin; qd once a day;

a Confidence intervals falling within the zone of indifference were considered to establish evidence of no difference, and confidence intervals outside the zone of indifference were considered to establish difference. If the confidence intervals crossed into the zone of indifference, an effect (positive or negative) of the treatment option on the outcome could not be established (inconclusive). For the 2010 systematic review, we used a zone of clinical indifference of +/− 5% for the difference in success rate between two treatment options.

b Short vs. long term duration refers to the length of treatment from the patient perspective, rather than from the perspective of drug action.

We also identified seven new or updated systematic reviews of the comparative effectiveness of different options for treating uncomplicated AOM in average-risk children (Table 7 and Appendix I),53–59 in addition to the four systematic reviews that we reported on in the 2001 report.53, 60–64 Table 7 summarizes the key features of these reviews; the findings of these reviews are summarized in the relevant sections below or at the end of the descriptions of our pooled findings.

Table 7 Review Articles Examining Comparative Effectiveness of Treatment Strategies in Uncomplicated Acute Otitis Media^a^

Author (year) (quality) b | Review focus | Databases (included dates) | Study design | Target population | Outcomes | Number of trials and participants | Author’s highlight conclusion
Marcy, 2001^13,c^ (y,y,y,y,y,y, y,y,y,y,n) | natural history antibiotics (ab) vs. no ab ab regimen | CENTRAL (TCL, through Mar 1999), MEDLINE (1966–Mar 1999), HlthSTAR (1975–Mar 1999), IPA International Pharmaceutical Abstracts (1970–Mar 1999), CINAHL (1982–Mar 1999), BIOSIS (1970–Mar 1999), and EMBASE (1980–Mar 1999); hand search | RCT; Cohort, for natural history | AOM 4wk–18y | Clinical failure; adverse effects | 80 trials total | Rx with amp/amox ↓ clinical failure by 12% vs. no a; ab regimen outcomes not different; cefixime & amoxicillin- clavulanate ↑ adverse effects
Rosenfeld, 1994^61^ (y,y,n,y,n,y, y,y,y,n,n) | ab vs. no ab ab regimen | MEDLINE (Jan 1966–Jun 1992); Current Contents (3 months through Jun 29, 1992); hand search | RCT | AOM 4wk–18y | Clinical response; MEE presence | 33 trials total | ab effect modest but significant; no significant difference between ab regimens studied
Damoiseaux, 1998^62^ (y,n,y,y,n,y, y,y,n,n,n) | ab vs. no ab | MEDLINE (1966–Jan 1997); EMBASE (1974–Jan 1997); hand search | RCT | AOM <2 years old | Clinical resolution within 7d | 4 trials 416 children | No significant difference between ab and no ab in <2y olds
Kozyrskyj, 2000^53^ (y,y,y,y,y,y, y,y,y,y,n) | ab <7d vs. ≥7d | MEDLINE (Jan 1966–Jul 1997); EMBASE (Jan 1966–Jul 1997); Science Citation Index (Mar 1998); Current Contents (Mar 1998); hand search | RCT | AOM 4wk–18y | Clinical resolution 31d & 1–3m; relapse; recurrence | 32 trials total | ab 5d→effective Rx for AOM
Glasziou, 2004^54^ (y,y,y,y,y,y, y,y,y,n,n) | ab vs. no ab | CENTRAL (1966–Jan 2000; TCL, issue 1, 2003); Current Contents (1966–Jan 2000); Index Medicus (1958–1965); MEDLINE (Jan 2000–Mar 2003); EMBASE (Jan 1990–Mar 2003); hand search | RCT | AOM Children, age not specified | Severity and duration of pain; mid- to long-term hearing problems; adverse effects; recurrent attacks | 8 trials total | ab of small benefit for AOM Rx
Foxlee, 2006^55^ (y,y,y,y,y,y, y,y,y,n,n) | topical analgesia Subgroups: <2y vs. ≥2y ; concurrent ab | CENTRAL (TCL, issue 2, 2006); MEDLINE (1966–May 2006); EMBASE (1990–Dec 2005); LILACS (1982–Sep 2005); hand search | RCT or quasi- RCT | AOM without perforation in Adults and children | Pain severity and duration; parental satisfaction; days missed from school or work; adverse events | 4 trials total | evidence insufficient to make conclusions on topical analgesia effectiveness
Rovers, 2006^56^ (y,n/a,n,n,n,y,y,y,y,y,n) | ab vs. no ab Subgroups: <2y vs. ≥2y; laterality; otorrhea | CENTRAL; PubMed; EMBASE (dates not specified) | RCT | AOM 0–12 years | Pain &/or fever 3–7d | 6 trials total | ab beneficial for <2 year old with bilat AOM & AOM with otorrhea
Spurling, 2007^57^ (y,y,y,n,y,y, y,y,y,y,n) | Delayed (>48 hrs) ab vs. immediate ab | CENTRAL (TCL, issue 1, 2004; TCL, issue 4, 2006); MEDLINE (Jan 1966–Jan 2007); EMBASE (1990–Jan 2007); Current Contents (1998–Jan 2007) | RCT | Respiratory tract infections All ages (For identified AOM studies 6m–12y) | Clinical outcomes; ab use; patient satisfaction; health- seeking behaviors; alternative therapies (For identified AOM studies pain, malaise, and fever) | 2 trials total for AOM in children | immediate ab→ improved pain and malaise on day 3; delayed ab→diarrhea reduced (thought not an a priori outcome of this review)
Coleman, 2008^58^ (y,y,y,y,y,y, y,y,y,y,n) | decongestant &/or antihistamine | CENTRAL (TCL, issue 2, 2001; TCL, issue 3, 2003; TCL, issue 2, 2007); MEDLINE (Jan 1966–May 2007); EMBASE (Jan 1990–May 2007); hand search | RCT | AOM <18y | Clinical resolution at 2wk, 1wk, 4wk; symptom resolution; medication side effects; AOM complications | 15 trials total | lack of benefit for decongestant &/or antihistamine; increased risk of side effects
Thanaviratananich, 2008^59^ (y,y,y,y,y,y, y,y,y,y,y) | amox or amox-clav once or twice daily vs. three times daily | CENTRAL (TCL, issue 1, 2008); MEDLINE (Jan 1950–Mar 2008); EMBASE (1974–Mar 2008); Science Citation Index (2001–Mar 2008); NLM Gateway (HSR Project) (Mar 2008); hand search | RCT | AOM ≤12y | Clinical cure at end of antibiotic therapy, i.e. 7d and 14 d, with respect to otalgia, fever, bacteriologic cure; also, clinical cure during therapy and post- treatment, recurrent OM, acute mastoiditis, adverse reactions | 6 trials total | evidence appears biased so no data pooling performed; no firm conclusions

a Abbreviations: ab=antibiotic; amox-clav=amoxicillin-clavulanate; CENTRAL=Cochrane Central Register of Controlled Trials; CINAHL=Cumulative Index to Nursing & Allied Health Literature; HlthSTAR=HealthSTAR; IPA=International Pharmaceutical Abstracts; MEE=middle ear effusion; Rx=treatment; TCL=The Cochrane Library

b AMSTAR quality criteria (Shea, Grimshaw, Wells, et al., 2007)

1. Was an ‘a priori’ design provided?
2. Was there duplicate study selection and data extraction?
3. Was a comprehensive literature search performed?
4. Was the status of publication (i.e. grey literature) used as an inclusion criteria?
5. Was a list of studies (included and excluded) provided?
6. Were the characteristics of the included studies provided?
7. Was the scientific quality of the included studies assessed and documented?
8. Was the scientific quality of the included studies used appropriately in formulating conclusions?
9. Were the methods used to combine the findings of studies appropriate?
10. Was the likelihood of publication bias assessed?
11. Was the conflict of interested stated?

c Marcy (2001) is the 2001 AHRQ AOM systematic review that is being updated.

A total of 46 RCTs (published since the 2001 AOM report) that compared the effectiveness of treatment options in uncomplicated AOM were newly identified for this review update. They encompassed different antibiotics, different regimens, and different outcomes. The number of articles for each comparison for each reported outcome measure is provided in Table 8. These 46 trials were added to the trials identified in the 2001 AOM report (Tables showing the numbers of articles included from the 2001 AOM report as well as the articles included in these analyses are provided in Appendix G). We identified the treatment comparisons that involved three or more articles and conducted meta-analysis to pool the data for each. The following comparisons had three or more studies on the treatment success rate:

- Ampicillin or amoxicillin vs. placebo
- Ampicillin or amoxicillin vs. ceftriaxone (single dose)
- Amoxicillin-clavulanate (7–10 days) vs. ceftriaxone (single dose)
  Amoxicillin-clavulanate (7–10 days) vs. Azithromycin (≤5 days)
- Azithromycin (<5 days) vs. cefaclor (7–10 days)
- Antibiotics vs. placebo

Findings for subgroups of patients are reported in the response to Key Question 5.

Table 8 Listing of Treatment Option Comparisons and Outcomes

Comp# | Comparison | Author, Year | Tx success/failure^a^ | Invasive infection^b^ | Bacteriologic cure | Disease recurrence | Adverse effects | Quality of life | Parent Satisfaction | Cost | Other^c^
1 | Amox vs. Amox+Fenspiride | Zielnik- Jurkiewicz, 2005^65^ | 1
2 | Amox vs. Azithromycin | Arguedas, 2005^66^ | 1 | | | 1 | 1
3 | Amox vs. Azithromycin | Morris, 2010^67^ | 1 | | | | | | | | 1
4 | Amox vs. Ceftriaxone | Zhang, 2003^68^ | 1
5 | Amox-clav vs. Amox-sulbactam | Casellas, 2005^69^ | 1 | | 1 | 1 | 1
6 | Amox-clav vs. Azithromycin | Dagan, 2000^7^ | 1 | | 1 | | 1
7 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 1 | | | | 1
8 | Amox-clav vs. Azithromycin | Guven, 2006^52^ | 1 | | 1 | 1 | 1
9 | Amox-clav vs. Azithromycin | Biner, 2007^71^ | 1 | | | 1 | 1
10 | Amox-clav vs. Cefaclor | Subba Rao, 1998^5^ | 1 | | 1 | 1 | 1
11 | Amox-clav vs. Cefdinir 7mg | Block, 2000^72^ | 1 | | | | 1 | | | | 1
12 | Amox-clav vs. Cefdinir 14mg | Block, 2000^72^ | 1 | | | | 1 | | | | 1
13 | Amox-clav vs. Cefdinir 7mg | Adler, 2000^73^ | 1 | | | 1 | 1
14 | Amox-clav vs. Cefdinir 14mg | Adler, 2000^73^ | 1 | | | 1 | 1
15 | Amox-clav vs. Cefdinir | Cifaldi, 2004^74^ | | | | | | | 1 | 1 | 1
16 | Amox-clav vs. Cefdinir | Block, 2004^75^ | 1 | | | | 1 | | 1 | 1 | 1
17 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 1 | | | | 1
18 | Amox-clav vs. Ceftriaxone | Cohen, 1999^77^ | 1 | 1 | 1 | | 1 | | | | 1
19 | Amox-clav vs. Ceftriaxone | Wang, 2004^78^ | 1 | | | | 1
20 | Amox-clav vs. Ceftriaxone | Biner, 2007^71^ | 1 | | | 1 | 1
21 | Amox-clav 40 mg vs. Cefuroxime | Pessey, 1999^79^ | 1 | | 1 | | 1
22 | Amox-clav 80 mg vs. Cefuroxime | Pessey, 1999^79^ | 1 | | 1 | | 1
23 | Amox-clav vs. Ciprodex drops | Dohar, 2006^80^ | 1 | | 1 | | 1
24 | Azithromycin vs. Cefaclor | Dagan, 2000^81^ | 1 | | 1
25 | Azithromycin vs. Cefaclor | Oguz, 2003^82^ | 1 | | | 1 | 1
26 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 1 | | | | 1 | | 1
27 | Azithromycin vs. Ceftriaxone | Biner, 2007^71^ | 1 | | | 1 | 1
28 | Cefaclor vs. Cefprozil | Carvalho, 1998^84^ | 1 | | | | 1
29 | Cefdinir vs. Cefprozil | Block, 2000^85^ | 1 | | | | 1
30 | Cefaclor vs. Cefpodoxime | Tsai, 1998^86^ | 1 | | | 1 | 1
31 | Amox vs. Wait- and-see | McCormick, 2005^3^ | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1
32 | PcV vs. Wait- and-see | Neumark, 2007^87^ | 1 | 1 | | | | | | 1 | 1
33 | Amox vs. Placebo | Damoiseaux, 2000^88^ | 1 | | | | 1
34 | Amox vs. Placebo | Le Saux, 2005^89^ | 1 | 1 | | | 1 | | | | 1
35 | Lidocaine drop vs. Placebo | Bolt, 2008^90^ | 1 | | | | 1
36 | Probiotic vs. Placebo | Hatakka, 2007^91^ | 1 | | | 1
37 | Homeopathic vs. Placebo | Jacobs, 2001^92^ | 1 | | | | 1
38 | Amox vs. PrescriptionHold | Little, 2001^2^ | 1 | | | | | 1 | 1 | 1
39 | Amox vs. PrescriptionHold | Little, 2006^93^ | 1 | | | | | 1
40 | Antibiotic vs. PrescriptionHold | Spiro, 2006^94^ | 1 | | | | 1 | | 1 | 1 | 1
41 | PrescriptionHold vs. Wait-and-see | Chao, 2008^95^ | 1 | | | | | | 1 | | 1
42 | Amox high vs. low dose | Garrison, 2004^96^ | 1 | | | 1 | 1 | | | | 1
43 | Amox-clav high vs. low dose | Pessey, 1999^79^ | 1 | | 1 | | 1
44 | Amox-clav high vs. low dose | Bottenfield, 1998^97^ | 1 | | | 1 | 1
45 | Amox-clav bid vs. tid | Damrikarnlert, 2000^6^ | 1 | | 1 | | 1 | | | | 1
46 | Cefdinir high vs. low dose | Adler, 2000^73^ | 1 | | | 1 | 1
47 | Cefdinir high vs. low dose | Block, 2000^72^ | 1 | | | | 1 | | | | 1
48 | Amox-clav 5-day vs. 10-day | Cohen, 1998^98^ | 1 | 1 | 1 | 1 | 1 | | | | 1
49 | Cefaclor 5-day vs. 10-day | Catania, 2004^99^ | 1 | | | 1 | 1
50 | Cefpodoxime 5- day vs. 10-day | Cohen, 2000^100^ | 1 | | | | 1
51 | Ceftriaxone vs. Ceftriaxone+Prednisolone | Chonmaitree, 2003^101^ | 1 | | | 1 | | | | | 1
52 | Ceftriaxone vs. Ceftriaxone+Antihistamine | Chonmaitree, 2003^101^ | 1 | | | 1 | | | | | 1
53 | Ceftriaxone vs. Ceftriaxone+Prednisolone+Antihistamine | Chonmaitree, 2003^101^ | 1 | | | 1 | | | | | 1
54 | Ceftriaxone+Prednisolone vs. Cetriaxone+Antihistamine | Chonmaitree, 2003^101^ | 1 | | | 1 | | | | | 1
55 | Ceftriaxone+Prednisolone vs. Ceftriaxone+Predinisolone+Antihistamine | Chonmaitree, 2003^101^ | 1 | | | 1 | | | | | 1
56 | Ceftriaxone+Antihistamine vs. Ceftriaxone+Predinisolone+Antihistamine | Chonmaitree, 2003^101^ | 1 | | | 1 | | | | | 1
57 | Otikon drops vs. Topical Anesthetic | Sarrell, 2001^102^ | 1 | | | | 1 | 1
58 | Anesthetic vs. Anesthetic+Amox | Sarrell, 2003^103^ | 1 | | | | 1
59 | Anesthetic vs. NHED | Sarrell, 2003^103^ | 1 | | | | 1
60 | Anesthetic vs. NHED+Amox | Sarrell, 2003^103^ | 1 | | | | 1
61 | Anesthetic+Amox vs. NHED | Sarrell, 2003^103^ | 1 | | | | 1
62 | Anesthetic+Amox vs. NHED+Amox | Sarrell, 2003^103^ | 1 | | | | 1
63 | NHED vs. NHED+Amox | Sarrell, 2003^103^ | 1 | | | | 1
| | | 61 | 5 | 13 | 24 | 47 | 4 | 7 | 6 | 19

a Included success/failure defined by improvement of signs and/or symptoms

b Included otologic complications

c Included healthcare utilization, compliance, tolerability, PE tube placement, need for change of treatment, duration of AOM

### Ampicillin or Amoxicillin vs. Placebo

The 2001 report found a rate difference of −12% (95% CI: −22%, −3; NNT=8, 95% CI: 4, 33) (in terms of clinical failure rate) favoring ampicillin/amoxicillin treatment vs. placebo based on five trials.104–108

One new meta-analysis was identified relevant to this comparison. A meta-analysis by Glasziou (2004) reported a possible benefit for antibiotics for pain at 2 to 7 days with an odds ratio of 0.57 (95% CI: 0.45, 0.73) with a number needed to treat of 15 children, but not for pain at 24 hours, abnormal tympanogram at one or three months, perforation, contralateral otitis, or late recurrence.109

Two new RCTs88, 89 were also identified that addressed the comparison of ampicillin or amoxicillin vs. placebo.

The ages of children in these studies ranged from 2 months to 14 years (no two studies included the same age range). The outcome assessed in the five older trials was success rate at days 2–18, whereas the outcome assessed in the two new trials was success rate at days 11–14. We considered the trials sufficiently clinically similar to justify pooling. Sample sizes ranged from 30 to 488. The studies reviewed for the initial report varied somewhat in their definitions of treatment success (including absence of persistent symptoms [fever, earache, crying, irritability], improvement, absence of otorrhea, cumulative clinical resolution); however, we felt these outcomes were sufficiently similar to pool. The Jadad quality scores of the five older studies were 5,2,1,4, and 2 out of 5; the two newer studies both had scores of 5.

The random effects pooled rate difference for clinical success by day 14 between ampicillin/amoxicillin and placebo was estimated at 12% (95% confidence interval [CI] 5%, 18%), and the NNT for a clinical success was nine (95% CI: 6, 20) (Figure 2 and Table 9). Using an a priori MCID of 5% (as will be used for all remaining comparisons in this report), ampicillin/amoxicillin has a significantly higher success rate than placebo.

Figure 2 Shrinkage Plot for Ampicillin/Amoxicillin vs Placebo for Treatment Success

Figure 2 depicts a shrinkage plot for ampicillin/amoxicillin versus placebo for treatment success. Seven studies note risk differences in percentages. The random effects pooled rate difference for clinical success by day 14 between ampicillin/amoxicillin and placebo was estimated at 12 percent; 95 percent confidence interval five percent and eighteen percent, and the number needed to treat for a clinical success was nine at a 95 percent confidence interval six percent and twenty percent.

Table 9 Ampicillin/Amoxicillin vs. Placebo; Outcome Indicator: Treatment Success Rate

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Success Rate (%) | Placebo Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Halsted, 1967^104^ | 2–66 mos | Success at day 14–18 | 30 | 27 | 92.0 | 100.0 | −8.0 | −20.9, 4.9
Laxdal, 1970^105^ | <15 yrs | Success at day 7 | 49 | 48 | 89.8 | 62.5 | 27.3 | 11.2, 43.4
Howie, 1972^106^ | <=2.5 yrs | Success at day 2–7 | 36 | 116 | 47.2 | 20.7 | 26.5 | 8.6, 44.4
Burke, 1991^107^ | 3–<10 yrs | Success at day 7 | 114 | 118 | 98.2 | 85.6 | 12.7 | 5.9, 19.4
Kaleida, 1991^108^ | 7 mo–12 yrs | No effusion at day 14 | 401 | 408 | 53.1 | 38.0 | 15.1 | 8.3, 21.9
Damoiseaux, 2000^88^ | 6 mos–2yrs | Clinical success at day 11 | 112 | 120 | 35.7 | 30.0 | 5.7 | −6.4, 17.8
Le Saux, 2005^89^ | 6 mos–5yrs | Clinical resolution at day 14 | 250 | 240 | 92.8 | 84.2 | 8.6 | 3.0, 14.3
Random effects estimates | | | 987 | 1071 | 73.2 | 60.2 | 11.5 | 5.0, 18.0
Test of heterogeneity Chi-square test value | | | | | | | 19.28
Test of heterogeneity Chi-square test p-value | | | | | | | 0.04
Test of heterogeneity I-squared | | | | | | | 68.9%
Number Needed to Treat (NNT) | | | | | | | 9 (6, 20)
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.77

The I^2^ statistic for this analysis was 68.9%, indicating the presence of unexplained heterogeneity, which could be due to the differences in the populations studied and/or research methods employed. Therefore, caution is advised in interpreting overall summary measures. Egger‘s test did not yield evidence suggestive of publication bias (p=0.77).

As a sensitivity analysis, we excluded the study by Halsted (1967),104 since it was clearly an outlier, in that the 95% confidence limits favored placebo far more strongly than any other individual study. The pooled analysis with the remaining six articles88, 89, 105–108 yielded a rate difference of 13% (95% CI: 8%, 19%), with seven children (95% CI: 5, 12) needing treatment with ampicillin or amoxicillin to gain a case of clinical success (Figure 3 and Table 10). The I^2^ statistic for the pooled analysis excluding the Halsted study was 61.9%. It is not clear why Halsted (1967) would introduce heterogeneity as it is from a similar time period as Laxdal (1970) and Howie (1972) and was of high quality, as were the studies by Burke (1991), Damoiseaux (2000), and LeSaux (2005).88, 89, 104–107

Figure 3 Shrinkage Plot for Ampicillin/Amoxicillin vs. Placebo for Treatment Success (Excluded Halsted 1967 Study)

Table 10 Ampicillin/Amoxicillin vs. Placebo; Outcome Indicator: Treatment Success Rate (Excluded Halsted 1967 Study)

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Success Rate (%) | Placebo Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Laxdal, 1970^105^ | <15 yrs | Success at day | 49 | 48 | 89.8 | 62.5 | 27.3 | 11.2, 43.4
Howie, 1972^106^ | <=2.5 yrs | Success at day 2–7 | 36 | 116 | 47.2 | 20.7 | 26.5 | 8.6, 44.4
Burke, 1991^107^ | 3–<10 yrs | Success at day 7 | 114 | 118 | 98.2 | 85.6 | 12.7 | 5.9, 19.4
Kaleida, 1991^108^ | 7 mo–12 yrs | No effusion at day 14 | 401 | 408 | 53.1 | 38.0 | 15.1 | 8.3, 21.9
Damoiseaux, 2000^88^ | 6 mos–2yrs | Clinical success at day 11 | 112 | 120 | 35.7 | 30.0 | 5.7 | −6.4, 17.8
Le Saux, 2005^89^ | 6 mos–5yrs | Clinical resolution at day 14 | 250 | 240 | 92.8 | 84.2 | 8.6 | 3.0, 14.3
Random effects estimates | | | 962 | 1050 | 70.1 | 53.5 | 13.4 | 8.3, 18.6
Test of heterogeneity Chi-square test value | | | | | | | 9.51
Test of heterogeneity Chi-square test p-value | | | | | | | 0.09
Test of heterogeneity I-squared | | | | | | | 47.4%
Number Needed to Treat (NNT) | | | | | | | 7 (5, 12)
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.18

As an additional sensitivity analysis, we pooled the four studies with a quality score of at least 3 of 5^88, 89, 104, 107^, which yielded a rate difference of 6% (95% CI: −1%, 13%) for a clinical success, which was about half that of the primary analysis and no longer met the conventional levels of statistical significance.88, 89, 104, 107 (Figure 4 and Table 11) Further excluding the study by Halsted (1967) which continued to be an outlier among these four articles, yielded a rate difference of 10% (95% CI: 6%, 14%) or a NNT of 10 (95% CI: 7, 18) for a clinical success without apparent heterogeneity (I^2^=0.0%) or publication bias.88, 89, 107 This sensitivity analysis modestly changed the NNT: 10 children needed treatment with ampicillin or amoxicillin to gain a case of clinical success, rather than nine as with the original seven articles.88, 89, 104–108 (Figure 5 and Table 12)

Figure 4 Shrinkage Plot for Ampicillin/Amoxicillin vs. Placebo for Treatment Success (Included Studies with Quality Score 3, 4, or 5)

Table 11 Ampicillin/Amoxicillin vs. Placebo; Outcome Indicator: Treatment Success Rate (Included Studies with Quality Score 3, 4 or 5)

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Success Rate (%) | Placebo Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Halsted, 1967^104^ | 2–66 mos | Success at day 14–18 | 25 | 21 | 92.0 | 100.0 | −8.0 | −20.9, 4.9
Burke, 1991^107^ | 3–<10 yrs | Success at day 7 | 114 | 118 | 98.2 | 85.6 | 12.7 | 5.9, 19.4
Damoiseaux, 2000^88^ | 6 mos–2yrs | Clinical success at day 11 | 112 | 120 | 35.7 | 30.0 | 5.7 | −6.4, 17.8
Le Saux, 2005^89^ | 6 mos–5yrs | Clinical resolution at day 14 | 250 | 240 | 92.8 | 84.2 | 8.6 | 3.0, 14.3
Random effects estimates | | | 501 | 499 | 80.1. | 75.2 | 6.4 | −0.6, 13.4
Test of heterogeneity Chi-square test value | | | | | | | 7.87
Test of heterogeneity Chi-square test p-value | | | | | | | 0.049
Test of heterogeneity I-squared | | | | | | | 61.9%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.26

Figure 5 Shrinkage Plot for Ampicillin/Amoxicillin vs. Placebo for Treatment Success (Included Studies with Quality Score 3, 4, or 5 (Excluded Halsted 1967 Study)

Figure 5 depicts a shrinkage plot for ampicillin/amoxicillin versus placebo for treatment success (Included Studies with Quality Score 3, 4, or 5 (Excluded Halsted 1967 Study). This sensitivity analysis modestly changed the number needed to treat to 10 children who needed treatment with ampicillin or amoxicillin to gain a case of clinical success, rather than nine as with the original seven articles.

Table 12 Ampicillin/Amoxicillin vs. Placebo; Outcome Indicator: Treatment Success Rate (Included Studies with Quality Score 3, 4 or 5 (Excluded Halsted 1967 Study)

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Success Rate (%) | Placebo Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Burke, 1991^107^ | 3–<10 yrs | Success at day 7 | 114 | 118 | 98.2 | 85.6 | 12.7 | 5.9, 19.4
Damoiseaux, 2000^88^ | 6 mos–2yrs | Clinical success at day 11 | 112 | 120 | 35.7 | 30.0 | 5.7 | −6.4, 17.8
Le Saux, 2005^89^ | 6 mos–5yrs | Clinical resolution at day 14 | 250 | 240 | 92.8 | 84.2 | 8.6 | 3.0, 14.3
Random effects estimates | | | 476 | 478 | 76.3 | 66.7 | 9.8 | 5.7, 13.8
Test of heterogeneity Chi-square test value | | | | | | | 4.69
Test of heterogeneity Chi-square test p-value | | | | | | | 0.48
Test of heterogeneity I-squared | | | | | | | 0.0%
Number Needed to Treat (NNT | | | | | | | 10 (7, 18)
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.26

The quality of evidence for this conclusion is moderate due to heterogeneity in the results of studies, with the higher quality studies reporting smaller benefits, meaning that further high quality research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate.

### Ampicillin or Amoxicillin vs. Ceftriaxone

One new RCT was identified that addressed this comparison.68 The 2001 AOM report identified three trials.110–112

The ages of children in these trials ranged from 5 months to 12 years. Sample sizes ranged from 22 to 107. The outcome assessed in these four articles was treatment success rate at days 5–14. Definitions of treatment success in both the original and the new studies varied somewhat (e.g., clinical cure; rate of acute symptom resolution; clinical and tympanometric appearance of tympanic membrane); however, we felt these outcomes were sufficiently similar to justify pooling. The Jadad quality scores for the three older articles were 4, 4, and 1 out of 5; the newer study scored 2 out of 5.^68^

The random effects pooled rate difference for clinical success by day 14 between ampicillin/amoxicillin and ceftriaxone was estimated at 0% (95% CI: −7%, 7%) for a clinical success (Table 13, and Figure 6).Thus, it is not possible to establish an advantage of either antibiotic over the other or their equivalence based on the current evidence. In order to show equivalence, the 95% confidence interval must lie within the zone of MCID. It is also worth noting that Zhang and colleagues reported a negative rate difference favoring ceftriaxone, while the other three older articles reported no rate difference; however, Zhang (2003), unlike the other three articles, did not report stringent criteria for entry of patients into the study and, like Kara (1998), had low study quality.68, 112

Table 13 Ampicillin/Amoxicillin vs. Ceftriaxone; Outcome Indicator: Treatment Success Rate

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Ceftriaxone Sample Size | Amoxicillin Success Rate (%) | Ceftriaxone Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Varsano, 1988^110^ | 6 mos–8 yrs | Success at day 7 | 22 | 22 | 86.4 | 81.8 | 4.5 | −17.0, 26.1
Green, 1993^111^ | 5 mos–5 yrs | Success at day 10 | 107 | 105 | 97.2 | 94.3 | 2.9 | −2.5, 8.3
Kara, 1998^112^ | 6 mos–6 yrs | Success at day 5 | 25 | 25 | 92.0 | 84.0 | 8.0 | −9.9, 25.9
Zhang, 2003^68^ | 6 mos–12 yrs | Success at day 10–14 | 106 | 106 | 90.6 | 97.2 | −6.6 | −13.0, −0.2
Random effects estimates | | | 260 | 258 | 93.1 | 93.4 | 0 | −6.9, 7.0
Test of heterogeneity Chi-square test value | | | | | | | 6.09
Test of heterogeneity Chi-square test p-value | | | | | | | 0.107
Test of heterogeneity I-squared | | | | | | | 50.7%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.70

Figure 6 Shrinkage Plot for Ampicillin/Amoxicillin vs. Ceftriaxone for Treatment Success

Figure 6 depicts a shrinkage plot for ampicillin/amoxicillin versus ceftriaxone for treatment success. The random effects pooled rate difference for clinical success by day 14 between ampicillin/amoxicillin and ceftriaxone was estimated at zero point one percent (ninety-five percent confidence interval: negative seven percent and positive seven percent) for a clinical success.

The I^2^ statistic for this analysis was 50.7%, indicating the presence of unexplained heterogeneity, which could be due to differences in population studied and/or research methods employed. Therefore, caution is advised in interpreting overall summary measures. Egger‘s test did not yield evidence suggestive of publication bias (p=0.70). The two higher quality studies110, 111 showed no difference between amoxicillin and ceftriaxone, whereas one of the lower quality studies112 showed no difference and the other68 favored ceftriaxone.

The quality of evidence for this conclusion is moderate, meaning that further high quality research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate.

### Amoxicillin-Clavulanate (7–10 days) vs. Ceftriaxone (single dose)

Two new RCTs were identified that addressed this comparison.71, 78 The 2001 AOM report identified three.77, 113, 114

The ages of the children ranged from 3 months to 10 years. Sample sizes ranged from 32 to 271. The outcome assessed in these five trials was treatment success rate at days 3–16. The definitions of treatment success varied slightly (improvement in clinical signs and symptoms; resolution; acute symptom resolution); however, we concluded that these studies were sufficiently clinically similar to justify pooling. The Jadad scores for the two newer trials were 1 and 2; the Jadad scores for the older trials were 2, 4, and 2 out of 5.

The random effects pooled rate difference for clinical success by day 16 between amoxicillin-clavulanate (7–10 days) and ceftriaxone (single dose) was estimated at 3% (95% CI: −2%, 7%) (Table 14 and Figure 7). Thus, the advantage of either antibiotic over the other cannot be established based on the current evidence.

Table 14 Amoxicillin-Clavulanate (7–10 Days) vs. Ceftriaxone (single Dose); Outcome Indicator: Treatment Success Rate

Author, Year | Age | Definition of outcome | Amox-clav Sample Size | Ceftriaxone Sample Size | Amox-clav Success Rate (%) | Ceftriaxone Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Bauchner, 1996^113^ | 3 mos–6 yrs | Success at day 14–16 | 271 | 267 | 89.7 | 81.3 | 8.4 | 2.5, 14.3
Varsano, 1997^110^ | 6 mos–8 yrs | Success at day 11 | 106 | 109 | 95.3 | 95.4 | −0.1 | −5.8, 5.5
Cohen, 1999^77^ | 4–30 mos | Success at day 12–14 | 228 | 235 | 48.2 | 49.4 | −1.1 | −10.2, 8.0
Wang, 2004^78^ | 3 mos–6 yrs | Success at day 10 | 32 | 41 | 78.1 | 75.6 | 2.5 | −16.9, 22.0
Biner, 2007^71^ | 6 mos–10 yrs | Success at day 3 | 39 | 34 | 87.2 | 85.3 | 1.9 | −14.0, 17.8
Random effects estimates | | | 676 | 686 | 79.8 | 77.4 | 2.8 | −1.6, 7.2
Test of heterogeneity Chi-square test value | | | | | | | 5.19
Test of heterogeneity Chi-square test p-value | | | | | | | 0.27
Test of heterogeneity I-squared | | | | | | | 22.9%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.78

Figure 7 Shrinkage Plot for Amoxicillin-clavulanate (7–10 days) vs. Ceftriaxone (single dose) for Treatment Success

Figure 7 depicts a shrinkage plot for amoxicillin-clavulanate (seven to ten days) versus ceftriaxone (single dose) for treatment success. The random effects pooled rate difference for clinical success by day sixteen between amoxicillin-clavulanate (seven to ten days) and ceftriaxone (single dose) was estimated at three percent (ninety-five percent confidence interval: negative two and positive seven percent).

The I^2^ statistic for this analysis was 22.9%, indicating no evidence of heterogeneity. Egger‘s test did not yield evidence suggestive of publication bias (p=0.78).

The quality of evidence for this conclusion is moderate, meaning that further high quality research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate.

### Amoxicillin-Clavulanate (7–10 days) vs. Azithromycin (≤5 days)

Four new RCTs were identified that addressed this comparison.7, 52, 70, 111 Five articles were identified in the 2001 report.115–119

The ages of the children in these trials ranged from 6 months to 12 years. Sample sizes ranged from 15 to 198 (total pooled sample was 875).The outcome assessed in these nine articles was treatment success rate at days 3–14. The definitions of treatment success varied (e.g., follow-up middle ear fluid culture negative or absent; complete resolution of signs or symptoms; bacteriologic cure; a score indicating absence of clinical and bacteriologic signs); however, we concluded that these studies were sufficiently clinically similar to justify pooling. The Jadad scores for the newer trials were 2, 5, 2, and 1 out of 5; the scores for the older trials were 1, 2, 2, 2, and 3 out of 5.

The random effects pooled rate difference for clinical success by day 14 between amoxicillin-clavulanate (7–10 days) and azithromycin (≤5 days) was estimated at −0.3% (95% CI: −7%, 6%) (Table 15, and Figure 8).Thus, the advantage of one antibiotic over the other or their equivalence cannot be established based on the current evidence. It is worth noting that the magnitude of the 1992 Pestalozza study115 result is an outlier compared to the results of the other eight studies. However, the only apparent difference is the small size of each treatment group, i.e., 15 each, compared with the other studies.

Table 15 Amoxicillin-Clavulanate (7–10 Days) vs. Azithromycin (≤5 Days); Outcome Indicator: Treatment Success Rate

Author, Year | Age | Definition of outcome | Amox-clav Sample Size | Azithromycin Sample Size | Amox-clav Success Rate (%) | Azithromycin Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Pestalozza, 1992^115^ | 11 mos–9 yrs | Success at day 12–14 | 15 | 15 | 40.0 | 93.3 | −53.3 | −81.2, −25.5
Daniel, 1993^116^ | 2–8 yrs | Success at day 10–12 | 54 | 103 | 100.0 | 94.2 | 5.8 | 0.5, 11.1
Schaad, 1993^117^ | 6 mos–10.2 yrs | Success at day 7–20 | 189 | 192 | 97.4 | 93.8 | 3.6 | −0.5, 7.7
Principi, 1995^118^ | 6 mos–12 yrs | Success at day 10–14 | 198 | 215 | 73.2 | 85.1 | −11.9 | −19.7, −4.1
Arguedas, 1996^119^ | 6 mos–12 yrs | Success at day 10–11 | 45 | 47 | 95.6 | 100.0 | −4.4 | −11.6, 2.7
Dagan, 2000^7^ | 6 mos–9 yrs | Success at day 12–14 | 70 | 73 | 85.7 | 69.9 | 15.9 | 2.5, 29.2
Dunne, 2003^70^ | 6 mos–12 yrs | Success at day 10 | 181 | 185 | 87.8 | 82.7 | 5.1 | −2.1, 12.4
Guven, 2006^52^ | 6 mos–12 yrs | Success at day 11–13 | 84 | 90 | 81.0 | 77.8 | 3.2 | −8.8, 15.2
Biner, 2007^71^ | 6 mos–10 yrs | Success at day 3 | 39 | 31 | 87.2 | 87.1 | 0.1 | −15.7, 15.9
Random effects estimates | | | 875 | 951 | 86.1 | 86.4 | −0.3 | −6.5, 5.9
Test of heterogeneity Chi-square test value | | | | | | | 39.8
Test of heterogeneity Chi-square test p-value | | | | | | | <0.001
Test of heterogeneity I-squared | | | | | | | 79.9%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.28

Figure 8 Shrinkage Plot for Amoxicillin-Clavulanate (7–10 days) vs. Azithromycin (≤5 days) for Treatment Success

Figure 8 depicts a shrinkage plot for amoxicillin-clavulanate (seven to ten days) versus azithromycin (less than or equal to five days) for treatment success. The random effects pooled rate difference for clinical success by day fourteen between amoxicillin-clavulanate (seven to ten days) and azithromycin (Less than or equal to five days) was estimated at zero point three percent confidence interval negative seven percent and positive six percent.

The I^2^ statistic for this analysis was 79.9%, indicating the presence of unexplained heterogeneity, which could be due to the differences in the population studied and/or research methods employed. Therefore, caution is advised in interpreting overall summary measures. Egger‘s test did not yield evidence suggestive of publication bias (p=0.28).

As a sensitivity analysis, we excluded the Pestalozza study (1992),115 as it appeared to be an outlier. The pooled analysis with the remaining eight articles52, 70, 71, 81, 116–119 yielded a rate difference of 2% (95% CI: −3%, 7%), so the advantage of one antibiotic over the other or their equivalence still cannot be established, confirming the primary analysis (Figure 9 and Table 16). Possible heterogeneity and publication bias were still present among the remaining eight articles (I^2^=70.6%, Egger‘s test=0.85). Also, the two higher quality studies, Arguedas (1996) and Dunne (2003), both individually had insignificant results that could establish neither the advantage of one antibiotic over the other nor their equivalence.70, 119 Amoxicillin-clavulanate was shown to have higher clinical success rates than azithromycin by day 14 when the pathogen was HF (RD =26%, 95% CI: 6, 46; NNT=4, 95% CI: 2, 17) in one study (Dagan, 2000).7

Figure 9 Shrinkage Plot for Amoxicillin-Clavulanate (7–10 days) vs, Azithromycin (≤5 days) for Treatment Success (Excluded Pestalozza 1992 Study)

Figure 9 depicts a shrinkage plot for amoxicillin-clavulanate (seven to ten days) versus azithromycin (less than or equal to five days) for treatment success. (Excluded the Pestalozza nineteen ninety two study).

Table 16 Amoxicillin-Clavulanate (7–10 Days) vs. Azithromycin (≤5 Days); Outcome Indicator: Treatment Success Rate (Excluding Pestalozza 1992 Study)

Author, Year | Age | Definition of outcome | Amox-clav Sample Size | Azithromycin Sample Size | Amox-clav Success Rate (%) | Azithromycin Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Daniel, 1993^116^ | 2–8 yrs | Success at day 10–12 | 54 | 103 | 100.0 | 94.2 | 5.8 | 0.5, 11.1
Schaad, 1993^117^ | 6 mos–10.2 yrs | Success at day 7–20 | 189 | 192 | 97.4 | 93.8 | 3.6 | −0.5, 7.7
Principi, 1995^118^ | 6 mos–12 yrs | Success at day 10–14 | 198 | 215 | 73.2 | 85.1 | −11.9 | −19.7, −4.1
Arguedas, 1996^119^ | 6 mos–12 yrs | Success at day 10–11 | 45 | 47 | 95.6 | 100.0 | −4.4 | −11.6, 2.7
Dagan, 2000^7^ | 6 mos–9 yrs | Success at day 12–14 | 70 | 73 | 85.7 | 69.9 | 15.9 | 2.5, 29.2
Dunne, 2003^70^ | 6 mos–12 yrs | Success at day 10 | 181 | 185 | 87.8 | 82.7 | 5.1 | −2.1, 12.4
Guven, 2006^52^ | 6 mos–12 yrs | Success at day 11–13 | 84 | 90 | 81.0 | 77.8 | 3.2 | −8.8, 15.2
Biner, 2007^71^ | 6 mos–10 yrs | Success at day 3 | 39 | 31 | 87.2 | 87.1 | 0.1 | −15.7, 15.9
Random effects estimates | | | 86.0 | 936 | 86.9 | 86.3 | 1.7 | −3.3, 6.7
Test of heterogeneity Chi-square test value | | | | | | | 23.8
Test of heterogeneity Chi-square test p-value | | | | | | | <0.001
Test of heterogeneity I-squared | | | | | | | 70.6%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.85

The quality of evidence for this conclusion is moderate due to heterogeneity in the results of studies, meaning that further high quality research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate.

### Cefaclor vs. Azithromycin

Two new RCTs were identified that addressed this comparison.81, 82 The 2001 report identified only one article.120

The ages of the children included in these trials ranged from 6 months to 13 years. Sample size ranged from 33 to 120. The outcome assessed in these three articles was treatment success rate at days 10–14; the definition of treatment success varied among the studies (bacteriologic cure; a composite score; complete resolution of all clinical and otoscopic findings; disappearance or improvement in signs and symptoms). However, we concluded that the definitions were sufficiently clinically similar to justify pooling. The Jadad quality score for the article in the 2001 report was 2 out of 5 and those of the two newer articles were 2 and 3. The random effects pooled rate difference for clinical success by day 14 between cefaclor and azithromycin was estimated at −0.7% (95% CI: −4%, 3%) (Table 17, and Figure 10).Thus, the two drugs are equivalent in efficacy. Amoxicillin-clavulanate was shown to have higher clinical success rates than cefaclor by day 34 (RD =26%, 95% CI: 6, 46; NNT=4, 95% CI: 2, 17) in one study (Subba Rao, 1998).5

Table 17 Cefaclor vs. Azithromycin; Outcome Indicator: Treatment Success Rate

Author, Year | Age | Definition of outcome | Cefaclor Sample Size | Azithromycin Sample Size | Cefaclor Success Rate (%) | Azithromycin Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Rodriguez, 1996^120^ | 6 mos–13 yrs | Success at day 10–14 | 120 | 114 | 96.7 | 98.2 | −1.6 | −5.6, 2.4
Dagan, 2000^81^ | 6 mos–9 yrs | Success at day 10 | 59 | 62 | 84.7 | 82.3 | 2.5 | −10.7, 15.7
Oguz, 2003^82^ | 6 mos–10 yrs | Success at day 10 | 33 | 39 | 97.0 | 94.9 | 2.1 | −7.0, 11.2
Random effects estimates | | | 212 | 215 | 94.0 | 93.0 | −0.7 | −4.3, 2.8
Test of heterogeneity Chi-square test value | | | | | | | 1.03
Test of heterogeneity Chi-square test p-value | | | | | | | 0.60
Test of heterogeneity I-squared | | | | | | | 0.0%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.18

Figure 10 Shrinkage Plot for Cefaclor vs. Azithromycin for Treatment Success

The I^2^ statistic for this analysis was 0.0%, indicating the absence of unexplained heterogeneity. Egger’s test did not yield evidence suggestive of publication bias (p=0.18).

The quality of evidence for this conclusion is considered high, meaning further high quality research is very unlikely to change our confidence in the estimate of effect.

### Antibiotics vs. Wait-and-See/Prescription to Hold

One relevant meta-analysis was identified that compared the use of any antibiotics to that of the wait-and-see approach or the similar approach of prescribing antibiotics if needed. A meta-analysis by Spurling (2007) identified three studies that compared delayed vs. immediate antibiotic therapy.2, 93, 94 Two new RCTs were identified that addressed these comparisons as well.3, 87

Two studies looked at the wait-and-see approach3, 87, and two looked at the prescription-to-hold approach.2, 93, 94 In all four studies, the majority of patients in the immediate antibiotic group complied with use of the prescribed antibiotic (range of 83% to 99%), and many of those in the wait-and-see and prescription-to-hold groups ultimately used prescribed antibiotics, as well (range of 1% to 38%).3, 87

Of the four studies in this comparison, one study compared amoxicillin to the wait-and-see approach3 and another compared amoxicillin to the prescription-to-hold approach.2 The McCormick (2005) article reported a 15% rate difference (95% CI: 6%, 23%; NNT=7, 95% CI: 4, 17), favoring amoxicillin compared to wait-and-see for success rate at day 12 as perceived by the parent. The Little (2001) article reported a 16% rate difference (95% CI: 6%, 26%; NNT=6, 95% CI: 4, 17), also favoring amoxicillin compared to prescription-to-hold for success at day 3 as perceived by the parent. We conclude that in both studies, immediate amoxicillin therapy has a higher success rate than the “no immediate treatment” approaches, even though 34% in the McCormick (2005) and 24% in the Little (2001) wait-and-see and prescription-to-hold groups, respectively were on antibiotics later in the course of the disease. (Table 18)

Table 18 Antibiotics vs. Wait-and-See/Prescription Hold

Author, Year | Outcome | Tx 1 | Tx 2 | Tx 1 Sample Size | Tx 2 Sample Size | Tx12 % on antibiotic | Tx22 % on antibiotic | Tx 1 Outcome Rate (%) | Tx 2 Outcome Rate (%) | % RD (95% CI) | NNT (95% CI)
Wait-and-See (WAS)
McCormick, 2005^3^ | Success day 12 | amx | WAS | 107 | 107 | 83 | 34 | 95 | 80 | 15 (6, 24) | 7 (4, 17)
“ | Cure Before day 30 | “ | “ | 109 | 100 | “ | “ | 77 | 66 | 11 (−1, 23) | n/a
“ | AOM extra office visit | “ | “ | 111 | 108 | “ | “ | 13 | 20 | −7 (−17, 3) | n/a
“ | AOM ED visit | “ | “ | 111 | 108 | “ | “ | 1 | 4 | −3 (−7, 1) | n/a
“ | AOM extra phone call | “ | “ | 111 | 108 | “ | “ | 23 | 24 | −1 (−12, 10) | n/a
“ | Parent missed school/work | “ | “ | 111 | 108 | “ | “ | 14 | 9 | 5 (−3.5, 14) | n/a
Neumark, 2007^87^ | Success day 14 | PcV | WAS | 87 | 82 | 83 | 1 | 82 | 85 | −4 (−15, 7) | n/a
“ | Pain Day 3–7 | “ | “ | 76 | 87 | “ | “ | 2 | 5 | −3 (−9, 3) | n/a
“ | Analgesic use Day 3–7 | “ | “ | 76 | 87 | “ | “ | 3 | 10 | −7 (−15, 1) | n/a
“ | Fever>38oC Day 3–7 | “ | “ | 76 | 87 | “ | “ | 3 | 6 | −3 (−9, 3) | n/a
“ | Success 3 months | “ | “ | 86 | 75 | “ | “ | 85 | 84 | 1 (−10, 12) | n/a
“ | Perforation 3 months | “ | “ | 86 | 75 | “ | “ | 0 | 0 | 0 | n/a
“ | Serous OM 3 months | “ | “ | 86 | 75 | “ | “ | 12 | 11 | 1 (−9,11) | n/a
“ | Work Loss | “ | “ | 76 | 87 | “ | “ | 56 | 53 | 3 (−12, 18) | n/a
Prescription Hold (PH)
Little, 2001, 2006^2, 93^ | Success day 3 | Amx | PH | 135 | 150 | 99 | 24 | 86 | 70 | RD 16 (6, 26) | 6 (4, 17)
“ | Parent belief ab effective | “ | “ | 131 | 140 | “ | “ | 76 | 46 | RD 31 (19, 42) | 3 (2, 5)
“ | Parent satisfied with treatment | “ | “ | 131 | 150 | “ | “ | 94 | 77 | RD 17 (9, 31) | 6 (4, 11)
“ | Parent likely to consult MD in future | “ | “ | 132 | 147 | “ | “ | 83 | 63 | RD 20 (9, 31) | 5 (3, 11)
“ | Earache 3 months | “ | “ | Not reported | Not reported | “ | “ | Not reported | Not reported | OR 0.89 (0.5, 1.7) | n/a
“ | Earache 1 year | “ | “ | Not reported | Not reported | “ | “ | Not reported | Not reported | OR 1.03 (0.6, 1.8) | n/a
Spiro, 2006^94^ | Did not fill prescription Day 4–6 | Ab | PH | 133 | 132 | 87 | 38 | 13 | 62 | RD −49 (−59, − 37) | 2 (2, 3)
“ | No analgesic Day 4–6 | “ | “ | “ | “ | “ | “ | 90 | 93 | RD −3 (−10, 4) | n/a
“ | No MD visit Day 4–6 | “ | “ | “ | “ | “ | “ | 92 | 90 | RD 2 (−5, 9) | n/a
“ | Otalgia Day 4–6 | “ | “ | “ | “ | “ | “ | 67 | 64 | RD 3 (−8, 14) | n/a
“ | Fever Day 4–6 | “ | “ | “ | “ | “ | “ | 35 | 32 | RD 3 (−8, 14) | n/a
“ | No Analgesic Day 11–14 | “ | “ | 123 | 124 | “ | “ | 11 | 5 | RD 6 (−18, 6) | n/a
“ | No MD visit Day 11–14 | “ | “ | “ | “ | “ | “ | 89 | 85 | RD 4 (−4, 12) | n/a
“ | Otalgia Day 11–14 | “ | “ | “ | “ | “ | “ | 61 | 67 | RD −6 (−18, 6) | n/a
“ | Fever Day 11–14 | “ | “ | “ | “ | “ | “ | 31 | 32 | RD −1 (−13, 11) | n/a

Abbreviations: amx=amoxicillin; PcV=phenoxymethylpenicillin; NNT=number-to-treat; OR=odds ratio; RD=rate difference; Tx=treatment

2 Estimates of patients in a treatment group on antibiotic are either directly from the study articles or based on information from the study articles for the treatment groups as a whole and not for the subgroup analyses within each study.

The Little (2006)93 article reported the long-term outcomes (3-month and 1-year) on the same groups of patients whose short-term outcomes were reported in their 2001 article.2 The Spiro (2006) article reported the difference between the antibiotic and prescription-to-hold approaches (91% of the prescription-to-hold group and 93% of the standard prescription group received prescriptions for amoxicillin; the remainder received prescriptions for other antibiotics) on health services utilization (filling prescriptions on day 4–6) as the primary outcome measure and presence of otalgia and fever at day 4–6 and 11–14 as the secondary outcomes.94 The Neumark 2007 article compared phenoxymethylpenicillin with the wait-and-see approach. The findings from these three studies are reported in Table 22.^87^

Table 22 Review Articles Examining Comparative Effectiveness of Treatment Strategies in Recurrent Acute Otitis Media or Persistent or Relapsing Acute Otitis Media^a^

Author (year) (quality) b | Review focus | Databases (included dates) | Study design | Target population | Outcomes | Number of trials and participants | Author’s highlight conclusion
Bonati, 1992^139^ (y,y,n,n,n, y,y,y,y,n,n) | ab prophylaxis in reducing ROM | MEDLINE (1966 through 1991); hand search | RCT | Patients with ROM5 | AOM rate | 8 studies 420 children | chemoprophyl axis effective in reducing AOM episodes during winter and spring
Williams. 1993^140^ (y,y,y,y,n, y,y,n,y,n,n) | Use of antibiotics in preventing ROM and in treating OME | MEDLINE (1966 through April 1993); Current Contents (1990 through 1992); textbooks, monographs | RCT | Patients with ROM or OME | Number of episodes of AOM per patient- month while under treatment | 9 studies 958 participants | antibiotics have beneficial but limited effect on ROM
Abes, 2003^134^ (y,y,y,y,y,y, y,n,y,y,n) | ofloxacin otic solution | Medline through PubMed (1966 to 2000); CD version of the Cochrane Library; Centerwatch Clinical Trial Listing Service; Trial Banks; Research and Researcher Registry; Manual searches | RCT and non-randomized clinical trial | Adults and/or children with acute or chronic suppurative otitis media | Cure rate; resolution of otalgia; resolution of otorrhea; bacterial eradication; adverse events | 2 studies (children with tympanostomy tubes and AOM) | No conclusion offered by authors on these two studies
Straetemans, 2004^141^ (y,y,y,y,y, y,y,y,y,y,n) | PPV & PCV to prevent AOM | CENTRAL (TCL, Issue2, 2003); MEDLINE (Jan 1966–Jun 2003; EMBASE (Jan 1990–June 2003); hand search | RCT | 0–12y | AOM total number; proportion of children with AOM; bacterial culture results | 8 trials on PPV 4 trials on PCV | pneumococcal vaccine does not benefit children with ROM <1y old
Leach. 2008^142^ (y,y,y,y,y, y,y,y,y,y,n) | long-term ab vs. placebo or no treatment to prevent AOM | CENTRAL (TCL, Issue 1, 2006); MEDLINE (Jan 1966–March week 3 2006); OLD MEDLINE (1950–1965); EMBASE (1990–Dec 2005); hand search | RCT | 0–18y at increased risk for future AOM in otitis prone and high risk children3 | AOM/CSOM during intervention; number of episodes of AOM/CSOM during intervention per child-year | 13 studies 1358 children | long-term ab reduce AOM probability while on treatment; ab reduce number of AOM episodes per year from 3 to ~1.5
McDonald. 2008^143^ (y,y,y,n,y, y,y,y,y,n,n) | tympanosto my tube vs. non-surgical treatment to reduce ROM | CENTRAL (TCL, Issue 1, 2008); MEDLINE (1950–March 2008); EMBASE (1974–March 2008); CINAHL; mRCT; NRR; LILACS; KoreaMed; IndMed; PakMediNet; Zetoc; ISI Proceedings; Cambridge Scientific Abstracts; hand search (last search date Mar 2008) | RCT | 0–16y with ROM4 | AOM frequency following treatment; proportion of children with ROM following treatment | 2 studies 148 children | ventilation tube plays significant role to maintain a disease-free state in the first six months after tube insertion.
Wall. 2009^138^ (n,n,n,n,n,y, y,n,n/a,n/a,n) | ciprodex otic suspension vs. ciprofloxacin, ofloxacin, or amox-clav | MEDLINE; hand search | Not specified a priori RCTs identified | AOM in children with tympanostomy tubes & acute otitis externa (Identified studies included children 6m–12y) | Not specified a priori Identified studies included clinical outcome “per protocol” and bacteriologic cure | 3 trials total | topical fluoroquinolon es safe and efficacious in treatment of ear infections

a Abbreviations: ab=antibiotic; AOM=acute otitis media; CENTRAL=Cochrane Central Register of Controlled Trials; CINAHL=Cumulative Index to Nursing & Allied Health Literature; CSOM=chronic suppurative otitis media; HlthSTAR=HealthSTAR; IPA=International Pharmaceutical Abstracts; MEE=middle ear effusion; mRCT=metaRegister; NRR=National Research Register; Rx=treatment; PCV=pneumococcal conjugated vaccines; PPV=pneumococcal polysaccharide vaccines; TCL=The Cochrane Library

b AMSTAR quality criteria (Shea, Grimshaw, Wells, et al., 2007)144

1. Was an ‘a priori’ design provided?
2. Was there duplicate study selection and data extraction?
3. Was a comprehensive literature search performed?
4. Was the status of publication (i.e. grey literature) used as an inclusion criteria?
5. Was a list of studies (included and excluded) provided?
6. Were the characteristics of the included studies provided?
7. Was the scientific quality of the included studies assessed and documented?
8. Was the scientific quality of the included studies used appropriately in formulating conclusions?
9. Were the methods used to combine the findings of studies appropriate?
10. Was the likelihood of publication bias assessed?
11. Was the conflict of interested stated?

c Otitis prone children with ≥3 AOM in 6 months or ≥4 AOM in 1 year; high-risk children with history of AOM with perforation; children in high-risk populations with CSOM prevalence ≥4%

d ROM defined as ≥3 AOM in six months or ≥4 AOM in 1 year

e Included patients with 3 or more documented episodes of RAOM/diagnosed on the basis of tympanic membrane exam, and who had received continued antimicrobial

It can be observed from the 95% confidence intervals of these outcome measures that no conclusion can be established with respect to the effectiveness of either treatment option in the pairs in terms of success rates. Although, the Spiro 2006 article established that those given prescriptions for immediate antibiotics filled the prescription more often than those who were given prescriptions “to hold,” no differences were seen in absence of otalgia or fever between groups at either follow-up point.94

The quality of evidence for these conclusions is moderate, meaning that further high quality research is likely to have an important impact on our confidence in the estimate of the effect and may change the estimate.

### Other Meta-Analyses

Short duration vs. long duration antibiotic therapy. Kozyrskyj (2000) reported that five days of antibiotics were as effective as 10 days of treatment for uncomplicated AOM based on signs and symptoms, relapse, or re-infection, with a risk difference of 6% (95% CI: 2%, 10%) at 8 to 19 days, favoring 10 days treatment with a NNT of 17 children (95% CI: 10, 50) and a risk difference of 3% (95% CI: −0.3%, 6%) at 30 days.53

Amoxicillin or amoxicillin-clavulanate once or twice daily vs. three times daily. Thanaviratananich (2008) reported that the available evidence was biased, so no definitive conclusions could be drawn.59

Topical analgesia. A review by Foxlee (2006) concluded that the existing evidence was insufficient to make definitive conclusions on the effectiveness of topical analgesia.55

Decongestant and/or antihistamine treatment. Coleman (2008) reported that despite a slight benefit of combined decongestant-antihistamine at two weeks of persistent AOM with a fixed relative risk of 0.76 (95% CI: 0.60, 0.96; NNT=10, 95% CI: 8, 13), decongestants and/or antihistamines were not beneficial in general and specifically not for early cure rates, symptom resolution, prevention of surgery, or other complications, and resulted in an increased risk of other side effects (odds ratio 5 [95% CI: 2,14]).58

### Summary

We identified 63 comparisons of treatment options for uncomplicated AOM that encompassed different antibiotics and regimens. Our analyses yielded inconclusive results for many of these comparisons. For 12 comparisons, we reached stronger conclusions (Table 19). Meta-analyses of ampicillin or amoxicillin vs. placebo (Table 9) demonstrated higher clinical success rates for ampicillin or amoxicillin, with nine children needing to be treated for a clinical success. Little (2001) and McCormick (2005) individually demonstrated higher clinical success rates as perceived by the parent for amoxicillin than for prescription-to-hold at day 3 and wait-and-see at day 12 options, respectively; however, these results are tempered by Spiro’s comparison of immediate antibiotic therapy to the prescription-to-hold option (2006) and Neumark’s comparison of immediate antibiotic therapy to the wait-and-see option (2007), which had inconclusive results. Meta-analysis of three studies demonstrated equivalence of clinical success rates between cefaclor and azithromycin in treatment of uncomplicated AOM (Table 17). In addition, single studies of comparisons (that could not be pooled) produced strong results. Amoxicillin-clavulanate was shown to have higher clinical success rates than azithromycin by day 14 when the pathogen was HF in one study (Dagan, 2000) and higher success rates than cefaclor by day 34 in another study (Subba Rao, 1998).5, 7 Equivalent clinical success rates were also demonstrated in individual studies of amoxicillin vs. azithromycin for one of many outcomes assessed (Morris, 2010)67, amoxicillin vs. erythromycin (Scholz, 1998)4, amoxicillin-clavulanate vs. amoxicillin-sulbactam (Casellas, 2005), cefixime vs. ampicillin or amoxicillin (Table 36 in Marcy, 2001), cefaclor 50 mg/kg/day vs. 40 mg/kg/day (Catania, 2004), and amoxicillin-clavulanate 45/64/mg/kg/day divided into two daily doses vs. 40/10/mg/kg/day divided into three daily doses.88 In addition, individual studies of amoxicillin-clavulanate >60mg/kg/d vs. amoxicillin-clavulanate 40mg/kg/d and high-dose amoxicillin bid vs. lower-dose amoxicillin tid that in the 2001 report were assessed as demonstrating equivalent clinical success rates are now assessed as inconclusive utilizing an MCID of 5%. Each of these single study results requires replication before strong conclusions can be reached.

Table 19 Treatment Comparisons with Conclusive Evidence in Any Clinical Success Outcome in Uncomplicated Otitis Media

Article | Treatment 1 | | Rate for Treatment 1 | Rate for Treatment 2 | Rate Difference (95% CI) | Conclusion
7 studies Table 9 | Ampicillin/Amoxicillin | Placebo | 69.0% (681/987) | 53.1% (569/1071) | 12% (5, 18) | Amp/Amox better (success day 2–14)
3 studies Table 17 | Cefaclor | Azithromycin | 93.4% (198/212) | 93.0% (200/215) | −0.7% (−4.3, 2.8) | Equivalence (success day 10–14)
4 Studies Table 36 in Marcy (2001) | Cefixime | Ampicillin/Amoxicillin | 90.0% (245/274) | 91.1% (240/265) | 0.1% (−3.9, 4.2) | Equivalence (success at day 10– 15)
Casellas 2005^69^ | Amoxicillin - clavulanate 80 mg/kg/day = bid for 10 days | Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | 98.3% (115/117) | 98.3% (115/117) | 0% (−3.3, 3.3) | Equivalent (success day 12– 14)
Catania, 2004^99^ | Cefaclor 50 mg/kg/day = bid for 5 days | Cefaclor 40 mg/kg/day = bid for 10 days | 95.5% (195/204) | 94.8% (195/206) | 0.7% (−3.5, 4.9) | Equivalent (cured end of therapy)
Dagan, 2000^7^ | Amoxicillin - clavulanate 45/6.4 mg/kg/day/bid for 10 days | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | 90.9% (30/33) | 64.7% (22/34) | 26% (6, 36) | Amox-clav better (success day 12–14 when pathogen is H. Influ).
Damrikarnlert, 2000^6^ | Amoxicillin - clavulanate 45/64 mg/kg/day/bid for 7–10 days | Amoxicillin-clavulanate 40/10 mg/kg/day/tid for 7–10 days | 94.0% (187/199) | 94.1% (175/186) | 0.1% (−4.8, 4.6) | Equivalent (success day 7–12)
Little, 2001^2^ | Amoxicillin tid for 7 days | Prescription to Hold | 85.9% (116/135) | 70.0% (105/150) | 16% (6, 26) | Amox better (success day 3)
McCormick, 2005^3^ | Amoxicillin 90 mg/kg/day/bid for 10 days | Wait and see | 95.3% (102/107) | 80.4% (86/107) | 15% (6, 24) | Amox better (success day 0–12)
Morris, 2010^67^ | Amoxicillin 50 mg/kg/day/bid for 7 days | Azithromycin 30mg/kg as a single dose | 99% (155/156) | 98% (144/147) | 1% (−1, 4) | Equivalence (no new pain between day 6–11)
Scholz, 1998^4^ | Amoxicillin 50 mg/kg/day/bid for 10 days | Erythromycin 40 mg/kg/day/bid for 10 days | 97.8% (136/139) | 97.2% (137/141) | 0.6% (−3, 4) | Equivalence (free of recurrence day 31– 40)
Subba Rao, 1998^5^ | Amoxicillin - clavulanate 250 mg for > 6 y = tid for 7 days, ---125 mg for < 6 y = tid for 7 days | Cefaclor 125 or 250 mg = tid for 7 days | 97.1% (102/105) | 83.9% (94/112) | 13% (5.3, 21) | Amox-clav better (success day 28– 34)

Table 36 Findings of Adverse Events from Eight Articles on Effectiveness of Prevention of Acute Otitis Media in Recurrent Otitis Media

Comp # | Comparison | Author, Year | Patient Population | Intervention | Findings of Adverse Events | | | | Conclusion
1 | Amox vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | | Amoxicillin | Azithromycin | Diff(95% CI) | GI: Inconclusive
1 | Amox vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | | | | | GI: Inconclusive
1 | Amox vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | GI | 2.5% (1/40) | 0% (0/31) | 2.5%(−3. 8) | GI: Inconclusive
1 | Amox vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | | | | | GI: Inconclusive
2 | Amox vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | No adverse events studied.
3 | Amox vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | No adverse events studied.
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | No adverse events studied.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | Sulfafurazole | Placebo | Diff (95% CI) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Any | 8% (5/60) | 3% (2/60) | 5% (−3.4, 13) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Diarrhea | 3% (2/60) | 2% (1/60) | 2% (−4.8,7.2) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Skin rash | 3% (2/60) | 0% (0/60) | 3% (−1.3,7.9) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Unknown | 2% (1/60) | 2% (1/60) | 0% (−4.6, 4.6) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | AE | Sulfafurazole | Adenoidectomy | Diff(95% CI) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | Any | 8.3% (5/60) | 0% (0/60) | 8%(1.2,15) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | Diarrhea | 3% (2/60) | 0% (0/60) | 3%(−1.3, 8) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | Skin rash | 3% (2/60) | 0% (0/60) | 3%(−1.3, 8) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | Unknown | 2% (1/60) | 0% (0/60) | 2%(−1.6,5.0) | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg,qd, 6mos) Adenoidectomy | | | | | Unknown adverse events equivalent. Any mention, diarrhea, and skin rash inconclusive.
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | | Adenoidectomy | Placebo | Diff (95% CI) | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | | | | | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Any | 0% (0/60) | 3% (2/60) | −3% (−8, 1.3) | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | | | | | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Diarrhea | 0% (0/60) | 2% (1/60) | −2% (−5.0,1.6) | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | | | | | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Skin rash | 0% (0/60) | 0% (0/60) | 0% (0, 0) | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | | | | | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Unknown | 0% (0/60) | 2% (1/60) | −2% (−5.0,1.6) | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | | | | | Diarrhea, skin rash and unknown are equivalent. Any mention inconclusive
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | | Adenoidectomy | Placebo | Diff(95% CI) | Inconclusive
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | | | | | Inconclusive
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Erythematous rashes during treatment | 7.2% (6/83) | 3.9% (7/181) | 3%(−2.3, 9) | Inconclusive
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | | | | | Inconclusive
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | AE | Adenoidectomy | Adenotonsillectomy | Diff(95% CI) | Equivalence in incipient malignant hyperthermia, postoperative pneumonia, postoperative persistent velopharyngea l insufficiency, and serious sickness during antimicrobial treatment. Inconclusive in erythematous rashes during treatment, hemorrhage after hospital discharge, perioperative and postoperative complications, postoperative transient (under 44 days) velopharyngeal insufficiency, retained in hospital one additional day.
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Erythematous rashes during treatment | 7.2% (6/83) | 2.2% (4/178) | 5% (0,10)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Hemorrhage after hospital discharge | 0% (0/83) | 2.2% (4/178) | −2% (−5.4,1)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Incipient malignant hyperthermia | 1.2% (1/83) | 0.6% (1/178) | 0.6% (−1.7,1)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Periop & postop complications | 4.8% (4/83) | 14.6% (26/178) | −10% (−18,−1.5)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Postop pneumonia | 1.2% (1/83) | 0% (0/178) | 1.2% (−0.4,2.8)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Postop velopharyngeal insufficiency – persistent (9mo) | 0% (0/83) | 0.6% (1/178) | −0.6% (−2.3,1.1)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Postop velopharyngeal insufficiency-transient (<=43 d) | 2.4% (2/83) | 5.1% (9/178) | −2.7% (−8,2.6)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Retained in hospital 1 > day and/or readmitted to hospital due to fever, poor fluid intake orally, vomiting, and/or dehydration | 0% (0/83) | 6% (11/178) | −6% (−11,−0.8)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Serious sickness during antimicrobial treatment | 0% (0/83) | 0.6% (1/178) | −0.6% (−2.3,1.1)
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | | Adenotonsillectomy | Placebo | Diff (95% CI) | Inconclusive
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | | | | | Inconclusive
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Erythematous rashes during treatment | 2.2% (4/178) | 3.9% (7/181) | −1.7% (−5.3,1.9) | Inconclusive
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | | | | | Inconclusive
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | | Ceftibuten 5d | Ceftibuten 10d | Diff (95% CI) | Inconclusive
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | | | | | Inconclusive
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | GI disturbance | 6.7% (6/90) | 16.7% (15/900) | −10% (−19,−0.6) | Inconclusive
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | | | | | Inconclusive
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | No adverse events studied. | | | | Equivalent
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only | | Adeno+Tympan | Tympan only | Diff (95% CI)
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only | Neck abscess or type 1 diabetes | 0% (0/109) | 1% (1/108) | −1%(−3, 1)
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Propolis+Zinc | Controls | Diff (95% CI) | Equivalence in vomiting and rash.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | | | | Equivalence in vomiting and rash.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Vomiting | 1.6% (1/61) | 1.6% (1/61) | 0% (−5, 5) | Equivalence in vomiting and rash.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | | | | Equivalence in vomiting and rash.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Rash | 1.6% (1/61) | 0.0% (0/61) | 1.6% (−2, 5) | Equivalence in vomiting and rash.

## Key Question IV What Is the Comparative Effectiveness of Different Management Options for Recurrent Otitis Media (Uncomplicated) and Persistent Otitis Media or Relapse of Acute Otitis Media?

### Description of the Studies

This question was not addressed in the 2001 AOM report. Thus, in order to address this study question, we employed several strategies. We began by identifying articles from our searches on uncomplicated AOM (Key Question III) that dealt with recurrent, persistent, or relapsing AOM. Of the 62 RCTs identified in our review update that addressed the effectiveness of treatment options, 14 compared treatment options in children with ROM, persistent AOM, or AOM treatment failure. Among these studies are 21 treatment comparisons. Eight studied the treatment of AOM in children with presumed or explicitly defined recurrent and/or persistent AOM, and/or AOM with treatment failure. Thirteen studied the prevention of AOM in children with ROM. The 21 comparisons are listed in Tables 20 and 21 together with a description of the characteristics of the study populations and interventions and the main findings. Findings by patient subgroups are reported in the findings for Key Question V.

Table 20 Summary of Findings from Eight Studies on Effectiveness of Treatment of Acute Otitis Media in Recurrent Otitis Media or Persistent Acute Otitis Media

Comp # | Comparison | Author, Year | Patient Population | Intervention | Findings | | Conclusion
1 | Amoxicillin- clavulanate (Amox-clav) vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non- US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses) Gatifloxacin (10mg/kg, qd) | Success rate on day 3–10: | | Not enough evidence to conclude
1 | Amoxicillin- clavulanate (Amox-clav) vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non- US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses) Gatifloxacin (10mg/kg, qd) | Amox-clav: | 84% (102/121) | Not enough evidence to conclude
1 | Amoxicillin- clavulanate (Amox-clav) vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non- US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses) Gatifloxacin (10mg/kg, qd) | Gatifloxacin: | 90% (222/246) | Not enough evidence to conclude
1 | Amoxicillin- clavulanate (Amox-clav) vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non- US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses) Gatifloxacin (10mg/kg, qd) | Mean difference (95% CI): | −5.9% (−12.9%, 1.1%) | Not enough evidence to conclude
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Success rate on day 10: | | Not enough evidence to conclude
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Amox-clav: | 79% (92/117) | Not enough evidence to conclude
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Gatifloxacin: | 85% (105/124) | Not enough evidence to conclude
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Mean difference (95% CI): | −6.1% (−15.9%, 3.7%) | Not enough evidence to conclude
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, including US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Success rate on day 2–5: | | Not enough evidence to conclude
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, including US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Amox-clav: | 91% | Not enough evidence to conclude
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, including US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Levofloxacin: | 94% | Not enough evidence to conclude
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, including US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Mean difference (95% CI): | −3.2% (−6.2%, − 0.2%) | Not enough evidence to conclude
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM^b^ 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Success rate on day 12–16: | | Not enough evidence to conclude
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM^b^ 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Amox-clav: | 84% (122/145) | Not enough evidence to conclude
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM^b^ 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Azithromycin: | 86% (128/149) | Not enough evidence to conclude
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM^b^ 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Mean difference (95% CI): | −1.8% (−10.0%, 6.4%) | Not enough evidence to conclude
5 | Amox-clav vs. ciprofloxacin 0.3%- dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 sites in US | Amox-clav (90mg/kg/d, bid, 10d) cipro-dex (4 drops, bid, 7d) | Success rate on day 18–21: | | Cipro-dex higher success rate than amox-clav
5 | Amox-clav vs. ciprofloxacin 0.3%- dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 sites in US | Amox-clav (90mg/kg/d, bid, 10d) cipro-dex (4 drops, bid, 7d) | Amox-clav: | 58.5% (24/41) | Cipro-dex higher success rate than amox-clav
5 | Amox-clav vs. ciprofloxacin 0.3%- dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 sites in US | Amox-clav (90mg/kg/d, bid, 10d) cipro-dex (4 drops, bid, 7d) | Cipro-dex: | 84.6% (33/39) | Cipro-dex higher success rate than amox-clav
5 | Amox-clav vs. ciprofloxacin 0.3%- dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 sites in US | Amox-clav (90mg/kg/d, bid, 10d) cipro-dex (4 drops, bid, 7d) | Mean difference (95% CI): | −26% (−46%, −6%) | Cipro-dex higher success rate than amox-clav
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Success rate on day 10: | | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Cefaclor: | 93.6% (73/78) | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Cefuroxime: | 92.9% (65/70) | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Mean difference (95% CI): | 0.7% (−7%, 9%) | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Success rate on day 20–26: | | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Cefaclor: | 85.9% (67/78) | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Cefuroxime: | 87.1% (61/70) | Not enough evidence to conclude
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Mean difference (95% CI): | −1.2% (−12%, 10%) | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Success rate on day 8: | | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Cipro: | 91.2% (73/80) | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Cipro-dex: | 94.2% (82/87) | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Mean difference (95% CI): | −3% (−11%,4.9%) | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Success rate on day 14: | | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Cipro: | 93.8% (75/80) | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Cipro-dex: | 98.9% (86/87) | Not enough evidence to conclude
7 | Cipro 0.3% otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Mean difference (95% CI): | −5% (−11%,0.5%) | Not enough evidence to conclude
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Success rate on day 18–21: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 90% (162/180) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 78.2% (133/170) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 12% (4.2%, 19%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Success rate on day 3: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 93.7% (194/207) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 79.6% (172/216) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 14% (7.6%, 21%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Success rate on day 11: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 96.1% (199/207) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 89.8% (194/216) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 6% (1.4%, 11%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Success rate on day 18: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 93.7% (194/207) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 88.4% (191/216) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 5% (−0.2%, 11%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Otorrhea absence on day 3: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 32.2% (62/207) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 18.5% (40/216) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 14% (5.4%, 22%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Otorrhea absence on day 11: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 84.6% (176/207) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 63.4% (137/216) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 21% (13%, 30%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Otorrhea absence day 18: | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cipro-dex: | 85.0% (176/206) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Ofloxacin: 70.8% (153/216) | | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18
8 | Cipro 0.3%-dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Mean difference (95% CI): | 14% (6%, 22%) | Cipro-dex higher success rate than ofloxacin at day 3 & not enough evidence to conclude for days 11, 18, and 18–21; Cipro-dex higher otorrhea absence days 3, 11, and 18

a AOM Treatment Failure: infection within 14 days of last antibiotic dose or failure to improve after 48 hours

b Persistent AOM: signs or symptoms of AOM after 48 hours of treatment

Table 21 Summary of Findings from Seven Articles on Effectiveness of Prevention of Acute Otitis Media in Recurrent Otitis Media

Comp # | Comparison | Author, Year | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amoxicillin vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | Effective rate (#AOM episodes dropped to <50% after prophylaxis) in 6–27 months: | | | | Not enough evidence to conclude
1 | Amoxicillin vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | Amoxicillin: | | 89% (34/38) | | Not enough evidence to conclude
1 | Amoxicillin vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | Azithromycin: | | 81% (25/31) | | Not enough evidence to conclude
1 | Amoxicillin vs. azithromycin | De Diego, 2001^128^ | 9–120 months 1 institution in Spain | Amoxicillin (20mg/kg/d, 3mos) Azithromycin (10mg/kg/wk, 3mos) | Mean difference (95% CI): | | 8.9% (−7.8%, 25.6%) | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Success rate (none or 1 AOM episode in 6 months | | | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Amoxicillin: | | 90% (36/40) | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Sulfisoxazole: | | 78% (28/36) | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Mean difference (95% CI): | | 12.2% (−4.2%, 28.6%) | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Success rate (none or 1 AOM episode in 1 year | | | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Amoxicillin: | | 68% (27/40) | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Sulfisoxazole: | | 64% (23/36) | | Not enough evidence to conclude
2 | Amoxicillin vs. sulfisoxazole | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Sulfisoxazole (50mg/kg/d) | Mean difference (95% CI): | | 3.6% (−17.8%, 25.0%) | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Success rate (none or 1 AOM episode in 6 months | | | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Amoxicillin: | | 90% (36/40) | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Placebo: | | 71% (29/41) | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Mean difference (95% CI): | | 19.3% (2%, 36.6%) | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Success rate (none or 1 AOM episode in 1 year | | | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Amoxicillin: | | 68% (27/40) | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Placebo: | | 66% (27/41) | | Not enough evidence to conclude
3 | Amoxicillin vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Amoxicillin (20mg/kg/d) Placebo | Mean difference (95% CI): | | 1.7% (−18.9%, 22.2%) | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Success rate (none or 1 AOM episode in 6 months | | | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Sulfisoxazole: | | 78% (28/36) | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Placebo: | | 71% (29/41) | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Mean difference (95% CI): | | 7.1% (−12.5%, 26.7%) | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Success rate (none or 1 AOM episode in 1 year | | | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Sulfisoxazole: | | 64% (23/36) | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Placebo: | | 66% (27/41) | | Not enough evidence to conclude
4 | Sulfisoxazole vs. placebo | Teele, 2000^129^ | 0–1 year 2 sites in US | Sulfisoxazole (50mg/kg/d) Placebo | Mean difference (95% CI): | | −1.9% (−23.3%, 19.5%) | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 6 months | | | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Sulfafurazole: | | 63% (29/46) | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Placebo: | | 45% (21/47) | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Mean difference (95% CI): | | 18.3% (−2.0%, 38.6%) | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 2 years | | | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Sulfafurazole: | | 34% (14/41) | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Placebo: | | 22% (10/45) | | Not enough evidence to conclude
5 | Sulfafurazole vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Placebo | Mean difference (95% CI): | | 11.9% (−7.1%, 30.9%) | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 6 months | | | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Sulfafurazole: | | 63% (29/46) | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Adenoidectomy: | | 58% (34/59) | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Mean difference (95% CI): | | 5.4% (−13.5%, 24.3%) | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 2 years | | | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Sulfafurazole: | | 34% (14/41) | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Adenoidectomy: | | 28% (16/58) | | Not enough evidence to conclude
6 | Sulfafurazole vs. adenoidectomy | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Sulfafurazole (50mg/kg, qd, 6mos) Adenoidectomy | Mean difference (95% CI): | | 6.5% (−11.9%, 24.9%) | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 6 months | | | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Adenoidectomy: | | 58% (34/59) | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Placebo: | | 45% (21/47) | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Mean difference (95% CI): | | 12.9% (−6.2%, 32.0%) | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 2 years | | | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Adenoidectomy: | | 28% (16/58) | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Placebo: | | 22% (10/45) | | Not enough evidence to conclude
7 | Adenoidectomy vs. placebo | Koivunen, 2004^130^ | 10mos–2yrs 1 hosp in Finland | Adenoidectomy Placebo | Mean difference (95% CI): | | 5.4% (−11.5%, 22.3%) | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Success rate (% with no AOM episode) in 1 year in patients with no tonsil-related indications: | | | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Adenoidectomy: | | 31% (19/61) | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Placebo: | | 22% (17/79) | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Mean difference (95% CI): | | 9.6% (−5.0%, 24.2%) | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Success rate (% with<=1 AOM episode) in 1 year in patients with no tonsil-related indications: | | | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Adenoidectomy: | | 48% (29/61) | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Placebo: | | 51% (40/79) | | Not enough evidence to conclude
8 | Adenoidectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Placebo | Mean difference (95% CI): | | −3.1% (−19.8%, 13.6%) | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Success rate (% with no AOM episode) in 1 year in patients with no tonsil-related indications: | | | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Adenoidectomy: | | 31% (19/61) | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Adenotonsillectomy: | | 37% (26/71) | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Mean difference (95% CI): | | −5.5% (−21.7%, 10.7%) | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Success rate (% with<=1 AOM episode) in 1 year in patients with no tonsil-related indications: | | | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Adenoidectomy: | | 48% (29/61) | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Adenotonsillectomy: | | 59% (42/71) | | Not enough evidence to conclude
9 | Adenoidectomy vs. adenotonsillectomy | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenoidectomy Adenotonsillectomy | Mean difference (95% CI): | | −11.7% (−28.7%, 5.4%) | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Success rate (% with no AOM episode) in 1 year in patients with no tonsil-related indications: | | | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Adenotonsillectomy: | | 37% (26/71) | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Placebo: | | 22% (17/79) | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Mean difference (95% CI): | | 15.1% (0.6%, 29.6%) | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Success rate (% with<=1 AOM episode) in 1 year in patients with no tonsil-related indications: | | | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Adenotonsillectomy : | | 59% (42/71) | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Placebo: | | 51% (40/79) | | Not enough evidence to conclude
10 | Adenotonsillectomy vs. placebo | Paradise, 1999^26^ | 3–15yrs 1 hosp in US | Adenotonsillectomy Placebo | Mean difference (95% CI): | | 8.6% (−7.4%, 24.6%) | | Not enough evidence to conclude
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Success rate (no recurrence after treatment) up to day 14 from start of treatment: | | | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Ceftibuten 5d: | | 79% (70/89) | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Ceftibuten 10d: | | 96% (85/89) | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Mean difference (95% CI): | | −17% (−27%, −7%) | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Success rate (no recurrence after treatment) up to day 40 from start of treatment: | | | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Ceftibuten 5d: | | 65% (58/89) | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Ceftibuten 10d: | | 70% (62/89) | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
11 | Ceftibuten 5d vs. Ceftibuten 10d | Roos, 2000^131^ | 0.5–8yrs 6 centers in Sweden | Ceftibuten 5d (9mg/kg/d) Ceftibuten 10d (9mg/kg/d) | Mean difference (95% CI): | | −5.0% (−18.8%, 8.8%) | | Ceftibuten 10d had a higher short-term success rate than Ceftibuten 5d but there is not enough evidence to conclude for success rate on day 40.
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Success rate (% with no AOM) during 6-month intervention | | | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Probiotic: | | 28% (38/135) | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Placebo: | | 35% (47/134) | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Mean difference (95% CI): | | −7% (−18%, 4%) | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Success rate (%<3 AOM) during 6-month intervention | | | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Probiotic: | | 82% (111/135) | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Placebo: | | 83% (111/134) | | Not enough evidence to conclude
12 | Probiotics vs. placebo | Hatakka, 2007^91^ | 10mo–6yrs Helsinki, Finland | One probiotic capsule (Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99 and propionibacterium freudenreichii JS) qd for 6mos Placebo, qd for 6mos | Mean difference (95% CI): | | −1% (−10%, 8%) | | Not enough evidence to conclude
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only | Mean±SD (n) number of otitis media episodes during 1-year follow-up | | | | Not enough evidence to conclude
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only | Adeno+Tympan: | | 1.9 ± 1.9 (74) | | Not enough evidence to conclude
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only | Tympan only: | | 1.6 ± 1.6 (72) | | Not enough evidence to conclude
13 | Adenoidectomy and tympanostomy vs. Tympanostomy only | Hammaren-Malmi, 2005^132^ | 1–2yrs Helsinki, Finland | Adenoidectomy + tympanostomy Tympanostomy only | Difference of mean (95% CI): | | 0.30 (−0.28, 0.88) | | Not enough evidence to conclude
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Outcome: ≥1 episode of AOM during 3-month study period | | | | Propolis and zinc had a lower proportion of children with AOM and mean number of AOM episodes than the control during the study period.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Propolis+Zinc | | Controls | Diff (95% CI) | Propolis and zinc had a lower proportion of children with AOM and mean number of AOM episodes than the control during the study period.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | 51% (31/61) | | 71% (43/61) | −20% (−37, −3) | Propolis and zinc had a lower proportion of children with AOM and mean number of AOM episodes than the control during the study period.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Outcome: mean number of episodes of AOM per child/month during 3-month study period | | | | Propolis and zinc had a lower proportion of children with AOM and mean number of AOM episodes than the control during the study period.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Propolis/Zn | Controls | Diff(95% CI) | p | Propolis and zinc had a lower proportion of children with AOM and mean number of AOM episodes than the control during the study period.
14 | Propolis and zinc vs. Elimination of environmental risk factors | Marchisio, 2010^133^ | 1–5yrs Italy | 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | 0.23±0.26 | 0.34±0.29 | 0.11(0.01, 0.21) | 0.3 | Propolis and zinc had a lower proportion of children with AOM and mean number of AOM episodes than the control during the study period.

Also identified were seven systematic reviews that addressed the question of prevention of recurrent AOM. We present the results of these reviews below.

In addition to the literature search described for Key Question III, we also conducted a search of the literature from 1966 to the present using the strategy described in Appendix A. This search identified some 1400 titles. A screen of a sample of these titles revealed very few actually relevant to the topic. We therefore did not pursue this search strategy, which would have added mostly older (pre-2001) articles.

### Findings on Treatment of Acute Otitis Media in Children With Recurrent Otitis Media

The systematic review by Abes (2003) is relevant only for children with tympanostomy tubes, presumably for ROM or persistent OME or some other chronic middle-ear condition not specified by the investigators.134 Abes (2003) compared ofloxacin 0.3% otic solution to other otic antibiotic drops and oral antibiotics in treating acute or chronic suppurative otitis media in a systematic review that complied with nine of 11 quality criteria but was not focused solely on children.134 They identified two studies of children 1–12 years old with tympanostomy tubes and AOM.135, 136 Goldblatt (1998) reported a clinical success rate (Peto odds ratio) of 1.44 (95% CI: 0.86, 2.42) between ofloxacin otic solution received by 140 children and other medical treatments received by 146 children.137 Dohar (1999) reported a clinical success rate (Peto odds ratio) of 2.76 (95% CI: 1.72, 4.42) between ofloxacin otic solution received by 143 children and other medical treatments received by 218 children.136 Based on these two studies with different findings, we cannot draw any conclusion regarding the superiority of any of the treatments or their equivalence in these children with tympanostomy tubes who presumably had ROM or persistent otitis media with effusion or some other chronic middle-ear condition, not specified by Abes. Another review, by Wall (2009), complied with only two of 11 quality criteria, so the results are not reported here.138(Table 22).

The overall quality of evidence for these comparisons is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Studies identified by the AOM review update on treatment of AOM in children with recurrent and/or persistent AOM. Five individual studies compared antibiotic treatments for AOM in children with ROM or persistent AOM. None of the studies demonstrated significant advantage for any particular treatment.121–125

Amoxicillin-clavulanate vs. gatifloxacin. Two RCTs addressed this comparison among 367 and 241 children with recurrent AOM and/or AOM with treatment failure (AOMTF), where AOMTF was defined as infection within 14 days of the last antibiotic dose or failure to improve after 48 hours. The children ranged in age from 6 months to 7 years.121, 122 Saez-Llorens (2005) examined the success rate on day 3–10 while Sher (2005) examined the success rate on day 10. Saez-Llorens (2005) found a mean difference of −6% (95% CI: −13%, 1.%) and Sher (2005) found a mean difference of −6% (95% CI: −16%, 4%), both favoring gatifloxacin but without statistical significance. The advantage of either treatment over the other or their equivalence cannot be established based on the current evidence.

Amoxicillin-clavulanate vs. levofloxacin. One RCT addressed this comparison in children with recurrent and/or persistent AOM, where persistence was defined as signs or symptoms of AOM after 48 hours of treatment or after three days of treatment.123 It compared the treatment success rates among children 6 months to 5 years of age in 6 different countries on day 2–5 of treatment (Jadad quality score 3 of 5). The success rate difference between amoxicillin-clavulanate and levofloxacin was −3% (95% CI: −6%, −0.2%). We cannot determine the advantage of either treatment or their equivalence based on the current evidence. In order to show equivalence, the 95% confidence interval must lie within the zone of MCID.

Amoxicillin-clavulanate vs. azithromycin. One RCT addressed this comparison in children with recurrent and/or persistent AOM.124 The study, which included 294 children 6 months to 6 years of age (Jadad quality score 3 of 5), reported a treatment success rate difference of −2% (95% CI : −10%, 6%) between amoxicillin-clavulanate and azithromycin. We cannot draw any conclusion regarding the superiority of either treatment or their equivalence from the existing evidence.

Cefaclor vs. cefuroxime. One RCT addressed this comparison.125 The study, which included 148 children 3 months to 12 years of age who had failed initial AOM treatment (Jadad quality score 2 of 5), reported a treatment success rate difference between cefaclor and cefuroxime at day 10 of 0.7% (95% CI : −7%, 9%) at day 10 and −1.2% (95% CI : −12%, 10%) at day 20–26. We cannot draw any conclusion regarding the superiority of either treatment or their equivalence from the existing evidence in these children, who had failed initial AOM treatment, presumably with persistent or relapsing AOM, although not specified by the authors.

The overall quality of evidence for these comparisons is considered low, meaning that further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Children with tympanostomy tubes. Three additional individual studies were identified that studied the effect of otic antibiotic drops in treatment of AOM in children who had tympanostomy tubes. As was the case for the studies included in the Abes (2003) review, these studies are unclear on the indication for tympanostomy tubes, whether for ROM or persistent otitis media with effusion or some other chronic middle-ear condition, so it is difficult to assess the generalizability of the findings.80, 126, 127

Amoxicillin-clavulanate vs. ciprofloxacin-dexamethasone. One RCT addressed this comparison.80 The study, which included 80 children 6 months to 12 years of age with tympanostomy tubes and AOM (Jadad quality score 2 of 5), reported a treatment success rate difference between amoxicillin-clavulanate and ciprofloxacin 0.3%-dexamethasone 0.1% otic drops at day 18–21 of −26% (95% CI: −46%, −6%). Ciprofloxacin-dexamethasone otic drops had a higher success rate than amoxicillin-clavulanate in these children with tympanostomy tubes for indications not specified by the investigators.

Ciprofloxacin vs. ciprofloxacin-dexamethasone. One RCT addressed this comparison.126 The study, which included 167 children 6 months to 12 years of age with tympanostomy tubes and AOM (Jadad quality score 2 of 5), reported a treatment success rate difference between ciprofloxacin 0.3% otic drops and ciprofloxacin 0.3%-dexamethasone 0.1% otic drops at day 8 of −3% (95% CI: −11%, 5%) and at day 14 of −5% (95% CI: −11%, 0.5%). We cannot draw any conclusion regarding the superiority of either treatment or their equivalence from the existing evidence in these children with tympanostomy tubes for indications not specified by the investigators.

Ciprofloxacin-dexamethasone vs. ofloxacin. One RCT addressed this comparison.127 The study, which included 423 children 6 months to 12 years of age with tympanostomy tubes and AOM (Jadad quality score 2 of 5), reported a treatment success rate difference between ciprofloxacin 0.3%-dexamethasone 0.1% otic drops and ofloxacin 0.3% otic drops of 14% (95% CI: 8%, 21%), at day 3, of 6% (95% CI: 1%, 11%) at day 11,of 5% (95% CI: −0.2%, 11%) at day 18, and difference in clinical cure rate at day 18–21 of 12% (95% CI: 4%, 19%). The study also reported a difference in otorrhea absence of 14% (95% CI: 5.4%, 22%) at day 3, 21% (95% CI: 13%, 30%) at day 11, and 14% (95% CI: 6%, 22%) at day 18. Ciprofloxacin-dexamethasone otic drops had a higher success rate than ofloxacin otic drops for clinical success at day 3, for clinical cure at days 18–21, and for otorrhea absence at days 3, 11, and 18 in these children with tympanostomy tubes for indications not specified by the investigators.

### Findings on Prevention of Acute Otitis Media in Children with Recurrent Otitis Media

Previous systematic reviews. We identified five previous systematic reviews of prevention of AOM in children with ROM.139–143 (See Appendix I for complete descriptions of these systematic reviews.) Three addressed antibiotic prophylaxis of children with ROM.139, 140, 142 One addressed the role of tympanostomy tubes for children with ROM.143 Table 22 summarizes the references found in these five systematic reviews and the controls, interventions, and outcomes utilized in each of the relevant studies from these systematic reviews. As comparison, Table 22 also includes the seven articles identified for this report on prevention of AOM in children with ROM. Of the articles identified for this report, only Teele (2000) was included in one of the previous systematic reviews (Leach, 2006), although the study by Koivunen (2004) was listed as pending assessment in that same review.129, 130, 142 Note that these systematic reviews utilized the 95% confidence limits to judge significance of findings and did not use the concept of the zone of MCID.

Antibiotic prophylaxis. Because the 2006 review by Leach included all studies utilized by the earlier reviews by Bonati (1992) and Williams (1993), we will report only the main findings from Leach (2006).139, 140, 142

Leach (2006) conducted a literature search encompassing 1950–2006 and identified 16 studies129, 145–159 that addressed the effectiveness of antibiotic prophylaxis to prevent AOM in children 0–18 years old at increased risk of future episodes of AOM as defined as otitis prone with three or more episodes of AOM in six months or four or more episodes of AOM in one year, high-risk children with a history of AOM with perforation, and children in high-risk populations with chronic suppurative otitis media prevalence ≥4%. The Leach (2006) systematic review scored affirmatively on 10 of 11 AMSTAR quality criteria but did not specifically address the conflicts of interest of each study included in the review.142 The following are the primary outcomes of this review for all high-risk populations:

Pooling data from 13 studies, 12 on children with ROM of varying definition (of which seven met the current review’s criteria and one was on children from a high-risk population), the risk ratio for any AOM during the intervention was 0.6 (95% CI: 0.5, 0.8; random-effects model, I^2^=52%, p=0.02), i.e. an absolute risk reduction of 20%, equivalent to needing to treat five children (95% CI: 4, 6) with long-term antibiotics to prevent one child from getting an episode of AOM while on treatment.129, 145, 146, 148, 150, 152–159 Pooling data from 12 studies, the incidence rate ratio for episodes of AOM during the intervention was 0.5 (95% CI: 0.4, 0.6; random effects-model, I^2^=65%), but the studies were statistically hetereogeneous.145, 147, 148, 150, 151, 153–157, 159 For both primary outcomes, none of the studies reported on AOM with perforation or chronic suppurative otitis media.

Perhaps more relevant to the current review, the Leach review (2006) did sub-group analysis of otitis prone vs. non-otitis-prone children for the primary outcomes. Pooling data from seven studies, the risk ratio for any AOM during the intervention for otitis prone children was 0.7 (95% CI: 0.6, 0.8; fixed-effect model, I^2^=33%).150, 151, 153–156, 159, 160

Pooling data from eight studies, the incidence rate ratio for episodes of AOM during the intervention for otitis prone children was 0.5 (95% CI: 0.4, 0.7; random-effects model, I^2^=73%), but the studies were statistically heterogeneous.147, 150, 151, 153–156, 159 Leach (2006) concluded that antibiotics will prevent 1.5 episodes of AOM for every 12 months of treatment per otitis-prone child (95% CI: 1.2, 2.1) who would otherwise average three episodes of AOM annually. The results were not affected by sensitivity analyses.

Tympanostomy tubes. McDonald and colleagues (2008) conducted a literature search encompassing 1950–2008 and identified two studies that addressed the effectiveness of tympanostomy tube placement to prevent AOM in children 0–16 years old with ROM as defined as three or more AOM episodes in six months or four or more AOM episodes in one year.161, 162 The McDonald (2008) systematic review scored affirmatively on eight of 11 AMSTAR quality criteria but did not address publication status, publication bias assessment, and conflicts of interest of each study included in the review.143 Pooling data from two studies, the odds ratio for more than one episode of AOM for six months following tympanostomy tube placement was 0.2 (95% CI: 0.1, 0.4). 161, 162 McDonald (2008) concluded that ventilation tube placement played a significant role in maintaining a disease-free state in the first six months after tube insertion in children with ROM in these two studies.143

Studies identified by the AOM review update on prevention of AOM in children with ROM. Seven studies identified by our searches address the prevention of AOM in children with ROM.26, 91, 128–132 These studies include five not identified by or pertinent to previous systematic reviews, one excluded by a previous systematic review, and one included in a previous review for which we provide greater detail.129

Antibiotic or non-surgical treatment. Seven individual studies compared antibiotic or non-surgical treatments to prevent AOM in children with ROM. None of the studies demonstrated a long-term advantage for any particular antibiotic or non-surgical treatment.

Amoxicillin vs. azithromycin. One RCT addressed the comparison of amoxicillin and azithromycin (three months treatment duration) among 69 children ranging in age from 9 months to 10 years (Jadad quality score 2 of 5).128 The treatment outcome of interest was 50% reduction in AOM episodes. The study reported a rate difference of 9% in this outcome between amoxicillin and azithromycin at six to 27 months (95% CI: −8%, 26%). No conclusion can be derived from the existing evidence regarding the superiority of one or the other agent or their equivalence. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Amoxicillin vs. sulfisoxazole. One RCT (Teele, 2000) addressed the comparison of amoxicillin and sulfisoxazole among 76 children ranging in age from birth to 1 year (Jadad quality score 3).129 The study reported a success rate difference between amoxicillin and sulfisoxazole of 12% (95% CI: −4%, 29%) in six-month follow-up and a success rate difference of 4% (95% CI: −18%, 25%) in 12-month follow-up. No conclusion of antibiotic advantage or equivalence can be derived from the existing evidence. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Amoxicillin vs. placebo. The Teele (2000) study also compared amoxicillin vs. placebo among 81 children.129 The study reported a success rate difference between amoxicillin and placebo of 19% (95% CI: 2%, 37%) in six-month follow-up and a success rate difference of 2% (95% CI: −19%, 22%) in 12-month follow-up. No conclusion can be derived from the existing evidence regarding the efficacy of amoxicillin with a MCID of ±5%. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Sulfisoxazole/sulfafurazole vs. placebo. Two RCTs addressed this comparison among 77 children, 0 to 12 months of age, and 93 children, 10 months to 2 years of age, respectively.129, 130 The Teele 2000 article defined success as one or fewer AOM episodes at six-month or one-year follow-up, whereas Koivunen (2004) defined success as one or fewer AOM episodes in two months, two or fewer AOM episodes in six months, or less than two months of MEE at six-month or two-year follow-up (Jadad quality score 3 of 5).129, 130 The Teele 2000 study reported a success rate difference between sulfisoxazole and placebo of 7% (95% CI: −13%, 27%) in six-month follow-up and a success rate difference of −2% (95% CI: −23%, 20%) in 12-month follow-up.129, 130 reported a success rate difference between sulfafurazole and placebo of 18% (95% CI: −2%, 39%) at six-month follow-up and a success rate difference of 12% (95% CI of −7%, 31%) at two-year follow-up.130 No conclusion can be derived from the existing evidence regarding the efficacy of sulfisoxazole/sulfafurazole for either outcome. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Ceftibuten 5-day vs. ceftibuten 10-day. One trial compared five days with 10 days of ceftibuten.131 The study included 178 children, ages 6 months to 8 years, and defined treatment success as no recurrence. Treatment success was measured at two different time points: at day 14 and at day 40. At day 14, the difference in treatment success between the five-day and 10-day treatment options was −17% (95% CI: −27%, −7%); the 95% CI for the day-14 success rate is outside the zone of MCID of ±5%, favoring the longer treatment option. At day 40, the difference in treatment success between the five-day and 10-day treatment options was −5% (95% CI: −19%, 9%), again favoring the longer treatment. The long-term effectiveness of the ceftibuten 10-day treatment option cannot be established at this point. The overall quality of evidence for this comparison is considered low, meaning that further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Probiotics vs. placebo. One RCT assessed the effects of treatment with probiotics compared with placebo in a group of 269 children ages 10 months to 6 years.91 The Jadad quality score for this trial was 5. The treatment consisted of one capsule daily for six months; the capsule contained Lactobacillus rhamnosus GG and LC705, Bifidobacterium breve 99, and propionibacterium freudenreichii JS. Treatment success was defined by the number of AOM episodes during the 6-month intervention period (proportion of children experiencing no episodes of AOM, proportion experiencing fewer than three AOM episodes). The difference in treatment success between probiotics and placebo was −7% (95% CI: −18%, 4%) for no AOM episodes and −1% (95% CI: −10%, 8%) for fewer than three AOM episodes during the six-month follow-up period. No conclusion of treatment advantage or equivalence can be derived from the existing evidence for either outcome. The overall quality of evidence for this comparison is considered low, meaning that further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Propolis and zinc vs. elimination of environmental risk factors. Propolis is “a natural product collected by bees from the exudates of plants” (Marchisio, 2010).133 One RCT assessed the effects of treatment with propolis and zinc plus elimination of environmental risk factors compared with elimination of environmental risk factors alone. The Jadad quality score for this trial was 2. The treatment consisted of 0.3 ml/kg/d of 30% hydroglyceric extract of propolis and 1.2% zinc sulfate once daily for three months. The proportion of children with AOM and febrile respiratory tract infections and of children treated with antibiotics for those conditions during the study period was measured as was the mean number of episodes of AOM and respiratory tract infections and antibiotic courses. Also, mean duration of bilateral OME and parental satisfaction were measured. The difference in the proportion of children with one or more episodes of AOM was 26.2% (95% CI: 9.6%, 42.8%) less in the treatment group as was the mean number of antibiotic courses for AOM, −0.34 (95% CI: −0.59, −0.09). The overall quality of evidence for this comparison is considered low, meaning that further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Surgical vs. surgical or non-surgical treatment. Six comparisons of surgical vs. surgical or non-surgical treatments to prevent AOM in children with ROM were identified. None of the comparisons demonstrated a significant advantage for any particular surgical or non-surgical treatment.

Sulfafurazole vs. adenoidectomy. Koivunen (2004) also reported a comparison between sulfafurazole and adenoidectomy.130 The study defined treatment success as one or fewer episodes of AOM in two months or two or fewer episodes of AOM in six months or less than two months of MEE at six-month or two-year follow-ups. A total of 105 children were examined at six months. The reported difference in success rate between sulfafurazole and adenoidectomy was 5% (95% CI: −14%, 24%) at the six-month follow-up and a difference of 7% (95% CI: −12%, 25%) at the two-year follow-up, both favoring the drug. Thus, no conclusion of advantage or equivalence can be derived for either treatment from the existing evidence for either outcome. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Adenoidectomy vs. placebo. Two RCTs addressed this comparison.26, 130 Paradise (1999) defined treatment success as no AOM episode in one year, or one or fewer AOM episodes in one year in patients with no tonsil-related indications.26 This study compared 140 children ranging in age from 3 to 15 years and had a Jadad quality score of 2.^26^ Koivunen (2004) defined treatment success as one or fewer episodes of AOM in two months, or two or fewer episodes of AOM in six months, or less than two months of MEE at the six-month or two-year follow-ups.130 Paradise (1999) reported a difference in treatment success rates of 10% (95% CI: −5%, 24%) when success was defined as no AOM episodes during the year (favoring the procedure) and a difference of −3% (95% CI: −20%, 14%) when success was defined as one or fewer AOM episodes during the year.26 Koivunen (2004) reported a difference of 13% (95% CI: −6%, 32%) at 6-month follow-up and a success rate difference of 5% (95% CI: −11%, 22%) at two-year follow-up, both favoring the procedure.130 Thus, no conclusion of surgical advantage or equivalence can be derived from the existing evidence for any outcome. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Adenoidectomy vs. adenotonsillectomy. Paradise (1999) also compared adenoidectomy with adenotonsillectomy in a total of 132 children.26 The study defined treatment success as no AOM episode in one year or as one or fewer AOM episodes in one year in patients with no tonsil-related indications. The reported difference in treatment success was −6% (95% CI: −22%, 11%) when success was defined as no AOM episodes during the year and −12% (95% CI: −29%, 5%) when success was defined as one or fewer AOM episodes during the year, both favoring adenotonsillectomy. Thus, no conclusion of advantage or equivalence for the surgical procedures can be derived from the existing evidence for either outcome. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Adenotonsillectomy vs. placebo. Paradise (1999) also compared adenotonsillectomy with placebo in a total of 150 children.26 The study defined treatment success as no AOM episode in one year or as one or fewer AOM episodes in one year in patients with no tonsil-related indications. The difference in success rates was 15% (95% CI: 0.6%, 30%) when success was defined as no AOM episodes during the year and 9% (95% CI: −7%, 25%) when success was defined as one or fewer AOM episodes during the year, both favoring the procedure. Thus, no conclusion of advantage or equivalence can be derived for either intervention from the existing evidence for either outcome with a MCID of ±5%. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

Adenoidectomy plus tympanostomy vs. tympanostomy alone. One RCT compared the efficacy of adenoidectomy plus tympanostomy with that of tympanostomy alone for prevention of AOM in children with ROM.132 The study, which enrolled a total of 198 children ranging in age from one to two years, defined treatment success as the mean number of otitis media episodes during one year of follow-up (Jadad quality score was 2 of 5). No conclusion of advantage or equivalence of the surgical procedure can be derived from the existing evidence for either outcome. The overall quality of evidence for this comparison is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

### Summary

To answer the question, we assessed the efficacy of both treatment and prevention of AOM in children with ROM, persistent AOM, or AOM treatment failure.

Regarding the treatment of AOM in children with ROM, persistent AOM, or AOM treatment failure, the available evidence identified for this study provided the following conclusions:

- The evidence did not allow us to reach strong conclusions regarding the comparisons of amoxicillin-clavulanate vs. gatifloxacin, amoxicillin-clavulanate vs. levofloxacin, and amoxicillin-clavulanate vs. azithromycin.
- For children with tympanostomy tubes and AOM, ciprofloxacin 0.3%-dexamethasone 0.1% otic drops appeared to have higher success rate than amoxicillin-clavulanate at days 18–21 in one study.80
- In another study of children with tympanostomy tubes, ciprofloxacin-dexamethasone had a higher success rate than ofloxacin 0.3% otic drops at day three but not at days 11, 18, or 18–21 (end of treatment assessment), and produced a higher rate of otorrhea absence at days 3, 11, and 18.^127^ However, in both studies it is not entirely clear why the children had tympanostomy tubes, whether for ROM, persistent otitis media with effusion, or some other chronic middle-ear condition; so, the generalizability of these findings is limited.

Regarding the prevention of AOM in children with ROM, the available evidence from prior systematic reviews provided the following conclusions:

- Long-term antibiotics, defined as weeks or longer, decreased episodes of AOM from 3 to 1.5 for every 12 months of treatment per otitis-prone child during active treatment.142
- Tympanostomy tube placement played a significant role in maintaining a disease-free state in the first six months after tube insertion in children with ROM.143 This conclusion is qualified by the observation that only two studies contributed data to this pooled analysis. It may also be tempered by the issue of AOM diagnostic accuracy in the presence of tympanostomy tubes possibly confounding these results, i.e. the pressure equalization and drainage afforded by the tubes and their physical presence decreasing the intensity or visibility of signs and symptoms used to diagnose AOM, leading to false negatives.
- A statement cannot be made regarding the role of pneumococcal vaccine in reducing AOM in children with ROM based on the available systematic review.141 Although pooled analyses favored a modest benefit for the vaccine, methodologic problems with the original studies included in the analysis preclude a strong conclusion.

No definitive conclusions could be drawn regarding the 13 comparisons identified by this study for prevention of AOM in children with ROM that looked at amoxicillin vs. azithromycin, amoxicillin vs. sulfisoxazole, amoxicillin vs. placebo, sulfisoxazole vs. placebo, ceftibuten five-day vs. 10-day, probiotics vs. placebo, sulfafurazole vs. adenoidectomy, adenoidectomy vs. placebo, adenoidectomy vs. adenotonsillectomy, adenotonsillectomy vs. placebo, ceftibuten five-day vs. 10-day, probiotics vs. placebo and adenoidectomy plus tympanostomy vs. tympanostomy.

## Key Question V Do Treatment Outcomes in Key Questions III and IV Differ by Characteristics of the Condition (AOM), Patient, Environment, and/or Health Care Delivery System?

Of the 48 RCTs newly identified in our review that addressed the effectiveness of treatment options in uncomplicated acute otitis media (Key Question 3), 15 trials reported analyses for subgroups stratified by age, presence of MEE, laterality, identity of daytime caretaker (use of daycare), hearing deficit and severity, otorrhea, examiner, and pneumococcal vaccine. Of the 10 trials identified in our review that addressed the effectiveness of treatment options in recurrent otitis media (Key Question 4), three reported analysis by age subgroups. One reported stratified analysis by laterality and severity of otitis media. A listing of the articles reporting subgroup analysis and the drug comparisons studied is provided in Table 23. In addition, we report relevant findings from previous systematic reviews as cited in the responses to Key Questions III and IV.

Table 23 Listing of Articles Reported Subgroup Analysis on Effectiveness of Treatment Options

(A) KQ3 – Uncomplicated Otitis Media
Factor | # Comp | Comparisons | Author, Year
Age | 14 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^
| | Amoxicillin vs. Azithromycin | Morris, 2010^67^
| | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^
| | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^
| | Amoxicillin (Amox)-clavulanate (clav) 5d vs. Amox-clav 10d | Cifaldi, 2004^74^
| | Amox-clav vs. Cefdinir (qd10d) | Block, 2000^72^
| | Amox-clav vs. Cefdinir (bid10d) | Block, 2000^72^
| | Amox-clav vs. Cefdinir (bid5d) | Block, 2004^75^
| | Amox-clav vs. Cefprozil | Hedrick, 2001^76^
| | Amox-clav vs. Cefuroxime | Pessey, 1999^79^
| | Azithromycin vs. Cefdinir | Block, 2005^83^
| | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^
| | Cefprozil vs. Cefdinir | Block, 2000^85^
Laterality | 2 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^
| | Amox-clav vs. Cefprozil | Hedrick, 2001^76^
Caretaker | 2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^
| | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^
Hearing deficit and severity | 1 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^
Otorrhea | 1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^
Examiner | 1 | Aqueous lidocaine drop vs. placebo | Bolt, 2008^90^
Pneumococcal vaccine | 1 | Amox-clav vs. Cefdinir | Block, 2004^75^

(B) KQ4 – Recurrent Otitis Media
Factor | # Comp | Comparisons | Author, Year
Age | 3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^
| | Amox-clav vs. Gatifloxacin | Sher, 2005^122^
| | Amox-clav vs. Azithromycin | Arrieta, 2003^124^
Laterality | 1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^
Severity | 1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^

### Age Factor in Uncomplicated Acute Otitis Media

We identified 14 trials for the review update that analyzed the effectiveness of treatment options by age group. The study by Cifaldi (2004) examined effectiveness from the parent’s perspective only, whereas the other 13 articles reported other clinical outcomes. The latter 13 studies assessed 14 treatment comparisons by age group. Table 24 provides a summary of the findings on clinical success rate by age groups.

Table 24 Summary of Findings from 13 Articles (14 Comparisons) Assessing Clinical Success Rate of Interventions in Uncomplicated Acute Otitis Media Stratified by Age

Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | Outcome: Success rate (cure or improvement) at day 12–14: −0.2% (−10, 9) | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | Amox | Azithromycin | Diff (95% CI) | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | All pts | 84.1% (127/151) | 3.9% (130/155) | 0.2% (−8, 8) | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | <=2yrs | 81.8% (99/121) | 82.0% (109/133) | −0.2% (−10, 9) | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | >2yrs | 93.3% (28/30) | 95.4% (21/22) | −2.1% (−15, 11) | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | Diff (95% CI) | −12% (−26, 3.1) | −13% (−30, 3.2) | | Not enough evidence to conclude
1 | Amoxicillin vs. Azithromycin | Arguedas, 2005^66^ | 6–30 months Multi-centers in US, Finland, Chile, Costa Rica | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | Outcome: Clinical success between day 6 and day 11 | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | Amox | Azithromycin | Diff (95% CI) | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | All pts | 46% (72/155) | 50% (83/165) | −4% (−15, 7) | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | <=2yrs | 46% (57/125) | 51% (64/125) | −5% (−18, 7) | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | >2yrs | 50% (15/30) | 47% (19/40) | 3% (−21, 26) | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | | | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | Diff (95% CI) | −4% (−24, 15) | 4% (−14, 21) | | Not enough evidence to conclude
2 | Amoxicillin vs. Azithromycin | Morris, 2010^67^ | 6 months–6 years Aboriginal 16 centers Australia Rural and remote communities | Amoxicillin 50 mg/kg/day / bid for 7 days Vs. Azithromycin 30 mg/kg as a single dose | | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | Outcome: Clinical success on day 9–11 | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | Amox | Erythromycin | Diff (95% CI) | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | By drugs | 96% (133/139) | 94% (132/141) | 2% (−3, 7) | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | (combines both antibiotic groups) | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | <=2yrs | >2years | Diff (95% CI) | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | By Age | 90% (35/39) | 95% (230/241) | −6% (−13, 2) | Not enough evidence to conclude
3 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | Outcome: Cumulative clinical resolution rates at 14 days | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | Amox | Placebo | Diff (95% CI) | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | All ages | 93% (232/250) | 84% (202/240) | −9% (−14, −3) | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | 6–23 mo | 85% (76/89) | 79% (73/92) | −6% (−17,5.2) | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | 2–5 yrs | 97% (156/161) | 87% (129/148) | −10% (−16, −3.8) | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | Diff (95% CI) | −12% (−19, −5.3) | −8% (−18, 1.6) | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
4 | Amoxicillin vs. Erythromycin | Le Saux, 2005^89^ | 6 months–5 years Canada Emergency room, Pediatric practice | Amoxicillin 60 mg/kg/day / tid for 10 days vs. placebo | | | | | Not enough evidence to conclude between treatment effectiveness within age group. Age <2 years had lower success rate than >=2 years
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | Outcome: Success rate at Day 0–12 | | | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | | | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | Amox | Wait-and- see | Diff (95% CI) | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | | | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | Total | 95% (102/107) | 80% (86/107) | 15% (6, 24) | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | | | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | <2 yrs | 94% (60/64) | 78% (42/54) | 16% (4, 28) | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | | | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | ≥2 yrs | 98% (42/43) | 83% (44/53) | 5% (−4, 13) | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | | | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | Diff (95% CI) | −4% (−12, 3.9) | −5% (−20, 10) | | Amox had higher success rate for all age; cannot conclude by age group.
5 | Amoxicillin vs. Wait-and-see | McCormick, 2005^3^ | 6 months- 12years U.S. Hospital clinic/ outpatient, University/ academic | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Wait and see | | | | | Amox had higher success rate for all age; cannot conclude by age group.
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Outcome: Clinical success (cure+improvement) at day 10 | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Amox- clav | Azithro | Diff (95% CI) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | All ages | 88% (159/181) | 83% (153/183) | 5%(−2, 12) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | ≤2 yrs | 85% (44/52) | 76% (45/59) | 9% (−6, 24) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | >2 yrs | 73% (94/129) | 86% (108/126) | −13%(−23, −3) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Diff (95% CI) | 12% (−2, 26) | −10% (−22, 2) | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Outcome: Clinical success (cure+improvement) at day 24–28 | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Amox-clav | Azithro | Diff (95% CI) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | All ages | 69% (124/180) | 74% (134/182) | −5%(−14, 4.3) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | ≤2 yrs | 58% (30/52 | 60% (35/58) | −2%(−20, 16) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | >2 yrs | 73% (94/128) | 80% (99/124) | −7% (−18, 3.5) | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Diff (95% CI) | −15% (−30, 0) | −20% (−34, −6) | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
6 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Clinical success at day 24–28 for Azithromycin higher among those >2yrs than ≤2yrs. Others are inconclusive
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | Outcome: Clinical success (cure or improvement) 2–4 days after treatment: Amox-clav vs. Cefdinir QD | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | A-C | CDR-QD | Diff (95% CI) | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | Total | 86% (86/100) | 83% (85/102) | 0.7% (−7, 13) | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | <2 yrs | 79% (31/39) | 80% (45/56) | −1% (−17, 15) | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | ≥2 yrs | 90% (55/61) | 87% (40/46) | 3% (−9, 15) | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | 2–5 yrs | 85% (35/41) | 84% (31/37) | 1.6% (−14, 18) | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | 6–12 yrs | 100% (20/20) | 100% (9/9) | 0.0% | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | Diff (95% CI) | −11% (−25, 2.8) | −7% (−22, 8) | | Not enough evidence to conclude
7 | Amox-clav vs. Cefdinir (QD 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days | | | | | Not enough evidence to conclude
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | Outcome: Clinical success (cure or improvement) 2–4 days after treatment: Amox-clav vs. Cefdinir BID | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | A-C | CDR-BID | Diff (95% CI) | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | Total | 86% (86/100) | 80% (81/101) | 6% (−4, 16) | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | <2 yrs | 79% (31/39) | 62% (30/48) | 17% (−2, 36) | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | ≥2 yrs | 90% (55/61) | 96% (51/53) | −6% (−15, 3.4) | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | 2–5 yrs | 85% (35/41) | 95% (35/37) | −9% (−23, 4) | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | 6–12 yrs | 100% (20/20) | 100% (16/16) | 0.0% | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | Diff (95% CI) | −11% (−25, 2.8) | −34% (−50, −19) | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
8 | Amox-clav vs. Cefdinir (BID 10days) | Block, 2000^72^ | 6 months–12years Multi-centers in U.S. | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | | | Not enough evidence to conclude relative effectiveness between treatments within each age group. Age <2 years had lower success rate with CDR-BID
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | Outcome: Success at end-of-treatment visit (study days 7–9 for Cefdinir; study days 12–14 for Amox-clav) | | | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | A-C | Cefdinir | Diff (95% CI) | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | Total | 85% (164/192) | 88% (170/194) | −2% (−9, 4.6) | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | <2 yrs | 78% (64/82) | 88% (79/90) | −10% (−21, 2.4) | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | 2–6 yrs | 91% (100/110) | 88% (91/104) | 3% (−4.9, 12) | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | Diff (95% CI) | −13% (−23, −3) | 0% (−9, 9) | | Not enough evidence to conclude
9 | Amox-clav vs. Cefdinir (BID 5- day) | Block, 2004^75^ | 6 months–6years Multi-centers in U.S. | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Outcome: Clinical success (cure or improved) at day 4–7 after treatment | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | A-C | Cefprozil | Diff (95% CI) | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Total | 89% (116/130) | 87% (110/127) | 2% (−6, 10) | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | <2 yrs | 86% (55/64) | 80% (47/59) | 6% (−7, 19) | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | 2–7 yrs | 92% (61/66) | 93% (63/68) | −1% (−10, 8) | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Diff (95% CI) | −6% (−17, 4.7) | −13% (−25, −1.3) | | Not enough evidence to conclude
10 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | Outcome: Satisfactory clinical response post- treatment – A-C10d vs. CE | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | A-C10d | CAE | Diff (95% CI) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | Total | 88% (181/205) | 86% (175/203 ) | 2% (−4.5, 8.5) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | <1.5 yrs | 89% (116/131) | 83% (111/134 ) | 6% (−2.4, 14) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | 1.5–3 yrs | 88% (65/74) | 93% (64/69) | −5% (−15, 4.7) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | Diff (95% CI) | 1% (−8, 10) | −10% (−20, 0) | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | Outcome: Satisfactory clinical response post- treatment – A-C8d vs. CE | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | A-C8d | CAE | Diff (95% CI) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | Total | 88% (145/165) | 86% (175/203) | 2% (−4.9, 9) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | <1.5 yrs | 84% (83/99) | 83% (111/134) | 1% (−9, 11) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | 1.5–3 yrs | 94% (62/66) | 93% (64/69) | 1% (−7, 9) | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | Diff (95% CI) | −10% (−20, 0) | −10% (−20, 0) | | Not enough evidence to conclude
11 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | 6 months–3years Multi-centers in France | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days (A-C10d) vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days (A-C8d) vs. Cefuroxime 30 mg/kg/day / bid for 5 days (CAE) | | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | Outcome: Clinical success (cure or improve) on day 7–9 at end-of-therapy | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | Azithro | Cefdinir | Diff (95% CI) | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | Total | 85% (149/176) | 87% (151/174) | −2% (−9, 5.3) | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | 0–2 yrs | 82% (54/66) | 81% (48/59) | 1% (−13, 15) | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | >2 yrs | 86% (95/110) | 90% (103/115) | −4% (−12, 4.5) | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | | | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | Diff (95% CI) | −4% (−15, 7) | −9% (−20, 1.6) | | Not enough evidence to conclude
12 | Azithromycin vs. Cefdinir | Block, 2005^83^ | 6 months–6years Multi-centers in U.S. | Azithromycin 10 mg/kg/day = qd for 1 day, --- 5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg | | | | | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | Outcome: Clinical success (cure or improve) on day 12–14 per protocol population | | | | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | CPD 5d | CPD 10d | Diff (95% CI) | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | Total | 84.1% (175/208) | 92.4% (194/210) | −8% (−14, −2.1) | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | | | Not enough evidence to conclude
13 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | Data by age group not reported. Multivariable analysis showed that younger age (Odds ratio 1.074, p=0.0096), treatment duration (Odds ratio, not reported), day-care attendance (Odds ratio 0.390, p=0.0098), and history of otitis media with effusion (Odds ratio 0.346, p=0.0091) “were independently predictive of poor treatment” outcome. | | | | Not enough evidence to conclude
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | Outcome: clinical cure on day 9–11 (4–6 days post therapy for cefdinir and +/−1 day post therapy for Cefprozil) | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | Cefdinir | Cefprozil | Diff (95% CI) | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | Total | 80.0% (152/190) | 82.5% (151/183) | −2.5%(−10,5.4) | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | <2yrs | 71% (49/69) | 71% (41/58) | 0.3%(−16, 16) | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | ≥2 yrs | 84% (102/121) | 88% (110/125) | −4% (−12, 4.9) | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | Diff (95% CI) | −13% (−25, 1.4) | −17% (−29, −5.5) | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | 2–5yrs | 85.1% (57/67) | 87.1% (61/70) | −2% (−14, 10) | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.
14 | Cefdinir Vs. Cefprozil | Block, 2000^85^ | 6months–12years Multi-centers in U.S. | Cefprozil 30 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | 6–12yrs | 83.3% (45/54) | 89.1% (49/55) | −6% (−19, 7) | Not enough evidence to conclude the effectiveness between treatments within age group. Age <2 years had lower success rate than age >=2 years when treated with Cefprozil.

Using the articles identified in the 2001 report and articles newly identified in this review that assessed the effectiveness of treatment options in uncomplicated AOM by age groups, we identified two treatment comparisons with more than two trials: Ampicillin/Amoxicillin vs. placebo and Amoxicillin-clavulanate (7–10 days) vs. Azithromycin (<5 days). The findings of the meta-analysis are presented in Tables 25, 26, 27, 28, and 29, respectively. The shrinkage plots are presented in Figures 11, 12, 13, and 14, respectively.

Table 25 Ampicillin/Amoxicillin vs. Placebo; Outcome Indicator: Treatment Success Rate for Age ≤2 Years

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Success Rate (%) | Placebo Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Howie, 1972^106^ | ≤2yrs | Success at day 2–7 | 36 | 116 | 47.2 | 20.7 | 26.5 | 8.6, 44.4
Kaleida, 1991^108^ | ≤2yrs | No effusion at day 2 | 226 | 209 | 47.8 | 32.1 | 15.7 | 6.7, 24.8
Damoiseaux, 2000^88^ | ≤2yrs | Clinical success at day 11 | 112 | 120 | 35.7 | 30.0 | 5.7 | −6.4, 17.8
Le Saux, 2005^89^ | ≤2yrs | Clinical resolution at day 14 | 89 | 92 | 85.4 | 79.3 | 6.0 | −5.0, 17.1
Random effects estimates | | | 463 | 537 | 54.2 | 40.5 | 12.2 | 4.2, 20.2
Test of heterogeneity Chi-square test value | | | | | | | 5.40
Test of heterogeneity Chi-square test p-value | | | | | | | 0.14
Test of heterogeneity I-squared | | | | | | | 44.5%
Number Needed to Treat (NNT) | | | | | | | 8 (5, 24)
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.66

Table 26 Ampicillin/Amoxicillin vs. Placebo; Outcome Indicator: Treatment Success Rate for Age >2 Years

Author, Year | Age | Definition of outcome | Amoxicillin/Ampicillin Sample Size | Placebo Sample Size | Amoxicillin Success Rate (%) | Placebo Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Burke, 1991^107^ | 3–<10yrs | Success at day 7 | 114 | 118 | 98.2 | 85.6 | 12.7 | 5.9, 19.4
Kaleida, 1991^108^ | >2–12yrs | No effusion at day 14 | 226 | 209 | 47.8 | 32.1 | 15.7 | 6.7, 24.8
Le Saux, 2005^89^ | >2–5yrs | Clinical resolution at day 14 | 161 | 148 | 96.9 | 87.2 | 9.7 | 3.7, 15.7
Random effects estimates | | | 501 | 475 | 81.3 | 68.3 | 11.9 | 7.9, 16.0
Test of heterogeneity Chi-square test value | | | | | | | 1.54
Test of heterogeneity Chi-square test p-value | | | | | | | 0.46
Test of heterogeneity I-squared | | | | | | | 0%
Number Needed to Treat (NNT) | | | | | | | 8 (6, 13)
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.19

Table 27 Amoxicillin-Clavulanate (7–10 Days) vs. Azithromycin (<5 Days); Outcome Indicator: Treatment Success Rate for Age ≤2 Years

Author, Year | Age | Definition of outcome | Amox-clav Sample Size | Azithromycin Sample Size | Amox-clav Success Rate (%) | Azithromycin Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Schaad, 1993^117^ | ≤2yrs | Success at day 7–20 | 14 | 14 | 85.7 | 85.7 | 0.0 | −25.9, 25.9
Principi, 1995^118^ | ≤2yrs | Success at day 10–14 | 49 | 61 | 61.2 | 75.4 | −14.2 | −31.6, 3.2
Dunne, 2003^70^ | ≤2yrs | Success at day 10 | 52 | 59 | 84.6 | 76.3 | 8.3 | −6.3, 23.0
Random effects estimates | | | 115 | 134 | 74.8 | 76.94 | −1.6 | −16.6, 13.4
Test of heterogeneity Chi-square test value | | | | | | | 3.88
Test of heterogeneity Chi-square test p-value | | | | | | | 0.14
Test of heterogeneity I-squared | | | | | | | 48.4%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.81

Table 28 Amoxicillin-Clavulanate (7–10 Days) vs. Azithromycin (<5 Days); Outcome Indicator: Treatment Success Rate for Age >2 Years

Author, Year | Age | Definition of outcome | Amox-clav Sample Size | Azithromycin Sample Size | Amox-clav Success Rate (%) | Azithromycin Success Rate (%) | Rate Difference In % | 95% CI of Rate Difference In %
Daniel, 1993^116^ | >2–8yrs | Success at day 10–12 | 54 | 103 | 100.0 | 94.2 | 5.8 | 0.5, 11.1
Schaad, 1993^117^ | >2–10yrs | Success at day 7–20 | 175 | 178 | 98.3 | 94.4 | 3.9 | 0.0, 7.8
Principi, 1995^118^ | >2–12yrs | Success at day 10–14 | 149 | 154 | 77.2 | 89.0 | −11.8 | −20.2, −3.4
Dunne, 2003^70^ | >2–12yrs | Success at day 10 | 129 | 126 | 89.1 | 85.7 | 3.4 | −4.7, 11.5
Random effects estimates | | | 507 | 561 | 89.9 | 90.9 | 0.8 | −6.6, 8.3
Test of heterogeneity Chi-square test value | | | | | | | 18.2
Test of heterogeneity Chi-square test p-value | | | | | | | <0.001
Test of heterogeneity I-squared | | | | | | | 83.5%
Test of publication bias, Egger’s asymmetry test p-value | | | | | | | 0.38

Table 29 Comparison of Treatment Success Rate Between Age ≤2 And Age >2 Years by Treatment Option Based on Pooled Data

Treatment | Studies | Success Rate in % | | Rate Difference in % (95% CI)
Ampicillin/Amoxicillin | 4 studies for age <=2 years (Howie, 1972^106^; Kaleida, 1991^108^; Damoiseaux, 2000^88^; Le Saux, 2005^89^) 3 studies for age >2 years (Burke, 1991^107^ ; Kaleida, 1991^108^; Le Saux, 2005^89^) | Age <=2 Age > 2 | 52.% (241/463) 75% (376/501) | −23% (−29, −17)
Placebo | 4 studies for age <=2 years (Howie, 1972^106^; Kaleida, 1991^108^; Damoiseaux, 2000^88^; Le Saux, 2005^89^) 3 studies for age >2 years (Burke, 1991^107^ ; Kaleida, 1991^108^; Le Saux, 2005^89^) | Age <=2 Age > 2 | 37% (200/537) 63% (297/475) | −25% (−32, −19)
Amoxicillin-clavulanate (7–10 days) | 3 studies for age <=2 years (Schaad, 1993^117^ ; Principi, 1995^118^; Dunne, 2003^70^) 4 studies for age >2 years (Daniel, 1993^116^; Schaad, 1993^117^; Principi, 1995^118^; Dunne, 2003^70^) | Age <=2 Age > 2 | 75% (86/115) 90% (456/507) | −15% (−22, −8)
Azithromycin (<5 days) | 3 studies for age <=2 years (Schaad, 1993^117^ ; Principi, 1995^118^; Dunne, 2003^70^) 4 studies for age >2 years (Schaad, 1993^117^ ; Principi, 1995^118^; Dunne, 2003^70^) | Age <=2 Age > 2 | 77% (103/134) 91% (510/561) | −14% (−20, −8)

Figure 11 Shrinkage Plot for Ampicillin/Amoxicillin vs. Placebo for Treatment Success for AGE ≤2 Years

Figure eleven depicts a shrinkage plot for ampicillin/amoxicillin versus placebo for treatment success for age less than two years.

Figure 12 Shrinkage Plot for Ampicillin/Amoxicillin vs. Placebo for Treatment Success for AGE>2 Years

Figure twelve depicts a shrinkage plot for shrinkage plot for ampicillin/amoxicillin versus placebo for treatment success for age greater than years. Using the articles identified in the 2001 report and articles newly identified in this review that assessed the effectiveness of treatment options in uncomplicated acute otits media by age groups, we identified two treatment comparisons with more than two trials: ampicillin/amoxicillin versus placebo and amoxicillin-clavulanate (seven to ten days days) versus azithromycin (less than five days).

Figure 13 Shrinkage Plot for Amoxicillin-clavulanate (7–10 days) vs. Azithromycin (<5 days) for Treatment Success for AGE ≤2 Years

Figure thirteen depicts a shrinkage plot for amoxicillin-clavulanate (seven to ten days days) versus azithromycin (less than five days) for treatment Success for age less than or equal to two years. Using the articles identified in the 2001 report and articles newly identified in this review that assessed the effectiveness of treatment options in uncomplicated acute otits media by age groups, we identified two treatment comparisons with more than two trials: ampicillin/amoxicillin versus placebo and amoxicillin-clavulanate (seven to ten days days) versus azithromycin (less than five days).

Figure 14 Shrinkage Plot for Amoxicillin-Clavulanate (7–10 days) vs. Azithromycin (<5 days) for Treatment Success for AGE >2 Years

Figure fourteen depicts a shrinkage plot for amoxicillin-clavulanate (seven to ten days) versus azithromycin (less than five days) for treatment success for age greater than two years. Using the articles identified in the 2001 report and articles newly identified in this review that assessed the effectiveness of treatment options in uncomplicated acute otits media by age groups, we identified two treatment comparisons with more than two trials: ampicillin/amoxicillin versus placebo and amoxicillin-clavulanate (seven to ten days days) versus azithromycin (less than five days).

Difference in treatment effect between age groups. In general, the results of individual trials and of meta-analyses show that children over the age of 2 have better outcomes from AOM, regardless of whether they are treated with antibiotics or not, compared to children 2 years of age or younger. No differences were seen in our meta-analyses in the rate difference for treatment success between children younger or older than 2 years when comparing ampicillin/amoxicillin to placebo or when comparing amoxicillin-clavulanate to azithromycin (Figures 11–14). Similar conclusions were found in an individual patient meta-analysis conducted by Rovers (2006).

Meta-analyses. Data from two trials, one comparing ampicillin or amoxicillin vs. placebo and the other comparing amoxicillin-clavulanate vs. azithromycin, demonstrated that children over 2 years old had better clinical success rates in both treatment arms for uncomplicated AOM than children 2 years old and under. First, comparing the clinical success between children 2 years old and under treated with ampicillin or amoxicillin in four trials88, 89, 106, 108 with children over 2 years of age in three trials89, 107, 108 treated with ampicillin or amoxicillin, a rate difference of −23% (95% CI: −29%, −17%; NNT=4 (95% CI: 3, 6)) favoring treatment of children over 2 years old was demonstrated (Table 29). A similar result was demonstrated utilizing the same trials to compare children 2 years of age and under with those over 2 years of age treated with placebo, resulting in a rate difference of −25% (95% CI: −32, −19%; NNT=4 (95% CI: 3, 5) favoring children over 2 years old. Thus, children over 2 years of age had better clinical success rates in both ampicillin and placebo groups for treatment of uncomplicated AOM.

Comparing the clinical success between children 2 years old and under treated with amoxicillin-clavulanate in three trials70, 117, 118 with those over 2 years old in four trials,70, 116–118 a rate difference of −15% (95% CI: −22%, −8%); NNT=7 (95% CI: 5, 13), favoring treatment of children over 2 years old was demonstrated (Table 29). A similar result was demonstrated using the same trial to compare children 2 years old or less treated with azithromycin with those over 2 years old, resulting in a rate difference of −14% (95% CI: −20, −8; NNT=7, 95% CI: 5, 13), favoring treatment of children over 2 years old.

Thus, children over 2 years old also had better clinical success rates in both ampicillin/amoxicillin, amoxicillin-clavulanate and azithromycin groups for treatment of uncomplicated AOM. Children over 2 years were also more likely to get better on their own than children 2 and under.

Individual studies. Four additional individual RCTs demonstrated a higher clinical success rate for children older than two years of age than for children less than two years of age using an a priori established MCID of +/− 5%.

The 2005 study by LeSaux demonstrated success rate differences between 6–23-month-old children and 2–5-year-old children of −12% (95% CI: −19, −5.3; NNT=8, 95% CI: 5, 19) for amoxicillin treatment and of −8% (95% CI: −18, 1.6; NNT= 13, 95% CI: 5, 63) for placebo.89

A 2000 study by Block demonstrated a success rate difference for twice-daily cefdinir between children under 2 years old and those 2 years old and older of −34% (95% CI: −50, −19; NNT=3, 95% CI: 2, 5).85

Another 2000 study by Block also demonstrated a success rate difference for twice daily cefprozil between children under 2 years old and those 2 years old and older of −17% (95% CI: −29, −5.5; NNT=6, 95% CI: 3, 18).85

The 2000 study by Cohen that compared the effectiveness of 5- and 10-day cefpodoxime treatments did not report the clinical success rate by age but performed a multivariate analysis and reported that younger age (Odds ratio [OR] 1.074, p=0.0096), treatment duration (OR not reported), day-care attendance (OR 0.390, p=0.0098), and history of OME (OR 0.346, p=0.0091) “were independently predictive of poor treatment” outcome.100

Previous systematic reviews. Using individual patient data from six of ten eligible studies identified, a systematic review56 provided information on the effect of antibiotic treatment of uncomplicated AOM between age groups. Though Rovers (2006) reported that the effect of antibiotics was not modified by age alone, their data indicate that children 2 years of age or older had less pain or fever at 3–7 days than those younger than 2 years old when not treated with antibiotics (RD=−17%, 95% CI: −24, −10; NNT=6, 95% CI: 4, 10) and also when treated with antibiotics (RD=−13%, 95% CI: −19, −7; NNT=8, 95% CI: 5, 14). As noted below, age and laterality together modify the effect of treatment.

Difference in treatment effect within age groups. A difference in treatment effect within age groups was demonstrated in one meta-analysis conducted for this review and in a previous meta-analysis that used individual patient data (Rovers, 2006). Another meta-analysis conducted for this review and a previous meta-analysis that looked only at children 2 years old or under (Damoiseaux, 1998) showed no difference between treatment groups.

Meta-analyses. Comparing ampicillin or amoxicillin vs. placebo by age group showed a rate difference of 12% (95% CI: 4%, 20%; NNT=8; 95% CI: 5, 25), favoring ampicillin/amoxicillin in children 2 years old and under.88, 89, 106, 108 and a rate difference of 12% (95% CI: 8%, 16%; NNT=8, 95% CI: 6, 13), favoring ampicillin/amoxicillin in children over 2 years old.89, 107, 108 The meta-analyses showed no heterogeneity within each group of articles and no evidence of publication bias. (Table 25, Table 26, Figure 11 and Figure 12) It should be noted that the Howie (1972), Burke (1991), and Kaleida (1991) studies had 95% confidence intervals outside of the MCID favoring ampicillin/amoxicillin.106–108 Thus, the only definitive conclusion possible from these data is that for children over 2 years old, ampicillin/amoxicillin appears to have an advantage over placebo (NNT=8, 95% CI: 6, 13).

Comparing amoxicillin-clavulanate vs. azithromycin by age group showed a rate difference of −2% (95% CI: −17%, 13%) in children 2 years old and under and a rate difference of 0.8% (95% CI: −7%, 8%) in children over 2 years old70, 117, 118 in meta-analyses that showed possible heterogeneity within the group of articles reporting data for children over 2 years of age but no evidence of publication bias. (Table 27, Table 28, Figure 13, and Figure 14) It should be noted that the study by Principi (1995) had 95% confidence intervals clearly favoring azithromycin for children over 2 years, unlike the other studies.118 Thus, no conclusion regarding the advantage of either treatment over the other or their equivalence for either age group can be made.

Previous systematic reviews. Two systematic reviews (Damoiseaux, 1998; Rovers, 2006) provide information on the role of age within treatment groups for uncomplicated AOM in average risk children. Damoiseaux (1998) studied children under two years old and found no effect of antibiotics on clinical improvement within seven days (OR 1.31, 95% CI: 0.83–2.08). Rovers found a positive effect of antibiotics on pain, fever, or both at 3–7 days for both age groups, and the rate difference for children 2 years old or under was −15% (95% CI: −23, −7; NNT=7, 95% CI: 4, 14), whereas that for children over 2 years old was −11% (95% CI: −16, −6; NNT=9, 95% CI: 6, 17).

### Laterality Factor in Uncomplicated Acute Otitis Media

We identified two individual articles and one systematic review that analyzed the effectiveness of treatment options by laterality. Table 30 provides a summary of the findings.

Table 30 Summary of Findings from Two Articles and One Previous Systematic Review Reporting Effectiveness of Interventions in Uncomplicated Otitis Media Stratified by Laterality

Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | Outcome: Clinical success on day 9–11 by laterality (combines both antibiotic groups) | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | Bilateral | | Unilateral | Diff(95% CI) | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | 87.3% (69/79) | | 97.5% (196/201) | −10%(−16, −4) | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Outcome: Clinical success (cure or improved) at day 4–7 after treatment by Laterality | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | A-C | Cefprozil | Diff (95% CI) | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Total | 89% (116/130) | 87% (110/127) | 2% (−6, 10) | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Unilateral | 93% (66/71) | 89% (73/82) | 4% (−5.2, 13) | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Bilateral | 85% (50/59) | 82% (37/45) | 3% (−11, 17) | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Diff (95% CI) | 8% (−3, 19) | 7% (−5.4, 19) | | Not enough evidence to conclude
2 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | | | | Not enough evidence to conclude
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Outcome: Pain, fever, or both at 3–7 days by Laterality | | | | In the no antibiotic group, a smaller proportion of children with unilateral disease had pain or fever at 3–7 days then children with bilateral disease; but, not enough evidence to conclude when stratified by age.
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | | Unilateral | Bilateral | Diff (95% CI)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Antibiotic | 24% (104/432) | 27%(64/237) | −3%(−10, 4)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Placebo | 30%(132/ 440) | 47%(104/ 219) | −17%(−25, −10)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Diff (95% CI) | −6%(−12, 0) | −20%(−28, −11)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | <2 years old
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Antibiotic | 35%(45/129) | 30%(42/139) | 5%(−6, 16)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Placebo | 40%(53/132) | 55%(74/134) | −15%(−27, −3)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Diff (95%CI) | −5%(−17, 7) | −25%(−36, −14)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | ≥ 2 years old
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Antibiotic | 19%(59/304) | 23%(20/87) | −4%(−14, 5)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Placebo | 26%(79/307) | 35%(30/86) | −9%(−20, 2)
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic
3 | Antibiotic vs. placebo | Rovers, 2006^56^ | 0–12years Systematic review of individual patient data from six studies | Antibiotics vs. No antibiotic | Diff (95% CI) | −7%(−14, 0) | −12%(−25, 1)

Difference in treatment effect between laterality groups. In general, the results of individual trials and meta-analyses show that children with bilateral disease responded as well to treatment as those with unilateral disease. If left untreated, children with unilateral disease did better than those with bilateral disease.

Individual studies. Scholz 1998 compared amoxicillin with erythromycin in 280 children ranging in age from 6 months to 11 years at days 9 to 11 after treatment initiation (Jadad quality score was 5 out 5).127 This study demonstrated a success rate difference between unilateral and bilateral AOM for children on either amoxicillin or erythromycin of −10% (95% CI: −16, −4[NNT=10, 95% CI: 6, 25]).

Hedrick 2001 compared amoxicillin-clavulanate with cefprozil in 257 children ranging in age from 6 months to 7 years at days 4 to 7 after treatment initiation (Jadad quality score was 2 of 5).128 This study demonstrated a lack of success rate differences between unilateral and bilateral AOM for amoxicillin-clavulanate of 8% (95% CI: −3%, 19%) and for cefprozil of 7% (95% CI: −5.4%, 19%).

Previous systematic reviews. A meta-analysis by Rovers (2006) of individual patient data from six studies reported data showing a greater proportion of children without pain or fever at 3–7 days in children with unilateral compared to bilateral disease when not treated with antibiotics (RD=−18, 95% CI: −25, −10; NNT=6, 95% CI: 4, 10).53 The effect of laterality was not seen in the group treated with antibiotics (RD=−3%, 95% CI: −10, 4).

Treatment effect within laterality groups. The comparison of treatment effect in an individual study and a previous systematic review identified for the present review generally showed better clinical outcomes for children receiving antibiotics than for those receiving no treatment among children with bilateral AOM but not for those with unilateral disease; this difference was also seen in children less-than two years old.

Individual studies. The Hedrick 2001 study also demonstrated a lack of success rate differences between amoxicillin-clavulanate cefprozil treatment among patients with unilateral AOM (RD=4%, 95% CI: −5.2, 13) and those with bilateral AOM (RD= 3%, 95% CI: −11, 17).

Previous Systematic Reviews. Rovers‘ (2006) meta-analysis of individual patient data from six studies reported a benefit for antibiotics compared to placebo for resolving pain and/or fever at 3 to 7 days in children with bilateral disease (RD=−20%, 95% CI: −28%, −11%; NNT=5, 95% CI: 4, 9) but not for children with unilateral disease (RD=−6%, 95% CI: −12, 0). When stratified by age, this effect was seen in children under 2 years of age with bilateral AOM, as treatment with antibiotics resulted in a significant resolution of pain or fever at 3–7 days compared to placebo (RD=−25%, 95% CI: −36%, −14%; NNT=4, 95% CI: 3, 7) but not for children under 2 years old with unilateral disease (RD=−5%, 95% CI: −17, 7).

### Childcare Setting Factor in Uncomplicated Otitis Media

We identified two studies by Cohen that analyzed the effectiveness of treatment options by child care setting (home vs. caretaker vs. sitter vs. external day care). Table 31 provides a summary of the findings.98, 100 The 1998 study by Cohen compared the clinical success of 5-and 10-day regimens of amoxicillin-clavulanate by child care setting among 518 children 4 to 30 months of age (Jadad quality score was 5). The 2000 study by Cohen compared the clinical success of 5- and 10-day cefpodoxime regimens by child care setting among 649 children 4 to 30 months of age (Jadad quality score was 3). The following success rate differences were found between home and outside care sites (either sitter or day-care):

- Amoxicillin-clavulanate 5-day regimen, 14% (95% CI: 1.1%, 28%)
- Amoxicillin-clavulanate 10-day regimen, 3% (95% CI: −7%, 13%)
- Cefpodoxime 5-day regimen, 7% (95% CI: −3.4%, 17%)
- Cefpodoxime 10-day regimen, −0.3% (95% CI: −7.5%, 7%).

Table 31 Summary of Findings from 2 Articles Reporting Effectiveness of Interventions in Uncomplicated Otitis Media Stratified by Childcare Setting

Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | Outcome: Clinical success (cure or improve) per protocol population by setting of child care | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | Amox-clav 5d | Amox-clav 10d | Diff (95% CI) | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | Home | 85.1% (57/67) | 89.6% (69/77) | −4.5%(−15, 6) | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | Caretaker | 70.8% (68/96) | 86.8.% (79/91) | −16% (−28, − 4.2) | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | Sitter | 73.6%(39/53) | 88.6% (39/44) | −15%(−31, 0.9) | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | Day-care | 67.3% (29/43) | 85.1% (40/47) | −18%(−35, 0.3) | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | Diff (H-C) (95% CI) | 14% (1.1, 28) | 3% (−7, 13) | | Not enough evidence to conclude
1 | Amox-clav 5d vs. Amox-clav 10d | Cohen, 1998^98^ | 4–30 months Multi-centers in France | Amoxicillin-clavulanate 80/10 mg/kg/day/tid for 10 days vs. Amoxicillin-clavulanate 80/10 for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | Outcome: clinical success (cure or improve) per protocol population by day-care modality | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | CPD 5d | CPD 10d | Diff (95% CI) | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | Home | 88.1% (74/84) | 92.2% (95/103) | −4.1% (−13, 4.4) | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | Caretaker | 81.4% (101/124) | 92.5% (99/107) | −11% (−20, − 2.3) | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | Sitter | 86.8% (66/76) | 100%(47/47) | −13% (−23, −3.2) | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | Day-care | 72.9% (35/48) | 86.7% (52/60) | −14% (−29, 1.2) | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | | | | | Not enough evidence to conclude
2 | Cefpodoxime 5d vs. Cefpodoxime 10d | Cohen, 2000^100^ | 4–30 months Multi-centers in France | Cefpodoxime 8 mg/kg/day/bid for 10 days vs. Cefpodoxime 8 mg/kg/day/bid for 5 days | Diff (H-C) (95% CI) | 7% (−3.4, 17) | −0.3% (−7.5, 7) | | Not enough evidence to conclude

Thus, no conclusion can be drawn regarding differences in clinical success of a treatment option with the type of caretaker and setting based on these two studies.

### Other Factors Studied in Uncomplicated Otitis Media

We identified only four other factors whose influence on treatment effectiveness was assessed---severity factor, presence of otorrhea at initial visit, examiner (parent vs. physician), and pneumococcal vaccine status---and only one article assessed the effect of each of these factors. Table 32 provides a summary of the findings. With one exception (presence or absence of otorrhea at initial visit), no differences were seen.

Table 32 Summary of Findings from Articles Each Reporting Effectiveness of Interventions in Uncomplicated Otitis Media Stratified by a Risk Factor

(A) Hearing deficit and severity
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7 years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day/bid for 10 days vs. Cefprozil 30 mg/kg/day/bid for 10 days | Outcome: Clinical success (cure or improved) at day 4–7 after treatment by Severity | | | | Not enough evidence to conclude
1 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7 years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day/bid for 10 days vs. Cefprozil 30 mg/kg/day/bid for 10 days | | A-C | Cefprozil | Diff (95% CI) | Not enough evidence to conclude
1 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7 years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day/bid for 10 days vs. Cefprozil 30 mg/kg/day/bid for 10 days | Moderate | 92% (83/90) | 85% (64/75) | 7% (−2.7, 17) | Not enough evidence to conclude
1 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7 years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day/bid for 10 days vs. Cefprozil 30 mg/kg/day/bid for 10 days | Severe | 82% (32/39) | 88% (45/51) | −6% (−21, 9) | Not enough evidence to conclude
1 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | 6 months–7 years Multi-centers in U.S. | Amoxicillin-clavulanate 90/6.4 mg/kg/day/bid for 10 days vs. Cefprozil 30 mg/kg/day/bid for 10 days | Diff (95% CI) | 10% (−2, 22) | −3% (−15, 9) | | Not enough evidence to conclude

(B) Otorrhea
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | Conclusion
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day/bid for 10 days vs. Erythromycin 40 mg/kg/day/bid for 10 days | Outcome: Clinical success on day 9–11 by otorrhea at entry | | | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day/bid for 10 days vs. Erythromycin 40 mg/kg/day/bid for 10 days | Otorrhea at entry | No Otorrhea at entry | Diff (95% CI) | Not enough evidence to conclude
1 | Amoxicillin vs. Erythromycin | Scholz, 1998^4^ | 6 months–11 years 19 centers in Germany Pediatric practice | Amoxicillin 50 mg/kg/day/bid for 10 days vs. Erythromycin 40 mg/kg/day/bid for 10 days | 94.7% (36/38) | 94.6% (229/242) | 0.1%(−8, 8) | Not enough evidence to conclude

(C) Examiner
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Aqueous lidocaine drop vs. placebo | Bolt, 200890 | 3–17 years Tertiary children’s hospital emergency department in Australia | 2% aqueous lidocaine 3 drops hourly for 1 day vs. Placebo | Outcome: Reduction by 50% in pain score on day 30 | | | | Significantly more reduction in pain by parent if treated with lidocaine. Not enough evidence to conclude for doctor’s assessment
1 | Aqueous lidocaine drop vs. placebo | Bolt, 200890 | 3–17 years Tertiary children’s hospital emergency department in Australia | 2% aqueous lidocaine 3 drops hourly for 1 day vs. Placebo | | Lidocaine | Placebo | Diff (95% CI) | Significantly more reduction in pain by parent if treated with lidocaine. Not enough evidence to conclude for doctor’s assessment
1 | Aqueous lidocaine drop vs. placebo | Bolt, 200890 | 3–17 years Tertiary children’s hospital emergency department in Australia | 2% aqueous lidocaine 3 drops hourly for 1 day vs. Placebo | By parent | 90% (28/31) | 63% (20/32) | 27%(6, 48) | Significantly more reduction in pain by parent if treated with lidocaine. Not enough evidence to conclude for doctor’s assessment
1 | Aqueous lidocaine drop vs. placebo | Bolt, 200890 | 3–17 years Tertiary children’s hospital emergency department in Australia | 2% aqueous lidocaine 3 drops hourly for 1 day vs. Placebo | By doctor | 84% (26/31) | 66% (21/32) | 18% (−3.4,39) | Significantly more reduction in pain by parent if treated with lidocaine. Not enough evidence to conclude for doctor’s assessment
1 | Aqueous lidocaine drop vs. placebo | Bolt, 200890 | 3–17 years Tertiary children’s hospital emergency department in Australia | 2% aqueous lidocaine 3 drops hourly for 1 day vs. Placebo | Diff (95% CI) | 6% (−11, 23) | −3% (−26, 20) | | Significantly more reduction in pain by parent if treated with lidocaine. Not enough evidence to conclude for doctor’s assessment

(D) Pneumococcal vaccine
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amox-clav vs. Cefdinir | Block, 200475 | 6 months–6years Multi-centers in U.S. | Amoxicillin-clavulanate 45/6.4 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | Outcome: Success at end-of-treatment visit (study days 7–9 for Cefdinir; study days 12–14 for Amox-clav) by PCV7 | | | | Not enough evidence to conclude
1 | Amox-clav vs. Cefdinir | Block, 200475 | 6 months–6years Multi-centers in U.S. | Amoxicillin-clavulanate 45/6.4 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | | Amox-clav | Cefdinir | Diff (95% CI) | Not enough evidence to conclude
1 | Amox-clav vs. Cefdinir | Block, 200475 | 6 months–6years Multi-centers in U.S. | Amoxicillin-clavulanate 45/6.4 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | Had PCV7 | 82% (102/124) | 92% (115/125) | −10%(−18, −2) | Not enough evidence to conclude
1 | Amox-clav vs. Cefdinir | Block, 200475 | 6 months–6years Multi-centers in U.S. | Amoxicillin-clavulanate 45/6.4 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | No PCV7 | 91% (62/68) | 80% (55/69) | 11% (−0.8, 23) | Not enough evidence to conclude
1 | Amox-clav vs. Cefdinir | Block, 200475 | 6 months–6years Multi-centers in U.S. | Amoxicillin-clavulanate 45/6.4 mg/kg/day/bid for 10 days vs. Cefdinir 14 mg/kg/day/bid for 5 days | Diff (95% CI) | −9% (−20, 1.5) | 12% (2.4, 22) | | Not enough evidence to conclude

Moderate vs. severe disease. The 2001 study by Hedrick compared the clinical success of amoxicillin-clavulanate with that of cefprozil stratified by illness severity among 255 children ranging in age from 6 months to 7 years (Jadad quality score 2).76 This study demonstrated success rate differences between moderate and severe disease for amoxicillin-clavulanate of 10% (95% CI: −2%, 22%) and for cefprozil of −3% (95% CI: −15%, 9%).

Presence or absence of otorrhea. Scholz (1998) compared the clinical success of amoxicillin vs. erythromycin, stratified by the presence or absence of otorrhea at initial visit, among 280 children, ranging in age from 6 months to 11 years (Jadad quality score 5).4 This study demonstrated a success rate difference between those with and without otorrhea at study entry and treated with either amoxicillin or erythromycin of 0.1% (95% CI: −8, 8). Data from a systematic review by Rovers (2006) using individual patient data from six studies suggested that in children not treated with antibiotics, those with otorrhea were more likely to have pain, fever, or both at 3–7 days than those without otorrhea, a rate difference of 18% (95% CI: 4%, 32%), but this was not the case for children on antibiotics, where no difference was demonstrated (RD=−4%, 95% CI: −18%, 10%). The Rovers (2006) systematic review also found that the benefit from antibiotics vs. no antibiotics for resolution of pain, fever, or both at 3–7 days was greater for children with otorrhea (RD=−36%, 95% CI: −53%, −19%; NNT=3, 95% CI: 2, 5) than for children without otorrhea (RD=−14%, 95% CI: −23%, −5%; NNT=8, 95% CI: 4, 20).

Physician vs. parent assessment. Bolt (2008) compared the reduction in pain score using aqueous lidocaine drop vs. placebo, stratified by assessor— parent vs. doctor—among 162 children ranging in age from 3 to 17 years (Jadad quality score 4).90 This study demonstrated 50% pain score reduction differences between those examined by a parent vs. a doctor when using lidocaine of 6% (95% CI: −11%, 23%) and for placebo of −3% (95% CI: −26, 20). Although the type of examiner had no significant effect within treatment groups, lidocaine was significantly better than placebo in the children with a parent examiner (difference of 27% [95% CI: 6%, 48%]).

Vaccine treatment. Block (2004) compared the clinical success of amoxicillin-clavulanate with cefdinir (5 days) stratified by whether the patient had received PCV7 vaccine or not, among 386 children ranging in age from 6 months to 6 years (Jadad quality score 2).75 The study demonstrated success rate differences between those who received PCV7 and those who did not receive PCV7 of −9% (95% CI: −20%, 1.5%) for amoxicillin-clavulanate and of 12% (95% CI: 2.4%, 22%) for cefdinir.

### Effectiveness of Treatments in Recurrent Otitis Media, Stratified by Age, Laterality, and Severity

We identified three studies that analyzed the effectiveness of treatment options by age groups in recurrent otitis media.122–124 The 2005 study by Sher also provided subgroup analysis by laterality and severity.122 Table 33 provides a summary of the findings.

Table 33 Summary of Findings from Three Articles Reporting Effectiveness of Interventions in Recurrent Otitis Media Stratified by Age, Laterality, and Severity

(A) Age
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Outcome: Success rate on day 12–16 | | | | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | Amox-clav | Azithromycin | Diff (95% CI) | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | <=2yrs | 79% (73/92) | 85% (82/96) | −6% (−17, 5) | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | >2yrs | 92% (49/53) | 87% (46/53) | 5% (−7, 17) | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Diff (95% CI) | −13% (−26, − 0.5) | −2% (−14, 10) | | Not enough evidence to conclude
1 | Amox-clav vs. Azithromycin | Arrieta, 2003^124^ | 0.5–6 years 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Outcome: Success rate on day 10 (test of day visit) by age group | | | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | Amox-clav | Gatifloxacin | Diff (95% CI) | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | <2yrs | 78% (45/58) | 79% (49/62) | −1% (−16, 14) | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | >=2yrs | 80% (47/59) | 90% (56/62) | −11% (−23,2.7) | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | | | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Diff (95% CI) | −2% (−17, 13) | −11% (−24, 1.7) | | Not enough evidence to conclude
2 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | | | | Not enough evidence to conclude
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Outcome: Clinical success (cure and improved) at 10–17 days | | | | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | | | | | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | | Levofloxacin | Amox-clav | Diff (95% CI) | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | | | | | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | 0.5–2yr | 79% (318/404) | 76% (315/417) | −3.2 (−8.9, 2.6) | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | | | | | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | >2–<5yr | 90% (267/296) | 87% (263/302) | −3.1 (−8.2, 2.0) | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | | | | | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.
3 | Amox-clav vs. Levofloxacin | Noel, 2008^123^ | 0.5-<5 years 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Diff (95% CI) | −11% (−16, − 5.5) | −11% (−17, −5.1) | | Not enough evidence to conclude difference in effectiveness between treatments within each age group. Age <=2yrs had lower success rate for both treatments.

(B) Laterality
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Outcome: Success rate on day 10 (test of day visit) by laterality | | | | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | Amox-clav | Gatifloxacin | Diff (95% CI) | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Unilateral | 82% (40/49) | 84% (48/57) | −3% (−17, 12) | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Bilateral | 76% (52/68) | 85% (57/67) | −9% (−22, 4.7) | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Diff (95% CI) | 6% (−9, 21) | −1% (−14, 12) | | Not enough evidence to conclude

(C) Severity
Comp # | Comparison | Article | Patient Population | Intervention | Findings | | | | Conclusion
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Outcome: Success rate on day 10 (test of day visit) by severity | | | | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | | Amox-clav | Gatifloxacin | Diff (95% CI) | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Mild/Mod | 85% (45/53) | 84% (47/56) | 1% (−13, 15) | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Severe | 73% (47/64) | 85% (58/68) | −12 (−26, 2) | Not enough evidence to conclude
1 | Amox-clav vs. Gatifloxacin | Sher, 2005^122^ | 0.5–7 years 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses), 10d Gatifloxacin (10mg/kg, qd) 10d | Diff (95% CI) | 12% (−3, 27) | −1% (−14, 12) | | Not enough evidence to conclude

The three studies compared the effectiveness of amoxicillin-clavulanate vs. three different treatments: azithromycin,124 gatifloxacin,122 and levofloxacin123 by age groups. It can be observed from the 95% confidence intervals that no definitive conclusions could be made for the first two comparisons. For levofloxacin, Noel (2008) demonstrated a success rate difference by day 17 between 0.5–2-year-old children and 2–5 year old children treated with levofloxacin of −11% (95% CI: −16, −5.5); the confidence limit outside of the MCID (NNT=9, 95% CI: 6, 18), implies a lower success rate for younger children.123 A similar age association was seen for amoxicillin-clavulanate in this study, with a success rate difference between the two age groups of −11% (95% CI: −17, −5; NNT=9, 95% CI: 6, 20). It should be noted that the differences in clinical success rate between levofloxacin and amoxicillin-clavulanate within each age group was not significant.

Sher (2005) included stratified analysis by laterality and by severity. Based on the 95% confidence intervals for the success rates, no definitive conclusions can be made, and more data or studies are needed.122

### Summary

For uncomplicated AOM, the available evidence indicates that treatment effect may be modified by age, laterality, and otorrhea. In a meta-analysis conducted for this report, children over 2 years old did better than children two years old and under in the ampicillin/amoxicillin group (NNT=4, 95% CI: 3, 6) and in the placebo group (NNT=4, 95% CI: 3, 5). A systematic review by Rovers (2006) reported data that also show that children 2 years and older had less pain or fever at 3–7 days than younger children, whether treated or not treated with antibiotics. Comparing children over 2 years to those two and under, another meta-analysis in this review showed the older age group with better clinical success than the younger age group whether treated with amoxicillin-clavulanate (NNT=7, 95% CI: 5, 13) or with azithromycin (NNT=7, 95% CI: 5, 13). In addition three individual studies showed greater success rates in children older than two years of age in treatment of uncomplicated AOM with amoxicillin, cefdinir, and cefprozil and also in the placebo group of one study.85, 89, 163

In addition, for children over 2 years old, ampicillin/amoxicillin appeared to have an advantage over placebo (NNT=8, 95% CI: 6, 13). For children 2 years old and under, the 95% confidence interval also favored ampicillin/amoxicillin but crossed the +/−5% MCID, so a definitive conclusion could not be made. Meta-analyses by age sub-group for a comparison of amoxicillin-clavulanate vs. azithromycin were without definitive conclusion.

The systematic review by Rovers (2006) also found that the effect of antibiotics (compared to placebo or no treatment) was greater in children with bilateral AOM (NNT=5, 95% CI: 4, 9) than in those with unilateral AOM, in which there was no difference. Also, the increase in effect of antibiotics (compared to placebo or no treatment) in bilateral AOM was of greater magnitude in children 2 years and younger (NNT=4, 95% CI: 3, 7) than in children over 2 years old, in whom there was again no difference. We also identified two individual studies (Scholz, 1998; Hedrick, 2001) that assessed laterality, with results that did not allow for definitive conclusions and were not included in the Rovers (2006) systematic review.

Rovers (2006) also found that antibiotic effect was greater in children with AOM who had otorrhea (NNT=3, 95% CI: 2, 5) compared to those without otorrhea (NNT=8, 95% CI: 4, 20), and we identified one individual study (Scholz, 1998) that did not show such an effect.

Definitive conclusions could not be made regarding subgroup analyses by childcare setting, severity, examiner, or pneumococcal vaccine status.

For ROM, the available evidence in one study by Noel (2008) demonstrated an association of treatment success with age, favoring children older than two years of age treated with either levofloxacin (NNT=9, 95% CI: 6, 18) or amoxicillin-clavulanate (NNT=9, 95% CI: 6, 20).123 However, the available evidence did not allow definitive conclusions when assessing available treatment options by laterality and severity, when taking into consideration both the 95% confidence limit and a +/−5 % zone of MCID.

The overall quality of evidence for these comparisons is considered low, meaning that further high quality research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.

## Key Question VI What Adverse Effects Have Been Observed for the Treatments Whose Outcomes Are Addressed in Key Questions 3 and 4?

### Description of the Studies

We examined the incidence of adverse events in the RCTs identified for this report that compared the effectiveness of one or more treatment options. We also searched the FDA MedWatch Database for adverse events associated with use of medications for the treatment of AOM; however, none could be identified.

### Adverse Effects Observed In Treatment of Uncomplicated Acute Otitis Media

Of the 44 RCTs newly identified for this report that compared the effectiveness of treatment options in uncomplicated AOM, there are 63 treatment comparisons. Of the 63 treatment comparisons, 42 included comparisons of the percent of cases that had experienced an adverse event between pairs of treatment options. The incidence rate for each treatment group and the rate difference between two treatment options can be found in the Evidence Tables. The findings for newly identified RCTs are summarized in Table 34. The combined findings for the 2001 report and the present report are summarized in Table 34a.

Table 34 Findings of Adverse Events by Treatment Option Comparisons for Uncomplicated Otitis Media

Comp# | Comparison | Author, Year | Adverse effects reported | Significant Differences | Equivalence | Inconclusive
1 | Amox vs. Amox+Fenspiride | Zielnik-Jurkiewicz, 2005^65^ | No
3 | Amox vs. Ceftriaxone | Zhang, 2003^68^ | No
4 | Amox vs. Erythromycin | Scholz, 1998^4^ | Yes | | | Tx related, possibly tx related
5 | Amox-clav vs. Amox-sulbactam | Casellas, 2005^69^ | Yes | | Severe diarrhea (0.7% in both treatment arm) | Any mention, diarrhea day 12–14, diarrhea day 3, minor
6 | Amox-clav vs. Azithromycin | Dagan, 2000^7^ | Yes | | | Any mention, diarrhea, tx related, vomiting
7 | Amox-clav vs. Azithromycin | Dunne, 2003^70^ | Yes | | Vomiting (1% vs. 2%) | Any mention, diarrhea, rash
8 | Amox-clav vs. Azithromycin | Guven, 2006^52^ | Yes | | | Any mention, abd pain, diarrhea
9 | Amox-clav vs. Azithromycin | Biner, 2007^71^ | Yes | | | Diarrhea, vomiting
10 | Amox-clav vs. Cefaclor | Subba Rao, 1998^5^ | Yes | | Fever (0% vs. 1.7%) | Diarrhea, headache, vomiting
11 | Amox-clav vs. Cefdinir | Block, 2000^72^ | Yes | Any mention higher in Amox-clav (42% vs. 14% in CefQD and 23% in CefBID) Diarrhea higher in Amox-clav (35% vs. 10% in CefQD and 13% in CefBID) | | Rash
12 | Amox-clav vs. Cefdinir | Adler, 2000^73^ | Yes | | | Any mention, diarrhea, tx related
13 | Amox-clav vs. Cefdinir | Cifaldi, 2004^74^ | No
14 | Amox-clav vs. Cefdinir | Block, 2004^75^ | Yes | | | Diaper rash, diarrhea, vomiting
15 | Amox-clav vs. Cefprozil | Hedrick, 2001^76^ | Yes | | | Any mention, diarrhea, rash, vomiting
16 | Amox-clav vs. Ceftriaxone | Cohen, 1999^77^ | Yes | Any mention higher in Amox-clav (31% vs. 14%) Diarrhea higher in Amox-clav (27% vs. 14%)
17 | Amox-clav vs. Ceftriaxone | Wang, 2004^78^ | Yes | | | Any mention, diarrhea, GI, skin and appendages, rash
18 | Amox-clav vs. Ceftriaxone | Biner, 2007^71^ | Yes | | | Diarrhea, vomiting
19 | Amox-clav vs. Cefuroxime | Pessey, 1999^79^ | Yes | | | Any mention, diarrhea
20 | Azithromycin vs. Cefaclor | Dagan, 2000^81^ | No
21 | Azithromycin vs. Cefaclor | Oguz, 2003^82^ | Yes | | | Diarrhea, vomiting
22 | Azithromycin vs. Cefdinir | Block, 2005^83^ | Yes | | | Abnormal stool, diarrhea
23 | Azithromycin vs. Ceftriaxone | Biner, 2007^71^ | Yes | | | Diarrhea, vomiting
24 | Cefaclor vs. Cefprozil | Carvalho, 1998^84^ | Yes | | | Any mention, vomiting
25 | Cefdinir vs. Cefprozil | Block, 2000^85^ | Yes | | Rash (3.2% vs. 3.8%) | Diarrhea
26 | Cefaclor vs. Cefpodoxime | Tsai, 1998^86^ | Yes | | | Any mention, abd discomfort, diarrhea, intolerable abd discomfort, intolerable urticaria, pruritis, skin rash, sweating
27 | Cefaclor vs. Cefuroxime | Turik, 1998^125^ | Yes | | Asthma, respiratory disorder, vomiting (0% vs. 1%) | Any mention, diarrhea, diarrhea during tx, increased cough, rhinitis
28 | Amox vs. Wait- and-see | McCormick, 2005^3^ | Yes | | Serious events (0% in both arms)
29 | PcV vs. Wait-and- see | Neumark, 2007^87^ | No
30 | Amox vs. Placebo | Damoiseaux, 2000^88^ | Yes | | | Diarrhea day 4, diarrhea day 10
31 | Amox vs. Placebo | Le Saux, 2005^89^ | Yes | | | Diarrhea, rash
32 | Lidocaine drop vs. Placebo | Bolt, 2008^90^ | Yes | | | Ear discharge, dizziness
33 | Probiotic vs. Placebo | Hatakka, 2007^91^ | No
34 | Homeopathic vs. Placebo | Jacobs, 2001^92^ | Yes | | Any mention (0% in both arms)
35 | Amox vs. Prescription to Hold | Little, 2001^2^ | No
36 | Amox vs. Prescription to Hold | Little, 2006^93^ | No
37 | Antibiotic vs. Prescription to Hold | Spiro, 2006^94^ | Yes | Diarrhea at 4–6 day follow-up higher in Antibiotic group (21% vs. 7%) | | Diarrhea at 11–14 day follow-up, otalgia, vomiting
38 | Prescription to Hold vs. Wait-and- see | Chao, 2008^95^ | No
39 | Amox high vs. low dose | Garrison, 2004^96^ | Yes | | | GI distress, skin rash
40 | Amox-clav high vs. low dose | Pessey, 1999^79^ | Yes | | | Any mention, diarrhea
41 | Amox-clav high vs. low dose | Bottenfield, 1998^97^ | Yes | | Diaper rash (4% vs. 5%) Severe rash (1% vs. 0%) Severe erythema multiform (0% vs. 0.4%) Severe GI (0% vs. 0.4%) Severe moniliasis (0.4% vs. 0%) | Any mention, need tx, cough, fever, severe diarrhea, URI, vomiting
42 | Amox-clav bid vs. tid | Damrikarnlert, 2000^6^ | Yes | | Abd pain, enteritis, fever, rash (0.5% vs. 0%) Constipation, ear disorder, enlarged abdomen, enterocolitis, erythematous rash, nervousness, somnolence, stomatitis (ulcerative): (0% vs. 0.5%) Dermatitis (0.5% vs. 1.9%) Nervousness (1% vs. 0%) Otitis media (0.5% vs. 1%) Uticaria (0% vs. 1.5%) Vomiting (2% vs. 0.5%) | Tx related, diarrhea
43 | Cefdinir high vs. low dose | Adler, 2000^73^ | Yes | | | Any mention, diarrhea, tx related
44 | Amox vs. Azithromycin | Arguedas, 2005^66^ | Yes | | Rash (2.6% vs. 2.5%) | Abd pain, diarrhea, vomiting, tx related
45 | Cefdinir high vs. low dose | Block, 2000^72^ | Yes | | | Any mention, diarrhea, and rash
46 | Amox-clav 5-day vs. 10-day | Cohen, 1998^98^ | Yes | | | Any mention, drug-related, diarrhea, skin rash
47 | Cefaclor 5-day vs. 10-day | Catania, 2004^99^ | Yes | | Abd pain (1.5% vs. 2.4%) Skin rash (2.5% vs. 2.9%) Diarrhea (2.0% vs. 2.4%) Vomiting (0.5% vs. 0.5%) | New AOM episode
48 | Cefpodoxime 5- day vs. 10-day | Cohen, 2000^100^ | Yes | | | Any mention
49 | Ceftriaxone vs. Ceftriaxone+Prednisolone | Chonmaitree, 2003^101^ | No
50 | Ceftriaxone vs. Ceftriaxone+Antihistamine | Chonmaitree, 2003^101^ | No
51 | Ceftriaxone vs. Ceftriaxone+Prednisolone+Antihistamine | Chonmaitree, 2003^101^ | No
52 | Ceftriaxone+Prednisolone vs. Ceftriaxone+Antihistamine | Chonmaitree, 2003^101^ | No
53 | Ceftriaxone+Prednisolone vs. Ceftriaxone+Predinisolone+Antihistamine | Chonmaitree, 2003^101^ | No
54 | Ceftriaxone+Antihistamine vs. Ceftriaxone+Predinisolone+Antihistamine | Chonmaitree, 2003^101^ | No
55 | Ciprofloxacin- dexamethasone drops vs. Cipro otic drops | Roland, 2003^126^ | Yes | | Burning (1% vs. 2%) Excessive crying (1% vs. 1%) Pain (1% vs. 2%) Pruritus (1% vs. 1%) Taste perversion (0% vs. 1%) | Precipitate
56 | Ciprofloxacin- dexamethasone drops vs. Ofloxacin drops | Roland, 2004^127^ | Yes | | Cough, crying, diarrhea, ear debris, edema eardrum, headache, hyperemia eardrum: (0% vs. 0.3%) Discomfort ear (3.4% vs. 1%) Dizziness, erythema, tinnitus, tympanostomy tube blockage: (0.3% vs. 0%) Super-Infection ear, irritation ear, pruritus ear, irritability, pruritus ear: (0% vs. 0.7%) Monilia oral (0.3% vs. 0.3%) Pain ear (2.4% vs. 3%) Precipitate ear (2.4% vs. 3%) Serious tx related (0% in both arms) Taste perversion (0.3% vs. 1%)
57 | Otikon drops vs. Topical Anesthetic | Sarrell, 2001^102^ | Yes | | Any mention (0% in both arms)
58 | Anesthetic vs. Anesthetic+Amox | Sarrell, 2003^103^ | Yes | | Any mention (0% in both arms)
59 | Anesthetic vs. NHED | Sarrell, 2003^103^ | Yes | | Any mention (0% in both arms)
60 | Anesthetic vs. NHED+Amox | Sarrell, 2003^103^ | Yes | | Any mention (0% in both arms)
61 | Anesthetic+Amox vs. NHED | Sarrell, 2003^103^ | Yes | | Any mention (0% in both arms)
62 | Anesthetic+Amox vs. NHED+Amox | Sarrell, 2003^103^ | Yes | | Any mention (0% in both arms)
63 | NHED vs. NHED+Amox | Sarrell, 2003^103^ | Yes | | Any mention (0% in both arms)

Table 34a Comparison of Rates of Adverse Events Between Drugs (Significant Differences Only)

| 2001 Report | | 2009 Update
Comparison | Number of trials | AE rate Difference (95% CI) | Number of new trials | Total number of trials | AE rate difference (95% CI) | Conclusion
Uncomplicated AOM
Overall AE
Amoxicillin-clavulanate (7–10d) vs. Azithromycin (5d) | 3 | 19%( 9%, 29%) | 0 | 3 | N/A | Amoxicillin-clavulanate associated with greater overall AE rate
Amoxicillin-clavulanate vs. cefdinir (qd) | 0 | N/A | 1 | 1 | 28% (17%, 39%) | Amoxicillin-clavulanate associated with greater overall AE rate
Amoxicillin-clavulanate vs. cefdinir (bid) | 0 | N/A | 1 | 1 | 19% (8%, 31%) | Amoxicillin-clavulanate associated with greater overall AE rate
Amoxicillin clavulanate vs. ceftriaxone | 0 | N/A | 1 | 1 | 16% (9%, 24%) | Amoxicillin-clavulanate associated with greater overall AE rate
Gastrointestinal AEs
Amoxicillin-clavulanate (7–10d) vs. Azithromycin (5d) | 3 | 18% (8%, 28%) | 0 | 0 | N/A | Amoxicillin-clavulanate associated with greater rate of GI AE
Diarrhea
Ampicillin or amoxicillin vs. cefixime | 5 | −8% (−13, −4) | 0 | 0 | N/A | Cefixime associated with greater rate of diarrhea
Amoxicillin clavulanate vs. cefdinir | 0 | | 1 | 1 | 25% (15%, 35%) in Cef QD and 22% (11%, 32%) in Cef BID | Amoxicillin clavulanate associated with greater rate of diarrhea
Amoxicillin clavulanate vs. ceftriaxone | 0 | | 1 | 1 | 13% (6%, 20%) | Amoxicillin clavulanate associated with greater rate of diarrhea
Recurrent Otitis Media
Diarrhea
Amoxicillin-clavulanate vs. ciprofloxacin-dexamethasone ear drops | 0 | N/A | | | | Greater for amoxicillin- clavulanate in 1 study, but equivalent in 41; no conclusion possible in 23 comparisons

Table notes: AE adverse event; bid twice a day; CI confidence interval; d day; NNT number needed to treat; qd once a day

Using the 95% confidence intervals for the rate differences and the zone of MCID of 5% as reference, we grouped the findings into “significant differences,” “equivalence,” or “inconclusive.” The findings in many studies are inconclusive. However some findings show significant differences or equivalence.

Diarrhea was found to be significantly higher in children treated with amoxicillin-clavulanate when compared to cefdinir85 and ceftriaxone.77 The adverse event rates ranged from 27% to 35% with amoxicillin-clavulanate and from 10% to 14% in the other treatment options. Diarrhea was also significantly higher in children treated with antibiotics (primarily amoxicillin) than in children given a prescription to hold on days 4–6 (23% vs. 8%; 95% CI: 6, 24) in one study.94

When any mention of an adverse event was considered, the rate for amoxicillin-clavulanate was found to be significantly higher than for cefdinir given once a day (42% vs. 14%),85 higher than cefdinir given twice a day (42% vs. 23%),85 and higher than ceftriaxone (31% vs. 14%).77

Findings of equivalence were identified in the following comparisons:

- Severe diarrhea in amoxicillin-clavulanate vs. amoxicillin-sulbactam (0.7% for both)69
- Vomiting in amoxicillin-clavulanate vs. azithromycin (1% vs. 2%)70
- Fever in amoxicillin-clavulanate vs. cefaclor (0% vs. 2%)5
- Rash in cefdinir vs. cefprozil (3% vs. 4%)85
- Serious events in amoxicillin vs. wait-and-see (0% for both)3
- Any mention of an adverse event in children receiving a homeopathic remedy vs. placebo (5% in both arms)92
- Diaper rash (4% vs. 5%), severe rash (1% vs. 0%), severe erythema multiform (0% vs. 0.4%), severe gastroenteritis (0% vs. 0.4%), and severe moniliasis (0.4% vs. 0%) in amoxicillin-clavulanate high dose vs. low dose97
- Abdominal pain, enteritis, fever, rash (0.5% vs. 0%), constipation, ear disorder, enlarged abdomen, enterocolitis, erythematous rash, nervousness, somnolence, ulcerative stomatitis (0% vs. 0.5%), dermatitis (0.5% vs. 2%), nervousness (1% vs. 0%), otitis media (0.5% vs. 1%), urticaria (0% vs. 1.5%), vomiting (2% vs. 0.5%) in amoxicillin-clavulanate twice daily vs. three times daily comparison6
- Rash (2.6% vs. 2.5%) in amoxicillin vs. azithromycin comparison66
- Abdominal pain (1.5% vs. 2.4%), skin rash (2.5% v. 2.9%), diarrhea (2% vs. 2.4%), vomiting (0.5% vs. 0.5%) in cefaclor 5-day vs. 10-day comparison99
- Any mention of an adverse event (0% in all arms) in comparisons between otikon drops, topical anesthetic, anesthetic plus amoxicillin, naturopathic treatment ear drops (NHED), and NHED plus amoxicillin102

### Adverse Effects in Studies of Treatment of Acute Otitis Media in Children with Recurrent Otitis Media or Persistent Acute Otitis Media

Of the 58 RCTs identified in our review update that addressed the effectiveness of treatment options, 14 studied children with ROM, persistent AOM, or AOM treatment failure. Among the 14 studies are 21 treatment comparisons. Eight comparisons studied the treatment of AOM in children with presumed or explicitly defined recurrent and/or persistent AOM, and/or AOM with treatment failure. Table 35 provides the findings on the comparison of the adverse event rates between treatment options for the eight comparisons.

Table 35 Comparison of Adverse Event Rates Between Treatment Options from Eight Comparisons on Effectiveness of Treatment of Acute Otitis Media in Recurrent Otitis Media

Comp # | Comparison | Author, Year | Patient Population | Intervention | Findings of Adverse Events | | | | Conclusion
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | Amox-clav | Gatifloxacin | Diff(95%CI) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Any | 59% (81/136) | 55% (153/277) | 4% (−6, 14) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Arthralgia | 2% (2/136) | 2% (6/277) | 0% (−2.9, 2.9) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Drug-related | 15% (20/136) | 18% (49/277) | −3% (−11, 4.7) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Vomiting | 5% (7/136) | 8% (23/277) | −3% −8, 2.2) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Diarrhea | 7% (10/136) | 3% (8/277) | 4% (−0.2, 8) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Abd pain | 2% (2/136) | 4% (11/277) | −2% (−5.7, 1.7) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Diaper rash | 2% (3/136) | 1% (2/277) | 1%(−1.4, 3 .4) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | Serious* | 2% (2/136) | 0% (0/277) | 2%(0.3, 3.7) | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
1 | Amox-clav vs. gatifloxacin | Saez-Llorens, 2005^121^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 20 sites non-US | Amox-clav (45mg/6.4mg/kg/d in 2 divided doses, 10d) Gatifloxacin (10mg/kg, qday, 10d) | * one was generalized seizure | | | | Arthralgia, diaper rash, serious events equivalent Drug-related, vomiting, diarrhea, abd pain inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | Amox-clav | Gatifloxacin | Diff(95%CI) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Any | 27% (46/173) | 24% (42/176) | 3%(−6, 12) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Abd pain or diarrhea (severe in intensity) | 0.6% (1/173) | 0% (0/176) | 0.6(−0.4,1.7) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Anorexia | 0% (0/173) | 0.6% (1/176) | −0.6%(−1.8,0.6) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Arthralgia event unrelated to treatment | 1.2% (2/173) | 0.5% (1/176) | 0.6%(−1.4,2.6) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Deaths or Serious drug related events | 0% (0/173) | 0% (1/173) | 0% (0, 0) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Diaper rash | 6.4% (11/173) | 5.1% (9/176) | 1.3%(−3.6,6) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Diarrhea | 18% (31/173) | 10% (17/176) | 8% (1, 15) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | Vomiting | 6% (10/173) | 7% (12/176) | −1%(−6, 4) | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
2 | Amox-clav vs. gatifloxacin | Sher, 2005^122^ | 0.5–7 years ROM and/or AOM treatment failure^a^ 26 sites in US 1 site in Costa Rica | Amox-clav (90mg/6.4mg/kg/d in 2 doses, 10d) Gatifloxacin (10mg/kg, qd, 10d) | | | | | Abd pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths or serious drug-related equivalent. Diaper rash, diarrhea, vomiting inconclusive
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | | Levofloxacin | Amox-clav | Diff(95%CI) | Arthralgia, arthralgia disorder, arthritis disorder, arthropathy, fever, gait disorder, muscle weakness, otitis media not related to treatment failure, pathologic fracture, musculoskeletal disorder, musculoskeletal adverse events, rhinitis, synovitis: equivalent Dermatitis, diarrhea, URI, vomiting: inconclusive
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | 1 or more up to visit 4 | 54% (448/827) | 58% (475/823) | −4%(−8,1.3)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Arthralgia | 1.5% (12/827) | 0.7%(6/823) | 0.8%(−0.2,1.8)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Arthralgia disorder | 1.2% (10/827) | 0.6% (5/823) | 0.6%(−0.3,1.5)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Arthritis disorder | 0.2% (2/827) | 0% (0/823) | 0.2%(−0.1,0.5)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Arthropathy | 0% (0/827) | 0.2% (2/823) | −0.2%(−0.5,0.1)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Dermatitis | 13% (108/827) | 16% (129/823) | −3%(−6, 0.8)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Diarrhea | 13% (108/827) | 20% (161/823) | −7%(−10, −3)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Fever | 7% (60/827) | 8% (64/823) | −1%(−3, 2)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Gait abnormality disorder | 0.1% (1/827) | 0% (0/823) | 0.1%(−0.1,0.3)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Muscle weakness | 0% (0/827) | 0.1% (1/823) | −0.1%(−0.3,0.1)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Otitis media not related to treatment failure | 5% (45/827) | 4% (34/823) | 1% (−0.8, 3.4)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Pathologic fracture | 0% (0/827) | 0.5% (4/823) | −0.5%(−1, 0)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Musculoskeletal disorder (DSMC) | 1.5% (12/827) | 0.6% (5/823) | 1%(−0.1, 1.9)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Musculoskeletal adverse events | 2.8% (23/827) | 2.3% (19/823) | 0.5%(−1, 2)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Rhinitis | 5% (43/827) | 5% (39/823) | 0.5%(−1.6,2.6)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Synovitis | 0.1% (1/827) | 0% (0/823) | 0.1%(−0.1,0.3)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | URI | 6% (53/827) | 9% (78/823) | 3%(−5.7,−0.5)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d) | Vomiting | 10% (81/827) | 7% (61/823) | 2%(−0.3, 5.1)
3 | Amox-clav vs. levofloxacin | Noel, 2008^123^ | 0.5–<5 years ROM and/or persistent AOM^b^ 66 centers in 6 countries, incl US | Amox-clav (45mg/kg bid, 10d) Levofloxacin (10mg/kg bid, 10d)
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | Amox-clav | Azithromycin | Diff(95%CI) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Any | 42.2% (62/147) | 32.0% (49/153) | 10%(−0.7, 21) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Abd pain | 2.0% (3/147) | 3.9% (6/153) | −2%(−5.7, 2) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Anorexia | 2.7% (4/147) | 3.3% (6/153 | −0.6%(−4, 3) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Dermatitis | 2.0% (3/147) | 0.7% (1/153) | 1.3%(−1.3, 4) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Diarrhea | 29.9% (44/147) | 19.6% (30/153) | 10%(0.5, 20) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Rash | 4.8% (7/147) | 3.3% (5/153) | 1.5%(−3, 6) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | Vomiting | 8.2% (12/147) | 5.2% (8/153) | 3%(−2.6, 9) | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
4 | Amox-clav vs. azithromycin | Arrieta, 2003^124^ | 0.5–6 years ROM and/or persistent AOM b 13 US and 5 Latin American centers | Amox-clav (95mg/kg, bid, 10d) Azithromycin (20mg/kg, qd, 3d) | | | | | Anorexia, dermatitis: equivalent Abd pain, diarrhea, rash, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | Amox-clav | Cipro-Dex | Diff(95%CI) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Any | 29% (12/41) | 13% (5/39) | 16%(−1.4,34) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Dermatitis | 7% (3/41) | 0% (0/39) | 7%(−1,16) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Device block or taste perversion | 0% (0/41) | 3% (1/39) | −3%(−8,2.3) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Diarrhea | 20% (8/41) | 0% (0/39) | 20%(6.4,33) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Ear pain | 0% (0/41) | 5% (2/39) | −5%(−2,1.7) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Gastroenteritis | 5% (2/41) | 0% (0/39) | 5%(−2,12) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Infection skin or nausea or oral moniliasis | 2.4% (1/41) | 0% (0/39) | 2.4%(−2.4,7) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | Vomiting | 2.4% (1/41) | 2.6% (1/39) | −0.2%(−7, 7) | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
5 | Amox-clav vs. ciprofloxacin 0.3%-dexamethasone 0.1% (cipro-dex) otic drops | Dohar, 2006^80^ | 0.5–12 years with tympanostomy tubes 6 site in US | Amox-clav (90mg/kg/d, bid, 10d) Cipro-dex (4 drops, bid, 7d) | | | | | Diarrhea: higher in amox-clav Any, dermatitis, device block or taste perversion, ear pain, gastroenteritis, infection skin or nausea or oral moniliasis, vomiting: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | Cefaclor | Cefuroxime axetil | Diff(95%CI) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Any | 31% (32/104) | 31% (32/104) | −5%(−18, 8) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Asthma or Bronchospas m unrelated to study drug or respiratory disorder or vomiting | 0% (0/104) | 1% (1/101) | −1%(−2.9, 0.9) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Diarrhea | 2% (2/104) | 1% (11/101) | −9%(−16,−2.3) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Diarrhea during treatment | 0% (0/104) | 8% (8/101) | −8%(−13,−2.5) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Increased cough | 7% (7/104) | 0% (0/101) | 7% (1.7,12) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | Rhinitis | 9% (9/104) | 10% (10/101) | −1%(−9, 7) | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
6 | Cefaclor vs. cefuroxime | Turik, 1998^125^ | 3 months–12 years AOM treatment failure 13 sites | Cefaclor (40mg/kg/d, bid, 10d) Cefuroxime (40mg/kg/d, bid, 10d) | | | | | Asthma or bronchospasm unrelated to study drug or respiratory disorder or vomiting: equivalent Any, diarrhea, diarrhea during treatment, increased cough, rhinitis: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | Cipro alone | Cipro-dex | Diff(95%CI) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Excessive crying | 1% (1/98) | 1% (1/103) | 0% (−2.8, 2.8) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Burning | 1% (1/98) | 2% (2/103) | −1%(−4.2,2.4) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Pain | 1% (1/98) | 2% (2/103) | −1%(−4.2,2.4) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Precipitate | 3% (3/98) | 0% (0/103) | 3%(−0.3,6.5) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Pruritus | 1% (1/98) | 1% (1/103) | 0%(−2.8,2.8) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | Taste perversion | 0% (0/98) | 1% (1/103) | −1%(−3, 1) | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
7 | Ciprofloxacin 0.3% (cipro) otic drops vs. Cipro 0.3%- dex 0.1% otic drops | Roland, 2003^126^ | 0.5–12 years with tympanostomy tubes 18 sites in US | Cipro (3 drops, bid, 7d) Cipro-dex (3 drops, bid, 7d) | | | | | Excessive crying, burning, pain, pruritis, taste perversion: equivalent Precipitate: inconclusive
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | | Cipro-dex | Ofloxacin | Diff(95%CI) | Cough or crying or diarrhea or ear debris or edema eardrum or headache or hyperemia eardrum; discomfort ear; dizziness or erythema or tinnitus or tympanostomy tube blockage; super-infection ear or irritation ear or pruritus ear; irritability; monilia oral; pain ear; precipitate ear; serious treatment related; taste perversion: equivalent
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Cough or crying or diarrhea or ear debris or edema eardrum or headache or hyperemia eardrum | 0% (0/297) | 0.3% (1/302) | −0.3%(−0.9,0.3):
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Discomfort ear | 3.4% (10/297) | 1% (3/302) | 2.4%(0.1,4.7)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Dizziness or erythema or tinnitus or tympanostomy tube blockage | 0.3% (1/297) | 0%(0/302) | 0.3%(−0.3,0.9)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Infection super ear or irritation ear or pruritus ear | 0% (0/297) | 0.7% (2/302) | −0.7%(−1.6,0.2)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Irritability | 0.7% (2/297) | 0% (0/302) | 0.7%(−0.2,1.6)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Monilia oral | 0.3% (1/297) | 0.3% (1/302) | 0%(−0.9,0.9)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Pain ear | 2.4% (7/297) | 3.0% (9/302) | −0.6%(−3.2,2)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Precipitate ear | 0.7% (2/297) | 1.0% (3/302) | −0.3%(−1.8,1.2)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Serious Tx related | 0% (0/297) | 0% (0/302) | 0% (0, 0)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d)
8 | Cipro 0.3%- dex 0.1% otic drops vs. ofloxacin 0.3% otic drops | Roland, 2004^127^ | 0.5–12 years with tympanostomy tubes 39 sites in US | Cipro-dex (4 drops, bid, 7d) Ofloxacin (5 drops, bid, 10d) | Taste perversion | 0.3% (1/297) | 1% (3/302) | −0.7%(−2,0.6)

a AOM Treatment Failure: infection within 14 days of last antibiotic dose or failure to improve after 48 hours

b Persistent AOM: signs or symptoms of AOM after 48 hours of treatment

In the comparison between amoxicillin-clavulanate and gatifloxacin, equivalence was found with respect to the rate of arthralgia, diaper rash, and serious events (ranged from 0% to 2%).121 The rates for other adverse events were inconclusive: abdominal pain 2% vs. 4%, diarrhea 7% vs. 3%, vomiting 5% vs. 8% and drug-related events 15% vs. 18%.

In the comparison between high-dose amoxicillin-clavulanate and gatifloxacin, equivalence was found with respect to the rate of abdominal pain, severe diarrhea, anorexia, arthralgia unrelated to treatment, deaths, or serious drug-related events (ranging from 0% to 1.2%).122 The rates for the following adverse events were inconclusive: diaper rash 6% vs. 5%, diarrhea 18% vs. 10%, and vomiting 6% vs. 7%.

In the comparison between amoxicillin-clavulanate and levofloxacin, equivalence was found in a majority of adverse events including arthralgia, arthralgia disorder, arthritis disorder, arthropathy, fever, gait disorder, muscle weakness, otitis media not related to treatment failure, pathologic fracture, musculoskeletal disorder, musculoskeletal adverse events, rhinitis, and synovitis.123 Their rates ranged from 0% to 8%. The rates for the following adverse events were inconclusive: dermatitis 13% vs. 16%, diarrhea 13% vs. 20%, upper respiratory infection 6% vs. 9%, and vomiting 10% vs. 7%.

In the comparison between amoxicillin-clavulanate and azithromycin, equivalence was found in anorexia (2.7% vs. 3.3%) and dermatitis (2% vs. 1%).124 The rates for the following adverse events are inconclusive: abdominal pain 2% vs. 4%, diarrhea 30% vs. 20%, rash 5% vs. 3%, and vomiting 8% vs. 5%.

In the comparison between amoxicillin-clavulanate and ciprofloxacin-dexamethasone ear drops, diarrhea was found to be significantly higher in amoxicillin-clavulanate-treated children, with a rate difference of 20% (95% CI: 6%, 33%) and NNT=5.^80^

In the comparison between cefaclor and cefuroxime, equivalence was found with respect to the rate of asthma or bronchospasm unrelated to study drug, respiratory disorder, and vomiting (0% vs. 1%). The rates for the following adverse events were inconclusive: any adverse event 31% vs. 36%, diarrhea 2% vs. 1%, diarrhea during treatment 0% vs. 8%, increased cough 7% vs. 0%, and rhinitis 10% vs. – 1%.125

In the comparison between ciprofloxacin-dexamethasone and ciprofloxacin ear drops, equivalence was found with respect to the rate of excessive crying (both 1%), burning (1% vs. 2%), pain (1% vs. 2%), pruritis (3% vs. 0%), and taste perversion (0% vs. 1%). The rate for the ear precipitate was inconclusive (3% vs. 0%).126

In the comparison between ciprofloxacin-dexamethasone and ofloxacin ear drops, equivalence was found with respect to the rate of cough or crying or diarrhea or ear debris or eardrum edema or headache or eardrum hyperemia (0% vs. 0.3%), ear discomfort (3% vs. 1%), dizziness or erythema or tinnitus or tympanostomy tube blockage (0.3% vs. 0%), ear super-infection or ear irritation or ear pruritus (0% vs. 0.7%), irritability (0.7% vs. 0%), oral monilia (both 0.3%), ear pain (2% vs. 3%), ear precipitate (0.7% vs. 1%), serious treatment related events (both 0%), and taste perversion (0.3% vs. 1%).127

### Adverse Events Associated with Prevention of Acute Otitis Media in Children with Recurrent Otitis Media

Of the 58 RCTs identified in our review update that addressed the effectiveness of treatment options, 14 studied children with ROM. Among the 14 studies are 21 treatment comparisons. Thirteen comparisons studied the prevention of AOM in children with ROM. Of the 13 comparisons, four did not report or did not study adverse events. Table 36 provides the findings on the comparison of the adverse event rates between treatment options for the remaining comparisons.

In the comparison between amoxicillin and azithromycin, the difference in gastrointestinal adverse event rate was inconclusive (2.5% vs. 0%).128

In the comparisons between sulfafurazole and placebo and between sulfafurazole and adenoidectomy, equivalence was found in “unknown” adverse events (2% in sulfafurazole and placebo, 0% in adenoidectomy).130 The rates for the following adverse events are inconclusive: diarrhea (ranged from 0% to 3%), skin rash (ranged from 0% to 3%), and any mention (ranged from 0% in adenoidectomy to 8% in sulfafurazole).

In the comparison between adenoidectomy and placebo, equivalence was found in diarrhea, skin rash, and unknown events (range from 0% to 2%).130 Difference in any mention of adverse event rate was inconclusive.

In the comparison between adenoidectomy and adenotonsillectomy, equivalence in adverse event rates was found in incipient malignant hyperthermia (1.2% vs. 0.6%), postoperative pneumonia (1.2% vs. 0%), postoperative persistent (9 months) velopharyngeal insufficiency (0% vs. 0.6%), and serious sickness during antimicrobial treatment (0% vs. 0.6%).26 The rate differences for the following adverse events are inconclusive: erythematous rashes during treatment (7% vs. 2%), hemorrhage after hospital discharge (0% vs. 2%), perioperative and postoperative complications (5% vs. 15%), postoperative transient (under 44 days) velopharyngeal insufficiency (2% vs. 5%), and retention in hospital one additional day due to fever, poor fluid intake orally, vomiting, and/or dehydration (0% vs. 6%).

In the comparisons between adenoidectomy and placebo and between adenotonsillectomy and placebo, the difference in erythematous rashes during treatment rates between treatment options was inconclusive, ranging from 2% in adenotonsillectomy to 7% in adenoidectomy.26

In the comparison between ceftibuten 5-day and ceftibuten 10-day, the difference in gastrointestinal disturbance rates between the two treatment options (7% vs. 17%) was inconclusive.

In the comparison between propolis and zinc vs. the control, the rates of vomiting and rash were found to be equivalent (1.6% vs. 1.6% and 1.6% vs. 0%).

The Leach (2006) systematic review found that one additional child experienced diarrhea or an allergic reaction for every 100 children treated, which was not statistically significant (relative risk 2.0, 95% CI: 0.3, 15; random-effects model, I^2^=53%) based on eleven studies (Casselbrant, 1992; Gaskins, 1982; Gonzalez, 1986; Gray 1981; Liston 1983; Perrin 1974; Principi, 1989; Schuller, 1983; Sigh, 1993; Teele, 2000; Varsano, 1985), they reiterated a concern in their discussion that antibiotics are not without risk.

Leach (2006) also studied the issue of antibiotic resistant organisms in two studies and found a statistically insignificant relative risk of 1.4 (95% CI: 0.8, 2.3; fixed-effect model, I^2^=0%) though there appeared to be an increased carriage of resistant pneumococcus or haemophilus (Casselbrant, 1992; Mandel 1996). This review concluded that the choice of whether or not to treat children with ROM with antibiotics to prevent AOM would have to balance the benefits and these risks.

### Summary

Although in general we could not reach definitive conclusions regarding clinically important differences in adverse event rates between most pairs of antibiotics, we noted significant differences in adverse event rates for a few antibiotic comparisons and equivalence in adverse event rates for several comparisons. For treatment of uncomplicated AOM, five adverse event rate comparisons showed a significant difference between two treatment options. Amoxicillin-clavulanate was associated with diarrhea more often than was cefdinir (with a NNT of four)85 and ceftriaxone (with a NNT of seven).77 The adverse event rates ranged from 27% to 35% with amoxicillin-clavulanate and from 10% to 14% for the other treatment options. For mention of any adverse event, amoxicillin-clavulanate had a higher rate than cefdinir once or twice daily85 and ceftriaxone.77 However, in the Block (2000) study,85 amoxicillin dose was 40mg/kg/day; whereas in the Cohen (1999) study,58 amoxicillin dose was 80mg/kg/day. Equivalence was demonstrated in 29 comparisons, leaving 99 comparisons inconclusive.

These findings complement the findings from the original review13 that showed that children treated with amoxicillin-clavulanate for seven to ten days had a 19% increased rate of overall adverse effects and an 18% increased rate of gastrointestinal adverse effects compared to children treated with five days of azithromycin for uncomplicated AOM. (Though not specified in the studies, the clavulanate/amoxicillin ratio was likely 31.25 mg per 125 mg of amoxicillin, i.e. the original formulation.) Six children would need to be treated with azithromycin rather than amoxicillin-clavulanate to avoid a gastrointestinal adverse event. The original review also found that children treated with cefixime had an 8% greater rate of diarrhea than children treated with ampicillin or amoxicillin for uncomplicated AOM, so 12 children would need to be treated with ampicillin or amoxicillin rather than cefixime to avoid a case of diarrhea.

For treatment of AOM in children with presumed or explicitly defined recurrent and/or persistent otitis media, and/or AOM with treatment failure, we found one significant difference in adverse event rate comparisons. Amoxicillin-clavulanate (90 mg/kg/day and 6.4 mg/kg/day) was associated with diarrhea more often than ciprofloxacin-dexamethasone ear drops with a NNT of five.80 (In the Dohar (2006) study amoxicillin 90mg/kg/day was prescribed with clavulanate 6.4mg/kg/day.) However, in 41 comparisons, the adverse event rates were equivalent. In 23 comparisons, a definitive conclusion was not possible.

For prevention of AOM in children with ROM, we did not find any significant differences in any of the adverse event rate comparisons. In 11 comparisons, the adverse event rates were equivalent, and in 18 comparisons, a definitive conclusion was not possible.

Although for all three groups, the evidence was generally insufficient to allow definitive conclusions, the available evidence did indicate an increased rate of gastrointestinal effects and diarrhea specifically with amoxicillin-clavulanate and cefixime in comparison with cefdinir, ceftriaxone, or ciprofloxacin-dexamethasone ear drops and with ampicillin or amoxicillin, respectively. In addition, amoxicillin-clavulanate appeared to have a higher overall adverse effect rate than cefdinir, ceftriaxone, or azithromycin.