# Methods

## Original Proposed Key Questions

The American Academy of Pediatrics requested that AHRQ commission an update of the 2001 evidence review, Management of Acute Otitis Media. AHRQ provided an initial list of questions.

1. What is the validity of clinical symptoms and otoscopic findings such as a bulging tympanic membrane to diagnose AOM? Do these clinical findings aid physicians in distinguishing AOM from OME?
2. What organisms (bacterial and viral) are associated with otitis media since the introduction of PCV7?
3. What are the patterns of antimicrobial resistance since the introduction of PCV7?
  a. New infections
  b. Recurrent infections
4. What is the comparative effectiveness of different treatment options (defined below) for treating AOM in average risk children ages <2 years, ages 2 years to <5years and ages ≥ 5 years?
  a. Treatment options include but not limited to:
    i. Amoxicillin (including high dose vs. low dose)
    ii. Amoxicillin-clavulanate (including high-dose vs. low-dose)
    iii. Cephalosporins (e.g. ceftriaxone, cefdinir, cefixime)
    iv. “Wait and see approach”
    v. Placebo
    vi. Duration of treatment
  b. Outcomes to consider but not limited to:
    i. Parent satisfaction
    ii. Duration of symptoms/illness
    iii. Treatment failure, mastoiditis, bacteremia, clinical cure, bacteriologic cure
    iv. Disease recurrence
5. What is the comparative effectiveness of different management options for recurrent otitis media?
  a. Management options include but not limited to:
    i. Amoxicillin-clavulanate
    ii. Cephalosporins (e.g. ceftriaxone, cefuroxime)
    iii. Quinolones
    iv. Antibiotic prophylaxis
  b. Outcomes to consider but not limited to:
    i. Parent satisfaction
    ii. Duration of symptoms/illness
    iii. Treatment failure, mastoiditis, bacteremia/Cure rates
6. What is the evidence that the comparative effectiveness of different treatment options in KQ 3 differs in subpopulations of patients?
  a. Subpopulations to include (but not limited to):
    i. Bilateral disease
    ii. Comorbidities (e.g. asthma –will need to define further)
    iii. Age groups (e.g. <1 month, 1-<2 months, 2-<6 mos, 6mos–<2 years, 2–5 years)
    iv. Race/Ethnicity
    v. Day care attendance
7. What are the comparative harms of different treatment options?
  a. Outcomes to consider (but not limited to):
    i. Antibiotic resistance
    ii. Diarrhea/vomiting

The final key questions, which were slightly revised in coordination with the technical expert panel, appear in Chapter 3 (Results).

## Technical Expert Panel

Each AHRQ evidence report is guided by a Technical Expert Panel (TEP). We invited a distinguished group of scientists and clinicians, including individuals with expertise in otolaryngology, audiology, infectious disease, epidemiology, and health services, to participate in the TEP for this report. Efforts were made to include the project leader and TEP members from the 2001 AHRQ AOM report. The list of TEP members is included in Appendix F. Two conference calls were held with the TEP.

The first call, held on September 25, 2008, reviewed the draft key questions (above) and proposed definitions for AOM and ROM (see below). TEP members proposed small revisions to the wording of the key questions, definitions, and outcomes and influencing factors to consider. A summary of this meeting is provided in Appendix F. The revised key questions appear in Chapter 3. The definitions that were accepted appear below and in Appendix A.

Between the first and second TEP calls, we polled the TEP about several points. In November, we polled the panel via email to clarify whether to accept studies that used nasopharyngeal cultures for diagnosis and characterization. The consensus was that we should not; the summary of responses appears in Appendix F. In February, we provided the TEP with a list of the trials included to that point to ascertain whether we had excluded any important studies.

The second call was held on March 10, 2009. During this call, we once again asked the TEP’s help in identifying any studies we had neglected to include. We also reviewed the scope of work to assess its completeness and discussed the TEP’s expectations for reporting of findings in the final report. A summary of this call appears in Appendix F. The scope appears in Appendix A.

## Definitions of Acute Otitis Media and Recurrent Otitis Media

Definition of AOM: A diagnosis of AOM requires 1) a history of acute onset of signs and symptoms, 2) the presence of MEE, and 3) signs and symptoms of middle-ear inflammation.13

Elements of the definition of AOM are all of the following:

1. Recent, usually abrupt, onset of signs and symptoms of middle-ear inflammation and MEE
2. The presence of MEE that is indicated by any of the following:
  a. Bulging of the tympanic membrane
  b. Limited or absent mobility of the tympanic membrane
  c. Air-fluid level behind the tympanic membrane
  d. Otorrhea
3. Signs or symptoms of middle-ear inflammation as indicated by either
  a. Distinct erythema of the tympanic membrane or
  b. Distinct otalgia (discomfort clearly referable to the ear[s] that results in interference with or precludes normal activity or sleep)

Definition of Recurrent AOM (ROM): A diagnosis of ROM requires three or more episodes of AOM within six months or four episodes within 12 months, including at least one episode during the preceding six months.26–28

Definition of Persistent Otitis Media: Persistent otitis media is manifested by persistence during antimicrobial therapy of symptoms and signs of middle ear infection (treatment failure) and/or relapse of AOM within one month of completion of antibiotic therapy. When two episodes of otitis media occur within one month, it may be difficult to distinguish recurrence of AOM (i.e. a new episode) from persistent otitis media (i.e., relapse).23

Between the first and second TEP calls, we polled the TEP about several points. In November, we polled the panel via email to clarify whether to accept studies that used nasopharyngeal cultures for diagnosis and characterization. The consensus was that we should not; the summary of responses appears in Appendix F. In February, we provided the TEP with a list of the trials included to that point to ascertain whether we had excluded any important studies.

The second call was held on March 10, 2009. During this call, we once again asked the TEP’s help in identifying any studies we had neglected to include. We also reviewed the scope of work to assess its completeness and discussed the TEP’s preferences for the format used to describe findings in the final report. A summary of this call appears in Appendix F. The scope appears in Appendix A.

## Literature Search

Our search for studies began in July 2008 with an electronic search of PubMed® for reports on AOM diagnosis, treatment outcomes, and the effects of the PCV7 vaccine on the microbiology and epidemiology of AOM, using the search strategies designed for the first AOM systematic review supplemented with additional key words for newer treatment modalities, vaccine outcomes, and recurrent AOM. Separate sets of searches were conducted for Key Question I, Key Question II, and Key Questions III through VI (see Chapter 3); these searches are described further in Chapter 3 (Appendix A shows our specific search terms and strategies; Appendix H shows a conceptual framework that helped guide the searches and approach). Simultaneously, we also searched for and identified a number of systematic reviews that addressed several of the key questions.

We also searched the Cochrane Controlled Clinical Trials Register Database and the Cochrane Database of Reviews of Effectiveness (DARE). (The Cochrane Collaboration is an international organization that helps people make well-informed decisions about health care by preparing, maintaining, and promoting the accessibility of systematic reviews on the effects of heath care interventions.) Finally, we searched the Web of Science for relevant proceedings. Search updates were conducted in January and August 2009, and in August 2010.

In addition to the keyword searches, relevant articles were identified by using the Science Citation Index to search for articles that cited the 2001 AOM report and its resulting publications and by reference mining other relevant systematic reviews as well as the articles accepted for inclusion. We also identified several relevant international meeting proceedings and sought abstracts that responded to the key questions (the findings reported in most of these abstracts had been subsequently published in full-text articles). Finally, as described above, we polled the TEP for any studies we had overlooked.

## Article Review

### Study Inclusion

Although our literature search was unrestricted by study design, the studies included in the review are of one of the following types of designs.

Review articles identified by the search were classified as either systematic (including meta-analyses) or nonsystematic. Systematic reviews were identified by reading the methods section of the article to determine whether an acceptable method was employed to identify evidence (such as a description of the name of the computerized database searched and the full set of search terms used, as well as details about the method for accepting and rejecting identified articles). Only systematic reviews were included.

Randomized controlled trials (RCTs) are studies where the participants are definitely assigned prospectively to one of two (or more) alternative forms of intervention, using a process of random allocation (e.g., random number generation, coin flips).

Controlled clinical trials (CCTs) are studies where participants (or other units) are either

a. definitely assigned prospectively to one of two (or more) alternative forms of health care using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier)
  OR
b. possibly assigned prospectively to one of two (or more) alternative forms of health care using a process of random or quasi-random allocation.

Observational studies (such as cohort and cases series) are those where the investigators do not control who gets the interventions. The decision was made to exclude observational studies unless controlled trials were insufficient to answer the key questions pertaining to treatment.

To be included, studies had to report on diagnosis or treatment of AOM, primary or recurrent; or the effects of the Prevnar® vaccine on bacterial microbiology/epidemiology.

### Screening

Two reviewers, both pediatricians trained in the critical analysis of scientific literature, independently reviewed lists of titles obtained from each search. Abstracts were obtained for all potentially relevant titles, and the clinicians independently reviewed the abstracts, resolving disagreements by consensus. Using a single-page “screening form” (included in Appendix B), they reviewed the abstracts retrieved from the various sources to assess whether they reported original data (or appeared to be systematic reviews) and responded to one of the key questions.

Full text articles were obtained for all accepted abstracts. Relevant study-level information was then abstracted from these articles onto review forms. This information included study design, sample size and identity, treatment protocol, types of outcomes reported and by whom, potential influencing factors, and study quality. The two reviewers independently reviewed each study and resolved disagreements by consensus. The lead investigator resolved any disagreements that remained after discussions between the reviewers.

## Data Abstraction & Synthesis of Results

### Review and Assessment of Study Quality

The criteria for the assessment of study quality were established prior to the review of articles. The criteria developed by Jadad, Moore, Carroll et al. (1996) were used to evaluate the quality of RCTs.29 For a given study, we awarded one point if the study was described as randomized, one point if the study was described as double-blind, and one point if it described withdrawals and dropouts. We awarded an extra point if the method of randomization was appropriate and another if the method of double-blinding was appropriate; conversely, we subtracted one point each if the method of randomization or double-blinding was inappropriate. Thus, studies could receive a Jadad score ranging from 0 to 5 points.

The criteria used to evaluate the quality of cohort studies and case-control studies were based on the work by the McMaster University Group.30–32 The quality of cohort studies was evaluated against eight components, which included the presence or absence of a clear definition of the study cohort, an early inception point, a clear pathway of patient entry, complete follow-up, description of dropouts, objective outcome criteria, ‘blind’ outcome assessment, and adjustment for extraneous factors. The quality of studies that examined diagnostic tests was evaluated using QUADAS criteria.33 The quality of systematic reviews was evaluated using the Assessment of Multiple Systematic Reviews (AMSTAR) criteria. Quality reviews were carried out in the same manner as the screening of articles for inclusion/exclusion. Articles were not masked prior to review. Two physician reviewers independently evaluated the quality of the articles and filled out the quality review forms. Conferences were held to resolve discrepancies whenever needed.

### Data Abstraction

For the articles eligible for inclusion in the Evidence Report, data abstraction was carried out by two physician reviewers. Data abstracted included parameters necessary to define study groups, inclusion/exclusion criteria, influencing factors, and outcome measures. Data for analysis were abstracted by a biostatistician and checked by a physician reviewer. We used a sequential resolution strategy to match and resolve the screening and review results of the two reviewers. The data abstraction form used is included in Appendix B.

### Supplemental Analysis for Key Question III

Key Question III addresses the comparative effectiveness of different treatment options for treating uncomplicated AOM in average risk children for treatment options including but not limited to antibiotics, “wait-and-see” approach, analgesics, and placebo and for outcomes including but not limited to treatment failure, invasive infections, bacteriologic cure, disease recurrence, quality of life or functional outcome, and parent satisfaction. Among the included articles we tabulated the number of articles by treatment options and by outcomes in order to assess whether there was an adequate number of articles for pooling analysis.

Our review of data to address this key question (as well as questions pertaining to prevention and treatment of ROM) had several limitations. First, definitions for clinical success were usually not equivalent between studies comparing the same treatments. For example, studies used different clinical criteria to define success, and success was often measured at different time points. Second, the inclusion criteria for participants also varied widely among studies. Some studies used only one of the three criteria for AOM diagnosis, while others considered two or all three. It is possible that some studies with less stringent inclusion criteria may have included participants who did not have AOM, but rather had OME or no middle ear infective process at all. Third, the timing of study completion could affect results. In analysis, the articles eligible for analysis for the key question were grouped according to the specific treatment options they compared. Each comparison consisted of articles that were considered homogeneous from the standpoint of clinical practice.

Since this key question was addressed in the first evidence report published in 2001, we combined the articles identified in that report with newly identified articles in this evidence report. Comparisons that included three or more articles from the old and new searches were subjected to meta-analyses or quantitative syntheses where their data were pooled.

We used the Der Simonian and Laird random effects model34 to pool rate differences across studies. This method produces a summary measure that is a weighted mean. It weights each study’s measure by the inverse of the sum of the within-study variance and the between-study variance. This approach allows both sampling variation and between-study heterogeneity to affect the pooled estimate. Among the three effect measures—rate difference, relative risk, and odds ratio—the TEP and the project staff chose as most suitable the rate difference and its 95 percent confidence interval. It should be noted that we have used the absolute rate difference rather than the relative rate difference to measure the effect size throughout the report. Further, we reported the findings on the success rate instead of the failure rate throughout the report as recommended by the TEP.

In addition to the pooled estimate, we report the Q statistic and p-value for the Chi-squared test of heterogeneity, which tests the null hypothesis that the individual study results are homogeneous.35 A test of heterogeneity was performed using the I^2^ statistic.36 I^2^ values close to 100% represent very high degrees of heterogeneity. The I^2^ statistic uses the Q statistic to measure the degree of inconsistency (excess variability) across studies: I^2^=100% x(Q-[k-1])/Q, where k is the number of studies included in the analysis. Its advantage is that it can be used for studies with different outcomes and it provides an assessment of the degree of heterogeneity.

For assessment of publication bias, we examined funnel plots and derived the Egger‘s asymmetry test.

We used Stata 10.0 to perform the meta-analyses.37

### Supplemental Analysis for Key Question IV

Key Question IV is the same question as Key Question III except that the study population comprises children with RECURRENT otitis media. The same analytical approach was taken. First we tabulated the number of articles by treatment options and by outcomes in order to assess whether the number of articles was adequate for pooled analysis.

The articles eligible for analysis for the key question were grouped by comparisons of treatment options. Each comparison consisted of articles that were considered homogeneous from the standpoint of clinical practice. Although this key question was NOT addressed in the 2001 evidence report, we used the articles identified in that report along with articles newly identified for this report. Comparisons that involved three or more articles were subjected to meta-analyses or quantitative syntheses where their data were pooled.

### Supplemental Analysis for Key Question V

Key Question V poses the same question as Key Questions III and IV except that this question specifies analysis of the treatment effectiveness by characteristics of the condition (AOM), patient, environment, and/or health care delivery system, including but not limited to laterality, otorrhea or perforation, AOM severity, comorbidities (e.g. asthma), age group, race, ethnicity, and day care attendance. For this key question, we further divided the articles within each comparison into subgroups by influencing factors to the extent possible. The same analytical approach was taken. Comparisons that involved three or more articles were subjected to meta-analyses or quantitative syntheses where their data were pooled.

### Supplemental Analysis for Key Question VI

Key Question VI addresses the comparative safety of the various treatment options used for a) treating uncomplicated AOM, b) preventing AOM in children with ROM, or c) treating AOM in children with ROM. Among the included articles, we identified the number of articles by treatment options in order to assess whether there were an adequate number of articles for pooling analysis.

Adverse events were recorded onto a spreadsheet that identified each trial arm, the description of the adverse event from the original article, the number of participants in each group, and the number of participants affected. We counted each event as if it had been experienced by a unique individual. However, because a single individual might have experienced more than one event, our assumption may have overestimated the actual number of people who experienced an adverse event.

If a trial report mentioned a particular type of adverse event in the discussion but did not report data on that adverse event (either that no participants experienced that adverse event or some number of participants experienced the adverse event), we excluded that trial from the analysis of that particular type of event. In other words, we did not assume an adverse event occurred unless the trial report specifically stated that some number of events was observed (at the same time, for such studies, we did not assume that NO participants experienced the event). By taking this approach, we may have either overestimated or underestimated the number of participants who experienced a particular adverse event, respectively

After abstracting the data, we identified mutually exclusive groups of similar events, based on clinical expertise. For each adverse-event subgroup, we report the number of trials that provided data for any event in the subgroup. We also report the total number of individuals in the medication groups in the relevant trials who were observed to have experienced the event and the total number of patients in the medication groups in those trials. We then report the analogous counts for the control groups in the relevant trials. We analyzed and pooled the findings of the articles in the same way for this question as for Key Questions III and IV except that the outcome measure was the adverse event rate. Comparisons that included three or more articles were subjected to meta-analyses or quantitative syntheses where their data were pooled. We used the Der Simonian and Laird random effects model34 to pool rate differences across studies.

### Use of Observational Studies to Assess Comparative Effectiveness

Observational studies can help augment the evidence from trials about the comparative effectiveness of treatments. Such studies can provide evidence of benefits and harms in populations of patients with less restrictive clinical characteristics than those typically enrolled in trials, and large observational studies can provide the statistical power needed to detect rare adverse effects. We searched for large observational studies assessing benefits or harms of treatment of AOM in children, but found none that addressed the key questions pertaining to treatment efficacy or safety. However, a small number of observational studies were included for the purpose of responding to Key Question I, on diagnostic criteria, and Key Question II, on the impact of the PCV7 vaccine.

### Rating the Overall Quality of Scientific Evidence

We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group, which considers four key elements to classify the quality of evidence: study design, study quality, consistency, and directness.

- Study design refers to the basic design of the study (i.e., RCT, observational studies).
- Study quality refers to the study methods and execution.
- Consistency refers to the similarity of effects estimates across studies.
- Directness refers to the extent to which the study details (participants, interventions, outcome measures) are generalizable to those of interest.

Based on these four criteria, GRADE classifies the quality of evidence as high, moderate, low, or very low, where

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact in our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient = Any estimate of effect is very uncertain (this term was modified from “Very Low” by the EPC).

The criteria for consideration when assigning grade of evidence are as follows.

Type of evidence:

- Randomized trial = high
- Observational study = low
- Any other evidence = insufficient

Decrease grade if:

- Serious (−1) or very serious (−2) limitation to study quality
- Important inconsistency (−1)
- Some (−1) or major (−2) uncertainty about directness
- Imprecise or sparse data (−1)
- High probability of reporting bias (−1)

Increase grade if:

- Strong evidence of association-significant relative risk of > 2 (or < 0.5) based on consistent evidence from two or more observational studies, with no plausible confounders (+1)
- Very strong evidence of association-significant relative risk of > 5 (or < 0.2) based on direct evidence with no major threats to validity (+2)
- Evidence of a dose-response gradient (+1)
- All plausible confounders would have reduced the effect (+1)

As part of our consideration in rating the quality of scientific evidence, we also assessed the quantitative strength of the evidence, taking into consideration the magnitude of treatment effects, the number of studies that have evaluated the given topic, and the overall sample size across all included studies.

When comparing an outcome between two groups, statistical significance is used to answer the question “is there a difference?” If there is a difference, the next question is “is this difference clinically important?” Not all differences that are statistically significant are clinically important. The concept of the “minimum clinically important difference” (MCID) sets a threshold for the smallest difference that would be clinically meaningful. Ideally, this would be determined empirically, through studies of construct validity of different thresholds for the clinical question of interest. Such work has been done in conditions like rheumatoid arthritis and back pain. When empirical data are not present, the MCID is often arrived at by using clinical judgment or rules of thumb. Cohen first proposed a commonly used classification scheme for considering the size of a treatment effect.38 In Cohen’s classification, effect sizes of 0.20 are considered “small” effects. We used this threshold to set the MCID for the treatment of AOM at 5%.

Hypothetical examples of the application of the MCID and the statistical significance are presented in Figure 1. Scenario I is a situation where there exists a statistically significant difference between AOM outcomes in a trial comparing two treatments, but that difference is only 3%. Scenario II is where a trial finds no statistically significant difference in outcomes between treatments. In Scenarios I and II, since the 95% confidence intervals lie completely inside the zone of MCID, we conclude that there is sufficient evidence that Treatment A and Treatment B are not clinically different even though in scenario I the difference between treatments is statistically significant. In Scenario III, where the 95% confidence interval lies outside the zone of MCID to the right, we conclude that there is sufficient evidence that Treatment A is clinically better than Treatment B. In Scenario IV, where the 95% confidence interval lies outside the zone of MCID to the left, we can conclude that there is sufficient evidence that Treatment B is clinically better than Treatment A. In Scenarios V and VI, the 95% confidence intervals cross into the zone of MCID, and we conclude that there is insufficient evidence to make any conclusion on the relative effectiveness of Treatments A and B.

It should be noted that the determination of the size of the zone of MCID must take into consideration the topic, the treatment options, the outcome measures, and the balance of proving equivalence or significance. The zone of MCID must be the limits within which any difference found between two treatment options is considered clinically irrelevant. A narrow zone of MCID will allow more differences to be significant but will make it more difficult (require a larger sample size) to prove equivalence. A wide zone of MCID will make it easier to prove equivalence (i.e., permit a smaller sample size) but more difficult to prove significance (i.e., require a larger sample size).

Readers who believe the MCID should be smaller or larger can adjust their interpretations of the evidence to fit their own assumptions.

Figure 1 Statistical Inference Using Confidence Interval (CI) and Minimal Clinically Important Difference (MCID)

Figure 1 depicts a line graph showing six different scenarios in treatments where the zone of minimal clinically important difference. Two scenarios, numbers three and four, fall outside of the minimal clinically important difference zone.

## Peer Review

A draft of this report was prepared in May 2009 and sent to the TEP members and national and international experts for review. Peer reviewer comments were considered by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers, and service as a peer reviewer or member of the TEP cannot be construed as endorsement of the report’s findings.