# Comparison of Original Research Studies Included in Systematic Reviews

| Damoiseaux 1998 - "Antibiotic treatment of acute otitis media in children under 2 years of age" Br.J.Gen.Prac. 48(437): 1861-1864 | Foxlee 2006 - "Topical analgesia for acute otitis media" Cochr. Database Syst Revs (3) | Glasziou 2004 - "Antibiotics for acute otitis media in children" Cochr. Database Syst Revs (1) | Kozyrskyj 2000 - "Short course antibiotics for acute otitis media" Cochr. Database Syst Revs (2) | Rosenfeld 1994 - "Clinical efficacy of antimicrobial drugs for acute otitis media: metaanalysis…" J. Pediatrics 124:355-367 | Rovers 2006 - "Antibiotics for acute otitis media: a meta-analysis…" Lancet 368(9545): 1429-1435 | Spurling 2007 - "Delayed antibiotics for respiratory infections" Cochr. Database Syst Revs (3) | Takata 2001 - "Evidence assessment of management of acute otitis media: I. The role of antibiotics…" Pediatrics 108:239-247 | AHRQ Report No. 15 - "Management of Acute Otitis Media" - References | Bonati 1992 -"Metaanalysis of antimicrobial prophylaxis for recurrent acute otits-media" Clinical Trials and Meta-Analysis 28(1):39-50 | Leach 2006 - "Antibiotics for the prevention of acute and chronic suppurative otitis media in children" Cochrane Collaboration 2009, Issue 1 | McDonald 2008 - "Grommets (ventiliation tubes) for recurrent acute otitis media in children (Review)." The Cochrane Collaboration, 2009, Issue 1 | Straetemans 2004 - "Pnemococcal vaccines for preventing otitis media (Review)", Cochrane Collaboration 2008(3). | Williams 2003 - " Use of antibiotics in preventing recurrent otitis media and in treating otitis media with effusion: A meta-analytic attempt to resolve the brouhaha," JAMA 270(11):1344-1351. | Rothman 2003 - "Does this child have acute otitis media?" JAMA 2003; 290(12):1633-1640 | Abes 2003 - "A systematic review of the effectiveness of ofloxaxin[sic] for the treatment of suppurative otitis media," ORL J Otorhinolaryngol Relat Spec. 2003;65:106-116. | Thanaviratananich 2008 - "Once or twice daiily versus three times daily amoxicillin with or without clavulanate for the treatment of acute otitis media (Review)." Cochrane Collaboration 2009 | Wall 2009 -"Ciprofloxacin 0.3%/Dexamethasone 0.1% Sterile Otic Suspension for the Topical treatment of ear infections: A review of the literature." Pediatric Infectious Disease Journal, 28(2):141-144.
Abes J, Jamir J, Gloria-Cruz MT, Gumban V, Seredrica G: Comparative efficacy and safety of ofloxacin and polymixin otic drops for chronic suppurative otitis media. UPM J 1998;4:59-70. | | | | | | | | | | | | | | | | Incl
Abramson M. Topical anesthesia of the tympanic membrane. Archives of Otolaryngology 1969;90(2):147-9. | | excl
Adam D Five-day therapy with cefpodoxime versus ten-day treatment with cefaclor in infants with acute otitis media. Infection 1995; 23:398-400 | | | | | | | | Incl
Adam D. Five-day therapy with cefpodoxime versus ten-day treatment with cefaclor in infants with acute otitis media. Infection 1995;23:398-99. | | | | Incl
Agro AS, Garner ET, Wright JW, De Escobar IC, Villeda B, Seidlin M: Clinical trial of ototopical ofloxacin for treatment of chronic suppurative otitis media. Clin Ther 1998;20:744-758. | | | | | | | | | | | | | | | | Incl
ALHO OP What is the natural history of recurrent acute otitis media in infancy? JOURNAL OF FAMILY PRACTICE 43 : 258 1996 | Ref
ALTMAN DG Better reporting of randomised controlled trials: The CONSORT statement - Authors must provide enough information for readers to know how the trial was performed BRITISH MEDICAL JOURNAL 313 : 570 1996 | Ref
American Academy of Pediatrics Subcommittee on Management of Acute Otitis Media. Diagnosis and management of acute otitis media. Pediatrics 2004;113:1451-65. | | Ref | | | | | | | Ref
Appelman CL, Claessen JQ, Touw Otten FW, Hordijk GJ, de Melker RA. Severity of inflammation of tympanic membrane as predictor of clinical course of recurrent acute otitis media. BMJ 1993;306:895. | | | Incl
APPELMAN CLM CO-AMOXICLAV IN RECURRENT ACUTE OTITIS-MEDIA - PLACEBO CONTROLLED-STUDY BRITISH MEDICAL JOURNAL 303 : 1450 1991 | Incl | | Incl | Incl | | Incl | | Incl | Ref
Appelman CLM, van Balen FAM, van de Lisdonk EH,van Weert HCPM, Eizenga WH. NHG–Standaard Otitis Media Acuta. Huisarts en Wetenschap 1999; 42: 362–66.
Arason A, Kristinsson KG, Sigurdson JA, Stefansdottir G, Molstad S, Gudmundsson S. Do antimicrobials increase the carriage rate of penicillin resistant pneumoccci in children? Cross sectional prevalence study. British Medical Journal 1996;313:387–91. | | | | | | | Ref
Arguedas A, Loaiza C, Herrara M, Mohs E. Comparative trial of 3-day azithromycin versus 10-day amoxycillin/clavulante potassium in the treatment of children with acute otitis media with effusion. Int J Antimicrobial Agents 1996;6:233-8. | | | | Incl | | | | Incl | Ref
Arguedas A, Loaiza C, Rodriguez F, Herrera ML, et al. Comparative trial of 3 days of azithromycin versus 10 days of clarithromycin in the treatment of children with acute otitis media with effusion. J Chemother 1997;9:44-50. | | | | Incl | | | | Incl | Ref
Aronovitz G A multicenter, open label trial of azithromycin vs. amoxicillin/clavulanate for the management of acute otitis media in children. Pediatr Infect Dis J 1996; 15:S15-S19 | | | | Incl | | | | Incl | Ref
Arroll B, Goodyear-Smith F, Thomas D, KerseN. Delayed antibiotic prescriptions: What are the experiences and attitudes of physicians and patients?. The Journal of Family Practice 2002;51(11):954–9. | | | | | | | Ref
Arroll B, Kenealy T, Kerse N. Do delayed prescriptions reduce antibiotic use in respiratory tract infections? A systematic review. British Journal of General Practice 2003;53:871–7. | | | | | | | Ref
Arroll B, Kenealy T, Kerse N. Do delayed prescriptions reduce the use of antibiotics for the common cold? A single-blind controlled trial. Journal of Family Practice 2002;51(4):324–8. | | | | | | | Incl
ArrollB, Kenealy T. Antibiotics for the common cold and acute purulent rhinitis. Cochrane Database of Systematic Reviews 2005, Issue 3.Art.No.: CD000247. DOI:10.1002/14651858.CD000247.pub2. | | | | | | | Ref
BABA S A parallel comparative double blind study of cefixime with cefaclor in the treatment of acute suppurative otitis media in children JPN J ANTIBIOT 40 : 1 1987 | | | | | Incl
BAIN J ACUTE OTITIS-MEDIA - CLINICAL COURSE AMONG CHILDREN WHO RECEIVED A SHORT COURSE OF HIGH-DOSE ANTIBIOTIC BRITISH MEDICAL JOURNAL 291 : 1243 1985 | | | | Incl | excl | | | Incl | Ref
Barnett ED, Teele DW, Klein JO, Cabral HJ, Kharasch SJ. Comparison of ceftriaxone and trimethoprim-sulfamethoxazole for acute otitis media. Pediatrics 1997;99:23-8. | | | | Incl | | | | | Ref
Bass JW, Cashman TM, Frostad AL, Yamaoka M, Schooler RA, Dierdorff EP Antimicrobials in the treatment of acute otitis media. A second clinical trial. Am J Dis Child 1973; 125:397-402 | | | | | Incl | | | | Ref
Bass JW, Cohen SH, Corless JD, Mamunes P. Ampicillin compared to other antimicrobials in acute otitis media. JAMA. 1967;202;697-702 | | | | | Incl | | | | Ref
Bauchner H, Adams W, Barnett E, Klein J Therapy for acute otitis media. Preference of parents for oral or parenteral antibiotic. Arch Pediatr Adolesc Med 1996; 150:396-399 | | | | | | | | Incl | Ref
BEGG CB A MEASURE TO AID IN THE INTERPRETATION OF PUBLISHED CLINICAL-TRIALS STATISTICS IN MEDICINE 4 : 1 1985 | | | | | Ref
BEGUE P ACUTE OTITIS-MEDIA IN CHILDREN - A RANDOMIZED OPEN CLINICAL-TRIAL OF EFFECTIVENESS OF 2 MAJOR ANTIBIOTICS - (ERYTHROMYCIN ETHYLSUCCINATE ACETYL-SULFAFURAZOLE VERSUS AMOXICILLIN CLAVULANIC ACID ANNALES DE PEDIATRIE 37 : 127 1990 | | | | | Incl
Behre U, Burow HM, Quinn P, Cree F, Harrison HE. Efficacy of twice-daily dosing of amoxycillin/clavulanate in acute otitis media in children. Infection 1997;25(3):163-6. | | | | | | | | | | | | | | | | | Incl
BERGERON MG COMPARATIVE EFFICACIES OF ERYTHROMYCIN-SULFISOXAZOLE AND CEFACLOR IN ACUTE OTITIS-MEDIA - A DOUBLE-BLIND RANDOMIZED TRIAL PEDIATRIC INFECTIOUS DISEASE JOURNAL 6 : 654 1987 | | | | | Incl
Berlin JA. Does blinding of readers affect the results of meta-analyses? Lancet 1997 1997;350:185-6. | | | | Ref
Berman S, Byrns PJ, Bondy J, Smith PJ, Lezotte D. Otitis mediarelated antibiotic prescribing patterns, outcomes, and expenditures in a pediatric medicaid population. Pediatrics 1997;100(4):585–92. | | | | | | | Ref
Berman S, Lauer BA A controlled trial of cefaclor versus amoxicillin for treatment of acute otitis media in early infancy. Pediatr Infect Dis J 1983; 2:30-33 | | | | | | | | | Ref
Berman S. Otitis media in developing countries. Pediatrics 1996;96:126-31. | | Ref | Ref | Ref
Black S, Shinefield H, Fireman B, Lewis E, Ray P, Hansen JR, et al. Efficacy, safety and immunogenicity of heptavalent pneumococcal conjugate vaccine in children. Northern California Kaiser Permanente Vaccine Study Center Group. Pediatric Infectious Disease Journal 2000;19(3):187-95 | | | | | | | | | | | | | Incl
BLUESTONE CD CURRENT THERAPY FOR OTITIS-MEDIA AND CRITERIA FOR EVALUATION OF NEW ANTIMICROBIAL AGENTS CLINICAL INFECTIOUS DISEASES 14 : S197 1992 | | | | | Ref
Blumer JL, Bertino JS Jr, Husak MP Comparison of cefaclor and trimethoprim-sulfamethoxazole in the treatment of acute otitis media. Pediatr Infect Dis 1984; 3:25-29 | | | | | Incl | | | | Ref
BODOR FF SYSTEMIC ANTIBIOTICS FOR TREATMENT OF THE CONJUNCTIVITIS OTITIS MEDIA SYNDROMEPEDIATRIC INFECTIOUS DISEASE JOURNAL 8 : 287 1989 | | | | | Ref
Boesoirie T: A comparative study between ofloxacin ear drops and neomycin-polymixin b-hydrocortisone ear drops on the chronic suppurative otitis media. Department of ENT Head and Neck Surgery, University of Padjajaran, Bandung, Indonesia. Unpublished, 2000. | | | | | | | | | | | | | | | | Incl
BOISSEL JP CONSIDERATIONS FOR THE METAANALYSIS OF RANDOMIZED CLINICAL-TRIALS - SUMMARY OF A PANEL DISCUSSION CONTROLLED CLINICAL TRIALS 10 : 254 1989 | | | | | Ref
Bollag U, Bollag-Albrecht E Recommendations derived from practice audit for the treatment of acute otitis media. Lancet 1991; 338:96-99 | | | | | | | | Incl | Ref
Borzak S, Ridker PM. Discordance between meta-analyses and large-scale randomized, controlled trials. Ann Intern Med 1995;123:873-7. | | | | Ref
Bottenfield GW, Burch DJ, Hedrick JA, Schaten R, Rowinski CA, Davies JT Safety and tolerability of a new formulation (90 mg/kg/day divided every 12 h) of amoxicillin/clavulanate (Augmentin) in the empiric treatment of pediatric acute otitis media caused by drug-resistantStreptococcus pneumoniae. Pediatr Infect Dis J 1998; 17:963-968 | | | | | | | | Incl
Boulesteix J, Begue P, Dubreuil C, Acute otitis media in children: a study of nasopharyngeal carriage of potential pathogens and therapeutic efficacy of cefixime and amoxicillin-clavulanate. Infection 1995; 23:S79-S82
Boulesteix J, Dubreuil C, Moutot M, Rezvani Y, Rosembaum. Cefpodoxime proxetil 5 jours versus cefixime 8 jours, dans le traitement des otites moyennes aigues de l'enfant. Med Mal Infect 1995;25:534-9. | | | | Incl | | | | | Ref
Britten N, Ukoumunne O. The infl uence of patients’ hopes of receiving a prescription on doctors’ perceptions and the decisionto prescribe: a questionnaire survey. BMJ 1997; 315: 1506–10.
Brodie DP, Griggs JV, Cunningham K Comparative study of cefuroxime axetil suspension and amoxicillin syrup in the treatment of acute otitis media in general practice. J Int Med Res 1990; 18:235-239 | | | | | | | | | Ref
Brook I.Microbiology of common infections in the upper respiratory tract. Primary Care 1998;25(3):633–48. | | | | | | | Ref
Brookes ST, Whitley E, Peters TJ, Mulheran PA, Egger M, Davey Smith G. Subgroup analyses in randomised controlled trials: quantifying the risks of false- positives and false-negatives.Health Technol Assess 2001; 5: 1–56.
BROWNING GG CONTROVERSIES IN THERAPEUTICS - CHILDHOOD OTALGIA - ACUTE OTITIS-MEDIA .1. ANTIBIOTICS NOT NECESSARY IN MOST CASES BRITISH MEDICAL JOURNAL 300 : 1005 1990 | | | | | Ref
BRUIJNZEELS MA Everyday symptoms in childhood: occurrence and general practitioner consultation rates BRITISH JOURNAL OF GENERAL PRACTICE 48 : 880 1998 | Ref
Brunet J, Cozette P. [Clinical study of Otipax in infectious and barotraumatic pathology of the middle ear]. Therapeutique 1970;46(4):399-401. | | excl
Burke P, Bain J, Robinson D, Dunleavey J Acute red ear in children: controlled trial of non-antibiotic treatment in general practice. BMJ. 1991; 303:558-562 | Ref | | Incl | Ref | Incl | Incl | | Incl | Ref
Busmann GJ. [Local therapy of diseases of the middle ear]. Therapie der Gegenwart 1967;106(10):1326-9. | | excl
CALLAHAN CW COST-EFFECTIVENESS OF ANTIBIOTIC-THERAPY FOR OTITIS-MEDIA IN A MILITARY PEDIATRIC-CLINICPEDIATRIC INFECTIOUS DISEASE JOURNAL 7 : 622 1988 | | | | | Ref
CAMERON GG Comparative efficacy of ampicillin and trimethoprim-sulfamethoxazole in otitis media CAN MED ASSOC J 112 : 87 1975 | | | | | Incl
Canafax DM, Giebink GS. Clinical and pharmacokinetic basis for the antimicrobial treament of acute otitis media. Otolaryngol Clin North Am 1991;24:859-74. | | | | Ref
CARLIN SA EARLY RECURRENCES OF OTITIS-MEDIA - REINFECTION OR RELAPSE JOURNAL OF PEDIATRICS 110 : 20 1987 | | | | | Ref
Casselbrant ML, Kaleida PH, Rockette HE, Paradise JL, Bluestone CD, Kurs-Lasky M, et al. Efficacy of antimicrobial prophylaxis and of tympanostomy tube insertion for prevention of recurrent acute otitis media: results of a randomized clinical trial. Pediatric Infectious Disease Journal 1992;11(4):278-86. | | | | | | | | | | | Incl | | | Incl
Cates C. An evidence based approach to reducing antibiotics use in children with acute otitis media: controlled before and after study. British Medical Journal 1999;318:715–6. | | | Ref | | | | excl
Chalmers I, Adams M, Dickersin K, Hetherington J, Tarnow-Mordi W, Meinert C, et al. A cohort study of summary reports of controlled trials. The Journal of the American Medical Association 1990;263(10):1401-5. | | Ref | Ref | | | | Ref
CHALMERS TC A METHOD FOR ASSESSING THE QUALITY OF A RANDOMIZED CONTROL TRIAL CONTROLLED CLINICAL TRIALS 2 : 31 1981 | Ref
CHALMERS TC DATA ANAL CLIN MED Q : 85 1988 | | | | | Ref
CHALMERS TC METAANALYSIS OF CLINICAL-TRIALS AS A SCIENTIFIC DISCIPLINE .1. CONTROL OF BIAS AND COMPARISON WITH LARGE COOPERATIVE TRIALS STATISTICS IN MEDICINE 6 : 315 1987 | | | | | Ref
CHALMERS TC PROBLEMS INDUCED BY META-ANALYSES STATISTICS IN MEDICINE 10 : 971 1991 | | | | | Ref
Chalmers TC, Celano P, Sacks HS, Smith Jr H. Bias in treatment assignment in controlled clinical trials. N Engl J Med 1983;309:1358-61. | | | | Ref
Chamberlain JM, Boenning DA, Waisman Y, Ochsenschlager DW, Klein BL Single-dose ceftriaxone versus 10 days of cefaclor for otitis media. Clin Pediatr 1994; 33:642-646 | | | | Incl | | | | Incl | Ref
Chaput de Saintonge DM, Levine DF, Temple Savage IT, Burgess GW, Sharp J, Mayhew SR, et al. Trial of three-day and ten-day courses of amoxycillin in otitis media. BMJ Clinical Research Edition 1982;284(6322):1078-81. | | | excl | Incl | | | | Incl | Ref
Charles J, Pan Y, Britt H. Trends in childhood illness and treatment in Australian general practice, 1971-2001. Medical Journal of Australia 2004;180:216-9. | | Ref
CHONMAITREE T RESPIRATORY VIRUSES INTERFERE WITH BACTERIOLOGICAL RESPONSE TO ANTIBIOTIC IN CHILDREN WITH ACUTE OTITIS-MEDIA JOURNAL OF INFECTIOUS DISEASES 162 : 546 1990 | | | | | Ref
Claessen JQ, Appelman CL, Touw Otten FW, de Melker RA, Hordijk GJ. Persistence of middle ear dysfunction after recurrent acute otitis media. Clinical Otolaryngology 1994;19:35-40. | | | Incl | | | | | Incl | Ref
CLAESSEN JQPJ A REVIEW OF CLINICAL-TRIALS REGARDING TREATMENT OF ACUTE OTITIS-MEDIA CLINICAL OTOLARYNGOLOGY 17 : 251 1992 | Ref
Cohen ML. Epidemiology of drug resistance:implications for a post-antimicrobial era. Science 1992;257:1050-5. | | | | Ref
COHEN R RANDOMIZED OPEN STUDY OF PEDIAZOLE VERSUS CEFACLOR IN CHILDREN WITH ACUTE OTITIS-MEDIA ANNALES DE PEDIATRIE 38 : 115 1991 | | | | | Incl
Cohen R, de La Rocque F, Boucherat M, Levy C, Langue J, Bourrillon A Randomized trial comparing 5-day cefpodoxime proxetil and 8-day amoxicillin-clavulanate treatment of acute otitis media in children [Étude randomisée cefpodoxime proxetil 5 jours versus amoxicilline-acide clavulanique 8 jours dans le traitement de l'otite moyenne aigue de l'enfant]. Med Mal Infect 1997; 27:596-602 | | | | Incl | | | | | Ref
Cohen R, Levy C, Boucherat M, Levy C, Langue J, de La Rocque F A multicenter, randomized, double-blind trial of 5 versus 10 days of antibiotic therapy for acute otitis media in young children. J Pediatr 1998; 133:634-639 | | | | | | | | Incl | Ref
Coles SJ, Addlestone MB, Kamdar MK, Macklin JL A comparative study of clarithromycin and amoxicillin suspensions in the treatment of pediatric patients with acute otitis media. Infection 1993; 21:272-278 | | | | | | | | | Ref
Comeau M, Brummett R. Anesthesia of the human tympanic membrane by iontophoresis of a local anesthetic. The laryngoscope 1978;88(2 Pt 1):277-85. | | excl
Cook DJ, Sackett DL, Spitzer WO. Methodologic guidelines for systematic review of randomized control trials in health care from the Potsdam Consulation. J Clin Epidemiol 1995;48:161-71. | | | | Ref
Cruze, E.; Weldon, J. Minitab Reference Manual, Release 7; Minitab Inc: Forge Valley, PA, 1989. | | | | | Ref
Dagan R, Sikuler-Cohen M, Zamir O, Janco J, Givon-Lavi N, Fraser D. Effect of a conjugate pneumococcal vaccine on the occurrence of respiratory infections and antibiotic use in day-care center attendees. Pediatric Infectious Disease Journal 2001;20(10):951-8. | | | | | | | | | | | | | Incl
DALY KA EPIDEMIOLOGY OF OTITIS-MEDIA OTOLARYNGOLOGIC CLINICS OF NORTH AMERICA 24 : 775 1991 | | | | | Ref
Damoiseaux RA, van Balen FA, Hoes AW, Verheij TJ,de Melker RA. Primary care based randomised, double blind trial of amoxicillin versus placebo for acute otitus media in children aged under 2 years. BMJ 2000; 320:350-54 | | | | | | Incl
Damoiseaux RAMJ, van Balen FAM, Hoes AW, Verheij TJM and de Melker RA (2000) Primary care based randomised, double blind trial of amoxycillin versus placebo for acute otitis media in children aged under 2 years, British Medical Journal, 320: 330-334. | | | Ref
Damrikarnlert L, Jauregui AC, Kzadri M. Efficacy and safety of amoxycillin/clavulanate (Augmentin) twice daily versus three times daily in the treatment of acute otitis media in children. The Augmentin 454 Study Group. Journal of Chemotherapy 2000;12(1):78-97. | | | | | | | | | | | | | | | | | Incl
Daniel RR Comparison of azithromycin and co-amoxiclav in the treatment of otitis media in children. J Antimicrob Chemother 1993; 31:65-71 | | | | Incl | | Incl | | Incl | Ref
Del Mar C, Glasziou P, Hayem M Are antibiotics indicated as initial treatment for children with acute otitis media? A meta-analysis. BMJ 1997; 314:1526-1529 | Ref | | | Ref | | excl
Del Mar CB, Glasziou PP, Spinks AB. Antibiotics for sore throat.Cochrane Database of Systematic Reviews 2006, Issue 4.Art. No.:CD000023. DOI:10.1002/14651858.CD000023.pub3.
Department of Health Standing Medical Advisory Committee Subgroup on Antimicrobial Resistance 2000 Department of Health Standing Medical Advisory Committee Subgroup on Antimicrobial Resistance. The path of least resistance-main report. London: DoH 2000. w | | Ref
DERSIMONIAN R METAANALYSIS IN CLINICAL-TRIALS CONTROLLED CLINICAL TRIALS 7 : 177 1986 | | | | Ref | Ref | | Ref
DESAINTONGE DMC TRIAL OF 3-DAY AND 10-DAY COURSES OF AMOXYCILLIN IN OTITIS-MEDIA BRITISH MEDICAL JOURNAL 284 : 1078 1982 | | | | | Ref
DICKERSIN K FACTORS INFLUENCING PUBLICATION OF RESEARCH RESULTS - FOLLOW-UP OF APPLICATIONS SUBMITTED TO 2 INSTITUTIONAL REVIEW BOARDS JAMA-JOURNAL OF THE AMERICAN MEDICAL ASSOCIATION 267 : 374 1992 | | | | | Ref
Dickersin K, Scherer R, Lefebvre C. Identifying relevant studies for systematic reviews. BMJ 1994;309(6964):1286-91. | | | Ref | Ref
Dohar J, Garner E, Nielsen R, Biel MA, Seidlin M: Topical ofloxacin treatment of otorrhea in children with tympanostomy tubes. Arch Otolaryngol Head Neck Surg 1999;125:537-545. | | | | | | | | | | | | | | | | Incl
Dohar J, Giles W, Roland RS, et al. Topical ciprofloxacin/dexamethasone superior to oral amoxicillin/clavulanic acid in acute otitis media with otorrhea through tympanostomy tubes. Pediatrics. 2006;118:e561-e569. | | | | | | | | | | | | | | | | | | Incl
Douglas RM, Miles HB. Vaccination against Streptococcus pneumoniae in childhood: lack of demonstrable benefit in young Australian children. Journal Infectious Disease 1984;149(6):861-9. | | | | | | | | | | | | | Incl
Douglas RM, Hansman D, McDonald B, Paton J, Kirke K. Pneumococcal vaccine in aboriginal children - a randomized controlled trial involving 60 children. Community Health Study 1986;10(2):189-96. | | | | | | | | | | | | | Incl
Dowell J, Pitkethy M, Bain J, Martin S. A randomised controlled trial of delayed antibiotic prescribing as a strategy for managing uncomplicated respiratory tract infection in primary care. British Journal of General Practice 2001;51:200–5. | | | | | | | Ref
Dowell SF, Butler JC, Giebink GS, Acute otitis media: management and surveillance in an era of pneumococcal resistancea report from the Drug-Resistant Streptococcus pneumoniae Therapeutic Working Group. Pediatr Infect Dis J 1999; 18:1-9 | | | | | | | Incl
EASTERBROOK PJ PUBLICATION BIAS IN CLINICAL RESEARCH LANCET 337 : 867 1991 | | | | | Ref
Egger M, Smith GD, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ 1997;315:629-34. | | | | Ref
El-Daher N, Rawashedeh N, Al-Khalil I, Abu-ektaish F. Immediate versus delayed treatment of Group A beta-haemolytic streptococcal pharyngitis with penicillin V. Pediatric Infectious Disease Journal1991;10(2):126–30.
El-Sayed Y. Treatment of recurrent acute otitis media chemoprophylaxis versus ventiliation tube. Australian Journal of Otolaryngology 1996;2(4):352-5. | | | | | | | | | | | | Incl
Engelhard D, Cohen D, Strauss N, Randomised study of myringotomy, amoxicillin/clavulanate, or both for acute otitis media in infants. Lancet 1989; 2:141-143 | Incl | | excl | | Ref | | Incl
Eppes SC, Klein JD, Lewis LL. Ceftriaxone for acute otitis media. Pediatrics 1997;100:157. | | | | Ref
Eskola J, Kilpi T, Palmu A, Jokinen J, Haapakoski J, Herva E, et al. Efficacy of a Pneumococcal Conjugate Vaccine against Acute Otitis Media. New England Journal of Medicine 8-2-2001;344(6):403-9. | | | | | | | | | | | | | Incl
Everitt H, Little P, Smith P. A randomised controlled trial of managementstrategies for acute infective conjunctivitis in general practice.British Medical Journal 2006;333(7563):321. | | | | | | excl
FADEN H NASOPHARYNGEAL FLORA IN THE 1ST 3 YEARS OF LIFE IN NORMAL AND OTITIS-PRONE CHILDREN ANNALS OF OTOLOGY RHINOLOGY AND LARYNGOLOGY 100 : 612 1991 | | | | | Ref
Faden H, Bernstein J, Brodsky L, et al. Effect of prior antibiotic treatment on middle ear disease in children. Ann Otol Rhinol Laryngol 1992;101:87-91. | | | | Ref | Ref
Fahey T, Smucny J, Becker L, Glazier R. Antibiotics for acute bronchitis.CochraneDatabase of Systematic Reviews 2004, Issue 1.Art.No.:CD000245. DOI:10.1002/14651858.CD000245.pub2. | | | | | | | Ref
Fay DL, Schellhase KG, Wujek D. Naturopathic ear drops minimally effective for acute otitis media. The Journal of Family Practice 2003;52(9):673, 676. | | excl
FAYELUND H ACUTE AND LATENT MASTOIDITIS JOURNAL OF LARYNGOLOGY AND OTOLOGY 103 : 1158 1989 | | | | | Ref
FEDER HM COMPARATIVE TOLERABILITY OF AMPICILLIN, AMOXICILLIN, AND TRIMETHOPRIM-SULFAMETHOXAZOLE SUSPENSIONS IN CHILDREN WITH OTITIS-MEDIA ANTIMICROBIAL AGENTS AND CHEMOTHERAPY 21 : 426 1982 | | | | | excl
Feigin RD, Keeney RE, Nusrala J, Shackelford PG, Lins RD Efficacy of clindamycin therapy for otitis media. Arch Otolaryngol 1973; 98:27-31 | | | | | | | Ref | | Ref
FELDMAN S SIMILAR HEMATOLOGIC CHANGES IN CHILDREN RECEIVING TRIMETHOPRIM-SULFAMETHOXAZOLE OR AMOXICILLIN FOR OTITIS-MEDIA JOURNAL OF PEDIATRICS 106 : 995 1985 | | | | | excl
FELDMAN W TRIMETHOPRIM-SULFAMETHOXAZOLE V AMOXICILLIN IN THE TREATMENT OF ACUTE OTITIS-MEDIA CANADIAN MEDICAL ASSOCIATION JOURNAL 139 : 961 1988 | | | | | Incl
Feldman W, Sutcliffe T, Dulberg C Twice-daily antibiotics in the treatment of acute otitis media: trimethoprim-sulfamethoxazole versus amoxicillin-clavulanate [see comments]. Can Med Assoc J 1990; 142:115-118 | | | | | Incl | | | | Ref
Fireman B, Black SB, Shinefield HR, Lee J, Lewis E, Ray P. Impact of the pneumococcal conjugate vaccine on otitis media. Pediatric Infectious Disease Journal 2003;22:10-6. | | | | | | | | | | | | | Incl
Fort G. Analgesia in otorhinolaryngological diseases: Lysine clonixinate versus ibuprofen [Analgesia en afecciones otorrinolaringologicas Clonixinato de Lisina vs. Ibuprofeno]. Prensa Medica Argentina 2000;87(4):409-418. | | excl
Foshee WS Loracarbef (LY163892) versus amoxicillin-clavulanate in the treatment of bacterial acute otitis media with effusion. J Pediatr 1992; 120:980-986
Francois M. [Efficacy and tolerance of a local application of phenazone and chlorhydrate lidocaine (Otipax) in infants and children with congestive otitis]. Annales de Pediatrie 1993;40(7):481-4. | | excl
Francois M. [Treatment of acute otitis media]. Archives de Pediatrie 1995;2(1):86-8. | | excl
FRENKEL M ACUTE OTITIS-MEDIA - DOES THERAPY ALTER ITS COURSE POSTGRADUATE MEDICINE 82 : 84 1987 | | | | | Ref
Froom J, Culpepper L, Grob P, Diagnosis and antibiotic treatment of acute otitis media: report from International Primary Care Network. BMJ. 1990; 300:582-586 | Ref | | Ref | Ref | Ref | | | | Ref
Froom J, Culpepper L, Jacobs M. Antimicrobials for acute otitis media? A review from the International Primary Care Network. The British Medical Journal 1997;315:98-102. | | Ref | | | | | | Incl
FRY J ANTIBIOTICS IN ACUTE TONSILLITIS AND ACUTE OTITIS MEDIA BRITISH MEDICAL JOURNAL 2 : 883 1958 | | | | | Ref
Gaskins JD, Holt J, Kyong CU, Weart CW, Ward J. Chemoprophylaxis of recurrent otitis media using trimethoprim/sulfamethoxazole. Drug Intell Clin Pharm 1982; 16:387-390. | | | | | | | | | | Incl | Incl | | | Incl
Gates GA. Cost-effectiveness considerations in otitis media treatment. In: Lim D, Bluestone CD, Casselbrant M, Klein J, Ogra P, eds. Proceedings of the Sixth International Symposium: Recent Advances in Otitis Media; June 4-8, 1995; Fort Lauderdale, FL. Hamilton, Ontario: BC Decker Inc; 1996:1-4
Gebhart DE. Tympanostomy tubes in the otitis media prone child. Laryngoscope 1981;91(6):849-66. | | | | | | | | | | | | incl
Gehanno P, Taillebe M, Denis P, Jacquet P, Hoareau J, Gojon D, et al. Short-course cefotaxime compared with five-day co-amoxyclav in acute otitis media in children. J Antimicrob Chemother 1990;26 Suppl A:29-36. | | | | excl
Gendeh S: A comparative study of ofloxacin otic drops vs. framycetin sulfate-dexamethasone-gramicidin otic drops in the medical treatment of otitis externa and chronic suppurative otitis media. Department of ORL, Hospital University Kabangsaan Malaysia, Kuala Lumpur, Malaysia. Unpublished, 2000. | | | | | | | | | | | | | | | | Incl
Gerber M, Randolph M, DeMeo K, Kaplan E. Lack of impact of early antibiotic therapy for streptococcal pharyngitis on recurrence rates. The Journal of Pediatrics 1990;December:853–8.
GIEBINK GS Otitis media update: pathogenesis and treatment. ANN OTOL RHINOL LA S 155 : 21 1992 | | | | | Ref
GIEBINK GS ANTIMICROBIAL TREATMENT OF ACUTE OTITIS-MEDIA JOURNAL OF PEDIATRICS 119 : 495 1991 | | | | | Ref
Giebink GS, Batalden PB, Russ JN, Le CT. Cefaclor v amoxicillin in treatment of acute otitis media Am J Dis Child 1984; 138:287-292 | | | | | Incl | | Incl | | Ref
Glasziou PP, Del Mar CB, Sanders SL, Hayem M. Antibiotics for acute otitis media in children. The Cochrane Database of Systematic Reviews 2003, Issue 4.Art. No.: CD000219. DOI: 10.1002/14651858.CD000219.pub2. | | Ref | Ref
Goldblatt E, Dohar J, Nozza R, Nielsen RW, Goldberg T, Sidman JM, Seidlin M: Topical versus systemic amoxicillin/clavulanate in purulent otorrhea in children with tympanostomy tubes. Int J Pediatr Otorhinolaryngol 1998;46:91-101. | | | | | | | | | | | | | | | | Incl
Gonzalez C, Arnold JE, Woody EA, Erhardt JB, Pratt SR, Getts A, Kueser TJ, Kolmer JW. Prevention of recurrent acute otitis media: chemoprophylaxis versus tympanostomy tubes. Laryngoscope 1986; 96:1330-1334. | | | | | | | | | | Incl | Incl | | | Incl
Gooch WM III, Blair E, Puopolo A, Effectiveness of five days of therapy with cefuroxime axetil suspension for treatment of acute otitis media. Pediatr Infect Dis J 1996; 15:157-164 | | | | Incl | | | Ref | Incl | Ref
Gray B. Controlled trial of sulfamethoxazole-trimethoprim for the prevention of recurrent acute otitis media in young children. Current Chemotherapy & Immunotherapy. Proceedings of the 12th International Congress of Chemotherapy. Florence, Italy, 1981 | | | | | | | | | | | Incl
Green SM, Rothrock SG. Single-dose intramuscular ceftriaxone for acute otitis media in children. Pediatrics 1993;91:23-30. | | | | Incl | | | | | Ref
Greenland S, Finkle WD. A critical look at methods for handling missing covariates in epidemiologic regression analyses. Am J Epidemiol 1995; 142: 1255–64.
Gregoire G, Derderian F, Le Lorier J. Selecting the language of the publications included in a meta-analysis:is there a tower of babel bias? J Clin Epidemiol 1995;48:159-63. | | | | Ref
Guillemot D, Carbon C, Balkau B, Geslin P, Lecoeur H, Vauzelle-Kervroedan F, et al. Low dosage and long treatment duration of B-lactam: Risk factors for carriage of penicillin-resistant Streptococcus pneumoniae. JAMA 1997;279:365-70. | | | | Ref
Halsted C, Lepow ML, Balassanian N, Emmerich J, Wolinsky E Otitis media: microbiology and evaluation of therapy. Ann N Y Acad Sci 1967; 145:372-378 | | | | | | | | | Ref
Halsted C, Lepow ML, Balassanian N, Emmerich J, Wolinsky E.Otitis media: clinical observation, microbiology and evaluation of therapy. Am J Dis Child 1968; 115: 542–51. | Incl | | Incl | | Incl | | | Incl | Ref
Harrison CJ, Chartrand SA, Pichichero ME. Microbiologic and clinical aspects of a trial of once daily cefixime compared with twice daily cefaclor for treatment of acute otitis media in infants and children. Pediatr Infect Dis J 1993;12:62-9. | | | | excl
Harrison CJ, Marks MI, Welch DF. Microbiology of recently treated acute otitis media compared with previously untreated acute otitis media. Pediatr Infect Dis 1985;4:641-6. | | | | Ref | Ref
HATHAWAY TJ ACUTE OTITIS-MEDIA - WHO NEEDS POSTTREATMENT FOLLOW-UP PEDIATRICS 94 : 143 1994 | Ref
Heikkinen T, Ruuskanen O. Signs and symptoms predicting acute otitis media. Arch Pediatr Adolesc Med. 1995;149:26-29. | | | | | | | | | | | | | | | Incl
Helmi A, Ratna D, Zainul A, Sosialisman E, Alfian FH, Bambang H: The efficacy and safety of ofloxacin otic solution for active suppurative otitis media. Faculty of Medicine, University of Indonesia, Jakarta, Indonesia. Unpublished, 2000. | | | | | | | | | | | | | | | | Incl
Hendrickse WA, Kusmiesz H, Shelton S, Nelson JD Five vs. ten days of therapy for acute otitis media. Pediatr Infect Dis J 1988; 7:14-23 | | | | Incl | | excl | | Incl | Ref
Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ 2003; 327: 557–60.
Hoberman A, Paradise JL, Burch DJ, Equivalent efficacy and reduced occurrence of diarrhea from a new formulation of amoxicillin/clavulanate potassium (Augmentin) for treatment of acute otitis media in children. Pediatr Infect Dis J 1997; 16:463-470 | | | | Incl | | | | Incl | Ref | | | | | | | | Incl
Hoberman A, Paradise JL, Reynolds EA, Urkin J. Efficacy of Auralgan for treating ear pain in children with acute otitis media. Archives of Pediatrics & Adolescent Medicine 1997;151(7):675-8. | | Incl
HOWARD JE OTITIS MEDIA OF INFANCY AND EARLY-CHILDHOOD - DOUBLE-BLIND-STUDY OF 4 TREATMENT REGIMENS AMERICAN JOURNAL OF DISEASES OF CHILDREN 130 : 965 1976 | | | | | excl
HOWIE VM The "otitis-prone" condition.AM J DIS CHILD 129 : 676 1975 | Ref
HOWIE VM BACTERIOLOGICAL AND CLINICAL EFFICACY OF CEFIXIME COMPARED WITH AMOXICILLIN IN ACUTE OTITIS-MEDIA PEDIATRIC INFECTIOUS DISEASE JOURNAL 6 : 989 1987 | | | | | excl
HOWIE VM EFFICACY OF FIXED COMBINATION ANTIBIOTICS VERSUS SEPARATE COMPONENTS IN OTITIS MEDIA - EFFECTIVENESS OF ERYTHROMYCIN ESTOLATE, TRIPLE SULFONAMIDE, AMPICILLIN, ERYTHROMYCIN ESTOLATE-TRIPLE SULFONAMIDE, AND PLACEBO IN 280 PATIENTS WITH ACUTE OTITIS MEDIA UNDER 2 1/2 YEARS OF AGE CLINICAL PEDIATRICS 11 : 205 1972 | Incl | | Incl | | excl | excl | | Incl | Ref
Howie VM, Dillard R, Lawrence B In vivo sensitivity test in otitis media: efficacy of antibiotics. Pediatrics 1985; 75:8-13 | | | | | | | | | Ref
Howie VM, Ploussard JH. The "In Vitro Sensitivity Test'-Bacteriology of middle ear exudate. Pediatrics 1969;44:940-4. | | | | Ref
Huwiler-Muntener K, Juni P, Junker C, EggerM. Quality of reporting of randomized trials as a measure of methodologic quality. JAMA 2002;287(21):2801–4.
IINO Y PROGNOSTIC FACTORS FOR PERSISTENT MIDDLE-EAR EFFUSION AFTER ACUTE OTITIS-MEDIA IN CHILDREN ACTA OTO-LARYNGOLOGICA 113 : 761 1993 | Ref
Ingvarsson L. Acute otalgia in children—findings and diagnosis. Acta Paediatr Scand. 1982;71:705-710. | | | | | | | | | | | | | | | Incl
Ingvarsson L, Lundgren K Penicillin treatment of acute otitis media in children. A study of the duration of treatment. Acta Otolaryngol 1982; 94:283-287 | | | | Incl | | | Ref | Incl | Ref
Jacobson JA, Metcalf TJ, Parkin JL, Wenerstrom LG. Evaluation of cefaclor and amoxycillin in the treatment of acute otitis media. Postgrad Med J 1979;55(Suppl 4):39-41. | | | | excl | Incl | | | | Ref
JACOBY GA MECHANISMS OF DISEASE - NEW MECHANISMS OF BACTERIAL-RESISTANCE TO ANTIMICROBIAL AGENTS NEW ENGLAND JOURNAL OF MEDICINE 324 : 601 1991 | | | | | Ref
Jadad AR, Moore R, Carroll D, Jenkinson C, Reynolds DJM, Gavaghan DJ, et al. Assessing the quality of reports of randomized clinical trials:is blinding necessary? Control Clin Trials 1996;17:1-12. | | | | Ref
JENNER PN A GENERAL-PRACTICE STUDY OF A NEW APPROACH TO THE USE OF ANTIBIOTICS IN THE TREATMENT OF ACUTE OTITIS-MEDIA IN CHILDREN AGED 3 AND OVER BRITISH JOURNAL OF CLINICAL PRACTICE 41 : 820 1987 | | | | excl | Incl
JOHN WRB TREATMENT OF OTITIS-MEDIA IN CHILDREN - A COMPARISON BETWEEN CEFACLOR AND AMOXYCILLIN PRACTITIONER 227 : 1805 1983 | | | | | Incl
JOHNSON CE CEFIXIME COMPARED WITH AMOXICILLIN FOR TREATMENT OF ACUTE OTITIS-MEDIA JOURNAL OF PEDIATRICS 119 : 117 1991 | | | | excl | Incl | | | | Ref
JONES R 3-DAY AND 7-DAY TREATMENT IN ACUTE OTITIS-MEDIA - A DOUBLE-BLIND ANTIBIOTIC TRIALJOURNAL OF THE ROYAL COLLEGE OF GENERAL PRACTITIONERS 36 : 356 1986 | | | | Incl | Ref | | | Incl | Ref
Juni P,Witschi A, Bloch R, EggerM. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA 1999;282(11):1054–9.
Kafetzis DA Multi-investigator evaluation of the efficacy and safety of cefprozil, amoxicillin-clavulanate, cefixime and cefaclor in the treatment of acute otitis media. Eur J Clin Microbiol Infect Dis 1994; 13:857-865 | | | | | | | Ref | Incl
Kafetzis DA, Astra H, Mitropoulos L. Five-day versus ten-day treatment of acute otitis media with cefprozil. Eur J Clin Microbiol Infect Dis 1997;16:283-6. | | | | Incl | | | | | Ref
KALEIDA PH AMOXICILLIN OR MYRINGOTOMY OR BOTH FOR ACUTE OTITIS-MEDIA - RESULTS OF A RANDOMIZED CLINICAL-TRIAL PEDIATRICS 87 : 466 1991 | Incl | | Incl | Ref | Ref | Ref | | Incl | Ref
KALEIDA PH AMOXICILLIN-CLAVULANATE POTASSIUM COMPARED WITH CEFACLOR FOR ACUTE OTITIS-MEDIA IN INFANTS AND CHILDREN PEDIATRIC INFECTIOUS DISEASE JOURNAL 6 : 265 1987 | | | | | Incl
Kaprio E, Haapaniemi J, Bondesson G. Clinical efficacy of amoxycillin/clavulanic acid and cefaclor in acute otitis media. Acta Otolaryngol Suppl. 1988;449:45-6 | | | | | Incl
Kara CO, Ozuer MZ, Kilic I, Yalcin AN, Ergin H Comparison of amoxicillin with second and third generation cephalosporins in the treatment of acute otitis media. Infez Med 1998; 6:93-95 | | | | | | | | | Ref
Karma P, Luotonen J, Timonen M, Pontynen S, Pukander J, Herva E. Efficacy of pneumococcal vaccination against recurrent otitis media. Preliminary results of a field trial in Finland. Annals Otology Rhinology Laryngology Supplement 1980;89(3 Pt 2):357-62. | | | | | | | | | | | | | Incl
Karma PH, Penttila MA, Sipila MM, Kataja MJ. Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media, I: the value of different otoscopic findings. Int J Pediatr Otorhinolaryngol. 1989;17:37-49. | | | | | | | | | | | | | | | Incl
Karma P, Pukander J, Sipila M, Timonen M, Pontynen S. Herva E, et al. Prevention of otitis media in children by pneumococcal vaccination. American Journal of Otolaryngology 1985;6(3):173-84. | | | | | | | | | | | | | Incl
KENNA MA CEFIXIME VS CEFACLOR IN THE TREATMENT OF ACUTE OTITIS-MEDIA IN INFANTS AND CHILDREN PEDIATRIC INFECTIOUS DISEASE JOURNAL 6 : 992 1987 | | | | | Incl
Khurana CM. A multicenter, randomized, open label comparison of azithromycin and amoxicillin/clavulanate in acute otitis media among children attending day care or school. Pediatr Infect Dis J 1996;15 Suppl:S24-9. | | | | Incl | | | | Incl | Ref
KIM HKC COMPARISON OF BACAMPICILLIN AND AMOXICILLIN IN ACUTE OTITIS-MEDIA WITH EFFUSION BULLETIN OF THE NEW YORK ACADEMY OF MEDICINE 59 : 515 1983 | | | | | Incl
Klein JO, Teele DW, Rosner BA, et al. Epidemiology of acute otitis media in Boston children from birth to seven years of age. Recent Advances in Otitis Media with Effusion. Proceedings of the Fourth International Symposium. 1988:6-8. | | | | Ref
Klein JO. Epidemiology of otitis media. Pediatric Infectious Disease Journal 1989;8(Suppl 1):89. | | Ref | Ref
Klein JO. Protecting the therapeutic advantage of antimicrobial agents used for otitis media. Pediatr Infect Dis J. 1998;17:571-575, discussion 580
Klein JO. The burden of otitis media. Vaccine 2001;19(Suppl):2-8. | | Ref
KLIGMAN EW TREATMENT OF OTITIS-MEDIA .1. AMERICAN FAMILY PHYSICIAN 45 : 242 1992 | | | | | Ref
Koeppel FW. [Treatment of diseases of the ear canal and middle ear with Otobacid]. Munchener Medizinische Wochenschrift 1970;112(17):806-9. | | excl
Kontiokari T, Koivunen P, Niemela M, Pokka T, Uhari M. Symptoms of acute otitis media. Pediatr Infect Dis J. 1998;17:676-679. | | | | | | | | | | | | | | | Incl
Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SEA, Wincott JL, Sitar DS, Klassen TP, et al. Treatment of acute otitis media with a Shortened Course of Antibiotics. JAMA 1998;279:1736-42. | | | Ref
Kumar S, Little P, Britten N. Why do general practitioners prescribe antibiotics for sore throat?. British Medical Journal 2003;326:138–43. | | | | | | | Ref
Kurbasci M, Jones VF, Badgett JT, Thomas A. Two-week vs. six-week followup for acute otitis media [abstract]. Arch Pediatr Adolesc Med 1996;150:P19. | | | | Ref
Lacher G. [Clinical trial of Otipax: auricular pulverizations]. Revue de Laryngologie, D' Otologie et de Rhinologie 1969;90(11):719-22. | | excl
Landis B, Koch GG. The measurement of observer agreement for categorical data. Biometrics 1977;3:159-74. | | | | Ref
Laszlo I, Pupp L. Anaesthesia of tympanic membrane with lidocaine. Therapia Hungarica 1981;29(4):176-9. | | excl
LAUPACIS A AN ASSESSMENT OF CLINICALLY USEFUL MEASURES OF THE CONSEQUENCES OF TREATMENT NEW ENGLAND JOURNAL OF MEDICINE 318 : 1728 1988 | Ref | | | Ref | Ref
Laxdal OE, Merida J, Jones RH Treatment of acute otitis media: a controlled study of 142 children. Can Med Assoc J 1970; 102:263-268 | Incl | excl | Incl | | Incl | excl | | Incl | Ref
Le Saux N, Gaboury I, Baird M, et al. A randomized, double-blind,placebo-controlled noninferiority trial of amoxicillin for clinically diagnosed acute otitis media in children 6 months to 5 years of age. CMAJ 2005; 172: 335–41. | | | | | | Incl
Leigh AP, Robinson D, Millar ED A general practice comparative study of a new third-generation oral cephalosporin, cefixime, with amoxicillin in the treatment of acute paediatric otitis media. Br J Clin Pract 1989; 43:140-143 | | | | | Incl | | | | Ref
Lenoski EF, Wingert WA, Wehrle PF Drug trials in acute otitis media. Curr Ther Res Clin Exp 1968; 10:631-639 | | | | | Incl | | | | Ref
LIGHT RJ SUMMING UP SCI REV R : 3 1984 | | | | | Ref
LISBYSUTCH SM THERAPY OF OTITIS-MEDIA CLINICAL PHARMACY 9 : 15 1990 | | | | | Ref
LISTON TE THE BACTERIOLOGY OF RECURRENT OTITIS-MEDIA AND THE EFFECT OF SULFISOXAZOLE CHEMOPROPHYLAXIS PEDIATRIC INFECTIOUS DISEASE JOURNAL 3 : 20 1984 | | | | | Ref
Liston TE, Foshee WS, Pierson MWD Sulfisoxazole chemoprophylaxis for frequent otitis media. Pediatrics 1983; 71:524-530. | | | | | | | | | | Incl | Incl | | | incl
Little P, Gould C, Williamson I, Moore M, Warner G, Dunleavey J.Pragmatic randomised controlled trial of two prescribing strategies for childhood acute otitis media. BMJ 2001; 322:336–42. | | | excl | | | Incl | Incl
Little P, Moore M, Warner G, Dunleavy J, Williamson I. Longer term outcomes from a randomised trial of prescribing strategies in otitis media. British Journal of General Practice 2006;56(524):176– 82. [MEDLINE: 16536953]. | | | | | | | Ref
Little P, Rumsby K, Kelly J, Watson L, Moore M, Warner G, et al.Information leaflet and antibiotic prescribing strategies for acute lower respiratory infection. Journal of the American Medical Association 2005;293:3029–35. | | | | | | | Incl
Little P, Williamson I, Warner G, Gould C, Gantley M, Kinmonth AL. Open randomised trial of prescribing strategies inmanaging sore throat. British Medical Journal 1997;314(7082):722–7. | | | | | | | Incl
Little P. Delayed prescribing of antibiotics for upper respiratory tract infection. British Medical Journal 2005;331:301–2. | | | | | | | Ref
LOFTIN LH Current treatment of otitis media in children. ALA MED 60 : 24 1991 | | | | | Ref
LORENTZEN P TREATMENT OF ACUTE SUPPURATIVE OTITIS-MEDIA JOURNAL OF LARYNGOLOGY AND OTOLOGY 91 : 331 1977 | Ref
Macfarlane J, Holmes W, Macfarlane R, Britten N. Influence of patient’s expectations on antibiotic management of acute lower respiratory tract illness in general practice: questionnaire study. British Medical Journal 1997;315:1211–4. | | | | | | | Ref
MacLoughlin GJF, Barreto DG, de la Torre C, Pinetta EA, del Castilllo F, Palma L. Cefpodoxime proxetil suspension compared with cefaclor suspension for treatment of acute otitis media in paediatric patients. J Antimicrobial Chemotherapy 1996;37:565-73. | | | | excl
MacPhail E. Acute otitis media. Canadian Pharmaceutical Journal 1996;129(1):29-31. | | excl
Makela PH, Leinonen M, Pukander J, Karma P. A study of the pneumococcal vaccine in prevention of clinically acute atttacks of recurrent otitis media. Review Infectious Disease 1981;3 Suppl:124-32. | | | | | | | | | | | | | Incl
Makela PH, Sibakov M, Herva E, Henrichsen J, Luotonen J, Timonen M, et al. Pneumococcal vaccine and otitis media. Lancet 1980;2(8194):547-51. | | | | | | | | | | | | | Incl
MANDEL EM DURATION OF EFFUSION AFTER ANTIBIOTIC-TREATMENT FOR ACUTE OTITIS-MEDIA - COMPARISON OF CEFACLOR AND AMOXICILLIN PEDIATRIC INFECTIOUS DISEASE JOURNAL 1 : 310 1982 | | | | | Incl
MANDEL EM EFFICACY OF 20- VERSUS 10-DAY ANTIMICROBIAL TREATMENT FOR ACUTE OTITIS-MEDIA PEDIATRICS 96 : 5 1995 | Ref | | | excl
Mandel EM, Casselbrant ML, Rockette HE, Bluestone CD, Kurs-Lasky M. Efficacy of antimicrobial prophylaxis for recurrent middle ear effusion. Pediatric Infectious Diseases Journal 1996:15(12):1074-82. | | | | | | | | | | | Incl
Mangione-Smith R,McGlynn E, ElliotM. The relationship between perceived parental expectations and pediatrician antimicrobial prescribing behaviour. Pediatrics 1999;103:711–8. | | | | | | | Ref
MARCHANT CD A RANDOMIZED CONTROLLED TRIAL OF AMOXICILLIN PLUS CLAVULANATE COMPARED WITH CEFACLOR FOR TREATMENT OF ACUTE OTITIS-MEDIA JOURNAL OF PEDIATRICS 109 : 891 1986 | | | | | Incl
MARCHANT CD A RANDOMIZED CONTROLLED TRIAL OF CEFACLOR COMPARED WITH TRIMETHOPRIM-SULFAMETHOXAZOLE FOR TREATMENT OF ACUTE OTITIS-MEDIA JOURNAL OF PEDIATRICS 105 : 633 1984 | | | | | excl
MARCHANT CD ANTIBACTERIAL THERAPY FOR ACUTE OTITIS-MEDIA - A CRITICAL ANALYSIS REVIEWS OF INFECTIOUS DISEASES 4 : 506 1982 | | | | | Ref
MARCHANT CD MEASURING THE COMPARATIVE EFFICACY OF ANTIBACTERIAL AGENTS FOR ACUTE OTITIS-MEDIA - THE POLLYANNA PHENOMENON JOURNAL OF PEDIATRICS 120 : 72 1992 | | | | | Ref
MARCHANT CD RECENT ADV OTITIS ME : 281 1984 | | | | | excl
Marcy M, Takata G, Shekelle P, et al. Management of Acute Otitis Media. Evidence Report/Technology Assessment No. 15. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-97-0001). 2001 AHRQ Publication No. 01-E010. R | | Ref
Mathews JR, McGrath PJ, Pigeon H. Assessment and measurement of pain in children. Pain in Infants, Children, and Adolescents. Williams and Wilkins, 1993. | | Ref
Matz PS, Batista D, Vivier P, Alario AJ. Can a topical otic anesthetic reduce the need for antibiotics in acute otitis media? Pediatric Research 2001;49:131A. | | excl
Matz PS, Webster RA, Vivier P, Alario A. Use of a Topical Otic Analgesic as a Treatment Strategy for Acute Otitis Media. Unpublished manuscript presented at the Pediatric Academic Society Meeting; 2001; Baltimore:Pediatric Academic Society Meeting; 2001; | | excl
Maynard JE, Fleshman JK, Tschopp CF. Otitis media in Alaskan Eskimo children. Prospective evaluation of chemoprophylaxis. JAMA 1972;219(5)597-9. | | | | | | | | | | | Incl | | | Incl
McAuley L, Pham B, Tugwell P, Moher D Does the inclusion of grey literature influence the estimates of intervention effectiveness reported in meta-analyses? Lancet. 2000; 356:1228-1231
McCaig LF, Hughes JM. Trends in antimicrobial drug prescribing among office-based physicians. JAMA 1995;273:214-9. | | | | Ref
McConaghy JR. The evaluation and treatment of children with acute otitis media. The Journal of Family Practice 2001;50(5):457-9, 463-5. | | excl
McCormick DP, Chonmaitree T, Pittman C, et al. Nonsevere acute otitis media: a clinical trial comparing outcomes of watchful waiting versus immediate antibiotic treatment. Pediatrics 2005;115: 1455–65. | | | | | | Incl
MCCRACKEN GH SELECTION OF ANTIMICROBIAL AGENTS FOR TREATMENT OF ACUTE OTITIS-MEDIA WITH EFFUSION PEDIATRIC INFECTIOUS DISEASE JOURNAL 6 : 985 1987 | | | | | Ref
McCracken GH Treatment of acute otitis media in an era of increasing microbial resistance. Pediatr Infect Dis J 1998; 17:576-579
McLinn S A multicenter, double blind comparison of azithromycin and amoxicillin/clavulanate for the treatment of acute otitis media in children. Pediatr Infect Dis J 1996; 15:S20-S23 | | | | Incl | | | | Incl | Ref
MCLINN SE CEFACLOR IN TREATMENT OF OTITIS-MEDIA AND PHARYNGITIS IN CHILDREN AMERICAN JOURNAL OF DISEASES OF CHILDREN 134 : 560 1980 | | | | | excl | | | | Ref
MCLINN SE CURRENT CHEMOTHERAPY 1 : 123 1978 | | | | | excl
McLinn SE Randomized open label multicenter trial of cefixime compared with amoxicillin for treatment of acute otitis media with effusion. Pediatr Infect Dis 1987; 6:997-1001 | | | | | | | | | Ref
McLinn SE Recurrence of otitis media after antibiotic therapy: comparison of cephradine and amoxicillin. J Int Med Res 1979; 7:546-550 | | | | | | | | | Ref
Mehta C, Patel N. StatXact. Statistical software for exact nonparametric inference. Version 2.0. Cambridge, MA: Cytel Software Corporation, 1991. | | | | | Ref
Meistrup-Larsen KI, Mygind N, Thomsen J, Sorensen H, Vesterhauge S Penicillin therapy in acute otitis media. Report of a double-blind, placebo-controlled clinical trial. [Penicillin therapy of acute otitis media. A double-blind placebo-controlled study.] Ugeskr Laeger 1980; 142:2768-2772 | | | | | | | | Incl
Meistrup-Larsen KI, Sorensen H, Johnsen NJ, Thomsen J, Mygind N, Sederberg-Olsen J Two versus seven days penicillin treatment for acute otitis media. A placebo controlled trial in children. Acta Otolaryngol 1983; 96:99-104 | | | | Incl | | | | Incl | Ref
Menshikov NM. The use of lyase and desoxyribonuclease in acute otitis in children. Zhurnal Ushnykh, Nosovykh i Gorlovykh Boleznei 1968;28(2):77-9. | | excl
Millard J. [On the local treatment of infections of the ear canal and middle ear]. Deutsches Medizinisches Journal 1969;20(6):181-4. | | excl
Mills R, Uttley A, McIntyre M. Relationship between acute suppurative otitis media and chronic secretory otitis media:role of antibiotics. J R Soc Med 1984;77:754-7. | | | | Ref
Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials:an annotated bibliography of scales and checklists. Control Clin Trials 1995;16:62-73. | | | | Ref
Mohs E, Rodriguez-Solares A, Rivas E, Hoshy ZE. A comparative study of azithromycin and amoxycillin in paediatric patients with acute otitis media. J Antimicrob Chemother 1993;31 Suppl E:73-9. | | | | Incl
Murph JR, Dusdieker LB, Booth B, Murph WE. Is treatment of acute otitis media with once-a-day amoxicillin feasible? lin Pediatr 1993;32:528-34. | | | | excl | | | | | | | | | | | | | Incl
Murray BE. Can antibiotic resistance be controlled? Engl J Med 1994;330:1229-30. | | | | Ref
MYGIND N PENICILLIN IN ACUTE OTITIS-MEDIA - A DOUBLE-BLIND PLACEBO-CONTROLLED TRIALCLINICAL OTOLARYNGOLOGY 6 : 5 1981 | Incl | | Incl | Ref | Incl | Ref | | Incl | Ref
NADAL D ACUTE MASTOIDITIS - CLINICAL, MICROBIOLOGICAL, AND THERAPEUTIC ASPECTS EUROPEAN JOURNAL OF PEDIATRICS 149 : 560 1990 | | | | | Ref
Nasrin D, Collignon PJ, Roberts L, Wilson EJ, Pilotto LS, Douglas RM. Effect of beta lactam antibiotic use in children on pneumococcal resistance to penicillin: prospective cohort study. The British Medical Journal 2002;324(7328):324-8. | | Ref
Nassar WY, Allen BM A double-blind comparative clinical trial of cephalexin and ampicillin in the treatment of childhood acute otitis media. Curr Med Res Opin 1974; 2:198-203 | | | | | | | | | Ref
NATIONAL DISEASE THE : 1992 | | | | | Ref
Niemela M, Uhari M, Mottonen M, Pokka T. Costs arising from otitis media. Acta Paediatrica 1999;88(5):553–6. | | | | | | | Ref
Niemela M, Uhari M, Jounio-Ervasti K, Luotonen J, Alho OP, Vierimaa E. Lack of specific symptomatology in children with acute otitis media. Pediatr Infect Dis J. 1994;13:765-768. | | | | | | | | | | | | | | | Incl
NILSON BW ACUTE OTITIS MEDIA - TREATMENT RESULTS IN RELATION TO BACTERIAL ETIOLOGY PEDIATRICS 43 : 351 1969 | | | | | Incl | | | | Ref
ODIO CM COMPARATIVE TREATMENT TRIAL OF AUGMENTIN VERSUS CEFACLOR FOR ACUTE OTITIS-MEDIA WITH EFFUSION PEDIATRICS 75 : 819 1985 | | | | | Incl
O'Doherty B. An open comparative study of azithromycin versus cefaclor in the treatment of patients with upper respiratory tract infections. J Antimicrobial Chemotherapy 1996;37 Suppl C:71-81. | | | | excl
Ostfeld E, Segal J, Kaufstein M, Gelernter I. Management of acute otitis media without primary administration of systemic antimicrobial agents. In: Lim DJ, Bluestone CD, Klein JO,Nelson JD, eds. Recent advances in otitis media. Proceedings of the Fourth International Symposium. Toronto: BC Decker, 1987: 235–39. | | | excl | | Ref | excl | | Incl | Ref
Owen MJ, Anwar R, Nguyen HK, Swank PR, Bannister ER, Howie VM Efficacy of cefixime in the treatment of acute otitis media in children. Am J Dis Child 1993; 147:81-86 | | | | | | | | | Ref
Oxman A. Preparing and maintaining systematic reviews. Cochrane Reviewers' Handbook. Oxford: Update Software, 1995. | | | | Ref
Palmu AA, Herva E, Savolainen H, Karma P, Makela PH, Kilpi TM.Association of Clinical Signs and Symptoms with Bacterial Findings in Acute Otitis Media. Clin Infect Dis 2004; 38: 234–42. | | | | | | Ref
Paradise JL. Managing otitis media:a time for change. Pediatrics 1995;96:712-5. | | | | Ref
Paradise JL. Short-course antimicrobial treatment for acute otitis media. Not best for infants and young children. JAMA 1997;278:1640-42. | | | | Ref
Perrin JM, Charney E., MacWhinney JB, McInerny TK Miller RL, Nazarian LF. Sulfisoxazole as chemoprophylaxis for recurrent otitis media: A double-blind crossover study in pediatric practice. N Engl J Med 1974; 291:664-667. | | | | | | | | | | Incl | Incl | | | Incl
Persico M, Podoshin L, Fradis M, Grushka M, Golan D, Foltin V, Wellisch G, Chahaza Z, Kolin A, Winter S. Recurrent acute otitis media - prophylactic penicillin treatment: a prospective study - Part I. Int J Pediatr Otorhinolaryngol 1985;10: 37-46. | | | | | | | | | | Incl | Incl
Pestalozza G, Cioce C, Facchini M Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scand J Infect Dis Suppl 1992; 83:22-25 | | | | Incl | | | | Incl | Ref
PICHICHERO M COMPARISON OF CEFUROXIME AXETIL, CEFACLOR, AND AMOXICILLIN-CLAVULANATE POTASSIUM SUSPENSIONS IN ACUTE OTITIS-MEDIA IN INFANTS AND CHILDREN SOUTHERN MEDICAL JOURNAL 83 : 1174 1990 | | | | | Incl
Pichichero ME, Cohen R. Shortened course of antibiotic therapy for acute otitis media, sinusitis and tonsillopharyngitis. Pediatr Infect Dis J 1997;16:680-95. | | | | Ref
PichicheroM,Disney F, TalpeyW,Green J, Francis A, Roghmann K,et al.Adverse and beneficial effects of immediate treatment of Group A beta-haemolytic streptococcal pharyngitis with penicillin. PediatricInfectious Disease Journal 1987;6:635–43. | | | | | | | Incl
PIIPPO T DOUBLE-BLIND COMPARISON OF CEFIXIME AND CEFACLOR IN THE TREATMENT OF ACUTE OTITIS-MEDIA IN CHILDREN SCANDINAVIAN JOURNAL OF INFECTIOUS DISEASES 23 : 459 1991 | | | | | Incl
Pirozzo S, Del Mar C. Otitis media. In: Evidence-based Pediatrics and Child Health. 2nd Edition. BMJ Books, 2004. | | Ref
PLOUSSARD JH EVALUATION OF 5 DAYS OF CEFACLOR VS 10 DAYS OF AMOXICILLIN THERAPY IN ACUTE OTITIS-MEDIA CURRENT THERAPEUTIC RESEARCH-CLINICAL AND EXPERIMENTAL 36 : 641 1984 | | | | Incl | excl | | | Incl | Ref
Polyakova TS, Voznesensky NL, Mironov AA, Al Sakir M. Otinum in the therapy of middle ear diseases. Vestnik-Oto-Rino-Laringologii 1991;53(2):56-58. | | excl
POOLE JM Cefprozil vs. Cefixime and Cefaclor in Otitis Media in Children. INFECTIONS MED SE 9 : 21 1992 | | | | | Incl
PRELLNER K Is beta-lactamase-producing bacteria of major importance for unfavourable development of acute otitis media? ACTA OTOLARYNGOL STO 493 : 109 1992 | | | | | Ref
Principi N Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media. Eur J Clin Microbiol Infect Dis. 1995; 14:669-676 | | | | Incl | | | | Incl | Ref
Principi N, Marchisio P Cefixime vs amoxicillin in the treatment of acute otitis media in infants and children. Drugs 1991; 42:25-29 | | | | | Incl | | | | Ref
Principi N, Marchisio P, Massironi E, Grasso RM, Filiberti G. Prophylaxis of recurrent acute otitis media and middle-ear effusion. Comparison of amoxicillin with sulfamethoxazole and trimethoprim. Am J Dis Child 1989; 143:1414-1418. | | | | | | | | | | Incl | Incl | | | Incl
Principi N, Marchisio P, Bigalli L, Massironi E Amoxicillin twice daily in the treatment of acute otitis media in infants and children. Eur J Pediatr 1986; 145:522-525 | | | | | Ref | | | Incl | Ref | | | | | | | | Incl
Puczynski MS, Stankiewicz JA, O'Keefe JP Single dose amoxicillin treatment of acute otitis media. Laryngoscope 1987;97:16-18 | | | | Incl | | | | | Ref
PUHAKKA H, VIROLAINEN E, AANTAA E. TREATMENT OF ACUTE OTITIS-MEDIA IN CHILDREN - PENICILLIN-V OR AMOXICILLIN? ACTA OTO-LARYNGOLOGICA 1982; Suppl. 386:108-111 | | | | | excl
Pukander JS, Jero JP, Kaprio EA, Sorri MJ Clarithromycin vs. amoxicillin suspensions in the treatment of pediatric patients with acute otitis media. Pediatr Infect Dis J 1993; 12:S118-S121 | | | | | | | | | Ref
Reiss G, Reiss M. [Otorhinolaryngology--4: Pro and contra of ear drops]. Pflege Zeitschrift 2002;55(2):86-8. | | excl
Roark R, Berman S. Continuous twice daily or once daily amoxicillin prophylaxis compared with placebo for children with recurrent acute otitis media. Pediatric Infectious Disease Journal 1997;16(4)376-81. | | | | | | | | | | | Incl
ROBINS J A GENERAL ESTIMATOR FOR THE VARIANCE OF THE MANTEL-HAENSZEL ODDS RATIO AMERICAN JOURNAL OF EPIDEMIOLOGY 124 : 719 1986 | Ref
Rodriguez AF An open study to compare azithromycin with cefaclor in the treatment of children with acute otitis media. J Antimicrob Chemother 1996; 37:63-69 | | | | Incl | | | | Incl | Ref
Rodriguez WJ, Schwartz RH, Sait T, Erythromycin-sulfisoxazole vs amoxicillin in the treatment of acute otitis media in children. A double-blind, multiple-dose comparative study. Am J Dis Child 1985; 139:766-770 | | | | | | | | | Ref
Roland RS, Anon JB, Moe RD, et al. Topical ciprofloxacin/dexamethasone is superior to ciprofloxacin alone in pediatric patients with acute otitis media and otorrhea through tympanostomy tube. Laryngoscope. 2003;113:2116-2122. | | | | | | | | | | | | | | | | | | Incl
Roland RS, Kreisler LS, Reese B, et al. Topical ciprofloxacin/dexamethasone otic suspension is superior to ofloxacin otic solution in the treatment of children with acute otitis media with otorrhea through tympanostomy tube. Pediatrics. 2004;113:e40-e46. | | | | | | | | | | | | | | | | | | Incl
ROSEN C ACUTE OTITIS-MEDIA IN OLDER CHILDREN AND ADULTS TREATED WITH PHENOXYMETHYL PENICILLIN OR ERYTHROMYCIN STEARATE - BACTERIOLOGICAL AND IMMUNOLOGICAL ASPECTS ACTA OTO-LARYNGOLOGICA 96 : 247 1983 | | | | | excl
Rosen C, Christensen P, Henrichsen J, Hovelius B, Prellner K. Beneficial effect of pneumococcal vaccination on otitis media in children over two years old. International Journal Pediatric Otorhinolaryngology 1984;7(3):239-46. | | | | | | | | | | | | | Incl
Rosen C, Christensen P, Hovelius B, Prellner K. Effect of pneumococcal vaccination on upper respiratory tract infections in children. Design of a follow-up study. Scandinavian Journal Infectious Disease Supplement 1983;39:39-44. | | | | | | | | | | | | | Incl
Rosenfeld R. Personal communication 2005. | | Ref
ROSENFELD RM CLINICAL EFFICACY OF ANTIMICROBIAL DRUGS FOR ACUTE OTITIS-MEDIA - METAANALYSIS OF 5400 CHILDREN FROM 33 RANDOMIZED TRIALS JOURNAL OF PEDIATRICS 124 : 355 1994 | Ref | | Ref | Ref
Rosenfeld RM. An evidence-based approach to approach to treating otitis media. Ped Clin NA 1996;43:1165-81 | | | | Ref
Rosenfeld RM. Natural history of untreated otitis media. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. St Louis, MO: BC Decker Inc; 1999:157-177
Rosenfeld RM. Natural history of untreated otitis media. Laryngoscope 2003;113:1645-57. | | Ref
Rosenfeld RM. What to expect from medical therapy. In: Rosenfeld RM, Bluestone CD, eds. Evidence-Based Otitis Media. St Louis, MO: BC Decker Inc; 1999:179-205
Rothman R, Owens T, Simel D. Does this child have acute otitis media? JAMA 2003;290(12):1633-1640. | | | Ref
Rovers MM, Schilder AG, Zielhuis GA, Rosenfeld RM. Otitis media. Lancet 2004; 363: 465–73.
RUBENSTEIN MM TREATMENT OF ACUTE OTITIS MEDIA IN CHILDREN .3. A 3RD CLINICAL TRIAL AMERICAN JOURNAL OF DISEASES OF CHILDREN 109 : 308 1965 | | | | excl | excl | | | Incl | Ref
Rudberg RD. Acute otitis media: comparative therapeutic results of sulphonamide and penicillin administered in various forms. Acta Otolaryngology 1954; 113: 1–79 | | | excl | | Ref | excl
Ruohola A, Heikkinen T, Meurman O, Puhakka T, Lindblad N, Ruuskanen O. Antibiotic treatment of acute otorrhea through tympanostomy tube: Randomized double-blind placebo-controlled study with daily follow-up. Pediatrics 2003; 111: 1061–67. | | | excl | | | excl
Sano F, Sole D, Naspitz CK, Takara CK. Otitis media in children. Brasileira-de-Medicina 1995;52:113-122. | | excl
Sarrell EM, Cohen HA, Kahan E. Naturopathic treatment for ear pain in children. Pediatrics 2003a;111(5 Pt 1):574-9. | | Incl
Sarrell EM, Mandelberg A, Cohen HA. Efficacy of naturopathic extracts in the management of ear pain associated with acute otitis media. Archives of Pediatrics & Adolescent Medicine 2001;155(7):796-9. | | Incl
Schaad UB Multicentre evaluation of azithromycin in comparison with co-amoxiclav for the treatment of acute otitis media in children. J Antimicrob Chemother 1993; 31:81-88 | | | | Incl | | | | Incl | Ref
Schappert SM. Office Visits for Otitis Media: United States, 1975-90. Advance Data from Vital and Health Statistics. Hyattsville, MD: National Center for Health Statistics; 1992
Schecter NL. Management of common pain problems in the primary care pediatric setting. Pain in infants, children and adolescents. 2nd Edition. Lippincott Williams & Wilkins, 2003. | | Ref
Schentag JJ. Antibiotic treatment of acute otitis media in children:dosing considerations. Pediatr Infect Dis J 1995;14:S30-3. | | | | Ref
Scholz H, Noack R Multicenter, randomized, double-blind comparison of erythromycin estolate versus amoxicillin for the treatment of acute otitis media in children. AOM Study Group. Eur J Clin Microbiol Infect Dis 1998; 17:470-478 | | | | | | | | | Ref
Schuller DE. Prophylaxis of otitis media in asthmatic children. Pediatric Infectious Disease 1983;2(4):280-3. | | | | | | | | | | | Incl | | Incl | incl
Schulz KF, Chalmers I, Hayes R, Altman DG. Empirical evidence of bias:dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA 1995;273:408-12. [ | | | | Ref
SCHUTZMAN SA BACTEREMIA WITH OTITIS-MEDIA PEDIATRICS 87 : 48 1991 | | | | | Ref
SCHWARTZ RH AMOXICILLIN AS THE DRUG OF CHOICE FOR ACUTE OTITIS-MEDIA - ISNT IT TIME FOR ITS REASSESSMENT IN SOME AREAS OF THE COUNTRY PEDIATRIC INFECTIOUS DISEASE JOURNAL 8 : 806 1989 | | | | | Ref
Schwartz RH, Puglise J. Rodriguez WJ. Sulfamethoxazole prophylaxis in the otitis-prone child. Arch Dis Child 1982;57:590-593 | | | | | | | | | | Incl | Incl
Scott HV, Pannowitz D, Ketelbey JW. Cefixime:clinical trial against otitis media and tonsillitis. N Z Med J 1990;103:25-6. | | | | excl
Scottish Intercollegiate Guidelines Network. Guideline 66: Diagnosis and management of childhood otitis media in primary care: a national clinical guideline. http://www.sign.ac.uk/guidelines/fulltext/66/index.html (Accessed 16 August 2005) 2003. | | Ref
Sharland M, Kendall H, Yeates D, Randall A, Hughes G, Glasziou P, et al.Antibiotic prescribing in general practice and hospital admissions for peritonsillar abscess,mastoiditis and rheumatic fever in children:time trend analysis. British Medical Journal 2005;331:328–9. | | | | | | | Ref
Shikowitz MJ. Otitis media. Children's-Hospital-Quarterly 1989;1(4):289-299. | | excl
Sih T, Moura R, Caldas S, Schwartz B. Prophylaxis for recurrent acute otitis media: a Brazilian study. International Journal of Pediatric Otorhinolaryngology 1993;25(1-3):19-24. | | | | | | | | | | | Incl
Silverstein H, Call DL. Tetracaine base. An effective surface anesthetic for the tympanic membrane. Archives of Otolaryngology 1969;90(2):150-1. | | excl
Simon MW Five- vs 10-day treatment of acute otitis media with ceftibuten in infants and children. Adv Ther 1997; 14:312-317 | | | | | | | | Incl | Ref
Sloyer JL, Jr, Ploussard JH, Howie VM. Efficacy of pneumococcal polysaccharide vaccine in preventing acute otitis media in infants in Huntsville, Alabama. Review Infectious Disease 1981;3 Suppl:119-23. | | | | | | | | | | | | | Incl
Spencer RC, Hannington J, Fraser S, Mason T. Cefpodoxime proxetil versus co-amoxiclav in the treatment of acute infections of the ear, nose and throat in children-a multicentre randomized study (abstract 851). 18th International Congress of Chenotherapy:. | | | | excl
Spicer WJ, Christiansen K, Currie BJ, Dartnell JGA, Ferguson JK, Garland SM. Therapeutic Guidelines: Antibiotic. Version 12. North Melbourne: Therapeutic Guidelines Limited, 2003. | | Ref
Spiro DM, Tay KY, Arnold DH, Dziura JD, Baker MD, Shapiro ED. Wait-and-see prescription for the treatment of acute otitis media:a randomized controlled trial. Journal of the American Medical Association 2006;296(10):1235–41. | | | | | | | Incl
Stechenberg BW, Anderson D, Chang MJ, Cephalexin compared to ampicillin treatment of otitis media. Pediatrics 1976; 58:532-536 | | | | | | | | | Ref
STICKLER GB TREATMENT OF ACUTE OTITIS MEDIA IN CHILDREN .2. SECOND CLINICAL TRIAL JAMA-JOURNAL OF THE AMERICAN MEDICAL ASSOCIATION 187 : 85 1964 | | | | excl | excl
STICKLER GB TREATMENT OF ACUTE OTITIS MEDIA IN CHILDREN .4. A 4TH CLINICAL TRIAL AMERICAN JOURNAL OF DISEASES OF CHILDREN 114 : 123 1967 | | | | excl | excl | | | Incl | Ref
Stool SE, Berg AO, Berman S, et al. Otitis Media With Effusion in Children. Guideline Technical Report, No. 12. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, US Department of Health and Human Services; July 1994. ACHPR Publ. No. 95-0621
Stool SE, Field MJ. The impact of otitis media. Pediatic Infectious Disease Journal 1989;8(1 Suppl):11-4. | | | Ref | Ref | Ref
Subramaniam K, Jalaludin M, Krishnan G: Comparative study of ofloxacin otic drops versus neomycin-polymixin b-hydrocortisone in the medical management of chronic suppurative otitis media. Department of ORL University Malaya Medical Center, Kuala Lumpur, Malaysia. Unpublished, 2000. | | | | | | | | | | | | | | | | Incl
Supiyaphun P, Kerekhanjanarong V, Koransophonepun J, Sastarasadhit V: Comparison of ofloxacin otic solution with oral amoxycillin plus chloramphenicol ear drop in treatment of acute exacerbation of chronic suppurative otitis media. Department of ORL, Chulalongkorn Hospital, Faculty of Medicine, Chulalongkorn University, Bangkok. Unpublished. 1998. | | | | | | | | | | | | | | | | Incl
Takata, GS, Chan LS, Ernst R, Shekelle PG, Marcy SM. Management of Acute Otitis Media. Final Evidence Report. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, US Department of Health and Human Services; In press
Teele DW, Klein JO, Word BM, Rosner BA, Starobin S., Earle R Jr. et al. Antimicrobial prophylaxis for infants at risk for recurrent acute otitis media. Vaccine 2000;19(Suppl 1):140-3. | | | | | | | | | | | Incl
TEELE DW BACTERIOLOGY OF ACUTE OTITIS-MEDIA UNRESPONSIVE TO INITIAL ANTI-MICROBIAL THERAPY JOURNAL OF PEDIATRICS 98 : 537 1981
Teele DW, Klein JO, Bratton L, Fisch GR, Mathieu OR, Porter PJ, et al. Use of pneumococcal vaccine for prevention of recurrent acute otitis media in infants in Boston. The Greater Boston Collaborative Otitis Media Study Group. Review Infectious Disease Journal 1981;3 Suppl:113-18. | | | | | | | | | | | | | Incl
Thalin A, Densert 0, Larsson A, Lyden E, Ripa T. Is penicillin necessary in the treatment of acute otitis media? In: Sade J, ed. Proceedings of the International Conference on Acute and Secretory Otitis Media; 1985; Jerusalem. Amsterdam: Kugler Publications, 1985: 441–46. | | | | | Ref
THOENE DE PHARMACOTHERAPY OF OTITIS-MEDIA PHARMACOTHERAPY 11 : 212 1991 | | | Incl | | excl | Ref | | Incl | Ref
Thompson SG. Why sources of heterogeneity in meta-analysis should be investigated? BMJ 1994;309:1351-5. | | | | | Ref
Thomsen J, Meistrup-Larsen KI, Sorensen H, Larsen PK, Mygind N. Penicillin and acute otitis: short and long term results. Annals of Otology, Rhinology and Laryngology, Supplement 1980;89:271-4. | | | | Ref
Tilyard MW, Dovey SM, Walker SA Otitis media treatment in New Zealand general practice. N Z Med J 1997; 110:143-145 | | | Incl
Tong M, Woo J, Van Hasselt A: A double-blind comparative study of ofloxacin otic drops versus neomycin-polymixin b-hydrocortisone otic drops in the medical treatment of chronic suppurative otitis media. Laryngol Otol 1996;110:309-314. | | | | | | | | | | | | | | | | Incl
TOWNSEND E OTITIS MEDIA IN PEDRIATRIC PRACTICE NEW YORK STATE JOURNAL OF MEDICINE 64 : 1591 1964 | | | | | | | | Incl | Ref
UK Department of Health. The path of least resistance - main report. Department of Health Standing Medical Advisory Committee Sub-group on Antimicrobial resistance.www.advisorybodies.doh.gov.uk/smac1.htm (Accessed January 3, 2007) 2000. | | | | | Ref | | | Incl | Ref
United Kingdom Department of Health. PRODIGY guidance: Otitis media–acute. 2004. http://www.prodigy.nhs.uk (accessedSept 14, 2006). | | | | | | | Ref
van Buchem F, Peeters M, Van’ t Hof M. Acute otitis media: a new treatment strategy. Br Med J (Clin Res Ed) 1985; 290: 1033–37.
Van Buchem FL, Dunk JH, van 't Hof MA Therapy of acute otitis media: myringotomy, antibiotics, or neither? A double-blind study in children. Lancet 1981; 2:883-887 | Ref | Ref | excl | | Ref | excl | | Incl | Ref
Van ZuijlenDA, Schilder AG,Van Balen FA,Hoes AQ.National differences in incidences of acutemastoiditis: relationship to prescribing patterns for acute otitis media. Pediatric Infectious Disease 2001;20:140–4. | | | Incl | Ref | excl | Ref | | Incl | Ref
Varsano I, Frydman M, Amir J, Alpert G. Single intramuscular dose of ceftriaxone as compared to 7-day amoxicillin therapy for acute otitis media in children. Chemotherapy 1988;34,Suppl 1:39-46. | | | | | | | Ref
Varsano I, Volovitz B, Horev Z, et al. Single IM dose of ceftriaxone (CRO) compared to 10 days amoxicillin-clavulanate augmentin (AUG) for therapy of acute otitis media (AOM) in children (abstract 1059). Presented at the Sixth International Congress for I | | | | Incl | | | | | Ref
Varsano I, Volovitz B, Horev Z. Intramuscular ceftriaxone compared with oral amoxicillin-clavulanate for treatment of acute otitis media in children. Eur J Pediatr 1997; 156:858-863 | | | | excl
Varsano I, Volovitz B, Mimouti F. Sulfisoxazole prophylaxis of middle ear effusion and recurrent acute otitis media. Am J Dis Child 1985; 139:632-635. | | | | | | | | Incl | Ref | | Incl | | | Incl
Veenhoven R, Bogaert D, Uiterwaal C, Brouwer C, Kiezebrink H, Bruin J, et al. Effect of conjugate pneumococcal vaccine followed by polysaccharide pneumococcal vaccine on recurrent acute otitis media: a randomised study. The Lancet 2003;361:2189-95. | | | | | | | | | | | | | Incl
Verkatesum P, Innes JA. Antibiotic resistance in common acute respiratory pathogens. Thorax 1995;50:481–3. | | | | | | | | | | Incl | Incl
VITAL HLTH STATIS 10 176 : 1990 | | | | | | | Ref
Watson PD, Mortensen ME. Pharmacokinetics of common analgesics, antiinflammatories and antipyretics in children. Clinical Pharmacokinetics 1989;17:116-137. | | | | | Ref
Weippl G, Michos N, Stocker H. Clinical experience and results of treatment with suprofen in pediatrics. 4th communication: Assessment of pain in babies and infants/Analgesic effect of suprofen syrup in otitis media. Arzneimittelforschung 1985;35(11):1732 | | Ref
WEISS JC COST-EFFECTIVENESS IN THE CHOICE OF ANTIBIOTICS FOR THE INITIAL TREATMENT OF OTITIS-MEDIA IN CHILDREN - A DECISION-ANALYSIS APPROACH PEDIATRIC INFECTIOUS DISEASE JOURNAL 7 : 23 1988 | | excl
Westert GP, Schellevis FG, de Bakker DH, Groenewegen PP,Bensing JM, van der Zee J. Monitoring health inequalities through General Practice: the Second Dutch National Survey of General Practice. Eur J Public Health 2005; 15: 59–65. | | | | | Ref
WHO/CIBA Foundation Workshop. Prevention of hearing impairment from chronic otitis media. WHO/PDH/98.4 1996.
Willenberg W. [New preparation for the treatment of inflammatory ear diseases]. Zeitschrift fur Allgemeinmedizin 1975;51(16):759-62. | | Ref
WILSON A PRINCIPLES BEHIND PRACTICE .10. METAANALYSIS .2. ASSESSING THE QUALITY OF PUBLISHED META-ANALYSES MEDICAL JOURNAL OF AUSTRALIA 156 : 173 1992 | | excl
Woldman S. Treating ear pain in children with acute otitis media. Archives of Pediatrics & Adolescent Medicine 1998;152(1):102. | | | | | Ref
Yuen P, Lau S, Chau P, Hui Y, Wong SF, Wong S, Wei WI: Ofloxacin eardrop treatment for active chronic suppurative otitis media: Prospective randomized study. Am J Otol 1994;15:670-673. | | | | | | | | | | | | | | | | Incl
ZENK KE Pharmacologic treatment of otitis media and sinusitis in pediatrics J PEDIAT HLTH CARE 4 : 297 1990 | | excl

Incl = Included

Ref = In Reference List, but not specifically included

excl = Excluded