# Summaries of Systematic Reviews Included in Analyses

## Summary

The document is a summary of the systematic reviews that have relevance to any of the key questions in the present Workplan. It consists of 3 parts: Part 1 contains the characteristics of the systematic reviews and the highlighted conclusions; Part 2 contains our assessment of the quality of the systematic reviews using AMSTAR quality indicators; and Part 3 provides representative quantitative outcomes of the comparisons contained in the systematic reviews. Finally, we include references and the AMSTAR instrument.

We searched Medline and the Cochrane review database from 1998 through the present and identified reviews that have relevance to any of the key questions for the AOM update. We also included one review from 1994.

Based on the general conclusions of these reviews, we would say that we are well justified in redoing systematic reviews for KQ3–KQ6. In addition, since we did not identify any systematic review relevant to KQ1 or KQ2, those must be addressed, as well.

Part 1 Relevance to Management of Acute Otitis Media Update^1^

Author (year) | Content category by KQ | Review focus | Databases and included dates | Study design, inclusion criteria | Target population | Setting | Outcomes | Cost analsis | Number of trials, participants, and comparisons | Author’s highlight conclusion
Marcy (2001) 2 (initial AHRQ Management of AOM systematic review) | KQ3 KQ5 KQ6 | natural hx ab vs no ab ab regimen | CENTRAL (TCL, through Mar 1999), MEDLINE (1966-Mar 1999), HlthSTAR (1975-Mar 1999), IPAInternational Pharmaceutical Abstracts (1970-Mar 1999), CINAHL (1982-Mar 1999), BIOSIS (1970-Mar 1999), and EMBASE (1980-Mar 1999); hand search | RCT; Cohort, for natural hx | AOM 4wk–18y exclude patients with immunodeficiencies or craniofacial deficiencies, including cleft palate | Any setting | Clinical failure; adverse effects | No | 80 trials total: 74 addressed ab vs no ab & ab regimen See Comparison Table for specific trial and participant numbers 7 primary comparisons & 16 analyses reported (only analyses with ≥3 trials were conducted) | Rx with amp/amox ↓ clinical failure by 12% vs no ab; ab regimen outcomes not different; cefixime & amoxillin-clavulanate ↑ adverse effects
Rosenfeld (1994) | KQ3 KQ5 | ab vs no ab ab regimen | MEDLINE (Jan 1966–Jun 1992); Current Contents (3 months through Jun 29, 1992); hand search | RCT | AOM 4wk–18y exclude myringotomy, OM not described, mostly treatment failure or otitis prone | Not specified a priori | Clinical response, MEE presence | No | 33 trials total See Comparison Table for specific trial and participant numbers 3 primary comparisons & 16 analyses reported | ab effect modest but significant; no significant difference between ab regimens studied
Damoiseaux (1998) | KQ3 KQ5 | ab vs no ab | MEDLINE (1966-Jan 1997); EMBASE (1974-Jan 1997); hand search | RCT | AOM <2 years old | Not specified a priori | Clinical resolution within 7d | No | 4 trials 416 children 1 comparison & analysis | No significant difference be-tween ab and no ab in <2y olds
Kozyrskyj (2000) | KQ3 KQ5 KQ6 | ab <7d vs ≥7d | MEDLINE (Jan 1966–Jul 1997); EMBASE (Jan 1966– Jul 1997); Science Citation Index (Mar 1998); Current Contents (Mar 1998); hand search | RCT | AOM 4wk–18y Subgroups: ab ≤2d; oral short-acting ab; oral azithromycin; intramuscular ceftriaxone; <2 years old; perforated TM | Not specified a priori | Clinical resolution 31d & 1–3m; relapse; recurrence | No | 32 trials total See Comparison Table for specific trial and participant numbers 45 primary comparisons & 54 analyses (several utilizing 1 trial) | ab 5d → effective Rx for AOM
Glasziou (2004) | KQ3 KQ6 | ab vs no ab | CENTRAL (1966-Jan 2000; TCL, issue 1, 2003); Current Contents (1966-Jan 2000); Index Medicus (1958–1965); MEDLINE (Jan 2000–Mar 2003); EMBASE (Jan 1990–Mar 2003); hand search | RCT | AOM Children, age not specified | Any setting | Severity and duration of pain; mid- to long- term hearing problems; adverse effects; recurrent attacks | No | 8 trials total See Comparison Table for specific trial and participant numbers 1 comparison & 6 analyses | ab of small benefit for AOM Rx
Foxlee (2006) | KQ3 | topical analgesia | CENTRAL (TCL, issue 2, 2006); MEDLINE (1966-May 2006); EMBASE (1990-Dec 2005); LILACS (1982-Sep 2005); hand search | RCT or quasi- RCT | AOM without perforation in Adults and children Subgroups: <24mvs≥24m–<18y vs≥18y; topical analge-sic type; concurrent ab use exclude perforation | Primary care setting | Pain severity and duration; parental satisfaction; days missed from school or work; adverse events | No | 4 trials total See Comparison Table for specific trial and participant numbers 4 comparisons & 15 analyses | evidence insufficient to make conclusions on topical analgesia effectiveness
Rovers (2006) | KQ3 KQ5 KQ6 | ab vs no ab | CENTRAL; PubMed; EMBASE (dates not specified) | RCT | AOM 0–12 years Subgroups: <2y vs≥2y; bilateral AOM; otorrhoea | Not specified a priori | Pain &/or fever 3–7d | No | 6 trials total 3, 4 (10 trials identified & 6 investigators agreed to share data) See Comparison Table for specific trial and participant numbers 1 comparison & 21 analyses reported | ab beneficial for <2 year old with bilat AOM & AOM with otorrhea
Spurling (2007) | KQ3 | Delayed (>48 hrs) ab vs immediate ab | CENTRAL (TCL, issue 1, 2004; TCL, issue 4, 2006); MEDLINE (Jan 1966–Jan 2007); EMBASE (1990-Jan 2007); Current Contents (1998-Jan 2007) | RCT | Respiratory tract infections All ages (For identified AOM studies 6m–12y) | Not specified a priori | Clinical outcomes; ab use; patient satisfaction; health-seek-ing beha-viors; alter-native thera-pies (For identified AOM studies pain, malaise, and fever) | No | 2 trials total for AOM in children See Comparison Table for specific trial and participant numbers 3 comparisons & 9 analyses (all utilizing 1 trial) | immediate ab→ improved pain and malaise on day 3; delayed ab → diarrhea reduced (thought not an a priori outcome of this review)
Coleman (2008) | KQ3 KQ6 | decongestant &/or antihistamine | CENTRAL (TCL, issue 2, 2001; TCL, issue 3, 2003; TCL, issue 2, 2007); MEDLINE (Jan 1966–May 2007); EMBASE (Jan 1990–May 2007); hand search | RCT | <18 years old | Any setting | Clinical resolution at 2wk, 1wk, 4wk; symptom resolution; medication side effects; AOM complications | No | 15 trials total See Comparison Table for specific trial and participant numbers 5 comparisons & 52 analyses | lack of benefit for decongestant &/or antihistamine; increased risk of side effects

ab = antibiotic; amp/amox=ampicillin or amoxicillin; CENTRAL =Cochrane Central Register of Controlled Trials; CINAHL= Cumulative Index to Nursing & Allied Health Literature CI= confidence interval; Contra Otitis = contralateral otitis; HlthSTAR= Health STAR; IPA=International Pharmaceutical Abstracts; KQ=key question for Management of AOM Update; MEE= middle ear effusion; Rx=treatment; TCL=The Cochrane Library

1 For quality score of each systematic review, see next table.

2 Also, reference Takata, Chan, Shekelle, et al. (2001)

3 individual patient data meta-analyses

4 Ten trials identified; investigators of only six of the trials agreed to share their data.

Part 2 Systematic Reviews Quality

(AMSTAR: See Appendix)

Author (year) | a priori design | duplicate data extraction | comprehensive literature search | publication status | list of studies | provision of study characteristics | study quality assessed | study quality used | findings combined appropriately | publication bias assessed | conflict of interest
Marcy (2001) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Rosenfeld (1994) | Yes | Yes | No^6^ | Yes | No^7^ | Yes^8^ | Yes | Yes | Yes | No | No^9^
Damoiseaux (1998) | Yes | No^10^ | Yes | Yes | No^6^ | Yes | Yes | Yes | No | No | No
Kozyrskyj (2000) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Glasziou (2004) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes^11^ | Yes | No | No^5^
Foxlee (2006) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No^5^
Rovers (2006) | Yes | n/a^12^ | No^13^ | No | No^14^ | Yes | Yes | Yes | Yes | Yes | No^5^
Spurling (2007) | Yes | Yes | Yes^15^ | No^16^ | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Coleman (2008) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No^5^

AMSTAR=Assessment of Multiple Systematic Reviews (Shea, Grimshaw, Wells, et al, 2007)

5 Conflict of interest was addressed in the systematic review but not in all the included studies.

6 Searched Medline, three months of Current Contents, and extensive hand search

7 Excluded studies were not listed.

8 Study characteristics were summarized in the narrative but characteristics of individual studies were not given in a table.

9 Percent of studies funded in whole or in part was reported, though not clear if all studies reported conflict of interest.

10 Study inclusion was scored by four investigators, but the number of data extractors was not reported.

11 Quality was measured but not used in formulating conclusions or recommendations.

12 This meta-analysis utilized individual patient data.

13 Dates searched were not reported, and the hand search was limited to one symposia series.

14 Excluded studies were not listed

15 Reported hand search was not as extensive as might be expected.

16 Unlike most Cochrane reviews this review does not explicitly state if publications were excluded based on language.

Part 3 Comparison Table Representative Comparisons from Systematic Reviews

Study | Comparison primary subgroup | Outcome | Trials | Participants | OR, RD, RR, or WMD | 95% CI
Marcy (2001) 17 | amp/amox vs no ab | Rx failure 2–7d | 5 | 1518 | RD −12.3% | −21.8 % to −2.8%
| pcn vs amp/amox | Rx failure 7–14d | 3 | 491 | RD 4.5% | −1.8% to 10.7%
| cefaclor vs amp/amox | Rx failure 3–7d | 4 | 185 | RD −5.4% | −15.2% to 4.4%
| | Rx failure 5–21 d | 5 | 315 | RD 0.5% | −5.7% to 6.8%
| cefixime vs amp/amox | Rx failure 10–15d | 4 | 519 | RD −0.1% | −4.2% to 3.9%
| | recurrence 3–5wk | 3 | 144 | RD 1.6% | −5.1 % to 8.4%
| | diarrhea | 5 | 754 | RD 8.4% | 3.8% to 13.1%
| | vomiting | 5 | 754 | RD 2 % | 0% to 4%
| | rash | 4 | 714 | RD 5.8% | −2.4% to 13.9%
| ceftriaxone vs amox | Rx failure 5–10d | 3 | 306 | RD 3.4% | −1.6% to 8.5%
| azith vs amox-clav | Rx failure 10–14d | 5 | 1045 | RD 2.1% | −0.6% to 4.8%
| | any adverse effect | 3 | 1366 | RD −19.2% | −29.2% to−9.2%
| | GI adverse effect | 3 | 1366 | RD −18.0% | −28.0% to−8.0%
Rosenfeld (1994) 18 | pcn vs no ab | Rx failure 7–14d | 2 | 242 | RD −15.7% | −26.7% to−4.7%
| aminopcn vs no ab | Rx failure 7–14d | 3 | 386 | RD −12.9% | −19.0% to −6.8%
| any ab vs no ab | Rx failure 7–14d | 4 | 535 | RD −13.7% | −19.2% to −8.2%
| amp vs pcn | Rx failure 7–14d | 3 | 497 | RD −6.8% | −15.2% to 1.5%
| amp vs pcn/ssx | Rx failure 7–14d | 3 | 462 | RD 0.9% | −7.6% to 9.4%
| aminopcn vs ery | Rx failure 7–14d | 3 | 525 | RD 3.1% | −3.9% to 10.2%
| aminopcn vs tmp-smx | Rx failure 7–14d | 2 | 275 | RD 0.2% | −8.8% to 9.2%
| amox vs cefaclor | Rx failure 7–14d | 4 | 453 | RD 6.4% | −10.2 to 22.9%
| amox vs cefixime | Rx failure 7–14d | 3 | 404 | RD −3.9% | −10.4 to 2.6%
| | MEE 30d | Not reported | Not reported | RD −15.0% | −35.5% to 5.5%
| cefaclor vs ery/ssx | Rx failure 7–14d | 2 | 222 | RD −7.0% | −6.5% to 20.4%
| cefaclor vs amox-clav | Rx failure 7–14d | 5 | 776 | RD 2.8% | −1.3% to 6.8%
| | MEE 30d | Not reported | Not reported | RD 1.6% | −5.1% to 8.3%
| cefaclor vs cefixime | Rx failure 7–14d | 4 | 966 | RD 1.2% | −2.4% to 4.7%
| | MEE 30d | Not reported | Not reported | RD 1.8% | −19.0% to 22.6%
Damoiseaux (1998) | ab vs no ab <2y old | clinical resolution | 4 | 416 | OR 1.31 | 0.83 to 2.08
Kozyrskyj (2000) 19 | ≤48° ab vs >7d ab | Rx failure ≤1m | 2 | 118 | OR 2.99 | 1.04 to 8.54
| >48°≤7d ab vs >7d ab | Rx failure ≤1m | 12 | 3118 | OR 1.38 | 1.15 to 1.66
| | Rx failure 8–19d | 5 | 1524 | OR 1.52 | 1.17 to 1.98
| | Rx failure 20–30d | 9 | 2115 | OR 1.22 | 0.98 to 1.54
| | Rx failure ≤3m | 5 | 1054 | OR 1.16 | 0.90 to 1.50
| | Rx failure 90d | 2 | 207 | OR 1.16 | 0.65 to 2.06
| | Rx failure 30–40d | 3 | 847 | OR 1.16 | 0.87 to 1.55
| <2y old | Rx failure ≤1m | 3 | 118 | OR 0.71 | 0.30 to 1.64
| ≥2y old | Rx failure ≤1m | 3 | 235 | OR 1.01 | 0.53 to 1.94
| perforated TM | Rx failure ≤1m | 1 | 27 | OR 3.62 | 0.81 to 16.1
| non-perforated TM | Rx failure ≤1m | 1 | 101 | OR 1.06 | 0.40 to 2.75
| include chronic OM | Rx failure ≤1m | 9 | 2220 | OR 1.39 | 1.15 to 1.70
| exclude chronic OM | Rx failure ≤1m | 3 | 898 | OR 1.29 | 0.76 to 2.20
| include chronic OM | Rx failure 20–30d | 7 | 1459 | OR 1.19 | 0.93 to 1.51
| exclude chronic OM | Rx failure 20–30d | 2 | 656 | OR 1.55 | 0.79 to 3.04
| only “cured” | Rx failure ≤1m | 11 | 3062 | OR 1.35 | 1.14 to 1.59
| only “cured” | Rx failure 20–30d | 8 | 2059 | OR 1.24 | 1.01 to 1.54
| | GI adverse effects | 10 | 3576 | OR 0.54 | 0.43 to 0.66
| excluding amox-clav | GI adverse effects | 7 | 2131 | OR 1.13 | 0.81 to 1.57
| ceftriaxone | Rx failure ≤1m | 3 | 671 | OR 1.25 | 0.90 to 1.72
| | Rx failure ≤3m | 2 | 312 | OR 0.91 | 0.57 to 1.47
| | GI adverse effects | 1 | 402 | OR 2.89 | 1.70 to 4.91
| azithromycin 3–5d | Rx failure ≤1m | 11 | 2593 | OR 1.09 | 0.86 to 1.38
| | Rx failure 8–19d | 10 | 2569 | OR 1.11 | 0.82 to 1.51
| | Rx failure 20–30d | 6 | 1254 | OR 1.02 | 0.78 to 1.34
| <2y old | Rx failure ≤1m | 2 | 138 | OR 1.92 | 0.73 to 5.04
| ≥2y old | Rx failure ≤1m | 2 | 656 | OR 1.34 | 0.61 to 2.94
| Rx 3d | Rx failure ≤1m | 8 | 1558 | OR 1.17 | 0.71 to 1.92
| include chronic OM | Rx failure ≤1m | 7 | 1688 | OR 0.96 | 0.70 to 1.31
| exclude chronic OM | Rx failure ≤1m | 4 | 905 | OR 1.29 | 0.89 to 1.85
| include chronic OM | Rx failure 20–30d | 4 | 740 | OR 0.83 | 0.57 to 1.21
| exclude chronic OM | Rx failure 20–30d | 2 | 514 | OR 1.27 | 0.86 to 1.86
Kozyrskyj (2000) | only “cured” | Rx failure 20–30d | 4 | 728 | OR 0.83 | 0.59 to 1.16
| only “cured” | Rx failure ≤1m | 9 | 2067 | OR 0.70 | 0.57 to 0.87
| | GI adverse effects | 9 | 2818 | OR 0.26 | 0.19 to 0.37
Glasziou (2004) | ab vs no ab | pain 24h | 4 | 717 | OR 1.03 | 0.76 to 1.39
| | pain 2–7d | 9 | 2287 | OR 0.57 | 0.45 to 0.73
| | abnl tympanogram 1m | 3 | 472 | OR 0.91 | 0.62 to 1.32
| | abnl tympanogram 3m | 2 | 370 | OR 0.75 | 0.47 to 1.21
| | perforation | 2 | 381 | OR 0.51 | 0.20 to 1.26
| | vomiting, diarrhea, rash | 4 | 938 | OR 1.94 | 1.28 to 2.94
| | contralateral otitis | 3 | 666 | OR 0.45 | 0.16 to 1.23
| | late recurrence | 5 | 1669 | OR 1.00 | 0.78 to 1.26
Foxlee (2006) 20 | top anaesth vs placebo | 25% ↓ pain 10min | 1 | 27 | RR 1.18 | 0.65 to 2.15
| | 25% ↓ pain 20min | 1 | 27 | RR 1.24 | 0.87 to 1.76
| | 25% ↓ pain 30min^21^ | 1 | 27 | RR 1.37 | 1.06 to 1.77
Rovers (2006)^22,23^ | ab vs no ab | pain &/or fever 3–7d | 6 | 1643 | RD −13% | −17% to −9%
| <2y old | pain &/or fever 3–7d | 6 | 567 | RD −15% | −23% to −7%
| ≥2y old | pain &/or fever 3–7d | 6 | 1076 | RD −11 % | −16% to −6%
| unilateral | pain &/or fever 3–7d | 6 | 872 | RD −6% | −12% to 0%
| bilateral | pain &/or fever 3–7d | 6 | 456 | RD −20% | −28% to −11%
| < 2y old & bilateral | pain &/or fever 3–7d | 6 | 273 | RD −25% | −36% to −14%
| <2 y old & unilateral | pain &/or fever 3–7d | 6 | 261 | RD −5% | −17% to 7%
| ≥2y old& bilateral | pain &/or fever 3–7d | 6 | 183 | RD −12% | −25% to 1%
| ≥2y old & unilateral | pain &/or fever 3–7d | 6 | 611 | RD −7% | −14% to 0%
| otorrhea | pain &/or fever 3–7d | 6 | 116 | RD −36% | −53% to −19%
| no otorrhea | pain &/or fever 3–7d | 6 | 439 | RD −14% | −23% to −5%
Spurling (2007) | delayed ab vs imm ab | pain 3d | 1 | 212 | OR 1.93 | 0.96 to 3.88
| | pain 4–6d | 1 | 265 | OR 0.89 | 0.54 to 1.48
| | pain 7d | 1 | 212 | OR 6.55 | 0.33 to 128.35
| | pain severity 3d | 1 | 213 | WMD 0.75 | 0.26 to 1.24
| | pain severity 7d | 1 | 212 | WMD 0.12 | −0.04 to 0.28
| | malaise 3d | 1 | 285 | OR 2.62 | 1.44 to 4.76
| | malaise severity 3d | 1 | 284 | WMD 0.43 | −0.11 to 0.75
| | malaise severity 7d | 1 | 285 | WMD 0.69 | 0.31 to 1.07
| | fever 4–6d | 1 | 265 | OR 0.88 | 0.53 to 1.47
Coleman (2008) | decong/antihist vs none^24^ | persisting AOM 2wk | 12 | 2300 | OR 0.80 | 0.63 to 1.00
| | persisting AOM <7d | 2 | 143 | OR 0.83 | 0.36 to 1.91
| | persisting AOM >2wk | 3 | 378 | OR 1.39 | 0.69 to 2.80
| | otalgia | 2 | 287 | OR 0.79 | 0.43 to 1.47
| | fever | 1 | 98 | OR 3.90 | 0.05 to 330.46
| | hearing loss | 2 | 976 | OR 1.45 | 0.58 to 3.61
| | drowsy | 2 | 567 | OR 8.68 | 0.53 to 143.30
| | hyperactivity | 3 | 251 | OR 0.79 | 0.10 to 5.94
| | other side effect | 3 | 416 | OR 5.00 | 1.73 to 14.48
| | prolonged OM 8–12wk | 1 | 106 | OR 0.83 | 0.25 to 2.74
| | recurrent AOM <2wk | 5 | 997 | OR 0.95 | 0.57 to 1.57
| | required surgery | 4 | 1172 | OR 1.28 | 0.67 to 2.46
| | mastoiditis or meningitis | 2 | 662 | OR not estimable | not estimable

ab = antibiotic; abnl=abnormal; amox-clay=amoxicillin-clavulanate; amp/amox=ampicillin or amoxicillin; azith=azithromycin; CI=confidence interval; ery=erythromycin; GI=gastrointestinal; imm=immediate; OM=otitis media; OR= odds ratio; pcn= penicillin; RD=rate difference; RR=relative risk; ssx=sulfisoxazole; TM=tympanic membrane; TMP-SMX= trimethoprim-sulfamethoxazole; top= topical; WMD-weighted mean difference

17 Sensitivity analyses deleting or including problematic articles were also reported but are not listed in this table.

18 Sensitivity analysis by AOM diagnostic specificity was also reported but is not listed in this table.

19 Subgroup analyses by quality and sensitivity analyses excluding trials comparing different antibiotics were also reported but are not listed in this table.

20 Results for analyses comparing topical anaesthetic and naturopathic drops were also reported but apparently the studies showed significant heterogeneity and are not included in this table.

21 Measuring 50% pain reduction at 10, 20, and 30 minutes showed no difference.

22 individual patient data meta-analyses

23 Results of analyses for pain alone at 3–7 days with subgroup analyses and fever alone at 3–7 days without subgroups analyses were also reported but are not included in this table.

24 Analyses for decongestant and antihistamine alone and for decongestant and antihistamine together as well as subgroup analyses by primary outcome by various quality criteria, route of medication, and method to diagnose AOM resolution were also reported but are not included in this table.

Appendix AMSTAR Quality Indicators

(Shea, Grimshaw, Wells, et al, 2007)

1. Was an ‘a priori’ design provided? The research question and inclusion criteria should be established before the conduct of the review. | □Yes □No □Can’t answer □Not applicable
2. Was there duplicate study selection and data extraction? There should be at least two independent data extractors and a consensus procedure for disagreements should be in place. | □Yes □No □Can’t answer □Not applicable
3. Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g. Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and where feasible the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found. | □Yes □No □Can’t answer □Not applicable
4. Was the status of publication (i.e. grey literature) used as an inclusion criterion? The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language etc. | □Yes □No □Can’t answer □Not applicable
5. Was a list of studies (included and excluded) provided? A list of included and excluded studies should be provided. | □Yes □No □Can’t answer □Not applicable
6. Were the characteristics of the included studies provided? In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed e.g. age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases should be reported. | □Yes □No □Can’t answer □Not applicable
7. Was the scientific quality of the included studies assessed and documented? ‘A priori’ methods of assessment should be provided (e.g., for effectiveness studies if the author(s) chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies alternative items will be relevant. | □Yes □No □Can’t answer □Not applicable
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating recommendations. | □Yes □No □Can’t answer □Not applicable
9. Were the methods used to combine the findings of studies appropriate? For the pooled results, a test should be done to ensure the studies were combinable, to assess their homogeneity (i.e. Chi-squared test for homogeneity, I^2^). If heterogeneity exists a random effects model should be used and/or the clinical appropriateness of combining should be taken into consideration (i.e. is it sensible to combine?). | □Yes □No □Can’t answer □Not applicable
10. Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). | □Yes □No □Can’t answer □Not applicable
11. Was the conflict of interest stated? Potential sources of support should be clearly acknowledged in both the systematic review and the included studies. | □Yes □No □Can’t answer □Not applicable

### References

Coleman C, Moore M. Decongestants and antihistamines for acute otitis media in children. Cochrane Database Syst Rev. 2008;(3):CD001727. [pmid: 18646076].
Damoiseaux RA, van Balen FA, Hoes AW, de Melker RA. Antibiotic treatment of acute otitis media in children under two years of age: evidence based?. Br J Gen Pract. 1998;48(437):1861-1864. [pmid: 10198511].
Foxlee R, Johansson A, Wejfalk J, Dawkins J, Dooley L, Del Mar CB. Topical analgesia for acute otitis media. Cochrane Database Syst Rev. 2006;(3):CD005657. [pmid: 16856108].
Glasziou PP, Del Mar CB, Sanders SL, Hayem M. Antibiotics for acute otitis media in children. Cochrane Database Syst Rev. 2004;(1):CD000219. [pmid: 14973951].
Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SE, Wincott JL, Sitar DS, Klassen TP, Moffatt ME. Short course antibiotics for acute otitis media. Cochrane Database Syst Rev. 2000;(2):CD001095. [pmid: 10796591].
Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
Rosenfeld RM,, Vertrees JE, Carr J, Cipolle RJ, Uden DL, Biebink GS, Canafax DM. Clinical efficacy of antimicrobial drugs for acute otitis media: metaanalysis of 5400 children from thirty-three randomized trials. J Pediatr. 1994;124:355-367. [pmid: 8120703].
Rovers MM, Glasziou P, Appelman CL, Burke P, McCormick DP, Damoiseaux RA, Gaboury I, Little P, Hoes AW. Antibiotics for acute otitis media: a meta-analysis with individual patient data. Lancet. 2006;368(9545):1429-1435. [pmid: 17055944].
Shea BJ, Grimshaw JM, Wells GA, Boers M, Anderson N, Hamel C, Porter AC, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodologic quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
Spurling GK, Del Mar CB, Dooley L, Foxlee R. Delayed antibiotics for respiratory infections. Cochrane Database Syst Rev. 2007;(3):CD004417. [pmid: 17636757].
Takata GS, Chan LS, Shekelle P, Morton SC, Mason W, Marcy SM. Evidence assessment of management of acute otitis media: I. The role of antibiotics in treatment of uncomplicated acute otitis media. Pediatrics. 2001;108:239-247. [pmid: 11483783].
Whitlock EP, Lin JS, Chou R, Shekelle P, Robinson KA. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 148(10):776-782. [pmid: 18490690].

## Key Question 1

This document is a summary of the systematic reviews that have relevance to Key Question 1 (KQ1) regarding diagnosis of acute otitis media in the present Workplan. It consists of 3 parts: Part 1 contains the characteristics of the systematic reviews and the highlighted conclusions; Part 2 contains our assessment of the quality of the systematic reviews using AMSTAR quality indicators; and Part 3 provides representative quantitative outcomes of the comparisons contained in the systematic reviews. Finally, we include references and the AMSTAR instrument.

We searched Medline from 1998 through the present and identified reviews that have relevance to KQ1 for the AOM update. We searched the Cochrane Review database to the present. We also searched the Web of Science 1980–1997 and did hand searches of reference lists of study articles identified for inclusion in the AOM update.

Based on the general conclusions of these reviews we believe that we are justified in doing a systematic review for KQ1. We have also noted the studies included in these systematic reviews for possible inclusion in the present systematic review.

Part 1 Relevance to Key Question 1 of the Management of Acute Otitis Media Update^1^

Author (year) | Content category by KQ | Review focus | Databases and included dates | Study design, inclusion criteria | Target population | Setting | Outcomes | Cost analsis | Number of trials, participants, and comparisons | Author’s highlight conclusion
Rothman (2003) | KQ1 | Precision and accuracy of history taking and physical exam in diagnosing AOM in children | MEDLINE for English- language articles (1966 through May 2002); hand searches including bibliographies of retrieved articles and textbooks | Included:; 1. studies that examined symptoms & signs directly relevant to diagnosis of AOM; 2. studies that used tympanocentesis as standard.; 3. studies that used a standardized clinical definition of AOM as standard; Exduded:; 1. Studies on persistent OME; 2. studies that used non-independent comparison of symptoms to a standard of uncertain validity | Children, age not defined | not specified a priori | Accuracy of symptoms and accuracy of signs as measured by likelihood ratios, sensitivity and specificity. | No | 4 studies on accuracy of symptoms included 965 subjects, 0–15y 1 study on accuracy of signs included 2911 subjects, 6 mo–2.5y. | 1. Dx of AOM can be very difficult.; 2. Studies examining this condition are limited.; 3. A cloudy, bulging or clearly immobile tympanic membrane is most helpful for detecting AOM; 4. The degree of erythema may also be useful

Part 1 Abbreviations and Acronyms: ab= antibiotic; amp/amox=ampicillin or amoxicillin; CENTRAL=Cochrane Central Register of Controlled Trials; CINAHL=Cumulative Index to Nursing & Allied Health Literature CI=confidence interval; Contra Otitis=contralateral otitis; CSOM=chronic suppurative otitis media; ENT=ear, nose, and throat; HlthSTAR=Health STAR; IPA=International Pharmaceutical Abstracts; KQ= key question for Management of AOM Update; MEE=middle ear effusion; mRCT=meta Resgister, NRR=National Research Register; Rx=treatment; PCV= pneumococcal conjugated vaccines; PPV=pneumococcal polysaccharide vaccines; ROM=recurrent otitis media; TCL= The Cochrane Library

1 For quality score of each systematic review, see next table.

Part 2 Systematic Reviews Quality

(AMSTAR: See Appendix)

Author (year) | a priori design | duplicate data extraction | comprehensive literature search | publication status | list of studies | provision of study characteristics | study quality assessed | study quality used | findings combined appropriately | publication bias assessed | conflict of interest
Rothman (2003) | Yes | Yes | No^1^ | Yes | No^2^ | No^3^ | Yes | Yes | No^4^ | No | No

AMSTAR=Assessment of Multiple Systematic Reviews (Shea, Grimshaw, Wells, et al, 2007)

1 Only one electronic database was searched.

2 List of excluded studies not provided.

3 Only limited demographic or clinical characteristics were provided in the table.

4 Pooled analyses of multiple studies were not performed because of small number and heterogeneity of studies available.

Part 3 Comparison Table Representative Comparisons from Systematic Reviews

Study | Source | Trials (Citations) | # Participants | Symptom | Sensitivity in% | Specificity in% | Pos LR (95% CI) | Neg LR (95% CI)
Rothman (2003) | Niemela (1994) | 1 | 354 | Ear pain | 54 | 82 | 3.0 (2.1–4.3) | 0.6 (0.5–0.7)
Rothman (2003) | Niemela (1994) | 1 | 354 | Ear rubbing | 42 | 87 | 3.3 (2.1–5.1) | 0.7 (0.6–0.8)
Rothman (2003) | Niemela (1994) | 1 | 354 | Fever | 40 | 48 | 0.8 (0.6–1.0) | 1.2 (1.0–1.5)
Rothman (2003) | Niemela (1994) | 1 | 354 | Cough | 47 | 45 | 0.9 (0.7–1.1) | 1.2 (0.9–1.4)
Rothman (2003) | Niemela (1994) | 1 | 354 | Rhinitis | 75 | 43 | 1.3 (1.1–1.5) | 0.6 (0.4–0.8)
Rothman (2003) | Niemela (1994) | 1 | 354 | Excessive crying | 55 | 69 | 1.8 (1.4–2.3) | 0.7 (0.5–0.8)
Rothman (2003) | Niemela (1994) | 1 | 354 | Poor appetite | 36 | 66 | 1.1 (0.8–1.4) | 1.0 (0.8–1.1)
Rothman (2003) | Niemela (1994) | 1 | 354 | Vomiting | 11 | 89 | 1.0 (0.6–1.8) | 1.0 (0.9–1.1)
Rothman (2003) | Niemela (1994) | 1 | 354 | Soar throat | 13 | 74 | 0.5 (0.3–0.8) | 1.2 (1.1–1.3)
Rothman (2003) | Niemela (1994) | 1 | 354 | Headache | 9 | 76 | 0.4 (0.2–0.7) | 1.2 (1.1–1.3)
Rothman (2003) | Heikkinen (1995) | 1 | 302 | Ear pain | 60 | 92 | 7.3 (4.4–12.1) | 0.4 (0.4–0.5)
Rothman (2003) | Heikkinen (1995) | 1 | 302 | Fever | 69 | 23 | 0.9 (0.8–1.0) | 1.4 (0.9–2.0)
Rothman (2003) | Heikkinen (1995) | 1 | 302 | Cough | 84 | 17 | 1.0 (0.9–1.1) | 1.0 (0.6–1.6)
Rothman (2003) | Heikkinen (1995) | 1 | 302 | Rhinitis | 96 | 8 | 1.0 (1.0–1.1) | 0.5 (0.2–1.4)
Rothman (2003) | Heikkinen (1995) | 1 | 302 | Restless sleep | 64 | 51 | 1.3 (1.1–1.6) | 0.7 (0.5–0.9)
Rothman (2003) | Ingvarsson (1982) | 1 | 171 | Ear pain | 100 | NA | NA | NA
Rothman (2003) | Ingvarsson (1982) | 1 | 171 | Fever | 79 | 70 | 2.6 (1.9–3.6) | 0.3 (0.2–0.5)
Rothman (2003) | Ingvarsson (1982) | 1 | 171 | Upper respiratory tract infection | 96 | 29 | 1.4 (1.2–1.6) | 0.3 (0.2–0.5)
Rothman (2003) | Kontiokari (1998) | 1 | 138 | Parental suspicion of acute otitis media | 70 | 80 | 3.4 (2.8–4.2) | 0.4 (0.3–0.5)

Study | Source | Trials (Citations) | # Participants | Sign | | | Unadjusted Pos LR | Adjusted Pos LR (95% CI)
Rothman (2003) | Karma (1989) | 1 | 2911 | Color – Cloudy | | | 11.0 | 34.0 (28.0–42.0)
Rothman (2003) | Karma (1989) | 1 | 2911 | Color – Distinctly red | | | 2.6 | 8.4 (6.7–11.0)
Rothman (2003) | Karma (1989) | 1 | 2911 | Color – Slightly red | | | 0.4 | 1.4 (1.1–1.8)
Rothman (2003) | Karma (1989) | 1 | 2911 | Color – Normal | | | 0.1 | 0.2 (0.19–0.21)
Rothman (2003) | Karma (1989) | 1 | 2911 | Position – Bulging | | | 20.0 | 51.0 (36.0–73.0)
Rothman (2003) | Karma (1989) | 1 | 2911 | Position – Retracted | | | 1.3 | 3.5 (2.9–4.2)
Rothman (2003) | Karma (1989) | 1 | 2911 | Position – Normal | | | 0.4 | 0.50 (0.49–0.51)
Rothman (2003) | Karma (1989) | 1 | 2911 | Mobility – Distinctly impaired | | | 8.4 | 31.0 (26.0–37.0)
Rothman (2003) | Karma (1989) | 1 | 2911 | Mobility – Slightly impaired | | | 1.1 | 4.0 (3.4–4.7)
Rothman (2003) | Karma (1989) | 1 | 2911 | Mobility – Normal | | | 0.04 | 0.2 (0.19–0.21)

Appendix AMSTAR Quality Indicators

(Shea, Grimshaw, Wells, et al, 2007)

1. Was an ‘a priori’ design provided? The research question and inclusion criteria should be established before the conduct of the review. | □Yes □No □Can’t answer □Not applicable
2. Was there duplicate study selection and data extraction? There should be at least two independent data extractors and a consensus procedure for disagreements should be in place. | □Yes □No □Can’t answer □Not applicable
3. Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g. Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and where feasible the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found. | □Yes □No □Can’t answer □Not applicable
4. Was the status of publication (i.e. grey literature) used as an inclusion criterion? The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language etc. | □Yes □No □Can’t answer □Not applicable
5. Was a list of studies (included and excluded) provided? A list of included and excluded studies should be provided. | □Yes □No □Can’t answer □Not applicable
6. Were the characteristics of the included studies provided? In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed e.g. age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases should be reported. | □Yes □No □Can’t answer □Not applicable
7. Was the scientific quality of the included studies assessed and documented? ‘A priori’ methods of assessment should be provided (e.g., for effectiveness studies if the author(s) chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies alternative items will be relevant. | □Yes □No □Can’t answer □Not applicable
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating recommendations. | □Yes □No □Can’t answer □Not applicable
9. Were the methods used to combine the findings of studies appropriate? For the pooled results, a test should be done to ensure the studies were combinable, to assess their homogeneity (i.e. Chi-squared test for homogeneity, I^2^). If heterogeneity exists a random effects model should be used and/or the clinical appropriateness of combining should be taken into consideration (i.e. is it sensible to combine?). | □Yes □No □Can’t answer □Not applicable
10. Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). | □Yes □No □Can’t answer □Not applicable
11. Was the conflict of interest stated? Potential sources of support should be clearly acknowledged in both the systematic review and the included studies. | □Yes □No □Can’t answer □Not applicable

### References

Heikkinen T, Ruuskanen O. Signs and symptoms predicting acute otitis media. Arch Pediatr Adolesc Med. 1995;149:26-29. [pmid: 7827655].
Ingvarsson L. Acute otalgia in children – findings and diagnosis. Acta Paediatr Scand. 1982;71:705-710. [pmid: 6891167].
Karma PH, Penttila MA, Sipila MM, Kataja MJ. Otoscopic diagnosis of middle ear effusion in acute and non-acute otitis media. I: the value of different otoscopic findings. Int J Pediatr Otorhinolaryngol. 1989;17:37-49. [pmid: 2707977].
Kontiokari T, Koivunen P, Niemela M, Pokka T, Uhari M. Symptoms of acute otitis media. Pediatr Infect Dis J. 1998;17:676-679. [pmid: 9726339].
Niemela M, Uhari M, Juunio-Ervasti K, Luotonen J, Alho OP, Vierimaa E. Lack of specific symptomatology in children with acute otitis media. Pediatr Infect Dis J. 1994;13:765-768. [pmid: 7808842].
Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
Rothman R, Owens T, Simel DL. Does this child have acute otitis media?. JAMA. 2003;290:1633-1640. [pmid: 14506123].
Shea BJ, Grimshaw JM, Wells GA, Boers M, Anderson N, Hamel C, Porter AC, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodologic quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
Whitlock EP, Lin JS, Chou R, Shekelle P, Robinson KA. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776-782. [pmid: 18490690].

## Key Question 3

This document is a summary of the systematic reviews that have relevance to Key Question 3 (KQ3) regarding treatment of acute otitis media in the present Workplan. It consists of 3 parts: Part 1 contains the characteristics of the systematic reviews and the highlighted conclusions; Part 2 contains our assessment of the quality of the systematic reviews using AMSTAR quality indicators; and Part 3 provides representative quantitative outcomes of the comparisons contained in the systematic reviews. Finally, we include references and the AMSTAR instrument.

We searched Medline from 1998 through the present and identified reviews that have relevance to KQ3 for the AOM update. We searched the Cochrane Review database to the present. We also searched the Web of Science 1980–1997 and did hand searches of reference lists of study articles identified for inclusion in the AOM update.

Based on the general conclusions of these reviews we believe that we are justified in doing a systematic review for KQ3. We have also noted the studies included in these systematic reviews for possible inclusion in the present systematic review.

Part 1 Relevance to Key Question 3 of the Management of Acute Otitis Media Update^1^

Author (year) | Content category by KQ | Review focus | Databases and included dates | Study design, inclusion criteria | Target population | Setting | Outcomes | Cost analsis | Number of trials, participants, and comparisons | Author’s highlight conclusion
Marcy (2001) 2 (initial AHRQ Management of AOM systematic review) | KQ3 KQ5 KQ6 | natural hx ab vs no ab ab regimen | CENTRAL (TCL, through Mar 1999), MEDLINE (1966-Mar 1999), HlthSTAR (1975-Mar 1999), IPAInternational Pharmaceutical Abstracts (1970-Mar 1999), CINAHL (1982-Mar 1999), BIOSIS (1970-Mar 1999), and EMBASE (1980-Mar 1999); hand search | RCT; Cohort, for natural hx | AOM 4wk–18y exclude patients with immunodeficiencies or craniofacial deficiencies, including cleft palate | Any setting | Clinical failure; adverse effects | No | 80 trials total: 74 addressed ab vs no ab & ab regimen See Comparison Table for specific trial and participant numbers 7 primary comparisons &16 analyses reported (only analyses with ≥3 trials were conducted) | Rx with amp/amox ↓ clinical failure by 12% vs no ab; ab regimen outcomes not different; cefixime & amoxillin-clavulanate ↑ adverse effects
Rosenfeld (1994) | KQ3 KQ5 | ab vs no ab ab regimen | MEDLINE (Jan 1966–Jun 1992); Current Contents (3 months through Jun 29, 1992); hand search | RCT | AOM 4wk–18y exclude myringotomy, OM not described, mostly treatment failure or otitis prone | Not specified a priori | Clinical response, MEE presence | No | 33 trials total See Comparison Table for specific trial and participant numbers 3 primary comparisons & 16 analyses reported | ab effect modest but significant; no significant difference between ab regimens studied
Damoiseaux(1998) | KQ3 KQ5 | ab vs no ab | MEDLINE (1966-Jan 1997); EMBASE (1974-Jan 1997); hand search | RCT | AOM <2 years old | Not specified a priori | Clinical resolution within 7d | No | 4 trials 416 children 1 comparison & analysis | No significant difference be-tween ab and no ab in <2y olds
Kozyrskyj (2000) | KQ3 KQ5 KQ6 | ab <7d vs ≥ 7d | MEDLINE (Jan 1966–Jul 1997); EMBASE (Jan 1966–Jul 1997); Science Citation Index (Mar 1998); Current Contents (Mar 1998); hand search | RCT | AOM 4wk–18y Subgroups: ab ≤2d; oral short- acting ab; oral azithromycin; intramuscular ceftriaxone; <2 years old; perforated TM | Not specified a priori | Clinical resolution 31 d &1–3m; relapse; recurrence | No | 32 trials total See Comparison Table for specific trial and participant numbers 45 primary comparisons & 54 analyses (several utilizing 1 trial) | ab 5d → effective Rx for AOM
Abes (2003) | KQ3 | effectiveness of ofloxacin otic solution for treatment of suppurative otitis media. Incidence of side-effects or adverse events during course of treatment | Medline through PubMed (1966 to 2000); CD version of the Cochrane Library; Centerwatch Clinical Trial Listing Service; Trial Banks; Research and Researcher Registry; Manual searches. | RCT and non- randomized clinical trial | Adults and/or children who had clinical manifestations associated with acute or chronic suppurative otitis media. | Not specified a priori | cure rate resolution of otalgia resolution of otorrhea bacterial eradication | No | 11 studies 1484 adults and children | 0.3% ofloxacin otic solution is better than other otic antibiotic drops and other oral antibiotics in terms of overall cure rate and resolution of secondary outcome parameters.
Glasziou (2004) | KQ3 KQ6 | ab vs no ab | CENTRAL (1966-Jan 2000; TCL, issue 1, 2003); Current Contents (1966-Jan 2000); Index Medicus (1958–1965); MEDLINE (Jan 2000–Mar 2003); EMBASE (Jan 1990–Mar 2003); hand search | RCT | AOM Children, age not specified | Any setting | Severity and duration of pain; mid- to long- term hearing problems; adverse effects; recurrent attacks | No | 8 trials total See Comparison Table for specific trial and participant numbers 1 comparison &6 analyses | ab of small benefit for AOM Rx
Foxlee (2006) | KQ3 | topical analgesia | CENTRAL (TCL, issue 2, 2006); MEDLINE (1966-May 2006); EMBASE (1990-Dec 2005); LILACS (1982-Sep 2005); hand search | RCT or quasi- RCT | AOM without perforation in Adults and children Subgroups: <24mvs≥24m–<18yvs≥18y; topical analgesic type; concurrent ab use exclude perforation | Primary care setting | Pain severity and duration; parental satisfaction; days missed from school or work; adverse events | No | 4 trials total See Comparison Table for specific trial and participant numbers 4 comparisons & 15 analyses | evidence insufficient to make conclusions on topical analgesia effectiveness
Rovers (2006) | KQ3 KQ5 KQ6 | ab vs no ab | CENTRAL; PubMed; EMBASE (dates not specified) | RCT | AOM 0–12 years Subgroups: <2y vs ≥2y; bilateral AOM; otorrhoea | Not specified a priori | Pain &/or fever 3–7d | No | 6 trials total 3,4 (10 trials identified & 6 investigators agreed to share data) See Comparison Table for specific trial and participant numbers 1 comparison & 21 analyses reported | ab beneficial for <2 year old with bilat AOM & AOM with otorrhea
Spurling (2007) | KQ3 | Delayed (>48 hrs) ab vs immediate ab | CENTRAL (TCL, issue 1, 2004; TCL, issue 4, 2006); MEDLINE (Jan 1966–Jan 2007); EMBASE (1990-Jan 2007); Current Contents (1998-Jan 2007) | RCT | Respiratory tract infections All ages (For identified AOM studies 6m–12y) | Not specified a priori | Clinical outcomes; ab use; patient satisfaction; health-seek-ing beha-viors; alter-native thera-pies (For identified AOM studies pain, malaise, and fever) | No | 2 trials total for AOM in children See Comparison Table for specific trial and participant numbers 3 comparisons & 9 analyses (all utilizing 1 trial) | immediate ab→ improved pain and malaise on day 3; delayed ab → diarrhea reduced (thought not an a priori outcome of this review)
Coleman (2008) | KQ3 KQ6 | decongestant &/or antihistamine | CENTRAL (TCL, issue 2, 2001; TCL, issue 3, 2003; TCL, issue 2, 2007); MEDLINE (Jan 1966–May 2007); EMBASE (Jan 1990–May 2007); hand search | RCT | AOM <18y | Any setting | Clinical resolution at 2wk, 1wk, 4wk; symptom resolution; medication side effects; AOM complications | No | 15 trials total See Comparison Table for specific trial and participant numbers 5 comparisons & 52 analyses | lack of benefit for decongestant &/or antihistamine; increased risk of side effects
Thanaviratananich (2008) | KQ3 KQ6 | amox or amox-clav once or twice daily vs three times daily | CENTRAL (TCL, isuue 1, 2008); MEDLINE (Jan 1950–Mar 2008); EMBASE (1974-Mar 2008); Science Citation Index (2001-Mar 2008); NLM Gateway (HSR Project) (Mar 2008); hand search | RCT | AOM ≤12y | Not specified a priori | Clinical cure at end of antibiotic therapy, i.e. 7d and 14 d, with respect to otalgia, fever, bacteriologic cure; also, clinical cure during therapy and post-treatment, recurrent OM, acute mastoiditis, adverse reactions | No | 6 trials total See Comparison Table for specific trial and participant numbers 1 comparison & 8 analyses | evidence appears biased so no data pooling performed; no firm conclusions
Wall (2009) | KQ3 KQ6 | ciprodexotic suspension vs “a comparator” which included ciprofloxacin, ofloxacin, amox-clav | MEDLINE; hand search | Not specified a priori RCTs identified | AOM & acute otitis externa Otherwise bot specified a priori Identified studies included children 6m–12y | Not specified a priori | Not specified a priori Identified studies included clinical outcome “per protocol” and bacteriologic cure | No | 3 trials total See Comparison Table for specific trial and participant numbers | topical fluoroquinolones safe and efficacious in treatment of ear infections

Part 1 Abbreviations and Acronyms: ab= antibiotic; amp/amox=ampicillin or amoxicillin; amox=amoxicillin; amox-clav=amoxillin-clavulanate; CENTRAL=Cochrane Central Register of Controlled Trials; CINAHL=Cumulative Index to Nursing & Allied Health Literature CI= confidence interval; ciprodex=ciprofloxacin 0.3%/desmethasone 0.1%; Contra Otitis=contralateral otitis; HlthSTAR=HealthSTAR; IPA= International Pharmaceutical Abstracts; KQ=key question for Management of AOM Update; MEE=middle ear effusion; Rx=treatment; TCL=The Cochrane Library

1 For quality score of each systematic review, see next table.

2 Also, reference Takata, Chan, Shekelle, et al. (2001)

3 individual patient data meta-analyses

4 Ten trials identified; investigators of only six of the trials agreed to share their data.

Part 2 Systematic Reviews Quality

(AMSTAR: See Appendix)

Author (year) | a priori design | duplicate data extraction | comprehensive literature search | publication status | list of studies | provision of study characteristics | study quality assessed | study quality used | findings combined appropriately | publication bias assessed | conflict of interest
Marcy (2001) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Rosenfeld (1994) | Yes | Yes | No^6^ | Yes | No^7^ | Yes^8^ | Yes | Yes | Yes | No | No^9^
Damoiseaux (1998) | Yes | No^10^ | Yes | Yes | No^6^ | Yes | Yes | Yes | No | No | No
Kozyrskyj (2000) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Abes (2003) | Yes | Yes | Yes | Yes | Yes^9^ | Yes | Yes | No | Yes | Yes | No
Glasziou (2004) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes^11^ | Yes | No | No^5^
Foxlee (2006) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No^5^
Rovers (2006) | Yes | n/a^12^ | No^13^ | No | No^14^ | Yes | Yes | Yes | Yes | Yes | No^5^
Spurling (2007) | Yes | Yes | Yes^15^ | No^16^ | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Coleman (2008) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No^5^
Thanaviratananich (2008) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Wall (2009) | No | ? | No | No | No | Yes | Yes | No | n/a | n/a | No^5^

AMSTAR=Assessment of Multiple Systematic Reviews (Shea, Grimshaw, Wells, et el, 2007)

5 Conflict of interest was addressed in the systematic review but not in all the included studies.

6 Searched Medline, three months of Current Contents, and extensive hand search

7 Excluded studies were not listed.

8 Study characteristics were summarized in the narrative but characteristics of individual studies were not given in a table.

9 Percent of studies funded in whole or in part was reported, though not clear if all studies reported conflict of interest.

10 Study inclusion was scored by four investigators, but the number of data extractors was not reported.

11 Quality was measured but not used in formulating conclusions or recommendations.

12 This meta-analysis utilized individual patient data.

13 Dates searched were not reported, and the hand search was limited to one symposia series.

14 Excluded studies were not listed

15 Reported hand search was not as extensive as might be expected.

16 Unlike most Cochrane reviews this review does not explicitly state if publications were excluded based on language.

Part 3 Comparison Table Representative Comparisons from Systematic Reviews

Study | Comparison primary subgroup | Outcome | Trials | Participants | OR, RD, RR, or WMD | 95% CI
Marcy (2001) 17 | amp/amox vs no ab | Rx failure 2–7d | 5 | 1518 | RD −12.3% | −21.8 % to −2.8%
| pcn vs amp/amox | Rx failure 7–14d | 3 | 491 | RD 4.5% | −1.8% to 10.7%
| cefaclor vs amp/amox | Rx failure 3–7d | 4 | 185 | RD −5.4% | −15.2% to 4.4%
| | Rx failure 5–21 d | 5 | 315 | RD 0.5% | −5.7% to 6.8%
| cefixime vs amp/amox | Rx failure 10–15d | 4 | 519 | RD −0.1% | −4.2% to 3.9%
| | recurrence 3–5wk | 3 | 144 | RD 1.6% | −5.1 % to 8.4%
| | diarrhea | 5 | 754 | RD 8.4% | 3.8% to 13.1%
| | vomiting | 5 | 754 | RD 2% | 0% to 4%
| | rash | 4 | 714 | RD 5.8% | −2.4% to 13.9%
| ceftriaxone vs amox | Rx failure 5–10d | 3 | 306 | RD 3.4% | −1.6% to 8.5%
| azith vs amox-clav | Rx failure 10–14d | 5 | 1045 | RD 2.1% | −0.6% to 4.8%
| | any adverse effect | 3 | 1366 | RD −19.2% | −29.2% to−9.2%
| | GI adverse effect | 3 | 1366 | RD −18.0% | −28.0% to−8.0%
Rosenfeld (1994) 18 | pcn vs no ab | Rx failure 7–14d | 2 | 242 | RD −15.7% | −26.7% to −4.7%
| aminopcn vs no ab | Rx failure 7–14d | 3 | 386 | RD −12.9% | −19.0% to−6.8%
| any ab vs no ab | Rx failure 7–14d | 4 | 535 | RD −13.7% | −19.2% to−8.2%
| amp vs pcn | Rx failure 7–14d | 3 | 497 | RD −6.8% | −15.2% to 1.5%
| amp vs pcn/ssx | Rx failure 7–14d | 3 | 462 | RD 0.9% | −7.6% to 9.4%
| aminopcn vs ery | Rx failure 7–14d | 3 | 525 | RD 3.1% | −3.9% to 10.2%
| aminopcn vs tmp-smx | Rx failure 7–14d | 2 | 275 | RD 0.2% | −8.8% to 9.2%
| amox vs cefaclor | Rx failure 7–14d | 4 | 453 | RD 6.4% | −10.2 to 22.9%
| amox vs cefixime | Rx failure 7–14d | 3 | 404 | RD −3.9% | −10.4 to 2.6%
| | MEE 30 d | Not reported | Not reported | RD −15.0% | −35.5% to 5.5%
| cefaclor vs ery/ssx | Rx failure 7–14d | 2 | 222 | RD −7.0% | −6.5% to 20.4%
| cefaclor vs amox-clav | Rx failure 7–14d | 5 | 776 | RD 2.8% | −1.3% to 6.8%
| | MEE 30d | Not reported | Not reported | RD 1.6% | −5.1 % to 8.3%
| cefaclor vs cefixime | Rx failure 7–14d | 4 | 966 | RD 1.2% | −2.4% to 4.7%
| | MEE 30d | Not reported | Not reported | RD 1.8% | −19.0% to 22.6%
Damoiseaux (1998) | ab vs no ab <2y old | clinical resolution | 4 | 416 | OR 1.31 | 0.83 to 2.08
Kozyrskyj (2000) 19 | ≤48° ab vs >7d ab | Rx failure ≤1m | 2 | 118 | OR 2.99 | 1.04 to 8.54
| >48°≤7d ab vs >7d ab | Rx failure ≤1m | 12 | 3118 | OR 1.38 | 1.15 to 1.66
| | Rx failure 8–19d | 5 | 1524 | OR 1.52 | 1.17 to 1.98
| | Rx failure 20–30d | 9 | 2115 | OR 1.22 | 0.98 to 1.54
| | Rx failure ≤3m | 5 | 1054 | OR 1.16 | 0.90 to 1.50
| | Rx failure 90d | 2 | 207 | OR 1.16 | 0.65 to 2.06
| | Rx failure 30–40d | 3 | 847 | OR 1.16 | 0.87 to 1.55
| <2y old | Rx failure ≤1m | 3 | 118 | OR 0.71 | 0.30 to 1.64
| ≥2y old | Rx failure ≤1m | 3 | 235 | OR 1.01 | 0.53 to 1.94
| perforated TM | Rx failure ≤1m | 1 | 27 | OR 3.62 | 0.81 to 16.1
| non-perforated TM | Rx failure ≤1m | 1 | 101 | OR 1.06 | 0.40 to 2.75
| include chronic OM | Rx failure ≤1m | 9 | 2220 | OR 1.39 | 1.15 to 1.70
| exclude chronic OM | Rx failure ≤1m | 3 | 898 | OR 1.29 | 0.76 to 2.20
| include chronic OM | Rx failure 20–30d | 7 | 1459 | OR 1.19 | 0.93 to 1.51
| exclude chronic OM | Rx failure 20–30d | 2 | 656 | OR 1.55 | 0.79 to 3.04
| only “cured” | Rx failure ≤1m | 11 | 3062 | OR 1.35 | 1.14 to 1.59
| only “cured” | Rx failure 20–30d | 8 | 2059 | OR 1.24 | 1.01 to 1.54
| | GI adverse effects | 10 | 3576 | OR 0.54 | 0.43 to 0.66
| excluding amox-clav | GI adverse effects | 7 | 2131 | OR 1.13 | 0.81 to 1.57
| ceftriaxone | Rx failure ≤1m | 3 | 671 | OR 1.25 | 0.90 to 1.72
| | Rx failure ≤3m | 2 | 312 | OR 0.91 | 0.57 to 1.47
| | GI adverse effects | 1 | 402 | OR 2.89 | 1.70 to 4.91
| azithromycin 3–5d | Rx failure ≤1m | 11 | 2593 | OR 1.09 | 0.86 to 1.38
| | Rx failure 8–19d | 10 | 2569 | OR 1.11 | 0.82 to 1.51
| | Rx failure 20–30d | 6 | 1254 | OR 1.02 | 0.78 to 1.34
Kozyrskyj (2000) | <2y old | Rx failure ≤1m | 2 | 138 | OR 1.92 | 0.73 to 5.04
| ≥2y old | Rx failure ≤1m | 2 | 656 | OR 1.34 | 0.61 to 2.94
| Rx 3d | Rx failure ≤1m | 8 | 1558 | OR 1.17 | 0.71 to 1.92
| include chronic OM | Rx failure ≤1m | 7 | 1688 | OR 0.96 | 0.70 to 1.31
| exclude chronic OM | Rx failure ≤1m | 4 | 905 | OR 1.29 | 0.89 to 1.85
| include chronic OM | Rx failure 20–30d | 4 | 740 | OR 0.83 | 0.57 to 1.21
| exclude chronic OM | Rx failure 20–30d | 2 | 514 | OR 1.27 | 0.86 to 1.86
| only “cured” | Rx failure 20–30d | 4 | 728 | OR 0.83 | 0.59 to 1.16
| only “cured” | Rx failure ≤1m | 9 | 2067 | OR 0.70 | 0.57 to 0.87
| | GI adverse effects | 9 | 2818 | OR 0.26 | 0.19 to 0.37
Abes (2003) | Ofloxacin otic solution vs other medical treatment | Cure rate | 9 | 1290 | OR 2.67 | 2.04, 3.50
| | Otalgia resolution rate | 4 | 231 | OR 2.41 | 1.20, 4.82
| | Otorrhea resolution rate | 11 | 1266 | OR 2.78 | 2.12, 3.65
| | Any adverse event | 4 | 647 | OR 0.28 | 0.19, 0.42
| | Bacterial eradication rate | 6 | 488 | OR 3.86 | 2.54, 5.87
| Ofloxacin otic solution vs otic solutions containing antibiotics and steroids | Cure rate | 4 | 322 | OR 2.73 | 1.52, 4.90
| Ofloxacin otic solution vs oral systemic antibiotics | Otorrhea resolution rate | 3 | 421 | OR 2.78 | 2.12, 3.65
Glasziou (2004) | ab vs no ab | pain 24h | 4 | 717 | OR 1.03 | 0.76 to 1.39
| | pain 2–7d | 9 | 2287 | OR 0.57 | 0.45 to 0.73
| | abnl tympanogram 1m | 3 | 472 | OR 0.91 | 0.62 to 1.32
| | abnl tympanogram 3m | 2 | 370 | OR 0.75 | 0.47 to 1.21
| | perforation | 2 | 381 | OR 0.51 | 0.20 to 1.26
| | vomiting, diarrhea, rash | 4 | 938 | OR 1.94 | 1.28 to 2.94
| | contralateral otitis | 3 | 666 | OR 0.45 | 0.16 to 1.23
| | late recurrence | 5 | 1669 | OR 1.00 | 0.78 to 1.26
Foxlee (2006) 20 | top anaesth vs placebo | 25% ↓ pain 10min | 1 | 27 | RR 1.18 | 0.65 to 2.15
| | 25% ↓ pain 20min | 1 | 27 | RR 1.24 | 0.87 to 1.76
| | 25% ↓ pain 30min^21^ | 1 | 27 | RR 1.37 | 1.06 to 1.77
Rovers (2006)^22,23^ | ab vs no ab | pain &/or fever 3–7d | 6 | 1643 | RD −13% | −17% to −9%
| <2y old | pain &/or fever 3–7d | 6 | 567 | RD −15% | −23% to −7%
| ≥2y old | pain &/or fever 3–7d | 6 | 1076 | RD −11% | −16% to −6%
| unilateral | pain &/or fever 3–7d | 6 | 872 | RD −6% | −12% to 0%
| bilateral | pain &/or fever 3–7d | 6 | 456 | RD −20% | −28% to −11 %
| <2y old & bilateral | pain &/or fever 3–7d | 6 | 273 | RD −25% | −36% to −14%
| <2y old & unilateral | pain &/or fever 3–7d | 6 | 261 | RD −5% | −17% to 7%
| ≥2y old & bilateral | pain &/or fever 3–7d | 6 | 183 | RD −12% | −25% to 1 %
| ≥2y old & unilateral | pain &/or fever 3–7d | 6 | 611 | RD −7% | −14% to 0%
| otorrhea | pain &/or fever 3–7d | 6 | 116 | RD −36% | −53% to −19%
| no otorrhea | pain &/or fever 3–7d | 6 | 439 | RD −14% | −23% to −5%
Spurling (2007) | delayed ab vs imm ab | pain 3d | 1 | 212 | OR 1.93 | 0.96 to 3.88
| | pain 4–6d | 1 | 265 | OR 0.89 | 0.54 to 1.48
| | pain 7d | 1 | 212 | OR 6.55 | 0.33 to 128.35
| | pain severity 3d | 1 | 213 | WMD 0.75 | 0.26 to 1.24
| | pain severity 7d | 1 | 212 | WMD 0.12 | −0.04 to 0.28
| | malaise 3d | 1 | 285 | OR 2.62 | 1.44 to 4.76
| | malaise severity 3d | 1 | 284 | WMD 0.43 | −0.11 to 0.75
| | malaise severity 7d | 1 | 285 | WMD 0.69 | 0.31 to 1.07
| | fever 4–6d | 1 | 265 | OR 0.88 | 0.53 to 1.47
Coleman (2008) 24 | decong/antihist vs none | persisting AOM 2wk | 12 | 2300 | OR 0.80 | 0.63 to 1.00
| | persisting AOM <7d | 2 | 143 | OR 0.83 | 0.36 to 1.91
| | persisting AOM >2wk | 3 | 378 | OR 1.39 | 0.69 to 2.80
| | otalgia | 2 | 287 | OR 0.79 | 0.43 to 1.47
| | fever | 1 | 98 | OR 3.90 | 0.05 to 330.46
| | hearing loss | 2 | 976 | OR 1.45 | 0.58 to 3.61
| | drowsy | 2 | 567 | OR 8.68 | 0.53 to 143.30
| | hyperactivity | 3 | 251 | OR 0.79 | 0.10 to 5.94
| | other side effect | 3 | 416 | OR 5.00 | 1.73 to 14.48
| | prolonged OM 8–12wk | 1 | 106 | OR 0.83 | 0.25 to 2.74
| | recurrent AOM <2wk | 5 | 997 | OR 0.95 | 0.57 to 1.57
| | required surgery | 4 | 1172 | OR 1.28 | 0.67 to 2.46
| | mastoiditis or meningitis | 2 | 662 | OR not estimable | not estimable
Thanaviratananich (2008) | once or twice vs thrice daily | clinical cure at end of therapy | 5 | 1601 | RR 0.96 to 1.21 (not combined) | n/a
| | clinical cure at follow-up | 3 | 1362 | RR 0.93 to 1.00 (not combined) | n/a
| | overall adverse effects | 2 | 878 | RR 0.67 and 1.19 (not combined) | n/a
| | specific adverse effects
| | diarrhea | 2 | 878 | RR 0.63 and 0.80 (not combined) | n/a
| | skin adverse effects | 1 | 575 | RR 0.77 | 0.46 to 1.29
| | Compliance rate | 4 | 1520 | RR 0.0 to 1.14 (not combined) | n/a
| | persistent middle ear effusion at follow-up, 30d | 1 | 100 | RR 0.93 | 0.73 to 1.19
| | persistent middle ear effusion at follow-up, 60d | 1 | 100 | RR 0.98 | 0.98 to 1.35
| | persistent middle ear effusion at follow-up, 90d | 1 | 100 | RR 0.82 | 0.54 to 1.25
Wall (2009) | ciprodex vs “comparator” | clinical outcome | 3 | 880 | (not combined) | n/a
| | bacteriologic cure | 3 | 880 | (not combined) | n/a

Part 3 Abbreviations and Acronyms: ab=antibiotic; abnl=abnormal; amox-clav=amoxicillin-clavulanate; amp/amox=ampicillin or amoxicillin; azith=azithromycin; CI= confidence interval; ciprodex=ciprofloxacin 0.3%/desmethasone 0.1%’ ery=erythromycin; GI= gastrointestinal; imm=immediate; OM=otitis media; OR=odds ratio; pcn=penicillin; RD=rate difference; RR= relative risk; ssx=sulfisoxazole; TM=tympanic membrane; TMP-SMX=trimethoprim-sulfamethoxazole; top=topical; WMD-weighted mean difference

17 Sensitivity analyses deleting or including problematic articles were also reported but are not listed in this table.

18 Sensitivity analysis by AOM diagnostic specificity was also reported but is not listed in this table.

19 Subgroup analyses by quality and sensitivity analyses excluding trials comparing different antibiotics were also reported but are not listed in this table.

20 Results for analyses comparing topical anaesthetic and naturopathic drops were also reported but apparently the studies showed significant heterogeneity and are not included in this table.

21 Measuring 50% pain reduction at 10, 20, and 30 minutes showed no difference.

22 individual patient data meta-analyses

23 Results of analyses for pain alone at 3–7 days with subgroup analyses and fever alone at 3–7 days without subgroups analyses were also reported but are not included in this table.

24 Analyses for decongestant and antihistamine alone and for decongestant and antihistamine together as well as subgroup analyses by primary outcome by various quality criteria, route of medication, and method to diagnose AOM resolution were also reported but are not included in this table.

Appendix AMSTAR Quality Indicators

(Shea, Grimshaw, Wells, et al, 2007)

1. Was an ‘a priori’ design provided? The research question and inclusion criteria should be established before the conduct of the review. | □Yes □No □Can’t answer □Not applicable
2. Was there duplicate study selection and data extraction? There should be at least two independent data extractors and a consensus procedure for disagreements should be in place. | □Yes □No □Can’t answer □Not applicable
3. Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g. Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and where feasible the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found. | □Yes □No □Can’t answer □Not applicable
4. Was the status of publication (i.e. grey literature) used as an inclusion criterion? The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language etc. | □Yes □No □Can’t answer □Not applicable
5. Was a list of studies (included and excluded) provided? A list of included and excluded studies should be provided. | □Yes □No □Can’t answer □Not applicable
6. Were the characteristics of the included studies provided? In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed e.g. age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases should be reported. | □Yes □No □Can’t answer □Not applicable
7. Was the scientific quality of the included studies assessed and documented? ‘A priori’ methods of assessment should be provided (e.g., for effectiveness studies if the author(s) chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies alternative items will be relevant. | □Yes □No □Can’t answer □Not applicable
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating recommendations. | □Yes □No □Can’t answer □Not applicable
9. Were the methods used to combine the findings of studies appropriate? For the pooled results, a test should be done to ensure the studies were combinable, to assess their homogeneity (i.e. Chi-squared test for homogeneity, I^2^). If heterogeneity exists a random effects model should be used and/or the clinical appropriateness of combining should be taken into consideration (i.e. is it sensible to combine?). | □Yes □No □Can’t answer □Not applicable
10. Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). | □Yes □No □Can’t answer □Not applicable
11. Was the conflict of interest stated? Potential sources of support should be clearly acknowledged in both the systematic review and the included studies. | □Yes □No □Can’t answer □Not applicable

### References

Abes G, Espallardo N, Tong M, Subramaniam KN, Hermani B, Lasiminigrum L, Anggraeni R. A systematic review of the effectiveness of ofloaxin otic solution for the treatment of suppurative otitis media. ORL. 2003;65:106-116. [pmid: 12824733].
Coleman C, Moore M. Decongestants and antihistamines for acute otitis media in children. Cochrane Database Syst Rev. 2008;(3):CD001727. [pmid: 18646076].
Damoiseaux RA, van Balen FA, Hoes AW, de Melker RA. 1998. Antibiotic treatment of acute otitis media in children under two years of age: evidence based?. Br J Gen Pract. 1998;48(437):1861-1864. [pmid: 10198511].
Foxlee R, Johansson A, Wejfalk J, Dawkins J, Dooley L, Del Mar CB. Topical analgesia for acute otitis media. Cochrane Database Syst Rev. 2006;(3):CD005657. [pmid: 16856108].
Glasziou PP, Del Mar CB, Sanders SL, Hayem M. Antibiotics for acute otitis media in children. Cochrane Database Syst Rev. 2004;(1):CD000219. [pmid: 14973951].
Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SE, Wincott JL, Sitar DS, Klassen TP, Moffatt ME. Short course antibiotics for acute otitis media. Cochrane Database Syst Rev. 2000;(2):CD001095. [pmid: 10796591].
Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
Rosenfeld RM, Vertrees JE, Carr J, Cipolle RJ, Uden DL, Biebink GS, Canafax DM. Clinical efficacy of antimicrobial drugs for acute otitis media: metaanalysis of 5400 children from thirty-three randomized trials. J Pediatr. 1994;124:355-367. [pmid: 8120703].
Rovers MM, Glasziou P, Appelman CL, Burke P, McCormick DP, Damoiseaux RA, Gaboury I, Little P, Hoes AW. Antibiotics for acute otitis media: a meta-analysis with individual patient data. Lancet. 2006;368(9545):1429-1435. [pmid: 17055944].
Shea BJ, Grimshaw JM, Wells GA, Boers M, Anderson A, Hamel C, Porter AC, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodologic quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
Spurling GK, Del Mar CB, Dooley L, Foxlee R. Delayed antibiotics for respiratory infections. Cochrane Database Syst Rev. 2007;(3):CD004417. [pmid: 17636757].
Takata GS, Chan LS, Shekelle P, Morton SC, Mason W, Marcy SM. Evidence assessment of management of acute otitis media: I. The role of antibiotics in treatment of uncomplicated acute otitis media. Pediatrics. 2001;108:239-247. [pmid: 11483783].
Thanaviratananich S, Laopaiboon M, Vatanasapt P. Once or twice daily versus three times daily amoxicillin with or without clavulanate for the treatment of acute otitis media. Cochrane Database of Systematic Reviews. 2008;(4). Art. No.: CD004975. [doi: 10.1002/14651858.CD004975.pub2].
Wall GM, Stroman DW, Roland PS, Dohar J. Ciprofloxacin 0.3%/desamethasone 0.1% sterile otic suspension for the topical treatment of ear infections: a review of the literature. Pediatr Infect Dis J. 2009;28:141-144. [pmid: 19116600].
Whitlock EP, Lin JS, Chou R, Shekelle P, Robinson KA. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776-782. [pmid: 18490690].

## Key Question 4

This document is a summary of the systematic reviews that have relevance to Key Question 4 (KQ4) in the present Workplan. It consists of 3 parts: Part 1 contains the characteristics of the systematic reviews and the highlighted conclusions; Part 2 contains our assessment of the quality of the systematic reviews using AMSTAR quality indicators; and Part 3 provides representative quantitative outcomes of the comparisons contained in the systematic reviews. Finally, we include references and the AMSTAR instrument.

We searched Medline from 1998 through the present and identified reviews that have relevance to KQ4 for the AOM update. We searched the Cochrane Review database to the present. We also searched the Web of Science 1980–1997 and did hand searches of reference lists of study articles identified for inclusion in the AOM update.

Based on the general conclusions of these reviews we believe that we are justified in doing a systematic review for KQ4. We have also noted the studies included in these systematic reviews for possible inclusion in the present systematic review

Part 1 Relevance to Key Question 4 of the Management of Acute Otitis Media Update^1^

Author (year) | Content category by KQ | Review focus | Databases and included dates | Study design, inclusion criteria | Target population | Setting | Outcomes | Cost analsis | Number of trials, participants, and comparisons | Author’s highlight conclusion
Straetemans (2004) | KQ4 | PPV & PCV to prevent AOM | CENTRAL (TCL, Issue 2, 2003); MEDLINE (Jan 1966–Jun 2003; EMBASE (Jan 1990–June 2003); hand search | RCT | 0–12y exclude follow-up <6m after vaccination | not specified a priori | AOM total number; proportion of children with AOM; bacterial culture results | No | 8 trials on PPV & 4 trials on PCV | PPV makes a small difference in AOM for children >2y or with AOM history; PCV reduces number of children with ROM; pneumococcal vaccine does not benefit children with ROM <1y old
Leach (2008) | KQ4 | long-term* ab vs placebo or no treatment to prevent any AOM, AOM with perforation, CSOM | CENTRAL (TCL, Issue 1, 2006); MEDLINE (Jan 1966–March week 3 2006); OLD MEDLINE (1950–1965); EMBASE (1990-Dec 2005); hand search | RCT long-term ab ≥6-weeks ab | 0–18 y at increased risk for future AOM episodes* exclude immunodeficiency, craniofacial abnormalities, undergoing tympanostomy tube insertion, or other ENT surgery *otitis prone ≥3 AOM in 6 months or ≥4 AOM in 1 year; high- risk children with history of AOM with perforation; children in high-risk populations with CSOM prevalence ≥4% | not specified a priori | Primary outcomes:; 1. Any AOM/CSOM during intervention; 2. #episodes of AOM/CSOM during intervention per child-year; Secondary outcomes:; 1. recurring AOM/CSOM during intervention;; 2. any AOM/CSOM at the end of intervention;; 3. any SOM/CSOM following cessation of intervention;; 4. episodes of illness during intervention,; 5. any clinical side effects during intervention; 6. any antibiotic resistance during intervention. | No | Primary outcome #1: 13 studies 1358 children Primary outcome #2: 12 studies, 1112 children Secondary outcome #1: 5 studies, 329 children Secondary outcome #2: 0 studies Secondary outcome #3: 1 study, 117 children Secondary outcome #4: 0 studies. Secondary outcome #5: 11 studies, 715 children Secondary outcome #6: 2 studies, 181 children | Long-term ab reduce AOM probability while on treatment
McDonald (2008) | KQ4 | ventilation tube vs non- surgical treatment* to reduce ROM and ear disease symptoms *antibiotics/other treatment/no treatment | CENTRAL (TCL, Issue 1, 2008); MEDLINE (1950-March 2008); EMBASE (1974-March 2008); CINAHL; mRCT; NRR; LILACS; KoreaMed; IndMed; PakMediNet; Zetoc; ISI Proceedings; Cambridge Scientific Abstracts; hand search (last search date Mar 2008) | RCT | 0–16y with ROM* *≥3 AOM in 6 months or ≥4 AOM in 1 year | not specified a priori | Primary outcome #1: AOM frequency following treatment Primary outcome #2: proportion of children with ROM following treatment Secondary outcome #1: change in symptom scores for otalgia and otorrhoea Secondary outcome #2: alteration in frequency of otalgia and otorhoea Secondary outcome #3: # days at nursery/school lost secondary to AOM | No | 2 studies 148 children | Ventilation tube plays significant role to maintain a disease- free state in the first six months after tube insertion.
Bonati (1992) | KQ4 | Assess the efficacy of antibiotic prophylaxis in reducing Recurrent Acute Otitis Media (RAOM) | MEDLINE (1966 through 1991) and bibliographies of the articles | RCT English language | Patients with 3 or more documented episodes of RAOM;. Diagnosed on the basis of tympanic membrane exam, and who had received continued antimicrobial prophylaxis. | Not specified | Acute otitis media rate | No | 8 studies 420 children | Established the effectiveness of chemoprophylaxis in reducing the episodes of acute otitis media during the winter and spring months
Williams (1993) | KQ4 | Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion. (We will review only the studies on recurrent acute otitis media) | MEDLINE (1966 through April 1993) Current Contents (1990 through 1992) Textbooks, monographs. | RCT | Recurrent acute otitis media or Otitis media with effusion | Not specified | Number of episodes of AOM per patient-month while under treatment | None | 9 studies 958 subjects | Antibiotics appear to have beneficial but limited effect on recurrent otitis media

Part 1 Abbreviations and Acronyms: ab=antibiotic; amp/amox=ampicillin or amoxicillin; CENTRAL=Cochrane Central Register of Controlled Trials; CINAHL=Cumulative Index to Nursing & Allied Health Literature CI=confidence interval; Contra Otitis=contralateral otitis; CSOM=chronic suppurative otitis media; ENT=ear, nose, and throat; HlthSTAR=HealthSTAR; IPA=International Pharmaceutical Abstracts; KQ=key question for Management of AOM Update; MEE=middle ear effusion; mRCT=metaResgister, NRR=National Research Register; Rx=treatment; PCV=pneumococcal conjugated vaccines; PPV=pneumococcal polysaccharide vaccines; ROM=recurrent otitis media; TCL= The Cochrane Library

1 For quality score of each systematic review, see next table.

Part 2 Systematic Reviews Quality

(AMSTAR: See Appendix)

Author (year) | a priori design | duplicate data extraction | comprehensive literature search | publication status | list of studies | provision of study characteristics | study quality assessed | study quality used | findings combined appropriately | publication bias assessed | conflict of interest
Straetemans (2004) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes^2^ | Yes | No^3^
Leach (2008) | Yes | Yes | Yes | Yes^4^ | Yes | Yes | Yes | Yes | Yes^5^ | Yes | No^6^
McDonald (2008) | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes^7^ | No | No^8^
Bonati (1992) | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | No | No
Williams (1993) | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No | No

AMSTAR=Assessment of Multiple Systematic Reviews (Shea, Grimshaw, Wells, et al 2007)

2 Sensitivity analyses by study quality

3 Conflict of interest was addressed for the systematic review but not for the included studies.

4 Language was not a restriction; other publication issues not stated

5 Sensitivity analyses by study quality

6 Conflict of interest was addressed for the systematic review but not for the included studies.

7 Excluded studies from analysis based on quality component scores.

8 Conflict of interest was addressed for the systematic review but not for the included studies.

Part 3 Comparison Table: Representative Comparisons from Systematic Reviews

Study | Comparison primary subgroup | Outcome | Trials (Citations) | # Participants or Person-months | IRR, OR, RD, RR, or WMD | 95% CI
Straetemans (2004) | PPV vs control | Proportion children with AOM | 7 (6) | 5,495 | RR 0.94 | 0.86 to 1.03
| <24m | Proportion children with AOM | 4 | 3,578 | RR 0.98 | 0.87 to 1.11
| >24m | Proportion children with AOM | 2 | 759 | RR 0.84 | 0.65 to 1.09
| 6–54m | Proportion children with AOM | 1 | 1,158 | RR 0.90 | 0.77 to 1.06
| | AOM episodes due to vaccine type per person month | 3 | 47,905 | RR 0.72 | 0.43 to 1.21
| | AOM episodes due to non-vaccine type per person month | 3 | 47,905 | RR 0.91 | 0.60 to 1.39
| | AOM episodes per person month | 12 (8) | 80,115 | RR 0.88 | 0.79 to 0.97
| <24m | AOM episodes per person month | 7 | 56,575 | RR 0.93 | 0.84 to 1.04
| >24m | AOM episodes per person month | 5 | 23,540 | RR 0.77 | 0.67 to 0.89
| without previous AOM | AOM episodes per person month | 4 (3) | 59,333 | RR 0.91 | 0.82 to 1.01
| <24m | AOM episodes per person month | 2 | 45,003 | RR 0.94 | 0.87 to 1.02
| >24m | AOM episodes per person month | 2 | 14,330 | RR 0.74 | 0.47 to 1.17
| with previous AOM | AOM episodes per person month | 5 | 17,512 | RR 0.80 | 0.69 to 0.93
| <24m | AOM episodes per person month | 3 | 9,004 | RR 0.85 | 0.71 to 1.02
| >24m | AOM episodes per person month | 3 | 8,508 | RR .074 | 0.59 to 0.93
| PCV vs control | Proportion children with frequent AOM | 1 | 1,662 | RR 0.91 | 0.75 to 1.10
| | AOM episodes per person month | 4 | 1,282,598 | RR 0.97 | 0.87 to 1.08
| | AOM episodes due to vaccine-type per person month | 2 | 32,353 | RR 0.43 | 0.34 to 0.54
| | AOM episodes due to non-vaccine type per person month | 2 | 32,353 | RR 1.22 | 0.84 to 1.75
| | AOM episodes per person month in specific population | 2 | 11,441 | RR 1.05 | 0.66 to 1.67
Leach (2008) | ab vs control | any AOM or CSOM during intervention | 13 | 1,358 | RR 0.62 | 0.52 to 0.75
| <12m | “ | 1 | 117 | RR 0.60 | 0.42 to 0.84
| >12m | “ | 1 | 21 | RR 0.06 | 0.00 to 0.99
| Age not separated | “ | 11 | 1190 | RR 0.70 | 0.59 to 0.84
| otitis prone | “ | 7 | 636 | RR 0.72 | 0.62 to 0.84
| non-otitis prone | “ | 1 | 117 | RR 0.60 | 0.42 to 0.84
| Otitis proneness not separated | “ | 5 | 603 | RR 0.49 | 0.38 to 0.63
| high-risk population | “ | 1 | 364 | RR 0.61 | 0.44 to 0.84
| not high-risk population | “ | 12 | 994 | RR 0.62 | 0.51 to 0.76
| high quality randomization and allocation concealment | “ | 7 | 677 | RR 0.71 | 0.56 to 0.89
| not high quality randomization and allocation concealment | “ | 6 | 681 | RR 0.53 | 0.40 to 0.69
| high quality of blinding outcome assessment | “ | 11 | 1,277 | RR 0.65 | 0.55 to 0.77
| high quality for all six criteria | “ | 3 | 389 | RR 0.61 | 0.50 to 0.76
| <100 participants | “ | 7 | 339 | RR 0.49 | 0.30 to 0.81
| >100 participants | “ | 6 | 1,019 | RR 0.66 | 0.56 to 0.77
| Excluded age >36m | “ | 3 | 391 | RR 0.66 | 0.55 to 0.78
| included age >36m | “ | 10 | 967 | RR 0.58 | 0.43 to 0.77
| otitis prone at entry (2//6 or 3/12) | “ | 6 | 595 | RR 0.68 | 0.54 to 0.85
| less otitis prone at entry (2/6 or 3/18; 1 before 6m age or 2/12) | “ | 5 | 293 | RR 0.50 | 0.29 to 0.88
| free of MEE at entry | “ | 3 | 332 | RR 0.53 | 0.35 to 0.80
| free of MEE at entry not required | “ | 5 | 225 | RR 0.57 | 0.33 to 0.99
| excluded congenital anomalies | “ | 8 | 695 | RR 0.60 | 0.42 to 0.86
| exclusion not described | “ | 5 | 681 | RR 0.61 | 0.51 to 0.71
| conducted in USA | “ | 8 | 1,021 | RR 0.65 | 0.52 to 0.81
| not conducted in USA | “ | 4 | 296 | RR 0.50 | 0.35 to 0.71
| amox, pcn | “ | 8 | 1086 | RR 0.61 | 0.50 to 0.74
| ssx, tmp-smx | “ | 8 | 363 | RR 0.58 | 0.40 to 0.84
| not placebo controlled | “ | 2 | 129 | RR 0.28 | 0.02 to 3.69
| once daily | “ | 8 | 1131 | RR 0.61 | 0.52 to 0.72
| twice daily | “ | 6 | 286 | RR 0.68 | 0.43 to 1.06
| >3m therapy | “ | 2 | 190 | RR 0.67 | 0.26 to 1.72
| 3–6m therapy | “ | 8 | 532 | RR 0.59 | 0.45 to 0.79
| >6m therapy | “ | 3 | 636 | RR 0.62 | 0.50 to 0.76
| monthly active surveillance | “ | 8 | 997 | RR 0.67 | 0.57 to 0.79
| 4–6 weekly or 3 monthly surveillance | “ | 5 | 311 | RR 0.45 | 0.28 to 0.72
| 1970s | “ | 4 | 474 | RR 0.56 | 0.34 to 0.94
| 1980s | “ | 4 | 411 | RR 0.68 | 0.53 to 0.87
| 1990s | “ | 3 | 324 | RR 0.57 | 0.29 to 1.11
| high compliance | “ | 1 | 171 | RR 0.47 | 0.29 to 0.76
| not high compliance | “ | 1 | 193 | RR 0.77 | 0.50 to 1.19
| | episodes of AOM or CSOM during intervention | 12 | 1,112 | IRR 0.48 | 0.37 to 0.62
| <12m | “ | 1 | 33 | IRR 1.53 | 0.68 to 3.48
| >12m | “ | 2 | 12 | IRR 0.12 | 0.01 to 2.18
| Age not separated | “ | 10 | 1046 | IRR 0.45 | 0.35 to 0.57
| otitis prone | “ | 8 | 796 | IRR 0.52 | 0.37 to 0.73
| Otitis proneness not separated | “ | 4 | 316 | IRR 0.37 | 0.23 to 0.61
| high- risk population | “ | 1 | 224 | IRR 0.52 | 0.39 to 0.70
| not high- risk population | “ | 11 | 888 | IRR 0.51 | 0.30 to 0.87
| high quality randomization and allocation concealment | “ | 5 | 452 | IRR 0.58 | 0.39 to 0.86
| not high quality randomization and allocation concealment | “ | 7 | 660 | IRR 0.43 | 0.31 to 0.59
| high quality of blinding outcome assessment | “ | 9 | 821 | IRR 0.55 | 0.43 to 0.70
| high quality for all six criteria | “ | 2 | 284 | IRR 0.41 | 0.20 to 0.83
| <100 participants | “ | 8 | 548 | IRR 0.42 | 0.30 to 0.61
| >100 participants | “ | 4 | 564 | IRR 0.56 | 0.38 to 0.83
| excluded >36m | “ | 2 | 294 | IRR 0.59 | 0.47 to 0.75
| included >36m | “ | 10 | 818 | IRR 0.41 | 0.31 to 0.61
| otitis prone at entry (2//6 or 3/12) | “ | 6 | 627 | IRR 0.47 | 0.30 to 0.72
| less otitis prone at entry (2/6 or 3/18; 1 before 6m age or 2/12/) | “ | 4 | 171 | IRR 0.59 | 0.38 to 0.91
| free of MEE at entry | “ | 3 | 306 | IRR 0.39 | 0.22 to 0.67
| free of MEE at entry not required | “ | 7 | 526 | IRR 0.44 | 0.30 to 0.65
| excluded congenital anomalies | “ | 7 | 507 | IRR 0.53 | 0.37 to 0.76
| exclusion not described | “ | 5 | 605 | IRR 0.41 | 0.27 to 0.64
| conducted in USA | “ | 8 | 946 | IRR 0.50 | 0.36 to 0.70
| not conducted in USA | “ | 3 | 97 | IRR 0.33 | 0.20 to 0.52
| amox, pcn | “ | 6 | 631 | IRR 0.50 | 0.36 to 0.70
| ssx, tmp-smx | “ | 7 | 503 | IRR 0.52 | 0.28 to 0.96
| not placebo controlled | “ | 2 | 269 | IRR 0.27 | 0.19 to 0.39
| once daily | “ | 7 | 701 | IRR 0.53 | 0.39 to 0.71
| twice daily | “ | 6 | 467 | IRR 0.49 | 0.27 to 0.87
| >3m thereapy | “ | 2 | 86 | IRR 0.62 | 0.15 to 2.53
| 3–6 m therapy | “ | 5 | 189 | IRR 0.47 | 0.33 to 0.68
| >6m therapy | “ | 5 | 837 | IRR 0.45 | 0.32 to 0.63
| monthly active surveillance | “ | 7 | 698 | IRR 0.55 | 0.41 to 0.72
| 4–6 weekly or 3 monthly surveillance | “ | 5 | 414 | IRR 0.32 | 0.19 to 0.56
| 1970s | “ | 1 | 43 | IRR 0.50 | 0.26 to 0.98
| 1980s | “ | 3 | 338 | IRR 0.55 | 0.42 to 0.71
| 1990s | “ | 3 | 138 | IRR 0.47 | 0.16 to 1.35
| high compliance | “ | 2 | 140 | IRR 0.36 | 0.24 to 0.54
| not high compliance | “ | 2 | 153 | IRR 0.87 | 0.62 to 1.22
| | any rAOM or CSOM during intervention | 5 | 329 | RR 0.45 | 0.20 to 1.01
| | episodes of illness during intervention | 1 | 730 | RR 0.84 | 0.72 to 0.97
| | any clinical side effects during intervention | 11 | 714 | RR 1.99 | 0.25 to 15.89
| | any antibiotic resistance during intervention | 2 | 181 | RR 1.37 | 0.83 to 2.26
McDonald (2008) | grommets vs control | >1 episode of AOM | 2 | 148 | OR 0.18 | 0.08, 0.42
Bonati (1992) | Antimicrobial prophylaxis vs placebo | Recurrence of acute otitis media | 8 | 420 | OR 0.23 | 0.16 to 0.34
Williams (1993) | Antibiotics vs placebo | Recurrence rate (as defined above) | 9 | 958 | RD 0.11 | 0.03 to 0.19

Part 3 Abbreviations and Acronyms: ab= antibiotic; abnl= abnormal; amox-clav=amoxicillin-clavulanate; amp/amox=ampicillin or amoxicillin; azith= azithromycin; CI= confidence interval; ery=erythromycin; GI=gastrointestinal; imm=immediate; IRR=incidence rate ratio; OM= otitis media; OR=odds ratio; pcn= penicillin; RD =rate difference; Risk=Risk Ratio; RR= relative risk; ssx= sulfisoxazole; TM=tympanic membrane; TMP-SMX=trimethoprim-sulfamethoxazole; top=topical; WMD-weighted mean difference

Appendix AMSTAR Quality Indicators

(Shea, Grimshaw, Wells, et al, 2007)

1. Was an ‘a priori’ design provided? The research question and inclusion criteria should be established before the conduct of the review. | □Yes □No □Can’t answer □Not applicable
2. Was there duplicate study selection and data extraction? There should be at least two independent data extractors and a consensus procedure for disagreements should be in place. | □Yes □No □Can’t answer □Not applicable
3. Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g. Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and where feasible the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found. | □Yes □No □Can’t answer □Not applicable
4. Was the status of publication (i.e. grey literature) used as an inclusion criterion? The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language etc. | □Yes □No □Can’t answer □Not applicable
5. Was a list of studies (included and excluded) provided? A list of included and excluded studies should be provided. | □Yes □No □Can’t answer □Not applicable
6. Were the characteristics of the included studies provided? In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed e.g. age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases should be reported. | □Yes □No □Can’t answer □Not applicable
7. Was the scientific quality of the included studies assessed and documented? ‘A priori’ methods of assessment should be provided (e.g., for effectiveness studies if the author(s) chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies alternative items will be relevant. | □Yes □No □Can’t answer □Not applicable
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating recommendations. | □Yes □No □Can’t answer □Not applicable
9. Were the methods used to combine the findings of studies appropriate? For the pooled results, a test should be done to ensure the studies were combinable, to assess their homogeneity (i.e. Chi-squared test for homogeneity, I²). If heterogeneity exists a random effects model should be used and/or the clinical appropriateness of combining should be taken into consideration (i.e. is it sensible to combine?). | □Yes □No □Can’t answer □Not applicable
10. Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). | □Yes □No □Can’t answer □Not applicable
11. Was the conflict of interest stated? Potential sources of support should be clearly acknowledged in both the systematic review and the included studies. | □Yes □No □Can’t answer □Not applicable

### References

Bonati M, Marchetti F, Pistotti V, Agostini M, Bisogno G, Bussi R, Davico S, De Santis M, Forno S, Gangemi M, Merlin D, Merlo M, Murgia V, Pivetta S, Raimo F, Tamburlini G. Metaanalysis of antimicrobial prophylaxis for recurrent acute otitis-media. Clinical Trials and Meta-Analysis. 1992;28(1):39-50.
Leach AJ, Morris PS. Antibiotics for the prevention of acute and chronic suppurative otitis media in children. Cochrane Database of Systematic Reviews. 2006;(4). Art. No.: CD004401. [doi: 10.1002/14651858.CD004401.pub2].
McDonald S, Langton Hewer CD, Nunez DA. Grommets (ventilation tubes) for recurrent acute otitis media in children. Cochrane Database of Systematic Reviews. 2008;(4). Art. No.: CD004741. [doi: 10.1002/14651858.CD004741.pub2].
Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
Shea BJ, Grimshaw JM, Wells GA, Boers M, Anderson N, Hamel C, Porter AC, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodologic quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
Straetemans M, Sanders EAM, Veenhoven RH, Schilder AGM, Damoiseaux RAMJ, Zielhuis GA. Pneumococcal vaccines for preventing otitis media. Cochrane Database of Systematic Reviews. 2004;(1). Art.No.: CD001480. [doi: 10.1002/14651858.CD001480.pub2].
Whitlock EP, Lin JS, Chou R, Shekelle P, Robinson KA. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776-782. [pmid: 18490690].
Williams RL, Chalmers TC, Stange KC, Chalmers FT, Bowlin SJ. Use of antibiotics in preventing recurrent acute otitis-media and in treating otitis-media with effusion - a metaanalytic attempt to resolve the brouhaha. JAMA. 1993;270:1344-1351. [pmid: 8141875].