# Summary Tables for Studies Included in Comparisons

Table G.1 Comparisons for AOM1 Key Question 3 and AOM2 Key Question 3 on Antibiotics versus No Antibiotics

The general principle agreed upon was to separate amoxicillin-clavulanate, penicillin G, penicillin V, erythromycin estolate, triple sulfonamide, and erythromycin estolate-triple sulfonamide from ampicillin/amoxicillin and each other. Penicillin G is oxidized in the stomach and not well absorbed. Penicillin V does not cover Haemophilus influenza well. Erythromycin estolate is quite different from the other antibiotics. Triple sulfonamide is no longer in common usage.

Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Ampicillin or amoxicillin | Placebo | 5 | 2 | 7
Amoxicillin-clavulanate | Placebo | 1
Penicillin G plus sulfisoxazole | Placebo | 1
Penicillin V | Placebo | 2
Erythromycin estolate | Placebo | 1
Triple sulfonamide | Placebo | 1
Erythromycin estolate-triple sulfonamide | Placebo | 1

Table G.2 Comparisons for AOM1 Key Question 4a and AOM2 Key Question 3 on Amoxicillin or Trimethoprim-Sulfamethoxazole versus Other Antibiotics

The general principle agreed upon was to compare by individual antibiotic rather than by antibiotic class, spectrum, or pharmacokinetics.

Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Amoxicillin or ampicillin | Penicillin | 3
Amoxicillin or ampicillin | Amoxicillin-clavulanate | 0
Amoxicillin or ampicillin | Cephalexin | 2
Amoxicillin or ampicillin | Cephradine | 1
Amoxicillin or ampicillin | Cefuroxime axetil | 2
Amoxicillin or ampicillin | Cefaclor | 5
Amoxicillin or ampicillin | Loracarbef | 1
Amoxicillin or ampicillin | Cefixime | 5
Amoxicillin or ampicillin | Ceftriaxone | 3 | 1 | 4
Amoxicillin or ampicillin | Erythromycin estolate | 2
Amoxicillin or ampicillin | Clarithromycin | 2
Amoxicillin or ampicillin | Clindamycin | 1
Amoxicillin or ampicillin | Penicillin V and sulfisoxazole | 2
Amoxicillin or ampicillin | Triple sulfonamide | 1
Amoxicillin or ampicillin | Penicillin G plus triple sulfonamide | 1
Amoxicillin or ampicillin | Erythromycin ethylsuccinate- sulfisoxazole | 1
Amoxicillin or ampicillin | Oxytetracycline and procaine penicillin plus benzathine penicillin G injection plus sulfisoxazole | 1

Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Trimethoprim-sulfamethoxazole | Amoxicillin-clavulanate | 1
Trimethoprim-sulfamethoxazole | Cephalexin | 0
Trimethoprim-sulfamethoxazole | Cephradine | 0
Trimethoprim-sulfamethoxazole | Cefuroxime axetil | 0
Trimethoprim-sulfamethoxazole | Cefaclor | 3
Trimethoprim-sulfamethoxazole | Loracarbef | 0
Trimethoprim-sulfamethoxazole | Cefixime | 0
Trimethoprim-sulfamethoxazole | Ceftriaxone | 1
Trimethoprim-sulfamethoxazole | Erythromycin estolate | 0
Trimethoprim-sulfamethoxazole | Erythromycin ethylsuccinate | 0
Trimethoprim-sulfamethoxazole | Clarithromycin | 0
Trimethoprim-sulfamethoxazole | Clindamycin | 0
Trimethoprim-sulfamethoxazole | Penicillin-sulfasoxazole | 0
Trimethoprim-sulfamethoxazole | Erythromycin ethylsuccinate- sulfisoxazole | 0
Trimethoprim-sulfamethoxazole | Erythromycin ethylsuccinate-acetyl sulfafurazole | 0

Table G.3 Comparisons for AOM1 Key Question 4e and AOM2 Key Question 3 on Short-term versus Long-term Antibiotic Therapy

The general principle agreed upon was to compare by individual antibiotic stratified by therapy duration, <5 days versus 5 days.

Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Amoxicillin (<5d) | amoxicillin (7–10d) | 3
Penicillin V (<5d) | penicillin V (7–10d) | 1
Penicillin V (5d, either 25mg/kg/d or 50mg/kg/d) | penicillin V (7–10d) | 1 (two 5- day arms)
Benthazine penicillin G/procaine penicillin G/potassium penicillin G (Bicillin) (1 dose) | tetracycline (7–10d) | 1
Benthazine penicillin G/procaine penicillin G/potassium penicillin G (Bicillin) (1 dose) | benthazine penicillin/procaine penicilliln G/potassium penicillin G (Bicillin) (1 dose) plus triple sulfonamide (7d) | 2
Amoxicillin-clavulanate (5d, either 45mg/kg/d or 80 mg/kg/d) | amoxicillin-clavulanate (7–10d, either 40mg/kg/d or 45mg/kg/d or 80mg/kg/d) | 2
Cefaclor (<5d) | cefaclor (7–10d) | 1
Cefaclor (5d) | amoxicillin (7–10d) | 1
Cefaclor (5d) | cefaclor (7–10d) | 1
Cefuroxime axetil (5d) | amoxicillin-clavulanate (7–10d) | 1 | 1 | 2
Cefuroxime axetil (5d) | cefixime (7–10d) | 1
Cefpodoxime proxetil (5d) | amoxicillin-clavulanate (7–10d) | 2
Cefpodoxime proxetil (5d) | cefaclor (7–10d) | 1
Cefpodoxime proxetil (5d) | cefixime (7–10d) | 1
Cefprozil (5d) | cefprozil (7–10d) | 1
Ceftibuten (5d) | ceftibuten (10d) | 1
Ceftriaxone (1 dose) | amoxicillin (7–10d) | 3
Ceftriaxone (1 dose) | amoxicillin-clavulanate (7–10d) | 2 | 3 | 5
Ceftriaxone (1 dose) | cefaclor (7–10d) | 1
Ceftriaxone (1 dose) | cefuroxime axetil (7–10d) | 1
Ceftriaxone (1 dose) | trimethroprim-sulfamethoxazole (7–10d) | 1
Azithromycin (<5d) | amoxicillin-clavulanate (7–10d, either 40mg/kg/d or 45mg/kg/d) | 5 | 4 | 9
Azithromycin (<5d) | cefaclor (7–10d) | 2 | 2 | 4
Azithromycin (<5d) | clarithromycin (7–10d) | 1
Azithromycin (5d) | amoxicillin-clavulanate (7–10d) | 3
Cefdinir (5d) | amoxicillin-clavulanate (10d) | 0 | 2 | 2
Cefprozil (10d) | cefdinir (5d) | 0 | 1 | 1
Cefpodoxime (5d) | cefpodoxime (10d) | 0 | 1 | 1

Table G.4 Comparisons for AOM2 Key Question 3 But Not in AOM1

(i) For Uncomplicated Acute Otitis Media
Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Amoxicillin-clavulanate | Amoxicillin Sulbactam | 0 | 1 | 1
Amoxicillin-clavulanate | Cefaclor | 0 | 1 | 1
Amoxicillin-clavulanate | Cefdinir: 14 mg | 0 | 2 | 2
Amoxicillin-clavulanate | Cefdinir: 7 mg | 0 | 2 | 2
Amoxicillin-clavulanate | Cefprozil | 0 | 1 | 1
Amoxicillin-clavulanate | Ciprodex drops | 0 | 1 | 1
Amoxicillin-clavulanate: 40 mg 10 d | Amoxicillin-clavulanate: 80 mg 8 d | 0 | 1 | 1
Amoxicillin-clavulanate: 40/10 mg | Amoxicillin-clavulanate: 45/6.4 mg | 0 | 1 | 1
Amoxicillin-clavulanate: 45/6.4 mg 10 d | Amoxicillin-clavulanate: 90/6.4 mg 10 d | 0 | 1 | 1
Amoxicillin-clavulanate: 80 mg | Cefuroxime | 0 | 1 | 1
Amoxicillin | Azithromycin | 0 | 1 | 1
Amoxicillin | Prescription to Hold | 0 | 2 | 2
Amoxicillin | Wait and see | 0 | 1 | 1
Amoxicillin/NHED | Amoxicillin/Topical anesthetic nos | 0 | 1 | 1
Amoxicillin/NHED | NHED | 0 | 1 | 1
Amoxicillin/NHED | Topical anesthetic nos | 0 | 1 | 1
Amoxicillin/Topical anesthetic nos | NHED | 0 | 1 | 1
Amoxicillin/Topical anesthetic nos | Topical anesthetic nos | 0 | 1 | 1
Amoxicillin: 40–45 mg | Amoxicillin: 80–90 mg | 0 | 1 | 1
Amoxicillin: 80 mg | Amoxicillin: 80 mg/Fenspiride | 0 | 1 | 1
Antibiotic | Prescription to Hold | 0 | 1 | 1
Antihistamine/Ceftriaxone | Antihistamine/Ceftriaxone/Prednisolone | 0 | 1 | 1
Antihistamine/Ceftriaxone | Ceftriaxone | 0 | 1 | 1
Antihistamine/Ceftriaxone | Ceftriaxone/Prednisolone | 0 | 1 | 1
Antihistamine/Ceftriaxone/Prednisolone | Ceftriaxone | 0 | 1 | 1
Antihistamine/Ceftriaxone/Prednisolone | Ceftriaxone/Prednisolone | 0 | 1 | 1
Aqueous lidocaine | Placebo | 0 | 1 | 1
Azithromycin | Cefdinir | 0 | 1 | 1
Azithromycin | Ceftriaxone | 0 | 1 | 1
Cefaclor | Cefpodoxime | 0 | 1 | 1
Cefaclor | Cefprozil | 0 | 1 | 1
Cefaclor | Cefuroxime | 0 | 1 | 1
Cefdinir: 14 mg | Cefdinir: 7 mg | 0 | 2 | 2
Ceftriaxone | Ceftriaxone/Prednisolone | 0 | 1 | 1
Ciprofloxacin otic 3% | Ciprodex drops | 0 | 1 | 1
Ciprodex drops | Ofloxacin drops | 0 | 1 | 1
Homeopathic NOS | Placebo | 0 | 1 | 1
NHED | Topical anesthetic nos | 0 | 1 | 1
Otikon drops | Topical anesthetic nos | 0 | 1 | 1
Phenoxymethylpenicilin | Wait and see | 0 | 1 | 1
Prescription to Hold | Wait and see | 0 | 1 | 1

(ii) For Treatment of Acute Otitis Media in Recurrent Otitis Media
Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Amoxicillin-clavulanate | Azithromycin | 0 | 1 | 1
Amoxicillin-clavulanate | Gatifloxacin | 0 | 2 | 2
Amoxicillin-clavulanate | Levofloxacin | 0 | 1 | 1

(iii) For Prevention of Acute Otitis Media in Recurrent Otitis Media
Treatment A | Treatment B | # Studies in AOM1 | # Studies in AOM2 | Total
Adenoidectomy | Adenoidectomy and/or tonsillectomy | 0 | 1 | 1
Adenoidectomy | Placebo | 0 | 2 | 2
Adenoidectomy | Sulfa alone | 0 | 1 | 1
Adenoidectomy and/or tonsillectomy | Placebo | 0 | 1 | 1
Adenoidectomy/Tympanostomy tubes | Tympanostomy tubes | 0 | 1 | 1
Amoxicillin | Azithromycin | 0 | 1 | 1
Amoxicillin | Placebo | 0 | 1 | 1
Amoxicillin | Sulfa alone | 0 | 1 | 1
Ceftibuten: 9 mg - 10 days | Ceftibuten: 9 mg - 5 days | 0 | 1 | 1
Probiotic bacteria | Placebo | 0 | 1 | 1
Sulfa alone | Placebo | 0 | 2 | 2