# Technical Expert Panel Composition and Meeting Summaries

Table F-1 Technical Expert Panel Composition

Name, Affiliation, | Contact information/ Nominating Organization
Margaretha Casselbrant, MD, PhD Chair, Dept of Pediatric Otolaryngology University of Pittsburgh | Childrens Hospital of Pittsburgh Dept of Pediatric Otolaryngology 3705 5th Ave Ste 1650 Pittsburgh, PA 15213-2524 Email: cassml@chp.edu Society for Ear Nose Throat Advances in Children
Tasnee Chonmaitree, M.D. Professor, Pediatrics and Pathology Director, Pediatric Infectious Disease Fellowship Program Associate Director, UTMB Clinical Research Education Office University of Texas Medical Branch | University of Texas Medical Branch 301 University Blvd. Galveston, TX 77555-0371 Phone: (409) 772-4876 Fax: (409) 747-1753 E-mail: Tchonmai@utmb.edu Pediatric Infectious Disease Society
Katherine Finn Davis, PhD Coordinator for Nursing Research and Practice Center for Pediatric Nursing Research & Evidence Based Practice, Children’s Hospital of Philadelphia | E-mail: kfinndavis@yahoo.com cc correspondance to: pnp.representative@napnap.org National Association of Pediatric Nurse Practitioners, 20 Brace Road, Suite 200, Cherry Hill, NJ 08034-1600 National Association of Pediatric Nurse Associates and Practitioners
Ted Ganiats, MD Professor and Interim Chair, Dept. of Family and Preventive Medicine University of California at San Diego | University of California, San Diego Dept. of Family & Preventive Medicine 9500 Gilman Drive, 0628 La Jolla, CA 92093-0628 Tel: (858) 534-6058 Fax: (858) 534-7517 email: tganiats@ucsd.edu American Academy of Family Physicians
Mary Goessler, MD, MPM Medical Director of Quality Highmark, Inc. | 120 Fifth Avenue Ste P4501 Pittsburgh, PA 15222-3099 Phone: (412) 544 - 2629 Fax: (412) 544 - 2695 E-mail: mary.goessler@highmark.com America’s Health Insurance Programs
Diane Sabo, PhD Director of Audiology and Communication Disorders, Department of Audiology and Communication Disorders, Children’s Hospital of Pittsburgh | Children’s Hospital of Pittsburgh, Department of Audiology and Communication Disorders, 3705 Fifth Avenue, Pittsburgh PA 15213 Phone: (412) 692-5576 Fax: 412 692-7717 E-mail: DLS1@pitt.edu American Speech-Language Hearing Association
Alison Grimes, AudD Head, Audiology Dept. UCLA Medical Center | UCLA 200 Medical Plaza, #540 Los Angeles, CA 90095 E-mail: agrimes@mednet.ucla.edu American Academy of Audiology
Lawrence Kleinman, MD, MPH Vice Chair for Research and Education, Department of Health Policy Mount Sinai School of Medicine | Mount Sinai School of Medicine One Gustave L. Levy Place New York, NY 10029 212 659-9556 fax 212 423-2998 E-mail: lawrence.kleinman@mountsinai.org Academic Pediatric Association
Linda Landry Council Member Family Voices of California | 323-255-0354 (office) 323-717-7411 (cell) E-mail: lindajoyla@aol.com Family Voices LA
Allan Lieberthal, MD Clinical Professor of Pediatrics, USC and Chief of Immunization Team, Kaiser Permanente Hospital, Panorama City CA | 13652 Cantara Street. Panorama City, CA 91402. (818) 375-2412 Fax: 818/375-3870 E-mail: Allan.S.Lieberthal@kp.org American Academy of Pediatrics
Richard Rosenfeld, MD, MPH Professor of Clinical Otolaryngology, SUNY Health Science Center at Brooklyn, Brooklyn, NY | 134 Atlantic Avenue Brooklyn, NY 11201 E-mail: richrosenfeld@msn.com American Academy of Otolaryngology-Head and Neck Surgery
Pauline Thomas, MD Associate Professor New Jersey Medical School | New Jersey Medical School MSB F 506 185 South Orange Avenue Newark, NJ 07103 Phone: 973 972 9384 (office) Cell: 908 403 1615 Fax: 973 972 7625 E-mail: pthomas22@aol.com American Academy of Pediatrics

## AOM TEP Meeting 9/26/08

Attendance: Tasnee Chonmaitree, Katherine Finn Davis, Ted Ganiats, Mary Goessler, Lawrence Kleinman, Linda Landry, Allan Lieberthal, Richard Rosenfeld, Pauline Thomas, Caryn Davidson, Paul Shekelle, Glen Takata, Linda Chen, Tumaini Coker, Mary Ann Limbos, Sydne Newberry, Tina Murray)

Paul Shekelle introduced the role of the EPC and its responsibility for THE 2001 REPORT: The EPC team includes some clinicians, methodologists. However, the TEP consists of subject matter experts, consumers (and other end users), and representatives of the sponsoring organization/partner (AAP). The TEP’s role today is to help clarify key questions and enunciate the sponsoring organization’s and others’ needs.

Tina Murray described the role of the Task Order Officer (TOO):

The TOO’s role is to try to maintain timeliness, address administrative issues. The TOO tries to make sure the TEP is broadly representative, including end-users. AHRQ looks to TEP to help ensure report is useful to them.

Allan Lieberthal (representing AAP)

This TEP includes many veterans of the original EPC AOM report in 2001.

Following publication of that report, it took over four years to develop and approve new guidelines (2004).There were many controversies, including the right definition, the guideline regarding observation, first line antibiotics (AB), and dose. For the 2001 report, they were just beginning to get data on Prevnar. Now there are many more data on its efficacy as well as the role of viruses in OM. An important and final point to make is that AAP requested that AHRQ add recurrent AOM to the scope. This was a gap in the 2001 report.

### Discussion of the Definition of AOM

The definition of AOM was something the research team wrestled with in the 2001 report. The definitions proposed by the research team were distributed for the TEP’s consideration (see attached file or insert as footnote). The team also wanted to know how the TEP would operationalize the definitions and what to do about studies that provide little or no information on how they defined AOM for enrollment.

Rosenfeld said that part of accepting a definition is whether it is more inclusive or exclusive. . For our purposes, we want to err on the side of a few false positives rather than avoiding all false negatives. Thus a tight definition is better.

#### Three criteria should be considered individually: Time course, rapidity of onset, middle ear effusion (MEE)

But having said that, we can’t restrict the literature search to those that meet all three criteria. We can evaluate a study’s quality based on how closely it adheres to our definition, but don’t exclude studies on this basis. Paul rephrased: “So basically include any studies but conduct a sensitivity analysis that considers the number of criteria adhered to.”

Rosenfeld pointed out that a big problem is documenting MEE. How well is it documented? This is an overwhelming cause of false positives.

Lieberthal pointed out that a minimum criterion should be that authors define what THEY considered AOM

Shekelle asked if we want to be stricter regarding diagnosis questions, especially given that there is a gold standard diagnostic method, but be more inclusive and relaxed regarding treatment questions.

Kleinman responded that if our aim is to guide practice, we need to consider the implications for practice, especially in the inner city. Considering only AOM, in isolation, is fine, but if we are guiding practice, we need to consider the spectrum of otitis, and once we propose a definition, we need to consider the implications for other ME disease.

Ganiats said that an issue that came up last time (and was the subject of a minority report) was that studies that show the disease remits spontaneously did not have a good definition of AOM. The implication is that these spontaneous remissions didn’t really have the disease in the first place. He proposed the possibility of dividing evidence by studies that fulfill two criteria vs.. studies that fulfill all 3.

Thus, basically the TEP agreed with the following approach: “…accept any study purporting to study AOM or ROM and compare the trial definition to our study definition, report that analysis, and attempt to analyze results by adherence to our study definition, if sufficient data are available” and sensitivity analysis based on definition quality.

### KQ1 Validity of clinical symptoms…

What is the validity of clinical symptoms and otoscopic findings such as a bulging tympanic membrane to diagnose AOM? Do these clinical findings aid physicians in distinguishing AOM from OME?

a. What should be the gold standard? E.g. tympanocentesis for middle ear effusion (MEE), microbiologic agent isolation, rectal temperature as opposed to oral or axillary temperature, etc.
  Rosenfeld stated there is no gold standard. He also stated that if a child had a tympanocentesis that showed an infectious agent but had no clinical symptoms, he would not call that AOM. Consensus by a panel of MDs would be the only gold standard. Someone suggested developing a composite gold standard (a set of criteria).
  Again, tympanometry (as well as acoustic reflectometry) are useful in research but not the doctor’s office. Tympanometers used by general clinicians are not the same quality as those used in the research setting. Chonmaitree pointed out that the studies reviewed will have to have a definition of AOM and they may use tympanometry. Another issue is that instruments don’t always work well in very young children, the most important group.
  It was felt that it should be noted whether a study included tympanometry. The team noted they have already been noting this.
b. Which clinical symptoms and otoscopic findings are of particular interest that we should make every effort to report on, even if data are not available or already known to refute their use?
  The discussion did not reach this level of detail.
c. Should any other diagnostic tests other than otoscopy be included in the review? E.g. tympanometry, acoustic reflectometry, oto-acoustic emissions, et cetera
  The TEP agreed that clinical symptoms and otoscopic findings should be the focus. The focus should be on diagnostic criteria that must include MEE but differentiate AOM from OME. The TEP agreed that the review could include tympanometry for diagnosis of MEE. The TEP did not feel acoustic reflectometry was worth evaluating; in particular published studies were lacking.
d. In a prior systematic review, the TEP for the otitis media with effusion (OME) panel decided that diagnosing MEE in a child with OME was different from diagnosing MEE in a child with AOM, so we did not use AOM MEE studies for the OME review of MEE diagnosis. Should the same logic apply to this AOM review if MEE is decided by the TEP to be an integral component of diagnosing AOM?
  The TEP did not discuss this issue.
e. Other specifications?
  None were discussed.

### KQ2 What organisms (bacterial and viral) are associated with otitis media since the introduction of PNC7?

What are the patterns of antimicrobial resistance since the introduction of PNC7?

- New infections
- Recurrent infections

a. Should KQ2 include the effectiveness of the vaccine for preventing AOM?
  In general, the TEP felt we should address vaccine effectiveness only if time is available.
b. Are “New infections” initial episodes of AOM?
  No, they are generally regarded as episodes of AOM that occur after some elapsed period of time since the previous episode. The question is whether the bacteriology of the “new” infection is distinct from the previous infection.
c. Are “Recurrent infections” episodes of ROM? If so, which episode?
  The TEP seemed to want to re-phrase “New infections” and “Recurrent infections” to something related to the “antibiotic milieu,” i.e., whether or not the child had ever been exposed to an antibiotic, whether for AOM or any other condition. Some TEP members also expressed the desire to retain the concept of recurrent infection with the addition of persistent AOM and AOM relapse. See KQ4 for further discussion.
d. If possible, we will analyze by antibiotic use pattern in the trial region. Are there any other factors apart from PNC7 and antibiotic use patterns that should be included in the analysis?
  This issue was not discussed.
e. Other specifications?
  See “c”.

### KQ3 What is the comparative effectiveness of different treatment options (defined below) for treating AOM in average risk children ages <2 years, ages 2 years to <5 years and ages ≥ 5 years?

Treatment options include but not limited to:

- Amoxicillin (including high dose versus low dose)
- Amox-clav (including high dose versus low dose)
- Cephalosporins (e.g. ceftriaxone, cefdinir, cefixime)
- “Wait and see approach”
- Placebo
- Duration of treatment

Outcomes to consider but not limited to:

- Parent satisfaction
- Duration of symptoms/illness
- Treatment failure, mastoiditis, bacteremia, clinical cure, bacteriologic cure
- Disease recurrence

a. Any other antibiotics should be included that we should make every effort to report on, even if data are not available or already known to refute their use??
  The TEP was amenable to adding any FDA-approved antibiotic (especially erythromycin).
b. What is the definition of the “Wait and see approach”? e.g. AAP/AAFP Guidelines, Dutch guidelines, et cetera?
  Use the AAP/AAFP AOM guideline for observational treatment. Rosenfeld felt most of the new AOM studies would be on this issue: the “delayed treatment” approach, which is distinct from the “wait and see” approach. The delayed treatment approach is in contrast to immediate treatment.
c. Should analgesics be separated as an intervention? Oral versus topical?
  Initially there seemed to be a divergence of opinion, but the TEP seemed to be interested in studying analgesics.
d. Are we interested in dual treatment? E.g. antibiotic plus analgesic?
  This issue was not addressed.
e. What specific durations of treatment are of interest that we should make every effort to report on, even if data are not available or already known to refute their use?
  Rosenfeld believes no new studies of significance on short-duration therapy have been published since the Kozyrskyj (1998) publication of their systematic review. He treats children <2 years old for 7–10 days and children >5 years old for 3–5 days. He stated that for 2–5 years of age, some controversy exists.
f. Any other outcomes that we should make every effort to report on, even if data are not available?
  Lieberthal stated he was interested in bacteriologic as well as clinical outcomes. Ganiats stated that clinical outcomes were more important, especially for guideline development.
  Kleinman brought up the need for quality of life and functional status outcomes.
  Cost outcomes were also discussed, including days of school or daycare missed and days of parental work missed. Landry noted that parents need to pay for daycare regardless of whether child attends, which makes cost an even more compelling issue.
g. What is the definition of disease recurrence? E.g. is this in relation to the otitis-prone child?
  The TEP agreed that recurrence is defined as AOM relapse within 30 days. Kleinman recommended that we gather specific time to relapse information, as most relapse may actually occur much earlier than 30 days (might be worth assessing whether it should be 15 days).

### KQ4 What is the comparative effectiveness of different management options for recurrent otitis media?

Management options include but not limited to:

- Amox-clav
- Cephalosporins (e.g. ceftriaxone, cefuroxime)
- Quinolones
- Antibiotic prophylaxis

Outcomes to consider but not limited to:

- Parent satisfaction
- Duration of symptoms/illness
- Treatment failure, mastoiditis, bacteremia/Cure rates

a. Same questions as for KQ3.
  In essence “yes;” however, the major issue is discussed in “c”.
b. Are there any procedural interventions we should include that we should make every effort to report on, even if data are not available or already known to refute their use?
  Tympanostomy tubes were mentioned. Rosenfeld stated that antibiotic prophylaxis is already known not to be effective, though Kleinman stated the opposite later in the discussion.
c. KQ4 currently addresses ROM? What definitions of chronic suppurative and/or persistent OM should be used to differentiate from ROM?
  Lieberthal stated that the AAP intended KQ4 to address ROM, i.e. the otitis-prone child. However, many of the TEP members voiced uncertainty over the present usefulness of the terms ROM and otitis prone The TEP seemed to agree that KQ4 should address ROM but also acute recurrence of AOM within 30–60 days, i.e. persistent AOM or AOM relapse (Rosenfeld and Chonmaitree mentioned that Dagan and Arguedas are doing interesting studies on persistent AOM in South America).
  Coker noted that the definition and distinction (between recurrent, persistent/relapse, and otitis prone) has not been clear among the studies they have reviewed so far. Shekelle recommended determining how big a problem it would pose in analyzing the literature and then going back to the TEP. (Kleinman noted that OME and AOM can present in the same kids, that management may differ when kids show up acutely. He said this is something they need to consider).

### KQ5 What is the evidence that the comparative effectiveness of different treatment options in KQ #3 differs in subpopulations of patients?

Subpopulations to include (but not limited to):

- Bilateral disease
- Comorbidities (e.g. asthma –will need to define further)
- Age groups (e.g., <1 month, 1-<2 months, 2-<6 mos, 6 mos–<2 years, 2–5 years)
- Race/Ethnicity
- Day care attendance

a. What are other comorbidities in addition to asthma? Will any subpopulations be excluded such as those with craniofacial anomalies, immunodeficiencies, genetic disorders, et cetera?
  The TEP felt that most studies would exclude these comorbidities but did not state if we should a priori exclude studies on certain populations. They recommended referring to the Guidelines. [Bilateral disease was also mentioned as a comorbidity but it was unclear whether it should be excluded]
b. Are the proposed age intervals appropriate?
  Rosenfeld proposed not studying <6 month olds.
c. What is meant by race and ethnicity? Will we analyze the interaction?
  This issue was not discussed.
d. What are thresholds of daycare attendance the review should focus upon?
  This issue was not discussed.
e. What additional subpopulations should be considered for KQ5? E.g., AOM with perforation or otorrhea versus no perforation or no otorrhea, et cetera?
  Rosenfeld proposed analyzing by severity rating, e.g., the AAP/AAFP AOM Guideline severity rating.
f. Should a similar subpopulation analysis be done for KQ4 on ROM?
  This issue was not discussed.

### KQ6 What are the comparative harms of different treatment options?

Outcomes to consider (but not limited to):

- Antibiotic resistance
- Diarrhea/vomiting

a. What other harm outcomes should be included that we should make every effort to report on, even if data are not available or are already known not to be significant issues?
  Shekelle explained the research team would list all harms reported but wondered if we need to consider any in particular. Kleinman wondered if we need to consider the harms of withholding treatment (e.g., increased risk of suppurative complications); however this question was assessed in the first report. Only one study, a Dutch study, assessed it and it was done poorly.

Responses to Query Regarding Nasopharyngeal Swabs as Proxy for Ear Fluid November 18, 2008

Lieberthal: NP swabs do not accurately identify the organisms in the middle ear. They may reflect organisms that the child carries and may or may not be the same as the organism causing AOM.

Studies have looked at both clinical cure and bacteriologic cure. If there is bacteriologic cure there is more certainty of clinical cure. However clinical cure-the practical end point for providers-can occur without having sterilized the middle ear at the time of follow-up.

Rosenfeld:

1. Nasopharyngeal (NP) culture: This has been used as a surrogate for middle ear (ME) aspirates in some studies but the accuracy is poor. A negative NP culture for a particular pathogen has good predictive value for a negative ME culture for the same pathogen, but the value of a positive NP culture is no better than a coin toss at predicting ME results. The main value of NP cultures in OM studies has been to track changes in susceptibility of host organisms after antimicrobial therapy or vaccination.
2. Bacteriologic vs.. clinical efficacy: The primary endpoint relevant to clinical decision making for AOM is clinical response, since about 70–80% of bacteriologic “failures” are nonetheless clinical “successes.” The value of bacteriologic endpoints is in assessing new antimicrobials, or in teasing out subtle differences in comparative efficacy of existing antimicrobials for specific pathogens. We can certainly use this as a secondary endpoint if enough data exist, but it takes a distant second place to clinical efficacy for everyday management decisions.

Kleinman: I agree with Allan and would add that I am unaware of evidence that suggests that N-P eradication improves long or short term course.

Goessler: I also concur.

Casselbrant: I have no further comments.

## AOM TEP Meeting 2 Summary

TEP Discussants: Tasnee Chonmaitree; Katherine Finn Davis; Diane Sabo; Allan Lieberthal; Richard Rosenfeld; Pauline Thomas

AAP Staff Representative: Caryn Davidson

AHRQ Representative: Lt. Commander Carmen Kelly

SCEPC Staff Discussants: Linda Chan; Tumaini Coker; Mary Ann Limbos; Sydne Newberry; Paul Shekelle; Glenn Takata

Date/Time: Tuesday 3/10/2009, 11:30 am to 12:40 pm

### 1 Project Update

a. KQ1 Diagnosis: Identified recent systematic review and updated search. Screening titles.
b. KQ2 Microbiology: Identified 70 articles. Conducted second level of screening.
c. KQ3–6 Treatment and adverse effects: Screening and abstraction complete for original search and updated search; beginning pooling and data analysis.

### 2 Additional feedback on the list of articles included for treatment and adverse event questions: Anything we’ve omitted?

The panel was asked to review the lists of articles reviewed for the treatment questions to let us know if we have missed anything important. The searches date from 1998 (when the last AHRQ systematic review ended, allowing for some overlap, although older articles are being considered for recurrent/persistent OM). The search strategy builds on that of THE 2001 REPORT with the addition of new terms, e.g., watchful waiting. PubMed and Web of Science were searched for the update, as well as reference mining systematic reviews and accepted articles.

Dr. Chonmaitree noted that she had identified several more articles (including back-to-back articles by Hoberman in the January 2009 PID) in addition to a couple by her group (McCormick et al) that seemed to be missing from our lists. The panel suggested we try to determine how we had missed these articles.^1^ [Dr. Chonmaitree had also sent an email the previous day regarding Hotomi, Cates, and two Vernacchio articles.]

1 It turns out the McCormick et al article pertaining to treatment was identified but then inadvertently excluded when duplicate articles were being eliminated from a list of titles.

### 3 Including Observational Studies?

We also presented the strategy of including observational studies on treatment issues only when controlled trial data were lacking as recommended by current systematic review guidelines. Paul Shekelle clarified that we are focusing on clinical trial comparisons of antibiotics and other treatments. We’re now in the pooling stage. If we find cells with no data, we will look to observational studies or we will ask the panel if observational studies will be of use in this analysis. The panel briefly reviewed the frequency table.

There was a discussion of whether to examine each antibiotic separately or to pool. Dr. Rosenfeld suggested doing two sets of analysis: 1) drug a vs.. drug b (specific agents) and 2) combine all antibiotics, i.e. drug A vs.. all comparators. For the immediate vs.. deferred question, it is all right to pool different antibiotics for that comparison. Also, for the primary empiric decision - to treat or not – it is all right to pool. But when looking at treatment failures, we want to look separately.

### 4 Overall Scope

Finally, we asked for comments on the overall scope for this review: are we missing anything crucial? There was general agreement that it was a good summary.

Clarification was requested for the difference between practitioner and examiner in influencing factors. Several participants noted that sometimes the examiner in a study is not the patient’s practitioner, and sometimes the examiner is blinded, whereas the practitioner may not be blinded.

It was suggested we add the cost of antibiotics to the cost of outcomes, although there was discussion about the recent development that Walmart now carries an inexpensive generic amoxicillin-clavulanate. Someone mentioned that the amoxicillin-clavulanate ratio is lower in the generics, which can result in diarrhea.

Should we include cholesteatoma development as an otological complication? Other panel members felt the incidence was too low and the onset time too long. The term “ear fullness” needs to be corrected.

As a result of this discussion, the research team will provide definitions for each of the scope items.

### Other Business

AOM Definition. Are we devising a definition of AOM? Paul Shekelle noted that we’re documenting elements of definitions used in articles for potential sensitivity analysis. More restrictive definitions result in smaller numbers of trials.

Timeline. The panel asked about the timeline for the report (draft due week of April 12). The AAP expressed interest in having the report available for a June 30 meeting of the AAP AOM Guideline panel. Although the report may not be final by then, the panel should at least have the information they need.

Considering generalizability of findings. Richard Rosenfeld recommended that the generalizability of results needs to be emphasized in the write-up. For example, with respect to pneumatic otoscopy, the concern is that it has to be done with fairly well trained otoscopists and that the validity in trials is not applicable to the average primary care physician, who may be more skilled at other diagnostic techniques. It will be useful to document and comment on the circumstances to which the findings apply with respect to characteristics of the examiner. Also, with regard to the concept of watchful waiting/deferred antibiotic observation and management options, there is concern with the types of children involved in the clinical trials of this treatment option and the potentially poor quality of studies. The research team was advised to be attentive to studies that propose a reductionist approach: we need to define which patients these results can be extrapolated to. He emphasized that generalizability may be even more important than effect size.

Report format. A question was raised about the report’s format. The report will include text as well as evidence tables and flow charts. The link was sent to the panel.

Reporting effect sizes as risk ratios or odds ratios? The question was raised about how effect sizes were expressed in the first report. Dr. Shekelle responded that we mostly report RRs, which can be converted to the number needed to treat (NNT) or the number needed to harm. RR provides relative risk. According to Dr. Rosenfeld, Cochrane prefers to use odds ratios. Dr. Shekelle said that RRs are preferred, and Linda Chan noted that one can be converted to the other. Dr. Rosenfeld reported that risk ratios result in small differences in NNT, and that it is sometimes helpful to see absolute differences as well as relative differences. Dr. Takata noted that THE 2001 REPORT reported rate differences. Dr. Shekelle assured the panel that we can be flexible, but that we tend to avoid reporting odds ratios because of the tendency to overestimate what they mean.

Reporting failure rates or success rates? Dr. Rosenfeld asked whether we would report failure rates or success rates. Cochrane reports failure rates. The problem is that with self-limiting conditions, failure rates are fairly small. Doubling still produces a small failure rate, so it is deceptive. Reporting success rates may be preferable if one is anticipating a robust success rate. Dr. Lieberthal noted that the first AOM report used NNT. For the clinician, NNT is one of the easier statistics to understand. Also, success rate is preferable for clinicians, as differences are not inflated. There was general agreement that success rates are simpler to understand. Dr. Takata suggested that maybe this distinction of reporting failure versus success should be made in the guideline discussions. The front-line clinician is more likely to read the guideline than the technical report.

Zone of Indifference. Dr. Chan then raised the issue of the zone of indifference. A difference may be statistically significant but not clinically important. There are confidence intervals for failure rates as well as success rates. D r. Rosenfeld agreed that the zone of indifference is an important concept, equally so for adverse events, especially since AOM is a self-limiting disease. Thus adverse effects (AEs) may be the driving force in many treatment decisions. Much harm is done with well-meaning therapies and not enough has been done in previous reports to highlight AEs of treatment. Some discussion ensued about the degree to which AOM is self-limiting and the risk for severe complications like mastoiditis. (Dr. Rosenfeld cited a recent article by Thompson out of the UK in Pediatrics that showed a very low incidence of acute mastoiditis in AOM.) Regardless, the panel wants to see the same clarity and thoroughness in AE reporting as in the reporting of disease-related outcomes.

Definition of persistent OM: AOM or OME? Dr. Davis asked whether persistent OM (as defined in the scope) refers to AOM or OME. Dr. Takata said it is AOM and that we will clarify the definitions. Dr. Davis also noted that the definition should include middle ear inflammation, not infection (however Pichicero’s definition of “persistent” specifies infection, not inflammation).

This discussion raised questions about the definitions of recurrence and persistence. Is persistence relapse within a month or failure of symptoms to resolve within a month: These are two different conditions. Dr. Thomas asked “At what point is something a new episode as opposed to a continuation of the original episode?” Dr. Chonmaitree noted that Pichicero has apparently studied this question. In fact, it is his definition (from Pediatric Infectious Disease (2000) that we have adopted (the term is Persistent Otitis Media/Relapse of Acute Otitis Media)^2^. Dr. Lieberthal noted that recurrence would be characterized by clear evidence of prior resolution.

2 Pichicero ME. Recurrent and persistent otitis media. Pediatr Infect Dis J 2000;19:911–916

### Wrap-up

We may be contacting the panel before the report draft is sent out, for resolution of the need for including observational studies.