# List of Peer Reviewers

Name | Contact Info
Carmen C. Brewer | National Institute on Deafness and Other Communication Disorders 9000 Rockville Pike Building 10/5C306 Bethesda, MD 20892 Phone: 301-496-5294 Fax: 301-402-0409 brewerc@nidcd.nih.gov
Anne Marie Tharpe | Vanderbilt University 1215 21^st^ Ave South 6301 MCE South Tower Nashville, TN 37232-8718 Phone: 615-936-5001 Fax: 615-936-5014 anne.m.tharpe@vanderbilt.edu
Jonathan Finkelstein, MD, MPH | Harvard Medical School 133 Brookline Ave., 6^th^ Floor, Boston, MA 02215 Phone: 617-509-9898 Fax: 617-5099845 Jonathan_finkelstein@harvardpilgrim.org
Kathleen Daly | University of Minnesota Dept of Otolaryngology MMC 396 420 Delaware St SE Minneapolis, MN 55455 Phone: 612-625-3259 Fax: 612-625-2101 dalyx002@umn.edu
Allan Stuart Lieberthal MD, FAAP | Kaiser-Permanente 13652 Cantara St S1-101B Panorama City, CA 91402-5423 Phone: 818-375-2412 Fax: 818-375-4073 allan.s.lieberthal@kp.org
Aaron Carroll | Indiana University-Purdue University Indianapolis 410 W. 10thSt HITS 1020 Indianapolis, IN 46202 Phone: 317-278-0552 Fax: 317-278-0456 aaecarro@iupui.edu
Pauline Thomas | New Jersey Medical School MSB F 506, 185 South Orange Ave, Newark, NJ Phone: 973 972 9384 Fax: 973 972 7625 thomasp1@umdnj.edu
Theodore G. Ganiats MD | University of California San Diego 9500 Gilman Drive-0628 La Jolla, CA 92093-0628 Phone: 858-534-6085 Fax: 858-534-7517 tganiats@ucsd.edu
Richard Rosenfeld | SUNY Health Science Center at Brooklyn 134 Atlantic Avenue Brooklyn, NY 11201
Maroeska M. Rovers | UMC Utrecht, Julius Center for Care, PO Box 8550 3508 GA Utrecht The Netherlands Phone: +31 88 7559399 Fax: +31 88 7568099 m.rovers@umcutrecht.nl
Katherine Finn Davis | Center for Pediatric Nursing Research & Evidence Based Practice, Children’s Hospital of Philadelphia 3535 Market St, Ste 1317 Philadelphia, PA 19104 Phone: 267-426-6966 Fax: 267-426-0875 kfinndavis@yahoo.com
Lawrence C. Kleinman | Mt. Sinai Medical Center One Gustave L Levy Place Box 1077 New York, NY 10029 Phone: 212-659-9556 Fax: 212-423-2998 Lawrence.kleinman@mountsinai.org
Tasnee Chonmaitree, M.D. | Department of Pediatrics, Division of Infectious Doseases, University of Texas Medical Branch, 301 University Blvd., Galveston, TX 77555-0371 Phone: (409) 772-2798 Fax: (409) 747-1753 Tchonmai@utmb.edu
Donald T. Miller MD MPH FAAP | 4610 Trieste Drive Carlsbad, CA 92010 Phone: 760-207-0773 Fax: 760-757-3004 dtmillermd@gmail.com