# Evidence Tables For Randomized Controlled Trials

Author Year | Quality & AOM definition | Intervention | Time, Place, Inclusion, Exclusion Criteria | Influencing Factors and Sample Size | Outcomes | Findings
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | Place: Multicenter: 38 centers Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otoscopy (distinct TM erythema), AOM < 1 week Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, Concomitant/Concurrent infection needing antibiotic treatment, Topical antibiotic drops prior to study, Chronic suppurative OM, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea, Complication of OM, PE tubes/history of PE tubes, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=752 N=251 Amoxicillin- clavulanate N=248 Cefdinir 14 mg QD N=253 Cefdinir 7 mg BID Completing: N=665 N=210 Amoxicillin- clavulanate N=226 Cefdinir 14 mg QD N=229 Cefdinir 7 mg BID Analyzed: N=595 N=197 Amoxicillin- clavulanate N=195 Cefdinir 14 mg QD N=203 Cefdinir 7 mg BID | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Outcome: Success rate (cure or improvement) at day 11–16
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | A-C | Cef QD | Diff (95%CI)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | 90% (177/197) | 91% (177/195) | −1% (−7, 4.8)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | A-C | Cef BID | Diff (95%CI)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | 90% (177/197) | 89% (180/203) | 1% (−5, 7)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | Cef QD | Cef BID | Diff (95%CI)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | 91% (177/195) | 89% (180/203) | 2% (−4, 8)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | A-C | Cef QD | Diff (95%CI)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Any | 26.3% (66/251) | 16.5% (41/248) | 10%(2.6, 17)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Diarrhea | 12.7% (32/251) | 10.9% (27/248) | 2% (−3.9, 7.5)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Tx related | 20.3% (51/251) | 14.1% (35/248) | 6% (−0.2, 13)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | A-C | Cef BID | Diff (95%CI)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Any | 26.3% (66/251) | 23.3% (59/253) | 3%(−4.5, 10)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Diarrhea | 12.7% (32/251) | 15.8% (40/253) | −3%(−9, 3)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Tx related | 20.3% (51/251) | 17.8% (45/253) | 2%(−4.4, 9)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | | Cef QD | Cef BID | Diff (95%CI)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Any | 16.5% (41/248) | 23.3% (59/253) | −7% (−14, 0.2)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Diarrhea | 10.9% (27/248) | 15.8% (40/253) | 5% (−11, 1.1)
Adler 2000^73^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE | Amoxicillin-clavulanate 13.3 mg/kg/day = tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Disease recurrence; Adverse effects of treatment | Tx related | 14.1% (35/248) | 17.8% (45/153) | −4% (−11, 3.6)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | Study Time: 9/2002–7/2003 Place: United States, Finland, Chile, Costa Rica Multicenter: 19 centers Inclusion: 6–30 mo, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Fever Exclusion: Penicillin/beta-lactams, Macrolides, Antibiotic within 30 days, Chronic suppurative OM, TM perforation/Otorrhea >24 hours, PE tubes/history of PE tubes, Major Systemic disease/ condition, medical problem, Resistant bacteria | Influencing factors: Middle ear effusion, Age, Baseline pathogen Entering: N=312 N=154 Amoxicillin N=158 Azithromycin Completing: N=306 N=151 Amoxicillin N=155 Azithromycin Analyzed: N=312 N=154 Amoxicillin N=158 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate (cure or improvement) at day 12–14
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | | Amoxicillin | Azithromycin | Diff (95%CI)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All pts | 84% (127/151) | 84% (130/155) | 0.2%(−8, 8)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <=2yrs | 82% (99/121) | 82% (109/133) | −0.2% (−10, 9)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate (cure) at day 25–28 visit
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All pts | 78% (117/151) | 77% (117/152) | −0.5% (−10, 9)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <=2yrs | 75% (91/121) | 75% (98/130) | −0.2%(−11,11)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Abd pain: | 1.9% (3/154) | 3.8% (6/158) | −2%(−5.6, 1.8)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Diarrhea: | 17.5% (27/154) | 8.2% (13/158) | 9%(2, 17)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Rash: | 2.6% (4/154) | 2.5% (4/158) | 0.1%(−3.4,3.6)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Vomiting | 8.4% (13/154) | 8.2% (13/158) | 0.2%(−6, 6)
Arguedas 2005^66^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day / bid for 10 days vs. Azithromycin 30 mg/kg/day = qd for 1 day | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Tx related | 28.6% (44/154) | 19.6% (31/158) | 9%(−0.5, 18)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | Study Time: 3/2001–3/2002 Place: United States Multicenter: 18 centers Inclusion: 6 mo–6 yr, <25 kg, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Ear fullness, Recurrent AOM, Persistent AOM Exclusion: Penicillin/beta-lactams, Macrolides, Antibiotic within 30 days, TM perforation/Otorrhea, Complication of OM, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Major Systemic disease/ condition, medical problem, Heme/Onc Disorders, Investigational drug within 1 month, Hospitalization/need for admission | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Success rate on day 12–16
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Amox-clav | Azithromycin | Diff (95%CI)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Total | 84% (122/145) | 86% (128/149) | −2% (−10, 6)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | <=2yrs | 79% (73/92) | 85% (82/96) | −6% (−17, 5)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | >2yrs | 92% (49/53) | 87% (46/53) | 5% (−7, 17)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Adverse events
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Any | 42.2% (62/147) | 32.0% (49/153) | 10%(−0.7, 21)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Abd pain | 2.0% (3/147) | 3.9% (6/153) | −2%(−5.7, 2)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Anorexia | 2.7% (4/147) | 3.3% (6/153) | −0.6%(−4, 3)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Dermatitis | 2.0% (3/147) | 0.7% (1/153) | 1.3%(−1.3, 4)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Diarrhea | 29.9% (44/147) | 19.6% (30/153) | 10%(0.5, 20)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Rash | 4.8% (7/147) | 3.3% (5/153) | 1.5%(−3, 6)
Arrieta 2003^124^ | Jadad quality score 1 (0−5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/45 vs. Azithromycin | | Influencing factors: Age Completing: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin Analyzed: N=296 N=145 Amoxicillin- clavulanate N=151 Azithromycin | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Vomiting | 8.2% (12/147) | 5.2% (8/153) | 3%(−2.6, 9)
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | Study Time: 2/1996–5/1998 Place: Netherlands Multicenter: 53 centers Office setting/ private practice, General/ family practice Inclusion: 6–24 mo, Acute onset S&S (parent/guardian report), Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Otorrhea, S&S of middle ear inflammation (MEI), Otalgia, Fever, Irritability, Other constitutional symptoms NOS Exclusion: Penicillin/beta-lactams, Antibiotic within 4 weeks, Cranio-facial, Immunosuppressed /compromised/deficient | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | Outcome: Clinical outcome between 6 months and 3 years
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | | Amoxicillin | Placebo | Diff (95% CI)
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | No recurrent AOM
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | | 37% (28/75) | 57% (49/86) | −20% (−5, −35)
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | No referral
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | | 31% (24/78) | 30% (62/89) | 0% (−14, 14)
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | No surgery
Bezakova 2009^164^ | Jadad quality score 1 (0–5):4 [1,1,0,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo Completing: N=168 N=90 Placebo Analyzed: N=168 N=90 Placebo | Disease recurrence; Healthcare utilization | | 79% (16/78) | 70% (27/90) | 9%(−23, 4)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | Study Time: 2/2001–4/2003 Place: Hospital, ENT Inclusion: 6 mo–10 yr, Acute onset S&S (parent/guardian report), Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, S&S of middle ear inflammation (MEI), Otalgia, Fever >38 C Exclusion: Penicillin/beta-lactams, Macrolides, Antibiotic within 2 weeks, AOM within 1 months, Recurrent AOM (>3 episodes in 12 months), TM perforation/Otorrhea, PE tubes/history of PE tubes, Cranio-facial, Immunosuppressed /compromised/deficient, Major Systemic disease/ condition, medical problem, On other medication/treatment | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Cumulative clinical resolution rate at day 3 after treatment initiation
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Amox-clav | Ceftriaxon | Diff (95%CI)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 87.2% (34/39) | 85.3% (29/34) | 2%(−14, 18)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithro | Diff (95%CI)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 87.2% (34/39) | 87.1% (27/31) | 0.1%(−16, 16)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Persistent middle ear fluid on day 30
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Amox-clav | Ceftriaxon | Diff (95%CI)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 14.7% (5/34) | 17.2% (5/29) | −2.5%(−21, 16)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithro | Diff (95%CI)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 14.7% (5/34) | 22.2% (6/27) | −7.5%(−27, 12)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Amox-clav | Ceftriaxon | Diff (95%CI)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Diarrhea | 7.7% (3/39) | 5.9% (2/34) | 2%(−10, 13)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Vomiting | 2.6% (1/39) | 2.9% (1/34) | −0.3%(−8, 7)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithro | Diff (95%CI)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Diarrhea | 7.7% (3/39) | 6.5% (2/31) | 1%(−11, 13)
Biner 2007^71^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Azithromycin 10 mg/kg/day = qd for 1 day, Azithromycin 5 mg/kg/day = qd for 4 days vs. Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days | | Analyzed: N=104 N=34 Ceftriaxone N=31 Azithromycin N=39 Amoxicillin- clavulanate | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Vomiting | 2.6% (1/39) | 3.2% (1/31) | −0.6%(−8, 7)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | Study Time: 10/1996–2/1997 Place: United States Multicenter: 13 centers Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otoscopy (distinct TM erythema), AOM Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, Topical antibiotic drops prior to study, Chronic suppurative OM, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea, Complication of OM, PE tubes/history of PE tubes, Cranio-facial, GI disorders/Liver, Renal Disorders, Major Systemic disease/ condition, medical problem, On other medication/treatment | Influencing factors: Age Entering: N=435 N=216 Cefprozil 10 days N=219 Cefdinir 5 days Completing: N=373 N=183 Cefprozil 10 days N=190 Cefdinir 5 days Analyzed: N=373 N=183 Cefprozil 10 days N=190 Cefdinir 5 days | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Outcome: clinical cure on day 9–11 (4–6 days post therapy for cefdinir and +/−1 day post therapy for Cefprozil)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | | Cefdinir | Cefprozil | Diff (95%CI)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Total | 80.0% (152/190) | 82.5% (151/183) | −2.5%(−10,5.4)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | <2yrs | 71.0% (49/69) | 70.7% (41/58) | 0.3%(−16, 16)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | 2–5yrs | 85.1% (57/67) | 87.1% (61/70) | −2% (−14, 10)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | 6–12yrs | 83.3% (45/54) | 89.1% (49/55) | −6% (−19, 7)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Outcome: clinical cure on test-of-cure visit on 17–21 day post therapy (days 17–21 for cefdinir and days22–26 for Cefprozil)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | | Cefdinir | Cefprozil | Diff (95%CI)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Total | 65.3% (124/190) | 64.5% (118/183) | 0.8% (−9, 10)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | <2yrs | 49.3% (34/69) | 48.3% (28/58) | 1% (−16, 18)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | 2–5yrs | 73.1% (49/67) | 64.3% (45/70) | 9% (−7, 24)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | 6–12yrs | 75.9% (41/54) | 81.8% (45/55) | −6%(−21, 9)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Outcome: Adverse events
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | | Cefdinir | Cefprozil | Diff (95%CI)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Diarrhea | 7.9% (15/190) | 4.4% (8/183) | 3.5%(−1.4,8)
Block 2000^85^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment | Rash | 3.2% (6/190) | 3.8% (7/183) | −0.6%(−4.3,3.1)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | Enrollment Time: 4/1992–8/1993 Place: United States Multicenter: 13 centers Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Loss of landmarks, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Decreased hearing, Onset of AOM symptoms within 7 days before entry, Irritability, Other constitutional symptoms NOS Exclusion: Antibiotic within 7 days, TM perforation/Otorrhea, PE tubes/history of PE tubes, Resistant bacteria | Influencing factors: Age Entering: N=384 N=128 Amoxicillin- clavulanate N=128 Cefdinir 14 mg QD N=128 Cefdinir 7 mg BID Completing: N=303 N=100 Amoxicillin- clavulanate N=102 Cefdinir 14 mg QD N=101 Cefdinir 7 mg BID Analyzed: N=303 N=100 Amoxicillin- clavulanate N=102 Cefdinir 14 mg QD N=101 Cefdinir 7 mg BID | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success (cure or improvement) 2–4 days after treatment: Amox-clav vs. Cefdinir QD
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | A-C | CDR-QD | Diff (95%CI)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Total | 86% (86/100) | 83.3% (85/102) | 0.7%(−7, 13)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | <2yrs | 79% (31/39) | 80% (45/56) | −0.9%(−17,15)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | 2–5yrs | 85% (35/41) | 84% (31/37) | 1.6%(−14, 18)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | 6–12yrs | 100% (20/20) | 100% (9/9) | 0.0%
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success (cure or improvement) 2–4 days after treatment: Amox-clav vs. Cefdinir BID
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | A-C | CDR-BID | Diff (95%CI)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Total | 86% (86/100) | 80% (81/101) | 5.9% (−4, 16)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | <2yrs | 79% (31/39) | 62% (30/48) | 17% (−2, 36)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | 2–5yrs | 85% (35/41) | 95% (35/37) | −9%(−23, 4)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | 6–12yrs | 100% (20/20) | 100% (16/16) | 0.0%
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success (cure or improvement) 2–4 days after treatment: Amox-clav vs. Cefdinir BID
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | CDR-QD | CDR-BID | Diff (95%CI)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Total | 83% (85/102) | 80% (81/101) | 3% (−7, 14)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | <2yrs | 80% (45/56) | 62% (30/48) | 18%(0.6,35)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | 2–5yrs | 84% (31/37) | 95% (35/37) | −11%(−25, 3)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | 6–12yrs | 100% (9/9) | 100% (16/16) | 0.0%
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Adverse events
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | A-C | CDR-QD | Diff (95%CI)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Any | 42% (54/128) | 14% (18/128) | 28%(17, 39)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Diarrhea | 35% (45/128) | 10% (13/128) | 25%(15, 35)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Rash | 8% (10/128) | 5% (6/128) | 3%(−2.8, 9)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | A-C | CDR-BID | Diff (95%CI)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Any | 42% (54/128) | 23% (29/128) | 20%(8, 31)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Diarrhea | 35% (45/128) | 13% (17/128) | 22%(11, 32)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Rash | 8% (10/128) | 6% (8/128) | 2%(−4.8, 7.8)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | CDR-QD | CDR-BID | Diff (95%CI)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Any | 14% (18/128) | 23% (29/128) | −9%(−18,0.9)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Diarrhea | 10% (13/128) | 13% (17/128) | −3%(−11,4.8)
Block 2000^72^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40/10 mg/kg/day / tid for 10 days vs. Cefdinir 14 mg/kg/day = qd for 10 days vs. Cefdinir 7 mg/kg/day = bid for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Rash | 5% (6/128) | 6% (8/128) | −2%(−7, 4)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | Enrollment Time: 2/2003–4/2003 Place: United States Multicenter: 28 centers Inclusion: 6 mo–6 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Air fluid level behind TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Presence of MEF by acoustic reflectometry, Otalgia, Decreased hearing Exclusion: Antibiotic within 2 weeks, Concomitant/Concurrent infection needing antibiotic treatment, Long acting antibiotic within 4 weeks, Otitis externa, Chronic suppurative OM, No symptoms of AOM, PE tubes/history of PE tubes | Influencing factors: Age, Pneumococcal Vaccine Entering: N=425 N=214 Augmentin [Amoxicillin-clavulanate] N=211 Cefdinir Completing: N=425 N=214 Augmentin [Amoxicillin- clavulanate] N=211 Cefdinir Analyzed: N=425 N=214 Augmentin [Amoxicillin-clavulanate] N=211 Cefdinir | Treatment failure; By otoscopic findings:; Bulging tympanic membrane [TM]; Loss of landmarks; Air fluid level behind TM; Presence of MEF by acoustic reflectometry; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); By otoscopy (distinct TM erythema); Other symptoms: fever; Other symptoms: decreased hearing; Adverse effects of treatment | Outcome: Success at end-of-treatment visit (study days 7–9 for Cefdinir; study days 12–14 for Amox-clav) by age group
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Amox-clav | Cefdinir | Diff (95%CI)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Total | 85% (164/192) | 88% (170/194) | −2% (−9, 4.6)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | <2yrs | 78% (64/82) | 88% (79/90) | −10%(−21, 1.4)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | 2–6yrs | 91% (100/110) | 88% (91/104) | 3% (−4.9, 12)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Outcome: Success at end-of-treatment visit (study days 7–9 for Cefdinir; study days 12–14 for Amox-clav) by PCV7
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Amox-clav | Cefdinir | Diff (95%CI)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Total | 85% (164/192) | 88% (170/194) | −2% (−9, 4.6)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | HadPCV7 | 82% (102/124) | 92% (115/125) | −10%(−18, −2)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | NoPCV7 | 91% (62/68) | 80% (55/69) | 11% (−0.8, 23)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Outcome: Adverse events
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | | Amox-clav | Cefdinir | Diff (95%CI)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Dia.rash | 10% (21/214) | 8% (17/211) | 2%(−4, 7)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Diarrhea | 10% (21/214) | 7% (15/211) | 3%(−3, 8)
Block 2004^75^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | | | | Vomiting | 5% (11/214) | 1% (2/211) | 4%(1, 7.5)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | Enrollment Time: 11/2003–1/2004 Place: United States Multicenter: 27 centers Inclusion: 6 mo–6 yr, Bulging tympanic membrane [TM], Loss of landmarks, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Presence of MEF by acoustic reflectometry, Otalgia, Decreased hearing, Ear fullness, AOM < 1 week Exclusion: Antibiotic within 2 weeks, Concomitant/Concurrent infection needing antibiotic treatment, Long acting antibiotic within 4 weeks, Otitis externa, Chronic suppurative OM, TM perforation/Otorrhea >24 hours, PE tubes/history of PE tubes | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | Treatment failure; By otoscopic findings:; Bulging tympanic membrane [TM]; Cloudy TM; Loss of landmarks; Erythematous TM; Air fluid level behind TM; Otorrhea; By Pneumatic otoscopy/tympanometry; Presence of MEF by acoustic reflectometry; By symptoms (otalgia, ear fullness); By otoscopy (distinct TM erythema); Other symptoms: fever; Other symptoms: decreased hearing; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Clinical success (cure or improve) on day 7–9 at end-of-therapy
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | | Azith | Cefdinir | Diff (95%CI)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | Total | 85% (149/176) | 87% (151/174) | −2% (−9, 5.3)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | 0–2yrs | 82% (54/66) | 81% (48/59) | 1% (−13, 15)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | >2yrs | 86% (95/110) | 90% (103/115) | −4% (−12, 4.5)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | Outcome: Adverse events
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | | Azith | Cefdinir | Diff (95%CI)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | Abn Stool | 4% (7/176) | 7% (12/174) | −3%(−8,2)
Block 2005^83^ | Jadad quality score 1 (0–5):3 [1,0,1,1,1] Definition: Presence of MEE, S&S of MEI | Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days vs. Cefdinir 7 mg/kg/day = bid for 5 days | | Influencing factors: Age Entering: N=357 N=181 Azithromycin N=176 Cefdinir Completing: N=350 N=176 Azithromycin N=174 Cefdinir Analyzed: N=350 N=176 Azithromycin N=174 Cefdinir | | Diarrhea | 3% (5/176) | 6% (10/174) | −3%(−6,0.6)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | Enrollment Time: 10/2003–7/2004 Place: Emergency room Inclusion: 3–17 yr, 34–35 lbs, Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Otalgia within last 3 days Exclusion: Any antibiotic, TM perforation/Otorrhea, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Neurological disease/impairment, Major Systemic disease/ condition, medical problem | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Reduction by 50% in pain score on day 30
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Lidocaine | Placebo | Diff (95%CI)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | By parent | 90% (28/31) | 63% (20/32) | 27%(6, 48)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | By doctor | 84% (26/31) | 66% (21/32) | 18% (−3.4,39)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Reduction by 25% in pain score on day 30
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Lidocaine | Placebo | Diff (95%CI)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | By parent | 95% (28/31) | 78% (25/32) | 21%(1, 41)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | By doctor | 90% (28/31) | 78% (25/32) | 12%(−6, 30)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Adverse events
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Lidocaine | Placebo | Diff (95%CI)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Ear Discharge
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | 6% (2/31) | 9% (3/32) | −3%(−16,10)
Bolt 2008^90^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. 2% aqueous lidocaine 3 drops hourly for 1 day | | Influencing factors: Examiner Entering: N=63 N=32 Placebo N=31 Lidocaine Completing: N=60 N=31 Placebo N=29 Lidocaine Analyzed: N=60 N=31 Placebo N=29 Lidocaine | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Dizziness | 10% (3/31) | 0% (0/32) | 10%(−0.8,20)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | Enrollment Time: 12/1996–2/1997 Place: United States Multicenter: 19 centers Inclusion: 3 mo–12 yr, <40 kg, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema) Exclusion: Penicillin/beta-lactams, Concomitant/Concurrent infection needing antibiotic treatment, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 24 hours, PE tubes/history of PE tubes, Cranio-facial, GI disorders/Liver, Renal Disorders, Major Systemic disease/ condition, medical problem, Metabolic/Inborn Errors of metabolism, Bowel function-altering meds within 48 hours, On other medication/treatment | Entering: N=453 N=230 Amoxicillin-clavulanate 45 mg N=223 Amoxicillin-clavulanate 90 mg Completing: N=404 N=207 Amoxicillin-clavulanate 45 mg N=197 Amoxicillin-clavulanate 90 mg Analyzed: N=404 N=207 Amoxicillin-clavulanate 45 mg N=197 Amoxicillin-clavulanate 90 mg | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Clinical success at the end of therapy
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | A-C 90 | A-C 45 | Diff (95% CI)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | 84.1%(149/177) | 78.8% (149/189) | 5% (−3, 13)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Global clinical success including recurrence on days 22–28
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | A-C 90 | A-C 45 | Diff (95%CI)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | 68.9% (122/177) | 67.9% (128/189) | 1% (−8, 10)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | A-C 90 | A-C 45 | Diff (95%CI)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Any | 45% (101/223) | 43% (98/230) | 3%(−6,12)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Need Tx | 24% (54/223) | 26% (61/230) | −2%(−10,5.7)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Cough | 11% (24/223) | 6% (14/230) | 5%(−0.4,10)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Fever | 5% (11/223) | 4% (8/230) | 1%(−2.3,5.1)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Dia Rash | 4% (9/223) | 5% (11/230) | −1%(−4.6,3)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Sev diarr | 10% (22/223) | 8% (19/230) | 2%(−3.7, 7)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Sev Rash | 1% (3/223) | 0% (0/230) | 1%(−0.2,2.8)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Sev erythema multiform
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | 0% (0/223) | 0.4% (1/230) | −0.4(−1.2,0.4)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Sev GI | 0% (0/223) | 0.4% (1/230) | −0.4(−1.2,0.4)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Sev moniliasis
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | 0.4% (1/223) | 0% (0/230) | 0.4(−0.4,1.2)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | URI | 3% (6/223) | 8% (19/230) | −6%(−10, −1.4)
Bottenfield 1998^97^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Vomiting | 6% (13/223) | 7% (16/230) | −1%(−5.7,3.3)
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; By otoscopic findings:; Bulging tympanic membrane [TM]; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Adverse effects of treatment | Outcome: Clinical success at the end of therapy (3rd visit)
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | | Cefaclor | | Cefprozil
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | Cured | *(18/19) | | 95.2% (20/21)
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | Partial cure | 0 | | 0
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | Failure | 0 | | 4.8% (1/21)
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | *Incomplete data | 1 | | 0
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | Outcome: Adverse events
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | | Cefaclor | Cefprozil | Diff995CI)
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | Any | 11% (2/19) | 0% (0/21) | 11% (−3, 24)
Carvalho 1998^84^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Other | Cefprozil 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / tid for 10 days | Inclusion: Otalgia, Fever, Irritability, Otoscopy characteristics Exclusion: Antibiotic within 7 days, Long acting antibiotic within 2 weeks, Cranio-facial, GI disorders/Liver, Renal Disorders | Entering: N=40 N=21 Cefprozil N=19 Cefaclor | | Vomiting | 0% (0/19 | 10% (2/21) | −10% (−23, 4)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | Study Time: 10/2001–10/2003 Place: Argentina Multicenter: 4 centers Inclusion: 6–48 mo, >6 kg, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Fever, New/first episode of AOM Exclusion: Penicillin/beta-lactams, Antibiotic within 2 weeks, Recurrent AOM, TM perforation/Otorrhea, Complication of OM, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient | Entering: N=289 N=149 Amoxicillin-clavulanate N=140 Amoxicillin Sulbactam Completing: N=234 N=117 Amoxicillin-clavulanate N=117 Amoxicillin Sulbactam Analyzed: N=234 N=117 Amoxicillin-clavulanate N=117 Amoxicillin Sulbactam | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Clinical success at days 12–14
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | A-C | A-S | Diff (95%CI)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | 98% (115/117) | 98% (115/117) | 0% (−3.3, 3.3)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Clinical success at days 28–42
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | A-C | A-S | Diff (95%CI)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | 95% (98/103) | 94% (97/103) | 1% (−5.2, 7)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Adverse events
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | A-C | A-S | Diff (95%CI)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Any | 27% (40/149) | 36% (50/140) | −9%(−20, 1.8)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Diarrhea, day 12–14
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | 3% (4/149) | 6% (8/140 | −3%(−8, 2)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Diarrhea, day 3
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | 5% (7/149) | 16% (23/140) | −12%(−19, −4.7)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Minor | 26% (39/149) | 36% (50/140) | −10%(−20, 1.2)
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Severe diarrhea
Casellas 2005^69^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80 mg/kg/day = bid for 10 days vs. Amoxicillin Sulbactam 80 mg/kg/day = bid for 10 days | | | Treatment failure; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | 0.7% (1/149) | 0.7% (1/140) | 0% (−1.9, 1.9)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | Study Time: 11/2001–3/2002 Place: Pediatric practice Multicenter: 22 centers Inclusion: 2–6 yr, Erythematous TM, Otalgia, Fever >38 C, Onset of AOM symptoms within 2 days before entry Exclusion: Allergic to other medication NOS, Antibiotic within 72 hours, GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient, Heme/Onc Disorders | Entering: N=410 N=204 Cefaclor 50 mg/5 days N=206 Cefaclor 40 mg/10 days Completing: N=400 N=204 Cefaclor 50 mg/5 days N=196 Cefaclor 40 mg/10 days Analyzed: N=400 N=204 Cefaclor 50 mg/5 days N=196 Cefaclor 40 mg/10 days | Treatment failure; By otoscopic findings:; Bulging tympanic membrane [TM]; Otorrhea; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Cured at end of therapy
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | | Cef 5D | Cef10D | Diff (95%CI)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | | 95.5% (195/204) | 94.8% (195/206) | 1%(−3.5, 4.9)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | Outcome: Adverse events
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | | Cef5D | Cef10D | Diff (95%CI)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | Any | 6% (12/204) | 8% (17/206) | −2%(−7, 3.2)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | Abd pain | 1.5% (3/204) | 2.4% (5/206) | −1%(−3.6, 1.8)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | Cut rash | 2.5% (5/204) | 2.9% (6/206) | −0.4%(−2.5,2.7)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | Diarrhea | 2.0% (4/204) | 2.4% (5/206) | −0.4%(−3.2,2.4)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | New OMA episode
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | | 9% (19/204) | 8% (17/206) | 1%(−4.5, 6.5)
Catania 2004^99^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Cefaclor 50 mg/kg/day = bid for 5 days vs. Cefaclor 40 mg/kg/day = bid for 10 days | | | | Vomiting | 0.5% (1/204) | 0.5% (1/206) | 0% (−1.4, 1.4)
Chao 2008^95^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Wait and see vs. Prescription to Hold | Study Time: 12/2005–11/2006 Place: Emergency room Inclusion: 2–12 yr, AOM Exclusion: Any antibiotic during present illness, Concomitant/Concurrent infection needing antibiotic treatment, AOM within 30 days, Cranio-facial, Immunosuppressed/compromised/deficient, No telephone, Prolonged ear pain | Entering: N=232 N=117 Wait and see N=115 Prescription to Hold Completing: N=206 N=100 Wait and see N=106 Prescription to Hold Analyzed: N=206 N=100 Wait and see N=106 Prescription to Hold | Parent satisfaction; Duration of AOM; Other antibiotic: No new abx Rx/no change in abx Rx | No clinical success rate studied. Adverse events not reported
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | Ceftriaxone 50 mg/kg/day = qd for 1 day vs. Ceftriaxone 50 mg/kg/day = qd for 1 day, Prednisolone 2 mg/kg/day / tid for 5 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day, Antihistamine 0.35 mg/kg/day / tid for 5 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day, Antihistamine 0.35 mg/kg/day / tid for 5 days, Prednisolone 2 mg/k | Enrollment Time: 7/1995–6/2000 Place: United States Hospital clinic/ outpatient Inclusion: 3 mo–6 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Fever, Recurrent AOM Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, PE tubes/history of PE tubes, Cranio-facial, Major Systemic disease/ condition, medical problem, On other medication/treatment, Exposure to varicella w/in 3 weeks | Completing: N=179 N=46 Placebo N=45 Prednisolone N=44 Antihistamine N=44 Prednisolone & antihistamine Analyzed: N=179 N=46 Placebo N=45 Prednisolone N=44 Antihistamine N=44 Prednisolone & antihistamine | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | Outcome: Clinical success on days 5–14
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | Corticosteroid | Placebo | Diff (95%CI)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | 84.4% (38/45) | 78.3% (36/46) | 6%(−10, 22)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | Antihistamine | Placebo | Diff (95%CI)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | 75.0% (33/44) | 78.3% (36/46) | −3%(−21, 14)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | Both drug | Placebo | Diff (95%CI)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | 88.6% (39/44) | 78.3% (36/46) | 10%(−5.1, 26)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | Corticosteroid | Antihistamine | Diff (95%CI)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | 84.4% (38/45) | 75.0% (33/44) | 9% (−7, 26)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | Corticosteroid | Both drugs | Diff (95%CI)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | 84.4% (38/45) | 88.6% (39/44) | −4%(−18, 10)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | Antihistamine | Both drugs | Diff (95%CI)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | | 75.0% (33/44) | 88.6% (39/44) | −14%(−30,2.5)
Chonmaitree 2003^101^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Presence of MEE, S&S of MEI | | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; PE tube placement; Healthcare utilization | Adverse events not reported
Cifaldi 2004^74^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Cefdinir 14 mg/kg/day / bid for 5 days | Place: Multicenter Inclusion: 6 mo–6 yr, AOM Exclusion: NR | Influencing factors: Age | Parent satisfaction; Cost outcomes; Compliance; Tolerability | This study does not report clinical success. It reports parent-reported outcomes.
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | Enrollment Time: 2/1995–5/1996 Place: France Multicenter Inclusion: 4–30 mo, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, S&S of middle ear inflammation (MEI), Otalgia, Fever Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, TM perforation/Otorrhea, PE tubes/history of PE tubes, Major Systemic disease/ condition, medical problem | Influencing factors: Parent/caretaker Entering: N=385 N=191 Amoxicillin-clavulanate 10 day N=194 Amoxicillin- clavulanate 5 day Completing: N=331 N=168 Amoxicillin- clavulanate 10 day N=163 Amoxicillin- clavulanate 5 day Analyzed: N=378 N=186 Amoxicillin-clavulanate 10 day N=192 Amoxicillin- clavulanate 5 day | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures; Otologic complications, i.e., cholestetoma; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success (cure or improve) per protocol population By outcome days
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | | Amox-clav 5d | Amox-clav 10d | Diff (95%CI)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | 12–14 d | 76.7% (125/163) | 88.1% (148/168) | −11%(−20, −3.2)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | 28–42 d | 40.4% (57/141) | 46% (64/139) | −5.6%(−17, 6)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Outcome: Clinical success 9cure or improve) per protocol population by setting of child care
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | | Amox-clav 5d | Amox-clav 10d | Diff (95%CI)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Home | 85.1% (57/67) | 89.6% (69/77) | −4.5%(−15, 6)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Caretaker | 70.8% (68/96) | 86.8% (79/91) | −16% (−28, − 4)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Sitter | 73.6% (39/53) | 88.6% (39/44) | −15%(−31, 0.9)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Day-care | 67.3% (29/43) | 85.1% (40/47) | −18%(−35, 0.3)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Outcome: Adverse events
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | | Amox-clav 5d | Amox-clav 10d | Diff (95%CI)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Any | 45% (88/194) | 43% (80/188) | 2.8%(−7, 13)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Drug-related
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | | 31% (60/194) | 29% (55/188) | 2%(−8,, 11)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Diarrhea | 23% (44/194) | 26% (49/188) | −3%(−12, 5.2)
Cohen 1998^98^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80/10 for 5 days | | | | Skin rash | 4% (8/194) | 7% (13/188) | −3%(−7, 1.8)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | Enrollment Time: 2/1995–5/1996 Place: France Multicenter Inclusion: 4–30 mo, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Otalgia, Otoscopy (distinct TM erythema), Fever Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, TM perforation/Otorrhea, PE tubes/history of PE tubes, Major Systemic disease/ condition, medical problem | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | Treatment failure; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures; Otologic complications, i.e., cholestetoma; PE tube placement | Outcome: Success rate at days 12–14:
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | Amox-clav | Ceftriaxon | Diff (95%CI)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Per Protocol
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 82.5% (188/228) | 79.2% (186/235) | 3% (−3.9, 10)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Intent-to-treat
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 77.1% (199/258) | 74.5% (190/255) | 3% (−4.8, 10)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Outcome: Success rate at days 28–42:
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | Amox-clav | Ceftriaxon | Diff (95%CI)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Per Protocol
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 55.1% (103/187) | 59.0% (108/183) | −4% (−14, 6.2)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Intent-to-treat
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 55.8% (111/199) | 58.9% (112/190) | −3% (−13, 6.7)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Outcome: Otitis media with effusion at days 28–42:
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | Amox-clav | Ceftriaxon | Diff (95%CI)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Per Protocol
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 20.3% (38/187) | 16.9% (31/183) | 3% (−4.5, 11)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Intent-to-treat
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 20.6% (41/199) | 16.3% (31/190) | 4% (−3.4, 12)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Outcome: Other infections at days 28–42:
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | Amox-clav | Ceftriaxon | Diff (95%CI)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Per Protocol
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 9.1% (17/187) | 11.5% (21/183) | −2% (−9, 3.8)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Intent-to-treat
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | 8.0% (16/199) | 10.5% (20/190) | −2.5% (−8, 3)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Outcome: Adverse events
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | | Amox-clav | Ceftriaxon | Diff (95%CI)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Any | 31% (79/258) | 14% (36/255) | 16%(9, 24)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | Diarrhea | 27% (70/258) | 14% (36/255) | 13%(6, 20)
Cohen 1999^77^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 80/10 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone Completing: N=463 N=228 Amoxicillin- clavulanate N=235 Ceftriaxone Analyzed: N=513 N=258 Amoxicillin-clavulanate N=255 Ceftriaxone | | The article also publishes data on the carriage of Streptococcus pneumoniae, Haemophilus influenzae and Moraxella catarrhalis before treatment and at Days 12 to 14.
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | Enrollment Time: 10/1996–4/1997 Place: France Multicenter Inclusion: 4–30 mo, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Otalgia, Otoscopy (distinct TM erythema), Fever Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, TM perforation/Otorrhea, PE tubes/history of PE tubes, Major Systemic disease/ condition, medical problem | Influencing factors: Age, Parent/caretaker Entering: N=450 N=223 Cefpodoxime 10 day N=227 Cefpodoxime 5 day Completing: N=418 N=210 Cefpodoxime 10 day N=208 Cefpodoxime 5 day Analyzed: N=448 N=222 Cefpodoxime 10 day N=226 Cefpodoxime 5 day | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Clinical success (cure or improve) on day 12–14 per protocol population
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | CPD 5d | CPD 10d | Diff (95%CI)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Total | 84.1% (175/208) | 92.4% (194/210) | −8% (−14, −2.1)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Data by age group not reported. Multivariable analysis showed the response to treatment was significantly influenced by the treatment duration, the day-care modality, age, and a history of otitis media with effusion. Outcome: Clinical success (cure or improve) on day 28–42 per protocol population
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | CPD 5d | CPD 10d | Diff (95%CI)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Total | 85.4% (134/157) | 83.7% (144/172) | −2% (−6, 9)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Relapse or recurrence
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | CPD 5d | CPD 10d | Diff (95%CI)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Total | 14.6% (23/157) | 16.3% (28/172) | −2% (−9, 6.1)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: clinical success (cure or improve) per protocol population by day-care modality
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | CDP 5d | CDP 10d | Diff (95%CI)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Home | 88.1% (74/84) | 92.2% (95/103) | −4.1%(−13, 4)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Caretaker | 81.4% (101/124) | 92.5% (99/107) | −11%(−20, −2)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Sitter | 86.8% (66/76) | 100%(47/47) | −13%(−23, −3)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Day-care | 72.9% (35/48) | 86.7% (52/60) | −14%(−29, 1)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | CDP 5d | CDP 10d | Diff (95%CI)
Cohen 2000^100^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 8 mg/kg/day / bid for 10 days vs. Cefpodoxime 8 mg/kg/day / bid for 5 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Any | 12% (26/224) | 16% (36/222) | 3% (−11, 1.8)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | Enrollment Time: 12/1997–8/1998 Place: United States, Israel, Dominican Republic Multicenter: 12 centers Inclusion: 6–48 mo, <41 kg, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Loss of landmarks, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia within last 24 hours, Otoscopy (distinct TM erythema), Ear fullness Exclusion: Allergic to other medication NOS, Penicillin/beta-lactams, Macrolides, Antibiotic within 72 hours, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 24 hours, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Immunosuppressed/compromised/deficient, Other Infectious diseases (meningitis), On other medication/treatment | Influencing factors: Pathogen Entering: N=238 N=118 Amoxicillin-clavulanate N=120 Azithromycin Completing: N=169 N=84 Amoxicillin-clavulanate N=85 Azithromycin Analyzed: N=136 N=65 Amoxicillin-clavulanate N=71 Azithromycin | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Clinical success at days 12–14
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Pathogen | Amox-clav | Azithromycin | Diff (95%CI)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | All type | 86% (60/70) | 70% (51/73) | 16%(2, 30)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | HF | 91% (30/33) | 65% (22/34) | 26% (6, 46)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | SP | 86% (18/21) | 80% (16/20) | 6% (−17, 29)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Others | 75% (12/16) | 68% (13/19) | 7% (−23, 37)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Clinical success at days 22–28
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Pathogen | Amox-clav | Azithromycin | Diff (95%CI)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | All type | 71% (46/65) | 66% (44/67) | 5%(−11,21)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | HF | 81% (25/31) | 58% (18/31) | 23%(0.1, 46)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | SP | 62% (13/21) | 72% (13/18) | −10%(−40,20)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Others | 62% (8/13) | 72% (13/18) | −10%(−43,23)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Bacteriologic success at days 4–6
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Pathogen | Amox-clav | Azithromycin | Diff (95%CI)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | All type | 83% (64/65) | 49% (35/71) | 34%(18, 50)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | HF | 87% (26/30) | 39% (13/33) | 48%(24, 72)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | SP | 90% (18/20) | 68% (13/19) | 22%(−3.4, 47)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Others | 67% (10/15) | 47% (9/19) | 20%(−14, 54)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Adverse events
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Azithromycin | Diff (95%CI)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Any | 27% (32/118) | 22% (26/120) | 3% (−11, 1.8)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Related to treatment
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | 10% (12/118) | 2% (2/120) | 8% (2.5, 14)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Diarrhea | 8% (9/118) | 4% (5/120) | 3% (−2.6, 9)
Dagan 2000^7^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 1 day, ---5 mg/kg/day = qd for 4 days | | | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Vomiting | 8% (10/118) | 0% (0/120) | 8% (3.4, 14)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Place: Israel Emergency room Inclusion: 3–36 mo, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Fever, Onset of AOM symptoms within 7 days before entry, Tympanocentesis preformed Fluid obtained, Irritability, Other constitutional symptoms NOS Exclusion: Antibiotic within 72 hours, Concomitant/Concurrent infection needing antibiotic treatment, Chronic suppurative OM, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), Lack of effusion on tympanocentesis, TM perforation/Otorrhea, Endocrine disorders (diabetes), Immunosuppressed /compromised/deficient | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Clinical success
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Day 10 | 85% (50/59) | 82% (51/62) | 3%(−10, 16)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Bacteriologic success in initially culture-positive cases
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | SP | 63% (17/27) | 71% (12/17) | 8%(−37, 21)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | HF | 48% (12/25) | 47% (14/30) | 1%(−26, 28)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Others | 100% (4/4) | 100% (4/4) | 0% (0, 0)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Bacteriologic success in initially culture-negative cases
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | SP | 81% (26/32) | 98% (45/46) | −17%(−30, −4)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | HF | 88% (30/34) | 85% (28/33) | 3%(−13, 19)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Others | 95% (52/55) | 98% (58/59) | −3%(−10, 4)
Dagan 2000^81^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Influencing factors: Pathogen Entering: N=138 N=68 Cefaclor N=70 Azithromycin Completing: N=122 N=59 Cefaclor N=63 Azithromycin Analyzed: N=122 N=59 Cefaclor N=63 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Adverse events not reported by drug arm.
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | Study Time: 2/1996–5/1998 Place: Netherlands Multicenter: 53 centers Office setting/ private practice, General/ family practice Inclusion: 6–24 mo, Acute onset S&S (parent/guardian report), Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Otorrhea, S&S of middle ear inflammation (MEI), Otalgia, Fever, Irritability, Other constitutional symptoms NOS Exclusion: Penicillin/beta-lactams, Antibiotic within 4 weeks, Cranio-facial, Immunosuppressed /compromised/deficient | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Outcome: Clinical outcome at day 4
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | Amoxicillin | Placebo | Diff (95% CI)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | No persistent symptoms
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | 41% (48/117) | 28% (34/123) | 13% (1, 25)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Improvement in eardrum
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | 23% (26/114) | 17% (21/120) | 6% (−4, 16)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Outcome: Clinical success at day 11
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | Amoxicillin | Placebo | Diff (95% CI)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | 36% (40/112) | 30% (36120) | 6% (−6, 18)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Outcome: Middle ear effusion present at 6 weeks
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | Amoxicillin | Placebo | Diff (95% CI)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | 64% (69/107) | 67% (70/105) | 3% (−10, 16)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Outcome: Adverse effects - Diarrhea
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | Amoxicillin | Placebo | Diff (95% CI)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Day 4 | 17% (20/117) | 10% (12/123) | −7% (−16, 2)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Day 10 | 12% (14/117) | 8% (10/123) | −4% (−12, 4)
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Outcome: Duration of symptoms in days
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | | Amoxicillin Median | Placebo Median | p-value
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Fever | 2 | 3 | 0.004
Damoiseaux 2000^88^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, S&S of MEI | Placebo vs. Amoxicillin 40 mg/kg/day / tid for 10 days | | Entering: N=240 N=123 Placebo N=117 Amoxicillin Completing: N=235 N=120 Placebo N=115 Amoxicillin Analyzed: N=235 N=120 Placebo N=115 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Adverse effects of treatment | Pain/crying | 8 | 9 | 0.43
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | Study Time: 8/1996–3/1998 Place: Multicenter: 18 centers Inclusion: 2 mo–12 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Loss of landmarks, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Decreased hearing, Ear fullness Exclusion: Penicillin/beta-lactams, Antibiotic within 10 days, Concomitant/Concurrent infection needing antibiotic treatment, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 24 hours, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Investigational drug within 30 days | Entering: N=415 N=206 Amoxicillin-clavulanate 40/10 TID N=209 Amoxicillin-clavulanate 45/6.4 BID Completing: N=324 N=151 Amoxicillin-clavulanate 40/10 TID N=173 Amoxicillin-clavulanate 45/6.4 BID Analyzed: N=386 N=187 Amoxicillin-clavulanate 40/10 TID N=199 Amoxicillin-clavulanate 45/6.4 BID | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); By otoscopy (distinct TM erythema); Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success at the end of therapy on day 7–12
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | A-C BID | A-C TID | Diff (95%CI)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 94.0% (187/199) | 94.1% (175/186) | 0.1%(−4.8,4.6)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Outcome: Clinical success at follow-up on day 38–42
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | A-C BID | A-C TID | Diff (95%CI)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 93.3% (168/180) | 87.9% (153/174) | 5.4%(−0.7, 12)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Outcome: Bacteriological success at end of therapy on day 7–12
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | A-C BID | A-C TID | Diff (95%CI)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 77.8% (7/9) | 84.6% (11/13) | −7%(−40, 26)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Outcome: Adverse events
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | A-C BID | A-C TID | Diff (95%CI)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | At least 1 treatment related
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 12% (25/209) | 18% (37/206) | −6%(−13, 0.9)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Abdominal pain or enteritis or fever or rash
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 0.5% (1/209) | 0% (0/206) | 0.5%(−0.5,1.5)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Constipation or ear disorder or enlarged abdomen or enterocolitis or erythematous rash or somnolence or stomatitis (ulcerative)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 0% (0/209) | 0.5% (1/206) | −0.5%(−1.5,0.5)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Dermatitis
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 0.5% (1/209) | 1.9% (4/206) | −1.4%(−3.5,0.7)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Diarrhea | 7% (15/209) | 11% (22/206) | −3.5%(−9, 2.8)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Nervous | 1% (2/209) | 0% (0/206) | −0.5%(−0.4,2.4)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Otitis media
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | | 0.5% (1/209) | 1% (2/206) | −0.5%(−2.2,1.2)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Urticaria | 0% (0/209) | 1.5% (3/206) | −1.5%(−3.2,0.2)
Damrikarnlert 2000^6^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 40/10 mg/kg/day / tid for 7–10 days vs. Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 7–10 days | | | | Vomiting | 2% (4/209) | 0.5% (1/206) | 1.4%(−0.7,3.5)
De Diego 2001^128^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Amoxicillin 20 mg/kg/day = qd for 12 weeks vs. Azithromycin 10 mg/kg/day = q week for 12 weeks | Study Time: 1/1998–5/1999 Inclusion: Recurrent AOM | Entering: N=71 N=40 Amoxicillin N=31 Azithromycin Completing: N=69 N=38 Amoxicillin N=31 Azithromycin Analyzed: N=69 N=38 Amoxicillin N=31 Azithromycin | Disease recurrence; Adverse effects of treatment | Outcome: Effective rate (#AOM episodes dropped to <50% after prophylaxis) in 6–27 months
De Diego 2001^128^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Amoxicillin 20 mg/kg/day = qd for 12 weeks vs. Azithromycin 10 mg/kg/day = q week for 12 weeks | Study Time: 1/1998–5/1999 Inclusion: Recurrent AOM | Entering: N=71 N=40 Amoxicillin N=31 Azithromycin Completing: N=69 N=38 Amoxicillin N=31 Azithromycin Analyzed: N=69 N=38 Amoxicillin N=31 Azithromycin | Disease recurrence; Adverse effects of treatment | | Amoxicillin | Azithromycin | Diff (95%CI)
De Diego 2001^128^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Amoxicillin 20 mg/kg/day = qd for 12 weeks vs. Azithromycin 10 mg/kg/day = q week for 12 weeks | Study Time: 1/1998–5/1999 Inclusion: Recurrent AOM | Entering: N=71 N=40 Amoxicillin N=31 Azithromycin Completing: N=69 N=38 Amoxicillin N=31 Azithromycin Analyzed: N=69 N=38 Amoxicillin N=31 Azithromycin | Disease recurrence; Adverse effects of treatment | | 89% (34/38) | 81% (25/31) | 9% (−8, 26)
De Diego 2001^128^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Amoxicillin 20 mg/kg/day = qd for 12 weeks vs. Azithromycin 10 mg/kg/day = q week for 12 weeks | Study Time: 1/1998–5/1999 Inclusion: Recurrent AOM | Entering: N=71 N=40 Amoxicillin N=31 Azithromycin Completing: N=69 N=38 Amoxicillin N=31 Azithromycin Analyzed: N=69 N=38 Amoxicillin N=31 Azithromycin | Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
De Diego 2001^128^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Amoxicillin 20 mg/kg/day = qd for 12 weeks vs. Azithromycin 10 mg/kg/day = q week for 12 weeks | Study Time: 1/1998–5/1999 Inclusion: Recurrent AOM | Entering: N=71 N=40 Amoxicillin N=31 Azithromycin Completing: N=69 N=38 Amoxicillin N=31 Azithromycin Analyzed: N=69 N=38 Amoxicillin N=31 Azithromycin | Disease recurrence; Adverse effects of treatment | | Amoxicillin | Azithromycin | Diff (95%CI)
De Diego 2001^128^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Not specified | Amoxicillin 20 mg/kg/day = qd for 12 weeks vs. Azithromycin 10 mg/kg/day = q week for 12 weeks | Study Time: 1/1998–5/1999 Inclusion: Recurrent AOM | Entering: N=71 N=40 Amoxicillin N=31 Azithromycin Completing: N=69 N=38 Amoxicillin N=31 Azithromycin Analyzed: N=69 N=38 Amoxicillin N=31 Azithromycin | Disease recurrence; Adverse effects of treatment | GI | 2.5% (1/40) | 0% (0/31) | 2.5%(−3. 8)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | Enrollment Time: 5/2003–5/2004 Inclusion: 6 mo–12 yr, Otorrhea, AOM < 3 weeks, Patent tympanostomy tubes Exclusion: Any antibiotic, Antibiotic within 3 days, Any complications requiring antibiotics, Concomitant/Concurrent infection needing antibiotic treatment, Topical antibiotic drops prior to study, Otitis externa, TM perforation/Otorrhea >3 weeks, Complication of OM, History of otic/ME surgery (excluding tubes), Cranio-facial, Endocrine disorders (diabetes), GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient, On other medication/treatment, Menarche | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Clinical cure or absence of otorrhea at test-of-cure visit on day 18–21
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Ciprodex | Diff (95%CI)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | | 58.5% (24/41) | 84.6% (33/39) | −26%(−46, −6)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Adverse events
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Ciprodex | Diff (95%CI)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Any | 29% (12/41) | 13% (5/39) | 16%(−1.4,34)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Dermatitis | 7% (3/41) | 0% (0/39) | 7%(−1,16)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Device block or taste perversion
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | | 0% (0/41) | 3% (1/39) | −3%(−8,2.3)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Diarrhea | 20% (8/41) | 0% (0/39) | 20%(6.4,33)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Ear pain | 0% (0/41) | 5% (2/39) | −5%(−12,1.7)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Gastroenteritis
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | | 5% (2/41) | 0% (0/39) | 5%(−2,12)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Infection skin or nausea or oral moniliasis
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | | 2.4% (1/41) | 0% (0/39) | 2.4%(−2.4,7)
Dohar 2006^80^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Not specified | Amoxicillin-clavulanate 90 mg/kg/day / bid for 10 days vs. Ciprodex drops 4 drops = bid for 7 days | | Entering: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex Analyzed: N=80 N=41 Amoxicillin-clavulanate N=39 Ciprodex | Treatment failure; By otoscopic findings:; Otorrhea; Bacteriologic cure/failure; Adverse effects of treatment | Vomiting | 2.4% (1/41) | 2.6% (1/39) | −0.2%(−7, 7)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Study Time: 1/2000–3/2000 Place: Multicenter: 28 centers Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Loss of landmarks, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Presence of MEF by acoustic reflectometry, S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Decreased hearing, Ear fullness, Fever Exclusion: Penicillin/beta-lactams, Macrolides, Any antibiotic, Antibiotic within 30 days, Other antibiotic Tx, AOM of more than 4 weeks duration, Metabolic/Inborn Errors of metabolism | Influencing factors: Age Entering: N=373 N=185 Amoxicillin-clavulanate N=188 Azithromycin Completing: N=362 N=180 Amoxicillin-clavulanate N=182 Azithromycin Analyzed: N=362 N=180 Amoxicillin-clavulanate N=182 Azithromycin | Treatment failure; Presence of MEF by otoscopic findings; Bulging tympanic membrane [TM]; Loss of landmarks; Impaired TM mobility; Presence of MEF by acoustic reflectometry; Adverse effects of treatment | Outcome: Clinical success (cure+improvement) at day 10
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Amox-clav | Azithro | Diff (95%CI)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | All ages | 88% (159/181 | 83% (153/183) | 5%(−2, 12)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | <=2 yrs | 85% (44/52) | 76% (45/59) | 9% (−6, 24)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | >2 yrs | 73% (94/129) | 86% (108/126) | −13%(−23, −3)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Outcome: Clinical success (cure+improvement) at day 24–28
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Amox-clav | Azithro | Diff (95%CI)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | All ages | 69% (124/180) | 74% (134/182) | −5%(−14, 4.3)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | <=2 yrs | 58% (30/52) | 60% (35/58) | −2%(−20, 16)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | >2 yrs | 73% (94/128) | 80% (99/124) | −7% (−18, 3.5)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Outcome: Signs of tympanic membrane disease at day 10
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Amox-clav | Azithro | Diff (95%CI)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Bulging | 13% (23/178) | 22% (40/183) | −9%(−17, −1.1)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Loss of landmarks
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | 20% (36/178) | 31% (56/183) | −11%(−20, −2)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Impaired mobility
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | 28% (46/162) | 39% (67/170) | −11%(−21, −0.8)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Outcome: Signs of tympanic membrane disease at day 24–28
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Amox-clav | Azithro | Diff (95%CI)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Bulging | 16% (29/176) | 10% (17/177) | 6% (−1, 13)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Loss of landmarks
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | 22% (38/176) | 11% (20/178) | 11% (3.3, 19)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Impaired mobility
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | 26% (42/160) | 18% (29/164) | 8%(−1, 17)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Outcome: Abnormal acoustic reflectometry
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Amox-clav | Azithro | Diff (95%CI)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Day 10 | 63% (109/174) | 61% (108/176) | 2%(−8, 12)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Day 24–28 | 59% (100/170) | 45% (77/170) | 14%(3.4, 25)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Outcome: Adverse events
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | | Amox-clav | Azithro | Diff (95%CI)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Any | 20% (37/185) | 11% (21/188) | 9% (1.4, 16)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Diarrhea | 15% (27/185) | 6% (11/188) | 9% (2.6, 15)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Rash | 4% (8/185) | 0% (0/188) | 4% (1.4, 7)
Dunne 2003^70^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | | Vomiting | 1% (2/185) | 2% (4/188) | −1%(−3.5,1.5)
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | Study Time: 12/1999–12/2002 Place: United States Office setting/ private practice, Pediatric practice Inclusion: >3 mo, <18 kg, AOM, AOM requiring antibiotic, Age of child Upper age limit not specified, Weight of child Lower weight limit not specified Exclusion: Penicillin/beta-lactams, Concomitant/Concurrent infection needing antibiotic treatment, Other antibiotic Tx, Unable/unlikely to return to follow-up | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success at 3–4 day visit
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Amox-low dose | Amox-high dose | Diff (95%CI)
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 95% (68/76) | 88% (66/75) | 7%(−2, 16)
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Adverse events
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Amox-low dose | Amox-high dose | Diff (95%CI)
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Skin rash | 15% (11/75) | 12% (9/77) | 3%(−8, 14)
Garrison 2004^96^ | Jadad quality score 1 (0–5):2 [1,1,0,0,0] Definition: Not specified | Amoxicillin 40–45 mg/kg/day for 5–10 days vs. Amoxicillin 80–90 mg/kg/day for 5–10 days | | Entering: N=162 N=80 Amoxicillin 40–45 N=82 Amoxicillin 80–90 Completing: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 Analyzed: N=151 N=76 Amoxicillin 40–45 N=75 Amoxicillin 80–90 | Treatment failure; Disease recurrence; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | GI distress | 30% (22/74) | 33% (25/76) | −3%(−18, 12)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Study Time: 6/2002–4/2004 Place: Turkey Hospital clinic/ outpatient Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Loss of landmarks, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Fever Exclusion: Penicillin/beta-lactams, Macrolides, Antibiotic within 2 weeks, Chronic suppurative OM, TM perforation/Otorrhea 24 hours, GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient, Major Systemic disease/ condition, medical problem | Influencing factors: Pathogen Entering: N=180 N=86 Amoxicillin-clavulanate N=94 Azithromycin Completing: N=174 N=84 Amoxicillin-clavulanate N=90 Azithromycin Analyzed: N=174 N=84 Amoxicillin-clavulanate N=90 Azithromycin | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Clinical cure (complete resolution of signs and symptoms
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithromycin | Diff (95%CI)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Day2–4 | 37% (32/86) | 36% (32/90) | 1%(−13, 15)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Day11–13 | 81% (68/84) | 78% (70/90) | 3%(−9, 15)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Day26–28 | 88% (74/80) | 78% (70/78) | 10%(−2, 22)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Clinical cure (complete resolution of signs and symptoms
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Culture | Amox-clav | Azithromycin | Diff (95%CI)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Negative | 80% (24/30) | 100% (38/38) | −20%(−34, −6)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | SP | 100% (10/10) | 67% (20/30) | 33% (2, 64)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Others | 88% (28/32) | 71% (10/14) | 17% (−7, 41)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Reinfection rate
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithromycin | Diff (95%CI)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Day26–28 | 5% (4/84) | 13% (12/90) | −8%(−17, 0.6)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Persistence of MEE
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithromycin | Diff (95%CI)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Day11–13 | 19% (16/84) | 22% (20/90) | −3%(−15, 9)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Day26–28 | 8% (6/80) | 10% (8/78) | −2%(−11, 7)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Side effects
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Azithromycin | Diff (95%CI)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Any | 5% (4/84) | 4% (4/90) | 1%(−5.2, 7)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Abd pain | 5% (4/84) | 0% (0/90) | 5%(0.3, 9)
Guven 2006^52^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | | Treatment failure; Disease recurrence; Adverse effects of treatment | Diarrhea | 0% (0/84) | 4% (4/90) | 4%(−9, 0)
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | Study Time: 3/2001–12/2002 Place: Hospital Inclusion: 1–4 yr, Recurrent AOM, OME Exclusion: PE tubes/history of PE tubes, Respiratory Illness, Cranio-facial, Endocrine disorders (diabetes), Adenoidectomy and/or tonsillectomy | Influencing factors: Recurrent otitis media/ otitis prone Entering: N=217 N=108 Tubes N=109 Tubes & Adenoid Completing: N=207 N=103 Tubes N=104 Tubes & Adenoid Analyzed: N=198 N=96 Tubes N=102 Tubes & Adenoid | Disease recurrence; Adverse effects of treatment | Outcome: Number of otitis media episodes during 1-year follow-up
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | | Mean±SD (n) | Mean±SD (n)
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | | Adeno+Tympan: | Tympan only: | Diff (95%CI)
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | | 1.9 ± 1.9 (74) | 1.6 ± 1.6 (72) | 0.3(−0.9, 0.9)
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | | Adeno+Tympan: | Tympan only: | Diff (95%CI)
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | Neck abscess or type 1 diabetes
Hammaren-Malmi 2005^132^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Acute onset of S&S, S&S of MEI | Tympanostomy tubes vs. Adenoidectomy, Tympanostomy tubes | | | Disease recurrence; Adverse effects of treatment | | 0% (0/109) | 1% (1/108) | −1%(−3, 1)
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | Study Time: 9/2001–4/2002 Place: Finland Inclusion: 10 mo–6 yr, Recurrent AOM Exclusion: OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), History of otic/ME surgery (excluding tubes), PE tubes/history of PE tubes, Cranio-facial, Major Systemic disease/ condition, medical problem | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | Outcome: Success rate (% <4 URI) during 6-month intervention
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | | Probiotic | Placebo | Diff (95%CI)
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | | 28% (38/135) | 18% (24/134) | 10% (0.2, 20)
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | Outcome: Success rate (%<6URI) during 6-month intervention
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | | Probiotic | Placebo | Diff (95%CI)
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | | 80% (108/135) | 70% (94/134) | 10% (−0.5, 20)
Hatakka 2007^91^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Probiotic bacteria 1 capsule = qd for 24 weeks | | Entering: N=309 N=154 Placebo N=155 Probiotic bacteria Completing: N=269 N=134 Placebo N=135 Probiotic bacteria Analyzed: N=269 N=134 Placebo N=135 Probiotic bacteria | Disease recurrence; Duration of AOM | Adverse events not reported
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | Place: United States, Costa Rica Multicenter Inclusion: 6 mo–7 yr, Bulging tympanic membrane [TM], Cloudy TM, Loss of landmarks, Air fluid level behind TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otalgia, Decreased hearing, Ear fullness Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, Concomitant/Concurrent infection needing antibiotic treatment, Recurrent AOM (>2 episodes in 6 months), Otitis externa, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 48 hours, Complication of OM, PE tubes/history of PE tubes, Respiratory Illness, Cranio-facial, GI disorders/Liver, Renal Disorders, Major Systemic disease/ condition, medical problem, Metabolic/Inborn Errors of metabolism, Investigational drug within 1 month | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Outcome: Clinical success (cure or improved) at day 4–7 after treatment by Age
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | | A-C | Cefprozil | Diff (95%CI)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Total | 89% (116/130) | 87% (110/127) | 2% (−6, 10)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | <2 yrs | 86% (55/64) | 80% (47/59) | 6% (−7, 19)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | 2–7yrs | 92% (61/66) | 93% (63/68) | −1% (−10, 8)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Outcome: Clinical success (cure or improved) at day 4–7 after treatment by Laterality
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | | A-C | Cefprozil | Diff (95%CI)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Total | 89% (116/130) | 87% (110/127) | 2% (−6, 10)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Unilateral | 93% (66/71) | 89% (73/82) | 4% (−5.2, 13)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Bilateral | 85% (50/59) | 82% (37/45) | 3% (−11, 17)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Outcome: Clinical success (cure or improved) at day 4–7 after treatment by Severity
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | | A-C | Cefprozil | Diff (95%CI)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Total | 89% (116/130) | 87% (110/127) | 2% (−6, 10)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Moderate | 92% (83/90) | 85% (64/75) | 7% (−2.7, 17)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Severe | 82% (32/39) | 88% (45/51) | −6% (−21, 9)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Outcome: Adverse events
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | | A-C | Cefprozil | Diff (95%CI)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Any | 32% (49/153) | 19% (28/150 | 13%(3.5, 23)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Diarrhea | 19% (29/153) | 9% (14/150) | 10%(1.8,18)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Rash | 11% (16/153) | 6% (9/150) | 5%(−1.7,11)
Hedrick 2001^76^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin-clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Cefprozil 30 mg/kg/day / bid for 10 days | | Influencing factors: Hearing deficit and severity, Laterality, Age Completing: N=303 N=153 Amoxicillin-clavulanate N=150 Cefprozil Analyzed: N=292 N=146 Amoxicillin-clavulanate N=146 Cefprozil | Treatment failure; Adverse effects of treatment | Vomiting | 6% (9/153) | 2% (3/150) | 4%(−0.5, 8)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | Study Time: 1/1996–1/1997 Place: United States Office setting/private practice, Pediatric practice Inclusion: 18 mo–6 yr, Presence of middle ear effusion (MEE), Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otalgia, Fever Exclusion: Antibiotic within 1 week, TM perforation/Otorrhea, History of otic/ME surgery (excluding tubes), PE tubes/history of PE tubes, Cranio-facial, Major Systemic disease/condition, medical problem, On other medication/treatment, Adenoidectomy and/or tonsillectomy, Prolonged ear pain | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | Outcome: Clinical success at different time points
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | | Homeopathic | Placebo | Diff (95%CI)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | 5-day | 81% (29/36) | 69% (27/39) | 11%(−8, 31)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | 2-wk | 69% (25/36) | 51% (20/39) | 18%(−4, 40)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | 6-wk | 58% (21/36) | 38% (15/39) | 20%(−3, 42)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | Outcome: Absence of MEE
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | | Homeopathic | Placebo | Diff (95%CI)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | 2-wk | 28% (10/36) | 23% (9/39) | 5%(−15, 24)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | 6-wk | 44% (16/36) | 59% (23/39) | −14%(−37, 8)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | Outcome: Adverse events
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | | Homeopathic | Placebo | Diff (95%CI)
Jacobs 2001^92^ | Jadad quality score 1 (0–5):4 [1,1,1,0,1] Definition: Presence of MEE, S&S of MEI | Placebo vs. Homeopathic NOS 3 pellets = tid for 5 days | | Influencing factors: Middle ear effusion Entering: N=75 N=39 Placebo N=36 Homeopathic Completing: N=72 N=38 Placebo N=34 Homeopathic Analyzed: N=75 N=39 Placebo N=36 Homeopathic | Treatment failure; Presence of MEE [also persistent effusion, OME]; Adverse effects of treatment | Any | 0% (0/36) | 0% (0/39) | 0% (0, 0)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | Study Time: 4/1994–4/1997 Place: Finland Hospital clinic/outpatient Inclusion: 10–24 mo, Recurrent AOM Exclusion: Any antibiotic during present illness, History of otic/ME surgery (excluding tubes), PE tubes/history of PE tubes, Cranio-facial, Immunosuppressed/compromised/deficient | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 6 months
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Sulfafurazole | Placebo | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | 63% (29/46) | 45% (21/47) | 18% (−2, 39)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 2 years
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Sulfafurazole | Placebo | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | 34% (14/41) | 22% (10/45) | 12% (−7, 31)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 6 months
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Sulfafurazole | Adenoidectomy | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | 63% (29/46) | 58% (34/59) | 5% (−14, 24)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 2 years
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Sulfafurazole | Adenoidectomy | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | 34% (14/41) | 28% (16/58) | 6% (−12, 25)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 6 months
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Adenoidectomy | Placebo | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | 58% (34/59) | 45% (21/47) | 13% (−6, 32)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Success rate (<=1 in 2 months or <=2 in 6 months of AOM or <2 months of MEE) at 2 years
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Adenoidectomy | Placebo | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | 28% (16/58) | 22% (10/45) | 5% (−12, 22)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Outcome: Adverse events
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Sulfafurazole | Placebo | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Any | 8% (5/60) | 3% (2/60) | 5%(−3.4, 13)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Diarrhea | 3% (2/60) | 2% (1/60) | 2%(−4.8,7.2)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Skin rash | 3% (2/60) | 0% (0/60) | 3%(−1.3,7.9)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Unknown | 2% (1/60) | 2% (1/60) | 0%(−4.6, 4.6)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Sulfafurazole | Adenoidectomy | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Any | 8.3% (5/60) | 0% (0/60) | 8%(1.2,15)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Diarrhea | 3% (2/60) | 0% (0/60) | 3%(−1.3, 8)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Skin rash | 3% (2/60) | 0% (0/60) | 3%(−1.3, 8)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Unknown | 2% (1/60) | 0% (0/60) | 2%(−1.6,5.0)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | | Adenoidectomy | Placebo | Diff (95%CI)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Any | 0% (0/60) | 3% (2/60) | −3%(−8, 1.3)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Diarrhea | 0% (0/60) | 2% (1/60) | −2%(−5.0,1.6)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Skin rash | 0% (0/60) | 0% (0/60) | 0%(0, 0)
Koivunen 2004^130^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Sulfa alone 50 mg/kg/day = qd for 24 weeks vs. Placebo vs. Adenoidectomy | | Entering: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy Completing: N=174 N=59 Placebo N=56 Sulfa alone N=59 Adenoidectomy Analyzed: N=180 N=60 Placebo N=60 Sulfa alone N=60 Adenoidectomy | Disease recurrence; Adverse effects of treatment; Healthcare utilization | Unknown | 0% (0/60) | 2% (1/60) | −2%(−5.0,1.6)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | Study Time: 12/1999–3/2002 Place: Canada Multicenter: 3 centers Emergency room, Pediatric practice Inclusion: 6 mo–5 yr, Acute onset S&S (parent/guardian report), Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otalgia, Fever, Onset of AOM symptoms within 4 days before entry Exclusion: Allergic to other medication NOS, Penicillin/beta-lactams, Antibiotic within 2 weeks, Recurrent AOM (>4 episodes in 12 months), TM perforation/Otorrhea, Complication of OM, History of otic/ME surgery (excluding tubes), PE tubes/history of PE tubes, Respiratory Illness, Cranio-facial, Immunosuppressed/compromised/deficient, Major Systemic disease/condition, medical problem | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Outcome: Cumulative clinical resolution rates at 14 days-ALL
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | | Amox | Placebo | Diff (95%CI)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | All ages | 92.8% (232250) | 84.2% (202/240) | −9% (−14, −3)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | 6–23 mo | 85.4% (76/89) | 79.3% (73/92) | −6% (−17, 5.2)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | 2–5 yrs | 96.9% (156/161) | 87.2% (129/148) | −10% (−16, −4)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Outcome: Cumulative clinical resolution rates at 14 days-Among Children with MEE
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | | Amox | Placebo | Diff (95%CI)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | All ages | 93.2% (150/161) | 83.0% (112/135) | −10% (−18, −3)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | 6–23 mo | 87.1% (54/62) | 83.3% (45/54) | −4% (−17, 9)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | 2–5 yrs | 99.0% (96/99) | 82.7% (67/81) | −14% (−24, −6)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Outcome: Presence of middle ear fluid
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | | Amox | Placebo | Diff (95%CI)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | At 1-mo | 29.2% (68/233) | 34.7% (77/222) | −5%(−14, 3.1)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | At 3-mo | 25.4% (58/228) | 22.4% (47/210) | 3%(−5, 11)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Outcome: Occurrence of adverse events - 6 to 23 months
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | | Amox | Placebo | Diff (95%CI)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Diarrhea | 22.5% (20/89) | 18.5% (17/92) | 4%(−8, 16)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Rash | 14.6% (13/89) | 9.8% (9/92) | 5%(−4.7, 14)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Outcome: Occurrence of adverse events - 2–5 years
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | | Amox | Placebo | Dif(95%CI)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Diarrhea | 4.1% (6/146) | 6.8% (10/148) | −3%(−8, 2.5)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | Rash | 2.7% (4/146) | 7.4% (11/148) | −5%(−10, 0.3)
Le Saux 2005^89^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Amoxicillin 60 mg/kg/day/tid for 10 days | | Influencing factors: Middle ear effusion, Age Entering: N=512 N=254 Placebo N=258 Amoxicillin Completing: N=490 N=240 Placebo N=250 Amoxicillin Analyzed: N=490 N=240 Placebo N=250 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Other symptoms: fever; Invasive infections, e.g., mastoiditis, bacteremia; Adverse effects of treatment; Duration of AOM | The article also published results for Days 1, 2, and 3 for: fever, pain, irritability, vomiting, No. of analgesic doses, No. of codeine doses, and able to do usual activities.
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | Place: United Kingdom Multicenter Office setting/private practice, General/family practice Inclusion: 6 mo–10 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Air fluid level behind TM, S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema) Exclusion: Antibiotic within 2 weeks, Strong indication of antibiotics (bulging eardrum, perforation, pus, tubes), Chronic suppurative OM, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), Complication of OM, Major Systemic disease/condition, medical problem | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Outcome: Success rate at day 3 after first visit
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | Antibiotic | RxHold | Diff (95%CI)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | 86% (116/135) | 70% (105/150) | 16%(6.3, 26)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Outcome: Duration of symptoms (days), mean (range)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | Antibiotic | RxHold | Diff (95% CI) | p-value
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Earache | 2.6(0–10) | 3.6 (0–11) | −1.1 (−0.5, −1.5) | <0.01
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Discharge | 0.6 (0–7) | 1.2 (0–14) | −0.7 (−0.2, −1.1) | <0.01
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Night dist | 1.6 (0–8) | 2.4 (0–11) | −0.7 (−0.3, −1.1) | <0.01
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Crying | 1.5 (0–7) | 2.2 (0–11) | −0.7 (−0.3, −1.1) | <0.01
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Pain score | 2.3 (1–5) | 2.4 (1–6) | −0.2 (−0.4, 0.1) | 0.24
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Outcome: Side effects
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | Antibiotic | RxHold | Diff (95%CI)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Rash | 5% (6/133) | 5% (8/149) | −1%(−6, 4.2)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Diarrhea | 19% (25/133) | 9% (14/149) | 9%(1, 18)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Outcome: Healthcare utilization, mean (range)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | Antibiotic | RxHold | Diff (95% CI) | p-value
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | School days missed
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | 2.0 (0–8) | 2.2 (0–13) | −0.2 (−0.8, 0.4) | 0.56
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Daily No. of spoons of paracetamol consumed
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | 1.7 (0–6) | 2.3 (0–8) | −0.5 (−0.8, −0.3) | <0.01
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Outcome: Parents’ belief and satisfaction
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | Antibiotic | RxHold | Diff (95% CI)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Belief that antibiotics are very effective
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | 76% (100/131) | 46% (64/140) | 31%(19, 42)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Very satisfied with treatment approach
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | 94% (123/131) | 77% (115/150) | 17%(9, 26)
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | Very likely to consult doctor in future
Little 2001^2^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin tid for 7 days vs. Prescription to Hold | | Entering: N=315 N=151 Amoxicillin N=164 Prescription to hold Completing: N=285 N=135 Amoxicillin N=150 Prescription to hold Analyzed: N=285 N=135 Amoxicillin N=150 Prescription to hold | Signs or symptoms of MEI; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes | | 83% (109/132) | 63% (92/147) | 20%(9, 31)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | Place: United Kingdom Inclusion: 6 mo–10 yr, S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema) Exclusion: Antibiotic within 2 weeks, Strong indication of antibiotics (bulging eardrum, perforation, pus, tubes), AOM within 2 weeks, Chronic suppurative OM, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), Complication of OM, Major Systemic disease/condition, medical problem | Influencing factors: Symptoms and signs, Prior episodes of otitis media, Child care setting Entering: N=315 N=151 Amoxicillin N=164 Prescription to Hold Completing: N=219 N=99 Amoxicillin N=120 Prescription to Hold Analyzed: N=219 N=99 Amoxicillin N=120 Prescription to Hold | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | Outcome: Earache
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | | Amox | RxHold | OR (95% CI)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | At 3 mos | | | 0.89 (0.48, 1.65)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | At 1 yr | | | 1.03 (0.60, 1.78)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | Outcome: Poor scores on the function scale
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | | Amox | RxHold | OR (95% CI)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | At 3 mos | | | 1.37 (0.72, 2.60)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | At 1 yr | | | 1.16 (0.61, 2.23)
Little 2006^93^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: S&S of MEI | Amoxicillin vs. Prescription to Hold | | | By symptoms (otalgia, ear fullness); Quality of life or functional outcome | Data by influencing factor could not be abstracted by treatment groups.
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | Study Time: 12/2004–3/2005 Place: Italy University/academic Inclusion: 1–5 yr, Otoscopy (distinct TM erythema), Recurrent AOM, Free of AOM currently, OME, >= 2 episodes documented with symptoms, otoscopy, tympanometry Exclusion: Antibiotic within 2 weeks, Persistent TM perforation/Otorrhea, Tympanostomy tubes, Cleft palate, Immunosuppressed/compromised/deficient, Received blood products recently, Severe atopy, Obstructive adenoids, Sleep apnea | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | Treatment failure; By Pneumatic otoscopy/tympanometry; By otoscopy (distinct TM erythema); Disease recurrence; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Bacteriologic outcomes by nasopharyngeal cultures; Episodes of AOM (prevention study); Compliance; Any respiratory, relaspe defined as reappearance of any s or s <= 4 days after treatment ended; recurrence: 5–14 days | Outcome: ≥1 episode during 3-month study period
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | | Propolis+Zinc | Controls | Diff (95%CI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | AOM | 50.8% (31/61) | 70.5% (43/61 | −19.7% (−36.7, −2.7)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | RTI* | 73.8% (45/61) | 77.0% (47/61) | −3.3% (−18.5, 12.1)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | *febrile respiratory tract infection (RTI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Outcome: ≥1 antibiotic course during 3-month study period
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | | Propolis+Zinc | Controls | Diff (95%CI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | AOM | 49.2% (30/61) | 75.4% (46/61) | −26.2% (−42.8, −9.6)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | RTI* | 75..4% (46/61) | 81.9% (50/61) | −6.5% (−21.0, 8.0)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | *febrile respiratory tract infection (RTI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Outcome: Parent satisfaction
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Degree satisfaction | Propolis+Zinc | Controls | Diff (95%CI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Unsatisfied | 0.0% (0/61) | 27.4% (17/61) | −27.9% (−38, −16)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Satisfied | 65.6% (40/61) | 62.3% (38/61) | −3.3% (−13, 20)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Very satisfied | 34.4% (21/61) | 9.8% (6/61) | 24.6% (10, 39)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Outcome: adverse events
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Adverse event | Propolis+Zinc | Controls | Diff (95%CI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Vomiting | 1.6% (1/61) | 1.6% (1/61) | 0% (−5, 5)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Rash | 1.6% (1/61) | 0.0% (0/61) | 1.6% (−2, 5)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Outcome: mean number of episodes per child/month during 3-month study period
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | | Propolis+Zinc | Controls | Diff (95%CI) | p-value
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | AOM | 0.23 (±0.26) | 0.34 (±0.29) | 0.11 (0.01, 0.21) | 0.3
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | RTI* | 1.20 (±0.94) | 1.36 (±1.26) | 0.43 (−0.23, 0.55) | 0.43
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | *febrile respiratory tract infection (RTI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Outcome: mean number of antibiotic course for AOM during 3-month study period
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | | Propolis+Zinc | Controls | Diff (95%CI) | p-value
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | AOM | 0.64 (±0.69) | 0.98 (±0.73) | 0.34 (0.09, 0.59) | 0.005
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | RTI* | 1.29 (±1.15) | 1.31 (±0.96) | 0.92 (−0.36, 0.40) | 0.92
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | *febrile respiratory tract infection (RTI)
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | Outcome: mean duration in months of bilateral OME per child
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | | Propolis+Zinc | Controls | Diff (95%CI) | p-value
Marchisio 2010^133^ | Jadad quality score 1 (0–5):2 [1,0,0,1,0] Definition: Presence of MEE, S&S of MEI ROM -≥3 AOM in preceding 6 months or ≥4 episodes in preceding 12 months with most recent in previous 2–8 weeks | Elimination of environmental risk factors vs. 30% hydroglyceric extract of propolis; 1.2% zinc sulfate 0.3 ml/kg/d = QD for 3 months Plus Elimination of environmental risk factors | | Entering: N=122 N=61 Envt Analyzed: N=122 N=61 Envt | | | 8.62 (±3.73) | 9.50 (±4.06) | 0.88 (−0.50, 2.26) | 0.24
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | Enrollment Time: 5/2000–3/2003 Place: Hospital clinic/outpatient, University/academic Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), S&S of middle ear inflammation (MEI), Non-severe AOM at onset Exclusion: Penicillin/beta-lactams, Concomitant/Concurrent infection needing antibiotic treatment, TM perforation/Otorrhea, PE tubes/history of PE tubes, Cranio-facial, Immunosuppressed/compromised/deficient, Major Systemic disease/condition, medical problem | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | Treatment failure; Invasive infections, e.g., mastoiditis, bacteremia; Disease recurrence; Adverse effects of treatment; Quality of life or functional outcome; Parent satisfaction; Cost outcomes; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Success rate at Day 12
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Age | Amoxicillin | Wait-and-see | Diff (95%CI)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | 0.5–12yrs | 95.3% (102/107) | 80.4% (86/107) | 15%(6, 24)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | <2yrs | 93.8% (60/64) | 77.8% (42/54) | 16% (4, 28)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | >=2yrs | 97.7% (42/43) | 83.0% (44/53) | 15% (2, 27)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Outcome: Cure rate before Day 30
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Age | Amoxicillin | Wait-and-see | Diff((95%CI)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | 0.5–12yrs | 77.1% (84/109) | 66.0% (66/100) | 11%(−1, 23)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | <2yrs | 76.9% (50/65) | 56% (28/50) | 21%(4, 38)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | >=2yrs | 77.3% (34/44) | 76% (38/50) | 1.3%(−16, 18)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Outcome: Parent/Child Quality of Life
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Measure | Amoxicillin | Wait-and-see | Diff (95%CI)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | AOM-related extra office visit
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 13% (14/111) | 20% (22/108) | −7%(−17, 3)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | AOM-related emergency department visit
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 1% (1/111) | 4% (4/108) | −3%(−7, 1)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | AOM-related extra phone calls
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 23% (26/111) | 24% (26/108) | −1%(−12, 10)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Parent missed work or school
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 14% (14/111) | 9% (10/108) | 5%(−3.5, 14)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Doses of pain medicine [Mean±SD (n)] | | | p-value
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 3.4± 4.0 (105) | 7.7±7.5 | <0.01
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Outcome: Adverse events
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | Amoxicillin | Wait-and-see | Diff (95%CI)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | ABX-related adverse events
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 12% (13/111) | 5% (5/108) | 7%(−0.4, 14)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | Serious adverse events related to AIM
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | | 0% (0/111) | 0% (0/108) | 0% (0, 0)
McCormick 2005^3^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin 90 mg/kg/day/bid for 10 days vs. Wait and see | | Influencing factors: Age Entering: N=223 N=112 Amoxicillin N=111 Wait and see Completing: N=218 N=110 Amoxicillin N=108 Wait and see Analyzed: N=218 N=110 Amoxicillin N=108 Wait and see | | [The article also reported ABX-Resistance patterns of S. Pneumoniae strains isolated from the nasopharynx of subjects at enrollment and day 12.]
Morris 2010^67^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: AOM without perforation any tympanic membrane bulging and type B tympanogram; AOM with perforation - middle ear discharge observed and perforation recently healed or present for < 6 weeks or covering <2% of the pars tensa | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | Study Time: 3/2003–7/2005 Place: Australia Multicenter: 16 centers Hospital clinic/outpatient, Setting rural and remote communities Inclusion: Aboriginal children, 6 mos–6 y, New/first episode of AOM, Willingness of parents to bring child for follow-up visit Exclusion: Antibiotic within 7 days, Prior assignment to another arm of study, Allergy to penicillin or azithromycin, Other major illness requiring IV or IM antibiotics, Perforation covering >2% of the tympanic membrane | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | Treatment failure; Bulging tympanic membrane [TM]; Otorrhea; By symptoms (otalgia, ear fullness); Disease recurrence; Bacteriologic outcomes by nasopharyngeal cultures; Failure of a TM perforation to heal | Outcome: Clinical success between day 6 and day 11
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | | Azithromycin | Amoxicillin | Diff (95%CI)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Intention to treat | 50% (83/165) | 46% (72/155) | 4% (−7, 15)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Per protocol | 53% (74/140) | 47% (63/135) | 6% (−6, 18)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Age | Azithromycin | Amoxicillin | Diff (95%CI)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | <2 years old | 51% (64/125) | 46% (57/125) | 6% (−7, 18)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | ≥2 years old | 47% (19/40) | 50% (15/30) | −3% (−26, 21)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Diff (95%CI) | 4% (−14, 21) | −4% (−24, 15)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Baseline
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Diagnosis* | Azithromycin | Amoxicillin | Diff (95%CI)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | AOMwoP | 60% (81/134) | 54% (68/125) | 6% (−6, 18)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | AOMwiP | 8% (2/24) | 17 % (4/23) | −9% (−28, 10)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | *AOMwoP=without perforation; AOMwiP=with perforation
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Nasal
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Pathogen* | Azithromycin | Amoxicillin | Diff (95%CI)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | (+) SP | 50% (21/42) | 43% (40/92) | 7% (−12, 24)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | (−) SP | 54% (62/115) | 57 % (30/53) | −3% (−19, 13)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | (+) NCHi | 46% (40/86) | 44% (55/124) | 2% (−12, 16)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | (−) NCHi | 61% (43/71) | 71% (15/21) | −11% (−33, 12)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | * S pneumoniae (SP) or non-capsular Haemophilus influenzae (NCHi)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Outcome: Improvement by end of therapy
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | | Azithromycin | Amoxicillin | Diff (95%CI)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Intention to treat | 55% (87/158) | 51% (76/148) | 4% (−7, 15)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Per protocol | 56% (78/140) | 50% (67/135) | −6% (−6, 18)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Outcome: Other clinical outcomes
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | | Azithromycin | Amoxicillin | Diff (95%CI)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | No new pain | 99% (155/156) | 98% (144/147) | 1% (−1, 4)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Runny nose | 35% (55/158) | 46% (67/146) | −11% (−22, 0.1)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Skin sores | 4% (7/158) | 3% (4/146) | 2% (−3, 6)
Morris 2010^67^ | | Azithromycin 30 mg/kg as a single dose plus Amoxicillin Placebo vs. Amoxicillin 50 mg/kg/day/BID for 7 days, plus Azithromycin Placebo = QD for 1 day | | Influencing factors: Carriers/non carriers of Sp or NCHI - resistant or sensitive to antibiotic Entering: N=320 Completing: N=306 Analyzed: N=306 | | Nasal carriage of S. pneumonia, non-capsular H. influenzae, resistant S. pneumoniae, beta-lactamase-posituve non-capsular H. influenzae: See article. Ear discharge cultures positive for S. pneumoniae or non-capsular H. influenzae: See article.
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | Place: Sweden Multicenter: 32 centers Public health center/clinic/CHC Inclusion: 2–16 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI) Exclusion: Penicillin/beta-lactams, Concomitant/Concurrent infection needing antibiotic treatment, Recurrent AOM (>2 episodes in 6 months), Chronic suppurative OM, TM perforation/Otorrhea, Neurological disease/impairment, Immunosuppressed/compromised/deficient, Major Systemic disease/condition, medical problem | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Outcome: Success (recovery)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | PcV | Wait-and-see | Diff (95% CI)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Day2–7 | 100% (76/76) | 95% (83/87) | 5% (0, 10)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Day14 | 82% (71/87) | 85% (70/82) | −4%(−15, 7)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | 3Months | 85% (73/86) | 84% (63/75) | 1%(−10, 12)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Outcome: Long-term outcome at 3 months
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | PcV | Wait-and-see | Diff (95% CI)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Perforation | 0% (0/86) | 0% (0/75) | 0%
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Serous OM | 12% (10/86) | 11% (8/75) | 1% (−9, 11)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Outcome: Signs or symptoms at Day3–7
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | PcV | Wait-and-see | Diff (95%CI)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Pain severity 2–3
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | 2% (2/76) | 5% (4/87) | −3% (−9, 3)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Analgesics use
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | 3% (3/76) | 10% (8/87) | −7%(−15, 1)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Fever>38ºC
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | 3% (3/76) | 6% (5/87) | −3%(−9, 3)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Outcome: Economic
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | PcV | Wait-and-see | Diff (95%CI)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Parents at home
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | 56% (49/76) | 53% (42/87) | 3%(−12, 18)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | Days at home from work (median, range)
Neumark 2007^87^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Wait and see vs. Phenoxymethyl- penicillin 25 mg/kg/day = bid for 5 days | | Completing: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin Analyzed: N=179 N=92 Wait & See N=87 Phenoxymethylpenicillin | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Cost outcomes; Otologic complications, i.e., cholestetoma; Healthcare utilization | | 1.2 (0–7) | 1.2 (0–7) | 0.90
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | Study Time: 10/2002–5/2005 Place: Multicenter: 66 centers Inclusion: >6 mo, Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otalgia within last 24 hours, Otoscopy (distinct TM erythema), Recurrent AOM, Persistent AOM Exclusion: Penicillin/beta-lactams, Any antibiotic, Any antibiotic during present illness, Concomitant/Concurrent infection needing antibiotic treatment, PE tubes/history of PE tubes, Major Systemic disease/condition, medical problem, On other medication/treatment | Influencing factors: Age Entering: N=1650 N=823 Amoxicillin-clavulanate N=827 Levofloxacin Completing: N=1435 N=721 Amoxicillin-clavulanate N=714 Levofloxacin Analyzed: N=1305 N=675 Amoxicillin-clavulanate N=630 Levofloxacin | Treatment failure; By Pneumatic otoscopy/tympanometry; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); By otoscopy (distinct TM erythema); Other symptoms: fever; Adverse effects of treatment | Outcome: Clinical success (cure and improved) at 2–5 days
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Age | Levofloxacin | Amox-clav | Diff (95%CI)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5-<5yr | 94% (592/630) | 91% (613/675) | −3.2 (−6.0, −0.3)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5–2yr | 92% (327/357) | 88% (347/394) | −3.5 (−7.3, 0.8)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | >2-<5yr | 97% (265/273) | 95% (266/281) | −2.4 (−5.7, 0.9)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Outcome: Clinical success (cure and improved) at 10–17 days
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Age | Levofloxacin | Amox-clav | Diff (95%CI)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5-<5yr | 84% (585/700) | 80% (578/719) | −3.2 (−7.2, 0.8)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5–2yr | 79% (318/404) | 76% (315/417) | −3.2 (−8.9, 2.6)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | >2-<5yr | 90% (267/296) | 87% (263/302) | −3.1 (−8.2, 2.0)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Outcome: Clinical cure (not including improved) at 2–5 days
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Age | Levofloxacin | Amox-clav | Diff (95%CI)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5-<5yr | 72% (456/630) | 70% (472/675) | −2.5 (−7.4, 2.5)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5–2yr | 69% (246/357) | 66% (261/394) | −2.7 (−9.4, 4.0)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | >2-<5yr | 77% (210/273) | 75% (211/281) | −1.8 (−8.9, 5.3)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Outcome: Clinical cure (not including improved) at 10–17 days
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Age | Levofloxacin | Amox-clav | Diff (95%CI)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5-<5yr | 75% (524/700) | 74% (531/719) | −1.0 (−5.6, 3.5)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 0.5–2yr | 70% (284/404) | 70% (291/417) | −0.5 (−6.7, 5.8)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | >2-<5yr | 81% (240/296) | 80% (240/302) | −1.6 (−8.0, 4.8)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Outcome: Adverse events
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | Levofloxacin | Amox-clav | Diff (95%CI)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | 1 or more up to visit 4
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 54% (448/827) | 58% (475/823) | −4%(−8,1.3)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Arthralgia | 1.5% (12/827) | 0.7%(6/823) | 0.8%(−0.2,1.8)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Arthralgia disorder
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 1.2% (10/827) | 0.6% (5/823) | 0.6%(−0.3,1.5)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Arthritis disorder
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 0.2% (2/827) | 0% (0/823) | 0.2%(−0.1,0.5)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Arthropathy
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 0% (0/827) | 0.2% (2/823) | −0.2%(−0.5,0.1)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Dermatitis | 13% (108/827) | 16% (129/823) | −3%(−6, 0.8)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Diarrhea | 13% (108/827) | 20% (161/823) | −7%(−10, −3)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Fever | 7% (60/827) | 8% (64/823) | −1%(−3, 2)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Gait abnormality disorder
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 0.1% (1/827) | 0% (0/823) | 0.1%(−0.1,0.3)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Muscle weakness
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 0% (0/827) | 0.1% (1/823) | −0.1%(−0.3,0.1)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Otitis media not related to treatment failure
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 5% (45/827) | 4% (34/823) | 1% (−0.8, 3.4)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Pathologic fracture
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 0% (0/827) | 0.5% (4/823) | −0.5%(−1, 0)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | Levofloxacin | Amox-clav | Diff (95%CI)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Musculoskeletal disorder (DSMC)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 1.5% (12/827) | 0.6% (5/823) | 1%(−0.1, 1.9)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Muscoskeletal adverse events
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | | 2.8% (23/827) | 2.3% (19/823) | 0.5%(−1, 2)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Rhinitis | 5% (43/827) | 5% (39/823) | 0.5%(−1.6,2.6)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Synovitis | 0.1% (1/827) | 0% (0/823) | 0.1%(−0.1,0.3)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | URI | 6% (53/827) | 9% (78/823) | −3%(−5.7,−0.5)
Noel 2008^123^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day = bid for 10 days vs. Levofloxacin 10 mg/kg/day = bid for 10 days | | | | Vomiting | 10% (81/827) | 7% (61/823) | 2%(−0.3, 5.1)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | Study Time: 1/1998–5/2000 Place: Turkey, Turkey Hospital clinic/ outpatient Inclusion: 6 mo–12 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Otorrhea, Diagnosis by ENT Exclusion: Any antibiotic, Antibiotic within 2 weeks, Long acting antibiotic within 6 weeks, Chronic suppurative OM, TM perforation/Otorrhea, Respiratory Illness, Renal Disorders, Immunosuppressed /compromised/deficient, Major Systemic disease/ condition, medical problem | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Outcome: Clinical success (cure + improvement)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day3–5 | 100% (33/33) | 98% (39/40) | 2%(−2.8, 6.8)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day10 | 97% (32/33) | 97% (38/39) | 0%(−8, 8)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day30 | 91% (30/33) | 94% (33/35) | −3%(−15, 10)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Outcome: Clinical cure
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day3–5 | 36% (12/33) | 32% (13/40) | 4%(−18, 26)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day10 | 85% (28/33) | 77% (30/39) | 8%(−10, 26)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day30 | 82% (27/33) | 91% (32/35) | −9%(−25, 7)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Outcome: Persistence of MEF
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day10 | 12% (4/33) | 21% (8/39) | −9%(−26, 8)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Day30 | 3% (1/33) | 9% (3/35) | −6%(−17, 5)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Outcome: Adverse events
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | | Cefaclor | Azithromycin | Diff (95%CI)
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | Diarrhea and vomiting
Oguz 2003^82^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE | Cefaclor 40 mg/kg/day / tid for 10 days vs. Azithromycin 10 mg/kg/day = qd for 3 days | | Entering: N=78 N=37 Cefaclor N=41 Azithromycin Completing: N=73 N=33 Cefaclor N=40 Azithromycin Analyzed: N=73 N=33 Cefaclor N=40 Azithromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence; Antibiotic resistance; Adverse effects of treatment | | 3% (1/37) | 2% (1/41) | 1%(−5.9, 8)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Success rate (% with no AOM episode) in 1 year in patients with no tonsil-related indications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Placebo | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 31% (19/61) | 22% (17/79) | 10% (−5, 24)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Success rate (% with<=1 AOM episode) in 1 year in patients with no tonsil-related indications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Placebo | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 48% (29/61) | 51% (40/79) | −3% (−20, 14)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Success rate (% with no AOM episode) in 1 year in patients with no tonsil-related indications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Adenotonsillectomy: | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 31% (19/61) | 37% (26/71) | −6% (−22, 11)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Success rate (% with<=1 AOM episode) in 1 year in patients with no tonsil-related indications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Adenotonsillectomy: | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 48% (29/61) | 59% (42/71) | −12% (−29, 5)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Success rate (% with no AOM episode) in 1 year in patients with no tonsil-related indications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenotonsillectomy | Placebo | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 37% (26/71) | 22% (17/79) | 15% (0.6, 30)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Success rate (% with<=1 AOM episode) in 1 year in patients with no tonsil-related indications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenotonsillectomy | Placebo | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 59% (42/71) | 51% (40/79) | 9% (−7, 25)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Outcome: Adverse events
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Placebo | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Erythematous rashes during treatment
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 7.2% (6/83) | 3.9% (7/181) | 3%(−2.3,9)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Adenotonsillectomy: | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Erythematous rashes during treatment
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 7.2% (6/83) | 2.2% (4/178) | 5%(0,10)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Hemorrhage after hospital discharge
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 0% (0/83) | 2.2% (4/178) | −2%(−5.4,1)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Incipient malignant hyperthermia
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 1.2% (1/83) | 0.6% (1/178) | 0.6%(−1.7,1)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Perioperative and postoperative complications
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 4.8% (4/83) | 14.6% (26/178) | −10%(−18,−1.5)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Postoperative pneumonia
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 1.2% (1/83) | 0% (0/178) | 1.2%(−0.4,2.8)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Postoperative velopharyngeal insufficiency - persistent (9mo)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 0% (0/83) | 0.6% (1/178) | −0.6%(−2.3,1.1)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenoidectomy | Adenotonsillectomy: | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Postoperative velopharyngeal insufficiency-transient (<=43 d)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 2.4% (2/83) | 5.1% (9/178) | −2.7%(−8,2.6)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Retained in hospital 1 additional day and/or readmitted to hospital due to fever, poor fluid intake orally, vomiting, and/or dehydration
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 0% (0/83) | 6% (11/178) | −6%(−11,−0.8)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Serum sickness during antimicrobial treatment
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 0% (0/83) | 0.6% (1/178) | −0.6%(−2.3,1.1)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | Adenotonsillectomy | Placebo | Diff (95%CI)
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | Erythematous rashes during treatment
Paradise 1999^26^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Other | Placebo vs. Adenoidectomy vs. Adenoidectomy and/or tonsillectomy | Study Time: 4/1980–4/1994 Place: United States Hospital Inclusion: 3–15 yr, Recurrent AOM Exclusion: PE tubes/history of PE tubes, Cranio-facial | Entering: N=461 N=181 Placebo N=100 Adenoid N=180 Adenoid/tonsil Completing: N=410 N=177 Placebo N=79 Adenoid N=154 Adenoid/tonsil | Disease recurrence; Adverse effects of treatment; PE tube placement; Days of ear pain; Days of Abx Tx; Duration of AOM | | 2.2% (4/178) | 3.9% (7/181) | −1.7%(−5.3,1.9)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | Place: France Multicenter: 50 centers Inclusion: 6–36 mo, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Loss of landmarks, Erythematous TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otalgia, Decreased hearing, Fever, Tympanocentesis preformed Not Specified Exclusion: Penicillin/beta-lactams, Antibiotic within 72 hours, Concomitant/Concurrent infection needing antibiotic treatment, TM perforation/Otorrhea, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient, Major Systemic disease/ condition, medical problem, Investigational drug within 3 months | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Satisfactory clinical response post-treatment - A-C10d vs. CAE
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | A-C10d | CAE | Diff (95%CI)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Total | 88% (181/205) | 86% (175/203) | 2% (−4.5, 8.5)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | <1.5 yrs | 89% (116/131) | 83% (111/134) | 6% (−2.4, 14)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | 1.5–3yrs | 88% (65/74) | 93% (64/69) | −5% (−15, 4.7)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Satisfactory clinical response post-treatment - A-C8d vs. CAE
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | A-C8d | CAE | Diff (95%CI)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Total | 88% (145/165) | 86% (175/203) | 2% (−4.9, 9)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | <1.5 yrs | 84% (83/99) | 83% (111/134) | 1% (−9, 11)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | 1.5–3yrs | 94% (62/66) | 93% (64/69) | 1% (−7, 9)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Satisfactory clinical response post-treatment - A-C10d vs. A-C8d
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Adverse events
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | A-C10d | A-C8d | Diff (95%CI)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Total | 88% (181/205) | 88% (145/165) | 0% (−7, 7)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | <1.5 yrs | 89% (116/131) | 84% (83/99) | 5% (−3.8, 14)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | 1.5–3yrs | 88% (65/74) | 94% (62/66) | −6% (−16, 4)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Adverse events
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | A-C10d | CAE | Diff (95%CI)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Any | 22% (57/255) | 15% (37/252) | 8%(1,14)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Diarrhea | 18% (46/255) | 10% (25/252) | 8%(2, 14)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | A-C8d | CAE | Diff (95%CI)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Any | 16% (33/209) | 15% (37/252) | 1%(−5.5,8)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Diarrhea | 10% (21/209) | 10% (25/252) | 0.1%(−5.4,5.6)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | A-C10d | A-C8d | Diff (95%CI)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Any | 22% (57/255) | 16% (33/209) | 7%(−0.6,14)
Pessey 1999^79^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 40 mg/kg/day / tid for 10 days vs. Amoxicillin- clavulanate 80 mg/kg/day / tid for 8 days vs. Cefuroxime 30 mg/kg/day / bid for 5 days | | Influencing factors: Age Entering: N=716 N=255 Amoxicillin- clavulanate 40 mg 10 days N=209 Amoxicillin- clavulanate 80 mg 8 days N=252 Cefuroxime | Treatment failure; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Diarrhea | 18% (46/255) | 10% (21/209) | 8%(1.6,14)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | Study Time: 3/2000–2/2001 Place: Multicenter: 18 centers Inclusion: 6 mo–12 yr, Otorrhea, AOM < 3 weeks, Patent tympanostomy tubes Exclusion: Antibiotic within 2 days, Long acting antibiotic within 2 weeks, Complication of OM, Cranio-facial, Endocrine disorders (diabetes), GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient, Other Infectious diseases (meningitis), Major Systemic disease/ condition, medical problem | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Clinical success (cure and improve) on day 8 (post-therapy)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | | Cipro alone | Cipro+Dex | Diff (95%CI)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Total | 91.2% (73/80) | 94.2% (82/87) | −3% (−11, 4.9)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | No data by age groups were reported.
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Clinical success (cure and improve) on day 14 (test-of-cure)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | | Cipro alone | Cipro+Dex | Diff (95%CI)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Total | 93.8% (75/80) | 98.9% (86/87) | −5% (−11, 0.5)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | No data by age groups were reported.
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Adverse event
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | | Cipro alone | Cipro+Dex | Diff (95%CI)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Excessive crying
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | | 1% (1/98) | 1% (1/103) | 0% (−2.8, 2.8)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Burning | 1% (1/98) | 2% (2/103) | −1%(−4.2,2.4)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Pain | 1% (1/98) | 2% (2/103) | −1%(−4.2,2.4)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Precipitate | 3% (3/98) | 0% (0/103) | 3%(−0.3,6.5)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Pruritus | 1% (1/98) | 1% (1/103) | 0%(−2.8,2.8)
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | Taste perversion
Roland 2003^126^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Cipro otic 3% 3 drops = bid for 7 days vs. Ciprodex drops 3 drops = bid for 7 days | | Influencing factors: Age Entering: N=201 N=98 Cipro otic N=103 Ciprodex Completing: N=167 N=80 Cipro otic N=87 Ciprodex Analyzed: N=167 N=80 Cipro otic N=87 Ciprodex | Treatment failure; Bacteriologic cure/failure; Adverse effects of treatment | | 0% (0/98) | 1% (1/103) | −1%(−3, 1)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | Place: United States, Canada Multicenter: 39 centers Inclusion: 6 mo–12 yr, Otorrhea, Onset of AOM symptoms within 21 days before entry, Patent tympanostomy tubes Exclusion: Any antibiotic, Concomitant/Concurrent infection needing antibiotic treatment, Other antibiotic Tx, Topical antibiotic drops prior to study, Otitis externa, TM perforation/Otorrhea >3 weeks, Complication of OM, History of otic/ME surgery (excluding tubes), Respiratory Illness, Cranio-facial, Endocrine disorders (diabetes), GI disorders/Liver, Renal Disorders, Immunosuppressed /compromised/deficient, Other Infectious diseases (meningitis), On other medication/treatment, Menarche | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: clinical cure at test-of-cure visit day 18–21
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Ciprodex | Ofloxacin | Diff (95%CI)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Total | 90% (162/180) | 78.2% (133/170) | 12%(4.2, 19)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Clinical success (cured or improved)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Ciprodex | Ofloxacin | Diff (95%CI)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Day 3 | 93.7% (194/207) | 79.6% (172/216) | 14%(7.6, 21)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Day 11 | 96.1% (199/207) | 89.8% (194/216) | 6%(1.4, 11)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Day 18 | 93.7% (194/207) | 88.4% (191/216) | 5%(−0.2, 11)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Absence of otorrhea
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Ciprodex | Ofloxacin | Diff (95%CI
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Day 3 | 32.2% (67/207) | 18.5% (40/216) | 14%(5.4, 22)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Day 11 | 84.6% (176/207) | 63.4% (137/216) | 21%(13, 30)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Day 18 | 85.0% (176/206) | 70.8% (153/216) | 14%(6, 22)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Outcome: Adverse events
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | Ciprodex | Ofloxacin | Diff (95%CI
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Cough or crying or diarrhea or ear debris or edema eardrum or headache or hyperemia eardrum
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0% (0/297) | 0.3% (1/302) | −0.3%(−0.9,0.3)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Discomfort ear:
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 3.4% (10/297) | 1% (3/302) | 2.4%(0.1,4.7)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Dizziness or erythema or tinnitus or tympanostomy tube blockage
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0.3% (1/297) | 0%(0/302) | 0.3%(−0.3,0.9)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Infection super ear or irritation ear or pruritus ear
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0% (0/297) | 0.7% (2/302) | −0.7%(−1.6,0.2)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Irritability | 0.7% (2/297) | 0% (0/302) | 0.7%(−0.2,1.6)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Monilia oral
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0.3% (1/297) | 0.3% (1/302) | 0%(−0.9,0.9)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Pain ear | 2.4% (7/297) | 3.0% (9/302) | −0.6%(−3.2,2)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Precipitate ear
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0.7% (2/297) | 1.0% (3/302) | −0.3%(−1.8,1.2)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Serious Tx related
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0% (0/297) | 0% (0/302) | 0% (0, 0)
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | Taste perversion
Roland 2004^127^ | Jadad quality score 1 (0–5):1 [1,0,0,0,0] Definition: Not specified | Ciprodex drops 4 drops = bid for 7 days vs. Ofloxacin drops 5 drops = bid for 10 days | | Entering: N=599 N=297 Ciprodex N=302 Ofloxacin Completing: N=423 N=207 Ciprodex N=216 Ofloxacin Analyzed: N=423 N=207 Ciprodex N=216 Ofloxacin | Treatment failure; By otoscopic findings:; Otorrhea; Other symptoms: decreased hearing; Bacteriologic cure/failure; Adverse effects of treatment; Other antibiotic: No new abx Rx/no change in abx Rx | | 0.3% (1/297) | 1% (3/302) | −0.7%(−2,0.6)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | Enrollment Time: 6/1995–6/1996 Place: Sweden Multicenter: 6 centers Inclusion: 6 mo–8 yr, <45 kg, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Otalgia, Recurrent AOM, Weight of child Lower weight limit not specified Exclusion: Penicillin/beta-lactams, Complication of OM, PE tubes/history of PE tubes, Immunosuppressed /compromised/deficient | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Success rate (no recurrence after treatment ) up to day 14 from start of treatment
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Age | Ceftibuten 5d | Ceftibuten 10d | Diff (95%CI)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | All | 79% (70/89) | 96% (85/89) | −16.8(−26.7, −7.0)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Success rate (no recurrence after treatment ) up to day 40 from start of treatment
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Age | Ceftibuten 5d | Ceftibuten 10d | Diff (95%CI)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | All | 65% (58/89) | 70% (62/89) | −5.0 (−18.8, 8.8)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Percent patients with adverse events
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | Ceftibuten 5d | Ceftibuten 10d | Diff (95%CI)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | All | 7% (6/90) | 17% (15/90) | −10.0(−19.4, −0.6)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | Outcome: Adverse events
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | Ceftibuten 5d | Ceftibuten 10d | Diff (95%CI)
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | GI disturbance
Roos 2000^131^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Ceftibuten 9 mg/kg/day = qd for 10 days vs. Ceftibuten 9 mg/kg/day = qd for 5 days | | Entering: N=180 N=90 Ceftibuten 10 days N=90 Ceftibuten 5 days Completing: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days Analyzed: N=178 N=89 Ceftibuten 10 days N=89 Ceftibuten 5 days | Disease recurrence; Adverse effects of treatment; Bacteriologic outcomes by nasopharyngeal cultures | | 6.7% (6/90) | 16.7% (15/900 | −10%(−19,−0.6)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | Enrollment Time: 5/2001–5/2002 Place: Multicenter: 20 centers Inclusion: 6 mo–7 yr, Recurrent AOM, Failed previous antibiotic Exclusion: Penicillin/beta-lactams, Any antibiotic, Antibiotic within 7 days, Concomitant/Concurrent infection needing antibiotic treatment, Otitis externa, TM perforation/Otorrhea, PE tubes/history of PE tubes, Cranio-facial, GI disorders/Liver, Renal Disorders, Major Systemic disease/ condition, medical problem, Metabolic/Inborn Errors of metabolism, Investigational drug within 1 month, On other medication/treatment | Influencing factors: Hearing deficit and severity, Laterality, Age, Recurrent otitis media/ otitis prone Entering: N=419 N=139 Amoxicillin- clavulanate N=280 Gatifloxacin Analyzed: N=413 N=136 Amoxicillin- clavulanate N=277 Gatifloxacin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10- all type of diagnoses
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 84% (102/121) | 90% (222/246) | −6%(−13, 1)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 80% (36/45) | 92% (81/88) | −12%(−24,−0.3)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 87% (66/76) | 89% (141/158) | −2%(−11, 7)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10-Recurrent OM only
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 81% (35/43) | 89% (67/75) | −8%(−21, 5.0)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 88% (14/16) | 94% (30/32) | −6%(−22, 10)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 78% (21/27) | 86% (37/43) | −8%(−26, 10)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10-AOM treatment failures only
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 85% (62/73) | 91% (140/154) | −6%(−15, 2.7)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 73% (19/26) | 89% (41/46) | −16%(−34, 2)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 92% (43/47) | 92% (99/108) | 0%(−9.3, 9.3)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10- both ROM and AOM tx failures
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 100% (5/5) | 88% (15/17) | 12% (−17, 41)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 100% (3/3) | 100% (10/10) | 0%
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 100% (2/2) | 71% (5/7) | 29%(−37, 95)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10- Unilateral cases
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 91% (49/54) | 92% (109/118) | −1%(−10, 8)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 86% (12/14) | 98% (40/41) | −12%(−25, 1.3)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 92% (37/40) | 90% (69/77) | 2%(−9, 13)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10- Bilateral cases
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 79% (53/67) | 88% (113/128) | −9%(−20, 1.6)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 77% (24/31) | 87% (41/47) | −10%(−27, 7)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 81% (29/36) | 89% (72/81) | −8%(−21, 5.4)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10- Mild/Moderate Severity cases
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 80% (33/41) | 89% (83/93) | −9%(−22, 4)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 67% (10/15) | 87% (20/23) | −20%(−46, 6)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 88% (23/26) | 90% (63/70) | −2%(−16, 12)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate at day 3–10- Severe Severity cases
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 86% (69/80) | 91% (139/153) | −5%(−13, 3.4)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 87% (26/30) | 94% (61/65) | −7%(−19, 4.9)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 86% (43/50) | 89% (78/88) | −3%(−14, 8)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Success rate (sustained cure) at day 21–28
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Age | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | All | 73% (88/121) | 74% (183/246) | −1%(−11, 9)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | <2yrs | 64% (29/45) | 70% (62/88) | −6%(−23, 11)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | 2–7yrs | 78% (59/76) | 77% (121/158) | 1%(−10, 12)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | | Amox-clav | Gatifloxacin | Diff (95%CI)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Any | 59% (81/136) | 55% (153/277) | 4%(−6, 14)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Arthralgia | 2% ( 2/136) | 2% ( 6/277) | 0%(−2.9, 2.9)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Drug-related | 15% (20/136) | 18% (49/277) | −3%(−11,4.7)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Vomiting | 5% ( 7/136) | 8% (23/277) | −3%(−8, 2.2)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Diarrhea | 7% (10/136) | 3% ( 8/277) | 4%(−0.2, 8)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Abd pain | 2% ( 2/136) | 4% (11/277) | −2%(−5.7, 1.7)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Diaper rash | 2% ( 3/136) | 1% ( 2/277) | 1%(−1.4, 3.4)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | Serious* | 2% ( 2/136) | 0% ( 0/277) | 2%(0.3, 3.7)
Saez-Llorens 2005^121^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Disease recurrence; Adverse effects of treatment | * one was generalized seizure
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | Study Time: 1/1998–10/1999 Place: Office setting/ private practice, Pediatric practice Multicenter Inclusion: 6–18 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Air fluid level behind TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Ear fullness Exclusion: Allergic to other medication NOS, AOM within 2 weeks, TM perforation/Otorrhea, Complication of OM, PE tubes/history of PE tubes, Immunosuppressed /compromised/deficient, On other medication/treatment, Inability to do visual scale | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Improvement in ear pain score (use the measurements at 30 minutes)
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Anesthetic (n=42) | Otikon (n=61)
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 4.3+/−2.2 | 3.1+/−2.0 | 1.2 (0.37, 2.03) | 0.005
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 2.1+/−1.0 | 1.4+/−0.8 | 0.7 (0.35, 1.05) | 0.000
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 1.4+/−0.6 | 1.1+/−0.5 | 0.3 (0.08, 0.52) | 0.007
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Adverse events
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Anesthetic | Otikon | Diff (95%CI)
Sarrell 2001^102^ | Jadad quality score 1 (0–5):3 [1,1,1,0,0] Definition: Presence of MEE, S&S of MEI | Topical anesthetic nos 5 drops = tid vs. Otikon drops 5 drops = tid | | Completing: N=103 N=42 Anesthetic drops N=61 Otikon drops Analyzed: N=103 N=42 Anesthetic drops N=61 Otikon drops | Treatment failure; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Adverse effects of treatment | Any | 0% (0/42) | 0% (0/61) | 0% (0,0)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 80 mg/kg/day / tid, Topical anesthetic nos 5 drops = tid vs. NHED 5 drops = tid vs. Amoxicillin 80 mg/kg/day / tid, NHED 5 drops = tid vs. Topical anesthetic nos 5 drops = tid NHED=Naturopat hic Herbal Extract Ear Drops | Study Time: 1/1999–1/2001 Place: Public health center/ clinic/CHC Inclusion: 5–18 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Erythematous TM, Air fluid level behind TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia Exclusion: TM perforation/Otorrhea, Complication of OM, PE tubes/history of PE tubes, Cranio-facial, Immunosuppressed /compromised/deficient, On other medication/treatment, Allergy to other medications, A or B on Tympanogram, Inability to do visual scale | Entering: N=180 N=45 Anesthetic with Amoxicillin N=45 NHED N=45 NHED with Amoxicillin N=45 Anesthetic Completing: N=171 N=43 Anesthetic with Amoxicillin N=44 NHED N=42 NHED with Amoxicillin N=42 Anesthetic Analyzed: N=171 N=43 Anesthetic with Amoxicillin N=44 NHED N=42 NHED with Amoxicillin N=42 Anesthetic | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Improvement in ear pain score (use the measurements at 30 minutes)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | NHED (n=44) | NHED+Amox (n=42)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 3.0+/−2.0 | 3.5+/−2.5 | −0.5(−1.5, 0.5) | 0.31
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 1.3+/−2.3 | 1.8+/−2.3 | −0.5(−1.5, 0.5) | 0.32
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 0.3+/−0.6 | 0.8+/−2.1 | −0.5(−1.2, 0.2) | 0.13
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | NHED (n=44) | Anesthetic (n=42)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 3.0+/−2.0 | 2.9+/−1.6 | 0.1(−0.7, 0.9) | 0.80
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 1.3+/−2.3 | 1.4+/−0.8 | −0.1(−0.8, 0.6) | 0.79
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 0.3+/−0.6 | 1.2+/−0.5 | −0.9(−1.1, −0.7) | 0.000
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | NHED (n=44) | Anesthetic+Amox (n=43)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 3.0+/−2.0 | 5.6+/−2.6 | −2.6(−3.6, −1.6) | 0.000
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 1.3+/−2.3 | 2.7+/−2.6 | −1.4(−2.4, −0.4) | 0.009
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 0.3+/−0.6 | 2.0+/−2.0 | −1.7(−2.3, −1.1) | 0.000
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | NHED+Amox (n=42) | Anesthetic (n=42)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 3.5+/−2.5 | 2.9+/−1.6 | 0.6(−0.3, 1.5) | 0.19
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 1.8+/−2.3 | 1.4+/−0.8 | 0.4(−0.4, 1.2) | 0.29
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 0.8+/−2.1 | 1.2+/−2.0 | −0.4(−1.3, 0.5) | 0.37
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | NHED+Amox (n=42) | Anesthetic+Amox (n=43)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 3.5+/−2.5 | 5.6+/−2.6 | −2.1(−3.2, −1.0) | 0.000
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 1.8+/−2.3 | 2.7+/−2.6 | −0.9(−2.0, 0.2) | 0.10
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 0.8+/−2.1 | 2.0+/−2.0 | −1.2(−2.1, −0.3) | 0.008
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Anesthetic (n=42) | Anesthetic+Amox (n=43)
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | | Mean+/−SD | Mean+/−SD | Diff (95%CI) | p-value
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 1 | 2.9+/−1.6 | 5.6+/−2.6 | −2.7(−3.6, −1.8) | 0.000
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 2 | 1.4+/−0.8 | 2.7+/−2.6 | −1.3(−2.1, −0.5) | 0.003
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Day 3 | 1.2+/−2.0 | 2.0+/−2.0 | −0.8(−1.7, 0.06) | 0.07
Sarrell 2003^103^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | | | | By symptoms (otalgia, ear fullness); Adverse effects of treatment | Outcome: Adverse events All treatment options had 0 adverse events: Diff (95%CI): 0%(0,0)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | Study Time: 9/1995–1/1996 Place: Germany Multicenter: 19 centers Pediatric practice Inclusion: 6 mo–11 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Decreased hearing, Ear fullness, Fever, Onset of AOM symptoms within 4 days before entry Exclusion: Penicillin/beta-lactams, Macrolides, Antibiotic within 7 days, Long acting antibiotic within 4 weeks, AOM within 4 weeks, Chronic suppurative OM, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 24 hours, PE tubes/history of PE tubes, Cranio-facial, Immunosuppressed /compromised/deficient, Major Systemic disease/ condition, medical problem | Influencing factors: Otorrhea, Laterality, Age Entering: N=302 N=151 Amoxicillin N=151 Erythromycin Completing: N=280 N=139 Amoxicillin N=141 Erythromycin Analyzed: N=280 N=139 Amoxicillin N=141 Erythromycin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Invasive infections, e.g., mastoiditis, bacteremia; Disease recurrence; Adverse effects of treatment | Outcome: Clinical success on day 9–11
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Amoxicillin | Erythromycin | Diff (95%CI)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | By drugs | 96% (133/139) | 94% (132/141) | 2% (−3, 7)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Age<=2years | Age>2years | Diff (95%CI)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | By Age | 89.7% (35/39) | 95.4% (230/241) | −5.7%(−13, 2)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Otorrhea at entry | No Otorrhea at entry | Diff (95%CI)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | By otorrhea | 94.7% (36/38) | 94.6% (229/242) | 0.1%(−8, 8)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Bilateral | Unilateral | Diff (95%CI)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | By Laterality | 87.3% (69/79) | 97.5% (196/201) | −10%(−16, −4)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | Outcome: Free of recurrence
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Amoxicillin | Erythromycin | Diff (95%CI)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | All pts | 95.0% (132/139) | 94.3% (133/141) | 0.7%(−4.6, 6)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | 31–40 d | 97.8% (136/139) | 97.2% (137/141) | 0.6 %(−3, 4)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | Outcome: Adverse events
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | Amoxicillin | Erythromycin | Diff (95%CI)
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | Tx-related or possibly tx-related
Scholz 1998^4^ | Jadad quality score 1 (0–5):5 [1,1,1,1,1] Definition: Presence of MEE, S&S of MEI | Amoxicillin 50 mg/kg/day / bid for 10 days vs. Erythromycin 40 mg/kg/day / bid for 10 days | | | | | 7% (11/151) | 5% (8/151) | 2% (−3.7,7.5)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | Enrollment Time: 3/2001–6/2002 Place: United States, Costa Rica Multicenter: 27 centers Inclusion: 6 mo–7 yr, Presence of middle ear effusion (MEE), S&S of middle ear inflammation (MEI), AOM treated with antibiotic at least 2 days, Recurrent AOM Exclusion: Antibiotic within 7 days, Other antibiotic Tx, Otitis externa, TM perforation/Otorrhea, PE tubes/history of PE tubes, Major Systemic disease/ condition, medical problem, Failed previous antibotic | Influencing factors: Laterality, Age, Severity Entering: N=349 N=173 Amoxicillin-clavulanate N=176 Gatifloxacin Completing: N=328 N=164 Amoxicillin- clavulanate N=164 Gatifloxacin Analyzed: N=241 N=117 Amoxicillin-clavulanate N=124 Gatifloxacin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Success rate on day 10 (test of day visit) by age group
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Gatifloxacin | Diff (95%CI)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Total | 79% (92/117) | 85% (105/124) | −6%(−16, 3.7)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | <2yrs | 78% (45/58) | 79% (49/62) | −1%(−16, 14)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | >=2yrs | 80% (47/59) | 90% (56/62) | −11%(−23,2.7)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Success rate on day 10 (test of day visit) by laterality
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Gatifloxacin | Diff (95%CI)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Unilateral | 82% (40/49) | 84% (48/57) | −3%(−17, 12)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Bilateral | 76% (52/68) | 85% (57/67) | −9%(−22, 4.7)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Success rate on day 10 (test of day visit) by SEVERITY
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Gatifloxacin | Diff (95%CI)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Mild/Mod | 85% (45/53) | 84% (47/56) | 1%(−13, 15)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Bilateral | 73% (47/64) | 85% (58/68) | −12(−26, 2)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Outcome: Adverse events
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | Amox-clav | Gatifloxacin | Diff (95%CI)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Any | 27% (46/173) | 24% (42/176) | 3%(−6, 12)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Abd pain or diarrhea (severe in intensity)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | 0.6% (1/173) | 0% (0/176) | 0.6(−0.4,1.7)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Anorexia | 0% (0/173) | 0.6% (1/176) | −0.6%(−1.8,0.6)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Arthralgia event unrelated to treatment
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | 1.2% (2/173) | 0.5% (1/176) | 0.6%(−1.4,2.6)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Deaths or Serious drug related events
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | 0% (0/173) | 0% (1/173) | 0% (0, 0)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Diaper rash
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | | 6.4% (11/173) | 5.1% (9/176) | 1.3%(−3.6,6)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Diarrhea | 18% (31/173) | 10% (17/176) | 8% (1, 15)
Sher 2005^122^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 90/6.4 mg/kg/day / bid for 10 days vs. Gatifloxacin 10 mg/kg/day = qd for 10 days | | | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Bacteriologic cure/failure; Adverse effects of treatment | Vomiting | 6% (10/173) | 7% (12/176) | −1%(−6, 4)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | Enrollment Time: 7/2004–7/2005 Place: Emergency room Inclusion: 6 mo–12 yr, AOM Exclusion: Antibiotic within 1 week, Concomitant/Concurrent infection needing antibiotic treatment, TM perforation/Otorrhea, PE tubes/history of PE tubes, Immunosuppressed /compromised/deficient, Hospitalization/need for admission, In other studies/trials, Unable/unlikely to return to follow-up, No telephone, Language barrier | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Healthcare utilization at day 4–6
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | | Antibiotic Rx | RxHold | Diff (95%CI)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Not fill Rx | 13% (17/133) | 62% (82/132) | −49%(−61, −37)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | No analgesic | 90% (120/133) | 93% (123/132) | −3%(−10, 3.7)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | No MD visit | 92% (125/133) | 90% (110132) | 2%(−4.9, 8.9)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Presence of symptoms and signs at day 4–6
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | | Antibiotic Rx | RxHold | Diff (95% CI)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Otalgia | 67% (89/133) | 64% (85/132) | 3%(−8, 14)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Fever | 35% (46/133) | 32% (42/132) | 3%(−8, 14)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Diarrhea | 23% (31/133) | 8% (10/132) | 15%(6, 24)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Vomiting | 11% (15/133) | 11% (15/132) | 0%(−7.5, 7.5)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Healthcare utilization at day 11–14
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | | Antibiotic Rx | RxHold | Diff (95%CI)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | No analgesic | 11% (13/123) | 5% (6/124) | 6%(−18, 6)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | No MD visit | 89% (109/123) | 85% (106124) | 4%(−4.4, 12)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Presence of symptoms and signs at day 11–14
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | | Antibiotic Rx | RxHold | Diff (95% CI)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Otalgia | 61% (75/123) | 67% (83/124) | −6%(−18, 6)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Fever | 31% (38/123) | 32% (40/124) | −1%(−13, 11)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Diarrhea | 24% (29/123) | 12% (15/124) | 12%(2.4, 22)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Vomiting | 10% (12/123) | 9% (11/124) | 1%(−6, 8)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Adverse event at 4–6 day follow-up
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | | Antibiotic Rx | RxHold | Diff (95%CI)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Diarrhea | 21% (31/145) | 7% (10/138) | 14%(6, 22)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Otalgia | 61% (89/145) | 62% (85/138) | −0.2%(−11,11)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Vomiting | 10% (15/145) | 11% (15/138) | −1%(−8, 7)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Outcome: Adverse event at 11–14 day follow-up
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Diarrhea | 20% (29/145) | 11% (15/138) | 9% (0.7, 18)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Otalgia | 52% (75/145) | 60% (83/138) | −8%(−20,3.2)
Spiro 2006^94^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Not specified | Antibiotic vs. Prescription to Hold | | Entering: N=283 N=145 Antibiotic N=138 Prescription to hold Completing: N=265 N=133 Antibiotic N=132 Prescription to hold Analyzed: N=265 N=133 Antibiotic N=132 Prescription to hold | Treatment failure; Adverse effects of treatment; Parent satisfaction; Cost outcomes; Healthcare utilization | Vomiting | 8% (12/145) | 8% (11/138) | 0.3%(−6, 7)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | Study Time: 9/1995–12/1996 Place: India, United Arab Emirates Multicenter: 6 centers Hospital clinic/ outpatient Inclusion: 1–12 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Loss of landmarks, Erythematous TM, Otorrhea, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Decreased hearing, Fever Exclusion: Penicillin/beta-lactams, Antibiotic within 7 days, Concomitant/Concurrent infection needing antibiotic treatment, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 24 hours, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Major Systemic disease/ condition, medical problem, Bowel function-altering meds, Concurrent use of antihistamine, On other medication/treatment | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Other symptoms: decreased hearing; Bacteriologic cure/failure; Disease recurrence; Adverse effects of treatment | Outcome: Success at end of study day 28–34
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | | Amox-clav | Cefaclor | Diff((95%CI)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Total | 91.4% (96/105) | 78.6%(88/112) | 13%(3.2, 22)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Outcome: Success at end of treatment on day 7
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | | Amox-clav | Cefaclor | Diff((95%CI)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Total | 97.1% (102/105) | 83.9% (94/112) | 13%(5.3, 21)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Outcome: Absence of tympanic membrane indicators (redness, bulging, loss of light reflex, rupture)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | | Amox-clav | Cefaclor | Diff((95%CI)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Day7 | 62.9% (66/105) | 44.6% (50/112) | 18%(5.0, 32)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Day10–12 | 90.0%(90/100) | 84.2% (85/101) | 6%(−3.5, 15)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Day28–34 | 93.8%(90/96) | 91.6% (87/95) | 2%(−5.2, 10)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Outcome: Absence of signs and symptoms (ear pain, ear discharge, hearing loss)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | | Amox-clav | Cefaclor | Diff((95%CI)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Day7 | 99.0% (104/105) | 83.9% (94/112) | 15%(7.6, 23)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Day10–12 | 97.0% (97/100) | 92.1% (93/101) | 5%(−1.4, 11)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Day28–34 | 97.9% (94/96) | 94.7% (90/95) | 3% (−2.1, 8)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Outcome: Adverse events
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | | Amox-clav | Cefaclor | Diff((95%CI)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Diarrhea | 7% (8/114) | 8.4% (10/119) | −1.4%(−8,5.5)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Fever | 0% (0/114) | 1.7% (2/119) | −1.7%(−4, 0.7)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Headache | 0% (0/114) | 2.5% (3/119) | −2.5%(−5.4,0.4)
Subba Rao 1998^5^ | Jadad quality score 1 (0–5):3 [1,0,1,1,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 250 mg for > 6 y = tid for 7 days, --- 125 mg for < 6 y = tid for 7 days vs. Cefaclor 125 or 250 mg = tid for 7 days | | Entering: N=233 N=114 Amoxicillin-clavulanate N=119 Cefaclor Completing: N=183 N=93 Amoxicillin- clavulanate N=90 Cefaclor Analyzed: N=217 N=105 Amoxicillin-clavulanate N=112 Cefaclor | | Vomiting | 2.6% (3/114) | 5% (6/119) | −2.4%(−7.3,2.5)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | Outcome: Success rate (none or 1 AOM episode in 6 months)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | Amoxicillin | Sulfisoxazole | Diff (95%CI)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | 90% (36/40) | 78% (28/36) | 12% (−4, 29)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | Outcome Success rate (none or 1 AOM episode in 1 year)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | Amoxicillin | Sulfisoxazole | Diff (95%CI)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | 68% (27/40) | 64% (23/36) | 4% (−18, 25)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | Outcome: Success rate (none or 1 AOM episode in 6 months)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | Amoxicillin | Placebo | Diff (95%CI)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | 90% (36/40) | 71% (29/41) | 19% (2, 37)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | Outcome: Success rate (none or 1 AOM episode in 1 year)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | Amoxicillin | Placebo | Diff (95%CI)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | 68% (27/40) | 66% (27/41) | 2% (−19, 22)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | Outcome: Success rate (none or 1 AOM episode in 6 months)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | Sulfisoxazole: | Placebo | Diff (95%CI)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | 78% (28/36) | 71% (29/41) | 7% (−12, 27)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | Outcome: Success rate (none or 1 AOM episode in 1 year)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | Sulfisoxazole | Placebo | Diff (95%CI)
Teele 2000^129^ | Jadad quality score 1 (0–5):3 [1,1,0,1,0] Definition: Acute onset of S&S, Presence of MEE, S&S of MEI | Placebo vs. Sulfa alone 50 mg/kg/day = qd vs. Amoxicillin 20 mg/kg/day = qd | Place: United States Multicenter: 2 centers Inclusion: Recurrent AOM | Entering: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Completing: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin Analyzed: N=117 N=41 Placebo N=36 Sulfa N=40 Amoxicillin | Treatment failure; Presence of MEE [also persistent effusion, OME]; Disease recurrence | | 64% (23/36) | 66% (27/41) | −2% (−23, 20)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | Study Time: 1/1996–7/1997 Inclusion: 3 mo–15 yr, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Loss of landmarks, Air fluid level behind TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), Otalgia, Fever Exclusion: Penicillin/beta-lactams, Antibiotic within 48 hours, TM perforation/Otorrhea, Immunosuppressed /compromised/deficient, Major Systemic disease/ condition, medical problem, Investigational drug within 2 weeks, Unable/unlikely to return to follow-up | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Success (cured or improved) at end of treatment day 10–14
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Cefaclor | Cefpodoxime | Diff (95%CI)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 90.0% (27/30) | 95.2% (20/21) | −5%(−20, 10)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Absence of middle ear effusion day 10–14
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Cefaclor | Cefpodoxime | Diff (95%CI)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 35.0% (7/20) | 26.7% (4/15) | 8%(−23, 39)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | Cefaclor | Cefpodoxime | Diff (95%CI)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Any | 15% (5/34) | 30% (7/23) | −16(−37,5.9)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Abdominal discomfort
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 3% (1/34) | 9% (2/23) | −6%(−18,6)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Diarrhea | 3% (1/34) | 17% (4/23) | −14%(−30,0.5)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Intolerable abd discomfort or intolerable urticaria leading to being switched to other tx group
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | | 3% (1/34) | 0% (0/23) | 3%(−4, 10)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Pruritis | 0% (0/34) | 4% (1/23) | −4%(−11, 3)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Skin rash | 6% (2/34) | 0% (0/23) | 6%(−4,16)
Tsai 1998^86^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefpodoxime 10 mg/kg/day = qd for 10 days vs. Cefaclor 45 mg/kg/day / tid for 10 days | | Entering: N=57 N=23 Cefpodoxime N=34 Cefaclor Completing: N=51 N=21 Cefpodoxime N=30 Cefaclor Analyzed: N=51 N=21 Cefpodoxime N=30 Cefaclor | Treatment failure; Presence of MEE [also persistent effusion, OME]; Signs or symptoms of MEI; Other symptoms: fever; Disease recurrence; Adverse effects of treatment | Sweating | 3% (1/34) | 0% (0/23) | 3% (−4, 10)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | Study Time: 2/1996–12/1996 Place: Multicenter: 13 centers Inclusion: 3 mo–12 yr, >5.5 kg, Presence of middle ear effusion (MEE), Bulging tympanic membrane [TM], Cloudy TM, Loss of landmarks, Erythematous TM, Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Decreased hearing, Ear fullness, Fever, AOM treated with antibiotic 2–10 days Exclusion: Penicillin/beta-lactams, Concomitant/Concurrent infection needing antibiotic treatment, OME (serous OM, nonsuppurative OM, mucoid OM secretory OM, glue ear), TM perforation/Otorrhea 24 hours, Complication of OM, PE tubes/history of PE tubes, GI disorders/Liver, Renal Disorders, Other Infectious diseases (meningitis), Major Systemic disease/ condition, medical problem, Investigational drug within 28 days, Menarche | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Outcome: Clinical success (cured or improved)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | | Cefaclor | Cefuroxime axetil | Diff (95%CI)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Day 10 | 93.6% (73/78) | 92.9% (65/70) | 0.7%(−7, 9)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Day20–26 | 85.9% (67/78) | 87.1% (61/70) | −1.2%(−12, 10)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Outcome: Adverse events
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | | Cefaclor | Cefuroxime axetil | Diff (95%CI)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Any | 31% (32/104) | 36% (36/101) | −5%(−18, 8)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Asthma or Bronchospasm unrelated to study drug or respiratory disorder or vomiting
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | | 0% (0/104) | 1% (1/101) | −1%(−2.9, 0.9)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Diarrhea | 2% (2/104) | 1% (11/101) | −9%(−16,−2.3)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Diarrhea during treatment
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | | 0% (0/104) | 8% (8/101) | −8%(−13,−2.5)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Increased cough
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | | 7% (7/104) | 0% (0/101) | 7% (1.7,12)
Turik 1998^125^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Cefuroxime 30 mg/kg/day / bid for 10 days vs. Cefaclor 40 mg/kg/day / bid for 10 days | | Entering: N=205 N=101 Cefuroxime N=104 Cefaclor Completing: N=189 N=91 Cefuroxime N=98 Cefaclor Analyzed: N=205 N=101 Cefuroxime N=104 Cefaclor | Treatment failure; Adverse effects of treatment | Rhinitis | 9% (9/104) | 10% (10/101) | −1%(−9, 7)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | Enrollment Time: 2/2000–4/2002 Place: China Inclusion: 3 mo–6 yr, Presence of middle ear effusion (MEE), Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), S&S of middle ear inflammation (MEI), Otalgia, Otoscopy (distinct TM erythema), Decreased hearing, Fever >38 C Exclusion: Antibiotic within 7 days, TM perforation/Otorrhea, PE tubes/history of PE tubes | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Clinical cure rate on day 11 after 10-day treatment (per protocol)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Ceftriaxon | Diff (95%CI)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | | 78.1% (25/32) | 75.6% (31/41) | 2.5%(−22, 17)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Clinical cure rate on day 11 after 10-day treatment (intent to treat)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Ceftriaxon | Diff (95%CI)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | | 60.0% (27/45) | 62.8% (32/51) | 3% (−17, 22)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | Outcome: Adverse events
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | | Amox-clav | Ceftriaxon | Diff (95%CI)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | Any | 36% (20/55) | 24% (13/54) | 12%(−5.0,30)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | Diarrhea | 31% (17/55) | 17% (9/54) | 14%(−1.8,30)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | GI | 34% (19/55) | 22% (12/54) | 12%(−4.6,29)
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | Skin & appendages or rash
Wang 2004^78^ | Jadad quality score 1 (0–5):2 [1,0,1,0,0] Definition: Presence of MEE, S&S of MEI | Amoxicillin- clavulanate 45 mg/kg/day / tid for 10 days vs. Ceftriaxone 50 mg/kg/day = qd for 1 day | | Entering: N=109 N=55 Amoxicillin-clavulanate N=54 Ceftriaxone Completing: N=78 N=35 Amoxicillin- clavulanate N=43 Ceftriaxone Analyzed: N=73 N=32 Amoxicillin-clavulanate N=41 Ceftriaxone | Treatment failure; Disease recurrence; Adverse effects of treatment | | 11% (6/55) | 7% (4/54) | 4%(−7, 14)
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | Study Time: 11/2001–4/2002 Place: China Multicenter: 3 centers Hospital, University/ academic, Children’s Inclusion: 1–12 yr, Acute onset S&S (parent/guardian report), Bulging tympanic membrane [TM], Erythematous TM, S&S of middle ear inflammation (MEI), Otoscopy (distinct TM erythema), Decreased hearing, Fever >38 C, Tympanocentesis preformed Not Specified, Weight of child Lower weight limit not specified, Weight of child Upper weight limit not specified Exclusion: Allergic to other medication NOS, Antibiotic within 7 days, AOM within 3 days, Recurrent AOM (>1 episodes in 6 months), Otitis externa, TM perforation/Otorrhea, Renal Disorders, Major Systemic disease/ condition, medical problem | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | Treatment failure; By otoscopic findings:; Bulging tympanic membrane [TM]; Erythematous TM; By Pneumatic otoscopy/tympanometry; By symptoms (otalgia, ear fullness); Other symptoms: fever; Other symptoms: decreased hearing | Outcome: Success rate at 10–14 days (cured or improved):
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | | Amox | Ceftriaxon | Diff (95%CI)
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | | 90.6% (96/106) | 97.2% (103/106) | −7%(−13, −0.2)
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | Outcome: Adverse effects
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | | Amox | Ceftriaxon | Diff (95%CI)
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | | 1.9% (2/106) | 1.9% (2/106) | 0%
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | | 2/106 | 2/106
Zhang 2003^68^ | Jadad quality score 1 (0–5):1 [1,0,1,0,0] Definition: Acute onset of S&S | Amoxicillin 40 mg/kg/day tid for 10 vs. Ceftriaxone 50 mg/kg/day for 1 day | | Entering: N=236 N=118 Ceftriaxone N=118 Amoxicillin Completing: N=212 N=106 Ceftriaxone N=106 Amoxicillin Analyzed: N=212 N=106 Ceftriaxone N=106 Amoxicillin | | Adverse events not reported by drug arm.
Zielnik- Jurkiewicz 2005^65^ | Jadad quality score 1 (0–5):4 [1,1,1,1,0] Definition: Not specified | Amoxicillin 80 mg/kg/day / tid for 10 days vs. Amoxicillin 80 mg/kg/day / tid for 10 days, Fenspiride 2 ml / tid for 10 days | Place: Poland Inclusion: Pneumatic otoscopy/tympanometry (limited or absent mobility of TM), AOM, Age of child Children, age not specified Exclusion: Any antibiotic, GI disorders/Liver, Adenoid hypertrophy | Entering: N=40 N=20 Amoxicillin N=20 Amoxicillin/Fenspiride Completing: N=40 N=20 Amoxicillin N=20 Amoxicillin/Fenspiride Analyzed: N=40 N=20 Amoxicillin N=20 Amoxicillin/Fenspiride | Otorrhea; Signs or symptoms of MEI; By symptoms (otalgia, ear fullness); Other symptoms: fever; Other symptoms: decreased hearing | In Polish. Adverse events not reported