# Sample Data Abstraction Forms

Screening Form

Key Question 1 Data Abstraction Form

Key Question 2 Second Level Screener

Key Questions 3-6 Data Abstraction Form