# Scope, Definitions and Search Strategies

Table A.1 Scope of the Report and Definitions

Disease Entity | Uncomplicated AOM, including recurrent and persistent AOM^1^
Patient Population | Age 4 weeks to 18 years Exclude: patients with immunodeficiencies and craniofacial deficiencies including cleft palate
Settings | All types of providers and practice settings
Interventions 2 | “Wait and see” approach/placebo
Interventions 2 | Antibiotic treatment (all classes, schedule, dosage, length, and mode)
Interventions 2 | Delayed antibiotic
Interventions 2 | Analgesics/other non-antibiotic medical therapies/surgery (including PE tubes)
Influencing factors | Age
Influencing factors | Race/ethnicity
Influencing factors | Laterality
Influencing factors | Otorrhea or perforation
Influencing factors | AOM severity
Influencing factors | Signs and physical symptoms (ear pulling, otorrhea, irritability, fever, tympanic membrane (TM) inflammation, retracted TM, middle ear effusion [MEE])
Influencing factors | Comorbidities (e.g., asthma)
Influencing factors | Day care attendance
Influencing factors | Environmental factors
Influencing factors | Practitioner
Influencing factors | Setting
Influencing factors | Parent/caretaker
Influencing factors | Examiner
Influencing factors | Recurrent OM/otitis prone
Influencing factors | Persistent/relapse OM (continued on next page)
Influencing factors | Diagnostic mode (otoscopy; tympanocentesis; pneumatic otoscopy/tympanometry; acoustic reflectometry
Outcome measures | Treatment failure
Outcome measures | Duration of symptoms or illness
Outcome measures | Presence of MEE by otoscopic findings (Bulging, cloudy, erythematous TM; air fluid level behind TM; Loss of landmarks; otorrhea)
Outcome measures | Presence of MEE by Pneumatic otoscopy/tympanometry (Limited or absent mobility of TM)
Outcome measures | Presence of MEE by acoustic reflectometry (presence of MEF)
Outcome measures | Presence of MEE by tympanocentesis
Outcome measures | Signs and symptoms of middle ear inflammation (MEI) by symptoms (otalgia, ear fullness)
Outcome measures | Signs or symptoms of MEI by otoscopy (distinct TM erythema)
Outcome measures | Other symptoms (decreased hearing, fever)
Outcome measures | Invasive infections
Outcome measures | Bacteriological cure/failure
Outcome measures | Disease recurrence
Outcome measures | Adverse effects of treatment (e.g., diarrhea, vomiting, bacterial resistance) and method of assessment
Outcome measures | Quality of life or functional outcome
Outcome measures | Parental satisfaction
Outcome measures | Cost of outcomes, e.g., Days school/daycare missed
Outcome measures | Bacteriologic outcomes by nasopharyngeal cultures
Outcome measures | Otologic complications- i.e., cholestetoma
Outcome measures | PE tube placement
Outcome measures | Health care utilization
Outcome measures | Microbial epidemiology and antibiotic resistance^3^
Time Period | 1998–2009^4^
Literature Sources | Medline
Literature Sources | Web of Science
Literature Sources | Cochrane Database of Systematic Reviews
Literature Sources | Proceedings of International Society of Otolaryngology
Literature Sources | References
Languages | No restriction
Study Design | Randomized controlled trials, blinded and unblinded
Study Design | Non-randomized controlled trials, blinded and unblinded
Study Design | Prospective and retrospective observational studies^5^
Study Design | Case-control studies6

1 Definition of AOM: A diagnosis of AOM requires 1) a history of acute onset of signs and symptoms, 2) the presence of middle ear effusion (MEE), and 3) signs and symptoms of middle-ear inflammation.

Elements of the definition of AOM are all of the following:

1. Recent, usually abrupt, onset of signs and symptoms of middle-ear inflammation and MEE
2. The presence of MEE that is indicated by any of the following:
  a. Bulging of the tympanic membrane
  b. Limited or absent mobility of the tympanic membrane
  c. Air-fluid level behind the tympanic membrane
  d. Otorrhea
3. Signs or symptoms of middle-ear inflammation as indicated by either
  a. Distinct erythema of the tympanic membrane or
  b. Distinct otalgia (discomfort clearly referable to the ear[s] that results in interference with or precludes normal activity or sleep)

Definition of Recurrent AOM (RAOM): A diagnosis of RAOM requires three or more episodes of acute otitis media within 6 months or four episodes within 12 months, including at least 1 episode during the preceding 6 months.

Definition of Persistent Otitis Media: Persistent otitis media is manifested by persistence during antimicrobial therapy of symptoms and signs of middle ear infection (treatment failure) and/or relapse of acute otitis media within 1 month of completion of antibiotic therapy. When two episodes of otitis media occur within 1 month, it may be difficult to distinguish recurrence of acute otitis media (i.e. a new episode) from persistent otitis media (i.e. relapse).

2 Antibiotics and other treatment modalities are considered individually for questions 3–6 on treatment outcomes;

3 These outcomes are considered only for question 2 on PNC7 vaccine.

4 Search for articles on recurrent and persistent AOM spanned 1966–2009

5 Where RCTs unavailable to answer a particular question

ACUTE OTITIS MEDIA – SEARCH METHODOLOGIES UPDATES FROM JULY 2008–AUGUST 2010

JULY 2008 – JANUARY 2009 UPDATES (Searches run 1/13–1/15/09)

DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 7/1/2008–1/13/2009 SEARCH STRATEGY: otitis media NUMBER OF ITEMS RETRIEVED: 288
DATABASE SEARCHED & TIME PERIOD COVERED: Cochrane – 7/1/2008–1/13/2009 SEARCH STRATEGY: otitis media.mp. NUMBER OF ITEMS RETRIEVED: Systematic Reviews - 14 DARE – 45 CCTR - 11 DATABASE SEARCHED & TIME PERIOD COVERED: Web of Science – 2008–2009 SEARCH STRATEGY: Topic=otitis media NOT Topic=(dog OR cat OR mice OR rats OR chinchilla* OR pig) NUMBER OF ITEMS RETRIEVED: 725

JANUARY – AUGUST 2009 UPDATES (Search run 8/24/09)

DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 2009 SEARCH STRATEGY: otitis media NUMBER OF ITEMS RETRIEVED: 412
DATABASE SEARCHED & TIME PERIOD COVERED: Cochrane - 2009 SEARCH STRATEGY: otitis media.mp. NUMBER OF ITEMS RETRIEVED: Systematic Reviews -87 DARE – 51 CCTR – 4
DATABASE SEARCHED & TIME PERIOD COVERED: Web of Science Databases - SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH. – 2009 SEARCH STRATEGY: Topic=(otitis media) NOT Topic=(dog OR cat OR mice OR rats OR chinchilla* OR pig OR mouse) NUMBER OF ITEMS RETRIEVED: 441

AUGUST 2009 – MAY 2010 UPDATES (Searches run 5/5/10)

DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 8/2009– 5/5/2010 SEARCH STRATEGY: otitis media NOT animal NOT (human OR humans) NOT dog OR cat OR mice OR mouse OR rat OR rats OR chinchilla* OR pig NUMBER OF ITEMS RETRIEVED: 426
DATABASE SEARCHED & TIME PERIOD COVERED: Web of Science Databases - SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH. – 2009– 5/5/2010 SEARCH STRATEGY: Topic=(otitis media) NOT Topic=(dog OR cat OR mice OR MOUSE OR RAT OR rats OR chinchilla* OR pig) NUMBER OF ITEMS RETRIEVED: 879

MAY–AUGUST 2010 UPDATES (Searches run 8/3/10)

DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 4/1/2010 –8/3/2010 SEARCH STRATEGY: otitis media NUMBER OF ITEMS RETRIEVED: 200
DATABASE SEARCHED & TIME PERIOD COVERED: Cochrane – 4/1/2010 –8/3/2010 SEARCH STRATEGY: otitis media.mp. NUMBER OF ITEMS RETRIEVED: Reviews - 33 DARE - 4
DATABASE SEARCHED & TIME PERIOD COVERED: Web of Science – 2010 SEARCH STRATEGY: TS=(otitis media) NOT TS=(dog OR cat OR mice OR MOUSE OR RAT OR rats OR chinchilla* OR pig) NUMBER OF ITEMS RETRIEVED: 374

Figure A.1 Literature Flow Diagram

Figure A.1. Literature Flow Diagram