# Appendixes

Appendix A Scope, Definitions and Search Strategies

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables For Randomized Controlled Trials

Appendix D List of Excluded studies

Appendix E List of Peer Reviewers

Appendix F Technical Expert Panel Composition and Meeting Summaries

Appendix G Summary Tables for Studies Included in Comparisons

Appendix H Conceptual Framework for the Report

Appendix I Summaries of Systematic Reviews Included in Analyses

Appendix J Comparison of Original Research Studies Included in Systematic Reviews