# Acknowledgments

We wish to acknowledge the invaluable guidance and expertise contributed to this project by the Technical Expert Panel members who are listed in Appendix F. We also thank CAPT Ernestine (Tina) Murray (AHRQ) for her patience, guidance, and input, and the Oregon Evidence-based Practice Center, Rose Relevo, for assistance with research on drug safety, and the administrative staff for assistance with preparation of the report.