# List of Acronyms/Abbreviations

AOM: acute otitis media
AMX: amoxicillin
CI: confidence interval
ENT: ear, nose, and throat specialist
GP: general practitioner
HF: Haemophilus influenzae
LR: likelihood ratio
MEE: middle ear effusion
MEF: middle ear fluid
NNT: number-to-treat
OME: Otitis media with effusion
OR: Odds ratio
PcV: phenoxymethylpencillin
PPV: polysaccharide pneumococcal vaccine
RCT: randomized controlled trial
RD: Rate difference
ROM: Recurrent otitis media
SP: streptococcus pneumoniae
TF: tympanic fluid
TM: tympanic membrane
Tx: treatment