# Technical Expert Panel

Philip Brooks, Ph.D.

Molecular Neurobiologist, Laboratory of Neurogenetics

National Institute of Alcohol Abuse and Alcoholism

Bethesda, MD

Joanne Dorgan, M.P.H., Ph.D.

Member, Division of Population Studies

Fox Chase Cancer Center

Philadelphia, PA

Joel Mason, M.D.

Scientist I and Director, Vitamins and Carcinogenesis Laboratory

Jean Mayer USDA Human Nutrition Research Center on Aging

Tufts University

Boston, MA

Mikko Salaspuro, M.D., Ph.D.

Professor, Research Unit of Substance Abuse Medicine

University of Helsinki

Helsinki, Finland

Helmut Seitz, M.D., Ph.D.

Director, Department of Medicine

Salem Medical Center and Laboratory of Alcohol Research

Heidelberg, Germany

## AHRQ Contacts

Stephanie Chang, M.D., M.P.H.

Director and Task Order Officer

Evidence-based Practice Center Program

Agency for Healthcare Research and Quality

Rockville, MD

Karen Lohmann Siegel, P.T., M.A.

CAPT, U.S. Public Health Service

Associate Director

Evidence-based Practice Center Program

Agency for Healthcare Research and Quality

Rockville, MD