# References and Included Studies

1 US Department of Health and Human Services, Public Health Service. National Toxicology Program. Alcoholic beverage consumption, Known to be a human carcinogen. Rockville (MD). U.S. Department of Health and Human Services. 2000:2.
2 Baan R, Straif K, Grosse Y, Secretan B, El Ghissassi F, Bouvard V, Altieri A, Cogliano V. WHO International Agency for Research on Cancer Monograph Working Group. Carcinogenicity of alcoholic beverages. Lancet Oncol. 04. 2007;8(4):292-3. [pmid: 17431955].
3 Seitz HK, Simanowski UA. Alcohol and carcinogenesis. Annu Rev Nutr. 1988;8:99-119. [pmid: 3060182].
4 Monteiro R, Calhau C, Silva AO, Pinheiro-Silva S, Guerreiro S, Gartner F, Azevedo I, Soares R. Xanthohumol inhibits inflammatory factor production and angiogenesis in breast cancer xenografts. J Cell Biochem. 08. 1. 2008;104(5):1699-707. [pmid: 18348194].
5 Holford NH. Clinical pharmacokinetics of ethanol. Clin Pharmacokinet. 11. 1987;13(5):273-92. [pmid: 3319346].
6 Levitt DG. PKQuest: measurement of intestinal absorption and first pass metabolism - application to human ethanol pharmacokinetics. BMC Clin Pharmacol. 08. 15. 2002;2(4). [pmid: 12182761].
7 Oneta CM, Simanowski UA, Martinez M, Allali-Hassani A, Pares X, Homann N, Conradt C, Waldherr R, Fiehn W, Coutelle C, Seitz HK. First pass metabolism of ethanol is strikingly influenced by the speed of gastric emptying. Gut. 11. 1998;43(5):612-9. [pmid: 9824340].
8 Zakhari S. Overview: how is alcohol metabolized by the body. Alcohol Res Health. 2006;29(4):245-54. [pmid: 17718403].
9 Nagy LE. Molecular aspects of alcohol metabolism: transcription factors involved in early ethanol-induced liver injury. Annu Rev Nutr. 2004;24:55-78. [pmid: 15189113].
10 Dumitrescu RG, Shields PG. The etiology of alcohol-induced breast cancer. Alcohol. 04. 2005;35(3):213-25. [pmid: 16054983].
11 Alcohol metabolism, tobacco and cancer, Cho C Alcohol, Tobacco, and Cancer. Switzerland. S. Karger AG. 07. 2006:29-47.
12 Jelski W, Szmitkowski M. Alcohol dehydrogenase (ADH) and aldehyde dehydrogenase (ALDH) in the cancer diseases. Clin Chim Acta. 09. 2008;395(1–2):1-5. [pmid: 18505683].
13 Alcohol and cancer of the large intestine, Cho C Alcohol, Tobacco, and Cancer. Switzerland. S. Karger AG. 07. 2006:63-77.
14 Seitz HK, Stickel F. Molecular mechanisms of alcohol-mediated carcinogenesis. Nat Rev Cancer. 08. 2007;7(8):599-612. [pmid: 17646865].
15 Jelski W, Zalewski B, Chrostek L, Szmitkowski M. The activity of class I, II, III, and IV alcohol dehydrogenase isoenzymes and aldehyde dehydrogenase in colorectal cancer. Dig Dis Sci. 06. 2004;49(6):977-81. [pmid: 15309886].
16 Jelski W, Orywal K, Kedra B, Szmitkowski M. Alcohol dehydrogenase and aldehyde dehydrogenase as tumour markers and factors intensifying carcinogenesis in colorectal cancer. Pol Merkur Lekarski. 06. 2008;24(144):506-10. (Pol). [pmid: 18702331].
17 Secretan B, Straif K, Baan R, Grosse Y, El Ghissassi F, Bouvard V, Benbrahim-Tallaa L, Guha N, Freeman C, Galichet L, Cogliano V. WHO International Agency for Research on Cancer Monograph Working Group. A review of human carcinogens--Part E: tobacco, areca nut, alcohol, coal smoke, and salted fish. Lancet Oncol. 11. 2009;10(11):1033-4. [pmid: 19891056].
18 Alcohol and breast cancer risk, Cho C Alcohol, Tobacco, and Cancer. Switzerland. S. Karger AG. 07. 2006:119-39.
19 Homann N, Konig IR, Marks M, Benesova M, Stickel F, Millonig G, Mueller S, Seitz HK. Alcohol and colorectal cancer: the role of alcohol dehydrogenase 1C polymorphism. Alcohol Clin Exp Res. 03. 2009;33(3):551-6. [pmid: 19120062].
20 Salaspuro M. Bacteriocolonic pathway for ethanol oxidation: characteristics and implications. Ann Med. 06. 1996;28(3):195-200. [pmid: 8811162].
21 Seitz HK, Egerer G, Oneta C, Kramer S, Sieg A, Klee F, Simanowski UA. Alcohol dehydrogenase in the human colon and rectum. Digestion. 03. 1996;57(2):105-8. [pmid: 8785998].
22 General mechanisms of cancer, Cho C Alcohol, Tobacco, and Cancer. Switzerland. S. Karger AG. 07. 2006:1-12.
23 Ketcham AS, Wexler H, Mantel N. Effects of alcohol in mouse neoplasia. Cancer Res. 06. 1963;23:667-70. [pmid: 14032175].
24 Poschl G, Seitz HK. Alcohol and cancer. Alcohol Alcohol. 05-06. 2004;39(3):155-65. [pmid: 15082451].
25 Wright RM, McManaman JL, Repine JE. Alcohol-induced breast cancer: a proposed mechanism. Free Radic Biol Med. 02. 1999;26(3–4):348-54. [pmid: 9895226].
26 National Institute on Alcohol Abuse and Alcoholism (NIAAA). Three stages of carcinogenesis. Bethesda (MD). National Institutes of Health (NIH). 02. 2001:1. Also available: http://www.niaaa.nih.gov/NR/rdonlyres/9E893CA5-39E0-47D8-B924-E4B883006642/0/lieb.pdf.
27 Prevalence and trends data Nationwide (states, DC, and territories) [internet]. Atlanta (GA). Centers for Disease Control and Prevention(CDC). 2008. accessed 2009 Aug 21. 2008 alcohol consumption: adults who have had at least one drink of alcohol within the past 30 days. [2 p]. Available: http://apps.nccd.cdc.gov/brfss/index.asp.
28 WHO. Global status report on alcohol 2004. Geneva. World Health Organization (WHO). 2004:94.
29 Dufour MC. What is moderate drinking? Defining “drinks” and drinking levels. Alcohol Res Health. 1999;23(1):5-14. [pmid: 10890793].
30 U.S. Department of Health and Human Services. U.S. Department of Agriculture. Dietary guidelines for Americans, 2005. Washington (DC). U.S. Department of Health and Human Services, U.S. Department of Agriculture. 2005:84. Also available: www.healthierus.gov/dietaryguidelines.
31 Harvard School of Public Health (HSPH). The nutrition source. Alcohol: balancing risks and benefits. [internet]. Boston (MA). Harvard School of Public Health (HSPH). 2009:9. Available: http://www.hsph.harvard.edu/nutritionsource/what-should-you-eat/alcohol-full-story/.
32 CDC. Alcohol. [internet]. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2009;(6). Availablehttp://www.cdc.gov/alcohol/faqs.htm.
33 Giovannucci E. Alcohol, one-carbon metabolism, and colorectal cancer: recent insights from molecular studies. J Nutr. 09. 2004;134(9):2475S-81S. [pmid: 15333745].
34 Hamajima N, Hirose K, Tajima K, Rohan T, Calle EE, Heath CW Jr, Coates RJ, Liff JM, Talamini R, Chantarakul N, Koetsawang S, Rachawat D, Morabia A, Schuman L, Stewart W, Szklo M, Bain C, Schofield F, Siskind V, Band P, Coldman AJ, Gallagher RP, Hislop TG, Yang P, Kolonel LM, Nomura AM, Hu J, Johnson. Alcohol, tobacco and breast cancer--collaborative reanalysis of individual data from 53 epidemiological studies, including 58,515 women with breast cancer and 95,067 women without the disease. Br J Cancer. 11. 18. 2002;87(11):1234-45. [pmid: 12439712].
35 O’Hanlon LH. Studies seek molecular clues on alcohol’s role in cancer. J Natl Cancer Inst. 11. 2. 2005;97(21):1563-4. [pmid: 16264173].
36 Cho E, Smith-Warner SA, Ritz J, van den Brandt PA, Colditz GA, Folsom AR, Freudenheim JL, Giovannucci E, Goldbohm RA, Graham S, Holmberg L, Kim DH, Malila N, Miller AB, Pietinen P, Rohan TE, Sellers TA, Speizer FE, Willett WC, Wolk A, Hunter DJ. Alcohol intake and colorectal cancer: a pooled analysis of 8 cohort studies. Ann Intern Med. 04. 20. 2004;140(8):603-13. [pmid: 15096331].
37 Zhang Y, Kreger BE, Dorgan JF, Splansky GL, Cupples LA, Ellison RC. Alcohol consumption and risk of breast cancer: the Framingham Study revisited. Am J Epidemiol. 01. 15. 1999;149(2):93-101. [pmid: 9921953].
38 Feigelson HS, Jonas CR, Robertson AS, McCullough ML, Thun MJ, Calle EE. Alcohol, folate, methionine, and risk of incident breast cancer in the American Cancer Society Cancer Prevention Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev. 02. 2003;12(2):161-4. [pmid: 12582027].
39 Smith-Warner SA, Spiegelman D, Yaun SS, van den Brandt PA, Folsom AR, Goldbohm RA, Graham S, Holmberg L, Howe GR, Marshall JR, Miller AB, Potter JD, Speizer FE, Willett WC, Wolk A, Hunter DJ. Alcohol and breast cancer in women: a pooled analysis of cohort studies. JAMA. 02. 18. 1998;279(7):535-40. [pmid: 9480365].
40 Purohit V, Khalsa J, Serrano J. Mechanisms of alcohol-associated cancers: introduction and summary of the symposium. Alcohol. 04. 2005;35(3):155-60. [pmid: 16054976].
41 Singletary K. Ethanol and experimental breast cancer: a review. Alcohol Clin Exp Res. 04. 1997;21(2):334-9. [pmid: 9113272].
42 Key TJ, Schatzkin A, Willett WC, Allen NE, Spencer EA, Travis RC. Diet, nutrition and the prevention of cancer. Public Health Nutr. 02. 2004;7(1A):187-200. [pmid: 14972060].
43 Schatzkin A, Longnecker MP. Alcohol and breast cancer. Where are we now and where do we go from here?. Cancer. 08. 1. 1994;74(3 Suppl):1101-10. [pmid: 8039145].
44 Epidemiology of alcohol-associated cancers, Cho C Alcohol, Tobacco, and Cancer. Switzerland. S. Karger AG. 07. 2006:13-28.
45 Lilla C, Koehler T, Kropp S, Wang-Gohrke S, Chang-Claude J. Alcohol dehydrogenase 1B (ADH1B) genotype, alcohol consumption and breast cancer risk by age 50 years in a German case-control study. Br J Cancer. 06. 6. 2005;92(11):2039-41. [pmid: 15886702].
46 Surveillance Epidemiology and End Results SEER stat fact sheets - cancer of the breast [internet]. Bethesda (MD). National Cancer Institute (NCI). accessed 2007 Feb 5. 3. Available: http://seer.cancer.gov/statfacts/html/breast_print.html.
47 Hines LM, Hankinson SE, Smith-Warner SA, Spiegelman D, Kelsey KT, Colditz GA, Willett WC, Hunter DJ. A prospective study of the effect of alcohol consumption and ADH3 genotype on plasma steroid hormone levels and breast cancer risk. Cancer Epidemiol Biomarkers Prev. 10. 2000;9(10):1099-105. [pmid: 11045794].
48 Coutelle C, Hohn B, Benesova M, Oneta CM, Quattrochi P, Roth HJ, Schmidt-Gayk H, Schneeweiss A, Bastert G, Seitz HK. Risk factors in alcohol associated breast cancer: alcohol dehydrogenase polymorphism and estrogens. Int J Oncol. 10. 2004;25(4):1127-32. [pmid: 15375565].
49 Freudenheim JL, Ambrosone CB, Moysich KB, Vena JE, Graham S, Marshall JR, Muti P, Laughlin R, Nemoto T, Harty LC, Crits GA, Chan AW, Shields PG. Alcohol dehydrogenase 3 genotype modification of the association of alcohol consumption with breast cancer risk. Cancer Causes Control. 10. 1999;10(5):369-77. [pmid: 10530606].
50 Terry MB, Knight JA, Zablotska L, Wang Q, John EM, Andrulis IL, Senie RT, Daly M, Ozcelik H, Briollais L, Santella RM. Alcohol metabolism, alcohol intake, and breast cancer risk: a sister-set analysis using the Breast Cancer Family Registry. Breast Cancer Res Treat. 12. 2007;106(2):281-8. [pmid: 17268812].
51 Izevbigie EB, Ekunwe SI, Jordan J, Howard CB. Ethanol modulates the growth of human breast cancer cells in vitro. Exp Biol Med (Maywood). 04. 2002;227(4):260-5. [pmid: 11910048].
52 Key J, Hodgson S, Omar RZ, Jensen TK, Thompson SG, Boobis AR, Davies DS, Elliott P. Meta-analysis of studies of alcohol and breast cancer with consideration of the methodological issues. Cancer Causes Control. 08. 2006;17(6):759-70. [pmid: 16783604].
53 National Cancer Institute (NCI). SEER stat fact sheets: cancer, colon and rectum. [internet]. Bethesda (MD). National Cancer Institute (NCI). accessed 2008 Oct 10. 4. Available: http://seer.cancer.gov/statfacts/html/colorect.html.
54 Markowitz SD, Bertagnolli MM. Molecular basis of colorectal cancer, N Engl J Med. 12. 17. 2009;361(25):2449-60. Also available: http://content.nejm.org/cgi/reprint/361/25/2449.pdf. [pmid: 20018966].
55 Nosova T, Jousimies-Somer H, Kaihovaara P, Jokelainen K, Heine R, Salaspuro M. Characteristics of alcohol dehydrogenases of certain aerobic bacteria representing human colonic flora. Alcohol Clin Exp Res. 05. 1997;21(3):489-94. [pmid: 9161610].
56 Jokelainen K, Siitonen A, Jousimies-Somer H, Nosova T, Heine R, Salaspuro M. In vitro alcohol dehydrogenase-mediated acetaldehyde production by aerobic bacteria representing the normal colonic flora in man. Alcohol Clin Exp Res. 09. 1996;20(6):967-72. [pmid: 8892513].
57 Jokelainen K, Matysiak-Budnik T, Makisalo H, Hockerstedt K, Salaspuro M. High intracolonic acetaldehyde values produced by a bacteriocolonic pathway for ethanol oxidation in piglets. Gut. 07. 1996;39(1):100-4. [pmid: 8881818].
58 Slattery ML, Wolff RK, Herrick J, Caan BJ, Samowitz W. Tumor markers and rectal cancer: support for an inflammation-related pathway. Int J Cancer. 10. 1. 2009;125(7):1698-704. [pmid: 19452524].
59 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions 5.0.2. Cochrane Library [book online], The Cochrane Collaboration. 2008. [updated 2009 Sep 1]. accessed 2009 Oct 7. Available: http://www.cochrane-handbook.org/.
60 Riegelman R. Studying a study & testing a test: how to read the medical evidence. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 11. Chapter 7. Interpretation. 1975:50-7.
61 Doll R, Hill AB. Smoking and carcinoma of the lung; preliminary report. Br Med J. 09. 30. 1950;2(4682):739-48. [pmid: 14772469].
62 Doll R, Hill AB. A study of the aetiology of carcinoma of the lung. Br Med J. 12. 13. 1952;2(4797):1271-86. [pmid: 12997741].
63 Hussain SP, Harris CC. Molecular epidemiology of human cancer. Toxicol Lett. 12. 28. 1998;(102–103):219-25. [pmid: 10022257].
64 Owens D, Lohr K, Atkins D, Treadwell J, Reston J, Bass E, Chang S, Helfand M. Grading the strength of a body of evidence when comparing medical interventions, Methods guide for comparative effectiveness reviews. Rockville (MD). Agency for Healthcare Research and Quality(AHRQ). 07. 2009:19. Also available: http://effectivehealthcare.ahrq.gov/ehc/products/122/328/2009_0805_grading.pdf.
65 Etique N, Chardard D, Chesnel A, Merlin JL, Flament S, Grillier-Vuissoz I. Ethanol stimulates proliferation, ERalpha and aromatase expression in MCF-7 human breast cancer cells. Int J Mol Med. 01. 2004;13(1):149-55. [pmid: 14654987].
66 Acetaldehyde-DNA adduts: implications for the molecular mechanism of alcohol-related carcinogenesis, Cho C Alcohol, tobacco, and cancer. Switzerland. S. Karger AG. 07. 2006:78-94.
67 Fan S, Meng Q, Gao B, Grossman J, Yadegari M, Goldberg ID, Rosen EM. Alcohol stimulates estrogen receptor signaling in human breast cancer cell lines. Cancer Res. 10. 15. 2000;60(20):5635-9. [pmid: 11059753].
68 Etique N, Flament S, Lecomte J, Grillier-Vuissoz I. Ethanol-induced ligand-independent activation of ERalpha mediated by cyclic AMP/PKA signaling pathway: an in vitro study on MCF-7 breast cancer cells. Int J Oncol. 12. 2007;31(6):1509-18. [pmid: 17982678].
69 Singletary KW, Frey RS, Yan W. Effect of ethanol on proliferation and estrogen receptor-alpha expression in human breast cancer cells. Cancer Lett. 04. 26. 2001;165(2):131-7. [pmid: 11275361].
70 Homann N, Tillonen J, Salaspuro M. Microbially produced acetaldehyde from ethanol may increase the risk of colon cancer via folate deficiency. Int J Cancer. 04. 15. 2000;86(2):169-73. [pmid: 10738242].
71 Salaspuro M. Microbial metabolism of ethanol and acetaldehyde and clinical consequences. Addict Biol. 1997;2(1):35-46.
72 Vitale JJ, Gottlieb. Alcohol and alcohol-related deficiencies as carcinogens. Cancer Res. 11. 1975;35(11 Pt. 2):3336-8. [pmid: 1192405].
73 Perez-Holanda S, Rodrigo L, Vinas-Salas J, Pinol-Felis C. Effect of ethanol consumption on colon cancer in an experimental model. Rev Esp Enferm Dig. 02. 2005;97(2):87-96. [pmid: 15801884].
74 Tong WM, Manhardt T, Lassnig H, Cross HS. Induction of epidermal growth factor receptor expression and mitogenesis by alcohol in human colon adenocarcinoma-derived Caco-2 cells. Anticancer Res. 07-08. 1999;19(4B):3321-5. [pmid: 10652628].
75 Rodriguez DA, Moncada C, Nunez MT, Lavandero S, Ponnappa BC, Israel Y. Ethanol increases tumor necrosis factor-alpha receptor-1 (TNF-R1) levels in hepatic, intestinal, and cardiac cells. Alcohol. 05. 2004;33(1):9-15. [pmid: 15353169].
76 Hartman TJ, Baer DJ, Graham LB, Stone WL, Gunter EW, Parker CE, Albert PS, Dorgan JF, Clevidence BA, Campbell WS, Tomer KB, Judd JT, Taylor PR. Moderate alcohol consumption and levels of antioxidant vitamins and isoprostanes in postmenopausal women. Eur J Clin Nutr. 02. 2005;59(2):161-8. [pmid: 15367922].
77 Ray G, Batra S, Shukla NK, Deo S, Raina V, Ashok S, Husain SA. Lipid peroxidation, free radical production and antioxidant status in breast cancer. Breast Cancer Res Treat. 01. 2000;59(2):163-70. [pmid: 10817351].
78 Afrasyap L, Guvenen G, Turkmen S. Plasma and erythrocyte total antioxidant status in patients with benign and malign breast disease. Cancer Biochem Biophys. 06. 1998;16(1–2):129-38. [pmid: 9923972].
79 Huang YL, Sheu JY, Lin TH. Association between oxidative stress and changes of trace elements in patients with breast cancer. Clin Biochem. 03. 1999;32(2):131-6. [pmid: 10211630].
80 Kumar K, Thangaraju M, Sachdanandam P. Changes observed in antioxidant system in the blood of postmenopausal women with breast cancer. Biochem Int. 09. 1991;25(2):371-80. [pmid: 1789800].
81 Meagher EA, Barry OP, Burke A, Lucey MR, Lawson JA, Rokach J, FitzGerald GA. Alcohol-induced generation of lipid peroxidation products in humans. J Clin Invest. 09. 1999;104(6):805-13. [pmid: 10491416].
82 van der Worp HB, Howells DW, Sena ES, Porritt MJ, Rewell S, O’Collins V, Macleod MR. Can animal models of disease reliably inform human studies?. PLoS Med. 2010;7(3):e1000245. [pmid: 20361020].
83 Basuroy S, Sheth P, Mansbach CM, Rao RK. Acetaldehyde disrupts tight junctions and adherens junctions in human colonic mucosa: protection by EGF and L-glutamine. Am J Physiol Gastrointest Liver Physiol. 08. 2005;289(2):G367-75. [pmid: 15718285].
84 Perse M, Cerar A. Dimethylhydrazine model is not appropriate for evaluating effect of ethanol on colorectal cancer. Rev Esp Enferm Dig. 08. 2007;99(8):463-6. [pmid: 18020863].
85 Dorgan JF, Baer DJ, Albert PS, Judd JT, Brown ED, Corle DK, Campbell WS, Hartman TJ, Tejpar AA, Clevidence BA, Giffen CA, Chandler DW, Stanczyk FZ, Taylor PR. Serum hormones and the alcohol-breast cancer association in postmenopausal women. J Natl Cancer Inst. 05. 2. 2001;93(9):710-5. [pmid: 11333294].
86 Reichman ME, Judd JT, Longcope C, Schatzkin A, Clevidence BA, Nair PP, Campbell WS, Taylor PR. Effects of alcohol consumption on plasma and urinary hormone concentrations in premenopausal women. J Natl Cancer Inst. 1993;85(9):722-7. [pmid: 8478958].
87 Ginsburg ES, Walsh BW, Shea BF, Gao X, Gleason RE, Feltmate C, Barbieri RL. Effect of acute ethanol ingestion on prolactin in menopausal women using estradiol replacement. Gynecol Obstet Invest. 1995;39(1):47-9. [pmid: 7890253].
88 Ginsburg ES, Mello NK, Mendelson JH, Barbieri RL, Teoh SK, Rothman M, Gao X, Sholar JW. Effects of alcohol ingestion on estrogens in postmenopausal women. JAMA. 12. 4. 1996;276(21):1747-51. [pmid: 8940324].
89 Saitoh M, Ramirez E, Babaian RJ. Ultrasonic volume monitoring in patient with prostate cancer treated by external beam radiation therapy. Urology. 03. 1994;43(3):342-8. [pmid: 7510913].
90 Marugame T, Tsuji E, Inoue H, Shinomiya S, Kiyohara C, Onuma K, Hamada H, Koga H, Handa K, Hayabuchi H, Kono S. Methylenetetrahydrofolate reductase polymorphism and risk of colorectal adenomas. Cancer Lett. 04. 14. 2000;151(2):181-6. [pmid: 10738112].
91 Holmberg B, Ekstrom T. The effects of long-term oral administration of ethanol on Sprague-Dawley rats--a condensed report. Toxicology. 02. 6. 1995;96(2):133-45. [pmid: 7886684].
92 Hilakivi-Clarke L, Cabanes A, de Assis S, Wang M, Khan G, Shoemaker WJ, Stevens RG. In utero alcohol exposure increases mammary tumorigenesis in rats. Br J Cancer. 06. 1. 2004;90(11):2225-31. [pmid: 15150620].
93 Singletary K, Nelshoppen J, Wallig M. Enhancement by chronic ethanol intake of N-methyl-N-nitrosourea-induced rat mammary tumorigenesis. Carcinogenesis. 04. 1995;16(4):959-64. [pmid: 7728981].
94 Singletary KW, McNary MQ. Influence of ethanol intake on mammary gland morphology and cell proliferation in normal and carcinogen-treated rats. Alcohol Clin Exp Res. 10. 1994;18(5):1261-6. [pmid: 7847617].
95 Castro GD, Delgado de Layno AM, Costantini MH, Castro JA. Rat breast microsomal biotransformation of ethanol to acetaldehyde but not to free radicals: Its potential role in the association between alcohol drinking and breast tumor promotion. Teratog Carcinog Mutagen. 2003;(Suppl 1):61-70. [pmid: 12616597].
96 Chhabra SK, Anderson LM, Perella C, Desai D, Amin S, Kyrtopoulos SA, Souliotis VL. Coexposure to ethanol with N-nitrosodimethylamine or 4-(Methylnitrosamino)-1-(3-pyridyl)-1-butanone during lactation of rats: marked increase in O(6)-methylguanine-DNA adducts in maternal mammary gland and in suckling lung and kidney. Toxicol Appl Pharmacol. 12. 1. 2000;169(2):191-200. [pmid: 11097872].
97 Watabiki T, Okii Y, Tokiyasu T, Yoshimura S, Yoshida M, Akane A, Shikata N, Tsubura A. Long-term ethanol consumption in ICR mice causes mammary tumor in females and liver fibrosis in males. Alcohol Clin Exp Res. 04. 24. 2000;4(Suppl 11):7S-22S. [pmid: 10803793].
98 Schrauzer GN, McGinness JE, Ishmael D, Bell LJ. Alcoholism and cancer. I. Effects of long-term exposure to alcohol on spontaneous mammary adenocarcinoma and prolactin levels in C3H/St mice. J Stud Alcohol. 03. 1979;40(3):240-6. [pmid: 571941].
99 Taylor AN, Ben-Eliyahu S, Yirmiya R, Chang MP, Norman DC, Chiappelli F. Actions of alcohol on immunity and neoplasia in fetal alcohol exposed and adult rats. Alcohol Alcohol Suppl. 1993;2:69-74. [pmid: 7748350].
100 Rogers AE, Conner BH. Dimethylbenzanthracene-induced mammary tumorigenesis in ethanol-fed rats. Nutr Res. 1990;10(8):915-28.
101 McDermott EW, O’Dwyer PJ, O’Higgins NJ. Dietary alcohol intake does not increase the incidence of experimentally induced mammary carcinoma. Eur J Surg Oncol. 06. 1992;18(3):251-4. [pmid: 1607037].
102 Hackney JF, Engelman RW, Good RA. Ethanol calories do not enhance breast cancer in isocalorically fed C3H/Ou mice. Nutr Cancer. 1992;18(3):245-53. [pmid: 1296198].
103 Grubbs C, Juliana M, Whitaker L. Effect of ethanol on initiation of methylnitrosourea (MNU)- and dimethybenzanthracene (DMBA)-induced mammary cancers. Proc Am Assoc Cancer Res. 1988;29:148.
104 Singletary KW, McNary MQ. Effect of moderate ethanol consumption on mammary gland structural development and DNA synthesis in the female rat. Alcohol. 03-04. 1992;9(2):95-101. [pmid: 1599632].
105 Singletary KW, McNary MQ, Odoms AM, Nelshoppen J, Wallig MA. Ethanol consumption and DMBA-induced mammary carcinogenesis in rats. Nutr Cancer. 1991;16(1):13-23. [pmid: 1923906].
106 Etique N, Grillier-Vuissoz I, Lecomte J, Flament S. Crosstalk between adenosine receptor (A2A isoform) and ERalpha mediates ethanol action in MCF-7 breast cancer cells. Oncol Rep (Athens). 04. 2009;21(4):977-81. [pmid: 19287996].
107 Singletary KW, Barnes SL, Van Breemen RB. Ethanol inhibits benzo[a]pyrene-DNA adduct removal and increases 8-oxo-deoxyguanosine formation in human mammary epithelial cells. Cancer Lett. 01. 2004;203(2):139-44. [pmid: 14732221].
108 Barnes SL, Singletary KW, Frey R. Ethanol and acetaldehyde enhance benzo[a]pyrene-DNA adduct formation in human mammary epithelial cells. Carcinogenesis. 2000;21(11):2123-8. [pmid: 11062178].
109 Zhu Y, Lin H, Li Z, Wang M, Luo J. Modulation of expression of ribosomal protein L7a (rpL7a) by ethanol in human breast cancer cells. Breast Cancer Res Treat. 2001;69(1):29-38. [pmid: 11759826].
110 Przylipiak A, Rabe T, Hafner J, Przylipiak M, Runnebaum R. Influence of ethanol on in vitro growth of human mammary carcinoma cell line MCF-7. Arch Gynecol Obstet. 1996;258(3):137-40. [pmid: 8781701].
111 Cyong JC, Okada H, Ishihara K, Hasegawa F. Effect of ethanol on cyclic nucleotide levels and the electron microscopic morphology of murine mammary tumor cells. Kitasato Arch Exp Med. 12. 1978;51(3–4):73-80. [pmid: 232731].
112 Dhar MS, Plummer HK III. Protein expression of G-protein inwardly rectifying potassium channels (GIRK) in breast cancer cells. BMC Physiol. 08. 31. 2006;6:8. [pmid: 16945134].
113 Verma M, Davidson EA. MUC1 upregulation by ethanol. Cancer Biochem Biophys. 07. 1999;17(1–2):1-11. [pmid: 10738897].
114 Zhu Y, Lin H, Wang M, Li Z, Wiggins RC, Luo J. Up-regulation of transcription of smooth muscle myosin alkali light chain by ethanol in human breast cancer cells. Int J Oncol. 06. 2001;18(6):1299-305. [pmid: 11351266].
115 Venkata NG, Aung CS, Cabot PJ, Monteith GR, Roberts-Thomson SJ. PPARalpha and PPARbeta Are differentially affected by ethanol and the ethanol metabolite acetaldehyde in the MCF-7 breast cancer cell line. Toxicol Sci. 03. 2008;102(1):120-8. [pmid: 18003597].
116 Nelson RL, Samelson SL. Neither dietary ethanol nor beer augments experimental colon carcinogenesis in rats. Dis Colon Rectum. 06. 1985;28(6):460-2. [pmid: 4006641].
117 Howarth AE, Pihl E. High-fat diet promotes and causes distal shift of experimental rat colonic cancer--beer and alcohol do not. Nutr Cancer. 1984;6(4):229-35. [pmid: 6545579].
118 Hayashi N, Tsutsumi M, Fukura M, Yano H, Tsuchishima M, Takase S. Effect of chronic dietary ethanol consumption on colonic cancer in rats induced by 1,1-dimethylhydrazine. Alcohol Clin Exp Res. 01. 2007;31(1 Suppl):S72-6. [pmid: 17331170].
119 Hakkak R, Korourian S, Ronis MJ, Ingelman-Sundberg M, Badger TM. Effects of diet and ethanol on the expression and localization of cytochromes P450 2E1 and P450 2C7 in the colon of male rats. Biochem Pharmacol. 01. 12. 1996;51(1):61-9. [pmid: 8534269].
120 Pronko P, Bardina L, Satanovskaya V, Kuzmich A, Zimatkin S. Effect of chronic alcohol consumption on the ethanol- and acetaldehyde-metabolizing systems in the rat gastrointestinal tract. Alcohol Alcohol. 2002;37(3):229-35. [pmid: 12003909].
121 Roy HK, Gulizia JM, Karolski WJ, Ratashak A, Sorrell MF, Tuma D. Ethanol promotes intestinal tumorigenesis in the MIN mouse. Multiple intestinal neoplasia. Cancer Epidemiol Biomarkers Prev. 11. 2002;11(11):1499-502. [pmid: 12433735].
122 Seitz HK, Simanowski UA, Garzon FT, Rideout JM, Peters TJ, Koch A, Berger MR, Einecke H, Maiwald M. Possible role of acetaldehyde in ethanol-related rectal cocarcinogenesis in the rat. Gastroenterology. 02. 1990;98(2):406-13. [pmid: 2295396].
123 Seitz HK, Czygan P, Simanowski U, Waldherr R, Veith S, Raedsch R, Kommerell B. Stimulation of chemically induced rectal carcinogenesis by chronic ethanol ingestion. Alcohol Alcohol. 1985;20(4):427-33. [pmid: 3910061].
124 Choi SW, Stickel F, Baik HW, Kim YI, Seitz HK, Mason JB. Chronic alcohol consumption induces genomic but not p53-specific DNA hypomethylation in rat colon. J Nutr. 11. 1999;129(11):1945-50. [pmid: 10539767].
125 Simanowski UA, Suter P, Russell RM, Heller M, Waldherr R, Ward R, Peters TJ, Smith D, Seitz HK. Enhancement of ethanol induced rectal mucosal hyper regeneration with age in F344 rats. Gut. 08. 1994;35(8):1102-6. [pmid: 7926914].
126 Niwa K, Tanaka T, Sugie S, Shinoda T, Kato K, Tamaya T, Mori H. Enhancing effect of ethanol or sake on methylazoxymethanol acetate-initiated large bowel carcinogenesis in ACI/N rats. Nutr Cancer. 1991;15(3–4):229-37. [pmid: 1866316].
127 Simanowski UA, Seitz HK, Baier B, Kommerell B, Schmidt-Gayk H, Wright NA. Chronic ethanol consumption selectively stimulates rectal cell proliferation in the rat. Gut. 03. 1986;27(3):278-82. [pmid: 3699547].
128 Garzon FT, Simanowski UA, Berger MR, Schmahl D, Kommerell B, Seitz HK. Acetoxymethyl-methylnitrosamine (AMMN) induced colorectal carcinogenesis is stimulated by chronic alcohol consumption. Alcohol Alcohol Suppl. 1987;1:501-2. [pmid: 3426722].
129 McGarrity TJ, Peiffer LP, Colony PC, Pegg AE. The effects of chronic ethanol administration on polyamine content during dimethylhydrazine-induced colorectal carcinogenesis in the rat. Carcinogenesis. 11. 1988;9(11):2093-8. [pmid: 3180344].
130 Hamilton SR, Sohn OS, Fiala ES. Inhibition by dietary ethanol of experimental colonic carcinogenesis induced by high-dose azoxymethane in F344 rats. Cancer Res. 06. 15. 1988;48(12):3313-8. [pmid: 3370634].
131 Hamilton SR, Sohn OS, Fiala ES. Effects of timing and quantity of chronic dietary ethanol consumption on azoxymethane-induced colonic carcinogenesis and azoxymethane metabolism in Fischer 344 rats. Cancer Res. 08. 15. 1987;47(16):4305-11. [pmid: 3111683].
132 Hamilton SR, Hyland J, McAvinchey D, Chaudhry Y, Hartka L, Kim HT, Cichon P, Floyd J, Turjman N, Kessie G, et al. Effects of chronic dietary beer and ethanol consumption on experimental colonic carcinogenesis by azoxymethane in rats. Cancer Res. 03. 15. 1987;47(6):1551-9. [pmid: 3815356].
133 Vaculova A, Hofmanova J, Soucek K, Andera L, Kozubik A. Ethanol acts as a potent agent sensitizing colon cancer cells to the TRAIL-induced apoptosis. FEBS Lett. 11. 5. 2004;577(1–2):309-13. [pmid: 15527805].
134 Asai K, Buurman WA, Reutelingsperger CP, Schutte B, Kaminishi M. Low concentrations of ethanol induce apoptosis in human intestinal cells. Scand J Gastroenterol. 11. 2003;38(11):1154-61. [pmid: 14686719].
135 Blasiak J, Trzeciak A, Malecka-Panas E, Drzewoski J, Wojewodzka M. In vitro genotoxicity of ethanol and acetaldehyde in human lymphocytes and the gastrointestinal tract mucosa cells. Toxicol In Vitro. 08. 2000;14(4):287-95. [pmid: 10906435].
136 Koivisto T, Salaspuro M. Acetaldehyde alters proliferation, differentiation and adhesion properties of human colon adenocarcinoma cell line Caco-2. Carcinogenesis. 11. 1998;19(11):2031-6. [pmid: 9855020].
137 Koivisto T, Salaspuro M. Effects of acetaldehyde on brush border enzyme activities in human colon adenocarcinoma cell line Caco-2. Alcohol Clin Exp Res. 12. 1997;21(9):1599-605. [pmid: 9438518].
138 Malagolini N, Dall’Olio F, Turrini I, Cessi C, Serafini-Cessi F. Effect of ethanol on human colon carcinoma CaCo-2 and HT-29 cell lines during the maturation process. Alcohol Clin Exp Res. 12. 1994;18(6):1386-91. [pmid: 7695034].
139 Papavassiliou ED, Arvind P, Tsioulias GJ, Qiao L, Goldin E, Staiano-Coico L, Rigas B. The effect of ethanol on the expression of HLA class I genes in human colon adenocarcinoma cell lines. Cancer Lett. 06. 15. 1994;81(1):33-8. [pmid: 8019985].
140 Lemos C, Peters GJ, Jansen G, Martel F, Calhau C. Modulation of folate uptake in cultured human colon adenocarcinoma Caco-2 cells by dietary compounds. Eur J Nutr. 09. 2007;46(6):329-36. [pmid: 17712586].
141 Pannequin J, Delaunay N, Darido C, Maurice T, Crespy P, Frohman MA, Balda MS, Matter K, Joubert D, Bourgaux JF, Bali JP, Hollande F. Phosphatidylethanol accumulation promotes intestinal hyperplasia by inducing ZONAB-mediated cell density increase in response to chronic ethanol exposure. Mol Cancer Res. 11. 2007;5(11):1147-57. [pmid: 18025260].
142 Suzuki R, Orsini N, Mignone L, Saji S, Wolk A. Alcohol intake and risk of breast cancer defined by estrogen and progesterone receptor status--a meta-analysis of epidemiological studies. [erratum appears in Int J Cancer 2008 Aug 15;123(4):981]. Int J Cancer. 04. 15. 2008;122(8):1832-41. [pmid: 18067133].
143 Lissowska J, Gaudet MM, Brinton LA, Chanock SJ, Peplonska B, Welch R, Zatonski W, Szeszenia-Dabrowska N, Park S, Sherman M, Garcia-Closas M. Genetic polymorphisms in the one-carbon metabolism pathway and breast cancer risk: A population-based case-control study and meta-analyses. Int J Cancer. 06. 15. 2007;120(12):2696-703. [pmid: 17311260].
144 Lewis SJ, Harbord RM, Harris R, Smith GD. Meta-analyses of observational and genetic association studies of folate intakes or levels and breast cancer risk. J Natl Cancer Inst. 11. 15. 2006;98(22):1607-22. [pmid: 17105984].
145 Corrao G, Bagnardi V, Zambon A, Arico S. Exploring the dose-response relationship between alcohol consumption and the risk of several alcohol-related conditions: a meta-analysis. Addiction. 10. 1999;94(10):1551-73. [pmid: 10790907].
146 Longnecker MP. Alcoholic beverage consumption in relation to risk of breast cancer: meta-analysis and review. Cancer Causes Control. 01. 1994;5(1):73-82. [pmid: 8123780].
147 Mizoue T, Inoue M, Wakai K, Nagata C, Shimazu T, Tsuji I, Otani T, Tanaka K, Matsuo K, Tamakoshi A, Sasazuki S, Tsugane S. Research Group for Development and Evaluation of Cancer Prevention Strategies. Alcohol drinking and colorectal cancer in Japanese: a pooled analysis of results from five cohort studies. Am J Epidemiol. 06. 15. 2008;167(12):1397-406. [pmid: 18420544].
148 Moskal A, Norat T, Ferrari P, Riboli E. Alcohol intake and colorectal cancer risk: a dose-response meta-analysis of published cohort studies. Int J Cancer. 02. 1. 2007;120(3):664-71. [pmid: 17096321].
149 Mizoue T, Tanaka K, Tsuji I, Wakai K, Nagata C, Otani T, Inoue M, Tsugane S. Research Group for the Development and Evaluation of Cancer Prevention Strategies. Alcohol drinking and colorectal cancer risk: an evaluation based on a systematic review of epidemiologic evidence among the Japanese population. Jpn J Clin Oncol. 09. 2006;36(9):582-97. [pmid: 16870695].
150 Franceschi S, La Vecchia C. Alcohol and the risk of cancers of the stomach and colon-rectum. Dig Dis. 09-10. 1994;12(5):276-89. [pmid: 7882548].
151 Zhang SM, Lee IM, Manson JE, Cook NR, Willett WC, Buring JE. Alcohol consumption and breast cancer risk in the Women’s Health Study. Am J Epidemiol. 03. 15. 2007;165(6):667-76. [pmid: 17204515].
152 Li Y, Baer D, Friedman GD, Udaltsova N, Shim V, Klatsky AL. Wine, liquor, beer and risk of breast cancer in a large population. Eur J Cancer. 03. 2009;45(5):843-50. [pmid: 19095438].
153 Li CI, Malone KE, Porter PL, Weiss NS, Tang MT, Daling JR. The Relationship between Alcohol Use and Risk of Breast Cancer by Histology and Hormone Receptor Status among Women 65–79 Years of Age. Cancer Epidemiol Biomarkers Prev. 10. 2003;12(10):1061-6. [pmid: 14578143].
154 Lew JQ, Freedman ND, Leitzmann MF, Brinton LA, Hoover RN, Hollenbeck AR, Schatzkin A, Park Y. Alcohol and risk of breast cancer by histologic type and hormone receptor status in postmenopausal women: the NIH-AARP Diet and Health Study. Am J Epidemiol. 08. 1. 2009;170(3):308-17. [pmid: 19541857].
155 Wayne S, Neuhouser ML, Ulrich CM, Koprowski C, Wiggins C, Baumgartner KB, Bernstein L, Baumgartner RN, Gilliland F, McTiernan A, Ballard-Barbash R. Association between alcohol intake and serum sex hormones and peptides differs by tamoxifen use in breast cancer survivors. Cancer Epidemiol Biomarkers Prev. 11. 2008;17(11):3224-32. [pmid: 18957523].
156 Deandrea S, Talamini R, Foschi R, Montella M, Dal Maso L, Falcini F, La Vecchia C, Franceschi S, Negri E. Alcohol and breast cancer risk defined by estrogen and progesterone receptor status: a case-control study. Cancer Epidemiol Biomarkers Prev. 08. 2008;17(8):2025-8. [pmid: 18708394].
157 Garcia-Closas M, Herbstman J, Schiffman M, Glass A, Dorgan JF. Relationship between serum hormone concentrations, reproductive history, alcohol consumption and genetic polymorphisms in pre-menopausal women. Int J Cancer. 11. 10. 2002;102(2):172-8. [pmid: 12385014].
158 Li CI, Chlebowski RT, Freiberg M, Johnson KC, Kuller L, Lane D, Lessin L, O’Sullivan MJ, Wactawski-Wende J, Yasmeen S, Prentice R. Alcohol consumption and risk of postmenopausal breast cancer by subtype: the Women’s Health Initiative Observational Study. J Natl Cancer Inst. 2010. 08. 23. Epub ahead of print. [pmid: 20733117].
159 Rundle A, Tang D, Mooney L, Grumet S, Perera F. The interaction between alcohol consumption and GSTM1 genotype on polycyclic aromatic hydrocarbon-DNA adduct levels in breast tissue. Cancer Epidemiol Biomarkers Prev. 09. 1. 2003;12(9):911-4. [pmid: 14504203].
160 Lavigne JA, Baer DJ, Wimbrow HH, Albert PS, Brown ED, Judd JT, Campbell WS, Giffen CA, Dorgan JF, Hartman TJ, Barrett JC, Hursting SD, Taylor PR. Effects of alcohol on insulin-like growth factor I and insulin-like growth factor binding protein 3 in postmenopausal women. Am J Clin Nutr. 02. 2005;81(2):503-7. [pmid: 15699241].
161 Choi JY, Abel J, Neuhaus T, Ko Y, Harth V, Hamajima N, Tajima K, Yoo KY, Park SK, Noh DY, Han W, Choe KJ, Ahn SH, Kim SU, Hirvonen A, Kang D. Role of alcohol and genetic polymorphisms of CYP2E1 and ALDH2 in breast cancer development. Pharmacogenetics. 02. 2003;13(2):67-72. [pmid: 12563175].
162 Lee KM, Abel J, Ko Y, Harth V, Park WY, Seo JS, Yoo KY, Choi JY, Shin A, Ahn SH, Noh DY, Hirvonen A, Kang D. Genetic polymorphisms of cytochrome P450 19 and 1B1, alcohol use, and breast cancer risk in Korean women. Br J Cancer. 03. 10. 2003;88(5):675-8. [pmid: 12618873].
163 Kabat GC, Miller AB, Jain M, Rohan TE. Dietary intake of selected B vitamins in relation to risk of major cancers in women. Br J Cancer. 09. 2. 2008;99(5):816-21. [pmid: 18665162].
164 Hussien MM, McNulty H, Armstrong N, Johnston PG, Spence RA, Barnett Y. Investigation of systemic folate status, impact of alcohol intake and levels of DNA damage in mononuclear cells of breast cancer patients. Br J Cancer. 04. 25. 2005;92(8):1524-30. [pmid: 15812544].
165 Zhu K, Davidson NE, Hunter S, Yang X, Payne-Wilks K, Roland CL, Phillips D, Bentley C, Dai M, Williams SM. Methyl-group dietary intake and risk of breast cancer among African-American women: a case-control study by methylation status of the estrogen receptor alpha genes. Cancer Causes Control. 11. 2003;14(9):827-36. [pmid: 14682440].
166 Eichholzer M, Luthy J, Moser U, Fowler B. Folate and the risk of colorectal, breast and cervix cancer: the epidemiological evidence. Swiss Med Wkly. 09. 22. 2001;131(37–38):539-49. [pmid: 11759174].
167 Tjonneland A, Christensen J, Olsen A, Stripp C, Nissen SB, Overvad K, Thomsen BL. Folate intake, alcohol and risk of breast cancer among postmenopausal women in Denmark. Eur J Clin Nutr. 02. 2006;60(2):280-6. [pmid: 16234832].
168 Zhang SM, Willett WC, Selhub J, Hunter DJ, Giovannucci EL, Holmes MD, Colditz GA, Hankinson SE. Plasma folate, vitamin B6, vitamin B12, homocysteine, and risk of breast cancer. J Natl Cancer Inst. 03. 5. 2003;95(5):373-80. [pmid: 12618502].
169 Semenza JC, Delfino RJ, Ziogas A, Anton-Culver H. Breast cancer risk and methylenetetrahydrofolate reductase polymorphism. Breast Cancer Res Treat. 02. 2003;77(3):217-23. [pmid: 12602921].
170 Maruti SS, Ulrich CM, White E. Folate and one-carbon metabolism nutrients from supplements and diet in relation to breast cancer risk. Am J Clin Nutr. 02. 2009;89(2):624-33. [pmid: 19116331].
171 Le Marchand L, Haiman CA, Wilkens LR, Kolonel LN, Henderson BE. MTHFR polymorphisms, diet, HRT, and breast cancer risk: the multiethnic cohort study. Cancer Epidemiol Biomarkers Prev. 12. 2004;13(12):2071-7. [pmid: 15598763].
172 Freudenheim JL, Bonner M, Krishnan S, Ambrosone CB, Graham S, McCann SE, Moysich KB, Bowman E, Nemoto T, Shields PG. Diet and alcohol consumption in relation to p53 mutations in breast tumors. Carcinogenesis. 06. 2004;25(6):931-9. [pmid: 14742318].
173 Beilby J, Ingram D, Hahnel R, Rossi E. Reduced breast cancer risk with increasing serum folate in a case-control study of the C677T genotype of the methylenetetrahydrofolate reductase gene. Eur J Cancer. 05. 2004;40(8):1250-4. [pmid: 15110890].
174 Jelski W, Chrostek L, Szmitkowski M, Markiewicz W. The activity of class I, II, III and IV alcohol dehydrogenase isoenzymes and aldehyde dehydrogenase in breast cancer. Clin Exp Med. 06. 2006;6(2):89-93. [pmid: 16820997].
175 Jelski W, Chrostek L, Markiewicz W, Szmitkowski M. Activity of alcohol dehydrogenase (ADH) isoenzymes and aldehyde dehydrogenase (ALDH) in the sera of patients with breast cancer. J Clin Lab Anal. 2006;20(3):105-8. [pmid: 16721836].
176 Triano EA, Slusher LB, Atkins TA, Beneski JT, Gestl SA, Zolfaghari R, Polavarapu R, Frauenhoffer E, Weisz J. Class I alcohol dehydrogenase is highly expressed in normal human mammary epithelium but not in invasive breast cancer: implications for breast carcinogenesis. Cancer Res. 06. 15. 2003;63(12):3092-100. [pmid: 12810634].
177 Visvanathan K, Crum RM, Strickland PT, You X, Ruczinski I, Berndt SI, Alberg AJ, Hoffman SC, Comstock GW, Bell DA, Helzlsouer KJ. Alcohol dehydrogenase genetic polymorphisms, low-to-moderate alcohol consumption, and risk of breast cancer. Alcohol Clin Exp Res. 03. 2007;31(3):467-76. [pmid: 17295732].
178 Sturmer T, Wang-Gohrke S, Arndt V, Boeing H, Kong X, Kreienberg R, Brenner H. Interaction between alcohol dehydrogenase II gene, alcohol consumption, and risk for breast cancer. Br J Cancer. 08. 27. 2002;87(5):519-23. [pmid: 12189549].
179 Pezzotti A, Kraft P, Hankinson SE, Hunter DJ, Buring J, Cox DG. The mitochondrial A10398G polymorphism, interaction with alcohol consumption, and breast cancer risk. PLoS ONE. 04. 24. 2009;4(4):e5356. [pmid: 19390621].
180 Jin MJ, Chen K, Zhang SS, Zhang YJ, Ren YJ, Xu H, Yao KY, Li QL, Ma XY. [Association of single nucleotide polymorphisms and haplotypes in DNA repair gene XRCC1 with susceptibility of breast cancer]. Zhejiang Da Xue Xue Bao Yi Xue Ban. 07. 2006;35(4):370-6. (Chi). [pmid: 16924699].
181 Zheng T, Holford TR, Zahm SH, Owens PH, Boyle P, Zhang Y, Zhang B, Wise JP Sr, Stephenson LP, Ali-Osman F. Glutathione S-transferase M1 and T1 genetic polymorphisms, alcohol consumption and breast cancer risk. Br J Cancer. 01. 13. 2003;88(1):58-62. [pmid: 12556960].
182 Park SK, Yoo KY, Lee SJ, Kim SU, Ahn SH, Noh DY, Choe KJ, Strickland PT, Hirvonen A, Kang D. Alcohol consumption, glutathione S-transferase M1 and T1 genetic polymorphisms and breast cancer risk. Pharmacogenetics. 06. 2000;10(4):301-9. [pmid: 10862521].
183 Vogel U, Christensen J, Nexo BA, Wallin H, Friis S, Tjonneland A. Peroxisome proliferator-activated receptor-gamma2 Pro12Ala, interaction with alcohol intake and NSAID use, in relation to risk of breast cancer in a prospective study of Danes [erratum appears in Carcinogenesis. 2007 Sep;28(9):2062]. Carcinogenesis. 02. 2007;28(2):427-34. [pmid: 16959787].
184 Vogel U, Christensen J, Nexo BA, Wallin H, Friis S, Tjonneland A. Erratum: Peroxisome Profilerator-Activated Receptor-gamma2 Pro12Ala, interaction with alcohol intake and NSAID use, in relation to risk of breast cancer in a prospective study of Danes (Carcinogenesis (2007) vol. 2 (427–434)). Carcinogenesis. 09. 2007;28(9):2062.
185 Stern MC, Conti DV, Siegmund KD, Corral R, Yuan JM, Koh WP, Yu MC. DNA repair single-nucleotide polymorphisms in colorectal cancer and their role as modifiers of the effect of cigarette smoking and alcohol in the Singapore Chinese Health Study. Cancer Epidemiol Biomarkers Prev. 11. 2007;16(11):2363-72. [pmid: 18006925].
186 Tranah GJ, Bugni J, Giovannucci E, Ma J, Fuchs C, Hines L, Samson L, Hunter DJ. O6-methylguanine-DNA methyltransferase Leu84Phe and Ile143Val polymorphisms and risk of colorectal cancer in the Nurses’ Health Study and Physicians’ Health Study (United States). Cancer Causes Control. 06. 2006;17(5):721-31. [pmid: 16633920].
187 Jin MJ, Chen K, Song L, Fan CH, Chen Q, Zhu YM, Ma XY, Yao KY. The association of the DNA repair gene XRCC3 Thr241Met polymorphism with susceptibility to colorectal cancer in a Chinese population. Cancer Genet Cytogenet. 11. 2005;163(1):38-43. [pmid: 16271954].
188 Ma J, Stampfer MJ, Giovannucci E, Artigas C, Hunter DJ, Fuchs C, Willett WC, Selhub J, Hennekens CH, Rozen R. Methylenetetrahydrofolate reductase polymorphism, dietary interactions, and risk of colorectal cancer. Cancer Res. 03. 15. 1997;57(6):1098-102. [pmid: 9067278].
189 Chen J, Giovannucci EL, Hunter DJ. MTHFR polymorphism, methyl-replete diets and the risk of colorectal carcinoma and adenoma among U.S. men and women: an example of gene-environment interactions in colorectal tumorigenesis. J Nutr. 02. 1999;129(2S Suppl):560S-4S. [pmid: 10064332].
190 Yamaji T, Iwasaki M, Sasazuki S, Sakamoto H, Yoshida T, Tsugane S. Methionine synthase A2756G polymorphism interacts with alcohol and folate intake to influence the risk of colorectal adenoma. Cancer Epidemiol Biomarkers Prev. 01. 2009;18(1):267-74. [pmid: 19124508].
191 Goode EL, Potter JD, Bigler J, Ulrich CM. Methionine synthase D919G polymorphism, folate metabolism, and colorectal adenoma risk. Cancer Epidemiol Biomarkers Prev. 01. 2004;13(1):157-62. [pmid: 14744749].
192 Weinstein SJ, Albanes D, Selhub J, Graubard B, Lim U, Taylor PR, Virtamo J, Stolzenberg-Solomon R. One-carbon metabolism biomarkers and risk of colon and rectal cancers. Cancer Epidemiol Biomarkers Prev. 11. 2008;17(11):3233-40. [pmid: 18990766].
193 de Vogel S, Bongaerts BW, Wouters KA, Kester AD, Schouten LJ, de Goeij AF, de Bruine AP, Goldbohm RA, van den Brandt PA, van Engeland M, Weijenberg MP. Associations of dietary methyl donor intake with MLH1 promoter hypermethylation and related molecular phenotypes in sporadic colorectal cancer. Carcinogenesis. 09. 2008;29(9):1765-73. [pmid: 18339680].
194 Sharp L, Little J, Brockton NT, Cotton SC, Masson LF, Haites NE, Cassidy J. Polymorphisms in the methylenetetrahydrofolate reductase (MTHFR) gene, intakes of folate and related B vitamins and colorectal cancer: a case-control study in a population with relatively low folate intake. Br J Nutr. 02. 2008;99(2):379-89. [pmid: 18053312].
195 Otani T, Iwasaki M, Hanaoka T, Kobayashi M, Ishihara J, Natsukawa S, Shaura K, Koizumi Y, Kasuga Y, Yoshimura K, Yoshida T, Tsugane S. Folate, vitamin B6, vitamin B12, and vitamin B2 intake, genetic polymorphisms of related enzymes, and risk of colorectal cancer in a hospital-based case-control study in Japan. Nutr Cancer. 2005;53(1):42-50. [pmid: 16351505].
196 Pufulete M, Al-Ghnaniem R, Rennie JA, Appleby P, Harris N, Gout S, Emery PW, Sanders TA. Influence of folate status on genomic DNA methylation in colonic mucosa of subjects without colorectal adenoma or cancer. Br J Cancer. 03. 14. 2005;92(5):838-42. [pmid: 15726099].
197 Matsuo K, Ito H, Wakai K, Hirose K, Saito T, Suzuki T, Kato T, Hirai T, Kanemitsu Y, Hamajima H, Tajima K. One-carbon metabolism related gene polymorphisms interact with alcohol drinking to influence the risk of colorectal cancer in Japan. Carcinogenesis. 12. 2005;26(12):2164-71. [pmid: 16051637].
198 Hirose M, Kono S, Tabata S, Ogawa S, Yamaguchi K, Mineshita M, Hagiwara T, Yin G, Lee KY, Tsuji A, Ikeda N. Genetic polymorphisms of methylenetetrahydrofolate reductase and aldehyde dehydrogenase 2, alcohol use and risk of colorectal adenomas: Self-Defense Forces Health Study. Cancer Sci. 08. 2005;96(8):513-8. [pmid: 16108833].
199 Larsson SC, Giovannucci E, Wolk A. Vitamin B6 intake, alcohol consumption, and colorectal cancer: a longitudinal population-based cohort of women. Gastroenterology. 06. 2005;128(7):1830-7. [pmid: 15940618].
200 van Engeland M, Weijenberg MP, Roemen GM, Brink M, de Bruine AP, Goldbohm RA, van den Brandt PA, Baylin SB, de Goeij AF, Herman JG. Effects of dietary folate and alcohol intake on promoter methylation in sporadic colorectal cancer: the Netherlands cohort study on diet and cancer. Cancer Res. 06. 15. 2003;63(12):3133-7. [pmid: 12810640].
201 Chen J, Giovannucci E, Hankinson SE, Ma J, Willett WC, Spiegelman D, Kelsey KT, Hunter DJ. A prospective study of methylenetetrahydrofolate reductase and methionine synthase gene polymorphisms, and risk of colorectal adenoma. Carcinogenesis. 12. 1998;19(12):2129-32. [pmid: 9886567].
202 Curtin K, Slattery ML, Ulrich CM, Bigler J, Levin TR, Wolff RK, Albertsen H, Potter JD, Samowitz WS. Genetic polymorphisms in one-carbon metabolism: Associations with CpG island methylator phenotype (CIMP) in colon cancer and the modifying effects of diet. Carcinogenesis. 08. 2007;28(8):1672-9. [pmid: 17449906].
203 Heijmans BT, Boer JM, Suchiman HE, Cornelisse CJ, Westendorp RG, Kromhout D, Feskens EJ, Slagboom PE. A common variant of the methylenetetrahydrofolate reductase gene (1p36) is associated with an increased risk of cancer. Cancer Res. 03. 15. 2003;63(6):1249-53. [pmid: 12649184].
204 Harnack L, Jacobs DR Jr, Nicodemus K, Lazovich D, Anderson K, Folsom AR. Relationship of folate, vitamin B-6, vitamin B-12, and methionine intake to incidence of colorectal cancers. Nutr Cancer. 2002;43(2):152-8. [pmid: 12588695].
205 Kim YI, Fawaz K, Knox T, Lee YM, Norton R, Arora S, Paiva L, Mason JB. Colonic mucosal concentrations of folate correlate well with blood measurements of folate status in persons with colorectal polyps. Am J Clin Nutr. 10. 1998;68(4):866-72. [pmid: 9771864].
206 Chen J, Giovannucci E, Kelsey K, Rimm EB, Stampfer MJ, Colditz GA, Spiegelman D, Willett WC, Hunter DJ. A methylenetetrahydrofolate reductase polymorphism and the risk of colorectal cancer. Cancer Res. 11. 1. 1996;56(21):4862-4. [pmid: 8895734].
207 Boutron-Ruault MC, Senesse P, Faivre J, Couillault C, Belghiti C. Folate and alcohol intakes: Related or independent roles in the adenoma- carcinoma sequence. Nutr Cancer. 1996;26(3):337-46. [pmid: 8910915].
208 Jiang QT, Chen K, Ma XY, Miao XP, Yao KY, Yu WP, Li LY, Zhu YM, Zhou HG. [A case-control study on the polymorphisms of methylenetetrahydrofolate reductases, drinking interaction and susceptibility in colorectal cancer]. Chung Hua Liu Hsing Ping Hsueh Tsa Chih. 07. 2004;25(7):612-6. (Chi). [pmid: 15308044].
209 Eklof V, Van Guelpen B, Hultdin J, Johansson I, Hallmans G, Palmqvist R. The reduced folate carrier (RFC1) 80G > A and folate hydrolase 1 (FOLH1) 1561C > T polymorphisms and the risk of colorectal cancer: a nested case-referent study. Scand J Clin Lab Invest. 2008;68(5):393-401. [pmid: 19172696].
210 Cao HX, Gao CM, Takezaki T, Wu JZ, Ding JH, Liu YT, Li SP, Su P, Cao J, Hamajima N, Tajima K. Genetic polymorphisms of methylenetetrahydrofolate reductase and susceptibility to colorectal cancer. Asian Pac J Cancer Prev. 04-06. 2008;9(2):203-8. [pmid: 18712959].
211 Schernhammer ES, Giovannuccci E, Fuchs CS, Ogino S. A prospective study of dietary folate and vitamin B and colon cancer according to microsatellite instability and KRAS mutational status. Cancer Epidemiol Biomarkers Prev. 10. 2008;17(10):2895-8. [pmid: 18843035].
212 Lightfoot TJ, Barrett JH, Bishop T, Northwood EL, Smith G, Wilkie MJ, Steele RJ, Carey FA, Key TJ, Wolf R, Forman D. Methylene tetrahydrofolate reductase genotype modifies the chemopreventive effect of folate in colorectal adenoma, but not colorectal cancer. Cancer Epidemiol Biomarkers Prev. 09. 2008;17(9):2421-30. [pmid: 18703816].
213 Dahlin AM, Van Guelpen B, Hultdin J, Johansson I, Hallmans G, Palmqvist R. Plasma vitamin B12 concentrations and the risk of colorectal cancer: a nested case-referent study. Int J Cancer. 05. 1. 2008;122(9):2057-61. [pmid: 18092327].
214 Hazra A, Wu K, Kraft P, Fuchs CS, Giovannucci EL, Hunter DJ. Twenty-four non-synonymous polymorphisms in the one-carbon metabolic pathway and risk of colorectal adenoma in the Nurses’ Health Study. Carcinogenesis. 07. 2007;28(7):1510-9. [pmid: 17389618].
215 Ashktorab H, Begum R, Akhgar A, Smoot DT, Elbedawi M, Daremipouran M, Zhao A, Momen B, Giardiello FM. Folate status and risk of colorectal polyps in African Americans. Dig Dis Sci. 06. 2007;52(6):1462-70. [pmid: 17372834].
216 Slattery ML, Curtin K, Sweeney C, Levin TR, Potter J, Wolff RK, Albertsen H, Samowitz WS. Diet and lifestyle factor associations with CpG island methylator phenotype and BRAF mutations in colon cancer. Int J Cancer. 02. 1. 2007;120(3):656-63. [pmid: 17096326].
217 Wang J, Gajalakshmi V, Jiang J, Kuriki K, Suzuki S, Nagaya T, Nakamura S, Akasaka S, Ishikawa H, Tokudome S. Associations between 5,10-methylenetetrahydrofolate reductase codon 677 and 1298 genetic polymorphisms and environmental factors with reference to susceptibility to colorectal cancer: a case-control study in an Indian population. Int J Cancer. 02. 15. 2006;118(4):991-7. [pmid: 16152599].
218 Le Marchand L, Wilkens LR, Kolonel LN, Henderson BE. The MTHFR C677T polymorphism and colorectal cancer: the multiethnic cohort study. Cancer Epidemiol Biomarkers Prev. 05. 2005;14(5):1198-203. [pmid: 15894672].
219 Jiang Q, Chen K, Ma X, Li Q, Yu W, Shu G, Yao K. Diets, polymorphisms of methylenetetrahydrofolate reductase, and the susceptibility of colon cancer and rectal cancer. Cancer Detect Prev. 2005;29(2):146-54. [pmid: 15829374].
220 Yin G, Kono S, Toyomura K, Hagiwara T, Nagano J, Mizoue T, Mibu R, Tanaka M, Kakeji Y, Maehara Y, Okamura T, Ikejiri K, Futami K, Yasunami Y, Maekawa T, Takenaka K, Ichimiya H, Imaizumi N. Methylenetetrahydrofolate reductase C677T and A1298C polymorphisms and colorectal cancer: the Fukuoka Colorectal Cancer Study. Cancer Sci. 11. 2004;95(11):908-13. [pmid: 15546509].
221 Kim DH, Ahn YO, Lee BH, Tsuji E, Kiyohara C, Kono S. Methylenetetrahydrofolate reductase polymorphism, alcohol intake, and risks of colon and rectal cancers in Korea. Cancer Lett. 12. 28. 2004;216(2):199-205. [pmid: 15533596].
222 Boyapati SM, Bostick RM, McGlynn KA, Fina MF, Roufail WM, Geisinger KR, Hebert JR, Coker A, Wargovich M. Folate intake, MTHFR C677T polymorphism, alcohol consumption, and risk for sporadic colorectal adenoma (United States). Cancer Causes Control. 06. 2004;15(5):493-501. [pmid: 15286469].
223 Sharp L, Little J. Polymorphisms in genes involved in folate metabolism and colorectal neoplasia: a HuGE review. Am J Epidemiol. 03. 1. 2004;159(5):423-43. [pmid: 14977639].
224 Giovannucci E, Chen J, Smith-Warner SA, Rimm EB, Fuchs CS, Palomeque C, Willett WC, Hunter DJ. Methylenetetrahydrofolate reductase, alcohol dehydrogenase, diet, and risk of colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 10. 2003;12(10):970-9. [pmid: 14578131].
225 Marugame T, Tsuji E, Kiyohara C, Eguchi H, Oda T, Shinchi K, Kono S. Relation of plasma folate and methylenetetrahydrofolate reductase C677T polymorphism to colorectal adenomas. Int J Epidemiol. 02. 2003;32(1):64-6. [pmid: 12690011].
226 Keku T, Millikan R, Worley K, Winkel S, Eaton A, Biscocho L, Martin C, Sandler R. 5,10-Methylenetetrahydrofolate reductase codon 677 and 1298 polymorphisms and colon cancer in African Americans and whites. Cancer Epidemiol Biomarkers Prev. 12. 2002;11(12):1611-21. [pmid: 12496052].
227 Le Marchand L, White KK, Nomura AM, Wilkens LR, Selhub JS, Tiirikainen M, Goodman MT, Murphy SP, Henderson BE, Kolonel LN. Plasma levels of B vitamins and colorectal cancer risk: The multiethnic cohort study. Cancer Epidemiol Biomarkers Prev. 08. 2009;18(8):2195-201. [pmid: 19661077].
228 Steck SE, Keku T, Butler LM, Galanko J, Massa B, Millikan RC, Sandler RS. Polymorphisms in methionine synthase, methionine synthase reductase and serine hydroxymethyltransferase, folate and alcohol intake, and colon cancer risk. J Nutrigenet Nutrigenomics. 06. 2008;1(4):196-204. [pmid: 19776626].
229 Giovannucci E, Rimm EB, Ascherio A, Stampfer MJ, Colditz GA, Willett WC. Alcohol, low-methionine-low-folate diets, and risk of colon cancer in men. J Natl Cancer Inst. 1995;87(4):265-73. [pmid: 7707417].
230 Levine AJ, Siegmund KD, Ervin CM, Diep A, Lee ER, Frankl HD, Haile RW. The methylenetetrahydrofolate reductase 677C-->T polymorphism and distal colorectal adenoma risk. Cancer Epidemiol Biomarkers Prev. 07. 2000;9(7):657-63. [pmid: 10919734].
231 Ma J, Stampfer MJ, Christensen B, Giovannucci E, Hunter DJ, Chen J, Willett WC, Selhub J, Hennekens CH, Gravel R, Rozen R. A polymorphism of the methionine synthase gene: association with plasma folate, vitamin B12, homocyst(e)ine, and colorectal cancer risk. Cancer Epidemiol Biomarkers Prev. 09. 1999;8(9):825-9. [pmid: 10498402].
232 Slattery ML, Potter JD, Samowitz W, Schaffer D, Leppert M. Methylenetetrahydrofolate reductase, diet, and risk of colon cancer. Cancer Epidemiol Biomarkers Prev. 06. 1999;8(6):513-8. [pmid: 10385141].
233 Ulrich CM, Kampman E, Bigler J, Schwartz SM, Chen C, Bostick R, Fosdick L, Beresford SA, Yasui Y, Potter JD. Colorectal adenomas and the C677T MTHFR polymorphism: evidence for gene-environment interaction. Cancer Epidemiol Biomarkers Prev. 08. 1999;8(8):659-68. [pmid: 10744125].
234 Kono S, Toyomura K, Yin G, Nagano J, Mizoue T. A case-control study of colorectal cancer in relation to lifestyle factors and genetic polymorphisms: design and conduct of the Fukuoka colorectal cancer study. Asian Pac J Cancer Prev. 10-12. 2004;5(4):393-400. [pmid: 15546244].
235 Simanowski UA, Homann N, Knuhl M, Arce L, Waldherr R, Conradt C, Bosch FX, Seitz HK. Increased rectal cell proliferation following alcohol abuse. Gut. 09. 2001;49(3):418-22. [pmid: 11511565].
236 Morita M, Tabata S, Tajima O, Yin G, Abe H, Kono S. Genetic polymorphisms of CYP2E1 and risk of colorectal adenomas in the Self Defense Forces Health Study. Cancer Epidemiol Biomarkers Prev. 07. 2008;17(7):1800-7. [pmid: 18628434].
237 Morita M, Le Marchand L, Kono S, Yin G, Toyomura K, Nagano J, Mizoue T, Mibu R, Tanaka M, Kakeji Y, Maehara Y, Okamura T, Ikejiri K, Futami K, Maekawa T, Yasunami Y, Takenaka K, Ichimiya H, Imaizumi N. Genetic polymorphisms of CYP2E1 and risk of colorectal cancer: the Fukuoka Colorectal Cancer Study. Cancer Epidemiol Biomarkers Prev. 01. 2009;18(1):235-41. [pmid: 19124503].
238 Pereira Serafim PV, Cotrim Guerreiro da Silva ID, Manoukias Forones N. Relationship between genetic polymorphism of CYP1A1 at codon 462 (Ile462Val) in colorectal cancer. Int J Biol Markers. 01-03. 2008;23(1):18-23. [pmid: 18409146].
239 Gao CM, Takezaki T, Wu JZ, Chen MB, Liu YT, Ding JH, Sugimura H, Cao J, Hamajima N, Tajima K. CYP2E1 Rsa I polymorphism impacts on risk of colorectal cancer association with smoking and alcohol drinking. World J Gastroenterol. 11. 21. 2007;13(43):5725-30. [pmid: 17963298].
240 Ishibe N, Stampfer M, Hunter DJ, Hennekens C, Kelsey KT. A prospective study of cytochrome P450 1A1 polymorphisms and colorectal cancer risk in men. Cancer Epidemiol Biomarkers Prev. 08. 2000;9(8):855-6. [pmid: 10952105].
241 Jung AY, Poole EM, Bigler J, Whitton J, Potter JD, Ulrich CM. DNA methyltransferase and alcohol dehydrogenase: gene-nutrient interactions in relation to risk of colorectal polyps. Cancer Epidemiol Biomarkers Prev. 02. 2008;17(2):330-8. [pmid: 18268116].
242 Yokoyama A, Muramatsu T, Ohmori T, Yokoyama T, Okuyama K, Takahashi H, Hasegawa Y, Higuchi S, Maruyama K, Shirakura K, Ishii H. Alcohol-related cancers and aldehyde dehydrogenase-2 in Japanese alcoholics. Carcinogenesis. 08. 1998;19(8):1383-7. [pmid: 9744533].
243 Gao CM, Takezaki T, Wu JZ, Zhang XM, Cao HX, Ding JH, Liu YT, Li SP, Cao J, Matsuo K, Hamajima N, Tajima K. Polymorphisms of alcohol dehydrogenase 2 and aldehyde dehydrogenase 2 and colorectal cancer risk in Chinese males. World J Gastroenterol. 08. 28. 2008;14(32):5078-83. [pmid: 18763293].
244 Jelski W, Zalewski B, Chrostek L, Szmitkowski M. Alcohol dehydrogenase (ADH) isoenzymes and aldehyde dehydrogenase (ALDH) activity in the sera of patients with colorectal cancer. Clin Exp Med. 12. 2007;7(4):154-7. [pmid: 18188528].
245 Yin G, Kono S, Toyomura K, Moore MA, Nagano J, Mizoue T, Mibu R, Tanaka M, Kakeji Y, Maehara Y, Okamura T, Ikejiri K, Futami K, Yasunami Y, Maekawa T, Takenaka K, Ichimiya H, Imaizumi N. Alcohol dehydrogenase and aldehyde dehydrogenase polymorphisms and colorectal cancer: the Fukuoka Colorectal Cancer Study. Cancer Sci. 08. 2007;98(8):1248-53. [pmid: 17517051].
246 Kuriki K, Hamajima N, Chiba H, Kanemitsu Y, Hirai T, Kato T, Saito T, Matsuo K, Koike K, Tokudome S, Tajima K. Relation of the CD36 gene A52C polymorphism to the risk of colorectal cancer among Japanese, with reference to with the aldehyde dehydrogenase 2 gene Glu487Lys polymorphism and drinking habit. Asian Pac J Cancer Prev. 01-03. 2005;6(1):62-8. [pmid: 15780035].
247 Tiemersma EW, Wark PA, Ocke MC, Bunschoten A, Otten MH, Kok FJ, Kampman E. Alcohol consumption, alcohol dehydrogenase 3 polymorphism, and colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 05. 2003;12(5):419-25. [pmid: 12750236].
248 Matsuo K, Hamajima N, Hirai T, Kato T, Koike K, Inoue M, Takezaki T, Tajima K. Aldehyde dehydrogenase 2 (ALDH2) genotype affects rectal cancer susceptibility due to alcohol consumption. J Epidemiol. 03. 2002;12(2):70-6. [pmid: 12033531].
249 Takeshita T, Morimoto K, Yamaguchi N, Watanabe S, Todoroki I, Honjo S, Nakagawa K, Kono S. Relationships between cigarette smoking, alcohol drinking, the ALDH2 genotype and adenomatous types of colorectal polyps in male self-defense force officials. J Epidemiol. 11. 2000;10(6):366-71. [pmid: 11210104].
250 Murata M, Tagawa M, Watanabe S, Kimura H, Takeshita T, Morimoto K. Genotype difference of aldehyde dehydrogenase 2 gene in alcohol drinkers influences the incidence of Japanese colorectal cancer patients. Jpn J Cancer Res. 07. 1999;90(7):711-9. [pmid: 10470282].
251 Yin SJ, Liao CS, Lee YC, Wu CW, Jao SW. Genetic polymorphism and activities of human colon alcohol and aldehyde dehydrogenases: no gender and age differences. Alcohol Clin Exp Res. 10. 1994;18(5):1256-60. [pmid: 7847616].
252 Yang H, Zhou Y, Zhou Z, Liu J, Yuan X, Matsuo K, Takezaki T, Tajima K, Cao J. A novel polymorphism rs1329149 of CYP2E1 and a known polymorphism rs671 of ALDH2 of alcohol metabolizing enzymes are associated with colorectal cancer in a southwestern Chinese population. Cancer Epidemiol Biomarkers Prev. 09. 2009;18(9):2522-7. [pmid: 19706845].
253 Diorio C, Brisson J, Berube S, Pollak M. Intact and total insulin-like growth factor-binding protein-3 (IGFBP-3) levels in relation to breast cancer risk factors: a cross-sectional study. Breast Cancer Res. 2008;10(3):R42. [pmid: 18471292].
254 Cleveland RJ, Gammon MD, Edmiston SN, Teitelbaum SL, Britton JA, Terry MB, Eng SM, Neugut AI, Santella RM, Conway K. IGF1 CA repeat polymorphisms, lifestyle factors and breast cancer risk in the long island breast cancer study project. Carcinogenesis. 04. 2006;27(4):758-65. [pmid: 16332723].
255 Cruz-Correa M, Cui H, Giardiello FM, Powe NR, Hylind L, Robinson A, Hutcheon DF, Kafonek DR, Brandenburg S, Wu Y, He X, Feinberg AP. Loss of imprinting of insulin growth factor II gene: a potential heritable biomarker for colon neoplasia predisposition. Gastroenterology. 04. 2004;126(4):964-70. [pmid: 15057734].
256 Ma J, Pollak MN, Giovannucci E, Chan JM, Tao Y, Hennekens CH, Stampfer MJ. Prospective study of colorectal cancer risk in men and plasma levels of insulin-like growth factor (IGF)-I and IGF-binding protein-3. J Natl Cancer Inst. 04. 7. 1999;91(7):620-5. [pmid: 10203281].
257 Otani T, Iwasaki M, Sasazuki S, Inoue M, Tsugane S. Japan Public Health Center-Based Prospective Study Group. Plasma C-reactive protein and risk of colorectal cancer in a nested case-control study: Japan Public Health Center-based prospective study. Cancer Epidemiol Biomarkers Prev. 04. 2006;15(4):690-5. [pmid: 16614110].
258 Otake T, Uezono K, Takahashi R, Fukumoto J, Tabata S, Abe H, Tajima O, Mizoue T, Ohnaka K, Kono S. C-reactive protein and colorectal adenomas: Self Defense Forces Health Study. Cancer Sci. 04. 2009;100(4):709-14. [pmid: 19469014].
259 Diergaarde B, Braam H, van Muijen GN, Ligtenberg MJ, Kok FJ, Kampman E. Dietary factors and microsatellite instability in sporadic colon carcinomas. Cancer Epidemiol Biomarkers Prev. 11. 2003;12(11 Pt 1):1130-6. [pmid: 14652271].
260 Diergaarde B, van Geloof WL, van Muijen GN, Kok FJ, Kampman E. Dietary factors and the occurrence of truncating APC mutations in sporadic colon carcinomas: a Dutch population-based study. Carcinogenesis. 02. 2003;24(2):283-90. [pmid: 12584179].
261 La Vecchia C, Negri E, Pelucchi C, Franceschi S. Dietary folate and colorectal cancer. Int J Cancer. 12. 10. 2002;102(5):545-7. [pmid: 12432561].
262 Faivre J, Boutron MC, Senesse P, Couillault C, Belighiti C, Meny B. Environmental and familial risk factors in relation to the colorectal adenoma--carcinoma sequence: results of a case-control study in Burgundy (France). Eur J Cancer Prev. 04. 1997;6(2):127-31. [pmid: 9237060].
263 Slattery ML, Schaffer D, Edwards SL, Ma KN, Potter JD. Are dietary factors involved in DNA methylation associated with colon cancer. Nutr Cancer. 1997;28(1):52-62. [pmid: 9200151].
264 Tsong WH, Koh WP, Yuan JM, Wang R, Sun CL, Yu MC. Cigarettes and alcohol in relation to colorectal cancer: the Singapore Chinese Health Study. Br J Cancer. 03. 12. 2007;96(5):821-7. [pmid: 17311023].
265 Mizoue T, Yamaji T, Tabata S, Yamaguchi K, Shimizu E, Mineshita M, Ogawa S, Kono S. Dietary patterns and colorectal adenomas in Japanese men: the Self-Defense Forces Health Study. Am J Epidemiol. 02. 15. 2005;161(4):338-45. [pmid: 15692077].
266 Yamada K, Araki S, Tamura M, Sakai I, Takahashi Y, Kashihara H, Kono S. Case-control study of colorectal carcinoma in situ and cancer in relation to cigarette smoking and alcohol use (Japan). Cancer Causes Control. 09. 1997;8(5):780-5. [pmid: 9328201].
267 Glynn SA, Albanes D, Pietinen P, Brown CC, Rautalahti M, Tangrea JA, Taylor PR, Virtamo J. Alcohol consumption and risk of colorectal cancer in a cohort of Finnish men. Cancer Causes Control. 03. 1996;7(2):214-23. [pmid: 8740734].
268 Boutron MC, Faivre J, Dop MC, Quipourt V, Senesse P. Tobacco, alcohol, and colorectal tumors: a multistep process. Am J Epidemiol. 06. 1. 1995;141(11):1038-46. [pmid: 7771440].
269 Martinez ME, McPherson RS, Annegers JF, Levin B. Cigarette smoking and alcohol consumption as risk factors for colorectal adenomatous polyps. J Natl Cancer Inst. 02. 15. 1995;87(4):274-9. [pmid: 7707418].
270 Honjo S, Kono S, Shinchi K, Imanishi K, Hirohata T. Cigarette smoking, alcohol use and adenomatous polyps of the sigmoid colon. Jpn J Cancer Res. 08. 1992;83(8):806-11. [pmid: 1399817].
271 Su LJ, Arab L. Alcohol consumption and risk of colon cancer: Evidence from the national health and nutrition examination survey I epidemiologic follow-up study. Nutr Cancer. 2004;50(2):111-9. [pmid: 15623458].
272 Ho JW, Lam TH, Tse CW, Chiu LK, Lam HS, Leung PF, Ng KC, Ho SY, Woo J, Leung SS, Yuen ST. Smoking, drinking and colorectal cancer in Hong Kong Chinese: A case-control study. Int J Cancer. 04. 20. 2004;109(4):587-97. [pmid: 14991582].
273 Pedersen A, Johansen C, Gronbaek M. Relations between amount and type of alcohol and colon and rectal cancer in a Danish population based cohort study. Gut. 06. 2003;52(6):861-7. [pmid: 12740343].
274 Ye W, Romelsjo A, Augustsson K, Adami HO, Nyren O. No excess risk of colorectal cancer among alcoholics followed for up to 25 years. Br J Cancer. 04. 7. 2003;88(7):1044-6. [pmid: 12671702].
275 Sharpe CR, Siemiatycki J, Rachet B. Effects of alcohol consumption on the risk of colorectal cancer among men by anatomical subsite (Canada). Cancer Causes Control. 2002;13(5):483-91. [pmid: 12146853].
276 Jedrychowski W, Steindorf K, Popiela T, Wahrendorf J, Tobiasz-Adamczyk B, Kulig J, Penar A, Hartleb M. Alcohol consumption and the risk of colorectal cancer at low levels of micronutrient intake. Med Sci Monit. 2002;8(5):CR357-63. [pmid: 12011778].
277 Kune S, Kune GA, Watson LF. Case-control study of alcoholic beverages as etiologic factors: The Melbourne Colorectal Cancer Study. Nutr Cancer. 1987;9(1):43-56. [pmid: 3808969].
278 Bongaerts BW, de Goeij AF, van den Brandt PA, Weijenberg MP. Alcohol and the risk of colon and rectal cancer with mutations in the K-ras gene. Alcohol. 04. 2006;38(3):147-54. [pmid: 16905440].
279 Terry MB, Neugut AI, Mansukhani M, Waye J, Harpaz N, Hibshoosh H. Tobacco, alcohol, and p53 overexpression in early colorectal neoplasia. BMC Cancer. 11. 6. 2003;3:29. [pmid: 14604438].
280 Bongaerts BW, de Goeij AF, de Vogel S, van den Brandt PA, Goldbohm RA, Weijenberg MP. Alcohol consumption and distinct molecular pathways to colorectal cancer. Br J Nutr. 03. 2007;97(3):430-4. [pmid: 17313702].
281 Mitrou PN, Watson MA, Loktionov AS, Cardwell C, Gunter MJ, Atkin WS, Macklin CP, Cecil T, Bishop TD, Primrose J, Bingham SA. MTHFR (C677T and A1298C) polymorphisms and risk of sporadic distal colorectal adenoma in the UK Flexible Sigmoidoscopy Screening Trial (United Kingdom). Cancer Causes Control. 08. 2006;17(6):793-801. [pmid: 16783607].
282 Wei Y, Wang L, Lan P, Zhao H, Pan Z, Huang J, Lu J, Wang J. The association between -1304T>G polymorphism in the promoter of MKK4 gene and the risk of sporadic colorectal cancer in southern Chinese population. Int J Cancer. 10. 15. 2009;125(8):1876-83. [pmid: 19610067].
283 Andersen V, Agerstjerne L, Jensen D, Ostergaard M, Saebo M, Hamfjord J, Kure E, Vogel U. The multidrug resistance 1 (MDR1) gene polymorphism G-rs3789243-A is not associated with disease susceptibility in Norwegian patients with colorectal adenoma and colorectal cancer; a case control study. BMC Med Genet. 2009;10:18. [pmid: 19250544].
284 Hansen RD, Sorensen M, Tjonneland A, Overvad K, Wallin H, Raaschou-Nielsen O, Vogel U. XPA A23G, XPC Lys939Gln, XPD Lys751Gln and XPD Asp312Asn polymorphisms, interactions with smoking, alcohol and dietary factors, and risk of colorectal cancer. Mutat Res. 06. 1. 2007;619(1–2):68-80. [pmid: 17363013].
285 Mitrou PN, Watson MA, Loktionov AS, Cardwell C, Gunter MJ, Atkin WS, Macklin CP, Cecil T, Bishop DT, Primrose J, Bingham SA. Role of NQO1C609T and EPHX1 gene polymorphisms in the association of smoking and alcohol with sporadic distal colorectal adenomas: results from the UKFSS Study. Carcinogenesis. 04. 2007;28(4):875-82. [pmid: 17082176].
286 Chen K, Jin M, Zhu Y, Jiang Q, Yu W, Ma X, Yao K. Genetic polymorphisms of the uridine diphosphate glucuronosyltransferase 1A7 and colorectal cancer risk in relation to cigarette smoking and alcohol drinking in a Chinese population. J Gastroenterol Hepatol. 06. 2006;21(6):1036-41. [pmid: 16724991].
287 Skjelbred CF, Saebo M, Wallin H, Nexo BA, Hagen PC, Lothe IM, Aase S, Johnson E, Hansteen IL, Vogel U, Kure EH. Polymorphisms of the XRCC1, XRCC3 and XPD genes and risk of colorectal adenoma and carcinoma, in a Norwegian cohort: a case control study. BMC Cancer. 2006;6:67. [pmid: 16542436].
288 Chen J, Kyte C, Chan W, Wetmur JG, Fuchs CS, Giovannucci E. Polymorphism in the thymidylate synthase promoter enhancer region and risk of colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 12. 2004;13(12):2247-50. [pmid: 15598787].
289 Zhu ZZ, Wang AZ, Jia HR, Jin XX, He XL, Hou LF, Zhu G. Association of the TP53 codon 72 polymorphism with colorectal cancer in a Chinese population. Jpn J Clin Oncol. 05. 2007;37(5):385-90. [pmid: 17599946].
290 Hansen RD, Sorensen M, Tjonneland A, Overvad K, Wallin H, Raaschou-Nielsen O, Vogel U. A haplotype of polymorphisms in ASE-1, RAI and ERCC1 and the effects of tobacco smoking and alcohol consumption on risk of colorectal cancer: a Danish prospective case-cohort study. BMC Cancer. 2008;8:54. [pmid: 18289367].
291 Vogel U, Christensen J, Dybdahl M, Friis S, Hansen RD, Wallin H, Nexo BA, Raaschou-Nielsen O, Andersen PS, Overvad K, Tjonneland A. Prospective study of interaction between alcohol, NSAID use and polymorphisms in genes involved in the inflammatory response in relation to risk of colorectal cancer. Mutat Res. 11. 1. 2007;624(1–2):88-100. [pmid: 17544013].
292 Hong YC, Lee KH, Kim WC, Choi SK, Woo ZH, Shin SK, Kim H. Polymorphisms of XRCC1 gene, alcohol consumption and colorectal cancer. Int J Cancer. 09. 1. 2005;116(3):428-32. [pmid: 15800946].
293 Tranah GJ, Giovannucci E, Ma J, Fuchs C, Hunter DJ. APC Asp1822Val and Gly2502Ser polymorphisms and risk of colorectal cancer and adenoma. Cancer Epidemiol Biomarkers Prev. 04. 2005;14(4):863-70. [pmid: 15824157].
294 Hansen RD, Krath BN, Frederiksen K, Tjonneland A, Overvad K, Roswall N, Loft S, Dragsted LO, Vogel U, Raaschou-Nielsen O. GPX1 Pro198Leu polymorphism, erythrocyte GPX activity, interaction with alcohol consumption and smoking, and risk of colorectal cancer. Mutat Res. 05. 12. 2009;664(1–2):13-9. [pmid: 19428376].
295 Marietta C, Thompson LH, Lamerdin JE, Brooks PJ. Acetaldehyde stimulates FANCD2 monoubiquitination, H2AX phosphorylation, and BRCA1 phosphorylation in human cells in vitro: implications for alcohol-related carcinogenesis. Mutat Res. 05. 12. 2009;664(1–2):77-83. [pmid: 19428384].
296 Taibi G, Carruba G, Cocciadiferro L, Granata OM, Nicotra CM. Low levels of both xanthine dehydrogenase and cellular retinol binding protein are responsible for retinoic acid deficiency in malignant human mammary epithelial cells. Ann N Y Acad Sci. 02. 2009;1155:268-72. [pmid: 19250215].
297 Jin W, Chen Y, Di GH, Miron P, Hou YF, Gao H, Shao ZM. Estrogen receptor (ER) beta or p53 attenuates ERalpha-mediated transcriptional activation on the BRCA2 promoter. J Biol Chem. 10. 31. 2008;283(44):29671-80. [pmid: 18765668].
298 Maciel ME, Castro GD, Castro JA. Inhibition of the rat breast cytosolic bioactivation of ethanol to acetaldehyde by some plant polyphenols and folic acid. Nutr Cancer. 2004;49(1):94-9. [pmid: 15456641].
299 Jordao AA Jr, Chiarello PG, Arantes MR, Meirelles MS, Vannucchi H. Effect of an acute dose of ethanol on lipid peroxidation in rats: action of vitamin E. Food Chem Toxicol. 03. 2004;42(3):459-64. [pmid: 14871588].
300 Stevens RG, Davis S, Mirick DK, Kheifets L, Kaune W. Alcohol consumption and urinary concentration of 6-sulfatoxymelatonin in healthy women. Epidemiology. 2000;11(6):660-5. [pmid: 11055626].
301 Colantoni A, La Paglia N, De Maria N, Emanuele MA, Emanuele NV, Idilman R, Harig J, Van Thiel DH. Influence of sex hormonal status on alcohol-induced oxidative injury in male and female rat liver. Alcohol Clin Exp Res. 09. 2000;24(9):1467-73. [pmid: 11003215].
302 Jones PA, Baker VA, Irwin AJ, Earl LK. Interpretation of the in vitro proliferation response of MCF-7 cells to potential oestrogens and non-oestrogenic substances. Toxicol In Vitro. 08. 1998;12(4):373-82. [pmid: 20654419].
303 Vincon P, Wunderer J, Simanowski UA, Koll M, Preedy VR, Peters TJ, Werner J, Waldherr R, Seitz HK. Inhibition of alcohol-associated colonic hyperregeneration by alpha-tocopherol in the rat. Alcohol Clin Exp Res. 01. 2003;27(1):100-6. [pmid: 12544013].
304 Leuratti C, Watson MA, Deag EJ, Welch A, Singh R, Gottschalg E, Marnett LJ, Atkin W, Day NE, Shuker DE, Bingham SA. Detection of malondialdehyde DNA adducts in human colorectal mucosa: relationship with diet and the presence of adenomas. Cancer Epidemiol Biomarkers Prev. 03. 2002;11(3):267-73. [pmid: 11895876].
305 Parlesak A, Menzl I, Feuchter A, Bode JC, Bode C. Inhibition of retinol oxidation by ethanol in the rat liver and colon. Gut. 12. 2000;47(6):825-31. [pmid: 11076882].
306 Koivisto T, Salaspuro M. Aldehyde dehydrogenases of the rat colon: Comparison with other tissues of the alimentary tract and the liver. Alcohol Clin Exp Res. 1996;20(3):551-5. [pmid: 8727253].
307 Nosova T, Jokelainen K, Kaihovaara P, Jousimies-Somer H, Siitonen A, Heine R, Salaspuro M. Aldehyde dehydrogenase activity and acetate production by aerobic bacteria representing the normal flora of human large intestine. Alcohol Alcohol. 11. 1996;31(6):555-64. [pmid: 9010546].
308 Rosenberg DW, Mankowski DC. Induction of cyp2e-1 protein in mouse colon. Carcinogenesis. 01. 1994;15(1):73-8. [pmid: 8293551].
309 Jokelainen K, Roine RP, Vaananen H, Farkkila M, Salaspuro M. In vitro acetaldehyde formation by human colonic bacteria. Gut. 09. 1994;35(9):1271-4. [pmid: 7959236].
310 Shimizu M, Lasker JM, Tsutsumi M, Lieber CS. Immunohistochemical localization of ethanol-inducible P450IIE1 in the rat alimentary tract. Gastroenterology. 10. 1990;99(4):1044-53. [pmid: 2203661].
311 Laufer EM, Hartman TJ, Baer DJ, Gunter EW, Dorgan JF, Campbell WS, Clevidence BA, Brown ED, Albanes D, Judd JT, Taylor PR. Effects of moderate alcohol consumption on folate and vitamin B12 status in postmenopausal women. Eur J Clin Nutr. 11. 2004;58(11):1518-24. [pmid: 15138463].
312 Perel P, Roberts I, Sena E, Wheble P, Briscoe C, Sandercock P, Macleod M, Mignini LE, Jayaram P, Khan KS. Comparison of treatment effects between animal experiments and clinical trials: systematic review. BMJ. 01. 27. 2007;334(7586):197-200. [pmid: 17175568].
313 Yi SW, Sull JW, Linton JA, Nam CM, Ohrr H. Alcohol consumption and digestive cancer mortality in Koreans: The Kangwha Cohort Study. J Epidemiol. 05. 5. 2010;20(3):204-11. Epub 2010 Mar 16. [pmid: 20234107].
314 Scheppach W, Bingham S, Boutron-Ruault MC, De Verdier MG, Moreno V, Nagengast FM, Reifen R, Riboli E, Seitz HK, Wahrendorf J. WHO consensus statement on the role of nutrition in colorectal cancer. Eur J Cancer Prev. 1999;8(1):57-62. [pmid: 10091044].
315 Seitz HK, Simanowski UA, Osswald BR. Epidemiology and pathophysiology of ethanol-associated gastrointestinal cancer. Pharmacogenetics. 12. 1992;2(6):278-87. [pmid: 1306128].
316 Weisburger JH. Proceedings: Chemical carcinogenesis in the gastrointestinal tract. Proc Natl Cancer Conf. 1972;7:465-73. [pmid: 4587656].
317 Kleinjans JC, Moonen EJ, Dallinga JW, Albering HJ, Van den Bogaard AE, Van Schooten FJ. Polycyclic aromatic hydrocarbons in whiskies. Lancet. 1996;348(9043):1731. [pmid: 8973440].
318 Potter JD, McMichael AJ, Hartshorne JM. Alcohol and beer consumption in relation to cancers of bowel and lung: An extended correlation analysis. J Chronic Dis. 1982;35(11):833-42. [pmid: 7142362].
319 Siegmund S, Haas S, Schneider A, Singer MV. Animal models in gastrointestinal alcohol research - A short appraisal of the different models and their results. Best Pract Res Clin Gastroenterol. 08. 2003;17(4):519-42. [pmid: 12828953].
320 Aye MM, Ma C, Lin H, Bower KA, Wiggins RC, Luo J. Ethanol-induced in vitro invasion of breast cancer cells: The contribution of MMP-2 by fibroblasts. Int J Cancer. 12. 10. 2004;112(5):738-46. [pmid: 15386367].
321 Luo J. Role of matrix metalloproteinase-2 in ethanol-induced invasion by breast cancer cells. J Gastroenterol Hepatol. 2006;21(Suppl 3):S65-8. [pmid: 16958676].
322 Luo J, Miller MW. Ethanol enhances erbB-mediated migration of human breast cancer cells in culture. Breast Cancer Res Treat. 09. 2000;63(1):61-9. [pmid: 11079160].
323 Ma C, Lin H, Leonard SS, Shi X, Ye J, Luo J. Overexpression of ErbB2 enhances ethanol-stimulated intracellular signaling and invasion of human mammary epithelial and breast cancer cells in vitro. Oncogene. 08. 14. 2003;22(34):5281-90. [pmid: 12917629].
324 Meng Q, Gao B, Goldberg ID, Rosen EM, Fan S. Stimulation of cell invasion and migration by alcohol in breast cancer cells. Biochem Biophys Res Commun. 07. 5. 2000;273(2):448-53. [pmid: 10873626].
325 McGarrity TJ, Nelson RL. Dimethylhydrazine and ethanol. Dis Colon Rectum. 1986;29(4):289-90. [pmid: 3948624].
326 Larsen NS. Study suggests mechanism for alcohol-breast cancer link. J Natl Cancer Inst. 1993;85(9):700-1. [pmid: 8478954].
327 Colombo LL, Lopez MC, Chen G, Watson RR. In vitro response of v-Ha-ras transgenic mouse lymphocytes after in vivo treatment with alcohol. Immunopharmacol Immunotoxicol. 11. 2001;23(4):597-606. [pmid: 11792018].
328 Fiala ES, Sohn OS, Hamilton SR. Effects of chronic dietary ethanol on in vivo and in vitro metabolism of methylazoxymethanol and on methylazoxymethanol-induced DNA methylation in rat colon and liver. Cancer Res. 1987;47(22):5939-43. [pmid: 3664495].
329 Zedeck MS. Colon carcinogenesis and the role of dehydrogenase enzyme activity: Inhibition of tumorigenesis by pyrazole. Prev Med. 1980;9(3):346-51. [pmid: 7208443].
330 Weisburger JH, Wynder EL. The role of genotoxic carcinogens and of promoters in carcinogenesis and in human cancer causation. Acta Pharmacol Toxicol (Copenh). 1984;55(Suppl 2):53-68. [pmid: 6385622].
331 Agrawal A, Murphy RF, Agrawal DK. DNA methylation in breast and colorectal cancers. Mod Pathol. 07. 2007;20(7):711-21. [pmid: 17464311].
332 Alberts DS. Reducing the risk of colorectal cancer by intervening in the process of carcinogenesis: a status report. Cancer J. 05-06. 2002;8(3):208-21. [pmid: 12074318].
333 Ambrosone CB. Oxidants and antioxidants in breast cancer. Antioxid Redox Signal. 2000;2(4):903-17. [pmid: 11213491].
334 Arasaradnam RP, Commane DM, Bradburn D, Mathers JC. A review of dietary factors and its influence on DNA methylation in colorectal carcinogenesis. Epigenetics. 07-08. 2008;3(4):193-8. [pmid: 18682688].
335 Folate alcohol methionine, and colon cancer risk: Is there a unifying theme?. Nutr Rev. 1994;52(1):18-20. [pmid: 8139796].
336 Bailey LB. Folate, methyl-related nutrients, alcohol, and the MTHFR 677C-->T polymorphism affect cancer risk: intake recommendations. J Nutr. 11. 2003;133(11 Suppl 1):3748S-53S. [pmid: 14608109].
337 Blot WJ. Alcohol and cancer. Cancer Res. 1992;52:2119s-23s. [pmid: 1544150].
338 Boffetta P, Hashibe M. Alcohol and cancer. Lancet Oncol. 02. 2006;7(2):149-56. [pmid: 16455479].
339 Bosetti C, Altieri A, La Vecchia C. Diet and environmental carcinogenesis in breast/gynaecological cancers. Curr Opin Obstet Gynecol. 02. 2002;14(1):13-8. [pmid: 11801871].
340 Brown LM. Epidemiology of alcohol-associated cancers. Alcohol. 04. 2005;35(3):161-8. [pmid: 16054977].
341 Campos FG, Logullo Waitzberg AG, Kiss DR, Waitzberg DL, Habr-Gama A, Gama-Rodrigues J. Diet and colorectal cancer: current evidence for etiology and prevention. Nutr Hosp. 01-02. 2005;20(1):18-25. [pmid: 15762416].
342 Chhabra SK, Souliotis VL, Kyrtopoulos SA, Anderson LM. Nitrosamines, alcohol, and gastrointestinal tract cancer: Recent epidemiology and experimentation. In Vivo. 1996;10(3):265-84. [pmid: 8797028].
343 Correa Lima MP, Gomes-da-Silva MH. Colorectal cancer: lifestyle and dietary factors. Nutr Hosp. 07-08. 2005;20(4):235-41. [pmid: 16045124].
344 Dossus L, Kaaks R. Nutrition, metabolic factors and cancer risk. Baillieres Best Pract Res Clin Endocrinol Metab. 08. 2008;22(4):551-71. [pmid: 18971118].
345 Dumitrescu RG, Cotarla I. Understanding breast cancer risk -- where do we stand in 2005. J Cell Mol Med. 01-03. 2005;9(1):208-21. [pmid: 15784178].
346 Ferguson LR, Bronzetti G, De Flora S. Mechanistic approaches to chemoprevention of mutation and cancer. Mutat Res. 12. 11. 2005;591(1–2):3-7. [pmid: 16095634].
347 Filion K. Rectal proliferation and alcohol abuse. Gut. 10. 2002;51(4):611. author reply 611–2. [pmid: 12235092].
348 Forman MR, Hursting SD, Umar A, Barrett JC. Nutrition and cancer prevention: a multidisciplinary perspective on human trials. Annu Rev Nutr. 2004;24:223-54. [pmid: 15189120].
349 Fraumeni JF Jr. Epidemiological opportunities in alcohol-related cancer. Cancer Res. 07. 1979;39(7 Pt 2):2851-2. [pmid: 445491].
350 Washington State Department of Labor and Industries. Work-related carpal tunnel syndrome diagnosis and treatment guideline. Olympia (WA). Washington State Department of Labor and Industries. 2009. 04. 16.
351 Giovannucci E. Epidemiologic studies of folate and colorectal neoplasia: a review. J Nutr. 08. 2002;132(8 Suppl):2350S-5S. [pmid: 12163691].
352 Goodwin PJ. Host-related factors in breast cancer: An underappreciated piece of the puzzle. J Clin Oncol. 07. 10. 2008;26(20):3299-300. [pmid: 18612145].
353 Hamid A, Wani NA, Kaur J. New perspectives on folate transport in relation to alcoholism-induced folate malabsorption--association with epigenome stability and cancer development. FEBS J. 04. 2009;276(8):2175-91. [pmid: 19292860].
354 Heavey PM, McKenna D, Rowland IR. Colorectal cancer and the relationship between genes and the environment. Nutr Cancer. 2004;48(2):124-41. [pmid: 15231447].
355 Homann N, Seitz HK, Wang XD, Yokoyama A, Singletary KW, Ishii H. Mechanisms in alcohol-associated carcinogenesis. Alcohol Clin Exp Res. 07. 2005;29(7):1317-20. [pmid: 16088994].
356 Huxley R. Asia Pacific Cohort Studies Collaboration. The role of lifestyle risk factors on mortality from colorectal cancer in populations of the Asia-Pacific region. Asian Pac J Cancer Prev. 04-06. 2007;8(2):191-8. [pmid: 17696730].
357 Key TJ, Verkasalo PK. Endogenous hormones and the aetiology of breast cancer. Breast Cancer Res. 1999;1(1):18-21. [pmid: 11250677].
358 Kim DH. The interactive effect of methyl-group diet and polymorphism of methylenetetrahydrofolate reductase on the risk of colorectal cancer. Mutat Res. 09. 1. 2007;622(1–2):14-8. [pmid: 17602711].
359 Klatsky AL. Diet, alcohol, and health: A story of connections, confounders, and cofactors. Am J Clin Nutr. 2001;74(3):279-80. [pmid: 11522547].
360 La Vecchia C. Nutritional factors and cancers of the breast, endometrium and ovary. Eur J Cancer Clin Oncol. 12. 1989;25(12):1945-51. [pmid: 2698810].
361 Lands WE. A review of alcohol clearance in humans. Alcohol. 02. 1998;15(2):147-60. [pmid: 9476961].
362 Ledermann S. Cancer, tobacco, wine and alcohol; analysis of their influence, if such should be the case. Concours Med. 03. 19. 1955;77(12):1218-25. [pmid: 14365150].
363 Li FY, Lai MD. Colorectal cancer, one entity or three. J Zhejiang Univ Sci B. 03. 2009;10(3):219-29. [pmid: 19283877].
364 Lieber CS. ALCOHOL: its metabolism and interaction with nutrients. Annu Rev Nutr. 2000;20:395-430. [pmid: 10940340].
365 Lindahl R. Aldehyde dehydrogenases and their role in carcinogenesis. Crit Rev Biochem Mol Biol. 1992;27(4–5):283-335. [pmid: 1521460].
366 Longnecker MP. Alcohol consumption and risk of cancer in humans: An overview. Alcohol. 1995;12(2):87-96. [pmid: 7772271].
367 Longnecker MP. Do hormones link alcohol with breast cancer. J Natl Cancer Inst. 1993;85(9):692-3. [pmid: 8478949].
368 Lowenfels AB. Alcohol and breast cancer. Lancet. 1990;335(8699):1216. [pmid: 1971051].
369 Mason JB, Choi SW. Effects of alcohol on folate metabolism: implications for carcinogenesis. Alcohol. 04. 2005;35(3):235-41. [pmid: 16054985].
370 Nanri A, Moore MA, Kono S. Impact of C-reactive protein on disease risk and its relation to dietary factors. Asian Pac J Cancer Prev. 04-06. 2007;8(2):167-77. [pmid: 17696726].
371 Payne JE. Colorectal carcinogenesis. Aust N Z J Surg. 01. 1990;60(1):11-8. [pmid: 2183744].
372 Potter JD. Colon cancer--do the nutritional epidemiology, the gut physiology and the molecular biology tell the same story. J Nutr. 02. 1993;123(2 Suppl):418-23. [pmid: 8429397].
373 Potter JD. Risk factors for colon neoplasia--epidemiology and biology. Eur J Cancer. 07-08. 1995;31A(7–8):1033-8. [pmid: 7576987].
374 Poschl G, Stickel F, Wang XD, Seitz HK. Alcohol and cancer: genetic and nutritional aspects. Proc Nutr Soc. 02. 2004;63(1):65-71. [pmid: 15070439].
375 Pufulete M, Emery PW, Sanders TA. Folate, DNA methylation and colo-rectal cancer. Proc Nutr Soc. 05. 2003;62(2):437-45. [pmid: 14506892].
376 Purohit V. Can alcohol promote aromatization of androgens to estrogens? A review. Alcohol. 11. 2000;22(3):123-7. [pmid: 11163119].
377 Rampersaud GC, Bailey LB, Kauwell GP. Relationship of folate to colorectal and cervical cancer: review and recommendations for practitioners. J Am Diet Assoc. 09. 2002;102(9):1273-82. [pmid: 12792626].
378 Rogers AE, Conner MW. Alcohol and cancer. Adv Exp Med Biol. 1986;206:473-95. [pmid: 3035901].
379 Rogers AE, Zeisel SH, Groopman J. Diet and carcinogenesis. Carcinogenesis. 1993;14(11):2205-17. [pmid: 8242845].
380 Rothman KJ. Research and prevention priorities for alcohol carcinogenesis, Environ Health Perspect. 11. 1995;103(Suppl 8):161-3. [pmid: 8741777].
381 Sarkar DK, Liehr JG, Singletary KW. Role of estrogen in alcohol promotion of breast cancer and prolactinomas. Alcohol Clin Exp Res. 05. 2001;25(5 Suppl ISBRA):230S-6S. [pmid: 11391076].
382 Salaspuro MP, Mezey E. Acetaldehyde, microbes, and cancer of the digestive tract. Crit Rev Clin Lab Sci. 2003;40(2):183-208. [pmid: 12755455].
383 Seitz HK, Becker P. Alcohol metabolism and cancer risk. Alcohol Res Health. 2007;30(1):38-41. [pmid: 17718399].
384 Seitz HK, Homann N. The role of acetaldehyde in alcohol-associated cancer of the gastrointestinal tract. Novartis Found Symp. 2007;285:110-9. discussion 119. [pmid: 17590990].
385 Seitz HK, Maurer B. The relationship between alcohol metabolism, estrogen levels, and breast cancer risk. Alcohol Res Health. 2007;30(1):42-3. [pmid: 17718400].
386 Seitz H, Poschl G. Alcohol and gastrointestinal cancer: Pathogenic mechanisms. Addict Biol. 1997;2(1):19-33.
387 Seitz HK, Gartner U, Egerer G, Simanowski UA. Ethanol metabolism in the gastrointestinal tract and its possible consequences. Alcohol Alcohol Suppl. 1994;2:157-62. [pmid: 8974330].
388 Seitz HK, Simanowski UA, Homann N, Waldherr R. Cell proliferation and its evaluation in the colorectal mucosa: effect of ethanol. Z Gastroenterol. 08. 1998;36(8):645-55. [pmid: 9773483].
389 Siegmund SV, Haas S, Singer MV. Animal models and their results in gastrointestinal alcohol research. Dig Dis. 02. 2006;23(3–4):181-94. [pmid: 16508282].
390 Simanowski UA, Stickel F, Maier H, Gartner U, Seitz HK. Effect of alcohol on gastrointestinal cell regeneration as a possible mechanism in alcohol-associated carcinogenesis. Alcohol. 03-04. 1995;12(2):111-5. [pmid: 7772260].
391 Stoll BA. Alcohol intake and late-stage promotion of breast cancer. Eur J Cancer. 11. 1999;35(12):1653-8. [pmid: 10674009].
392 Tan DJ, Barber JS, Shields PG. Alcohol drinking and breast cancer. Breast Cancer Online. 04. 2006;9(4):e15.
393 Taylor B, Rehm J. Moderate alcohol consumption and diseases of the gastrointestinal system: A review of pathophysiological processes. Dig Dis. 02. 2006;23(3–4):177-80. [pmid: 16508281].
394 Thies E, Siegers CP. Metabolic activation and tumourigenesis. Prog Pharmocol Clin Pharmacol. 1989;7(2):199-214.
395 Tsigris C, Konstantakaki M, Xiromeritis C, Nikiteas N, Yannopouloa A. Animal models of carcinogenesis in the digestive system. In Vivo. 09. 2007;21(5):803-12. [pmid: 18019415].
396 Ulrich CM. Folate and cancer prevention: A closer look at a complex picture. Am J Clin Nutr. 08. 1. 2007;86(2):271-3. [pmid: 17684194].
397 Walker AR, Burkitt DP. Colonic cancer--hypotheses of causation, dietary prophylaxis, and future research. Am J Dig Dis. 10. 1976;21(10):910-7. [pmid: 1015500].
398 Wang XD. Retinoids and alcohol-related carcinogenesis. J Nutr. 01. 2003;133(1):287S-90S. [pmid: 12514311].
399 Wang XD. Alcohol, vitamin A, and cancer. Alcohol. 04. 2005;35(3):251-8. [pmid: 16054987].
400 Weisburger JH, Spingarn NE, Wang YY, Vuolo LL. Assessment of the role of mutagens and endogenous factors in large bowel cancer. Cancer Bull Univ Tex. 1981;33(4):124-9.
401 Weisburger JH. Worldwide prevention of cancer and other chronic diseases based on knowledge of mechanisms. Mutat Res. 06. 18. 1998;402(1–2):331-7. [pmid: 9675332].
402 Welsch CW. Host factors affecting the growth of carcinogen-induced rat mammary carcinomas: a review and tribute to Charles Brenton Huggins. Cancer Res. 08. 1985;45(8):3415-43. [pmid: 3926298].
403 Williams RR. Breast and thyroid cancer and malignant melanoma promoted by alcohol-induced pituitary secretion of prolactin, T.S.H. and M.S.H. Lancet. 05. 8. 1976;1(7967):996-9. [pmid: 57445].
404 Winawer SJ, Shike M. Dietary factors in colorectal cancer and their possible effects on earlier stages of hyperproliferation and adenoma formation. J Natl Cancer Inst. 1992;84(2):74-5. [pmid: 1735881].
405 Wynder EL. Nutritional carcinogenesis. Ann N Y Acad Sci. 11. 30. 1977;300:360-78. [pmid: 279278].
406 Wynder EL. Environmental carcinogenesis. Clin Bull. 1978;8(1):3-9. [pmid: 352574].
407 Nozawa H, Nakao W, Takata J, Arimoto-Kobayashi S, Kondo K. Inhibition of PhIP-induced mammary carcinogenesis in female rats by ingestion of freeze-dried beer. Cancer Lett. 04. 8. 2006;235(1):121-9. [pmid: 15946793].
408 Martin AR, Villegas I, La Casa C, de la Lastra CA. Resveratrol, a polyphenol found in grapes, suppresses oxidative damage and stimulates apoptosis during early colonic inflammation in rats. Biochem Pharmacol. 04. 1. 2004;67(7):1399-410. [pmid: 15013856].
409 Gierer A. On the temperature dependence and mechanism of action of alcohol dehydrogenase. Biochim Biophys Acta. 05. 1955;17(1):111-21. [pmid: 13239634].
410 Briviba K, Pan L, Rechkemmer G. Red wine polyphenols inhibit the growth of colon carcinoma cells and modulate the activation pattern of mitogen-activated protein kinases. J Nutr. 09. 2002;132(9):2814-8. [pmid: 12221251].
411 Caderni G, De Filippo C, Luceri C, Salvadori M, Giannini A, Biggeri A, Remy S, Cheynier V, Dolara P. Effects of black tea, green tea and wine extracts on intestinal carcinogenesis induced by azoxymethane in F344 rats. Carcinogenesis. 11. 2000;21(11):1965-9. [pmid: 11062155].
412 Cerda SR, Wilkinson J 4th, Thorgeirsdottir S, Broitman SA. R-(+)-perillyl alcohol-induced cell cycle changes, altered actin cytoskeleton, and decreased ras and p34(cdc2) expression in colonic adenocarcinoma SW480 cells. J Nutr Biochem. 01. 1999;10(1):19-30. [pmid: 15539246].
413 Depeint F, Bruce WR, Shangari N, Mehta R, O’Brien PJ. Mitochondrial function and toxicity: Role of B vitamins on the one-carbon transfer pathways. Chem Biol Interact. 10. 27. 2006;163(1–2):113-32. [pmid: 16814759].
414 Farah IO. Assessment of cellular responses to oxidative stress using MCF-7 breast cancer cells, black seed (N. Sativa L.) extracts and H2O2. Int J Environ Res Public Health. 12. 2005;2(3–4):411-9. [pmid: 16819096].
415 Femia AP, Caderni G, Vignali F, Salvadori M, Giannini A, Biggeri A, Gee J, Przybylska K, Cheynier V, Dolara P. Effect of polyphenolic extracts from red wine and 4-OH-coumaric acid on 1,2-dimethylhydrazine-induced colon carcinogenesis in rats. Eur J Nutr. 03. 2005;44(2):79-84. [pmid: 15309424].
416 Gonthier MP, Cheynier V, Donovan JL, Manach C, Morand C, Mila I, Lapierre C, Remesy C, Scalbert A. Microbial aromatic acid metabolites formed in the gut account for a major fraction of the polyphenols excreted in urine of rats fed red wine polyphenols. J Nutr. 02. 1. 2003;133(2):461-7. [pmid: 12566484].
417 Hall CN, Badawi AF, O’Connor PJ, Saffhill R. The detection of alkylation damage in the DNA of human gastrointestinal tissues. Br J Cancer. 07. 1991;64(1):59-63. [pmid: 1854628].
418 Kabat GC, Rohan TE. Does excess iron play a role in breast carcinogenesis? An unresolved hypothesis. Cancer Causes Control. 12. 2007;18(10):1047-53. [pmid: 17823849].
419 Kabat GC, Miller AB, Jain M, Rohan TE. Dietary iron and heme iron intake and risk of breast cancer: a prospective cohort study. [erratum appears in Cancer Epidemiol Biomarkers Prev. 2007 Nov;16(11):2519]. Cancer Epidemiol Biomarkers Prev. 06. 2007;16(6):1306-8. [pmid: 17548704].
420 Lagiou P, Samoli E, Lagiou A, Georgila C, Zourna P, Barbouni A, Gkiokas G, Vassilarou D, Tsikkinis A, Sfikas C, Sekeris CE, Hsieh CC, Adami HO, Trichopoulos D. Diet and expression of estrogen alpha and progesterone receptors in the normal mammary gland. Cancer Causes Control. 07. 2009;20(5):601-7. [pmid: 19037733].
421 Etique N, Chardard D, Chesnel A, Flament S, Grillier-Vuissoz I. Analysis of the effects of different alcohols on MCF-7 human breast cancer cells. Ann N Y Acad Sci. 12. 2004;1030:78-85. [pmid: 15659783].
422 Linz AL, Xiao R, Parker JG, Simpson PM, Badger TM, Simmen FA. Feeding of soy protein isolate to rats during pregnancy and lactation suppresses formation of aberrant crypt foci in their progeny’s colons: Interaction of diet with fetal alcohol exposure. J Carcinog. 10. 15. 2004;3:14. [pmid: 15488141].
423 Luceri C, Caderni G, Sanna A, Dolara P. Red wine and black tea polyphenols modulate the expression of cycloxygenase-2, inducible nitric oxide synthase and glutathione-related enzymes in azoxymethane-induced f344 rat colon tumors. J Nutr. 06. 2002;132(6):1376-9. [pmid: 12042461].
424 Moon YJ, Wang X, Morris ME. Dietary flavonoids: effects on xenobiotic and carcinogen metabolism. Toxicol In Vitro. 03. 2006;20(2):187-210. [pmid: 16289744].
425 Morris JJ, Seifter E. The role of aromatic hydrocarbons in the genesis of breast cancer. Med Hypotheses. 07. 1992;38(3):177-84. [pmid: 1513270].
426 Nozawa H, Yoshida A, Tajima O, Katayama M, Sonobe H, Wakabayashi K, Kondo K. Intake of beer inhibits azoxymethane-induced colonic carcinogenesis in male Fischer 344 rats, Int J Cancer. 01. 20. 2004;108(3):404-11. [pmid: 14648707].
427 Nozawa H, Tazumi K, Sato K, Yoshida A, Takata J, Arimoto-Kobayashi S, Kondo K. Inhibitory effects of beer on heterocyclic amine-induced mutagenesis and PhIP-induced aberrant crypt foci in rat colon. Mutat Res Genet Toxicol Environ Mutagen. 04. 11. 2004;559(1–2):177-87. [pmid: 15066585].
428 Nozawa H, Nakao W, Zhao F, Kondo K. Dietary supplement of isohumulones inhibits the formation of aberrant crypt foci with a concomitant decrease in prostaglandin E2 level in rat colon. Mol Nutr Food Res. 08. 2005;49(8):772-8. [pmid: 15968705].
429 Peluso M, Airoldi L, Munnia A, Colombi A, Veglia F, Autrup H, Dunning A, Garte S, Gormally E, Malaveille C, Matullo G, Overvad K, Raaschou-Nielsen O, Clavel-Chapelon F, Linseisen J, Boeing H, Trichopoulou A, Palli D, Krogh V, Tumino R, Panico S, Bueno-De-Mesquita BH, Peeters PH, Kumle M, Agudo A. Ma. Bulky DNA adducts, 4-aminobiphenyl-haemoglobin adducts and diet in the European Prospective Investigation into Cancer and Nutrition (EPIC) prospective study. Br J Nutr. 2008;100(3):489-95. [pmid: 18275627].
430 Reddy BS, Wang CX, Samaha H, Lubet R, Steele VE, Kelloff GJ, Rao CV. Chemoprevention of colon carcinogenesis by dietary perillyl alcohol. Cancer Res. 02. 1. 1997;57(3):420-5. [pmid: 9012468].
431 Robson EJ, Khaled WT, Abell K, Watson CJ. Epithelial-to-mesenchymal transition confers resistance to apoptosis in three murine mammary epithelial cell lines. Differentiation. 06. 2006;74(5):254-64. [pmid: 16759291].
432 Schrauzer GN, Hamm D, Kuehn K, Nakonecny G. Effects of long term exposure to beer on the genesis and development of spontaneous mammary adenocarcinoma and prolactin levels in female virgin C3H/St mice. J Am Coll Nutr. 1982;1(3):285-91. [pmid: 6309941].
433 Takechi R, Hiramatsu N, Mamo JC, Pal S. Red wine polyphenolics suppress the secretion and the synthesis of Apo B48 from human intestinal CaCo-2 cells. Biofactors. 2004;22(1–4):181-3. [pmid: 15630279].
434 Wulf G, Garg P, Liou YC, Iglehart D, Lu KP. Modeling breast cancer in vivo and ex vivo reveals an essential role of Pin1 in tumorigenesis. EMBO J. 08. 18. 2004;23(16):3397-407. [pmid: 15257284].
435 Yamagishi M, Natsume M, Osakabe N, Nakamura H, Furukawa F, Imazawa T, Nishikawa A, Hirose M. Effects of cacao liquor proanthocyanidins on PhIP-induced mutagenesis in vitro, and in vivo mammary and pancreatic tumorigenesis in female Sprague-Dawley rats. Cancer Lett. 11. 28. 2002;185(2):123-30. [pmid: 12169385].
436 Gago-Dominguez M, Castelao JE, Pike MC, Sevanian A, Haile RW. Role of lipid peroxidation in the epidemiology and prevention of breast cancer. Cancer Epidemiol Biomarkers Prev. 12. 2005;14(12):2829-39. [pmid: 16364997].
437 Gaudet MM, Gammon MD, Santella RM, Britton JA, Teitelbaum SL, Eng SM, Terry MB, Bensen JT, Schroeder J, Olshan AF, Neugut AI, Ambrosone CB. MnSOD Val-9Ala genotype, pro- and anti-oxidant environmental modifiers, and breast cancer among women on Long Island, New York. Cancer Causes Control. 12. 2005;16(10):1225-34. [pmid: 16215873].
438 Giacosa A, Frascio F, Munizzi F. Epidemiology of colorectal polyps. Tech Coloproctol. 12. 2004;8(Suppl 2):s243-7. [pmid: 15666099].
439 Lewis RC, Bostick RM, Xie D, Deng Z, Wargovich MJ, Fina MF, Roufail WM, Geisinger KR. Polymorphism of the cyclin D1 gene, CCND1, and risk for incident sporadic colorectal adenomas. Cancer Res. 12. 1. 2003;63(23):8549-53. [pmid: 14679024].
440 Orita S, Hirose M, Takahashi S, Imaida K, Ito N, Shudo K, Ohigashi H, Murakami A, Shirai T. Modifying effects of 1′-acetoxychavicol acetate (ACA) and the novel synthetic retinoids Re-80, Am-580 and Am-55P in a two-stage carcinogenesis model in female rats. Toxicol Pathol. 03-04. 2004;32(2):250-7. [pmid: 15200164].
441 Schatzkin A, Freedman L, Schiffman M. An epidemiologic perspective on biomarkers. J Intern Med. 1993;233(1):75-9. [pmid: 8429292].
442 Visapaa JP, Jokelainen K, Nosova T, Salaspuro M. Inhibition of intracolonic acetaldehyde production and alcoholic fermentation in rats by ciprofloxacin. Alcohol Clin Exp Res. 08. 1998;22(5):1161-4. [pmid: 9726290].