# Results

## Evidence Base Describing Possible Mechanisms Connecting Alcohol Consumption and Breast Cancer Risk

### Human Studies

We included five studies (see Table C-1 in Appendix C) that evaluated the possible mechanisms connecting alcohol consumption and breast cancer risk: the first study examined effects of alcohol on estradiol, estrone, estrone sulfate, testosterone, androstenedione, progesterone, dehydroepiandrosterone (DHEA), DHEA sulfate (DHEAS), and androstenediol;85 the second study86 examined the effects of alcohol on plasma and urinary hormone concentrations in premenopausal women; the third study87 examined the effect of alcohol on prolactin levels in menopausal women using estradiol replacement; the fourth study88 examined the effects of alcohol on estrogen levels in postmenopausal women; and the fifth study76 examined the relationship of alcohol consumption with antioxidant nutrients and a biomarker of oxidative stress. Although none of these five studies reported direct evidence of cancer, we included them because alcohol was administered to examine alterations in hormonal mechanism(s) and biomarkers of oxidative stress that have been suggested to be linked to the development of breast cancer. Four studies87–90 reported increased serum hormonal levels and one study76 reported an increase in isoprostane levels, a biomarker of oxidative stress. Table C-1 in Appendix C provides a summary of study design, mechanisms examined, amount and duration of ethanol or acetaldehyde exposure, study results, and authors’ conclusions.

In the study by Dorgan et al., 51 healthy postmenopausal women consumed 15 or 30 grams of alcohol per day or an alcohol-free placebo beverage through three 8-week dietary periods. Each dietary period was preceded by a 2- to 5-week washout period when participants did not consume any alcohol. The results showed an increase in serum levels of both estrone sulfate and DHEAS. While this study did not report any direct evidence to show causation of cancer, Dorgan et al. concluded that results suggest a possible mechanism by which consumption of one or two alcoholic drinks per day by postmenopausal women could increase their risk of breast cancer.85 In the second study Reichman et al. examined 34 premenopausal women who consumed 30 g of ethanol daily for three menstrual cycles and no alcohol during three other cycles.86 The results showed an increase in plasma DHEA sulfate, plasma estrone, plasma estradiol, and urinary estradiol. Reichman et al. concluded that these results suggest a possible mechanism between alcohol consumption and risk of breast cancer again because of changes in hormone levels.86 In the third study, Ginsburg et al.87 conducted two randomized, crossover studies in post menopausal women: study 1 administered ethanol (1 mL/kg, 95% ethanol) vs. isocaloric drink; study 2 was similar to study 1 except authors removed transdermal estradiol patches after administration of either ethanol or isocaloric drink. In both crossover studies, Ginsburg et al.87 reported an increase in serum prolactin levels. In the fourth study Ginsburg et al.88 administered ethanol (pineapple juice and 40% ethanol at a dose of 2.2 mL/kg of body weight [0.7 g/kg of body weight] in a total volume of 300 mL) vs. placebo to 24 postmenopausal women and reported a 3-fold increase in circulating estradiol levels in women on estrogen replacement therapy (ERT). In the fifth study Hartman et al.76 administered a controlled diet plus each of three treatments (15 or 30 g alcohol/day or no-alcohol placebo beverage) to 53 postmenopausal women, during three 8-week periods in random order and reported that moderate alcohol consumption increased isoprostane, a biomarker of oxidative stress by 4.9%.

### Animal Studies

We included 15 studies using animal models to evaluate possible mechanisms connecting alcohol consumption with breast cancer risk (see Table C-2 in Appendix C). Of the 15 included studies, 14 reported on the mechanism(s) and one91 did not. The mechanisms examined in the 14 studies were:

- elevated levels of estrogen and or progesterone92–94
- biotransformation to acetaldehyde95
- formation of DNA adducts96
- elevation of serum prolactin97,98
- suppression of cellular immunity99
- enhancement of rate of tumor progression100–103
- effect on DNA synthesis104,105

Administration and duration of ethanol exposure varied across studies. Studies also varied on whether a carcinogen was co-administered to induce carcinogenesis. Of the 15 studies, 10 reported the use of a known carcinogen to induce cancer:

- dimethylene (a) anthracene [DMBA] (five studies)
- N-methyl-N-nitrosurea [MNU] (two studies)
- N-nitrosodimethylamine [NMDA] and 4-methylnitrosoamino-1-3-pyridyl-1-butanone [NNK] (one study)
- MADB106 [one study]
- bittner virus [one study].

Table C-2 in Appendix C provides a summary of mechanisms examined, amount and duration of ethanol or acetaldehyde exposure, carcinogen use, study results, and authors’ conclusions.

Outcomes measured varied across studies. Overall, six studies reported increased cancer formation (four studies co-administered a carcinogen92,93,103 and two studies did not91,97). The reported results of intermediate outcomes included:

- biotransformation of ethanol to acetaldehyde95
- increase in the formation of DNA adducts96
- increase in terminal-end bud density and a decrease in alveolar bud structures94,104,105
- a reduction in blood natural killer cytotoxicity99

Three studies reported no changes in outcomes and concluded that their findings did not support a link between alcohol consumption and the risk of breast cancer.100–102

### Cell Line Studies

We included 15 studies using cell lines to evaluate possible mechanisms connecting alcohol consumption with breast cancer risk (see Table C-3 in Appendix C). Cell lines examined in the studies included:

- MCF-7 (six studies)
- MCF-10F (two studies)
- T4TD (one study)
- MM46 tumor cells (one study)
- MDA-MB-453 (one study)
- MCF-7 + T47D (one study)
- MCF-7 + T84 (one study)
- MCF-7 + T47D + MDA-MB-231 (one study)
- MCF-7 + ZR75.1 + BT-20 + MDA-MB-231 (one study).

Various types of mechanism were reported by these studies:

- hormonal-related65,67–69,106
- DNA adduct formation107,108
- effect on cell proliferation51,109,110
- increase cAMP111
- change in potassium channels112
- mammary gland mucin upregulation113
- smooth muscle up-regulation during transcription114

Amount and duration of ethanol and/or acetaldehyde exposure varied across all studies. Ten studies administered ethanol alone, and two studies administered ethanol combined with acetaldehyde. Table C-3 in Appendix C provides a summary of mechanisms examined, amount and duration of ethanol or acetaldehyde exposure, study results, and authors’ conclusions.

Five studies reported an increase in the expression of mRNA,68,106,113,115 two studies reported an increase in the formation of DNA adducts,107,108 two studies reported an increase in cell proliferation,65,69 two studies reported enhancement of ^3^H-thymidine uptake,51,110 one study reported up-regulation of smooth muscle myosin alkali light chain,114 and one study109 reported reduction in the expression ribosomal protein L7a.

## Evidence Base for Describing Possible Mechanisms Connecting Alcohol Consumption and Colorectal Cancer Risk

### Human Studies

We included one study (see Table C-4 in Appendix C) using human tissues to evaluate the possible mechanism connecting alcohol consumption with colorectal cancer risk. The study exposed colonic mucosa to acetaldehyde vapor.83 Although no direct evidence to show a connection between acetaldehyde exposure and cancer risk was reported, the authors concluded that acetaldehyde may cause an increase in risk of colon cancer via loss of cell-cell adhesion.83 Table C-4 in Appendix C provides a summary of study design, mechanisms examined, amount and duration of acetaldehyde exposure, study results, and authors’ conclusions.

### Animal Studies

We included 19 studies using animal models to evaluate the possible mechanisms for alcohol consumption and colorectal cancer risk (see Table C-5 in Appendix C). Of the 19 included studies, 17 reported on the mechanism(s) examined and two116,117 did not. The mechanisms examined in the 17 studies included:

- cytochrome system expression118,119
- generation of acetaldehyde70,120–123
- DNA methylation124
- cell proliferation125–127
- local mucosal effect128,129
- effect on various phases of carcinogenesis73,130,131

Administration and duration of ethanol exposure varied across all studies. Studies also varied on whether a carcinogen was co-administered. Of the 19 studies, 12 reported the use of a known carcinogen to induce cancer:

- 1,1-dimethylhydrazine (DMH) (six studies)
- methylazoxymethanol (MAM) acetate (one study)
- acetoxymethyl-methylnitrosamine (AMMN) (one study)
- AMMN + cyanamide (CY) (one study)
- azoxymethane (AOM) (three studies).

Table C-5 in Appendix C provides a summary of mechanisms examined, amount and duration of ethanol or acetaldehyde exposure, carcinogen use, study results, and authors’ conclusions.

Outcomes measured varied across studies. Among the studies that co-administered a carcinogen, six73,123,126,128,129,132 reported increased cancer formation, one131 reported suppression of cancer formation, and two reported no effect.116,117 Another study that did not co-administer a carcinogen reported an increase in cancer formation.121 The reported results of intermediate outcomes include:

- increase in the number of aberrant crypt foci118,122,125,127
- increase in microsomal ethanol-oxidizing system activity120
- increase in acetaldehyde level resulting in folate degradation70
- undermethylation of DNA124
- increase in the expression of CYP2E1^119^
- decrease in the formation of DNA adducts130

### Cell Line Studies

We included 10 studies using cell lines to evaluate possible mechanisms connecting alcohol consumption with colorectal cancer risk (see Table C-6 in Appendix C). Cell lines examined in the studies included:

- Caco-2 (six studies)
- HT-29 (one study)
- colonic mucosa cells (one study)
- Caco-2 + HT-29 (one study)
- HT-29 + SW-1116 + HCT-15 (one study).

Various mechanisms were reported by these studies:

- folate uptake modulation133
- tumor necrosis factor modulation75,133
- inflammation and cell death134
- formation of crosslinks with DNA135
- initiation of cancer136,137
- cell differentiation138
- modulation of gene expression139

Amount and duration of ethanol and/or acetaldehyde varied across all studies (seven studies administered ethanol alone, three studies administered ethanol combined with acetaldehyde). Table C-6 in Appendix C provides a summary of mechanisms examined, amount and duration of ethanol or acetaldehyde exposure, study results, and authors’ conclusions.

Outcomes varied across all studies. Reported results included:

- inhibitory effect on both 3H-folic and 3H-methotrexate uptake140
- increase in tumor necrosis factor-alpha receptor-1^75^
- inflammation resulting in increased phosphatidylserine production134
- increase in mRNA expression74
- dual effect on cell proliferation (acute acetaldehyde exposure inhibitory and chronic acetaldehyde exposure stimulating)136
- increase in sucrase and maltase activity137,138
- increase in alkaline phosphatase and sucrose activities, limited cytotoxicity133
- damage to DNA strands135
- lack of effect on the expression of HLA class 1 antigens139

### Combination Study (Animal, Cell Line)

We included one study141 that used a combination of animal (mice) and cell line (Caco-2) to evaluate the possible mechanisms connecting alcohol consumption with colorectal cancer risk (see Table C-7 in Appendix C). Intestinal cell proliferation as a result of phosphatidylethanol accumulation was the examined mechanism. The animal study administered ethanol and the cell line study administered either ethanol or acetaldehyde. Outcome reported was disruption of cellular signals. Chronic alcohol exposure resulted in an increase of maximal intestinal density.141

## Systematic Reviews and Narrative Reviews of Epidemiology Studies

We identified and summarized the reported results and conclusions from 13 systematic reviews of epidemiology studies looking for an association between alcohol intake and cancer risk (seven on breast cancer [see Table 1], six on colorectal cancer [see Table 2]). While these studies were not considered part of our primary evidence base addressing the key questions of this report, they do provide important evidence connecting alcohol intake with breast and colorectal cancer risk in humans and provide a context for discussing the findings of the studies included in our primary evidence base. The tables provide the review objectives, the resources searched, inclusion criteria, a summary of results, and the authors’ conclusions. Key areas examined by the systematic reviews of breast cancer included:

- alterations in estrogen-dependent pathways
- polymorphisms in one-carbon metabolism pathways
- interaction with dietary folate intake
- dose-response relationships between alcohol intake and cancer risk.

Table 1 Systematic reviews/meta-analyses for breast cancer epidemiology studies

Study | Objective | Resources Searched and Inclusion Criteria | Results | Conclusions as Reported by Study Authors
Suzuki et al. 2008^142^ | To quantitatively assess the accumulated evidence on the association between alcohol intake and the risk of estrogen receptor (ER) and progesterone receptor (PR)– defined breast cancer subtypes and to evaluate whether the observed association differs across ER/PR status. | Eligible studies were identified by searching the MEDLINE database from January 1, 1970 through April 20, 2007 for relevant epidemiology studies of alcohol consumption in relation to the risk of breast cancer defined by ER/PR without any language restriction. [underlined: Evidence base:] Nineteen studies (4 prospective cohort studies and 16 case-control studies) | The risk of developing breast cancer was statistically significant comparing the highest vs. lowest consumption categories for developing: ER+ tumors 27% (1.17–1.38), all ER- tumors 14% (1.03–1.26), ER+PR+ tumors 22% (1.11–1.34), ER+PR- tumors 28% (1.07–1.53), but not ER-PR- tumors. An increase in alcohol consumption of 10 g of ethanol per day was associated with statistically significant increased risks for: all ER+ 12% (8%–15%), all ER− 7% (0%–14%), ER+PR+ 11% (7%–14%) and ER+PR− 15% (2%–30%), but not ER−PR−. | Estrogen-dependent pathway alone cannot account for the detected positive associations with alcohol for ER+PR+ and ER-PR+ tumors.
Lissowska et al. 2007^143^ | To examine the role of genetic polymorphisms in the one-carbon metabolism pathway and breast cancer risk. | Epidemiology studies of methylenetetrahydrofolate gene (MTHFR A222V and E429A) polymorphisms and breast cancer risk published through August 2006 were identified through a PubMed search. | There was no significant association of breast cancer risk with nutrients involved in one carbon metabolism (i.e., folate, vitamins B2, B6, B12, methionine) or with alcohol intake. | Study did not support association between polymorphisms in the one-carbon metabolism pathway and the risk of breast cancer.
Lewis et al. 2006^144^ | To summarize the available evidence from observational studies on this issue and a meta-analysis of the association between a common polymorphism in the 5,10-methylenetetra- hydrofolate reductase (MTHFR) gene. | MEDLINE and ISI Web of knowledge databases for relevant studies that were published through May 31, 2006. [underlined: Evidence base:] 19 studies (13 case-control studies and 9 cohort studies) of which seven cohort studies and one case-control study examined the interaction between alcohol and folate intakes with respect to risk of breast cancer. | Only two studies used the same cut off points for alcohol intake. Therefore, evidence for interaction between alcohol and folate intakes with respect to risk of breast cancer was inconclusive. | There is no association between a lack of dietary folate intake and breast cancer risk.
Key et al. 2006^52^ | To give an up-to-date assessment of the association of alcohol with female breast cancer, addressing methodological issues and shortfalls in previous overviews. | MEDLINE, EMBASE, Pascal (BIDS), Science Citation Index (BIDS), Social Sciences Citation Index (BIDS), Index to Scientific and Technical Proceedings (via BIDS), Biological Abstracts (BIOSIS), Biological Sciences, AIDS and Cancer Research Abstracts, Biology Digest, Conference Papers Index, Cochrane Library, NHS National Research Register (NRR), SIGLE (System for Information on Grey Literature), NTIS (National Technical Information Service), TOXLINE. [underlined: Evidence base:] 98 studies (75,728 drinkers vs. 60,653 non-drinkers) | Excess risk associated with alcohol consumption was 22% (9%–37%). Each additional 10 g ethanol per day increases breast cancer risk by 10% (5%–15%). Estimated population attributable risk in the U.S.A. and U.K. were, 1.6% and 6.0%, respectively. | Association between alcohol and breast cancer may be causal.
Hamajima et al. 2002^34^ | A collaborative reanalysis of individual data from 53 epidemiology studies, including 58,515 women with breast cancer and 95,067 women without the disease. | Resources searched were not reported by study authors. [underlined: Evidence base:] 53 studies (51 published, 2 unpublished) | The average consumption of alcohol reported by controls from developed countries was 6.0 g per day, i.e., about half a unit/drink of alcohol per day; greater in ever- smokers than never-smokers, (8.4 g per day and 5.0 g per day, respectively). Compared with women who reported no alcohol, relative risk (RR) of breast cancer was 1.32 (1.19–1.45, p <0.00001) for an intake of 35–44 g per day alcohol, and 1.46 (1.33–1.61, p <0.00001) for ≥45 g per day alcohol. For each additional 10 g per day intake of alcohol, the relative risk of breast cancer increased by 7.1% (5.5%–8.7%, p <0.00001). | Caution is needed to interpret the effect of alcohol on risk of breast cancer.
Corrao et al. 1999^145^ | To compare the strength of the evidence provided by the epidemiology literature on the association between alcohol consumption and the risk of six cancers (oral cavity, esophagus, colorectum, liver, larynx, breast). | MEDLINE from 1966 up to and including 1998, articles reported by other bibliographic databases available at the University of Miami (Current Contents from 1996, EMBASE from 1980, CAB abstracts from 1973, and Core Biomedical Collection from 1993). [underlined: Evidence base:] 200 epidemiology studies (29 breast). | RR for dose of alcohol intake for breast cancer in the Mediterranean region^*^ were: 1.6 (1.6–1.7) for 25 g per day, 2.7 (2.4–2.9) for 50 g per day, and 7.1 (5.8–18.6) for 100 g per day. RR for dose of alcohol intake in other areas^*^ were: 1.2 (1.1–1.3) for 25 g per day, 1.5 (1.2–1.8) for 50 g per day, and 2.1 (1.4–3.1) for 100 g per day. ^*^strata by region | Based on weak dose- response relationship, there is need for well-conducted epidemiology studies.
Smith-Warner et al. 1998^39^ | To assess the risk of invasive breast cancer associated with total and beverage-specific alcohol consumption and to evaluate whether dietary and nondietary factors modify the association. | Resources searched were not reported by study authors. [underlined: Evidence base:] 6 prospective studies that had at least 200 incident breast cancer cases, assessed long-term intake of food and nutrients, and used a validated diet assessment instrument. | For alcohol intake less than 60 g per day breast cancer risk increased linearly with increasing intake. Pooled multivariate RR for an increment of 10 g per day of alcohol (about 0.75–1 drink) was 1.09 (1.04–1.13). Multivariate-adjusted RR for total alcohol intake of 30 to <60 g per day (about 2–5 drinks) vs. nondrinkers was 1.41 (1.18–1.69). Limited data suggested that alcohol intake of at least 60 g per day were not associated with further increased risk. The specific type of alcoholic beverage did not strongly influence risk estimates. The association between alcohol intake and breast cancer was not modified by other factors. | Alcohol consumption is associated with a linear increase in breast cancer incidence in women over the range of consumption reported by most women. Among women who consume alcohol regularly, reducing alcohol consumption is a potential means to reduce breast cancer risk.
Longnecker 1993^146^ | To evaluate the association between alcohol consumption and risk of breast cancer. | MEDLINE from 1996 through September 1992, all abstracts presented at the society for Epidemiology Research from 1989–1994. [underlined: Evidence base:] 38 epidemiology studies | RR of breast cancer following daily alcohol consumption were 1.11 (1.07–1.16) for one drink, 1.24 (1.15–1.34) for two drinks, and 1.38 (1.23–1.55) for three drinks. | Causal role of alcohol remains uncertain.

Table 2 Systematic reviews/meta-analyses for colorectal cancer epidemiology studies

Study | Objective | Resources Searched and Inclusion Criteria | Results | Conclusions as Reported by Study Authors
Mizoue et al. 2008^147^ | To examine the association between alcohol consumption and colorectal cancer in Japanese. | Population-based cohort studies that were conducted in Japan, started between the mid-1980s and the mid-1990s, included more than 30,000 participants, obtained information on diet, including alcohol intake, using a validated questionnaire or a similar one at baseline, and collected incidence data for colorectal cancer during the follow-up period. [underlined: Evidence base (5 cohort studies):]; - The Japan Public Health Center-based Prospective Study (JPHC); - The Japan Collaborative Cohort Study (JACC); - The Miyagi Cohort Study; - The Takayama Study; ○ According to the authors, the JPHC was treated as two independent studies (JPHC I and JPHC II) because of a difference in the dietary questionnaires used; thus, data from a total of five studies were analyzed. | In men, multivariate-adjusted pooled hazard ratios for alcohol intake of 23–45.9 g per day, 46–68.9 g per day, 69–91.9 g per day, and >92 g per day, compared with nondrinkers, were 1.42 (1.21–1.66), 1.95 (1.53–2.49), 2.15 (1.74–2.64), and 2.96 (2.27–3.86), respectively (p for trend <0.001). The association was evident for both the colon and the rectum. A significant positive association was also observed in women. Twenty-five percent of colorectal cancer cases were attributable to an alcohol consumption of >23 g per day. | When compared to Western populations, alcohol-colorectal cancer association seems to be more evident in Japanese.
Moskal et al. 2007^148^ | To examine if current alcohol intake is associated with risk of colon and rectal cancer by summarizing the results of published prospective cohort studies with meta-analytic techniques. | Prospective cohort studies in MEDLINE published in English between 1990 and June 2005; (iii) referenced in MEDLINE. Since studies on specific types of alcohol (beer, wine, and liquor) were limited, the authors restricted the meta- analyses to total alcohol consumption on colorectal cancer risk. Studies in particular populations (i.e., cohorts of alcoholics or brewery workers) were not included. [underlined: Evidence base:] Sixteen prospective cohort studies | High alcohol intake was significantly associated with increased risk of colon 1.50 (1.25–1.79) and rectal cancer 1.63 (1.35–1.97). This was comparable to a 15% increase of risk of colon or rectal cancer for an increase of 100 g of alcohol intake per week. The association did not change significantly by anatomical site (colon, rectum). | Lifestyle recommendations for prevention of colorectal cancer should consider limiting alcohol intake.
Mizoue et al. 2006^149^ | To review epidemiology findings regarding the association between alcohol drinking and colorectal cancer among the Japanese population. | MEDLINE from 1965 to 2005 [underlined: Inclusion criteria:] Epidemiology studies on the association between alcohol drinking and colorectal cancer incidence or mortality among Japanese. [underlined: Evidence base:] Eighteen studies (5 cohort studies and 13 case-control studies). | A moderate or strong positive association was observed between alcohol drinking and colon cancer risk in all large-scale cohort studies, with some showing a dose-response relationship, and among several case-control studies. A positive association with rectal cancer was also reported, but it was less consistent, and the magnitude of the association was generally weaker compared with colon cancer. The RR of colon or colorectal cancer increased even among moderate drinkers consuming <46 g of alcohol per day, levels at which no material increase in the risk was observed in a pooled analysis of Western studies. | Among the Japanese population, alcohol consumption perhaps may increase the risk of colorectal cancer. Association with colon cancer is probable, and that for rectal cancer is possible.
Cho et al. 2004^36^ | To examine the relationship of total alcohol intake and intake from specific beverages to the incidence of colorectal cancer and to evaluate whether other potential risk factors modify the association. | The authors reported a pooled analysis of primary data from 8 cohort studies in 5 countries. | Increased risk for colorectal cancer was limited to persons with an alcohol intake of 30 g/day or greater (approximately >2 drinks per day), a consumption level reported by 4% of women and 13% of men. Compared with nondrinkers, the pooled RR were 1.16 (0.99–1.36) for persons who consumed 30 to <45 g per day and 1.41 (1.16–1.72) for those who consumed ≥45 g per day (p for trend <0.001). Evident for cancers of the proximal colon, distal colon, and rectum. No clear difference in relative risks was found among specific alcoholic beverage. | There was a correlation between a single determination of alcohol consumption and a modest relative elevation in the rate of colorectal cancer, mostly at the highest levels of consumption.
Corrao et al. 1999^145^ | To compare the strength of the evidence provided by the epidemiology literature on the association between alcohol consumption and the risk of six cancers (oral cavity, esophagus, colorectum, liver, larynx, breast). | MEDLINE from 1966 up to and including 1998, articles reported by other bibliographic databases available at the University of Miami (Current Contents from 1996, EMBASE from 1980, CAB abstracts from 1973, and Core Biomedical Collection from 1993). [underlined: Evidence base:] 200 epidemiology studies (16 colon [12 case-control, 4 cohort], 14 rectum [11 case-control, 3 cohort]). | [underlined: Colon studies]^**^ RR for dose of alcohol intake in colon studies (case-control) were 1.0 (1.0–1.1) for 25 g per day, 1.1 (1.0–1.2) for 50 g per day, and 1.1 (1.0–1.3) for 100 g per day. RR for dose alcohol intake in colon studies (cohort studies) were 1.4 (1.1–1.7) for 25 g per day, 1.9 (1.3–2.9) for 50 g per day, and 3.6 (1.6–8.5) for 100 g per day. ^**^Reported results were stratified by study design [underlined: Rectum studies]^***^ RR for dose of alcohol intake in rectum studies among men were 1.1 (1.0–1.2) for 25 g per day, 1.2 (1.1–1.5) for 50 g per day, and 1.5 (1.2–2.2) for 100 g per day. RR for dose of alcohol in rectum studies among women were 2.3 (1.3–4.0) for 25 g per day, 5.0 (1.6–16.4) for 50 g per day, and 25.7 (2.5–267.6) for 100 g per day. ^***^Reported results were stratified by gender | Based on weak dose- response relationship, there is need for well- conducted epidemiology studies.
Franceschi and La Vecchia 1994^150^ | To evaluate alcohol consumption and the risk of cancers of the stomach and colon-rectum. | [underlined: Evidence base:] 34 studies (15 cohort, 19 case-control). | Among the 15 cohort studies: seven studies were not very informative; and overall evidence from 8 studies showed colon cancer RR estimates varying within a narrow range of 1.0–1.7 [ranging between 1.1–1.3 in most studies], and rectal cancer 1.0–2.5 [ranging between 1.0–1.7 in most studies]. Among the 19 case-control studies: five studies were totally negative, and showed no evidence of association; 3 other studies showed overall significant associations; and remaining 11 studies showed no consistent overall association. | Epidemiology evidence regarding a causal role of alcoholic beverage consumption and colorectal carcinogenesis remains inconclusive.

Key areas examined by the systematic reviews of colorectal cancer include differences in Japanese versus western populations, and amount of alcohol intake and cancer risk.

## Reported Mechanisms in the Epidemiology Literature

A search of the literature identified the following mechanisms reported in breast and colorectal cancer epidemiology studies that were not included in our primary evidence base (see Table 3 and Table 4, respectively). These studies investigated the association between alcohol consumption and increased cancer risk primarily by administering questionnaires to study dietary behavior and amount of alcohol consumption and correlated these findings with cancer incidence. Some of these studies looked at different alcoholic beverages, for example wine, beer, and other spirits. However, none of these studies controlled alcohol exposure.

Table 3 Breast cancer epidemiology studies

Proposed Mechanism | References
Changes in circulating hormone levels | 37,151–158
DNA-adduct formation | 159
Changes in levels of insulin-like growth factor | 160
Changes in levels of biomarkers of inflammation | 77–81
Cytochrome P450 polymorphism | 161,162
Methylenetetrahydrofolate reductase polymorphism/Dietary/Vitamins | 38,163–173
Alcohol dehydrogenase/Acetaldehyde dehydrogenase polymorphism | 45,47–50,174–178
Other types of polymorphism | 179–184

Table 4 Colorectal cancer epidemiology studies

Proposed Mechanism | References
DNA repair polymorphisms | 90,166,185–234
Hyperproliferation of rectal mucosa | 141,235
Colonic microbial metabolism resulting in the generation of acetaldehyde | 55,56
Cytochrome P450 polymorphism | 236–240
Alcohol dehydrogenase and acetaldehyde dehydrogenase polymorphism | 19,241–252
Changes in levels of insulin-like growth factor | 253–256
Impact of C-reactive protein and Inflammation | 257,258
Methylenetetrahydrofolate reductase polymorphism/Dietary/Vitamins | 189,259–263
Other types of polymorphism and mechanisms | 259,264–294

Our searches of the literature identified hypothesis-generating studies that provide indirect evidence of potential mechanisms. These studies examined various metabolic pathways that have been proposed as potential connections between alcohol exposure and increased breast or colorectal cancer risk (see Table 5 and Table 6, respectively).

Table 5 Hypothesis-generating breast cancer studies

Study | Reported Mechanism
Marietta et al. 2009^295^ | Stimulation of Fanconi anemia–breast cancer associated (FANC–BRCA) DNA damage response network by acetaldehyde
Taibi et al. 2009^296^ | Low levels of both xanthine dehydrogenase and cellular retinol binding protein
Jin et al. 2008^297^ | Activation of BRCA2 transcription by estrogen receptor-beta
Maciel et al. 2004^298^ | Inhibition of bioactivation of ethanol to acetaldehyde by folic acid
Jordao et al. 2004^299^ | Increased lipid peroxidation
Stevens et al. 2000^300^ | Change in estrogen levels
Colantoni et al. 2000^301^ | Increased levels of malondialdehyde
Jones et al. 1998^302^ | Response of MCF-7 cells to potential estrogens and non-estrogenic substances

Table 6 Hypothesis-generating colorectal cancer studies

Study | Reported Mechanism
Jelski et al. 2004^15^ | Alcohol dehydrogenase and aldehyde dehydrogenase polymorphisms
Vincon et al. 2003^303^ | Generation of free radicals.
Leuratti et al. 2002^304^ | DNA adduct formation
Parlesak et al. 2000^305^ | Inhibition of retinol oxidation
Koivisto et al. 1996^306^ | Alcohol dehydrogenase polymorphism
Jokelainen et al. 1996^57^ | Generation of acetaldehyde by human colonic bacteria
Seitz et al. 1996^21^ | Alcohol dehydrogenase polymorphism
Nosova et al., 1996^307^ | Generation of acetaldehyde by human colonic bacteria
Rosenberg et al. 1994^308^ | Induction of cytochrome P450
Jokelainen et al. 1994^309^ | Generation of acetaldehyde by human colonic bacteria
Shimizu et al. 1990^310^ | Induction of cytochrome P450

These hypothesis-generating studies and epidemiology studies were incorporated into this report in order to review and discuss this literature base in comparison with our primary evidence base.

### Ongoing Clinical Trials

A search of the clinicaltrials.gov (http://clinicaltrials.gov/) Web site did not identify any ongoing trials related alcohol consumption and possible causal mechanisms for breast and colorectal cancers.