# Methods

## Technical Expert Panel

ECRI Institute, in consultation with AHRQ, recruited a technical expert panel (TEP) to give input on key steps including the selection and refinement of the questions to be examined. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts. The expert panel membership is provided in the front matter of this report.

ECRI Institute created a protocol for developing the evidence report. The process consisted of working with AHRQ and the TEP to outline the report’s objectives and to finalize Key Questions for the review. These Key Questions are presented in the Scope and Key Questions section of the Introduction. Upon AHRQ approval, the draft protocol was posted on the AHRQ Web site at http://www.ahrq.gov/clinic/tp/alccantp.htm.

## Peer Review and Public Commentary

A draft of the completed report was sent to the peer reviewers and the representatives of AHRQ. In response to the comments of the peer reviewers, revisions were made to the evidence report, and a summary of the comments and their disposition was submitted to AHRQ. Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

## Key Questions

The purpose of our assessment of the basic science literature concerning alcohol and cancer induction is not to determine the extent to which alcohol is a risk factor for breast and colorectal cancers, but instead to explore the evidence suggesting possible underlying causal mechanism(s) of the association between alcohol consumption and breast and colorectal cancers (see broken arrows from alcohol to cancer induction in Figure 2 and Figure 3). Therefore, we developed four Key Questions that address the potential mechanism(s) by which alcohol might be involved in the development of breast and colorectal cancers.

Figure 2 Analytical framework for breast cancer

KQ: Key Question

KQ 1: effect of alcohol on stages of carcinogenesis

KQ 2: effect of alcohol and other risk factors on stages of carcinogenesis

Figure two is a line and square drawing depicting the analytic framework for breast cancer. The two cell lines, either animal or human, are exposed to alcohol. Other risk factors, along with alcohol metabolites, induce cancer, or its promotion or progression, to breast cancer.

Figure 3 Analytical framework for colorectal cancer

KQ: Key Question

KQ 3: effect of alcohol on stages of carcinogenesis

KQ 4: effect of alcohol and other risk factors on stages of carcinogenesis

Figure three is a line and square drawing depicting the analytic framework for colorectal cancer. The two cell lines, either animal or human, are exposed to alcohol. Other risk factors, along with alcohol metabolites, induce cancer, or its promotion or progression, to colorectal cancer.

Key Question 1. What are the likely causal mechanisms by which alcohol contributes to the development of breast cancer? Which of the possible mechanisms (e.g., induction of P450 cytochromes and carcinogen metabolism, effects on blood hormone concentrations, effect of acetaldehyde or other alcohol metabolite on apoptosis and DNA repair, interactive effects on other nutritional factors, or others) are likely to be most important in breast cancer development?

Key Question 2. For the most likely mechanisms of action involving alcohol and the development of breast cancer, how might other factors modify the effect of alcohol on breast cancer (for example, age, latency of effect, intensity, duration, and recency of exposure, presence of co-carcinogens, presence of threshold effect)? Do the causal mechanisms vary by cell type or other tumor characteristics?

Key Question 3. What are the likely causal mechanisms by which alcohol contributes to the development of colorectal cancer? Which of the possible mechanisms (e.g., induction of P450 cytochromes and carcinogen metabolism, effects on blood hormone concentrations, effect of acetaldehyde or other alcohol metabolite on apoptosis and DNA repair, interactive effects on other nutritional factors, or others) are likely to be most important in colorectal cancer development?

Key Question 4. For the most likely mechanisms of action involving alcohol and the development of colorectal cancer, how might other factors modify the effect of alcohol on colorectal cancer (for example, age, latency of effect, intensity, duration, and recency of exposure, presence of co-carcinogens, presence of threshold effect)? Do the causal mechanisms vary by cell type or other tumor characteristics?

## Analytical Framework

Figure 2 for breast and Figure 3 colorectal cancer portray analytical framework that visually describe the potential links in a chain of evidence that connect alcohol to breast and colorectal cancers. Contained within the framework are the Key Questions being addressed by this report and the potential areas of study (humans, animals, tissues, cells, ethanol and its metabolites) that can be manipulated to examine the assumed connection between alcohol consumption and an increased risk of developing breast or colorectal cancer.

## Identification of Clinical Studies

The studies included in the primary evidence base for this technology assessment were identified using a multi-staged study selection process, and were based on inclusion criteria that were determined a priori, after the creation of the Key Questions and before any detailed examination of the literature base. Use of a priori inclusion criteria reduces the risk of bias because the decision to include or exclude each study is independent of the results of the study. In the first stage of the selection process, we performed a comprehensive literature search using broad criteria. In the second stage, we retrieved all articles that appeared to meet the a priori inclusion criteria, based on their published abstracts. In the final stage of the study selection, we reviewed the full text of each retrieved article, assessed its internal validity, and verified whether or not it met the a priori inclusion criteria.

## Electronic Database Searches

We searched 11 external databases, including PubMed and EMBASE, for studies on possible mechanisms of alcohol and breast and colorectal cancer development (i.e., initiation, promotion, and progression) to identify evidence relevant to the Key Questions 1–4 using Medical Subject Headings and free text words. Additionally, we used some of the search terms and sources that were suggested by the Technical Expert Panel members on October 28, 2009. Two reviewers in the investigative team independently screened search results, selected studies to be included and reviewed each trial for inclusion. To supplement the electronic searches, we manually examined the bibliographies of included studies, scanned the content of new issues of selected journals, and reviewed relevant gray literature for potential additional articles. Gray literature includes reports and studies produced by local government agencies, private organizations, educational facilities, and corporations that do not appear in the peer-reviewed literature. Although we examined gray literature sources to identify relevant information, we only consider published, peer-reviewed literature in this report. During the peer review process, any new studies or data recommended were subjected to the same inclusion and exclusion criteria. A complete list of the databases searched and the search strategy used to identify relevant studies are presented in Appendix A.

## Study Selection

Use of explicit inclusion criteria, decided upon before any data have been extracted from studies, is a vital tool in preventing reviewer biases. Some of the a priori criteria are based on study design, and other criteria ensure that the evidence is not derived from unusual patients or interventions, and/or outmoded technologies. We developed the same inclusion criteria for each Key Question that this report addresses.

## Criteria for Inclusion/Exclusion of Studies in the Review

We used the following formal criteria to determine which studies were included in the primary evidence base that addresses each Key Question. These studies are primarily experimental studies where the exposure to ethanol or acetaldehyde could be controlled and precise biochemical measurements could be made.

1. Any study, regardless of design, that provides data on the possible causal mechanism(s) of any association between alcohol consumption and the development of breast and colorectal cancers in any population setting, including humans, animals, and in vitro experimental studies.
2. In order to assess the outcome measure of carcinogenesis, there must be no breast or colorectal cancer present in human and animal studies prior to the start of the study.
3. Cell lines should be appropriate to the study of breast and colorectal cancers in humans.
4. Studies that report on metastatic lesions or tumor invasion were excluded because they do not discuss the likely causal mechanism(s) of the tumor at the primary site (breast or colorectal).
5. When the same study was published more than once, we used the data from the most recent publication. However, if the older report had provided data that was not provided by the most recent report, we included such data.
6. Studies must have administered ethanol. Studies that administered alcoholic beverages such as beer or malt liquor were excluded given that the exact composition of such drinks remains confidential.

Studies that did not specifically control alcohol exposure were also considered in this report but were not included in the primary evidence base addressing the Key Questions. Hypothesis-generating studies examining metabolic pathways that may connect alcohol to cancer risk and epidemiology studies of alcohol exposure (including those in patients with or without cancer) were incorporated into the report in order to review and discuss this literature for comparison with our primary evidence base from experimental studies.

## Literature Review Procedures

The abstracts for all identified documents were downloaded into the Mobius Analytics SRS 4.0 Web-based system for conducting systematic reviews. Using this system, we assessed abstracts in order to either include or exclude identified documents based on our inclusion criteria. If the abstract was missing or had insufficient information to make a decision on inclusion we ordered the full article. Full articles were then retrieved for review and categorization using Web-based forms. The Web-based system provided a structured framework to build and manage the numerous documents identified by our searches.

The review process underwent four levels:

- Level 1 – Abstract Review
- Level 2 – Full Document Review
- Level 3 – Background Document Review
- Level 4 – Evidence Base Document Review.

Each level has an electronic form for capturing data about each document identified in our searches (see Appendix B for sample data abstraction forms).

## Data Abstraction and Data Management

All documents that were identified as belonging in the evidence base of the report underwent data abstraction using EXCEL spreadsheets. Table B-1 in Appendix B provides a list of the data abstracted from each study and placed in to a separate column in the spreadsheet. Some of the columns were modified depending on whether a study examined humans, animals, or cell lines. The information in the spreadsheets was later used to create the evidence tables in this report.

### Disposition of the Documents Identified by Literature Searches

The SRS Web-based system allowed us to track all identified documents along with their complete citation. Literature searches were updated periodically and the new documents were added to the system and reviewed. Using the information contained in the SRS database we were able to create Figure 4 to illustrate an attrition diagram as well as separate tables that show the disposition of the documents identified by our literature searches. A total of 819 documents were identified by our searches. After review of the abstracts and then full documents, we included 264 documents for discussion within the report. Of these 264 documents, 66 met the requirements for the primary evidence base because they addressed one of the Key Questions. An additional 197 documents were included because they addressed issues related to alcohol and breast or colorectal cancer risk.

Figure 4 Disposition of the documents identified by literature searches

Figure four depicts boxes progressing from the top to the bottom describing the disposition of the documents identified by literature searches. They noted documents identified and concluded that sixty six studies addressed the key questions, constituting the primary evidence base of the report. They were six human studies (five breast cancer and one colorectal cancer); thirty four animal exposure (fifteen breast cancer and nineteen colorectal cancer); twenty five human cell lines (fifteen breast and 10 colorectal); and one combination of animal and cell line on colorectal cancer.

## Assessing the Evidence for Each Key Question

### Assessment of Internal and External Validity

A critical part in the process of creating a systematic review is assessing the validity of the results reported in each included study in the review. The validity of individual study results is determined in the context of the Key Questions these studies address. Internal validity is the extent to which a study’s design and conduct are likely to have prevented bias and produced results that describe a true relationship.59

The members of the Technical Expert Panel proposed several methods for evaluating the internal validity of studies using animals, tissues, or cells as the primary experimental model.

- Evidence from experimental studies offer the most compelling evidence that a mechanism/pathway is directly involved in increasing cancer risk with alcohol intake.
- Use of alcohol concentration levels in animal studies that far exceed levels that occur in humans are considered of low applicability.
- Cell lines should be appropriate to the study of breast and colorectal cancer in humans.

To ultimately establish the presence of a contributory cause between alcohol consumption and breast or colorectal cancer, the following criteria have to be fulfilled: association, exposure prior to the association, and demonstration that changing the cause alters the effect.14,60–63 Other supportive criteria such as strength of association, consistency of association, biological plausibility, and a dose-response relationship can be used to establish contributory cause.60–63

For this systematic review, we applied the “direct” vs. “indirect” evidence concept.64 Direct assessment measures are those which provide direct evidence that alcohol causes either breast or colorectal cancer. Such evidence as shown in Figure 1 may confirm the steps during cancer formation and possible sites of action of alcohol thus demonstrating a contributory cause.

Indirect measures typically focus on predictors that are correlated to carcinogenesis, but do not measure actual causation. Some of the most common indirect assessment measures include:3,10,13,14,18,41,55,65–81

- increased androgen and estrogen concentration
- inactivation of the BRCA1 gene
- formation of new capillaries (angiogenesis)
- depletion of s-adenosylmethionine (SAM)
- low iron levels, low folate and vitamin B_12_ levels
- induction of epidermal growth factor
- increase in tumor necrosis factor-alpha receptor
- acetaldehyde formation by colonic bacteria
- induction of CYP2E1
- impairment of retinoic acid
- generation of reactive oxygen species and reactive nitrogen species
- immune suppression (effects on peripheral T- and B-lymphocytes)
- increase in cell membrane permeability
- interference with DNA repair (acetaldehyde-DNA adducts)
- increased levels of biomarkers of oxidative stress.

Because of the focus on the how and why of causation of cancer, indirect measures are critical in our efforts to improve the evidence of direct causation in ongoing and future research of possible causal mechanisms explaining the increased risk of breast and colorectal cancer with alcohol consumption.

For this report, experimental studies that show direct evidence were treated as stronger evidence than studies of association which only showed indirect evidence. The strength of evidence supporting each proposed mechanism relating alcohol intake to the development of breast or colorectal cancer were categorized as either “Sufficient” or ”Insufficient.” Three domains were evaluated: the potential risk of bias, or “internal validity” of the evidence base, the size of the evidence base (number of studies examining any one proposed mechanism), and the consistency of the findings (agreement across studies examining the same proposed mechanism).

External validity is the extent to which the findings and conclusions from a study or report can be translated to a specific setting or population (i.e., generalizability).59 Generalizability is always strongest when results are collected in the specific setting or population of interest. However, clinical studies often cannot be conducted in such a setting or population, and results are instead collected from a more rigidly defined and less generalizable patient population. Human studies have more external validity than animal or cell line studies.

## Data Synthesis

No meta-analyses were planned for this report. Given that this systematic review is hypothesis-summarizing and generating, we present a narrative summary of the findings based on the number of different mechanisms proposed and the studies showing support or lack of support for each mechanism.

## Assessment of Internal Validity of Breast and Colorectal Studies

Internal validity, especially in the context of clinical studies, is the extent to which a study’s design and conduct are likely to have prevented bias.59,82 However, in the context of this report, which is assessing the results of human, animal and in vitro studies, we defined internal validity as the extent to which a direct relationship can be seen between the result of a given study and an increase in the risk of developing breast or colorectal cancer following ethanol consumption. Although we believe that the included studies are valid in design and outcomes measured for their intended purpose, we needed a measure of internal validity that was relevant to the connection between study results and cancer risk in humans. Therefore we considered human studies that administered alcohol having a higher internal validity than animal or in vitro studies. Animal studies that administered alcohol and did not use any known co-carcinogen were considered as having a higher internal validity (more direct relationship to an increase in cancer risk) than studies that administered a carcinogen. Studies that administered acetaldehyde or known carcinogens were considered as having lower internal validity and a less direct relationship with an increase in cancer risk in humans who consume alcohol.

## Assessment of External Validity of Breast and Colorectal Studies

In our report we did not identify any studies using human subjects that directly assessed the possible mechanism(s) associated with risk of breast cancer following alcohol consumption. However, we did identify one human study that indirectly reported on colorectal cancer risk association with alcohol consumption: exposure of colonic biopsy tissues to acetaldehyde.83 For the animal studies, generalizability may be compromised by administering ethanol concentrations that far exceed levels suitable for human consumption, by administering acetaldehyde, and by co-administering a known carcinogen.73,82,84 Therefore, the results of these studies may not be directly applicable to human settings.