# Introduction

## Scope

The purpose of this report is to systematically and objectively synthesize evidence from the basic science literature to clarify the possible causal mechanisms by which alcohol may contribute to cancer risk, focusing on the induction and development of breast cancer and colorectal cancer under the assumption that there is a causal relationship. Therefore, the primary evidence base for this report consists of studies that administer ethanol or acetaldehyde to humans, animals, tissues, or cells and then look for the development of breast or colorectal cancer, or for changes in metabolic pathways and cellular structures that may increase the risk for developing these cancers. Case-control and other epidemiology studies are not included in the primary evidence base for assessment of possible mechanisms. However, such studies may provide insight into the dose/response relationship between alcohol consumption and cancer risk.

Apart from alcohol (i.e., ethanol) and water, the exact composition of most alcoholic beverages (e.g., beer, wine, or distilled spirits) on the market remains confidential proprietary information.1 Therefore, the scope of this report is limited to ethanol. Other compounds (or contaminants) found in various alcoholic beverages that may play a role in the development of breast and colorectal cancers are outside the scope of this report. These compounds include nitrosamines, aflatoxins, polyphenols, ethyl carbamate (urethane), asbestos, and arsenic compounds.1–4

In addition, studies that evaluated tumor progression or metastatic spread of either breast or colorectal cancer during alcohol consumption are outside the scope of this report because they are not examining the mechanisms underlying the association of alcohol and the risk of developing cancer.

## Ethanol Metabolism

Orally-ingested ethanol from an alcoholic drink is rapidly and almost completely absorbed by the stomach, small intestines, and colon. The bioavailability of ethanol, the fraction of the ingested dose that reaches the systemic circulation, is about 80%.5 Therefore a large portion of ingested ethanol reaches the circulation (i.e., blood alcohol concentration) and is distributed to all body tissues including the breast, colon, and rectum. Blood alcohol concentration, however, may vary depending on the rate of gastric emptying and degree of metabolism during this first pass via the stomach and liver (i.e., first-pass metabolism of ethanol).6–8

Ethanol is metabolized in the body by two pathways (i.e., oxidative and nonoxidative).8 However, the nonoxidative pathway is minimal compared to the oxidative pathway.8 The liver is the major organ for the oxidative metabolism of ethanol.9,10 Ethanol is converted into acetaldehyde by cytosolic alcohol dehydrogenase (ADH).9–11 Due to variation in gene encoding there are multiple isoenzymes of ADH that vary in their enzyme activity (ADH1A, ADH1B*1, ADH1B*2, ADH1B*3, ADH1C*1, ADH1C*2, ADH4, ADH5, ADH6, and ADH7).2,3,9,11–17 The ADH1B*2 is lower in frequency amongst Caucasians and higher among Asians and is about 40 times more active compared to the ADH1B*1 in the conversion of ethanol to acetaldehyde.18 ADH1C*1 is very common in Asians, and metabolizes ethanol 2.5 times faster compared to ADH1C*2.^18,19^ Among individuals who consume alcohol, ADH1C*1, a fast-acting metabolizer of ethanol, results in accumulation of acetaldehyde. As a result of increased levels of acetaldehyde, these individuals may experience uncomfortable side effects, and may well have a tendency to consume less alcohol.18,19 The genetic polymorphism of ADH leads to differences in individual ethanol metabolism and individual differences in the susceptibility to alcohol-related tissue damage.8,18

Acetaldehyde, a metabolite of ethanol, is further metabolized to acetate primarily by mitochondrial aldehyde dehydrogenase (ALDH2).9,11 ALDH2 accounts for the greater part of acetaldehyde breakdown and exists as ALDH2*1 and ALDH2*2. Individuals with ALDH2*2 have blood acetaldehyde levels 20 times higher compared to those with ALDH2*1.^18^ Acetaldehyde is a highly toxic metabolite that binds to many cellular proteins and may be responsible for damage in the liver as well as other body tissues.8 It binds to deoxyribonucleic acid (DNA), resulting in the formation of a DNA adduct which may influence cancer development.3,11 Presence of a DNA adduct is a sign of exposure to specific cancer-causing agent, and is indicative of growing damage to the DNA.3,11,13 Acetaldehyde is a cancer-causing agent in animals.14

During each oxidative process, nicotinamide adenine dinucleotide (NAD^+^) is reduced to NADH. In the liver, ethanol metabolism also involves microsomal cytochromes P450 2E1 (CYP2E1).11 This pathway produces reactive oxygen species (ROS) such as superoxide anions and hydroxyl radicals which may increase the risk of tissue damage.2,8,11

Nonoxidative metabolism of alcohol involves two pathways.8 One pathway results in the formation of fatty acid ethyl esters and the other the formation of phosphatidyl ethanol.8,9

ADH is present in the human colonic mucosa as well as in the microflora inhabiting the colon, and ethanol is metabolized to acetaldehyde by ADH in both of these locations.20,21 ADH activity is significantly higher in the mucosa of the rectum than the colon.21 Aldehyde dehydrogenase activity is much greater in the liver than in the colonic mucosa, which favors the accumulation of acetaldehyde in the colon.20 Breast tissue contains ADH and CYP2E1.^10^ Breast tissue converts ethanol to acetaldehyde which is then metabolized to acetate by xanthine oxidoreductase.

## Alcohol and Cancer

Fewer than 10% of cancers can be attributed to an inherited genetic abnormality.22 The majority of cancers are the result of changes in the gene structure due to the loss of control mechanisms that prevent cancer development.22 Control mechanisms that may be altered during cancer development are: 1) tumor suppressor genes that lose their function causing a disruption in cellular adhesion and abnormal cell cycle progression, 2) DNA repair enzymes that become nonfunctional due to distorted methylation, and 3) proto-oncogenes that mutate into oncogenes.22

The course by which normal cells are transformed into cancer cells is termed carcinogenesis (see Figure 1).3,14 When administered in combination with a recognized carcinogen, ethanol or its metabolite (acetaldehyde) produces reactive oxygen species (ROS).10 ROS may increase the transformation of normal cells into cancerous cells in various organs by inhibition of DNA methylation as well as by interacting with metabolism of retinoids.3,10,14,23,24 Alcohol and its metabolites have been implicated in all three stages of cancer formation (see the asterisks in Figure 1): 3,9,11,13,14,24,25

- initiation stage by impact on DNA repair
- promotion stage by altered gene expression, enhanced cell division, suppression of immune response, and change in metabolism of vitamin A
- progression stage by expression of oncogenes, exchange of DNA between chromosomes, and additional mutations.

Figure 1 Three stages of carcinogenesis

* Source from http://www.niaaa.nih.gov/resources/graphicsgallery/immunesystem/lieb.htm26

Figure one depicts a line drawing noting the three stages of carcinogenesis. Stage one is the initiation of the carcinogen into the cell. The final result is an initiated cell. Stage two is promotion of the cell to a benign tumor cell. Stage three is progression into a cancer cell.

Alcohol consumption is highly prevalent in the general U.S. population. The 2008 prevalence and trends data from the Behavioral Risk Factor Surveillance System indicate that about 54% of U.S. adults consumed alcohol within the past 30 days.27 Though moderate alcohol consumption may have some potential health benefits, alcohol consumption has been identified as one of the major worldwide risks for burden of disease.28 In the U.S., a standard drink is 12 fl oz (beer), 8 fl oz of malt liquor, 5 fl oz (wine), and 1.5 fl oz (80% proof distilled spirit).29–32 Each is equivalent to 0.6 fluid ounces (12–14 g) of ethanol.29–32 Moderate daily alcohol consumption in the U.S. for men is two drinks and for women is one drink.29–32 However, variations have been reported worldwide in the definition of what is moderate for men and women.29

Several epidemiology studies have reported moderate to strong associations between the level of alcohol consumption and the incidence of cancers of the mouth, pharynx, larynx, esophagus, and liver.2,24,33–35 Although the association between alcohol and breast and colorectal cancer is comparatively less strong than the association with these other cancers, given the high prevalence and incidence of breast and colorectal cancer, reducing the effect of any contributing factor may have a large overall impact on cancer incidence and prevalence.3,24,33,34,36–41 Observed associations of alcohol consumption and cancer, however, can be confounded by other risk factors for cancer, such as age, smoking, family history, obesity and physical activity, race or ethnicity, and nutrition.14,36,42–44 Because of the high prevalence of alcohol consumption, exploring the potential underlying mechanism(s) of the association between alcohol consumption and breast and colorectal cancers, if any, is essential in developing primary preventive measures. In view of the fact that alcohol consumption is a modifiable behavior,45 recommending and promoting changes in behavior and appropriate preventive interventions may help reduce cancer risks in the general population.

## Breast Cancer

According to the US National Cancer Institute (NCI), breast cancer is the most common cancer among women.46 In 2009, it was anticipated that of the 192,370 women who were diagnosed, 40,170 would die of breast cancer.46 Risk factors include family history, age at first birth, obesity in post menopausal women, dietary factors, alcohol consumption, early menarche, hormonal replacement therapy, low-dose irradiation, and lactation.18,46 Estrogen-induced breast cancer may result from cell proliferation, activation of cytochrome P450, and DNA damage.10 Cell proliferation is significant in the maintenance of normal and healthy breast tissue and these risk factors may alter cell proliferation in a direction that favors cancer development. Furthermore, enzyme polymorphism affects alcohol metabolism and could influence the effect of alcohol consumption on hormonal levels, thereby resulting in an increased risk of breast cancer.47–50 Among patients diagnosed with breast cancer, unregulated breast epithelial cell growth has been reported.51 Alcohol consumption has been investigated as a risk factor in the development of breast cancer. In a 2006 meta-analysis of 98 studies of alcohol and breast cancer, Key et al. reported that each additional 10 g ethanol/day resulted in a 10% increase in the odds ratio (OR) of risk of breast cancer associated with alcohol consumption.52

## Colorectal Cancer

Of the estimated 75,590 men and 71,380 women diagnosed with colorectal cancer, 49,920 men and women were expected to die of the disease in 2009.^53^ Among adults with cancer, colorectal cancer is the second most common cause of death.54 Risk factors include:13,14,53–58

- age
- smoking
- low fiber diet
- high red meat/low fish intake
- inadequate intake of folate, B6 and retinoids
- obesity
- lack of physical activity
- low calcium intake
- alcohol (heavy consumption)
- an increase in colonic acetaldehyde level concentration
- chronic ulcerative colitis
- granulomatous colitis
- adenomatous polyps

In addition, following alcohol consumption, intracolonic ethanol is metabolized by colonic mucosal cells and intracolonic microbes. The risks of colorectal cancer development associated with alcohol consumption have been examined in epidemiology studies. In a 2004 meta-analysis of eight studies, Cho et al. reported that daily consumption of more than 45 g of alcohol increased the risk of colorectal cancer by 45%.36 In addition, Homann et al. in a 2009 study reported that individuals with ADH1C1*1 homozygosity and consumption of more than 30 g of alcohol per day have significant increase risk of colorectal cancer.19